# Bibliography

1 The Beta-Blocker Pooling Project (BBPP): subgroup findings from randomized trials in post infarction patients. The Beta-Blocker Pooling Project Research Group. Eur Heart J 1988;9(1):8–16.
2 Randomised trial of intravenous streptokinase, oral aspirin, both, or neither among 17,187 cases of suspected acute myocardial infarction: ISIS-2. ISIS-2 (Second International Study of Infarct Survival) Collaborative Group. Lancet 1988;2(8607):349–60.
3 Persistence of reduction in blood pressure and mortality of participants in the Hypertension Detection and Follow-up Program. Hypertension Detection and Follow-up Program Cooperative Group. Jama 1988;259(14):2113–22.
4 ISIS-3: a randomised comparison of streptokinase vs tissue plasminogen activator vs anistreplase and of aspirin plus heparin vs aspirin alone among 41,299 cases of suspected acute myocardial infarction. ISIS-3 (Third International Study of Infarct Survival) Collaborative Group. Lancet 1992;339(8796):753–70.
5 Morning peak in the incidence of myocardial infarction: experience in the ISIS-2 trial. ISIS-2 (Second International Study of Infarct Survival) Collaborative Group. Eur Heart J 1992;13(5):594–8.
6 Randomised trial of cholesterol lowering in 4444 patients with coronary heart disease: the Scandinavian Simvastatin Survival Study (4S). Lancet 1994;344(8934):1383–9.
7 GISSI-3: effects of lisinopril and transdermal glyceryl trinitrate singly and together on 6-week mortality and ventricular function after acute myocardial infarction. Gruppo Italiano per lo Studio della Sopravvivenza nell'infarto Miocardico. Lancet 1994;343(8906):1115–22.
8 Indications for fibrinolytic therapy in suspected acute myocardial infarction: collaborative overview of early mortality and major morbidity results from all randomised trials of more than 1000 patients. Fibrinolytic Therapy Trialists' (FTT) Collaborative Group. Lancet 1994;343(8893):311–22.
9 Collaborative overview of randomised trials of antiplatelet therapy--III: Reduction in venous thrombosis and pulmonary embolism by antiplatelet prophylaxis among surgical and medical patients. Antiplatelet Trialists' Collaboration. Bmj 1994;308(6923):235–46.
10 Collaborative overview of randomised trials of antiplatelet therapy--I: Prevention of death, myocardial infarction, and stroke by prolonged antiplatelet therapy in various categories of patients. Antiplatelet Trialists' Collaboration. BMJ 1994;308(6921):81–106.
11 ISIS-4: a randomised factorial trial assessing early oral captopril, oral mononitrate, and intravenous magnesium sulphate in 58,050 patients with suspected acute myocardial infarction. ISIS-4 (Fourth International Study of Infarct Survival) Collaborative Group. Lancet 1995;345(8951):669–85.
12 First-year results of CABRI (Coronary Angioplasty versus Bypass Revascularisation Investigation). CABRI Trial Participants. Lancet 1995;346(8984):1179–84.
13 Six-month effects of early treatment with lisinopril and transdermal glyceryl trinitrate singly and together withdrawn six weeks after acute myocardial infarction: the GISSI-3 trial. Gruppo Italiano per lo Studio della Sopravvivenza nell'Infarto Miocardico. J Am Coll Cardiol 1996;27(2):337–44.
14 A randomised, blinded, trial of clopidogrel versus aspirin in patients at risk of ischaemic events (CAPRIE). CAPRIE Steering Committee. Lancet 1996;348(9038):1329–39.
15 North of England evidence based guidelines development project: summary version of evidence based guideline for the primary care management angina. North of England Stable Angina Guideline Development Group. Bmj 1996;312(7034):827–32.
16 Coronary angioplasty versus medical therapy for angina: the second Randomised Intervention Treatment of Angina (RITA-2) trial. RITA-2 trial participants. Lancet 1997;350(9076);461–8.
17 Protocol for prospective collaborative overviews of major randomized trials of blood-pressure-lowering treatments. World Health Organization-International Society of Hypertension Blood Pressure Lowering Treatment Trialists' Collaboration. J Hypertens 1998;16(2):127–37.
18 Prevention of cardiovascular events and death with pravastatin in patients with coronary heart disease and a broad range of initial cholesterol levels. The Long-Term Intervention with Pravastatin in Ischaemic Disease (LIPID) Study Group. N Engl J Med 1998;339(19):1349–57.
19 Indications for ACE inhibitors in early treatment of acute myocardial infarction: systematic overview of individual data from 100,000 patients in randomized trials. ACE Inhibitor Myocardial Infarction Collaborative Group. Circulation 1998;97(22):2202–12.
20 Lowering blood homocysteine with folic acid based supplements: meta-analysis of randomised trials. Homocysteine Lowering Trialists' Collaboration. BMJ 1998;316(7135):894–8.
21 Collaborative overview (‘meta-analysis’) of prospective observational studies of the associations of usual blood pressure and usual cholesterol levels with common causes of death: protocol for the second cycle of the Prospective Studies Collaboration. J Cardiovasc Risk 1999;6(5):315–20.
22 Prediction of risk for patients with unstable angina. Evid Rep Technol Assess (Summ) 2000(31):1–3.
23 Direct thrombin inhibitors in acute coronary syndromes and during percutaneous coronary intervention: design of a meta-analysis based on individual patient data. Direct Thrombin Inhibitor Trialists' Collaborative Group. Am Heart J 2001;141(1):E2.
24 MRC/BHF Heart Protection Study of cholesterol lowering with simvastatin in 20,536 high-risk individuals: a randomised placebo-controlled trial. Lancet 2002;360(9326):7–22.
25 Abbott R D, Donahue R P, Kannel W B, et al. The impact of diabetes on survival following myocardial infarction in men vs women. The Framingham Study. JAMA. 1988;260(23):3456-60. [pmid: 2974889].
26 Abbott R D, Wilson P W, Kannel W B, et al. High density lipoprotein cholesterol, total cholesterol screening, and myocardial infarction. The Framingham Study. Arteriosclerosis. 1988;8(3):207-11. [pmid: 3370018].
27 Ades P A, Savage P D, Poehlman E T, et al. Lipid lowering in the cardiac rehabilitation setting. J Cardiopulm Rehabil. 1999;19(4):255-60. [pmid: 10453433].
28 Afonso L C, Edelson G W, Sowers J R. Metabolic abnormalities in hypertension. Curr Opin Nephrol Hypertens. 1997;6(3):219-23. [pmid: 9263663].
29 Airaksinen K E. Autonomic mechanisms and sudden death after abrupt coronary occlusion. Ann Med. 1999;31(4):240-5. [pmid: 10480754].
30 Al Suwaidi J, Berger P B, Holmes D R Jr. Coronary artery stents. Jama. 2000;284(14):1828-36. [pmid: 11025836].
31 Albert M A, Danielson E, Rifai N, et al. Effect of statin therapy on C-reactive protein levels: the pravastatin inflammation/CRP evaluation (PRINCE): a randomized trial and cohort study. Jama. 2001;286(1):64-70. [pmid: 11434828].
32 Alderman M H, Ooi W L, Madhavan S, et al. Treatment-induced blood pressure reduction and the risk of myocardial infarction. Jama. 1989;262(7):920-4. [pmid: 2754792].
33 Alexander K P, Shaw L J, Shaw L K, et al. Value of exercise treadmill testing in women. J Am Coll Cardiol. 1998;32(6):1657-64. [pmid: 9822093].
34 Allison J J, Kiefe C I, Centor R M, et al. Racial differences in the medical treatment of elderly Medicare patients with acute myocardial infarction. J Gen Intern Med. 1996;11(12):736-43. [pmid: 9016420].
35 Amanullah A M, Kiat H, Friedman J D, et al. Adenosine technetium-99m sestamibi myocardial perfusion SPECT in women: diagnostic efficacy in detection of coronary artery disease. J Am Coll Cardiol. 1996;27(4):803-9. [pmid: 8613606].
36 Anand S S, Yusuf S. Oral anticoagulant therapy in patients with coronary artery disease: a meta-analysis. Jama. 1999;282(21):2058-67. [pmid: 10591389].
37 Anderson K M, Castelli W P, Levy D. Cholesterol and mortality. 30 years of follow-up from the Framingham study. Jama. 1987;257(16):2176-80. [pmid: 3560398].
38 Ansell B J, Watson K E, Fogelman A M. An evidence-based assessment of the NCEP Adult Treatment Panel II guidelines. National Cholesterol Education Program. Jama. 1999;282(21):2051-7. [pmid: 10591388].
39 Antman E M, Cohen M, Radley D, et al. Assessment of the treatment effect of enoxaparin for unstable angina/non-Q-wave myocardial infarction. TIMI 11B-ESSENCE meta-analysis. Circulation. 1999;100(15):1602-8. [pmid: 10517730].
40 Aronow W S. Management of older persons after myocardial infarction. J Am Geriatr Soc. 1998;46(11):1459-68. [pmid: 9809771].
41 Arruda-Olson A M, Juracan E M, Mahoney D W, et al. Prognostic value of exercise echocardiography in 5,798 patients: is there a gender difference?. J Am Coll Cardiol. 2002;39(4):625-31. [pmid: 11849861].
42 Ascherio A, Willett W C. Health effects of trans fatty acids. Am J Clin Nutr. 1997;66(4 Suppl):1006S-1010S. [pmid: 9322581].
43 Atrens D M. The questionable wisdom of a low-fat diet and cholesterol reduction. Soc Sci Med. 1994;39(3):433-47. [pmid: 7939861].
44 Austin M A. Plasma triglyceride as a risk factor for cardiovascular disease. Can J Cardiol. 1998;14(Suppl B):14B-17B.
45 Austin M A. Epidemiology of hypertriglyceridemia and cardiovascular disease. Am J Cardiol. 1999;83(9B):13F-16F.
46 Austin M A, Hokanson J E, Edwards K L. Hypertriglyceridemia as a cardiovascular risk factor. Am J Cardiol. 1998;81(4A):7B-12B. [pmid: 9462597].
47 Avezum A, Tsuyuki R T, Pogue J, et al. Beta-blocker therapy for congestive heart failure: a systemic overview and critical appraisal of the published trials. Can J Cardiol. 1998;14(8):1045-53. [pmid: 9738164].
48 Ayanian J Z, Epstein A M. Differences in the use of procedures between women and men hospitalized for coronary heart disease. N Engl J Med. 1991;325(4):221-5. [pmid: 2057022].
49 Azar R R, Waters D D, McKay R G, et al. Short- and medium-term outcome differences in women and men after primary percutaneous transluminal mechanical revascularization for acute myocardial infarction. Am J Cardiol. 2000;85(6):675-9. [pmid: 12000039].
50 Baevsky R M, Petrov V M, Cornelissen G, et al. Meta-analyzed heart rate variability, exposure to geomagnetic storms, and the risk of ischemic heart disease. Scr Med (Brno). 1997;70(45):201-6. [pmcid: 51657]. [pmid: 11543511].
51 Balk E M, Ioannidis J P, Salem D, et al. Accuracy of biomarkers to diagnose acute cardiac ischemia in the emergency department: a meta-analysis. Ann Emerg Med. 2001;37(5):478-94. [pmid: 11326184].
52 Bandyopadhyay S, Bayer A J, O'Mahony M S. Age and gender bias in statin trials. Qjm. 2001;94(3):127-32. [pmid: 11259687].
53 Barbour M M, Hume A L, Lapane K L, et al. Predictors of future antihypertensive use in patients with mildly elevated blood pressure. Pharmacotherapy. 1995;15(3):272-8. [pmid: 7667162].
54 Barnes V, Schneider R, Alexander C, et al. Stress, stress reduction, and hypertension in African Americans: an updated review. J Natl Med Assoc. 1997;89(7):464-76. [pmid: 9220696].
55 Barratt A, Irwig L. Is cholesterol testing/treatment really beneficial?. Med J Aust. 1993;159(10):644-7. [pmid: 8232004].
56 Barrett-Connor E L. Obesity, atherosclerosis, and coronary artery disease. Ann Intern Med. 1985;103(6 Pt 2):1010-9. [pmid: 3904565].
57 Basinski A, Naylor C D. Aspirin and fibrinolysis in acute myocardial infarction: meta-analytic evidence for synergy. J Clin Epidemiol. 1991;44(10):1085-96. [pmid: 1834805].
58 Batchelor W B, Anstrom K J, Muhlbaier L H, et al. Contemporary outcome trends in the elderly undergoing percutaneous coronary interventions: results in 7,472 octogenarians. National Cardiovascular Network Collaboration. J Am Coll Cardiol. 2000;36(3):723-30. [pmid: 10987591].
59 Bates D W, Miller E, Bernstein S J, et al. Coronary angiography and angioplasty after acute myocardial infarction. Ann Intern Med. 1997;126(7):539-50. [pmid: 9092320].
60 Battleman D S, Callahan M. Gender differences in utilization of exercise treadmill testing: a claims-based analysis. J Healthc Qual. 2001;23(3):38-41. [pmid: 11378976].
61 Bax J J, Wijns W, Cornel J H, et al. Accuracy of currently available techniques for prediction of functional recovery after revascularization in patients with left ventricular dysfunction due to chronic coronary artery disease: comparison of pooled data. J Am Coll Cardiol. 1997;30(6):1451-60. [pmid: 9362401].
62 Beck C A, Lauzon C, Eisenberg M J, et al. Discharge prescriptions following admission for acute myocardial infarction at tertiary care and community hospitals in Quebec. Can J Cardiol. 2001;17(1):33-40. [pmid: 11173312].
63 Becker R C. Late thrombolytic therapy: mechanism of benefit and potential risk among patients treated beyond 6 hours. Coron Artery Dis. 1993;4(3):293-304. [pmid: 8269224].
64 Becker R C, Terrin M, Ross R, et al. Comparison of clinical outcomes for women and men after acute myocardial infarction. The Thrombolysis in Myocardial Infarction Investigators. Ann Intern Med. 1994;120(8):638-45. [pmid: 8135447].
65 Beckett N, Nunes M, Bulpitt C. Is it advantageous to lower cholesterol in the elderly hypertensive?. Cardiovasc Drugs Ther. 2000;14(4):397-405. [pmid: 10999646].
66 Beckwith C, Munger M A. Effect of angiotensin-converting enzyme inhibitors on ventricular remodeling and survival following myocardial infarction. Ann Pharmacother. 1993;27(6):755-66. [pmid: 8329800].
67 Bell D M. Analysis of number needed to treat and cost of platelet glycoprotein IIb/IIIa inhibitors in percutaneous coronary interventions and acute coronary syndromes. Pharmacotherapy. 1999;19(9):1086-93. [pmid: 10610016].
68 Bell M R, Grill D E, Garratt K N, et al. Long-term outcome of women compared with men after successful coronary angioplasty. Circulation. 1995;91(12):2876-81. [pmid: 7796495].
69 Bell M R, Holmes D R Jr, Berger P B, et al. The changing in-hospital mortality of women undergoing percutaneous transluminal coronary angioplasty. JAMA. 1993;269(16):2091-5. [pmid: 8468762].
70 Bergelson B A, Tommaso C L. Gender differences in clinical evaluation and triage in coronary artery disease. Chest. 1995;108(6):1510-3. [pmid: 7497752].
71 Bergelson B A, Tommaso C L. Gender differences in percutaneous interventional therapy of coronary artery disease. Cathet Cardiovasc Diagn. 1996;37(1):1-4. [pmid: 8770471].
72 Bergfeldt L. HLA-B27-associated cardiac disease. Ann Intern Med. 1997;127(8 Pt 1):621-9. [pmid: 9341061].
73 Bergman U, Anderssen M, Vaccheri A, et al. Marked differences in lipid-lowering drug use in Bologna, Italy and Funen, Denmark. Eur Heart J. 1999;20(15):1135.
74 Berlin J A, Colditz G A. A meta-analysis of physical activity in the prevention of coronary heart disease. Am J Epidemiol. 1990;132(4):612-28. [pmid: 2144946].
75 Bernstein S J, Hilborne L H, Leape L L, et al. The appropriateness of use of cardiovascular procedures in women and men. Arch Intern Med. 1994;154(23):2759-65. [pmid: 7993162].
76 Bhatt D L, Topol E J. Current role of platelet glycoprotein IIb/IIIa inhibitors in acute coronary syndromes. Jama. 2000;284(12):1549-58. [pmid: 11000650].
77 Bhopal R. What is the risk of coronary heart disease in South Asians? A review of UK research. J Public Health Med. 2000;22(3):375-85. [pmid: 11077913].
78 Bickell N A, Pieper K S, Lee K L, et al. Referral patterns for coronary artery disease treatment: gender bias or good clinical judgment?. Ann Intern Med. 1992;116(10):791-7. [pmid: 1567093].
79 Bijsterveld N R, Hettiarachchi R, Peters R, et al. Low-molecular weight heparins in venous and arterial thrombotic disease. Thromb Haemost. 1999;82(Suppl 1):139-47. [pmid: 10695506].
80 Bizjak E D, Mauro V F. Thrombolytic therapy: a review of its use in acute myocardial infarction. Ann Pharmacother. 1998;32(78):769-84. [pmid: 9681094].
81 Bjorntorp P. Evolution of the understanding of the role of exercise in obesity and its complications. Int J Obes Relat Metab Disord. 1995;19(Suppl 4):S1-4. [pmid: 8581082].
82 Blair S N, Brodney S. Effects of physical inactivity and obesity on morbidity and mortality: current evidence and research issues. Med Sci Sports Exerc. 1999;31(11 Suppl):S646-62. [pmid: 10593541].
83 Blair S N, Kohl H W 3rd, Paffenbarger R S Jr, et al. Physical fitness and all-cause mortality. A prospective study of healthy men and women. Jama. 1989;262(17):2395-401. [pmid: 2795824].
84 Blankenhorn D H, Hodis H N. Atherosclerosis--reversal with therapy. West J Med. 1993;159(2):172-9. [pmid: 8212682].
85 Blazing M A, O'Connor C M. Evidence supporting secondary prevention strategies. Curr Opin Cardiol. 1999;14(4):303-9. [pmid: 10448610].
86 Blustein J, Weitzman B C. Access to hospitals with high-technology cardiac services: how is race important?. Am J Public Health. 1995;85(3):345-51. [pmid: 7892917].
87 Boden W E, Vray M, Eschwege E, et al. Heart rate-lowering and -regulating effects of once-daily sustained-release diltiazem. Clin Cardiol. 2001;24(1):73-9. [pmid: 11195610].
88 Boersma E, Akkerhuis K M, Theroux P, et al. Platelet glycoprotein IIb/IIIa receptor inhibition in non-ST-elevation acute coronary syndromes: early benefit during medical treatment only, with additional protection during percutaneous coronary intervention. Circulation. 1999;100(20):2045-8. [pmid: 10562258].
89 Boersma E, Harrington R A, Moliterno D J, et al. Platelet glycoprotein IIb/IIIa inhibitors in acute coronary syndromes: a meta-analysis of all major randomised clinical trials. Lancet. 2002;359(9302):189-98. [pmid: 11812552].
90 Boersma E, Maas A C, Deckers J W, et al. Early thrombolytic treatment in acute myocardial infarction: reappraisal of the golden hour. Lancet. 1996;348(9030):771-5. [pmid: 8813982].
91 Boissel J P, Peyrieux J C, Destors J M. Is it possible to reduce the risk of cardiovascular events in subjects suffering from intermittent claudication of the lower limbs?. Thromb Haemost. 1989;62(2):681-5. [pmid: 2683189].
92 Bonet S, Agusti A, Arnau J M, et al. Beta-adrenergic blocking agents in heart failure: benefits of vasodilating and non-vasodilating agents according to patients' characteristics: a meta-analysis of clinical trials. Arch Intern Med. 2000;160(5):621-7. [pmid: 10724047].
93 Borgia M C, Medici F. Perspectives in the treatment of dyslipidemias in the prevention of coronary heart disease. Angiology. 1998;49(5):339-48. [pmid: 9591525].
94 Borzak S, Ridker P M. Discordance between meta-analyses and large-scale randomized, controlled trials. Examples from the management of acute myocardial infarction. Ann Intern Med. 1995;123(11):873-7. [pmid: 7486471].
95 Bostom A G, Silbershatz H, Rosenberg I H, et al. Nonfasting plasma total homocysteine levels and all-cause and cardiovascular disease mortality in elderly Framingham men and women. Arch Intern Med. 1999;159(10):1077-80. [pmid: 10335684].
96 Boushey C J, Beresford S A, Omenn G S, et al. A quantitative assessment of plasma homocysteine as a risk factor for vascular disease. Probable benefits of increasing folic acid intakes. JAMA. 1995;274(13):1049-57. [pmid: 7563456].
97 Bradley K A, Badrinath S, Bush K, et al. Medical risks for women who drink alcohol. J Gen Intern Med. 1998;13(9):627-39. [pmid: 9754520].
98 Brand F N, Abbott R D, Kannel W B. Diabetes, intermittent claudication, and risk of cardiovascular events. The Framingham Study. Diabetes. 1989;38(4):504-9. [pmid: 2925008].
99 Brand F N, Kiely D K, Kannel W B, et al. Family patterns of coronary heart disease mortality: the Framingham Longevity Study. J Clin Epidemiol. 1992;45(2):169-74. [pmid: 1573433].
100 Braunwald E, Maseri A, Armstrong P W, et al. Rationale and clinical evidence for the use of GP IIb/IIIa inhibitors in acute coronary syndromes. Eur Heart J. 1998;19(Suppl D):D22-30. [pmid: 9597519].
101 Brezinka V, Kittel F. Psychosocial factors of coronary heart disease in women: a review. Soc Sci Med. 1996;42(10):1351-65. [pmid: 8735892].
102 Brophy J M, Joseph L, Rouleau J L. Beta-blockers in congestive heart failure. A Bayesian meta-analysis. Ann Intern Med. 2001;134(7):550-60. [pmid: 11281737].
103 Brown B G, Zhao X Q, Chait A, et al. Lipid altering or antioxidant vitamins for patients with coronary disease and very low HDL cholesterol? The HDL-Atherosclerosis Treatment Study Design. Can J Cardiol. 1998;14(Suppl A):6A-13A.
104 Brown D L, Fann C S, Chang C J. Effect of glycoprotein IIb/IIIa inhibitors on the individual components of composite endpoints used in clinical trials of unstable angina and non-Q-wave myocardial infarction. Cardiovasc Drugs Ther. 2000;14(3):253-8. [pmid: 10935147].
105 Brown D L, Fann C S, Chang C J. Meta-analysis of effectiveness and safety of abciximab versus eptifibatide or tirofiban in percutaneous coronary intervention. Am J Cardiol. 2001;87(5):537-41. [pmid: 11230835].
106 Bucher H C, Griffith L E, Guyatt G H. Systematic review on the risk and benefit of different cholesterol-lowering interventions. Arterioscler Thromb Vasc Biol. 1999;19(2):187-95. [pmid: 9974397].
107 Buchwald H, Campos CT, Boen JR, et al. Gender-based mortality follow-up from the Program on the Surgical Control of the Hyperlipidemias (POSCH) and meta-analysis of lipid intervention trials. Women in POSCH and other lipid trials. Ann Surg 1996;224(4):486–98; discussion 498–500.
108 Budoff M J, Diamond G A, Raggi P, et al. Continuous probabilistic prediction of angiographically significant coronary artery disease using electron beam tomography. Circulation. 2002;105(15):1791-6. [pmid: 11956121].
109 Budoff M J, Shokooh S, Shavelle R M, et al. Electron beam tomography and angiography: sex differences. Am Heart J. 2002;143(5):877-82. [pmid: 12040352].
110 Burke A P, Farb A, Malcom G T, et al. Effect of risk factors on the mechanism of acute thrombosis and sudden coronary death in women. Circulation. 1998;97(21):2110-6. [pmid: 9626170].
111 Bush T L, Fried L P, Barrett-Connor E. Cholesterol, lipoproteins, and coronary heart disease in women. Clin Chem. 1988;34(8B):B60-70. [pmid: 3042201].
112 Byington R P, Jukema J W, Salonen J T, et al. Reduction in cardiovascular events during pravastatin therapy. Pooled analysis of clinical events of the Pravastatin Atherosclerosis Intervention Program. Circulation. 1995;92(9):2419-25. [pmid: 7586340].
113 Califf R M, Harrell F E Jr, Lee K L, et al. The evolution of medical and surgical therapy for coronary artery disease. A 15-year perspective. Jama. 1989;261(14):2077-86. [pmid: 2784512].
114 Cantor W J, Peterson E D, Popma J J, et al. Provisional stenting strategies: systematic overview and implications for clinical decision-making. J Am Coll Cardiol. 2000;36(4):1142-51. [pmid: 11028463].
115 Capewell S, MacIntyre K, Stewart S, et al. Age, sex, and social trends in out-of-hospital cardiac deaths in Scotland 1986-95: a retrospective cohort study. Lancet. 2001;358(9289):1213-7. [pmid: 11675057].
116 Capewell S, Morrison C E, McMurray J J. Contribution of modern cardiovascular treatment and risk factor changes to the decline in coronary heart disease mortality in Scotland between 1975 and 1994. Heart. 1999;81(4):380-6. [pmid: 10092564].
117 Carlisle D M, Leake B D, Shapiro M F. Racial and ethnic differences in the use of invasive cardiac procedures among cardiac patients in Los Angeles County, 1986 through 1988. Am J Public Health. 1995;85(3):352-6. [pmid: 7892918].
118 Carlisle D M, Leake B D, Shapiro M F. Racial and ethnic disparities in the use of cardiovascular procedures: associations with type of health insurance. Am J Public Health. 1997;87(2):263-7. [pmid: 9103107].
119 Carter B L, Kriesel H T, Steinkraus L, et al. Antihypertensive drug-prescribing patterns of internists and family physicians. J Fam Pract. 1989;29(3):257-61. [pmid: 2570121].
120 Castelli W P. Cholesterol and lipids in the risk of coronary artery disease--the Framingham Heart Study. Can J Cardiol. 1988;4(Suppl A):5A-10A. [pmid: 3282627].
121 Castelli W P. Diet, smoking, and alcohol: influence on coronary heart disease risk. Am J Kidney Dis. 1990;16(4 Suppl 1):41-6. [pmid: 2220800].
122 Castelli W P, Anderson K, Wilson P W, et al. Lipids and risk of coronary heart disease. The Framingham Study. Ann Epidemiol. 1992;2(12):23-8. [pmid: 1342260].
123 Castelli W P, Garrison R J, Wilson P W, et al. Incidence of coronary heart disease and lipoprotein cholesterol levels. The Framingham Study. Jama. 1986;256(20):2835-8. [pmid: 3773200].
124 Castelli W P, Wilson P W, Levy D, et al. Cardiovascular risk factors in the elderly. Am J Cardiol. 1989;63(16):12H-19H.
125 Castillo P A, Palmer C S, Halpern M T, et al. Cost-effectiveness of thrombolytic therapy for acute myocardial infarction. Ann Pharmacother. 1997;31(5):596-603. [pmid: 9161657].
126 Celis H, Fagard R, Staessen J, et al. The older hypertensive. Assessment and treatment. Neth J Med. 1993;43(Suppl 1):S66-77. [pmid: 8289979].
127 Cerqueira M D. Diagnostic testing strategies for coronary artery disease: special issues related to gender. Am J Cardiol. 1995;75(11):52D-60D.
128 Chaitman B R, Bourassa M G, Davis K, et al. Angiographic prevalence of high-risk coronary artery disease in patient subsets (CASS). Circulation. 1981;64(2):360-7. [pmid: 7249303].
129 Chandra N C, Ziegelstein R C, Rogers W J, et al. Observations of the treatment of women in the United States with myocardial infarction: a report from the National Registry of Myocardial Infarction-I. Arch Intern Med. 1998;158(9):981-8. [pmid: 9588431].
130 Chew D P, Bhatt D L, Sapp S, et al. Increased Mortality With Oral Platelet Glycoprotein IIb/IIIa Antagonists : A Meta-Analysis of Phase III Multicenter Randomized Trials. Circulation. 2001;103(2):201-206. [pmid: 11208677].
131 Chiamvimonvat V, Sternberg L. Coronary artery disease in women. Can Fam Physician. 1998;44:2709-17. [pmid: 9870124].
132 Chiriboga D E, Yarzebski J, Goldberg R J, et al. A community-wide perspective of gender differences and temporal trends in the use of diagnostic and revascularization procedures for acute myocardial infarction. Am J Cardiol. 1993;71(4):268-73. [pmid: 8427166].
133 Cho L, Bhatt D L, Wolski K, et al. Effect of smoking status and abciximab use on outcome after percutaneous coronary revascularization: Pooled analysis from EPIC, EPILOG, and EPISTENT. Am Heart J. 2001;141(4):599-602. [pmid: 11275926].
134 Cho L, Topol E J, Balog C, et al. Clinical benefit of glycoprotein IIb/IIIa blockade with Abciximab is independent of gender: pooled analysis from EPIC, EPILOG and EPISTENT trials. Evaluation of 7E3 for the Prevention of Ischemic Complications. Evaluation in Percutaneous Transluminal Coronary Angioplasty to Improve Long-Term Outcome with Abciximab GP IIb/IIIa blockade. Evaluation of Platelet IIb/IIIa Inhibitor for Stent. J Am Coll Cardiol. 2000;36(2):381-6. [pmid: 10933346].
135 Christenson R H, Duh S H. Evidence based approach to practice guides and decision thresholds for cardiac markers. Scand J Clin Lab Invest Suppl. 1999;230:90-102. [pmid: 10389207].
136 Clarke K W, Gray D, Keating N A, et al. Do women with acute myocardial infarction receive the same treatment as men?. Bmj. 1994;309(6954):563-6. [pmid: 7916228].
137 Clarkson T B, Kaplan J R, Adams M R, et al. Psychosocial influences on the pathogenesis of atherosclerosis among nonhuman primates. Circulation. 1987;76(1 Pt 2):I29-40. [pmid: 3297407].
138 Cleland J G, Bristow M R, Erdmann E, et al. Beta-blocking agents in heart failure. Should they be used and how?. Eur Heart J. 1996;17(11):1629-39. [pmid: 8922910].
139 Cleophas TJ, Hornstra N, van Hoogstraten B, et al. Homocysteine, a risk factor for coronary artery disease or not? A meta-analysis. Am J Cardiol 2000;86(9):1005–9, A8.
140 Clyne C A. Antithrombotic therapy in the primary and secondary prevention of coronary-related death and infarction: focus on gender differences. Cardiology. 1990;77(Suppl 2):99-109. [pmid: 2198101].
141 Cohen M. The role of low-molecular-weight heparins in arterial diseases: optimizing antithrombotic therapy. Thromb Res. 2000;100(2):V131-9. [pmid: 11053626].
142 Colditz G A, Halvorsen K T, Goldhaber S Z. Randomized clinical trials of transdermal nitroglycerin systems for the treatment of angina: a meta-analysis. Am Heart J. 1988;116(1 Pt 1):174-80. [pmid: 3134809].
143 Colditz G A, Willett W C, Stampfer M J, et al. Menopause and the risk of coronary heart disease in women. N Engl J Med. 1987;316(18):1105-10. [pmid: 3574358].
144 Collins R, MacMahon S, Flather M, et al. Clinical effects of anticoagulant therapy in suspected acute myocardial infarction: systematic overview of randomised trials. Bmj. 1996;313(7058):652-9. [pmid: 8811758].
145 Collins R, Peto R, Parish S, et al. ISIS-3 and GISSI-2: no survival advantage with tissue plasminogen activator over streptokinase, but a significant excess of strokes with tissue plasminogen activator in both trials. Am J Cardiol. 1993;71(12):1127-30. [pmid: 8475887].
146 Conlan M G, Folsom A R, Finch A, et al. Correlation of plasma protein C levels with cardiovascular risk factors in middle-aged adults: the Atherosclerosis Risk in Communities (ARIC) Study. Thromb Haemost. 1993;70(5):762-7. [pmid: 8128432].
147 Conti C R. Large vessel coronary vasospasm: diagnosis, natural history and treatment. Am J Cardiol. 1985;55(3):41B-49B. [pmid: 4014038].
148 Conti C R. Clinical decision making using cumulative meta-analysis. Clin Cardiol. 1993;16(3):167-8. [pmid: 8095197].
149 Cooke H M, Lynch A. Biorhythms and chronotherapy in cardiovascular disease. Am J Hosp Pharm. 1994;51(20):2569-80. [pmid: 7847420].
150 Cooper G S, Sandler D P. Age at natural menopause and mortality. Ann Epidemiol. 1998;8(4):229-35. [pmid: 9590601].
151 Cooper R. The role of genetic and environmental factors in cardiovascular disease in African Americans. Am J Med Sci. 1999;317(3):208-13. [pmid: 10100695].
152 Cooper R S, Ghali J K. Coronary heart disease: black-white differences. Cardiovasc Clin. 1991;21(3):205-25. [pmid: 2044105].
153 Corrao G, Rubbiati L, Bagnardi V, et al. Alcohol and coronary heart disease: a meta-analysis. Addiction. 2000;95(10):1505-23. [pmid: 11070527].
154 Corti M C, Guralnik J M, Bilato C. Coronary heart disease risk factors in older persons. Aging (Milano). 1996;8(2):75-89. [pmcid: 305699]. [pmid: 8737605].
155 Coutinho M, Gerstein H C, Wang Y, et al. The relationship between glucose and incident cardiovascular events. A metaregression analysis of published data from 20 studies of 95,783 individuals followed for 12.4 years. Diabetes Care. 1999;22(2):233-40. [pmid: 10333939].
156 Craig W Y, Neveux L M, Palomaki G E, et al. Lipoprotein(a) as a risk factor for ischemic heart disease: metaanalysis of prospective studies. Clin Chem. 1998;44(11):2301-6. [pmid: 9799757].
157 Croft J B, Keenan N L, Sheridan D P, et al. Waist-to-hip ratio in a biracial population: measurement, implications, and cautions for using guidelines to define high risk for cardiovascular disease. J Am Diet Assoc. 1995;95(1):60-4. [pmid: 7798582].
158 Cucherat M, Bonnefoy E, Tremeau G. Primary angioplasty versus intravenous thrombolysis for acute myocardial infarction. Cochrane Database Syst Rev 2000(2):CD001560.
159 Cui Y, Blumenthal R S, Flaws J A, et al. Non-high-density lipoprotein cholesterol level as a predictor of cardiovascular disease mortality. Arch Intern Med. 2001;161(11):1413-9. [pmid: 11386890].
160 Cullen P. Evidence that triglycerides are an independent coronary heart disease risk factor. Am J Cardiol. 2000;86(9):943-9. [pmid: 11053704].
161 Cutlip D E, Baim D S, Ho K K, et al. Stent thrombosis in the modern era: a pooled analysis of multicenter coronary stent clinical trials. Circulation. 2001;103(15):1967-71. [pmid: 11306525].
162 D'Agostino R B, Cobb J L, Wolf P A, et al. Aspirin use and cardiovascular disease in women. Jama. 1992;267(3):364-5. [pmid: 1727952].
163 D'Agostino R B Sr, Grundy S, Sullivan L M, et al. Validation of the Framingham coronary heart disease prediction scores: results of a multiple ethnic groups investigation. Jama. 2001;286(2):180-7. [pmid: 11448281].
164 D'Agostino R B, Kannel W B, Belanger A J, et al. Trends in CHD and risk factors at age 55–64 in the Framingham Study. Int J Epidemiol. 1989;18(3 Suppl 1):S67-72. [pmid: 2807709].
165 D'Agostino R B, Kannel W B, Stepanians M N, et al. Efficacy and tolerability of lovastatin in hypercholesterolemic women. Clin Ther. 1992;14(3):390-5. [pmid: 1638580].
166 D'Agostino R B, Russell M W, Huse D M, et al. Primary and subsequent coronary risk appraisal: new results from the Framingham study. Am Heart J. 2000;139(2 Pt 1):272-81. [pmid: 10650300].
167 D'Hoore W, Sicotte C, Tilquin C. Sex bias in the management of coronary artery disease in Quebec. Am J Public Health. 1994;84(6):1013-5. [pmid: 8203667].
168 Dagenais G R, Yusuf S, Bourassa M G, et al. Effects of ramipril on coronary events in high-risk persons: results of the Heart Outcomes Prevention Evaluation Study. Circulation. 2001;104(5):522-6. [pmid: 11479247].
169 Dahlof B, Devereux R B, Kjeldsen S E, et al. Cardiovascular morbidity and mortality in the Losartan Intervention For Endpoint reduction in hypertension study (LIFE): a randomised trial against atenolol. Lancet. 2002;359(9311):995-1003. [pmid: 11937178].
170 Danesh J, Collins R, Appleby P, et al. Association of fibrinogen, C-reactive protein, albumin, or leukocyte count with coronary heart disease: meta-analyses of prospective studies. Jama. 1998;279(18):1477-82. [pmid: 9600484].
171 Danesh J, Collins R, Peto R. Lipoprotein(a) and coronary heart disease. Meta-analysis of prospective studies. Circulation. 2000;102(10):1082-5. [pmid: 10973834].
172 Dargie H J, Ford I, Fox K M. Total Ischaemic Burden European Trial (TIBET). Effects of ischaemia and treatment with atenolol, nifedipine SR and their combination on outcome in patients with chronic stable angina. The TIBET Study Group. Eur Heart J. 1996;17(1):104-12. [pmid: 8682116].
173 Dattilo A M, Kris-Etherton P M. Effects of weight reduction on blood lipids and lipoproteins: a meta-analysis. Am J Clin Nutr. 1992;56(2):320-8. [pmid: 1386186].
174 Davie A P. ACE inhibitors after myocardial infarction. Clinical and economic considerations. Pharmacoeconomics. 2000;17(3):237-43. [pmid: 10947299].
175 Davis K B, Chaitman B, Ryan T, et al. Comparison of 15-year survival for men and women after initial medical or surgical treatment for coronary artery disease: a CASS registry study. Coronary Artery Surgery Study. J Am Coll Cardiol. 1995;25(5):1000-9. [pmid: 7897108].
176 de Albuquerque Fonseca L, Picano E. Comparison of dipyridamole and exercise stress echocardiography for detection of coronary artery disease (a meta-analysis). Am J Cardiol 2001;87(10):1193–6; A4.
177 de Feyter P J, Keane D, Deckers J W, et al. Medium- and long-term outcome after coronary balloon angioplasty. Prog Cardiovasc Dis. 1994;36(5):385-96. [pmid: 8140251].
178 de Gaetano G. Low-dose aspirin and vitamin E in people at cardiovascular risk: a randomised trial in general practice. Collaborative Group of the Primary Prevention Project. Lancet. 2001;357(9250):89-95. [pmid: 11197445].
179 de Jaegere P P, Eefting F D, Popma J J, et al. Clinical trials on intracoronary stenting. Semin Interv Cardiol. 1996;1(4):233-45. [pmid: 9552517].
180 Degeare V S, Dangas G, Stone G W, et al. Interventional procedures in acute myocardial infarction. Am Heart J. 2001;141(1):15-24. [pmid: 11136482].
181 DeGeare V S, Stone G W, Grines L, et al. Angiographic and clinical characteristics associated with increased in-hospital mortality in elderly patients with acute myocardial infarction undergoing percutaneous intervention (a pooled analysis of the primary angioplasty in myocardial infarction trials). Am J Cardiol. 2000;86(1):30-4. [pmid: 10867088].
182 Denollet J. Type D personality. A potential risk factor refined. J Psychosom Res. 2000;49(4):255-66. [pmid: 11119782].
183 Denvir M A, Martin W, Tweddel A C, et al. A comparison of adenosine and exercise stress 201T1 scintigraphy. Nucl Med Commun. 1994;15(6):410-6. [pmid: 7915828].
184 Detrano R. Variability in the accuracy of the exercise ST-segment in predicting the coronary angiogram: how good can we be?. J Electrocardiol. 1992;24(Suppl):54-61. [pmid: 1532411].
185 Detrano R, Gianrossi R, Froelicher V. The diagnostic accuracy of the exercise electrocardiogram: a meta-analysis of 22 years of research. Prog Cardiovasc Dis. 1989;32(3):173-206. [pmid: 2530605].
186 Detrano R, Gianrossi R, Mulvihill D, et al. Exercise-induced ST segment depression in the diagnosis of multivessel coronary disease: a meta analysis. J Am Coll Cardiol. 1989;14(6):1501-8. [pmid: 2809010].
187 Detrano R, Hsiai T, Wang S, et al. Prognostic value of coronary calcification and angiographic stenoses in patients undergoing coronary angiography. J Am Coll Cardiol. 1996;27(2):285-90. [pmid: 8557895].
188 Detrano R, Janosi A, Lyons K P, et al. Factors affecting sensitivity and specificity of a diagnostic test: the exercise thallium scintigram. Am J Med. 1988;84(4):699-710. [pmid: 3041808].
189 Detrano R, Lyons K P, Marcondes G, et al. Methodologic problems in exercise testing research. Are we solving them?. Arch Intern Med. 1988;148(6):1289-95. [pmid: 3288157].
190 Detre K M, Rosen A D, Bost J E, et al. Contemporary practice of coronary revascularization in U.S. hospitals and hospitals participating in the bypass angioplasty revascularization investigation (BARI). J Am Coll Cardiol. 1996;28(3):609-15. [pmid: 8772747].
191 Di Salvo T T, Paul S D, Lloyd-Jones D, et al. Care of acute myocardial infarction by noninvasive and invasive cardiologists: procedure use, cost and outcome. J Am Coll Cardiol. 1996;27(2):262-9. [pmid: 8557892].
192 Diaz L A, Brunken R C, Blackstone E H, et al. Independent contribution of myocardial perfusion defects to exercise capacity and heart rate recovery for prediction of all-cause mortality in patients with known or suspected coronary heart disease. J Am Coll Cardiol. 2001;37(6):1558-64. [pmid: 11345365].
193 DiBianco R. Bepridil treatment of chronic stable angina: a review of comparative studies versus placebo, nifedipine, and diltiazem. Am J Cardiol. 1992;69(11):56D-62D.
194 Dickes M S, Stammers A H, Pierce M L, et al. Outcome analysis of coronary artery bypass grafting: minimally invasive versus standard techniques. Perfusion. 1999;14(6):461-72. [pmid: 10585154].
195 Dimmitt S B. Recent insights into dietary fats and cardiovascular disease. Clin Exp Pharmacol Physiol. 1995;22(3):204-8. [pmid: 7554415].
196 Dippel D W. The results of CAPRIE, IST and CAST. Clopidogrel vs. Aspirin in Patients at Risk of Ischaemic Events. International Stroke Trial. Chinese Acute Stroke Trial. Thromb Res. 1998;92(1 Suppl 1):S13-6. [pmid: 9781832].
197 Doherty T M, Detrano R C, Mautner S L, et al. Coronary calcium: the good, the bad, and the uncertain. Am Heart J. 1999;137(5):806-14. [pmid: 10220628].
198 Doliszny K M, Luepker R V, Burke G L, et al. Estimated contribution of coronary artery bypass graft surgery to the decline in coronary heart disease mortality: the Minnesota Heart Survey. J Am Coll Cardiol. 1994;24(1):95-103. [pmid: 8006288].
199 Dollery C. Diuretic agents and beta-blockers in the treatment of hypertension. Hypertension. 1989;13(5 Suppl):I62-5. [pmid: 2577461].
200 Domanski M J, Exner D V, Borkowf C B, et al. Effect of angiotensin converting enzyme inhibition on sudden cardiac death in patients following acute myocardial infarction. A meta-analysis of randomized clinical trials. J Am Coll Cardiol. 1999;33(3):598-604. [pmid: 10080457].
201 Donahue R P, Goldberg R J, Chen Z, et al. The influence of sex and diabetes mellitus on survival following acute myocardial infarction: a community-wide perspective. J Clin Epidemiol. 1993;46(3):245-52. [pmid: 8455049].
202 Doran J P, Howie A J, Townend J N, et al. Detection of myocardial infarction by immunohistological staining for C9 on formalin fixed, paraffin wax embedded sections. J Clin Pathol. 1996;49(1):34-7. [pmid: 8666682].
203 Doughty R N, Rodgers A, Sharpe N, et al. Effects of beta-blocker therapy on mortality in patients with heart failure. A systematic overview of randomized controlled trials. Eur Heart J. 1997;18(4):560-5. [pmid: 9129883].
204 Downs J R, Clearfield M, Weis S, et al. Primary prevention of acute coronary events with lovastatin in men and women with average cholesterol levels: results of AFCAPS/TexCAPS. Air Force/Texas Coronary Atherosclerosis Prevention Study. Jama. 1998;279(20):1615-22. [pmid: 9613910].
205 Du W, Ash A S, Berlowitz D R, et al. Variations in the management of acute myocardial infarction. Importance of clinical measures of disease severity. J Gen Intern Med. 1996;11(6):334-41. [pmid: 8803739].
206 Duprez D. Is vascular disease in the female different from men?. Int Angiol. 1993;12(4):331-4. [pmid: 8207308].
207 Dzavik V, Carere R G, Teo K K, et al. An open design, multicentre, randomized trial of percutaneous transluminal coronary angioplasty versus stenting, with a heparin-coated stent, of totally occluded coronary arteries: rationale, trial design and baseline patient characteristics. Total Occlusion Study of Canada (TOSCA) Investigators. Can J Cardiol. 1998;14(6):825-32. [pmid: 9676168].
208 Eaton C B. Relation of physical activity and cardiovascular fitness to coronary heart disease, Part I: A meta-analysis of the independent relation of physical activity and coronary heart disease. J Am Board Fam Pract. 1992;5(1):31-42. [pmid: 1532879].
209 Ebell M H, White L L, Weismantel D. A systematic review of troponin T and I values as a prognostic tool for patients with chest pain. J Fam Pract. 2000;49(8):746-53. [pmid: 10947143].
210 Ebrahim S, Smith G D. Systematic review of randomised controlled trials of multiple risk factor interventions for preventing coronary heart disease. Bmj. 1997;314(7095):1666-74. [pmid: 9193292].
211 Eckman M H, Wong J B, Salem D N, et al. Direct angioplasty for acute myocardial infarction. A review of outcomes in clinical subsets. Ann Intern Med. 1992;117(8):667-76. [pmid: 1530199].
212 Eikelboom J W, Anand S S, Malmberg K, et al. Unfractionated heparin and low-molecular-weight heparin in acute coronary syndrome without ST elevation: a meta-analysis. Lancet. 2000;355(9219):1936-42. [pmid: 10859038].
213 Einbinder L C, Schulman K A. The effect of race on the referral process for invasive cardiac procedures. Med Care Res Rev. 2000;57(Suppl 1):162-80. [pmid: 11092162].
214 Elliott W J. Circadian variation in blood pressure: implications for the elderly patient. Am J Hypertens. 1999;12(2 Pt 2):43S-49S. [pmid: 10090294].
215 Ellis S G, Da Silva E R, Spaulding C M, et al. Review of immediate angioplasty after fibrinolytic therapy for acute myocardial infarction: insights from the RESCUE I, RESCUE II, and other contemporary clinical experiences. Am Heart J. 2000;139(6):1046-53. [pmid: 10827386].
216 Ellis S G, Roubin G S, King S B 3rd, et al. In-hospital cardiac mortality after acute closure after coronary angioplasty: analysis of risk factors from 8,207 procedures. J Am Coll Cardiol. 1988;11(2):211-6. [pmid: 2963055].
217 Emery E M, Schmid T L, Kahn H S, et al. A review of the association between abdominal fat distribution, health outcome measures, and modifiable risk factors. Am J Health Promot. 1993;7(5):342-53. [pmid: 10148711].
218 Engman M L. An update on EBCT (Ultrafast CT) scans for coronary artery disease. J Insur Med. 1998;30(3):175-9. [pmid: 10351178].
219 Eysmann S B, Douglas P S. Reperfusion and revascularization strategies for coronary artery disease in women. Jama. 1992;268(14):1903-7. [pmid: 1404716].
220 Fager G, Wiklund O. Cholesterol reduction and clinical benefit. Are there limits to our expectations?. Arterioscler Thromb Vasc Biol. 1997;17(12):3527-33. [pmid: 9437202].
221 Feit F, Mueller H S, Braunwald E, et al. Thrombolysis in Myocardial Infarction (TIMI) phase II trial: outcome comparison of a “conservative strategy” in community versus tertiary hospitals. The TIMI Research Group. J Am Coll Cardiol. 1990;16(7):1529-34. [pmid: 2123901].
222 Ferguson T B Jr, Muhlbaier L H, Salai D L, et al. Coronary bypass grafting after failed elective and failed emergent percutaneous angioplasty. Relative risks of emergent surgical intervention. J Thorac Cardiovasc Surg. 1988;95(5):761-72. [pmid: 2966264].
223 Fernandes C J Jr, Akamine N, Knobel E. Cardiac troponin: a new serum marker of myocardial injury in sepsis. Intensive Care Med. 1999;25(10):1165-8. [pmid: 10551977].
224 Fiebach N H, Hebert P R, Stampfer M J, et al. A prospective study of high blood pressure and cardiovascular disease in women. Am J Epidemiol. 1989;130(4):646-54. [pmid: 2773913].
225 Field A E, Coakley E H, Must A, et al. Impact of overweight on the risk of developing common chronic diseases during a 10-year period. Arch Intern Med. 2001;161(13):1581-6. [pmid: 11434789].
226 Findlay I N. Coronary bypass surgery in women. Curr Opin Cardiol. 1994;9(6):650-7. [pmid: 7819623].
227 Fioretti F, Tavani A, Gallus S, et al. Menopause and risk of non-fatal acute myocardial infarction: an Italian case-control study and a review of the literature. Hum Reprod. 2000;15(3):599-603. [pmid: 10686203].
228 Fiorino A S. Electron-beam computed tomography, coronary artery calcium, and evaluation of patients with coronary artery disease. Ann Intern Med. 1998;128(10):839-47. [pmid: 9599197].
229 Flather M D, Yusuf S, Kober L, et al. Long-term ACE-inhibitor therapy in patients with heart failure or left-ventricular dysfunction: a systematic overview of data from individual patients. ACE-Inhibitor Myocardial Infarction Collaborative Group. Lancet. 2000;355(9215):1575-81. [pmid: 10821360].
230 Fleischmann K E, Hunink M G, Kuntz K M, et al. Exercise echocardiography or exercise SPECT imaging? A meta-analysis of diagnostic test performance. Jama. 1998;280(10):913-20. [pmid: 9739977].
231 Flores-Runk P, Raasch R H. Ticlopidine and antiplatelet therapy. Ann Pharmacother. 1993;27(9):1090-8. [pmid: 8219445].
232 Fodor J G, Boulet A P, Savard D, et al. The role of diltiazem in treating hypertension and coronary artery disease: new approaches to preventing first events. Can J Cardiol. 1997;13(5):495-503. [pmid: 9179089].
233 Folsom AR. Epidemiology of fibrinogen. Eur Heart J 1995;16(Suppl A):21–3; discussion 23–4.
234 Folsom A R, Arnett D K, Hutchinson R G, et al. Physical activity and incidence of coronary heart disease in middle-aged women and men. Med Sci Sports Exerc. 1997;29(7):901-9. [pmid: 9243489].
235 Folsom A R, Burke G L, Byers C L, et al. Implications of obesity for cardiovascular disease in blacks: the CARDIA and ARIC studies. Am J Clin Nutr. 1991;53(6 Suppl):1604S-1611S. [pmid: 2031493].
236 Folsom A R, French S A, Zheng W, et al. Weight variability and mortality: the Iowa Women's Health Study. Int J Obes Relat Metab Disord. 1996;20(8):704-9. [pmid: 8856391].
237 Folsom A R, Kushi L H, Anderson K E, et al. Associations of general and abdominal obesity with multiple health outcomes in older women: the Iowa Women's Health Study. Arch Intern Med. 2000;160(14):2117-28. [pmid: 10904454].
238 Folsom A R, Nieto F J, McGovern P G, et al. Prospective study of coronary heart disease incidence in relation to fasting total homocysteine, related genetic polymorphisms, and B vitamins: the Atherosclerosis Risk in Communities (ARIC) study. Circulation. 1998;98(3):204-10. [pmid: 9697819].
239 Folsom A R, Stevens J, Schreiner P J, et al. Body mass index, waist/hip ratio, and coronary heart disease incidence in African Americans and whites. Atherosclerosis Risk in Communities Study Investigators. Am J Epidemiol. 1998;148(12):1187-94. [pmid: 9867265].
240 Folsom A R, Szklo M, Stevens J, et al. A prospective study of coronary heart disease in relation to fasting insulin, glucose, and diabetes. The Atherosclerosis Risk in Communities (ARIC) Study. Diabetes Care. 1997;20(6):935-42. [pmid: 9167103].
241 Ford E S, Cooper R S. Racial/ethnic differences in health care utilization of cardiovascular procedures: a review of the evidence. Health Serv Res. 1995;30(1 Pt 2):237-52. [pmid: 7721595].
242 Fox K A. Comparative analysis of long-term mortality after thrombolytic therapy. Am J Cardiol. 1991;68(16):38E-44E.
243 Freemantle N, Cleland J, Young P, et al. beta Blockade after myocardial infarction: systematic review and meta regression analysis. Bmj. 1999;318(7200):1730-7. [pmcid: 31101]. [pmid: 10381708].
244 French J K, Webster M W, Neutze J M, et al. Evidence-based assessment of the benefit of revascularisation in coronary disease: beyond the randomised trials. Aust N Z J Med. 1996;26(4):490-4. [pmid: 8873931].
245 French S A, Folsom A R, Jeffery R W, et al. Weight variability and incident disease in older women: the Iowa Women's Health Study. Int J Obes Relat Metab Disord. 1997;21(3):217-23. [pmid: 9080261].
246 Freund K M, Belanger A J, D'Agostino R B, et al. The health risks of smoking. The Framingham Study: 34 years of follow-up. Ann Epidemiol. 1993;3(4):417-24. [pmid: 8275219].
247 Froom J, Froom P, Benjamin M, et al. Measurement and management of hyperlipidemia for the primary prevention of coronary heart disease. J Am Board Fam Pract. 1998;11(1):12-22. [pmid: 9456442].
248 Fu Y, Chang W C, Mark D, et al. Canadian-American differences in the management of acute coronary syndromes in the GUSTO IIb trial: one-year follow-up of patients without ST-segment elevation. Global Use of Strategies to Open Occluded Coronary Arteries (GUSTO) II Investigators. Circulation. 2000;102(12):1375-81. [pmid: 10993855].
249 Fuentes R, Ilmaniemi N, Laurikainen E, et al. Hypertension in developing economies: a review of population-based studies carried out from 1980 to 1998. J Hypertens. 2000;18(5):521-9. [pmid: 10826553].
250 Fuller J H, Stevens L K, Wang S L. International variations in cardiovascular mortality associated with diabetes mellitus: the WHO Multinational Study of Vascular Disease in Diabetes. Ann Med. 1996;28(4):319-22. [pmid: 8862686].
251 Furberg C D. Lipid-lowering trials: results and limitations. Am Heart J. 1994;128(6 Pt 2):1304-8. [pmid: 7977011].
252 Furberg C D, Pitt B. Are all angiotensin-converting enzyme inhibitors interchangeable?. J Am Coll Cardiol. 2001;37(5):1456-60. [pmid: 11300461].
253 Furberg C D, Psaty B M. Corrections to the nifedipine meta-analysis. Circulation. 1996;93(7):1475-6. [pmid: 8641044].
254 Furberg C D, Psaty B M, Meyer J V. Nifedipine. Dose-related increase in mortality in patients with coronary heart disease. Circulation. 1995;92(5):1326-31. [pmid: 7648682].
255 Garber A M, Browner W S, Hulley S B. Cholesterol screening in asymptomatic adults, revisited. Part 2. Ann Intern Med. 1996;124(5):518-31. [pmid: 8602715].
256 Garber A M, Solomon N A. Cost-effectiveness of alternative test strategies for the diagnosis of coronary artery disease. Ann Intern Med. 1999;130(9):719-28. [pmid: 10357690].
257 Garg R, Yusuf S. Overview of randomized trials of angiotensin-converting enzyme inhibitors on mortality and morbidity in patients with heart failure. Collaborative Group on ACE Inhibitor Trials. Jama. 1995;273(18):1450-6. [pmid: 7654275].
258 Garrison R J, Gold R S, Wilson P W, et al. Educational attainment and coronary heart disease risk: the Framingham Offspring Study. Prev Med. 1993;22(1):54-64. [pmid: 8475012].
259 Garzon P P, Eisenberg M J. Functional testing for the detection of restenosis after percutaneous transluminal coronary angioplasty: a meta-analysis. Can J Cardiol. 2001;17(1):41-8. [pmid: 11173313].
260 Gaziano J M, Skerrett P J, Buring J E. Aspirin in the treatment and prevention of cardiovascular disease. Haemostasis. 2000;30(Suppl 3):1-13. [pmid: 11182624].
261 Genest J Jr, Jenner J L, McNamara J R, et al. Prevalence of lipoprotein (a) [Lp(a)] excess in coronary artery disease. Am J Cardiol. 1991;67(13):1039-145. [pmid: 1827234].
262 Ghali J K, Pina I L, Gottlieb S S, et al. Metoprolol CR/XL in female patients with heart failure: analysis of the experience in Metoprolol Extended-Release Randomized Intervention Trial in Heart Failure (MERIT-HF). Circulation. 2002;105(13):1585-91. [pmid: 11927527].
263 Giacomini M K. Gender and ethnic differences in hospital-based procedure utilization in California. Arch Intern Med. 1996;156(11):1217-24. [pmid: 8639016].
264 Gianrossi R, Detrano R, Mulvihill D, et al. Exercise-induced ST depression in the diagnosis of coronary artery disease. A meta-analysis. Circulation. 1989;80(1):87-98. [pmid: 2661056].
265 Gibbons R J, Balady G J, Beasley J W, et al. ACC/AHA guidelines for exercise testing: executive summary. A report of the American College of Cardiology/American Heart Association Task Force on Practice Guidelines (Committee on Exercise Testing). Circulation. 1997;96(1):345-54. [pmid: 9236456].
266 Gibbons R J, Balady G J, Beasley J W, et al. ACC/AHA Guidelines for Exercise Testing. A report of the American College of Cardiology/American Heart Association Task Force on Practice Guidelines (Committee on Exercise Testing). J Am Coll Cardiol. 1997;30(1):260-311. [pmid: 9207652].
267 Gibson C M, Moynihan J L, Al-Mousa E N, et al. Glycoprotein IIb/IIIa receptor inhibition in interventional cardiology. J Thromb Thrombolysis. 1999;7(3):287-302. [pmid: 10375390].
268 Gibson R S, Boden W E. Calcium channel antagonists: friend or foe in postinfarction patients?. Am J Hypertens. 1996;9(12 Pt 2):172S-176S. [pmid: 8968429].
269 Giles T D, Fisher M B, Rush J E. Lisinopril and captopril in the treatment of heart failure in older patients. Comparison of a long- and short-acting angiotensin-converting enzyme inhibitor. Am J Med. 1988;85(3B):44-7. [pmid: 2844087].
270 Gill D, Mayou R, Dawes M, et al. Presentation, management and course of angina and suspected angina in primary care. J Psychosom Res. 1999;46(4):349-58. [pmid: 10340234].
271 Giugliano R P, Llevadot J, Wilcox R G, et al. Geographic variation in patient and hospital characteristics, management, and clinical outcomes in ST-elevation myocardial infarction treated with fibrinolysis. Results from InTIME-II. Eur Heart J. 2001;22(18):1702-15. [pmid: 11511120].
272 Giugliano R P, McCabe C H, Antman E M, et al. Lower-dose heparin with fibrinolysis is associated with lower rates of intracranial hemorrhage. Am Heart J. 2001;141(5):742-50. [pmid: 11320361].
273 Glasser S P, Frishman W, White W B, et al. Circadian heart rate response to chronotherapy versus conventional therapy in patients with hypertension and myocardial ischemia. Clin Cardiol. 2000;23(7):524-9. [pmid: 10894441].
274 Godsland I F, Wynn V, Crook D, et al. Sex, plasma lipoproteins, and atherosclerosis: prevailing assumptions and outstanding questions. Am Heart J. 1987;114(6):1467-503. [pmid: 3318361].
275 Goldberg K C, Hartz A J, Jacobsen S J, et al. Racial and community factors influencing coronary artery bypass graft surgery rates for all 1986 Medicare patients. Jama. 1992;267(11):1473-7. [pmid: 1538537].
276 Goldberg L, Elliot D L. The effect of physical activity on lipid and lipoprotein levels. Med Clin North Am. 1985;69(1):41-55. [pmid: 3883078].
277 Goldman L, Coxson P, Hunink M G, et al. The relative influence of secondary versus primary prevention using the National Cholesterol Education Program Adult Treatment Panel II guidelines. J Am Coll Cardiol. 1999;34(3):768-76. [pmid: 10483959].
278 Goldman L, Weinstein M C, Williams L W. Relative impact of targeted versus populationwide cholesterol interventions on the incidence of coronary heart disease. Projections of the Coronary Heart Disease Policy Model. Circulation. 1989;80(2):254-60. [pmid: 2787708].
279 Gonzalez M A, Rodriguez Artalejo F, Calero J R. Relationship between socioeconomic status and ischaemic heart disease in cohort and case-control studies: 1960-1993. Int J Epidemiol. 1998;27(3):350-8. [pmid: 9698119].
280 Gotto A M Jr. Heart disease in the assessment and treatment of hypercholesterolemia: coronary artery disease and other atherosclerotic disease, family history, and left ventricular hypertrophy. Am J Med. 1994;96(6A):9S-18S. [pmid: 8017474].
281 Gotto A M Jr, Grundy S M. Lowering LDL cholesterol: questions from recent meta-analyses and subset analyses of clinical trial DataIssues from the Interdisciplinary Council on Reducing the Risk for Coronary Heart Disease, ninth Council meeting. Circulation. 1999;99(8):E1-7.
282 Gould A L, Cariski A T. Meta-analysis by the Program on the Surgical Control of the Hyperlipidemias (POSCH) investigators. Ann Surg. 1998;227(2):314-6. [pmid: 9488536].
283 Gould A L, Rossouw J E, Santanello N C, et al. Cholesterol reduction yields clinical benefit. A new look at old data. Circulation. 1995;91(8):2274-82. [pmid: 7697857].
284 Gould A L, Rossouw J E, Santanello N C, et al. Cholesterol reduction yields clinical benefit: impact of statin trials. Circulation. 1998;97(10):946-52. [pmid: 9529261].
285 Grady D, Herrington D, Vittner V, et al. Cardiovascular disease outcomes during 6.8 years of hormone therapy. Heart and Estrogen/progestin Replacement Study Follow-up (HERS II). JAMA. 2002;288:49-57. [pmid: 12090862].
286 Grady D, Rubin S M, Petitti D B, et al. Hormone therapy to prevent disease and prolong life in postmenopausal women. Ann Intern Med. 1992;117(12):1016-37. [pmid: 1443971].
287 Granger C B, Hirsch J, Califf R M, et al. Activated partial thromboplastin time and outcome after thrombolytic therapy for acute myocardial infarction: results from the GUSTO-I trial. Circulation. 1996;93(5):870-8. [pmid: 8598077].
288 Greendale G A, Lee N P, Arriola E R. The menopause. Lancet. 1999;353(9152):571-80. [pmid: 10028999].
289 Greenland P, Reicher-Reiss H, Goldbourt U, et al. In-hospital and 1-year mortality in 1,524 women after myocardial infarction. Comparison with 4,315 men. Circulation. 1991;83(2):484-91. [pmid: 1991367].
290 Gregoire J P, Moisan J, Guibert R, et al. Tolerability of antihypertensive drugs in a community-based setting. Clin Ther. 2001;23(5):715-26. [pmid: 11394730].
291 Gronbaek M. Wine and mortality. Evidence for causal inference?. Dan Med Bull. 2000;47(4):271-82. [pmid: 11064830].
292 Grumbach K, Anderson G M, Luft H S, et al. Regionalization of cardiac surgery in the United States and Canada. Geographic access, choice, and outcomes. Jama. 1995;274(16):1282-8. [pmid: 7563533].
293 Guerci A D, Spadaro L A, Goodman K J, et al. Comparison of electron beam computed tomography scanning and conventional risk factor assessment for the prediction of angiographic coronary artery disease. J Am Coll Cardiol. 1998;32(3):673-9. [pmid: 9741510].
294 Gueyffier F, Boissel J P, Boutitie F, et al. Effect of antihypertensive treatment in patients having already suffered from stroke. Gathering the evidence. The INDANA (INdividual Data ANalysis of Antihypertensive intervention trials) Project Collaborators. Stroke. 1997;28(12):2557-62. [pmid: 9412649].
295 Gueyffier F, Boissel J P, Pocock S, et al. Identification of risk factors in hypertensive patients: contribution of randomized controlled trials through an individual patient database. Circulation. 1999;100(18):e88-94. [pmid: 10545441].
296 Gueyffier F, Boutitie F, Boissel J P, et al. Effect of antihypertensive drug treatment on cardiovascular outcomes in women and men. A meta-analysis of individual patient data from randomized, controlled trials. The INDANA Investigators. Ann Intern Med. 1997;126(10):761-7. [pmid: 9148648].
297 Gueyffier F, Froment A, Gouton M. New meta-analysis of treatment trials of hypertension: improving the estimate of therapeutic benefit. J Hum Hypertens. 1996;10(1):1-8. [pmid: 8642184].
298 Gunnell D, Harvey I, Smith L. The invasive management of angina: issues for consumers and commissioners. J Epidemiol Community Health. 1995;49(4):335-43. [pmid: 7650455].
299 Gurwitz J H, Col N F, Avorn J. The exclusion of the elderly and women from clinical trials in acute myocardial infarction. Jama. 1992;268(11):1417-22. [pmid: 1512909].
300 Guyton jr Effect of niacin on atherosclerotic cardiovascular disease. Am J Cardiol 1998;82(12A):18U–23U; discussion 39U–41U.
301 Haberbosch W, Jantos C. Chlamydia pneumoniae infection is not an independent risk factor for arterial disease. Herz. 2000;25(2):79-83. [pmid: 10829243].
302 Hachamovitch R, Berman D S, Kiat H, et al. Effective risk stratification using exercise myocardial perfusion SPECT in women: gender-related differences in prognostic nuclear testing. J Am Coll Cardiol. 1996;28(1):34-44. [pmid: 8752792].
303 Hachamovitch R, Berman D S, Kiat H, et al. Value of stress myocardial perfusion single photon emission computed tomography in patients with normal resting electrocardiograms: an evaluation of incremental prognostic value and cost-effectiveness. Circulation. 2002;105(7):823-9. [pmid: 11854122].
304 Haffner S M. Impaired glucose tolerance, insulin resistance and cardiovascular disease. Diabet Med. 1997;14(Suppl 3):S12-8. [pmid: 9272608].
305 Hagberg J M, Park J J, Brown M D. The role of exercise training in the treatment of hypertension: an update. Sports Med. 2000;30(3):193-206. [pmid: 10999423].
306 Hamilton C A, Link K M, Salido T B, et al. Is imaging at intermediate doses necessary during dobutamine stress magnetic resonance imaging?. J Cardiovasc Magn Reson. 2001;3(4):297-302. [pmid: 11777220].
307 Hankey G J, Sudlow C L, Dunbabin D W. Thienopyridines or aspirin to prevent stroke and other serious vascular events in patients at high risk of vascular disease? A systematic review of the evidence from randomized trials. Stroke. 2000;31(7):1779-84. [pmid: 10884487].
308 Hankey GJ, Sudlow CL, Dunbabin DW. Thienopyridine derivatives (ticlopidine, clopidogrel) versus aspirin for preventing stroke and other serious vascular events in high vascular risk patients. Cochrane Database Syst Rev 2000(2):CD001246.
309 Hannan E L, Kilburn H Jr, O'Donnell J F, et al. Interracial access to selected cardiac procedures for patients hospitalized with coronary artery disease in New York State. Med Care. 1991;29(5):430-41. [pmid: 2020208].
310 Hannan E L, Kumar D. Geographic variation in the utilization and choice of procedures for treating coronary artery disease in New York State. Ischaemic Heart Disease Patient Outcomes Research Team (PORT). J Health Serv Res Policy. 1997;2(3):137-43. [pmid: 10180374].
311 Hansen E F, Andersen L T, Von Eyben F E. Cigarette smoking and age at first acute myocardial infarction, and influence of gender and extent of smoking. Am J Cardiol. 1993;71(16):1439-42. [pmid: 8517392].
312 Hansen J F. Treatment with verapamil during and after an acute myocardial infarction: a review based on the Danish Verapamil Infarction Trials I and II. The Danish Study Group on Verapamil in Myocardial Infarction. J Cardiovasc Pharmacol. 1991;18(Suppl 6):S20-5.
313 Hansen J F. Review of postinfarct treatment with verapamil: combined experience of early and late intervention studies with verapamil in patients with acute myocardial infarction. Danish Study Group on Verapamil in Myocardial Infarction. Cardiovasc Drugs Ther. 1994;8(Suppl 3):543-7. [pmid: 7841087].
314 Hansson L, Zanchetti A, Carruthers S G, et al. Effects of intensive blood-pressure lowering and low-dose aspirin in patients with hypertension: principal results of the Hypertension Optimal Treatment (HOT) randomised trial. HOT Study Group. Lancet. 1998;351(9118):1755-62. [pmid: 9635947].
315 Harker L A, Boissel J P, Pilgrim A J, et al. Comparative safety and tolerability of clopidogrel and aspirin: results from CAPRIE. CAPRIE Steering Committee and Investigators. Clopidogrel versus aspirin in patients at risk of ischaemic events. Drug Saf. 1999;21(4):325-35. [pmid: 10514023].
316 Harnick D J, Cohen J L, Schechter C B, et al. Effects of practice setting on quality of lipid-lowering management in patients with coronary artery disease. Am J Cardiol. 1998;81(12):1416-20. [pmid: 9645890].
317 Harris T, Cook E F, Garrison R, et al. Body mass index and mortality among nonsmoking older persons. The Framingham Heart Study. Jama. 1988;259(10):1520-4. [pmid: 3339789].
318 Hart R G, Halperin J L, McBride R, et al. Aspirin for the primary prevention of stroke and other major vascular events: meta-analysis and hypotheses. Arch Neurol. 2000;57(3):326-32. [pmid: 10714657].
319 Hasdai D, Holmes D R Jr, Topol E J, et al. Frequency and clinical outcome of cardiogenic shock during acute myocardial infarction among patients receiving reteplase or alteplase. Results from GUSTO-III. Global Use of Strategies to Open Occluded Coronary Arteries. Eur Heart J. 1999;20(2):128-35. [pmid: 10099909].
320 Haymart M R, Dickfeld T, Nass C, et al. Percutaneous coronary intervention vs. medical therapy: what are the implications for women?. J Womens Health Gend Based Med. 2002;11(4):347-55. [pmid: 12150497].
321 He J, Whelton P K. Elevated systolic blood pressure as a risk factor for cardiovascular and renal disease. J Hypertens Suppl. 1999;17(2):S7-13. [pmid: 10465061].
322 Healy B. The Yentl syndrome. N Engl J Med. 1991;325(4):274-6. [pmid: 2057027].
323 Hebert P R, Gaziano J M, Chan K S, et al. Cholesterol lowering with statin drugs, risk of stroke, and total mortality. An overview of randomized trials. Jama. 1997;278(4):313-21. [pmid: 9228438].
324 Hebert P R, Hennekens C H. An overview of the 4 randomized trials of aspirin therapy in the primary prevention of vascular disease. Arch Intern Med. 2000;160(20):3123-7. [pmid: 11074741].
325 Heiat A, Vaccarino V, Krumholz H M. An evidence-based assessment of federal guidelines for overweight and obesity as they apply to elderly persons. Arch Intern Med. 2001;161(9):1194-203. [pmid: 11343442].
326 Heidenreich P A, Alloggiamento T, Melsop K, et al. The prognostic value of troponin in patients with non-ST elevation acute coronary syndromes: a meta-analysis. J Am Coll Cardiol. 2001;38(2):478-85. [pmid: 11499741].
327 Heidenreich P A, Lee T T, Massie B M. Effect of beta-blockade on mortality in patients with heart failure: a meta-analysis of randomized clinical trials. J Am Coll Cardiol. 1997;30(1):27-34. [pmid: 9207617].
328 Heidenreich P A, McClellan M. Trends in treatment and outcomes for acute myocardial infarction: 1975-1995. Am J Med. 2001;110(3):165-74. [pmid: 11182101].
329 Heidenreich P A, McDonald K M, Hastie T, et al. Meta-analysis of trials comparing beta-blockers, calcium antagonists, and nitrates for stable angina. Jama. 1999;281(20):1927-36. [pmid: 10349897].
330 Held P H, Teo K K, Yusuf S. Effects of tissue-type plasminogen activator and anisoylated plasminogen streptokinase activator complex on mortality in acute myocardial infarction. Circulation. 1990;82(5):1668-74. [pmid: 2146038].
331 Held P H, Yusuf S, Furberg C D. Calcium channel blockers in acute myocardial infarction and unstable angina: an overview. Bmj. 1989;299(6709):1187-92. [pmid: 2513047].
332 Hennekens C H. Thrombolytic therapy: pre- and post-GISSI-2, ISIS-3, and GUSTO-1. Clin Cardiol. 1994;17(1 Suppl 1):I15-7. [pmid: 8156657].
333 Hennekens C H, Albert C M, Godfried S L, et al. Adjunctive drug therapy of acute myocardial infarction--evidence from clinical trials. N Engl J Med. 1996;335(22):1660-7. [pmid: 8929364].
334 Hermanson B, Omenn G S, Kronmal R A, et al. Beneficial six-year outcome of smoking cessation in older men and women with coronary artery disease. Results from the CASS registry. N Engl J Med. 1988;319(21):1365-9. [pmid: 3185646].
335 Herold P M, Kinsella J E. Fish oil consumption and decreased risk of cardiovascular disease: a comparison of findings from animal and human feeding trials. Am J Clin Nutr. 1986;43(4):566-98. [pmid: 3515901].
336 Hill K. The demography of menopause. Maturitas. 1996;23(2):113-27. [pmid: 8735350].
337 Hillegass W B, Newman A R, Raco D L. Glycoprotein IIb/IIIa receptor therapy in percutaneous coronary intervention and non-ST-segment elevation acute coronary syndromes. Estimating the economic implications. Pharmacoeconomics. 2001;19(1):41-55. [pmid: 11252545].
338 Hlatky M A, Pryor D B, Harrell F E Jr, et al. Factors affecting sensitivity and specificity of exercise electrocardiography. Multivariable analysis. Am J Med. 1984;77(1):64-71. [pmid: 6741986].
339 Hochman J S, McCabe C H, Stone P H, et al. Outcome and profile of women and men presenting with acute coronary syndromes: a report from TIMI IIIB. TIMI Investigators. Thrombolysis in Myocardial Infarction. J Am Coll Cardiol. 1997;30(1):141-8. [pmid: 9207635].
340 Hochman J S, Tamis J E, Thompson T D, et al. Sex, clinical presentation, and outcome in patients with acute coronary syndromes. Global Use of Strategies to Open Occluded Coronary Arteries in Acute Coronary Syndromes IIb Investigators. N Engl J Med. 1999;341(4):226-32. [pmid: 10413734].
341 Hoes A W, Grobbee D E, Lubsen J. Does drug treatment improve survival? Reconciling the trials in mild-to-moderate hypertension. J Hypertens. 1995;13(7):805-11. [pmid: 7594445].
342 Hoher M, Wohrle J, Grebe O C, et al. A randomized trial of elective stenting after balloon recanalization of chronic total occlusions. J Am Coll Cardiol. 1999;34(3):722-9. [pmid: 10483953].
343 Hokanson J E, Austin M A. Plasma triglyceride level is a risk factor for cardiovascular disease independent of high-density lipoprotein cholesterol level: a meta-analysis of population-based prospective studies. J Cardiovasc Risk. 1996;3(2):213-9. [pmid: 8836866].
344 Holme I. Relation of coronary heart disease incidence and total mortality to plasma cholesterol reduction in randomised trials: use of meta-analysis. Br Heart J. 1993;69(1 Suppl):S42-7. [pmid: 8427764].
345 Holme I. Effects of lipid-lowering therapy on total and coronary mortality. Curr Opin Lipidol. 1995;6(6):374-8. [pmid: 8750251].
346 Holme I. Cholesterol reduction and its impact on coronary artery disease and total mortality. Am J Cardiol. 1995;76(9):10C-17C.
347 Holme I. Relationship between total mortality and cholesterol reduction as found by meta-regression analysis of randomized cholesterol-lowering trials. Control Clin Trials. 1996;17(1):13-22. [pmid: 8721798].
348 Holme I, Ekelund L G, Hjermann I, et al. Quality-adjusted meta-analysis of the hypertension/coronary dilemma. Am J Hypertens. 1994;7(8):703-12. [pmid: 7986460].
349 Holmes D R Jr, Holubkov R, Vlietstra R E, et al. Comparison of complications during percutaneous transluminal coronary angioplasty from 1977 to 1981 and from 1985 to 1986: the National Heart, Lung, and Blood Institute Percutaneous Transluminal Coronary Angioplasty Registry. J Am Coll Cardiol. 1988;12(5):1149-55. [pmid: 2971699].
350 Honan M B, Harrell F E Jr, Reimer K A, et al. Cardiac rupture, mortality and the timing of thrombolytic therapy: a meta-analysis. J Am Coll Cardiol. 1990;16(2):359-67. [pmid: 2142705].
351 Horton H L, Marinchak R A, Rials S J, et al. Gender differences in device therapy for malignant ventricular arrhythmias. Arch Intern Med. 1995;155(21):2342-5. [pmid: 7487260].
352 Houghton T, Freemantle N, Cleland J G. Are beta-blockers effective in patients who develop heart failure soon after myocardial infarction? A meta-regression analysis of randomised trials. Eur J Heart Fail. 2000;2(3):333-40. [pmid: 10938496].
353 Howard G, Manolio T A, Burke G L, et al. Does the association of risk factors and atherosclerosis change with age? An analysis of the combined ARIC and CHS cohorts. The Atherosclerosis Risk in Communities (ARIC) and Cardiovascular Health Study (CHS) investigators. Stroke. 1997;28(9):1693-701. [pmid: 9303011].
354 Howes L G, Simons L A. Efficacy of drug intervention for lipids in the prevention of coronary artery disease. Aust N Z J Med. 1994;24(1):107-12. [pmid: 8002848].
355 Hu F B, Grodstein F, Hennekens C H, et al. Age at natural menopause and risk of cardiovascular disease. Arch Intern Med. 1999;159(10):1061-6. [pmid: 10335682].
356 Hu F B, Stampfer M J, Solomon C G, et al. The impact of diabetes mellitus on mortality from all causes and coronary heart disease in women: 20 years of follow-up. Arch Intern Med. 2001;161(14):1717-23. [pmid: 11485504].
357 Hubert H B, Feinleib M, McNamara P M, et al. Obesity as an independent risk factor for cardiovascular disease: a 26-year follow-up of participants in the Framingham Heart Study. Circulation. 1983;67(5):968-77. [pmid: 6219830].
358 Huckell V F, Bernstein V, Cairns J A, et al. Angiotensin-converting enzyme inhibition in myocardial infarction--Part 1: Clinical data. Can J Cardiol. 1997;13(2):161-9. [pmid: 9070168].
359 Hughes G C, Abdel-aleem S, Biswas S S, et al. Transmyocardial laser revascularization: experimental and clinical results. Can J Cardiol. 1999;15(7):797-806. [pmid: 10411618].
360 Hughes G C, Annex B H, Yin B, et al. Transmyocardial laser revascularization limits in vivo adenoviral-mediated gene transfer in porcine myocardium. Cardiovasc Res. 1999;44(1):81-90. [pmid: 10615392].
361 Hume A L, Barbour M M, Willey C J, et al. Changing trends in antihypertensive therapy in two New England communities during the 1980s. Pharmacotherapy. 1993;13(3):244-51. [pmid: 8100629].
362 Hunink M G, Kuntz K M, Fleischmann K E, et al. Noninvasive imaging for the diagnosis of coronary artery disease: focusing the development of new diagnostic technology. Ann Intern Med. 1999;131(9):673-80. [pmid: 10577330].
363 Hussain K M, Kogan A, Estrada A Q, et al. Referral pattern and outcome in men and women undergoing coronary artery bypass surgery--a critical review. Angiology. 1998;49(4):243-50. [pmid: 9555926].
364 Hutchinson L A, Pasternack P F, Baumann F G, et al. Is there detrimental gender bias in preoperative cardiac management of patients undergoing vascular surgery?. Circulation. 1994;90(5 Pt 2):II220-3. [pmid: 7955257].
365 Hutchinson R G, Watson R L, Davis C E, et al. Racial differences in risk factors for atherosclerosis. The ARIC Study. Atherosclerosis Risk in Communities. Angiology. 1997;48(4):279-90. [pmid: 9112876].
366 Insua J T, Sacks H S, Lau T S, et al. Drug treatment of hypertension in the elderly: a meta-analysis. Ann Intern Med. 1994;121(5):355-62. [pmid: 7726892].
367 Ioannidis J P, Salem D, Chew P W, et al. Accuracy of imaging technologies in the diagnosis of acute cardiac ischemia in the emergency department: a meta-analysis. Ann Emerg Med. 2001;37(5):471-7. [pmid: 11326183].
368 Iskandrian A E, Heo J, Nallamothu N. Detection of coronary artery disease in women with use of stress single-photon emission computed tomography myocardial perfusion imaging. J Nucl Cardiol. 1997;4(4):329-35. [pmid: 9278880].
369 Izzat M B, West R R, Bryan A J, et al. Coronary artery bypass surgery: current practice in the United Kingdom. Br Heart J. 1994;71(4):382-5. [pmid: 8198893].
370 Jackson R E, Anderson W, Peacock WFt, et al. Effect of a patient's sex on the timing of thrombolytic therapy. Ann Emerg Med. 1996;27(1):8-15. [pmid: 8572455].
371 Jacobs A K, Kelsey S F, Brooks M M, et al. Better outcome for women compared with men undergoing coronary revascularization: a report from the bypass angioplasty revascularization investigation (BARI). Circulation. 1998;98(13):1279-85. [pmid: 9751675].
372 Jacobs A K, Kelsey S F, Yeh W, et al. Documentation of decline in morbidity in women undergoing coronary angioplasty (a report from the 1993–94 NHLBI Percutaneous Transluminal Coronary Angioplasty Registry). National Heart, Lung, and Blood Institute. Am J Cardiol. 1997;80(8):979-84. [pmid: 9352963].
373 Jacobs D, Blackburn H, Higgins M, et al. Report of the Conference on Low Blood Cholesterol: Mortality Associations. Circulation. 1992;86(3):1046-60. [pmid: 1355411].
374 Jacobson T A. “The lower the better” in hypercholesterolemia therapy: a reliable clinical guideline?. Ann Intern Med. 2000;133(7):549-54. [pmid: 11015169].
375 Jaglal S B, Goel V, Naylor C D. Sex differences in the use of invasive coronary procedures in Ontario. Can J Cardiol. 1994;10(2):239-44. [pmid: 8143225].
376 Janzon M, Levin L A, Swahn E. Cost-effectiveness of an invasive strategy in unstable coronary artery disease; results from the FRISC II invasive trial. The Fast Revascularisation during InStability in Coronary artery disease. Eur Heart J. 2002;23(1):31-40. [pmid: 11741360].
377 Jarrett R J. The cardiovascular risk associated with impaired glucose tolerance. Diabet Med. 1996;13(3 Suppl 2):S15-9. [pmid: 8689856].
378 Jenkins PL, Weinehall L, Erb TA, et al. The Norsjo-Cooperstown healthy heart project: a case study combining data from different studies without the use of meta-analysis. Scand J Public Health 2001;Suppl(56):40–5.
379 Johnson P A, Goldman L, Orav E J, et al. Gender differences in the management of acute chest pain. Support for the “Yentl syndrome”. J Gen Intern Med. 1996;11(4):209-17. [pmid: 8744878].
380 Johnson P A, Lee T H, Cook E F, et al. Effect of race on the presentation and management of patients with acute chest pain. Ann Intern Med. 1993;118(8):593-601. [pmid: 8452325].
381 Jolliffe JA, Rees K, Taylor RS, et al. Exercise-based rehabilitation for coronary heart disease. Cochrane Database Syst Rev 2000;4.
382 Jones R H, Hannan E L, Hammermeister K E, et al. Identification of preoperative variables needed for risk adjustment of short-term mortality after coronary artery bypass graft surgery. The Working Group Panel on the Cooperative CABG Database Project. J Am Coll Cardiol. 1996;28(6):1478-87. [pmid: 8917261].
383 Jones R H, Kesler K, Phillips H R 3rd, et al. Long-term survival benefits of coronary artery bypass grafting and percutaneous transluminal angioplasty in patients with coronary artery disease. J Thorac Cardiovasc Surg. 1996;111(5):1013-25. [pmid: 8622299].
384 Kannel W B. Blood pressure as a cardiovascular risk factor: prevention and treatment. Jama. 1996;275(20):1571-6. [pmid: 8622248].
385 Kannel W B, Cupples L A, Ramaswami R, et al. Regional obesity and risk of cardiovascular disease; the Framingham Study. J Clin Epidemiol. 1991;44(2):183-90. [pmid: 1995775].
386 Kannel W B, D'Agostino R B, Belanger A J. Fibrinogen, cigarette smoking, and risk of cardiovascular disease: insights from the Framingham Study. Am Heart J. 1987;113(4):1006-10. [pmid: 3565227].
387 Kannel WB, D'Agostino RB, Belanger AJ. Risk reduction after quitting smoking. Quality of Life and Cardiovascular Care 1989:84–85.
388 Kannel W B, D'Agostino R B, Wilson P W, et al. Diabetes, fibrinogen, and risk of cardiovascular disease: the Framingham experience. Am Heart J. 1990;120(3):672-6. [pmid: 2389702].
389 Kannel W B, Schatzkin A. Sudden death: lessons from subsets in population studies. J Am Coll Cardiol. 1985;5(6 Suppl):141B-149B.
390 Kannel W B, Sorlie P, McNamara P M. Prognosis after initial myocardial infarction: the Framingham study. Am J Cardiol. 1979;44(1):53-9. [pmid: 453046].
391 Kannel W B, Wilson P W. Efficacy of lipid profiles in prediction of coronary disease. Am Heart J. 1992;124(3):768-74. [pmid: 1514505].
392 Katan M B. High-oil compared with low-fat, high-carbohydrate diets in the prevention of ischemic heart disease. Am J Clin Nutr. 1997;66(4 Suppl):974S-979S. [pmid: 9322576].
393 Kawachi I, Colditz G A, Speizer F E, et al. A prospective study of passive smoking and coronary heart disease. Circulation. 1997;95(10):2374-9. [pmid: 9170399].
394 Kawachi I, Colditz G A, Stampfer M J, et al. Smoking cessation in relation to total mortality rates in women. A prospective cohort study. Ann Intern Med. 1993;119(10):992-1000. [pmid: 8214996].
395 Kawachi I, Colditz GA, Stampfer MJ, et al. Smoking cessation and decreased risks of total mortality, stroke, and coronary heart disease incidence among women: a prospective cohort study. In: Burns DM, Garfinkel L, Samet JM, editors. Changes in cigarette-related disease risks and thier implications for prevention and control. Bethesda: National Cancer Institute; 1997. p. 531–65.
396 Kawachi I, Colditz G A, Stampfer M J, et al. Smoking cessation and time course of decreased risks of coronary heart disease in middle-aged women. Arch Intern Med. 1994;154(2):169-75. [pmid: 8285812].
397 Keelan P C, Bielak L F, Ashai K, et al. Long-term prognostic value of coronary calcification detected by electron-beam computed tomography in patients undergoing coronary angiography. Circulation. 2001;104(4):412-7. [pmid: 11468202].
398 Keenan C R, Chou T M. Revascularization in coronary artery disease. A review of randomized trial data. West J Med. 1998;168(4):280-5. [pmid: 9584677].
399 Keil J E, Sutherland S E, Knapp R G, et al. Mortality rates and risk factors for coronary disease in black as compared with white men and women. N Engl J Med. 1993;329(2):73-8. [pmid: 8510705].
400 Keil U. Coronary artery disease: the role of lipids, hypertension and smoking. Basic Res Cardiol. 2000;95(Suppl 1):I52-8. [pmid: 11192354].
401 Kellett J, Clarke J. Comparison of “accelerated” tissue plasminogen activator with streptokinase for treatment of suspected myocardial infarction. Med Decis Making. 1995;15(4):297-310. [pmid: 8544674].
402 Kelly R. Selections from current literature: treatment of hypertension. Fam Pract. 1992;9(1):104-8. [pmid: 1634020].
403 Kelsey S F, James M, Holubkov A L, et al. Results of percutaneous transluminal coronary angioplasty in women. 1985-1986 National Heart, Lung, and Blood Institute's Coronary Angioplasty Registry. Circulation. 1993;87(3):720-7. [pmid: 8443892].
404 Kennedy J, Shavelle R, Wang S, et al. Coronary calcium and standard risk factors in symptomatic patients referred for coronary angiography. Am Heart J. 1998;135(4):696-702. [pmid: 9539488].
405 Ketola E, Sipila R, Makela M. Effectiveness of individual lifestyle interventions in reducing cardiovascular disease and risk factors. Ann Med. 2000;32(4):239-51. [pmid: 10852140].
406 Khan S S, Nessim S, Gray R, et al. Increased mortality of women in coronary artery bypass surgery: evidence for referral bias. Ann Intern Med. 1990;112(8):561-7. [pmid: 2327676].
407 Kilaru P K, Kelly R F, Calvin J E, et al. Utilization of coronary angiography and revascularization after acute myocardial infarction in men and women risk stratified by the American College of Cardiology/American Heart Association guidelines. J Am Coll Cardiol. 2000;35(4):974-9. [pmid: 10732897].
408 Kim R J, Hillenbrand H B, Judd R M. Evaluation of myocardial viability by MRI. Herz. 2000;25(4):417-30. [pmid: 10948778].
409 Kimmelstiel C, Goldberg R J. Congestive heart failure in women: focus on heart failure due to coronary artery disease and diabetes. Cardiology. 1990;77(Suppl 2):71-9. [pmid: 2198097].
410 King SB, 3rd. The impact of performing a clinical trial on patient outcomes: lessons from the Emory Angioplasty vs. Surgery Trial. Trans Am Clin Climatol Assoc 1995;107:68–77; discussion 77–8.
411 Kinn J W, O'Neill W W, Benzuly K H, et al. Primary angioplasty reduces risk of myocardial rupture compared to thrombolysis for acute myocardial infarction. Cathet Cardiovasc Diagn. 1997;42(2):151-7. [pmid: 9328698].
412 Kinney M R, Burfitt S N, Stullenbarger E, et al. Quality of life in cardiac patient research: a meta-analysis. Nurs Res. 1996;45(3):173-80. [pmid: 8637799].
413 Kjeldsen S E, Kolloch R E, Leonetti G, et al. Influence of gender and age on preventing cardiovascular disease by antihypertensive treatment and acetylsalicylic acid. The HOT study. Hypertension Optimal Treatment. J Hypertens. 2000;18(5):629-42. [pmid: 10826567].
414 Kjeldsen S E, Warnold I, Hansson L. Influence of gender on prevention of myocardial infarction by antihypertensives and acetylsalicylic acid: the HOT study. J Gend Specif Med. 2000;3(8):35-8. [pmid: 11253266].
415 Kloner R A, Vetrovec G W, Materson B J, et al. Safety of long-acting dihydropyridine calcium channel blockers in hypertensive patients. Am J Cardiol. 1998;81(2):163-9. [pmid: 9591899].
416 Klungel O H, de Boer A, Paes A H, et al. Sex differences in the pharmacological treatment of hypertension: a review of population-based studies. J Hypertens. 1997;15(6):591-600. [pmid: 9218177].
417 Klungel O H, de Boer A, Paes A H, et al. Sex differences in antihypertensive drug use: determinants of the choice of medication for hypertension. J Hypertens. 1998;16(10):1545-53. [pmid: 9814628].
418 Klungel O H, Paes A H, de Boer A, et al. Sex differences in the medication choice for hypertension in general practice. A study with written case simulations. Pharm World Sci. 2000;22(4):140-6. [pmid: 11103384].
419 Knapp R G, Sutherland S E, Keil J E, et al. A comparison of the effects of cholesterol on CHD mortality in black and white women: twenty-eight years of follow-up in the Charleston Heart Study. J Clin Epidemiol. 1992;45(10):1119-29. [pmid: 1474408].
420 Knowler W C, Barrett-Connor E, Fowler S E, et al. Reduction in the incidence of type 2 diabetes with lifestyle intervention or metformin. N Engl J Med. 2002;346(6):393-403. [pmid: 11832527].
421 Ko W, Gold J P, Lazzaro R, et al. Survival analysis of octogenarian patients with coronary artery disease managed by elective coronary artery bypass surgery versus conventional medical treatment. Circulation. 1992;86(5 Suppl):II191-7. [pmid: 1423999].
422 Koenig W. Fibrinogen and coronary risk. Curr Cardiol Rep. 1999;1(2):112-8. [pmid: 10980829].
423 Kong D F, Califf R M, Miller D P, et al. Clinical outcomes of therapeutic agents that block the platelet glycoprotein IIb/IIIa integrin in ischemic heart disease. Circulation. 1998;98(25):2829-35. [pmid: 9860783].
424 Kong D F, Topol E J, Bittl J A, et al. Clinical outcomes of bivalirudin for ischemic heart disease. Circulation. 1999;100(20):2049-53. [pmid: 10562259].
425 Kotler T S, Diamond G A. Exercise thallium-201 scintigraphy in the diagnosis and prognosis of coronary artery disease. Ann Intern Med. 1990;113(9):684-702. [pmid: 2221649].
426 Krumholz H M, Douglas P S, Lauer M S, et al. Selection of patients for coronary angiography and coronary revascularization early after myocardial infarction: is there evidence for a gender bias?. Ann Intern Med. 1992;116(10):785-90. [pmid: 1567092].
427 Kudenchuk P J, Maynard C, Martin J S, et al. Comparison of presentation, treatment, and outcome of acute myocardial infarction in men versus women (the Myocardial Infarction Triage and Intervention Registry). Am J Cardiol. 1996;78(1):9-14. [pmid: 8712126].
428 Kuller L H, Simkin-Silverman L R, Wing R R, et al. Women's Healthy Lifestyle Project: A randomized clinical trial: results at 54 months. Circulation. 2001;103(1):32-7. [pmid: 11136682].
429 Kuntz K M, Tsevat J, Weinstein M C, et al. Expert panel vs decision-analysis recommendations for postdischarge coronary angiography after myocardial infarction. Jama. 1999;282(23):2246-51. [pmid: 10605977].
430 Kwok Y, Kim C, Grady D, et al. Meta-analysis of exercise testing to detect coronary artery disease in women. Am J Cardiol. 1999;83(5):660-6. [pmid: 10080415].
431 La Vecchia C. Sex hormones and cardiovascular risk. Hum Reprod. 1992;7(2):162-7. [pmid: 1577926].
432 LaCroix A Z, Lang J, Scherr P, et al. Smoking and mortality among older men and women in three communities. N Engl J Med. 1991;324(23):1619-25. [pmid: 2030718].
433 LaRosa J C, He J, Vupputuri S. Effect of statins on risk of coronary disease: a meta-analysis of randomized controlled trials. Jama. 1999;282(24):2340-6. [pmid: 10612322].
434 Larsen J, Vaccheri A, Andersen M, et al. Lack of adherence to lipid-lowering drug treatment. A comparison of utilization patterns in defined populations in Funen, Denmark and Bologna, Italy. Br J Clin Pharmacol. 2000;49(5):463-71. [pmid: 10792204].
435 Latini R, Maggioni A P, Flather M, et al. ACE inhibitor use in patients with myocardial infarction. Summary of evidence from clinical trials. Circulation. 1995;92(10):3132-7. [pmid: 7586285].
436 Latini R, Tognoni G, Maggioni A P, et al. Clinical effects of early angiotensin-converting enzyme inhibitor treatment for acute myocardial infarction are similar in the presence and absence of aspirin: systematic overview of individual data from 96,712 randomized patients. Angiotensin-converting Enzyme Inhibitor Myocardial Infarction Collaborative Group. J Am Coll Cardiol. 2000;35(7):1801-7. [pmid: 10841227].
437 Lau G S, Chan J C, Chu P L, et al. Use of antidiabetic and antihypertensive drugs in hospital and outpatient settings in Hong Kong. Ann Pharmacother. 1996;30(3):232-7. [pmid: 8833556].
438 Lau J, Antman E M, Jimenez-Silva J, et al. Cumulative meta-analysis of therapeutic trials for myocardial infarction. N Engl J Med. 1992;327(4):248-54. [pmid: 1614465].
439 Lau J, Ioannidis J P, Balk E M, et al. Diagnosing acute cardiac ischemia in the emergency department: a systematic review of the accuracy and clinical effect of current technologies. Ann Emerg Med. 2001;37(5):453-60. [pmid: 11326181].
440 Law M R, Wald N J, Thompson S G. By how much and how quickly does reduction in serum cholesterol concentration lower risk of ischaemic heart disease?. Bmj. 1994;308(6925):367-72. [pmid: 8043072].
441 Lear J T, Lawrence I G, Burden A C, et al. A comparison of stress test referral rates and outcome between Asians and Europeans. J R Soc Med. 1994;87(11):661-2. [pmid: 7837185].
442 Lear J T, Lawrence I G, Pohl J E, et al. Myocardial infarction and thrombolysis: a comparison of the Indian and European populations on a coronary care unit. J R Coll Physicians Lond. 1994;28(2):143-7. [pmid: 8006867].
443 Lechat P, Packer M, Chalon S, et al. Clinical effects of beta-adrenergic blockade in chronic heart failure: a meta-analysis of double-blind, placebo-controlled, randomized trials. Circulation. 1998;98(12):1184-91. [pmid: 9743509].
444 Lee I M, Rexrode K M, Cook N R, et al. Physical activity and coronary heart disease in women: is “no pain, no gain” passe?. Jama. 2001;285(11):1447-54. [pmid: 11255420].
445 Lee S, Spencer A. Beta-blockers to reduce mortality in patients with systolic dysfunction: a meta-analysis. J Fam Pract. 2001;50(6):499-504. [pmid: 11401736].
446 Lee T H, Boucher C A. Clinical practice. Noninvasive tests in patients with stable coronary artery disease. N Engl J Med. 2001;344(24):1840-5. [pmid: 11407346].
447 Lee W L, Cheung A M, Cape D, et al. Impact of diabetes on coronary artery disease in women and men: a meta-analysis of prospective studies. Diabetes Care. 2000;23(7):962-8. [pmid: 10895847].
448 Leis H P Jr. The relationship of diet to cancer, cardiovascular disease and longevity. Int Surg. 1991;76(1):1-5. [pmid: 2045244].
449 Leizorovicz A, Lechat P, Cucherat M, et al. Bisoprolol for the treatment of chronic heart failure: a meta-analysis on individual data of two placebo-controlled studies--CIBIS and CIBIS II. Cardiac Insufficiency Bisoprolol Study. Am Heart J. 2002;143(2):301-7. [pmid: 11835035].
450 Lerner D J, Kannel W B. Patterns of coronary heart disease morbidity and mortality in the sexes: a 26-year follow-up of the Framingham population. Am Heart J. 1986;111(2):383-90. [pmid: 3946178].
451 Lewington S, MacMahon S. Blood pressure, cholesterol, and common causes of death: a review. Prospective Studies Collaboration. Am J Hypertens. 1999;12(10 Pt 2):96S-98S. [pmid: 10555608].
452 Lewis S J, Sacks F M, Mitchell J S, et al. Effect of pravastatin on cardiovascular events in women after myocardial infarction: the cholesterol and recurrent events (CARE) trial. J Am Coll Cardiol. 1998;32(1):140-6. [pmid: 9669262].
453 Lewsey J D, Murray G D, Leyland A H, et al. Comparing outcomes of percutaneous transluminal coronary angioplasty with coronary artery bypass grafting; can routine health service data complement and enhance randomized controlled trials?. Eur Heart J. 1999;20(23):1731-5. [pmid: 10562481].
454 Lieu T A, Gurley R J, Lundstrom R J, et al. Primary angioplasty and thrombolysis for acute myocardial infarction: an evidence summary. J Am Coll Cardiol. 1996;27(3):737-50. [pmid: 8606291].
455 Lincoff A M, Califf R M, Anderson K M, et al. Evidence for prevention of death and myocardial infarction with platelet membrane glycoprotein IIb/IIIa receptor blockade by abciximab (c7E3 Fab) among patients with unstable angina undergoing percutaneous coronary revascularization. EPIC Investigators.Evaluation of 7E3 in Preventing Ischemic Complications. J Am Coll Cardiol. 1997;30(1):149-56. [pmid: 9207636].
456 Lincoff A M, Califf R M, Ellis S G, et al. Thrombolytic therapy for women with myocardial infarction: is there a gender gap? Thrombolysis and Angioplasty in Myocardial Infarction Study Group. J Am Coll Cardiol. 1993;22(7):1780-7. [pmid: 8245328].
457 Link N, Tanner M. Coronary artery disease: Part 1. Epidemiology and diagnosis. West J Med. 2001;174(4):257-61. [pmid: 11290684].
458 Lip G Y, Beevers D G. Alcohol, hypertension, coronary disease and stroke. Clin Exp Pharmacol Physiol. 1995;22(3):189-94. [pmid: 7554412].
459 Lobo R A. Lipids, clotting factors, and diabetes: endogenous risk factors for cardiovascular disease. Am J Obstet Gynecol. 1988;158(6 Pt 2):1584-91. [pmid: 3287930].
460 Loewen P, Sunderji R, Gin K. The efficacy and safety of combination warfarin and ASA therapy: a systematic review of the literature and update of guidelines. Can J Cardiol. 1998;14(5):717-26. [pmid: 9627529].
461 Lonn E, Roccaforte R, Yi Q, et al. Effect of long-term therapy with ramipril in high-risk women. J Am Coll Cardiol. 2002;40(4):693. [pmid: 12204499].
462 Lonn E M, Yusuf S. Evidence based cardiology: emerging approaches in preventing cardiovascular disease. Bmj. 1999;318(7194):1337-41. [pmid: 10323824].
463 Lowel H, Lewis M, Hormann A, et al. Case finding, data quality aspects and comparability of myocardial infarction registers: results of a south German register study. J Clin Epidemiol. 1991;44(3):249-60. [pmid: 1999684].
464 Lubsen J. The calcium channel antagonist debate: recent developments. Eur Heart J. 1998;19(Suppl I):I3-7. [pmid: 9743437].
465 MacMahon S, Sharpe N. Long-term antiplatelet therapy for the prevention of vascular disease. Med J Aust. 1991;154(7):477-80. [pmid: 1900910].
466 Maggioni A P, Sessa F, Latini R, et al. Treatment of acute myocardial infarction today. Am Heart J. 1997;134(2 Pt 2):S9-14. [pmid: 9313618].
467 Magrini N, Einarson T, Vaccheri A, et al. Use of lipid-lowering drugs from 1990 to 1994: an international comparison among Australia, Finland, Italy (Emilia Romagna Region), Norway and Sweden. Eur J Clin Pharmacol. 1997;53(34):185-9. [pmid: 9476029].
468 Mahaffey K W, Granger C B, Collins R, et al. Overview of randomized trials of intravenous heparin in patients with acute myocardial infarction treated with thrombolytic therapy. Am J Cardiol. 1996;77(8):551-6. [pmid: 8610601].
469 Mahaffey K W, Granger C B, Toth C A, et al. Diabetic retinopathy should not be a contraindication to thrombolytic therapy for acute myocardial infarction: review of ocular hemorrhage incidence and location in the GUSTO-I trial. Global Utilization of Streptokinase and t-PA for Occluded Coronary Arteries. J Am Coll Cardiol. 1997;30(7):1606-10. [pmid: 9385883].
470 Majeed A, Moser K, Maxwell R. Age, sex and practice variations in the use of statins in general practice in England and Wales. J Public Health Med. 2000;22(3):275-9. [pmid: 11077897].
471 Majumdar S R, Gurwitz J H, Soumerai S B. Undertreatment of hyperlipidemia in the secondary prevention of coronary artery disease. J Gen Intern Med. 1999;14(12):711-7. [pmid: 10632815].
472 Makela P, Valkonen T, Poikolainen K. Estimated numbers of deaths from coronary heart disease “caused” and “prevented” by alcohol: an example from Finland. J Stud Alcohol. 1997;58(5):455-63. [pmid: 9273909].
473 Malenka D J, O'Rourke D, Miller M A, et al. Cause of in-hospital death in 12,232 consecutive patients undergoing percutaneous transluminal coronary angioplasty. The Northern New England Cardiovascular Disease Study Group. Am Heart J. 1999;137(4 Pt 1):632-8. [pmid: 10223894].
474 Malhotra S, Karan R S, Bhargava V K, et al. A meta-analysis of controlled clinical trials comparing low-molecular weight heparins with unfractionated heparin in unstable angina. Indian Heart J. 2001;53(2):197-202. [pmid: 11428477].
475 Malmberg K, Yusuf S, Gerstein H C, et al. Impact of diabetes on long-term prognosis in patients with unstable angina and non-Q-wave myocardial infarction: results of the OASIS (Organization to Assess Strategies for Ischemic Syndromes) Registry. Circulation. 2000;102(9):1014-9. [pmid: 10961966].
476 Manolio T A, Pearson T A, Wenger N K, et al. Cholesterol and heart disease in older persons and women. Review of an NHLBI workshop. Ann Epidemiol. 1992;2(12):161-76. [pmid: 1342259].
477 Manson J E, Colditz G A, Stampfer M J, et al. A prospective study of maturity-onset diabetes mellitus and risk of coronary heart disease and stroke in women. Arch Intern Med. 1991;151(6):1141-7. [pmid: 2043016].
478 Manson J E, Colditz G A, Stampfer M J, et al. A prospective study of obesity and risk of coronary heart disease in women. N Engl J Med. 1990;322(13):882-9. [pmid: 2314422].
479 Manson J E, Hu F B, Rich-Edwards J W, et al. A prospective study of walking as compared with vigorous exercise in the prevention of coronary heart disease in women. N Engl J Med. 1999;341(9):650-8. [pmid: 10460816].
480 Manson J E, Stampfer M J, Colditz G A, et al. A prospective study of aspirin use and primary prevention of cardiovascular disease in women. Jama. 1991;266(4):521-7. [pmid: 2061978].
481 Manson J E, Tosteson H, Ridker P M, et al. The primary prevention of myocardial infarction. N Engl J Med. 1992;326(21):1406-16. [pmid: 1533273].
482 Manson J E, Willett W C, Stampfer M J, et al. Body weight and mortality among women. N Engl J Med. 1995;333(11):677-85. [pmid: 7637744].
483 Marber M, MacRae C, Joy M. Delay to invasive investigation and revascularisation for coronary heart disease in south west Thames region: a two tier system?. Bmj. 1991;302(6786):1189-91. [pmid: 2043817].
484 Marchioli R, Marfisi R M, Carinci F, et al. Meta-analysis, clinical trials, and transferability of research results into practice. The case of cholesterol-lowering interventions in the secondary prevention of coronary heart disease. Arch Intern Med. 1996;156(11):1158-72. [pmid: 8639010].
485 Marine JE, Freedberg KA, Davidoff R. Cost-effectiveness of stress-echocardiography. Cardiol Clin 1999;17(3):583–95, x.
486 Mark D B, Hlatky M A, Califf R M, et al. Cost effectiveness of thrombolytic therapy with tissue plasminogen activator as compared with streptokinase for acute myocardial infarction. N Engl J Med. 1995;332(21):1418-24. [pmid: 7723799].
487 Mark D B, Nelson C L, Califf R M, et al. Continuing evolution of therapy for coronary artery disease. Initial results from the era of coronary angioplasty. Circulation. 1994;89(5):2015-25. [pmid: 8181125].
488 Mark D B, Shaw L, Harrell F E Jr, et al. Prognostic value of a treadmill exercise score in outpatients with suspected coronary artery disease. N Engl J Med. 1991;325(12):849-53. [pmid: 1875969].
489 Maron D J. Percutaneous coronary intervention versus medical therapy for coronary heart disease. Curr Atheroscler Rep. 2000;2(4):290-6. [pmid: 11122756].
490 Martikainen J, Klaukka T, Reunanen A, et al. Recent trends in the consumption of lipid-lowering drugs in Finland. J Clin Epidemiol. 1996;49(12):1453-57. [pmid: 8970497].
491 Marwick T H, Shaw L J, Lauer M S, et al. The noninvasive prediction of cardiac mortality in men and women with known or suspected coronary artery disease. Economics of Noninvasive Diagnosis (END) Study Group. Am J Med. 1999;106(2):172-8. [pmid: 10230746].
492 Marz W, Wieland H. HMG-CoA reductase inhibition: anti-inflammatory effects beyond lipid lowering?. Herz. 2000;25(2):117-25. [pmid: 10829251].
493 Mathis A S. Newer antithrombotic strategies in the initial management of non-ST-segment elevation acute coronary syndromes. Ann Pharmacother. 2000;34(2):208-27. [pmid: 10676830].
494 Matsui K, Polanczyk C A, Gaspoz J M, et al. Management of patients with acute myocardial infarction at five academic medical centers: clinical characteristics, resource utilization, and outcome. J Investig Med. 1999;47(3):134-40.
495 Matsuo T, Kobayashi H, Kario K, et al. Fibrin D-dimer in thrombogenic disorders. Semin Thromb Hemost. 2000;26(1):101-7. [pmid: 10805290].
496 Maynard C, Althouse R, Cerqueira M, et al. Underutilization of thrombolytic therapy in eligible women with acute myocardial infarction. Am J Cardiol. 1991;68(5):529-30. [pmid: 1908180].
497 Maynard C, Litwin P E, Martin J S, et al. Gender differences in the treatment and outcome of acute myocardial infarction. Results from the Myocardial Infarction Triage and Intervention Registry. Arch Intern Med. 1992;152(5):972-6. [pmid: 1580724].
498 McGlynn E A, Naylor C D, Anderson G M, et al. Comparison of the appropriateness of coronary angiography and coronary artery bypass graft surgery between Canada and New York State. Jama. 1994;272(12):934-40. [pmid: 8084060].
499 McGregor M, Brophy J M. Use of abciximab (c7E3 Fab, ReoPro) as an adjunct to balloon angioplasty. Can J Cardiol. 1999;15(2):201-7. [pmid: 10079780].
500 McLeod A L, Northridge D B, Uren N G. Ultrasound guided stenting. Heart. 2001;85(6):605-6. [pmid: 11359730].
501 McNamara D J. Dietary cholesterol and atherosclerosis. Biochim Biophys Acta. 2000;1529(13):310-20. [pmid: 11111098].
502 Mehilli J, Kastrati A, Dirschinger J, et al. Differences in prognostic factors and outcomes between women and men undergoing coronary artery stenting. Jama. 2000;284(14):1799-805. [pmid: 11025832].
503 Mehta R H, Bates E R. Coronary stent implantation in acute myocardial infarction. Am Heart J. 1999;137(4 Pt 1):603-11. [pmid: 10097221].
504 Mehta R H, Bossone E, Eagle K A. Current concepts in secondary prevention after acute myocardial infarction. Herz. 2000;25(1):47-60. [pmid: 10713909].
505 Mehta S R, Eikelboom J W, Natarajan M K, et al. Impact of right ventricular involvement on mortality and morbidity in patients with inferior myocardial infarction. J Am Coll Cardiol. 2001;37(1):37-43. [pmid: 11153770].
506 Mehta S R, Yusuf S. The Clopidogrel in Unstable angina to prevent Recurrent Events (CURE) trial programme; rationale, design and baseline characteristics including a meta-analysis of the effects of thienopyridines in vascular disease. Eur Heart J. 2000;21(24):2033-41. [pmid: 11102254].
507 Mehta S R, Yusuf S, Peters R J, et al. Effects of pretreatment with clopidogrel and aspirin followed by long-term therapy in patients undergoing percutaneous coronary intervention: the PCI-CURE study. Lancet. 2001;358(9281):527-33. [pmid: 11520521].
508 Meilahn E N. Hemostatic factors and risk of cardiovascular disease in women. An overview. Arch Pathol Lab Med. 1992;116(12):1313-7. [pmid: 1456877].
509 Meleady R, Graham I. Plasma homocysteine as a cardiovascular risk factor: causal, consequential, or of no consequence?. Nutr Rev. 1999;57(10):299-305. [pmid: 10575905].
510 Mendelson G, Aronow W S. Underutilization of measurement of serum low-density lipoprotein cholesterol levels and of lipid-lowering therapy in older patients with manifest atherosclerotic disease. J Am Geriatr Soc. 1998;46(9):1128-31. [pmid: 9736107].
511 Merlo J, Ranstam J, Rastam L, et al. Age standardisation of drug utilisation: comparisons of different methods using cardiovascular drug data from Sweden and Spain. Eur J Clin Pharmacol. 1994;46(5):393-8. [pmid: 7957531].
512 Messeri P, Workman S, Saunders C, et al. The application of meta-analysis in assessing racial differences in the effects of antihypertensive medication. J Natl Med Assoc. 1997;89(7):477-85. [pmid: 9220697].
513 Messerli F H. Case-control study, meta-analysis, and bouillabaisse: putting the calcium antagonist scare into context. Ann Intern Med. 1995;123(11):888-9. [pmid: 7486476].
514 Michels K B, Rosner B A, Manson J E, et al. Prospective study of calcium channel blocker use, cardiovascular disease, and total mortality among hypertensive women: the Nurses' Health Study. Circulation. 1998;97(16):1540-8. [pmid: 9593558].
515 Michels K B, Yusuf S. Does PTCA in acute myocardial infarction affect mortality and reinfarction rates? A quantitative overview (meta-analysis) of the randomized clinical trials. Circulation. 1995;91(2):476-85. [pmid: 7805253].
516 Midgette A S, O'Connor G T, Baron J A, et al. Effect of intravenous streptokinase on early mortality in patients with suspected acute myocardial infarction. A meta-analysis by anatomic location of infarction. Ann Intern Med. 1990;113(12):961-8. [pmid: 2146913].
517 Midgette A S, Wong J B, Beshansky J R, et al. Cost-effectiveness of streptokinase for acute myocardial infarction: A combined meta-analysis and decision analysis of the effects of infarct location and of likelihood of infarction. Med Decis Making. 1994;14(2):108-17. [pmid: 8028463].
518 Mieres J H, Udelson J E. Meta-analysis of exercise testing to detect coronary artery disease in women. Am J Cardiol. 1999;84(12):1454-6. [pmid: 10606126].
519 Miettinen T A, Pyorala K, Olsson A G, et al. Cholesterol-lowering therapy in women and elderly patients with myocardial infarction or angina pectoris: findings from the Scandinavian Simvastatin Survival Study (4S). Circulation. 1997;96(12):4211-8. [pmid: 9416884].
520 Millard P S, Sturrock W A. Heparin and thrombolysis in acute MI. J Fam Pract. 1996;43(1):20-1. [pmid: 8691171].
521 Miller M, Byington R, Hunninghake D, et al. Sex bias and underutilization of lipid-lowering therapy in patients with coronary artery disease at academic medical centers in the United States and Canada. Prospective Randomized Evaluation of the Vascular Effects of Norvasc Trial (PREVENT) Investigators. Arch Intern Med. 2000;160(3):343-7. [pmid: 10668836].
522 Miller T D, Roger V L, Hodge D O, et al. Gender differences and temporal trends in clinical characteristics, stress test results and use of invasive procedures in patients undergoing evaluation for coronary artery disease. J Am Coll Cardiol. 2001;38(3):690-7. [pmid: 11527619].
523 Miller T D, Roger V L, Milavetz J J, et al. Assessment of the exercise electrocardiogram in women versus men using tomographic myocardial perfusion imaging as the reference standard. Am J Cardiol. 2001;87(7):868-73. [pmid: 11274942].
524 Milne R. HMG CO-A reductase inhibitor treatment in the prevention of coronary heart disease. Southampton: Wessex Institute for Health Research and Development; 1997. Report No.: DEC Report No. 72.
525 Moen E K, Asher C R, Miller D P, et al. Long-term follow-up of gender-specific outcomes after thrombolytic therapy for acute myocardial infarction from the GUSTO-I trial. Global Utilization of Streptokinase and Tissue Plasminogen Activator for Occluded Coronary Arteries. J Womens Health. 1997;6(3):285-93. [pmid: 9201663].
526 Montagne O, Vedel I, Durand-Zaleski I. Assessment of the impact of fibrates and diet on survival and their cost-effectiveness: evidence from randomized, controlled trials in coronary heart disease and health economic evaluations. Clin Ther. 1999;21(11):2027-35. [pmid: 10890271].
527 Montague T, Tsuyuki R, Burton J, et al. Prevention and regression of coronary atherosclerosis. Is it safe and efficacious therapy?. Chest. 1994;105(3):718-26. [pmid: 8131532].
528 Moore R D, Pearson T A. Moderate alcohol consumption and coronary artery disease. A review. Medicine (Baltimore). 1986;65(4):242-67. [pmcid: 126225]. [pmid: 3523113].
529 Morris J L, Cowan J C. Nitrates in myocardial infarction: a current perspective. Can J Cardiol. 1995;11(Suppl B):5B-10B.
530 Morrison C, Woodward M, Leslie W, et al. Effect of socioeconomic group on incidence of, management of, and survival after myocardial infarction and coronary death: analysis of community coronary event register. Bmj. 1997;314(7080):541-6. [pmid: 9055711].
531 Morrison L J, Verbeek P R, McDonald A C, et al. Mortality and prehospital thrombolysis for acute myocardial infarction: A meta-analysis. Jama. 2000;283(20):2686-92. [pmid: 10819952].
532 Moulds R F. Measurement of cost-effectiveness of drug therapy: a review of the treatment of hypertension. Med J Aust. 1990;153(Suppl):S4-6. [pmid: 2116584].
533 Muldoon M F, Manuck S B, Mendelsohn A B, et al. Cholesterol reduction and non-illness mortality: meta-analysis of randomised clinical trials. Bmj. 2001;322(7277):11-5. [pmcid: 26598]. [pmid: 11141142].
534 Nallamothu B K, Saint S, Bielak L F, et al. Electron-beam computed tomography in the diagnosis of coronary artery disease: a meta-analysis. Arch Intern Med. 2001;161(6):833-8. [pmid: 11268225].
535 Naylor C D, Ugnat A M, Weinkauf D, et al. Coronary artery bypass grafting in Canada: What is its rate of use? Which rate is right?. Cmaj. 1992;146(6):851-9. [pmid: 1544075].
536 Neal B, MacMahon S. An overview of 37 randomised trials of blood pressure lowering agents among 270,000 individuals. World Health Organization-International Society of Hypertension Blood Pressure Lowering Treatment Trialists' Collaboration. Clin Exp Hypertens. 1999;21(56):517-29. [pmid: 10423078].
537 Neal B, MacMahon S, Chapman N. Effects of ACE inhibitors, calcium antagonists, and other blood-pressure-lowering drugs: results of prospectively designed overviews of randomised trials. Blood Pressure Lowering Treatment Trialists' Collaboration. Lancet. 2000;356(9246):1955-64. [pmid: 11130523].
538 Nelson K M, Yeager B F. What is the role of angiotensin-converting enzyme inhibitors in congestive heart failure and after myocardial infarction?. Ann Pharmacother. 1996;30(9):986-93. [pmid: 8876861].
539 Nemergut C, Cheng JW. Use of direct thrombin inhibitors in acute coronary syndrome. Clin Ther 2000;22(8):937–48; discussion 898.
540 Newby K. Clinical outcomes according to time to treatment. Clin Cardiol 1997;20(11 Suppl 3):III11–5.
541 Nielsen W B, Vestbo J, Jensen G B. Isolated systolic hypertension as a major risk factor for stroke and myocardial infarction and an unexploited source of cardiovascular prevention: a prospective population-based study. J Hum Hypertens. 1995;9(3):175-80. [pmid: 7783098].
542 Nilsson R. A qualitative and quantitative risk assessment of snuff dipping. Regul Toxicol Pharmacol. 1998;28(1):1-16. [pmid: 9784428].
543 Njolstad I, Arnesen E, Lund-Larsen P G. Smoking, serum lipids, blood pressure, and sex differences in myocardial infarction. A 12-year follow-up of the Finnmark Study. Circulation. 1996;93(3):450-6. [pmid: 8565161].
544 O'Connor G T, Buring J E, Yusuf S, et al. An overview of randomized trials of rehabilitation with exercise after myocardial infarction. Circulation. 1989;80(2):234-44. [pmid: 2665973].
545 O'Connor G T, Morton J R, Diehl M J, et al. Differences between men and women in hospital mortality associated with coronary artery bypass graft surgery. The Northern New England Cardiovascular Disease Study Group. Circulation. 1993;88(5 Pt 1):2104-10. [pmid: 8222104].
546 O'Malley P G, Taylor A J, Jackson J L, et al. Prognostic value of coronary electron-beam computed tomography for coronary heart disease events in asymptomatic populations. Am J Cardiol. 2000;85(8):945-8. [pmid: 10760331].
547 O'Rourke R A, Brundage B H, Froelicher V F, et al. American College of Cardiology/American Heart Association Expert Consensus Document on electron-beam computed tomography for the diagnosis and prognosis of coronary artery disease. J Am Coll Cardiol. 2000;36(1):326-40. [pmid: 10898458].
548 O'Shea EB. A study of the use of aspirin by general practitioners in suspected myocardial infarction. Ir Med J 2001;94(2):48–50, 52.
549 Okin P M, Kligfield P. Gender-specific criteria and performance of the exercise electrocardiogram. Circulation. 1995;92(5):1209-16. [pmid: 7648667].
550 Olatidoye A G, Wu A H, Feng Y J, et al. Prognostic role of troponin T versus troponin I in unstable angina pectoris for cardiac events with meta-analysis comparing published studies. Am J Cardiol. 1998;81(12):1405-10. [pmid: 9645888].
551 Oldridge N B, Guyatt G H, Fischer M E, et al. Cardiac rehabilitation after myocardial infarction. Combined experience of randomized clinical trials. Jama. 1988;260(7):945-50. [pmid: 3398199].
552 Oler A, Whooley M A, Oler J, et al. Adding heparin to aspirin reduces the incidence of myocardial infarction and death in patients with unstable angina. A meta-analysis. Jama. 1996;276(10):811-5. [pmid: 8769591].
553 Oliver M F. Cholesterol and coronary disease--outstanding questions. Cardiovasc Drugs Ther. 1992;6(2):131-6. [pmid: 1390323].
554 Olsson G, Wikstrand J, Warnold I, et al. Metoprolol-induced reduction in postinfarction mortality: pooled results from five double-blind randomized trials. Eur Heart J. 1992;13(1):28-32. [pmid: 1533587].
555 Omenn G S, Anderson K W, Kronmal R A, et al. The temporal pattern of reduction of mortality risk after smoking cessation. Am J Prev Med. 1990;6(5):251-7. [pmid: 2268453].
556 Onder G, Gambassi G, Landi F, et al. Trends in antihypertensive drugs in the elderly: the decline of thiazides. J Hum Hypertens. 2001;15(5):291-7. [pmid: 11378830].
557 Opie L H, Yusuf S, Kubler W. Current status of safety and efficacy of calcium channel blockers in cardiovascular diseases: a critical analysis based on 100 studies. Prog Cardiovasc Dis. 2000;43(2):171-96. [pmid: 11014332].
558 Orchard T J. The impact of gender and general risk factors on the occurrence of atherosclerotic vascular disease in non-insulin-dependent diabetes mellitus. Ann Med. 1996;28(4):323-33. [pmid: 8862687].
559 Orlandini A, Tuero E, Paolasso E, et al. Usefulness of pharmacologic stress echocardiography in a chest pain center. Am J Cardiol 2000;86(11):1247–50, A6.
560 Ottani F, Galvani M, Nicolini F A, et al. Elevated cardiac troponin levels predict the risk of adverse outcome in patients with acute coronary syndromes. Am Heart J. 2000;140(6):917-27. [pmid: 11099996].
561 Packer M, Bristow M R, Cohn J N, et al. The effect of carvedilol on morbidity and mortality in patients with chronic heart failure. U.S. Carvedilol Heart Failure Study Group. N Engl J Med. 1996;334(21):1349-55. [pmid: 8614419].
562 Packer M, Coats A J, Fowler M B, et al. Effect of carvedilol on survival in severe chronic heart failure. N Engl J Med. 2001;344(22):1651-8. [pmid: 11386263].
563 Paganini-Hill A, Hsu G. Smoking and mortality among residents of a California retirement community. Am J Public Health. 1994;84(6):992-5. [pmid: 8203698].
564 Pagley P R, Yarzebski J, Goldberg R, et al. Gender differences in the treatment of patients with acute myocardial infarction. A multihospital, community-based perspective. Arch Intern Med. 1993;153(5):625-9. [pmid: 8439225].
565 Pahor M, Psaty B M, Alderman M H, et al. Health outcomes associated with calcium antagonists compared with other first-line antihypertensive therapies: a meta-analysis of randomised controlled trials. Lancet. 2000;356(9246):1949-54. [pmid: 11130522].
566 Pahor M, Psaty B M, Alderman M H, et al. Therapeutic benefits of ACE inhibitors and other antihypertensive drugs in patients with type 2 diabetes. Diabetes Care. 2000;23(7):888-92. [pmid: 10895836].
567 Pancholy S B, Fattah A A, Kamal A M, et al. Independent and incremental prognostic value of exercise thallium single-photon emission computed tomographic imaging in women. J Nucl Cardiol. 1995;2(2 Pt 1):110-6. [pmid: 9420775].
568 Pearce KA, Furberg CD, Rushing J. Does antihypertensive treatment of the elderly prevent cardiovascular events or prolong life? A meta-analysis of hypertension treatment trials. Arch Fam Med 1995;4(11):943–9; discussion 950.
569 Pearson M L, Kahn K L, Harrison E R, et al. Differences in quality of care for hospitalized elderly men and women. Jama. 1992;268(14):1883-9. [pmid: 1404712].
570 Pepine C J, Faich G, Makuch R. Verapamil use in patients with cardiovascular disease: an overview of randomized trials. Clin Cardiol. 1998;21(9):633-41. [pmid: 9755379].
571 Perlman J A, Wolf P H, Ray R, et al. Cardiovascular risk factors, premature heart disease, and all-cause mortality in a cohort of northern California women. Am J Obstet Gynecol. 1988;158(6 Pt 2):1568-74. [pmid: 3377034].
572 Perreault S, Hamilton V H, Lavoie F, et al. A head-to-head comparison of the cost effectiveness of HMG-CoA reductase inhibitors and fibrates in different types of primary hyperlipidemia. Cardiovasc Drugs Ther. 1997;10(6):787-94. [pmid: 9110123].
573 Peterson E D, Lansky A J, Anstrom K J, et al. Evolving trends in interventional device use and outcomes: results from the National Cardiovascular Network Database. Am Heart J. 2000;139(2 Pt 1):198-207. [pmid: 10650291].
574 Peto R, Collins R, Gray R. Large-scale randomized evidence: large, simple trials and overviews of trials. Ann N Y Acad Sci. 1993;703:314-40. [pmid: 8192313].
575 Petticrew M, McKee M, Jones J. Coronary artery surgery: are women discriminated against?. Bmj. 1993;306(6886):1164-6. [pmid: 8499817].
576 Pfeffer M A, Moye L A, Braunwald E, et al. Selection bias in the use of thrombolytic therapy in acute myocardial infarction. The SAVE Investigators. Jama. 1991;266(4):528-32. [pmid: 2061979].
577 Pfisterer M, Cox J L, Granger C B, et al. Atenolol use and clinical outcomes after thrombolysis for acute myocardial infarction: the GUSTO-I experience. Global Utilization of Streptokinase and TPA (alteplase) for Occluded Coronary Arteries. J Am Coll Cardiol. 1998;32(3):634-40. [pmid: 9741504].
578 Philbin E F, McCullough P A, DiSalvo T G, et al. Underuse of invasive procedures among Medicaid patients with acute myocardial infarction. Am J Public Health. 2001;91(7):1082-8. [pmid: 11441735].
579 Pi-Sunyer F X. Comorbidities of overweight and obesity: current evidence and research issues. Med Sci Sports Exerc. 1999;31(11 Suppl):S602-8. [pmid: 10593535].
580 Picano E, Bedetti G, Varga A, et al. The comparable diagnostic accuracies of dobutamine-stress and dipyridamole-stress echocardiographies: a meta-analysis. Coron Artery Dis. 2000;11(2):151-9. [pmid: 10758817].
581 Pignone M, Phillips C, Mulrow C. Use of lipid lowering drugs for primary prevention of coronary heart disease: meta-analysis of randomised trials. Bmj. 2000;321(7267):983-6. [pmcid: 27504]. [pmid: 11039962].
582 Pilote L, Califf R M, Sapp S, et al. Regional variation across the United States in the management of acute myocardial infarction. GUSTO-1 Investigators. Global Utilization of Streptokinase and Tissue Plasminogen Activator for Occluded Coronary Arteries. N Engl J Med. 1995;333(9):565-72. [pmid: 7623907].
583 Pilote L, Granger C, Armstrong P W, et al. Differences in the treatment of myocardial infarction between the United States and Canada. A survey of physicians in the GUSTO trial. Med Care. 1995;33(6):598-610. [pmid: 7760576].
584 Pocock S J, Henderson R A, Rickards A F, et al. Meta-analysis of randomised trials comparing coronary angioplasty with bypass surgery. Lancet. 1995;346(8984):1184-9. [pmid: 7475657].
585 Pocock S J, McCormack V, Gueyffier F, et al. A score for predicting risk of death from cardiovascular disease in adults with raised blood pressure, based on individual patient data from randomised controlled trials. BMJ. 2001;323(7304):75-81. [pmcid: 34541]. [pmid: 11451781].
586 Podrid P J. Proarrhythmia, a serious complication of antiarrhythmic drugs. Curr Cardiol Rep. 1999;1(4):289-96. [pmid: 10980856].
587 Popma J J, Chuang Y C, Satler L F, et al. Primary coronary angioplasty in patients with acute myocardial infarction. Tex Heart Inst J. 1994;21(2):148-57. [pmcid: 325150]. [pmid: 8061539].
588 Popma J J, Topol E J. Adjuncts to thrombolysis for myocardial reperfusion. Ann Intern Med. 1991;115(1):34-44. [pmid: 1675557].
589 Porsova-Dutoit I, Sulcova J, Starka L. Do DHEA/DHEAS play a protective role in coronary heart disease?. Physiol Res. 2000;49(Suppl 1):S43-56. [pmid: 10984071].
590 Port S, Demer L, Jennrich R, et al. Systolic blood pressure and mortality. Lancet. 2000;355(9199):175-80. [pmid: 10675116].
591 Potts J L, Thomas J. Traditional coronary risk factors in African Americans. Am J Med Sci. 1999;317(3):189-92. [pmid: 10100693].
592 Prescott E, Hippe M, Schnohr P, et al. Smoking and risk of myocardial infarction in women and men: longitudinal population study. BMJ. 1998;316(7137):1043-7. [pmcid: 28505]. [pmid: 9552903].
593 Pretre R, Turina M I. Analysis of trials of surgery vs angioplasty in myocardial revascularization. Semin Interv Cardiol. 1999;4(4):235-43. [pmid: 10738357].
594 Primatesta P, Poulter N R. Lipid concentrations and the use of lipid lowering drugs: evidence from a national cross sectional survey. Bmj. 2000;321(7272):1322-5. [pmcid: 27537]. [pmid: 11090516].
595 Prosser L A, Stinnett A A, Goldman P A, et al. Cost-effectiveness of cholesterol-lowering therapies according to selected patient characteristics. Ann Intern Med. 2000;132(10):769-79. [pmid: 10819699].
596 Psaty B M, Smith N L, Siscovick D S, et al. Health outcomes associated with antihypertensive therapies used as first-line agents. A systematic review and meta-analysis. Jama. 1997;277(9):739-45. [pmid: 9042847].
597 Puletti M, Sunseri L, Curione M, et al. Acute myocardial infarction: sex-related differences in prognosis. Am Heart J. 1984;108(1):63-6. [pmid: 6731284].
598 Quan A, Kerlikowske K, Gueyffier F, et al. Efficacy of treating hypertension in women. J Gen Intern Med. 1999;14(12):718-29. [pmid: 10632816].
599 Quan A, Kerlikowske K, Gueyffier F, et al. Pharmacotherapy for hypertension in women of different races. Cochrane Database Syst Rev 2000(3):CD002146.
600 Quinn M J, Plow E F, Topol E J. Platelet glycoprotein IIb/IIIa inhibitors: recognition of a two-edged sword?. Circulation. 2002;106(3):379-85. [pmid: 12119257].
601 Raggi P. Coronary calcium on electron beam tomography imaging as a surrogate marker of coronary artery disease. Am J Cardiol. 2001;87(4A):27A-34A.
602 Raine R A, Crayford T J, Chan K L, et al. Gender differences in the treatment of patients with acute myocardial ischemia and infarction in England. Int J Technol Assess Health Care. 1999;15(1):136-46. [pmid: 10407601].
603 Ramsey D J, Goff D C, Wear M L, et al. Sex and ethnic differences in use of myocardial revascularization procedures in Mexican Americans and non-Hispanic whites: the Corpus Christi Heart Project. J Clin Epidemiol. 1997;50(5):603-9. [pmid: 9180653].
604 Rao A V. Coronary heart disease risk factors in women: focus on gender differences. J La State Med Soc. 1998;150(2):67-72. [pmid: 9510611].
605 Redberg R F, Rifai N, Gee L, et al. Lack of association of C-reactive protein and coronary calcium by electron beam computed tomography in postmenopausal women: implications for coronary artery disease screening. J Am Coll Cardiol. 2000;36(1):39-43. [pmid: 10898410].
606 Rembold C M. Number-needed-to-treat analysis of the prevention of myocardial infarction and death by antidyslipidemic therapy. J Fam Pract. 1996;42(6):577-86. [pmid: 8656168].
607 Rexrode K M, Carey V J, Hennekens C H, et al. Abdominal adiposity and coronary heart disease in women. Jama. 1998;280(21):1843-8. [pmid: 9846779].
608 Ridker P M. High-sensitivity C-reactive protein: potential adjunct for global risk assessment in the primary prevention of cardiovascular disease. Circulation. 2001;103(13):1813-8. [pmid: 11282915].
609 Ridker P M, Buring J E, Shih J, et al. Prospective study of C-reactive protein and the risk of future cardiovascular events among apparently healthy women. Circulation. 1998;98(8):731-3. [pmid: 9727541].
610 Ridker P M, Glynn R J, Hennekens C H. C-reactive protein adds to the predictive value of total and HDL cholesterol in determining risk of first myocardial infarction. Circulation. 1998;97(20):2007-11. [pmid: 9610529].
611 Ridker P M, Haughie P. Prospective studies of C-reactive protein as a risk factor for cardiovascular disease. J Investig Med. 1998;46(8):391-5.
612 Ridker P M, Hennekens C H, Buring J E, et al. C-reactive protein and other markers of inflammation in the prediction of cardiovascular disease in women. N Engl J Med. 2000;342(12):836-43. [pmid: 10733371].
613 Ridker P M, Manson J E, Gaziano J M, et al. Low-dose aspirin therapy for chronic stable angina. A randomized, placebo-controlled clinical trial. Ann Intern Med. 1991;114(10):835-9. [pmid: 2014943].
614 Ridker P M, O'Donnell C, Marder V J, et al. Large-scale trials of thrombolytic therapy for acute myocardial infarction: GISSI-2, ISIS-3, and GUSTO-1. Ann Intern Med. 1993;119(6):530-2. [pmid: 8357123].
615 Ridker P M, Rifai N, Pfeffer M A, et al. Long-term effects of pravastatin on plasma concentration of C-reactive protein. The Cholesterol and Recurrent Events (CARE) Investigators. Circulation. 1999;100(3):230-5. [pmid: 10411845].
616 Rifai N, Ridker P M. High-sensitivity C-reactive protein: a novel and promising marker of coronary heart disease. Clin Chem. 2001;47(3):403-11. [pmid: 11238289].
617 Rifkind B M. High-density lipoprotein cholesterol and coronary artery disease: survey of the evidence. Am J Cardiol. 1990;66(6):3A-6A.
618 Rihal C S, Yusuf S. Chronic coronary artery disease: drugs, angioplasty, or surgery?. Bmj. 1996;312(7026):265-6. [pmid: 8611770].
619 Rill V, Brown D L. Practice of coronary angioplasty in California in 1995 : comparison to 1989 and impact of coronary stenting. Circulation. 1999;99(21):e12. [pmid: 10352008].
620 Rivetti L A, Gandra S M. An intraluminal shunt for off-pump coronary artery bypass grafting. Report of 501 consecutive cases and review of the technique. Heart Surg Forum. 1998;1(1):30-6. [pmid: 11276437].
621 Rochon P A, Clark J P, Binns M A, et al. Reporting of gender-related information in clinical trials of drug therapy for myocardial infarction. Cmaj. 1998;159(4):321-7. [pmid: 9732709].
622 Rockhill B, Willett W C, Manson J E, et al. Physical activity and mortality: a prospective study among women. Am J Public Health. 2001;91(4):578-83. [pmid: 11291369].
623 Roger V L, Farkouh M E, Weston S A, et al. Sex differences in evaluation and outcome of unstable angina. Jama. 2000;283(5):646-52. [pmid: 10665705].
624 Roger V L, Pellikka P A, Bell M R, et al. Sex and test verification bias. Impact on the diagnostic value of exercise echocardiography. Circulation. 1997;95(2):405-10. [pmid: 9008457].
625 Roig E, Castaner A, Simmons B, et al. In-hospital mortality rates from acute myocardial infarction by race in U.S. hospitals: findings from the National Hospital Discharge Survey. Circulation. 1987;76(2):280-8. [pmid: 3608117].
626 Rojas-Fernandez C H, Kephart G C, Sketris I S, et al. Underuse of acetylsalicylic acid in individuals with myocardial infarction, ischemic heart disease or stroke: data from the 1995 population-based Nova Scotia Health Survey. Can J Cardiol. 1999;15(3):291-6. [pmid: 10202192].
627 Rosamond W D, Shahar E, McGovern P G, et al. Trends in coronary thrombolytic therapy for acute myocardial infarction (the Minnesota Heart Survey Registry, 1990 to 1993). Am J Cardiol. 1996;78(3):271-7. [pmid: 8759803].
628 Rosano G M, Panina G. Oestrogens and the heart. Therapie. 1999;54(3):381-5. [pmid: 10500455].
629 Rosenberg L, Hennekens C H, Rosner B, et al. Early menopause and the risk of myocardial infarction. Am J Obstet Gynecol. 1981;139(1):47-51. [pmid: 7457520].
630 Roux S, Christeller S, Ludin E. Effects of aspirin on coronary reocclusion and recurrent ischemia after thrombolysis: a meta-analysis. J Am Coll Cardiol. 1992;19(3):671-7. [pmid: 1531663].
631 Rubins H B. Cholesterol in patients with coronary heart disease: how low should we go?. J Gen Intern Med. 1995;10(8):464-71. [pmid: 7472706].
632 Ruilope L M, Suarez C. How should we treat hypertensive women with cardiac and renal impairment?. Am J Hypertens. 1997;10(10 Pt 2):242S-246S. [pmid: 9366280].
633 Rumberger J A, Brundage B H, Rader D J, et al. Electron beam computed tomographic coronary calcium scanning: a review and guidelines for use in asymptomatic persons. Mayo Clin Proc. 1999;74(3):243-52. [pmid: 10089993].
634 Ryan T J, Ryan T J Jr, Jacobs A K. Primary PTCA versus thrombolytic therapy: an evidence-based summary. Am Heart J. 1999;138(2 Pt 2):S96-104. [pmid: 10426867].
635 Sacks F M. Lipid-lowering therapy in acute coronary syndromes. Jama. 2001;285(13):1758-60. [pmid: 11277832].
636 Sacks F M, Pfeffer M A, Moye L A, et al. The effect of pravastatin on coronary events after myocardial infarction in patients with average cholesterol levels. Cholesterol and Recurrent Events Trial investigators. N Engl J Med. 1996;335(14):1001-9. [pmid: 8801446].
637 Sacks H S, Chalmers T C, Berk A A, et al. Should mild hypertension be treated? An attempted meta-analysis of the clinical trials. Mt Sinai J Med. 1985;52(4):265-70. [pmid: 3873604].
638 Sadowski Z P, Alexander J H, Skrabucha B, et al. Multicenter randomized trial and a systematic overview of lidocaine in acute myocardial infarction. Am Heart J. 1999;137(5):792-8. [pmid: 10220626].
639 Safstrom K, Lindahl B, Swahn E. Risk stratification in unstable coronary artery disease--exercise test and troponin T from a gender perspective. FRISC-Study Group. Fragmin during InStability in Coronary artery disease. J Am Coll Cardiol. 2000;35(7):1791-800. [pmid: 10841226].
640 Saha S, Stettin G D, Redberg R F. Gender and willingness to undergo invasive cardiac procedures. J Gen Intern Med. 1999;14(2):122-5. [pmid: 10051783].
641 Salomaa V, Miettinen H, Niemela M, et al. Relation of socioeconomic position to the case fatality, prognosis and treatment of myocardial infarction events; the FINMONICA MI Register Study. J Epidemiol Community Health. 2001;55(7):475-82. [pmid: 11413176].
642 Sane D C, Stump D C, Topol E J, et al. Racial differences in responses to thrombolytic therapy with recombinant tissue-type plasminogen activator. Increased fibrin(ogen)olysis in blacks. The Thrombolysis and Angioplasty in Myocardial Infarction Study Group. Circulation. 1991;83(1):170-5. [pmid: 1898641].
643 Sanmuganathan P S, Ghahramani P, Jackson P R, et al. Aspirin for primary prevention of coronary heart disease: safety and absolute benefit related to coronary risk derived from meta-analysis of randomised trials. Heart. 2001;85(3):265-71. [pmid: 11179262].
644 Santana-Boado C, Candell-Riera J, Castell-Conesa J, et al. Diagnostic accuracy of technetium-99m-MIBI myocardial SPECT in women and men. J Nucl Med. 1998;39(5):751-5. [pmid: 9591568].
645 Santiago P, Vacek J L, Rosamond T L. Dobutamine stress echocardiography: clinical utility and predictive value at various infusion rates. Am Heart J. 1994;128(4):804-8. [pmid: 7942451].
646 Savoie I, Wright J, Bassett K. Lipid lowering therapy. Vancouver: BC Office of Health Technology Assessment, Centre for Health Services and Policy Research, University of British Columbia, Finnish Office for Health Care Technolog Assessment (FinOHTA); 1998. Report No.: 1896256112.
647 Schildkraut J M, Myers R H, Cupples L A, et al. Coronary risk associated with age and sex of parental heart disease in the Framingham Study. Am J Cardiol. 1989;64(10):555-9. [pmid: 2782245].
648 Schneider E C, Leape L L, Weissman J S, et al. Racial differences in cardiac revascularization rates: does “overuse” explain higher rates among white patients?. Ann Intern Med. 2001;135(5):328-37. [pmid: 11529696].
649 Scott I A, Harden H, Coory M. What are appropriate rates of invasive procedures following acute myocardial infarction? A systematic review. Med J Aust. 2001;174(3):130-6. [pmid: 11247616].
650 Selker H P, Zalenski R J, Antman E M, et al. An evaluation of technologies for identifying acute cardiac ischemia in the emergency department: a report from a National Heart Attack Alert Program Working Group. Ann Emerg Med. 1997;29(1):13-87. [pmid: 8998086].
651 Senior R, Soman P, Khattar R S, et al. Prognostic value of dobutamine stress echocardiography in patients undergoing diagnostic coronary arteriography. Am J Cardiol. 1997;79(12):1610-4. [pmid: 9202350].
652 Serruys P W, Unger F, Sousa J E, et al. Comparison of coronary-artery bypass surgery and stenting for the treatment of multivessel disease. N Engl J Med. 2001;344(15):1117-24. [pmid: 11297702].
653 Seymour R A, Steele J G. Is there a link between periodontal disease and coronary heart disease?. Br Dent J. 1998;184(1):33-8. [pmid: 9479812].
654 Shahar E, Folsom A R, Romm F J, et al. Patterns of aspirin use in middle-aged adults: the Atherosclerosis Risk in Communities (ARIC) Study. Am Heart J. 1996;131(5):915-22. [pmid: 8615310].
655 Shapira I, Fisman E Z, Drory Y, et al. Acute myocardial infarction in patients who have had coronary artery bypass surgery. South Med J. 1997;90(11):1129-32. [pmid: 9386056].
656 Sharrett A R, Patsch W, Sorlie P D, et al. Associations of lipoprotein cholesterols, apolipoproteins A-I and B, and triglycerides with carotid atherosclerosis and coronary heart disease. The Atherosclerosis Risk in Communities (ARIC) Study. Arterioscler Thromb. 1994;14(7):1098-104. [pmid: 8018665].
657 Shavelle D M, Budoff M J, LaMont D H, et al. Exercise testing and electron beam computed tomography in the evaluation of coronary artery disease. J Am Coll Cardiol. 2000;36(1):32-8. [pmid: 10898409].
658 Shaw L J, Eagle K A, Gersh B J, et al. Meta-analysis of intravenous dipyridamole-thallium-201 imaging (1985 to 1994) and dobutamine echocardiography (1991 to 1994) for risk stratification before vascular surgery. J Am Coll Cardiol. 1996;27(4):787-98. [pmid: 8613604].
659 Shaw L J, Hachamovitch R, Redberg R F. Current evidence on diagnostic testing in women with suspected coronary artery disease: choosing the appropriate test. Cardiol Rev. 2000;8(1):65-74. [pmid: 11174875].
660 Shaw L J, Miller D D, Romeis J C, et al. Gender differences in the noninvasive evaluation and management of patients with suspected coronary artery disease. Ann Intern Med. 1994;120(7):559-66. [pmid: 8116993].
661 Shea S, Cook E F, Kannel W B, et al. Treatment of hypertension and its effect on cardiovascular risk factors: data from the Framingham Heart Study. Circulation. 1985;71(1):22-30. [pmid: 3964720].
662 Shepherd J. New evidence, new guidelines. Atherosclerosis. 1998;140(2):197-8. [pmid: 9862268].
663 Sherman S E, D'Agostino R B, Cobb J L, et al. Physical activity and mortality in women in the Framingham Heart Study. Am Heart J. 1994;128(5):879-84. [pmid: 7942478].
664 Shibata M C, Flather M D, Wang D. Systematic review of the impact of beta blockers on mortality and hospital admissions in heart failure. Eur J Heart Fail. 2001;3(3):351-7. [pmid: 11378007].
665 Shinton R A, Beevers D G. A meta-analysis of mortality and coronary prevention in hypertensive patients treated with beta-receptor blockers. J Hum Hypertens. 1990;4(Suppl 2):31-4. [pmid: 1973461].
666 Silberberg J S, Henry D A. The benefits of reducing cholesterol levels: the need to distinguish primary from secondary prevention. 2. Implications for heart disease prevention in Australia. Med J Aust. 1991;155(10):670-4. [pmid: 1943895].
667 Silberberg JS, Henry DA. The benefits of reducing cholesterol levels: the need to distinguish primary from secondary prevention. 1. A meta-analysis of cholesterol-lowering trials. Med J Aust 1991;155(10):665–6, 669–70.
668 Sim I, Gupta M, McDonald K, et al. A meta-analysis of randomized trials comparing coronary artery bypass grafting with percutaneous transluminal coronary angioplasty in multivessel coronary artery disease. Am J Cardiol. 1995;76(14):1025-9. [pmid: 7484855].
669 Simes R J. Low cholesterol and risk of non-coronary mortality. Aust N Z J Med. 1994;24(1):113-9. [pmid: 8002849].
670 Simons-Morton D G, Calfas K J, Oldenburg B, et al. Effects of interventions in health care settings on physical activity or cardiorespiratory fitness. Am J Prev Med. 1998;15(4):413-30. [pmid: 9838981].
671 Sketris I S, Kephart G C, Hicks V A, et al. Prescribing patterns of antilipemic drugs and prevalence of hypercholesterolemia in the Nova Scotia population more than 65 years old. Ann Pharmacother. 1995;29(6):576-81. [pmid: 7663028].
672 Smith B J. Thrombolysis in acute myocardial infarction: analysis of studies comparing accelerated t-PA and streptokinase. J Accid Emerg Med. 1999;16(6):407-11. [pmid: 10572811].
673 Smith G D, Song F, Sheldon T A. Cholesterol lowering and mortality: the importance of considering initial level of risk. Bmj. 1993;306(6889):1367-73. [pmid: 8518602].
674 Solomon A J, Gersh B J. Management of chronic stable angina: medical therapy, percutaneous transluminal coronary angioplasty, and coronary artery bypass graft surgery. Lessons from the randomized trials. Ann Intern Med. 1998;128(3):216-23. [pmid: 9454530].
675 Soma M R, Baetta R, Crosignani P. The menopause and lipid metabolism: strategies for cardiovascular disease prevention. Curr Opin Lipidol. 1997;8(4):229-35. [pmid: 9253540].
676 Soriano J B, Hoes A W, Meems L, et al. Increased survival with beta-blockers: importance of ancillary properties. Prog Cardiovasc Dis. 1997;39(5):445-56. [pmid: 9122425].
677 Sorlie P D, Sharrett A R, Patsch W, et al. The relationship between lipids/lipoproteins and atherosclerosis in African Americans and whites: the Atherosclerosis Risk in Communities Study. Ann Epidemiol. 1999;9(3):149-58. [pmid: 10192646].
678 Sowers K M, Sowers J R. Obesity, hypertension, and vascular disease. Curr Hypertens Rep. 1999;1(2):140-4. [pmid: 10981056].
679 Spinler S A, Cziraky M J. Lipoprotein(A): physiologic function, association with atherosclerosis, and effects of lipid-lowering drug therapy. Ann Pharmacother. 1994;28(3):343-51. [pmid: 8193425].
680 Spinler S A, Nawarskas J J. Low-molecular-weight heparins for acute coronary syndromes. Ann Pharmacother. 1998;32(1):103-10. [pmid: 9475828].
681 Spurgeon A, Harrington J M, Cooper C L. Health and safety problems associated with long working hours: a review of the current position. Occup Environ Med. 1997;54(6):367-75. [pmid: 9245942].
682 Staessen J A, Fagard R, Thijs L, et al. Randomised double-blind comparison of placebo and active treatment for older patients with isolated systolic hypertension. The Systolic Hypertension in Europe (Syst-Eur) Trial Investigators. Lancet. 1997;350(9080):757-64. [pmid: 9297994].
683 Staessen J A, Gasowski J, Wang J G, et al. Risks of untreated and treated isolated systolic hypertension in the elderly: meta-analysis of outcome trials. Lancet. 2000;355(9207):865-72. [pmid: 10752701].
684 Staessen J A, Ginocchio G, Wang J G, et al. Genetic variability in the renin-angiotensin system: prevalence of alleles and genotypes. J Cardiovasc Risk. 1997;4(56):401-22. [pmid: 9865673].
685 Staessen J A, Kuznetsova T, Wang J G, et al. M235T angiotensinogen gene polymorphism and cardiovascular renal risk. J Hypertens. 1999;17(1):9-17. [pmid: 10100088].
686 Staessen J A, Wang J G, Ginocchio G, et al. The deletion/insertion polymorphism of the angiotensin converting enzyme gene and cardiovascular-renal risk. J Hypertens. 1997;15(12 Pt 2):1579-92. [pmid: 9488209].
687 Stampfer M J, Colditz G A. Estrogen replacement therapy and coronary heart disease: a quantitative assessment of the epidemiologic evidence. Prev Med. 1991;20(1):47-63. [pmid: 1826173].
688 Stampfer MJ, Colditz GA, Willett WC. Menopause and heart disease. A review. Ann N Y Acad Sci 1990;592:193–203; discussion 257–62.
689 Stason W, Schmid C H, Caubet J F, et al. Searching for signals: mortality and cardiovascular events in published randomized control trials of nifedipine in ischemic heart disease and hypertension. J Hypertens Suppl. 1996;14(2):S5-7. [pmid: 8934371].
690 Stason W B, Schmid C H, Niedzwiecki D, et al. Safety of nifedipine in angina pectoris: a meta-analysis. Hypertension. 1999;33(1):24-31. [pmid: 9931077].
691 Stason W B, Schmid C H, Niedzwiecki D, et al. Safety of nifedipine in patients with hypertension: a meta-analysis. Hypertension. 1997;30(1 Pt 1):7-14. [pmid: 9231814].
692 Stefanick M L, Mackey S, Sheehan M, et al. Effects of diet and exercise in men and postmenopausal women with low levels of HDL cholesterol and high levels of LDL cholesterol. N Engl J Med. 1998;339(1):12-20. [pmid: 9647874].
693 Steingart R M, Packer M, Hamm P, et al. Sex differences in the management of coronary artery disease. Survival and Ventricular Enlargement Investigators. N Engl J Med. 1991;325(4):226-30. [pmid: 2057023].
694 Stephens M B. Is electron-beam computed tomography (EBCT) a reliable tool for predicting coronary outcomes in an asymptomatic population?. J Fam Pract. 2000;49(8):688. [pmid: 10947131].
695 Sterling T D, Rosenbaum W L, Weinkam J J. Risk attribution and tobacco-related deaths. Am J Epidemiol. 1993;138(2):128-39. [pmid: 8342531].
696 Stern M P, Haffner S M. Body fat distribution and hyperinsulinemia as risk factors for diabetes and cardiovascular disease. Arteriosclerosis. 1986;6(2):123-30. [pmid: 3513749].
697 Stokes J 3rd, Kannel W B, Wolf P A, et al. Blood pressure as a risk factor for cardiovascular disease. The Framingham Study--30 years of follow-up. Hypertension. 1989;13(5 Suppl):I13-8. [pmid: 2535213].
698 Stone G W, Grines C L, Browne K F, et al. Comparison of in-hospital outcome in men versus women treated by either thrombolytic therapy or primary coronary angioplasty for acute myocardial infarction. Am J Cardiol. 1995;75(15):987-92. [pmid: 7747700].
699 Stone P H, Thompson B, Anderson H V, et al. Influence of race, sex, and age on management of unstable angina and non-Q-wave myocardial infarction: The TIMI III registry. Jama. 1996;275(14):1104-12. [pmid: 8601930].
700 Strandberg T E, Pitkanen A, Larjo P, et al. Attitude changes of general practitioners towards lowering LDL cholesterol. J Cardiovasc Risk. 1998;5(1):43-6. [pmid: 9816555].
701 Strauss R, Pfeifer C, Muhlberger V, et al. Effects of morbidity, age, gender and region on percutaneous transluminal coronary angioplasty (PTCA) utilisation. Public Health. 1999;113(2):79-87. [pmid: 10355307].
702 Stringer K A. The evolving role of platelet glycoprotein IIb/IIIa inhibitors in the management of acute coronary syndromes. Ann Pharmacother. 1999;33(6):712-22. [pmid: 10410186].
703 Sudano J J Jr, Baker D W. Antihypertensive medication use in Hispanic adults: a comparison with black adults and white adults. Med Care. 2001;39(6):575-87. [pmid: 11414262].
704 Sullivan A K, Holdright D R, Wright C A, et al. Chest pain in women: clinical, investigative, and prognostic features. Bmj. 1994;308(6933):883-6. [pmid: 8173366].
705 Superko H R, Krauss R M. Coronary artery disease regression. Convincing evidence for the benefit of aggressive lipoprotein management. Circulation. 1994;90(2):1056-69. [pmid: 8044919].
706 Swahn E. The care of patients with ischaemic heart disease from a gender perspective. Eur Heart J. 1998;19(12):1758-65. [pmid: 9886717].
707 Sytkowski P A, Kannel W B, D'Agostino R B. Changes in risk factors and the decline in mortality from cardiovascular disease. The Framingham Heart Study. N Engl J Med. 1990;322(23):1635-41. [pmid: 2288563].
708 Taggart DP. Angioplasty versus bypass surgery. Lancet 1996;347(8996):271–2; discussion 272–3.
709 Taillefer R, DePuey E G, Udelson J E, et al. Comparative diagnostic accuracy of Tl-201 and Tc-99m sestamibi SPECT imaging (perfusion and ECG-gated SPECT) in detecting coronary artery disease in women. J Am Coll Cardiol. 1997;29(1):69-77. [pmid: 8996297].
710 Tavel M E. Specificity of electrocardiographic stress test in women versus men. Am J Cardiol. 1992;70(4):545-7. [pmid: 1642198].
711 Tchernof A, Despres J P. Sex steroid hormones, sex hormone-binding globulin, and obesity in men and women. Horm Metab Res. 2000;32(1112):526-36. [pmid: 11246820].
712 Thadani U. Oral nitrates: more than symptomatic therapy in coronary artery disease?. Cardiovasc Drugs Ther. 1999;11(Suppl 1):213-8. [pmid: 9211013].
713 Thijs L, Fagard R, Lijnen P, et al. A meta-analysis of outcome trials in elderly hypertensives. J Hypertens. 1992;10(10):1103-9. [pmid: 1334990].
714 Thompson D, Edelsberg J, Colditz G A, et al. Lifetime health and economic consequences of obesity. Arch Intern Med. 1999;159(18):2177-83. [pmid: 10527295].
715 Tice J A, Ross E, Coxson P G, et al. Cost-effectiveness of vitamin therapy to lower plasma homocysteine levels for the prevention of coronary heart disease: effect of grain fortification and beyond. Jama. 2001;286(8):936-43. [pmid: 11509058].
716 Tijssen J G. Low-dose and high-dose acetylsalicylic acid, with and without dipyridamole: a review of clinical trial results. Neurology. 1998;51(3 Suppl 3):S15-6. [pmid: 9744825].
717 Tisdale J E. Antiplatelet therapy in coronary artery disease: review and update of efficacy studies. Am J Health Syst Pharm. 1998;55(19 Suppl 1):S8-16. [pmid: 9784797].
718 Tobin J N, Wassertheil-Smoller S, Wexler J P, et al. Sex bias in considering coronary bypass surgery. Ann Intern Med. 1987;107(1):19-25. [pmid: 3496029].
719 Tofler G H, Stone P H, Muller J E, et al. Effects of gender and race on prognosis after myocardial infarction: adverse prognosis for women, particularly black women. J Am Coll Cardiol. 1987;9(3):473-82. [pmid: 3819194].
720 Toiber F, Murthy VS. Prescribing and usage patterns of two antihypertensive agents: a comparison of terazosin and enalapril. Hosp Formul 1991;26(10):811–3, 817–8.
721 Topol E J. Coronary angioplasty for acute myocardial infarction. Ann Intern Med. 1988;109(12):970-80. [pmid: 2973762].
722 Topol EJ. How should intravenous thrombolytic agents for acute myocardial infarction be selected? Cardiovasc Clin 1990;21(1):57–75; discussion 76–8.
723 Topol E J. Treatment of acute myocardial infarction: in which patients should primary percutaneous transluminal coronary angioplasty be preferred to thrombolysis?. Cardiologia. 1996;41(9):843-7. [pmid: 8940780].
724 Topol E J, Holmes D R, Rogers W J. Coronary angiography after thrombolytic therapy for acute myocardial infarction. Ann Intern Med. 1991;114(10):877-85. [pmid: 2014950].
725 Tsang T S, Barnes M E, Gersh B J, et al. Risks of coronary heart disease in women: current understanding and evolving concepts. Mayo Clin Proc. 2000;75(12):1289-303. [pmid: 11126839].
726 Tsuyuki R T, Teo K K, Ikuta R M, et al. Mortality risk and patterns of practice in 2,070 patients with acute myocardial infarction, 1987-92. Relative importance of age, sex, and medical therapy. Chest. 1994;105(6):1687-92. [pmid: 7911417].
727 Tyroler H A. Serum lipoproteins as risk factors: recent epidemiologic studies in individuals with and without prevalent cardiovascular disease. Eur Heart J. 1990;11(Suppl H):21-5. [pmid: 2073910].
728 Vaccarino V, Horwitz R I, Meehan T P, et al. Sex differences in mortality after myocardial infarction: evidence for a sex-age interaction. Arch Intern Med. 1998;158(18):2054-62. [pmid: 9778206].
729 Vaccarino V, Krumholz H M, Berkman L F, et al. Sex differences in mortality after myocardial infarction. Is there evidence for an increased risk for women?. Circulation. 1995;91(6):1861-71. [pmid: 7882498].
730 Vaccarino V, Krumholz H M, Yarzebski J, et al. Sex differences in 2-year mortality after hospital discharge for myocardial infarction. Ann Intern Med. 2001;134(3):173-81. [pmid: 11177329].
731 Vaccarino V, Parsons L, Every NR, et al. Impact of history of diabetes mellitus on hospital mortality in men and women with first acute myocardial infarction. The National Registry of Myocardial Infarction 2 Participants. Am J Cardiol 2000;85(12):1486–9; A7.
732 Vaitkus P T. Percutaneous transluminal coronary angioplasty versus thrombolysis in acute myocardial infarction: a meta-analysis. Clin Cardiol. 1995;18(1):35-8. [pmid: 7704983].
733 van Campen L C, Visser F C, Visser C A. Ejection fraction improvement by beta-blocker treatment in patients with heart failure: an analysis of studies published in the literature. J Cardiovasc Pharmacol. 1998;32(Suppl 1):S31-5. [pmid: 9731693].
734 Van de Werf F. Implications of the GUSTO trial for thrombolytic therapy. Drugs. 1996;52(3):307-12. [pmid: 8875125].
735 Van de Werf F, Topol E J, Lee K L, et al. Variations in patient management and outcomes for acute myocardial infarction in the United States and other countries. Results from the GUSTO trial. Global Utilization of Streptokinase and Tissue Plasminogen Activator for Occluded Coronary Arteries. Jama. 1995;273(20):1586-91. [pmid: 7745771].
736 van der Schouw Y T, van der Graaf Y, Steyerberg E W, et al. Age at menopause as a risk factor for cardiovascular mortality. Lancet. 1996;347(9003):714-8. [pmid: 8602000].
737 van der Weijden T, Knottnerus J A, Ament A J, et al. Economic evaluation of cholesterol-related interventions in general practice. An appraisal of the evidence. J Epidemiol Community Health. 1998;52(9):586-94. [pmid: 10320860].
738 Van Train K F, Maddahi J, Berman D S, et al. Quantitative analysis of tomographic stress thallium-201 myocardial scintigrams: a multicenter trial. J Nucl Med. 1990;31(7):1168-79. [pmid: 2194003].
739 Vidt D G, Pohl M A. Aggressive blood pressure lowering is safe, but benefit is still hard to prove. Cleve Clin J Med. 1999;66(2):105-11. [pmid: 9988956].
740 Vorchheimer D A, Badimon J J, Fuster V. Platelet glycoprotein IIb/IIIa receptor antagonists in cardiovascular disease. Jama. 1999;281(15):1407-14. [pmid: 10217057].
741 Wallenius S, Peura S, Klaukka T, et al. Who is using antihypertensive drugs? A prescription analysis from Finland. Scand J Prim Health Care. 1996;14(1):54-61. [pmid: 8725095].
742 Walsh C R, Lloyd-Jones D M, Camargo C A Jr, et al. Clinical trials of unfractionated heparin and low-molecular-weight heparin in addition to aspirin for the treatment of unstable angina pectoris: do the results apply to all patients?. Am J Cardiol. 2000;86(9):908-12. [pmid: 11053697].
743 Walsh J M, Grady D. Treatment of hyperlipidemia in women. Jama. 1995;274(14):1152-8. [pmid: 7563487].
744 Wang J G, Staessen J A, Gong L, et al. Chinese trial on isolated systolic hypertension in the elderly. Systolic Hypertension in China (Syst-China) Collaborative Group. Arch Intern Med. 2000;160(2):211-20. [pmid: 10647760].
745 Waters D. Calcium channel blockers: an evidence-based review. Can J Cardiol. 1997;13(8):757-66. [pmid: 9284842].
746 Weaver W D, Simes R J, Betriu A, et al. Comparison of primary coronary angioplasty and intravenous thrombolytic therapy for acute myocardial infarction: a quantitative review. Jama. 1997;278(23):2093-8. [pmid: 9403425].
747 Weaver W D, White H D, Wilcox R G, et al. Comparisons of characteristics and outcomes among women and men with acute myocardial infarction treated with thrombolytic therapy. GUSTO-I investigators. Jama. 1996;275(10):777-82. [pmid: 8598594].
748 Weber M M. Surgical management of unstable angina and symptomatic coronary artery disease. J Cardiovasc Nurs. 2000;15(1):27-42. [pmid: 11061219].
749 Weintraub W S, Wenger N K, Jones E L, et al. Changing clinical characteristics of coronary surgery patients. Differences between men and women. Circulation. 1993;88(5 Pt 2):II79-86. [pmid: 8222200].
750 Weintraub W S, Wenger N K, Kosinski A S, et al. Percutaneous transluminal coronary angioplasty in women compared with men. J Am Coll Cardiol. 1994;24(1):81-90. [pmid: 8006286].
751 Welty F K, Mittleman M A, Healy R W, et al. Similar results of percutaneous transluminal coronary angioplasty for women and men with postmyocardial infarction ischemia. J Am Coll Cardiol. 1994;23(1):35-9. [pmid: 8277093].
752 Wenger N K, Speroff L, Packard B. Cardiovascular health and disease in women. N Engl J Med. 1993;329(4):247-56. [pmid: 8316269].
753 Wexler L, Brundage B, Crouse J, et al. Coronary artery calcification: pathophysiology, epidemiology, imaging methods, and clinical implications. A statement for health professionals from the American Heart Association. Writing Group. Circulation. 1996;94(5):1175-92. [pmid: 8790070].
754 White A D, Rosamond W D, Chambless L E, et al. Sex and race differences in short-term prognosis after acute coronary heart disease events: the Atherosclerosis Risk In Communities (ARIC) study. Am Heart J. 1999;138(3 Pt 1):540-8. [pmid: 10467206].
755 White C W. Benefit of aggressive lipid-lowering therapy: insights from the post coronary artery bypass graft study and other trials. Am J Med. 1998;105(1A):63S-68S. [pmid: 9707270].
756 White H D, Barbash G I, Califf R M, et al. Age and outcome with contemporary thrombolytic therapy. Results from the GUSTO-I trial. Global Utilization of Streptokinase and TPA for Occluded coronary arteries trial. Circulation. 1996;94(8):1826-33. [pmid: 8873656].
757 Wikstrand J, Berglund G, Tuomilehto J. Beta-blockade in the primary prevention of coronary heart disease in hypertensive patients. Review of present evidence. Circulation. 1991;84(6 Suppl):VI93-100. [pmid: 1683615].
758 Wilkinson P, Laji K, Ranjadayalan K, et al. Acute myocardial infarction in women: survival analysis in first six months. Bmj. 1994;309(6954):566-9. [pmid: 7916229].
759 Willett W C, Green A, Stampfer M J, et al. Relative and absolute excess risks of coronary heart disease among women who smoke cigarettes. N Engl J Med. 1987;317(21):1303-9. [pmid: 3683458].
760 Willett W C, Manson J E, Stampfer M J, et al. Weight, weight change, and coronary heart disease in women. Risk within the ‘normal’ weight range. Jama. 1995;273(6):461-5. [pmid: 7654270].
761 Williams J E, Massing M, Rosamond W D, et al. Racial disparities in CHD mortality from 1968-1992 in the state economic areas surrounding the ARIC study communities. Atherosclerosis Risk in Communities. Ann Epidemiol. 1999;9(8):472-80. [pmid: 10549880].
762 Williams P T. Physical fitness and activity as separate heart disease risk factors: a meta-analysis. Med Sci Sports Exerc. 2001;33(5):754-61. [pmid: 11323544].
763 Williams S V, Fihn S D, Gibbons R J. Guidelines for the management of patients with chronic stable angina: diagnosis and risk stratification. Ann Intern Med. 2001;135(7):530-47. [pmid: 11578158].
764 Wilson K, Gibson N, Willan A, et al. Effect of smoking cessation on mortality after myocardial infarction: meta-analysis of cohort studies. Arch Intern Med. 2000;160(7):939-44. [pmid: 10761958].
765 Wilson P W, Abbott R D, Castelli W P. High density lipoprotein cholesterol and mortality. The Framingham Heart Study. Arteriosclerosis. 1988;8(6):737-41. [pmid: 3196218].
766 Wong J B, Sonnenberg F A, Salem D N, et al. Myocardial revascularization for chronic stable angina. Analysis of the role of percutaneous transluminal coronary angioplasty based on data available in 1989. Ann Intern Med. 1990;113(11):852-71. [pmid: 2146912].
767 Wong N D, Wilson P W, Kannel W B. Serum cholesterol as a prognostic factor after myocardial infarction: the Framingham Study. Ann Intern Med. 1991;115(9):687-93. [pmid: 1929036].
768 Woodfield S L, Lundergan C F, Reiner J S, et al. Gender and acute myocardial infarction: is there a different response to thrombolysis?. J Am Coll Cardiol. 1997;29(1):35-42. [pmid: 8996292].
769 Wooster M B, Luzier A B. Reteplase: a new thrombolytic for the treatment of acute myocardial infarction. Ann Pharmacother. 1999;33(3):318-24. [pmid: 10200858].
770 Writing Group for the Women's Health Initiative Investigators. Risks and benefits of estrogen plus progestin in healthy postmenopausal women. Principal results from the Women's Health Initiative randomized controlled trial. JAMA. 2002;288:321-33. [pmid: 12117397].
771 Wu A H, Lane P L. Metaanalysis in clinical chemistry: validation of cardiac troponin T as a marker for ischemic heart diseases. Clin Chem. 1995;41(8 Pt 2):1228-33. [pmid: 7628112].
772 Yapp C K, Taylor L S, Ow C Y, et al. Hypertension management: a comparison of urban versus rural general practitioners in Western Australia. Clin Exp Pharmacol Physiol. 1995;22(67):447-9. [pmid: 8582098].
773 Yarzebski J, Col N, Pagley P, et al. Gender differences and factors associated with the receipt of thrombolytic therapy in patients with acute myocardial infarction: a community-wide perspective. Am Heart J. 1996;131(1):43-50. [pmid: 8554018].
774 Yudkin J S, Chaturvedi N. Developing risk stratification charts for diabetic and nondiabetic subjects. Diabet Med. 1999;16(3):219-27. [pmid: 10227567].
775 Yusuf S. Interventions that potentially limit myocardial infarct size: overview of clinical trials. Am J Cardiol. 1987;60(2):11A-17A.
776 Yusuf S. Calcium antagonists in coronary artery disease and hypertension. Time for reevaluation?. Circulation. 1995;92(5):1079-82. [pmid: 7648648].
777 Yusuf S, Anand S, Avezum A Jr, et al. Treatment for acute myocardial infarction. Overview of randomized clinical trials. Eur Heart J. 1996;17(Suppl F):16-29. [pmid: 8960444].
778 Yusuf S, Collins R, Peto R, et al. Intravenous and intracoronary fibrinolytic therapy in acute myocardial infarction: overview of results on mortality, reinfarction and side-effects from 33 randomized controlled trials. Eur Heart J. 1985;6(7):556-85. [pmid: 3899654].
779 Yusuf S, Pogue J. Primary angioplasty compared with thrombolytic therapy for acute myocardial infarction. Jama. 1997;278(23):2110-1. [pmid: 9403429].
780 Yusuf S, Sleight P, Pogue J, et al. Effects of an angiotensin-converting-enzyme inhibitor, ramipril, on cardiovascular events in high-risk patients. The Heart Outcomes Prevention Evaluation Study Investigators. N Engl J Med. 2000;342(3):145-53. [pmid: 10639539].
781 Yusuf S, Zhao F, Mehta S R, et al. Effects of clopidogrel in addition to aspirin in patients with acute coronary syndromes without ST-segment elevation. N Engl J Med. 2001;345(7):494-502. [pmid: 11519503].
782 Yusuf S, Zucker D, Peduzzi P, et al. Effect of coronary artery bypass graft surgery on survival: overview of 10-year results from randomised trials by the Coronary Artery Bypass Graft Surgery Trialists Collaboration. Lancet. 1994;344(8922):563-70. [pmid: 7914958].
783 Zahn R, Schiele R, Schneider S, et al. Decreasing hospital mortality between 1994 and 1998 in patients with acute myocardial infarction treated with primary angioplasty but not in patients treated with intravenous thrombolysis. Results from the pooled data of the Maximal Individual Therapy in Acute Myocardial Infarction (MITRA) Registry and the Myocardial Infarction Registry (MIR). J Am Coll Cardiol. 2000;36(7):2064-71. [pmid: 11127442].
784 Zarembski D G, Nolan P E Jr, Slack M K, et al. Meta-analysis of the use of low-dose beta-adrenergic blocking therapy in idiopathic or ischemic dilated cardiomyopathy. Am J Cardiol. 1996;77(14):1247-50. [pmid: 8651108].
785 Zusman R M, Chesebro J H, Comerota A, et al. Antiplatelet therapy in the prevention of ischemic vascular events: literature review and evidence-based guidelines for drug selection. Clin Cardiol. 1999;22(9):559-73. [pmid: 10486695].