# References

1 Grady D, Rubin S M, Petitti D B, et al. Hormone therapy to prevent disease and prolong life in postmenopausal women. Ann Intern Med. 1992;117(12):1016-37. [pmid: 1443971].
2 Wenger N K, Speroff L, Packard B. Cardiovascular health and disease in women. N Engl J Med. 1993;329(4):247-56. [pmid: 8316269].
3 Lerner D J, Kannel W B. Patterns of coronary heart disease morbidity and mortality in the sexes: a 26-year follow-up of the Framingham population. Am Heart J. 1986;111(2):383-90. [pmid: 3946178].
4 Healy B. The Yentl syndrome. N Engl J Med. 1991;325(4):274-6. [pmid: 2057027].
5 Chaitman B R, Bourassa M G, Davis K, et al. Angiographic prevalence of high-risk coronary artery disease in patient subsets (CASS). Circulation. 1981;64(2):360-7. [pmid: 7249303].
6 Greenland P, Reicher-Reiss H, Goldbourt U, et al. In-hospital and 1-year mortality in 1,524 women after myocardial infarction. Comparison with 4,315 men. Circulation. 1991;83(2):484-91. [pmid: 1991367].
7 Kelsey S F, James M, Holubkov A L, et al. Results of percutaneous transluminal coronary angioplasty in women. 1985-1986 National Heart, Lung, and Blood Institute's Coronary Angioplasty Registry. Circulation. 1993;87(3):720-7. [pmid: 8443892].
8 O'Connor G T, Morton J R, Diehl M J, et al. Differences between men and women in hospital mortality associated with coronary artery bypass graft surgery. The Northern New England Cardiovascular Disease Study Group. Circulation. 1993;88(5 Pt 1):2104-10. [pmid: 8222104].
9 Kannel W B, Sorlie P, McNamara P M. Prognosis after initial myocardial infarction: the Framingham study. Am J Cardiol. 1979;44(1):53-9. [pmid: 453046].
10 Puletti M, Sunseri L, Curione M, et al. Acute myocardial infarction: sex-related differences in prognosis. Am Heart J. 1984;108(1):63-6. [pmid: 6731284].
11 Tofler G H, Stone P H, Muller J E, et al. Effects of gender and race on prognosis after myocardial infarction: adverse prognosis for women, particularly black women. J Am Coll Cardiol. 1987;9(3):473-82. [pmid: 3819194].
12 Steingart R M, Packer M, Hamm P, et al. Sex differences in the management of coronary artery disease. Survival and Ventricular Enlargement Investigators. N Engl J Med. 1991;325(4):226-30. [pmid: 2057023].
13 Ayanian J Z, Epstein A M. Differences in the use of procedures between women and men hospitalized for coronary heart disease. N Engl J Med. 1991;325(4):221-5. [pmid: 2057022].
14 Shaw L J, Miller D D, Romeis J C, et al. Gender differences in the noninvasive evaluation and management of patients with suspected coronary artery disease. Ann Intern Med. 1994;120(7):559-66. [pmid: 8116993].
15 Grady D, Herrington D, Vittner V, et al. Cardiovascular disease outcomes during 6.8 years of hormone therapy. Heart and Estrogen/progestin Replacement Study Follow-up (HERS II). JAMA. 2002;288:49-57. [pmid: 12090862].
16 Writing Group for the Women's Health Initiative Investigators. Risks and benefits of estrogen plus progestin in healthy postmenopausal women. Principal results from the Women's Health Initiative randomized controlled trial. JAMA. 2002;288:321-33. [pmid: 12117397].
17 EndNote. In. 4.0 ed. Berkeley, CA: ISI ResearchSoft; 1988.
18 Microsoft Access. In. 9.0.4402 SR-1 ed. Redmond, WA: MIcrosoft Corporation; 1992.
19 Kwok Y, Kim C, Grady D, et al. Meta-analysis of exercise testing to detect coronary artery disease in women. Am J Cardiol. 1999;83(5):660-6. [pmid: 10080415].
20 Gianrossi R, Detrano R, Mulvihill D, et al. Exercise-induced ST depression in the diagnosis of coronary artery disease. A meta-analysis. Circulation. 1989;80(1):87-98. [pmid: 2661056].
21 Detrano R, Janosi A, Lyons K P, et al. Factors affecting sensitivity and specificity of a diagnostic test: the exercise thallium scintigram. Am J Med. 1988;84(4):699-710. [pmid: 3041808].
22 Fleischmann K E, Hunink M G, Kuntz K M, et al. Exercise echocardiography or exercise SPECT imaging? A meta-analysis of diagnostic test performance. JAMA. 1998;280(10):913-20. [pmid: 9739977].
23 Iskandrian A E, Heo J, Nallamothu N. Detection of coronary artery disease in women with use of stress single-photon emission computed tomography myocardial perfusion imaging. J Nucl Cardiol. 1997;4(4):329-35. [pmid: 9278880].
24 Miller T D, Roger V L, Milavetz J J, et al. Assessment of the exercise electrocardiogram in women versus men using tomographic myocardial perfusion imaging as the reference standard. Am J Cardiol. 2001;87(7):868-73. [pmid: 11274942].
25 Detrano R, Hsiai T, Wang S, et al. Prognostic value of coronary calcification and angiographic stenoses in patients undergoing coronary angiography. J Am Coll Cardiol. 1996;27(2):285-90. [pmid: 8557895].
26 Budoff M J, Shokooh S, Shavelle R M, et al. Electron beam tomography and angiography: sex differences. Am Heart J. 2002;143(5):877-82. [pmid: 12040352].
27 Collaborative overview of randomised trials of antiplatelet therapy--I: Prevention of death, myocardial infarction, and stroke by prolonged antiplatelet therapy in various categories of patients. Antiplatelet Trialists' Collaboration. BMJ. 1994;308(6921):81-106. [pmid: 8298418].
28 Randomised trial of intravenous streptokinase, oral aspirin, both or neither among 17, 187 cases of suspected acute myocardial infarction: ISIS-2. ISIS-2 (Second International Study of Infarct Survival) Collaborative Group. Lancet. 1988;2(8607):349-60. [pmid: 2899772].
29 de Gaetano G. Low-dose aspirin and vitamin E in people at cardiovascular risk: a randomised trial in general practice. Collaborative Group of the Primary Prevention Project. Lancet. 2001;357(9250):89-95. [pmid: 11197445].
30 Hansson L, Zanchetti A, Carruthers S G, et al. Effects of intensive blood-pressure lowering and low-dose aspirin in patients with hypertension: principal results of the Hypertension Optimal Treatment (HOT) randomised trial. HOT Study Group. Lancet. 1998;351(9118):1755-62. [pmid: 9635947].
31 Kjeldsen S E, Kolloch R E, Leonetti G, et al. Influence of gender and age on preventing cardiovascular disease by antihypertensive treatment and acetylsalicylic acid. The HOT study. Hypertension Optimal Treatment. J Hypertens. 2000;18(5):629-42. [pmid: 10826567].
32 Manson J E, Stampfer M J, Colditz G A, et al. A prospective study of aspirin use and primary prevention of cardiovascular disease in women. JAMA. 1991;266(4):521-7. [pmid: 2061978].
33 Leizorovicz A, Lechat P, Cucherat M, et al. Bisoprolol for the treatment of chronic heart failure: a meta-analysis on individual data of two placebo-controlled studies--CIBIS and CIBIS II. Cardiac Insufficiency Bisoprolol Study. Am Heart J. 2002;143(2):301-7. [pmid: 11835035].
34 Ghali J K, Pina I L, Gottlieb S S, et al. Metoprolol CR/XL in female patients with heart failure: analysis of the experience in Metoprolol Extended-Release Randomized Intervention Trial in Heart Failure (MERIT-HF). Circulation. 2002;105(13):1585-91. [pmid: 11927527].
35 The Beta-Blocker Pooling Project (BBPP): subgroup findings from randomized trials in post infarction patients. The Beta-Blocker Pooling Project Research Group. Eur Heart J. 1988;9(1):8-16.
36 Olsson G, Wikstrand J, Warnold I, et al. Metoprolol-induced reduction in postinfarction mortality: pooled results from five double-blind randomized trials. Eur Heart J. 1992;13(1):28-32. [pmid: 1533587].
37 Garg R, Yusuf S. Overview of randomized trials of angiotensin-converting enzyme inhibitors on mortality and morbidity in patients with heart failure. Collaborative Group on ACE Inhibitor Trials. JAMA. 1995;273(18):1450-6. [pmid: 7654275].
38 Flather M D, Yusuf S, Kober L, et al. Long-term ACE-inhibitor therapy in patients with heart failure or left-ventricular dysfunction: a systematic overview of data from individual patients. ACE-Inhibitor Myocardial Infarction Collaborative Group. Lancet. 2000;355(9215):1575-81. [pmid: 10821360].
39 Yusuf S, Sleight P, Pogue J, et al. Effects of an angiotensin-converting-enzyme inhibitor, ramipril, on cardiovascular events in high-risk patients. The Heart Outcomes Prevention Evaluation Study Investigators. N Engl J Med. 2000;342(3):145-53. [pmid: 10639539].
40 Dagenais G R, Yusuf S, Bourassa M G, et al. Effects of ramipril on coronary events in high-risk persons: results of the Heart Outcomes Prevention Evaluation Study. Circulation. 2001;104(5):522-6. [pmid: 11479247].
41 Lonn E, Roccaforte R, Yi Q, et al. Effect of long-term therapy with ramipril in high-risk women. J Am Coll Cardiol. 2002;40(4):693. [pmid: 12204499].
42 Indications for ACE inhibitors in the early treatment of acute myocardial infarction: systematic overview of individual data from 100,000 patients in randomized trials. ACE Inhibitor Myocardial Infarction Collaborative Group. Circulation. 1998;97(22):2202-12. [pmid: 9631869].
43 GISSI-3: effects of lisinopril and transdermal glyceryl trinitrate singly and together on 6-week mortality and ventricular function after acute myocardial infarction. Gruppo Italiano per lo Studio della Sopravvivenza nell'infarto Miocardico. Lancet. 1994;343(8906):1115-22. [pmid: 7910229].
44 ISIS-4: a randomised factorial trial assessing early oral captopril, oral mononitrate, and intravenous magnesium sulphate in 58,050 patients with suspected acute myocardial infarction. ISIS-4 (Fourth International Study of Infarct Survival) Collaborative Group. Lancet. 1995;345(8951):669-85. [pmid: 7661937].
45 Six-month effects of early treatment with lisinopril and transdermal glyceryl trinitrate singly and together withdrawn six weeks after acute myocardial infarction: the GISSI-3 trial. Gruppo Italiano per lo Studio della Sopravvivenza nell'Infarto Miocardico. J Am Coll Cardiol. 1996;27(2):337-44. [pmid: 8557903].
46 Cho L, Topol E J, Balog C, et al. Clinical benefit of glycoprotein IIb/IIIa blockade with Abciximab is independent of gender: pooled analysis from EPIC, EPILOG and EPISTENT trials. Evaluation of 7E3 for the Prevention of Ischemic Complications. Evaluation in Percutaneous Transluminal Coronary Angioplasty to Improve Long-Term Outcome with Abciximab GP IIb/IIIa blockade. Evaluation of Platelet IIb/IIIa Inhibitor for Stent. J Am Coll Cardiol. 2000;36(2):381-6. [pmid: 10933346].
47 Boersma E, Harrington R A, Moliterno D J, et al. Platelet glycoprotein IIb/IIIa inhibitors in acute coronary syndromes: a meta-analysis of all major randomised clinical trials. Lancet. 2002;359(9302):189-98. [pmid: 11812552].
48 Indications for fibrinolytic therapy in suspected acute myocardial infarction: collaborative overview of early mortality and major morbidity results from all randomised trials of more than 1000 patients. Fibrinolytic Therapy Trialists' (FTT) Collaborative Group. Lancet. 1994;343(8893):311-22. [pmid: 7905143].
49 Stone G W, Grines C L, Browne K F, et al. Comparison of in-hospital outcome in men versus women treated by either thrombolytic therapy or primary coronary angioplasty for acute myocardial infarction. Am J Cardiol. 1995;75(15):987-92. [pmid: 7747700].
50 Yusuf S, Zhao F, Mehta S R, et al. Effects of clopidogrel in addition to aspirin in patients with acute coronary syndromes without ST-segment elevation. N Engl J Med. 2001;345(7):494-502. [pmid: 11519503].
51 Mehta S R, Yusuf S, Peters R J, et al. Effects of pretreatment with clopidogrel and aspirin followed by long-term therapy in patients undergoing percutaneous coronary intervention: the PCI-CURE study. Lancet. 2001;358(9281):527-33. [pmid: 11520521].
52 Coronary angioplasty versus medical therapy for angina: the second Randomised Intervention Treatment of Angina (RITA-2) trial. RITA-2 trial participants. Lancet. 1997;350(9076):461-8. [pmid: 9274581].
53 First-year results of CABRI (Coronary Angioplasty versus Bypass Revascularisation Investigation). CABRI Trial Participants. Lancet. 1995;346(8984):1179-84. [pmid: 7475656].
54 Holmes D R Jr, Holubkov R, Vlietstra R E, et al. Comparison of complications during percutaneous transluminal coronary angioplasty from 1977 to 1981 and from 1985 to 1986: the National Heart, Lung, and Blood Institute Percutaneous Transluminal Coronary Angioplasty Registry. J Am Coll Cardiol. 1988;12(5):1149-55. [pmid: 2971699].
55 Weintraub W S, Wenger N K, Kosinski A S, et al. Percutaneous transluminal coronary angioplasty in women compared with men. J Am Coll Cardiol. 1994;24(1):81-90. [pmid: 8006286].
56 Mehilli J, Kastrati A, Dirschinger J, et al. Differences in prognostic factors and outcomes between women and men undergoing coronary artery stenting. JAMA. 2000;284(14):1799-805. [pmid: 11025832].
57 Bell M R, Holmes D R Jr, Berger P B, et al. The changing in-hospital mortality of women undergoing percutaneous transluminal coronary angioplasty. JAMA. 1993;269(16):2091-5. [pmid: 8468762].
58 Ellis S G, Roubin G S, King S B 3rd, et al. In-hospital cardiac mortality after acute closure after coronary angioplasty: analysis of risk factors from 8,207 procedures. J Am Coll Cardiol. 1988;11(2):211-6. [pmid: 2963055].
59 Bell M R, Grill D E, Garratt K N, et al. Long-term outcome of women compared with men after successful coronary angioplasty. Circulation. 1995;91(12):2876-81. [pmid: 7796495].
60 Davis K B, Chaitman B, Ryan T, et al. Comparison of 15-year survival for men and women after initial medical or surgical treatment for coronary artery disease: a CASS registry study. Coronary Artery Surgery Study. J Am Coll Cardiol. 1995;25(5):1000-9. [pmid: 7897108].
61 Jacobs A K, Kelsey S F, Brooks M M, et al. Better outcome for women compared with men undergoing coronary revascularization: a report from the bypass angioplasty revascularization investigation (BARI). Circulation. 1998;98(13):1279-85. [pmid: 9751675].
62 Fiebach N H, Hebert P R, Stampfer M J, et al. A prospective study of high blood pressure and cardiovascular disease in women. Am J Epidemiol. 1989;130(4):646-54. [pmid: 2773913].
63 Kannel W B. Blood pressure as a cardiovascular risk factor: prevention and treatment. JAMA. 1996;275(20):1571-6. [pmid: 8622248].
64 Nielsen W B, Vestbo J, Jensen G B. Isolated systolic hypertension as a major risk factor for stroke and myocardial infarction and an unexploited source of cardiovascular prevention: a prospective population-based study. J Hum Hypertens. 1995;9(3):175-80. [pmid: 7783098].
65 Perlman J A, Wolf P H, Ray R, et al. Cardiovascular risk factors, premature heart disease, and all-cause mortality in a cohort of northern California women. Am J Obstet Gynecol. 1988;158(6 Pt 2):1568-74. [pmid: 3377034].
66 Gueyffier F, Boutitie F, Boissel J P, et al. Effect of antihypertensive drug treatment on cardiovascular outcomes in women and men. A meta-analysis of individual patient data from randomized, controlled trials. The INDANA Investigators. Ann Intern Med. 1997;126(10):761-7. [pmid: 9148648].
67 Quan A, Kerlikowske K, Gueyffier F, et al. Efficacy of treating hypertension in women. J Gen Intern Med. 1999;14(12):718-29. [pmid: 10632816].
68 Quan A, Kerlikowske K, Gueyffier F, et al. Pharmacotherapy for hypertension in women of different races. Cochrane Database Syst Rev 2000(3):CD002146.
69 Wang J G, Staessen J A, Gong L, et al. Chinese trial on isolated systolic hypertension in the elderly. Systolic Hypertension in China (Syst-China) Collaborative Group. Arch Intern Med. 2000;160(2):211-20. [pmid: 10647760].
70 Orchard T J. The impact of gender and general risk factors on the occurrence of atherosclerotic vascular disease in non-insulin-dependent diabetes mellitus. Ann Med. 1996;28(4):323-33. [pmid: 8862687].
71 Lee W L, Cheung A M, Cape D, et al. Impact of diabetes on coronary artery disease in women and men: a meta-analysis of prospective studies. Diabetes Care. 2000;23(7):962-8. [pmid: 10895847].
72 Abbott R D, Donahue R P, Kannel W B, et al. The impact of diabetes on survival following myocardial infarction in men vs women. The Framingham Study. JAMA. 1988;260(23):3456-60. [pmid: 2974889].
73 Brand F N, Abbott R D, Kannel W B. Diabetes, intermittent claudication, and risk of cardiovascular events. The Framingham Study. Diabetes. 1989;38(4):504-9. [pmid: 2925008].
74 Kannel W B, D'Agostino R B, Wilson P W, et al. Diabetes, fibrinogen, and risk of cardiovascular disease: the Framingham experience. Am Heart J. 1990;120(3):672-6. [pmid: 2389702].
75 Manson J E, Colditz G A, Stampfer M J, et al. A prospective study of maturity-onset diabetes mellitus and risk of coronary heart disease and stroke in women. Arch Intern Med. 1991;151(6):1141-7. [pmid: 2043016].
76 Hu F B, Stampfer M J, Solomon C G, et al. The impact of diabetes mellitus on mortality from all causes and coronary heart disease in women: 20 years of follow-up. Arch Intern Med. 2001;161(14):1717-23. [pmid: 11485504].
77 Donahue R P, Goldberg R J, Chen Z, et al. The influence of sex and diabetes mellitus on survival following acute myocardial infarction: a community-wide perspective. J Clin Epidemiol. 1993;46(3):245-52. [pmid: 8455049].
78 Malmberg K, Yusuf S, Gerstein H C, et al. Impact of diabetes on long-term prognosis in patients with unstable angina and non-Q-wave myocardial infarction: results of the OASIS (Organization to Assess Strategies for Ischemic Syndromes) Registry. Circulation. 2000;102(9):1014-9. [pmid: 10961966].
79 Manolio T A, Pearson T A, Wenger NK, et al. Cholesterol and heart disease in older persons and women. Review of an NHLBI workshop. Ann Epidemiol. 1992;2(12):161-76. [pmid: 1342259].
80 Jacobs D, Blackburn H, Higgins M, et al. Report of the Conference on Low Blood Cholesterol: Mortality Associations. Circulation. 1992;86(3):1046-60. [pmid: 1355411].
81 Hokanson J E, Austin M A. Plasma triglyceride level is a risk factor for cardiovascular disease independent of high-density lipoprotein cholesterol level: a meta-analysis of population-based prospective studies. J Cardiovasc Risk. 1996;3(2):213-9. [pmid: 8836866].
82 Austin M A, Hokanson J E, Edwards K L. Hypertriglyceridemia as a cardiovascular risk factor. Am J Cardiol. 1998;81(4A):7B-12B. [pmid: 9462597].
83 Craig W Y, Neveux L M, Palomaki G E, et al. Lipoprotein(a) as a risk factor for ischemic heart disease: metaanalysis of prospective studies. Clin Chem. 1998;44(11):2301-6. [pmid: 9799757].
84 Walsh J M, Grady D. Treatment of hyperlipidemia in women. JAMA. 1995;274(14):1152-8. [pmid: 7563487].
85 Byington R P, Jukema J W, Salonen J T, et al. Reduction in cardiovascular events during pravastatin therapy. Pooled analysis of clinical events of the Pravastatin Atherosclerosis Intervention Program. Circulation. 1995;92(9):2419-25. [pmid: 7586340].
86 Buchwald H, Campos CT, Boen JR, et al. Gender-based mortality follow-up from the Program on the Surgical Control of the Hyperlipidemias (POSCH) and meta-analysis of lipid intervention trials. Women in POSCH and other lipid trials. Ann Surg 1996;224(4):486–98; discussion 498–500.
87 LaRosa J C, He J, Vupputuri S. Effect of statins on risk of coronary disease: a meta-analysis of randomized controlled trials. JAMA. 1999;282(24):2340-6. [pmid: 10612322].
88 Miettinen T A, Pyorala K, Olsson A G, et al. Cholesterol-lowering therapy in women and elderly patients with myocardial infarction or angina pectoris: findings from the Scandinavian Simvastatin Survival Study (4S). Circulation. 1997;96(12):4211-8. [pmid: 9416884].
89 MRC/BHF Heart Protection Study of cholesterol lowering with simvastatin in 20, 536 high-risk individuals: a randomised placebo-controlled trial. Lancet. 2002;360(9326):7-22. [pmid: 12114036].
90 Boushey C J, Beresford S A, Omenn G S, et al. A quantitative assessment of plasma homocysteine as a risk factor for vascular disease. Probable benefits of increasing folic acid intakes. JAMA. 1995;274(13):1049-57. [pmid: 7563456].
91 Lowering blood homocysteine with folic acid based supplements: meta-analysis of randomised trials. Homocysteine Lowering Trialists' Collaboration. BMJ. 1998;316(7135):894-8. [pmcid: 28491]. [pmid: 9569395].
92 Ridker P M, Buring J E, Shih J, et al. Prospective study of C-reactive protein and the risk of future cardiovascular events among apparently healthy women. Circulation. 1998;98(8):731-3. [pmid: 9727541].
93 Ridker P M, Hennekens C H, Buring J E, et al. C-reactive protein and other markers of inflammation in the prediction of cardiovascular disease in women. N Engl J Med. 2000;342(12):836-43. [pmid: 10733371].
94 Willett W C, Green A, Stampfer M J, et al. Relative and absolute excess risks of coronary heart disease among women who smoke cigarettes. N Engl J Med. 1987;317(21):1303-9. [pmid: 3683458].
95 Kawachi I, Colditz G A, Stampfer M J, et al. Smoking cessation and time course of decreased risks of coronary heart disease in middle-aged women. Arch Intern Med. 1994;154(2):169-75. [pmid: 8285812].
96 Paganini-Hill A, Hsu G. Smoking and mortality among residents of a California retirement community. Am J Public Health. 1994;84(6):992-5. [pmid: 8203698].
97 Njolstad I, Arnesen E, Lund-Larsen P G. Smoking, serum lipids, blood pressure, and sex differences in myocardial infarction. A 12-year follow-up of the Finnmark Study. Circulation. 1996;93(3):450-6. [pmid: 8565161].
98 Prescott E, Hippe M, Schnohr P, et al. Smoking and risk of myocardial infarction in women and men: longitudinal population study. BMJ. 1998;316(7137):1043-7. [pmcid: 28505]. [pmid: 9552903].
99 Kannel W B, D'Agostino R B, Belanger A J. Fibrinogen, cigarette smoking, and risk of cardiovascular disease: insights from the Framingham Study. Am Heart J. 1987;113(4):1006-10. [pmid: 3565227].
100 Freund K M, Belanger A J, D'Agostino R B, et al. The health risks of smoking. The Framingham Study: 34 years of follow-up. Ann Epidemiol. 1993;3(4):417-24. [pmid: 8275219].
101 LaCroix A Z, Lang J, Scherr P, et al. Smoking and mortality among older men and women in three communities. N Engl J Med. 1991;324(23):1619-25. [pmid: 2030718].
102 Wilson K, Gibson N, Willan A, et al. Effect of smoking cessation on mortality after myocardial infarction: meta-analysis of cohort studies. Arch Intern Med. 2000;160(7):939-44. [pmid: 10761958].
103 Omenn G S, Anderson K W, Kronmal R A, et al. The temporal pattern of reduction of mortality risk after smoking cessation. Am J Prev Med. 1990;6(5):251-7. [pmid: 2268453].
104 Kawachi I, Colditz G A, Stampfer M J, et al. Smoking cessation in relation to total mortality rates in women. A prospective cohort study. Ann Intern Med. 1993;119(10):992-1000. [pmid: 8214996].
105 Harris T, Cook E F, Garrison R, et al. Body mass index and mortality among nonsmoking older persons. The Framingham Heart Study. JAMA. 1988;259(10):1520-4. [pmid: 3339789].
106 Kannel W B, Cupples L A, Ramaswami R, et al. Regional obesity and risk of cardiovascular disease; the Framingham Study. J Clin Epidemiol. 1991;44(2):183-90. [pmid: 1995775].
107 Manson J E, Colditz G A, Stampfer M J, et al. A prospective study of obesity and risk of coronary heart disease in women. N Engl J Med. 1990;322(13):882-9. [pmid: 2314422].
108 Manson J E, Willett W C, Stampfer M J, et al. Body weight and mortality among women. N Engl J Med. 1995;333(11):677-85. [pmid: 7637744].
109 Willett W C, Manson J E, Stampfer M J, et al. Weight, weight change, and coronary heart disease in women. Risk within the ‘normal’ weight range. JAMA. 1995;273(6):461-5. [pmid: 7654270].
110 Rexrode K M, Carey V J, Hennekens C H, et al. Abdominal adiposity and coronary heart disease in women. JAMA. 1998;280(21):1843-8. [pmid: 9846779].
111 Field A E, Coakley E H, Must A, et al. Impact of overweight on the risk of developing common chronic diseases during a 10-year period. Arch Intern Med. 2001;161(13):1581-6. [pmid: 11434789].
112 Folsom A R, Burke G L, Byers C L, et al. Implications of obesity for cardiovascular disease in blacks: the CARDIA and ARIC studies. Am J Clin Nutr. 1991;53(6 Suppl):1604S-1611S. [pmid: 2031493].
113 Folsom A R, French S A, Zheng W, et al. Weight variability and mortality: the Iowa Women's Health Study. Int J Obes Relat Metab Disord. 1996;20(8):704-9. [pmid: 8856391].
114 French S A, Folsom A R, Jeffery R W, et al. Weight variability and incident disease in older women: the Iowa Women's Health Study. Int J Obes Relat Metab Disord. 1997;21(3):217-23. [pmid: 9080261].
115 Folsom A R, Kushi L H, Anderson K E, et al. Associations of general and abdominal obesity with multiple health outcomes in older women: the Iowa Women's Health Study. Arch Intern Med. 2000;160(14):2117-28. [pmid: 10904454].
116 Folsom A R, Stevens J, Schreiner P J, et al. Body mass index, waist/hip ratio, and coronary heart disease incidence in African Americans and whites. Atherosclerosis Risk in Communities Study Investigators. Am J Epidemiol. 1998;148(12):1187-94. [pmid: 9867265].
117 Manson J E, Hu F B, Rich-Edwards J W, et al. A prospective study of walking as compared with vigorous exercise in the prevention of coronary heart disease in women. N Engl J Med. 1999;341(9):650-8. [pmid: 10460816].
118 Lee I M, Rexrode K M, Cook N R, et al. Physical activity and coronary heart disease in women: is “no pain, no gain” passe?. JAMA. 2001;285(11):1447-54. [pmid: 11255420].
119 Rockhill B, Willett W C, Manson J E, et al. Physical activity and mortality: a prospective study among women. Am J Public Health. 2001;91(4):578-83. [pmid: 11291369].
120 Blair S N, Kohl H W 3rd, Paffenbarger R S Jr, et al. Physical fitness and all-cause mortality. A prospective study of healthy men and women. JAMA. 1989;262(17):2395-401. [pmid: 2795824].
121 Sherman S E, D'Agostino R B, Cobb J L, et al. Physical activity and mortality in women in the Framingham Heart Study. Am Heart J. 1994;128(5):879-84. [pmid: 7942478].
122 Oldridge N B, Guyatt G H, Fischer M E, et al. Cardiac rehabilitation after myocardial infarction. Combined experience of randomized clinical trials. JAMA. 1988;260(7):945-50. [pmid: 3398199].
123 O'Connor G T, Buring J E, Yusuf S, et al. An overview of randomized trials of rehabilitation with exercise after myocardial infarction. Circulation. 1989;80(2):234-44. [pmid: 2665973].
124 Jolliffe JA, Rees K, Taylor RS, et al. Exercise-based rehabilitation for coronary heart disease. Cochrane Database Syst Rev 2000;4.
125 Pocock S J, McCormack V, Gueyffier F, et al. A score for predicting risk of death from cardiovascular disease in adults with raised blood pressure, based on individual patient data from randomised controlled trials. BMJ. 2001;323(7304):75-81. [pmcid: 34541]. [pmid: 11451781].
126 D'Agostino R B Sr, Grundy S, Sullivan L M, et al. Validation of the Framingham coronary heart disease prediction scores: results of a multiple ethnic groups investigation. JAMA. 2001;286(2):180-7. [pmid: 11448281].
127 Hu F B, Grodstein F, Hennekens C H, et al. Age at natural menopause and risk of cardiovascular disease. Arch Intern Med. 1999;159(10):1061-6. [pmid: 10335682].
128 van der Schouw Y T, van der Graaf Y, Steyerberg E W, et al. Age at menopause as a risk factor for cardiovascular mortality. Lancet. 1996;347(9003):714-8. [pmid: 8602000].
129 Cooper G S, Sandler D P. Age at natural menopause and mortality. Ann Epidemiol. 1998;8(4):229-35. [pmid: 9590601].
130 Keil J E, Sutherland S E, Knapp R G, et al. Mortality rates and risk factors for coronary disease in black as compared with white men and women. N Engl J Med. 1993;329(2):73-8. [pmid: 8510705].
131 White A D, Rosamond W D, Chambless L E, et al. Sex and race differences in short-term prognosis after acute coronary heart disease events: the Atherosclerosis Risk In Communities (ARIC) study. Am Heart J. 1999;138(3 Pt 1):540-8. [pmid: 10467206].
132 Roig E, Castaner A, Simmons B, et al. In-hospital mortality rates from acute myocardial infarction by race in U.S. hospitals: findings from the National Hospital Discharge Survey. Circulation. 1987;76(2):280-8. [pmid: 3608117].
133 Salomaa V, Miettinen H, Niemela M, et al. Relation of socioeconomic position to the case fatality, prognosis and treatment of myocardial infarction events; the FINMONICA MI Register Study. J Epidemiol Community Health. 2001;55(7):475-82. [pmid: 11413176].
134 Capewell S, MacIntyre K, Stewart S, et al. Age, sex, and social trends in out-of-hospital cardiac deaths in Scotland 1986-95: a retrospective cohort study. Lancet. 2001;358(9289):1213-7. [pmid: 11675057].
135 Morrison C, Woodward M, Leslie W, et al. Effect of socioeconomic group on incidence of, management of, and survival after myocardial infarction and coronary death: analysis of community coronary event register. BMJ. 1997;314(7080):541-6. [pmid: 9055711].
136 Johnson P A, Goldman L, Orav E J, et al. Gender differences in the management of acute chest pain. Support for the “Yentl syndrome”. J Gen Intern Med. 1996;11(4):209-17. [pmid: 8744878].
137 Roger V L, Farkouh M E, Weston S A, et al. Sex differences in evaluation and outcome of unstable angina. JAMA. 2000;283(5):646-52. [pmid: 10665705].
138 Battleman D S, Callahan M. Gender differences in utilization of exercise treadmill testing: a claims-based analysis. J Healthc Qual. 2001;23(3):38-41. [pmid: 11378976].
139 Pagley P R, Yarzebski J, Goldberg R, et al. Gender differences in the treatment of patients with acute myocardial infarction. A multihospital, community-based perspective. Arch Intern Med. 1993;153(5):625-9. [pmid: 8439225].
140 Clarke K W, Gray D, Keating N A, et al. Do women with acute myocardial infarction receive the same treatment as men?. Bmj. 1994;309(6954):563-6. [pmid: 7916228].
141 Tsuyuki R T, Teo K K, Ikuta R M, et al. Mortality risk and patterns of practice in 2,070 patients with acute myocardial infarction, 1987-92. Relative importance of age, sex, and medical therapy. Chest. 1994;105(6):1687-92. [pmid: 7911417].
142 Chandra N C, Ziegelstein R C, Rogers W J, et al. Observations of the treatment of women in the United States with myocardial infarction: a report from the National Registry of Myocardial Infarction-I. Arch Intern Med. 1998;158(9):981-8. [pmid: 9588431].
143 Rojas-Fernandez C H, Kephart G C, Sketris I S, et al. Underuse of acetylsalicylic acid in individuals with myocardial infarction, ischemic heart disease or stroke: data from the 1995 population-based Nova Scotia Health Survey. Can J Cardiol. 1999;15(3):291-6. [pmid: 10202192].
144 Shahar E, Folsom A R, Romm F J, et al. Patterns of aspirin use in middle-aged adults: the Atherosclerosis Risk in Communities (ARIC) Study. Am Heart J. 1996;131(5):915-22. [pmid: 8615310].
145 Maynard C, Althouse R, Cerqueira M, et al. Underutilization of thrombolytic therapy in eligible women with acute myocardial infarction. Am J Cardiol. 1991;68(5):529-30. [pmid: 1908180].
146 Maynard C, Litwin P E, Martin J S, et al. Gender differences in the treatment and outcome of acute myocardial infarction. Results from the Myocardial Infarction Triage and Intervention Registry. Arch Intern Med. 1992;152(5):972-6. [pmid: 1580724].
147 Yarzebski J, Col N, Pagley P, et al. Gender differences and factors associated with the receipt of thrombolytic therapy in patients with acute myocardial infarction: a community-wide perspective. Am Heart J. 1996;131(1):43-50. [pmid: 8554018].
148 Pfeffer M A, Moye L A, Braunwald E, et al. Selection bias in the use of thrombolytic therapy in acute myocardial infarction. The SAVE Investigators. JAMA. 1991;266(4):528-32. [pmid: 2061979].
149 Kudenchuk P J, Maynard C, Martin J S, et al. Comparison of presentation, treatment, and outcome of acute myocardial infarction in men versus women (the Myocardial Infarction Triage and Intervention Registry). Am J Cardiol. 1996;78(1):9-14. [pmid: 8712126].
150 Petticrew M, McKee M, Jones J. Coronary artery surgery: are women discriminated against?. Bmj. 1993;306(6886):1164-6. [pmid: 8499817].
151 Strauss R, Pfeifer C, Muhlberger V, et al. Effects of morbidity, age, gender and region on percutaneous transluminal coronary angioplasty (PTCA) utilisation. Public Health. 1999;113(2):79-87. [pmid: 10355307].
152 Giacomini M K. Gender and ethnic differences in hospital-based procedure utilization in California. Arch Intern Med. 1996;156(11):1217-24. [pmid: 8639016].
153 Chiriboga D E, Yarzebski J, Goldberg R J, et al. A community-wide perspective of gender differences and temporal trends in the use of diagnostic and revascularization procedures for acute myocardial infarction. Am J Cardiol. 1993;71(4):268-73. [pmid: 8427166].
154 Giles T D, Fisher M B, Rush J E. Lisinopril and captopril in the treatment of heart failure in older patients. Comparison of a long- and short-acting angiotensin-converting enzyme inhibitor. Am J Med. 1988;85(3B):44-7. [pmid: 2844087].
155 Goldberg K C, Hartz A J, Jacobsen S J, et al. Racial and community factors influencing coronary artery bypass graft surgery rates for all 1986 Medicare patients. JAMA. 1992;267(11):1473-7. [pmid: 1538537].
156 Ramsey D J, Goff D C, Wear M L, et al. Sex and ethnic differences in use of myocardial revascularization procedures in Mexican Americans and non-Hispanic whites: the Corpus Christi Heart Project. J Clin Epidemiol. 1997;50(5):603-9. [pmid: 9180653].
157 Krumholz H M, Douglas P S, Lauer M S, et al. Selection of patients for coronary angiography and coronary revascularization early after myocardial infarction: is there evidence for a gender bias?. Ann Intern Med. 1992;116(10):785-90. [pmid: 1567092].
158 Bergelson B A, Tommaso C L. Gender differences in clinical evaluation and triage in coronary artery disease. Chest. 1995;108(6):1510-3. [pmid: 7497752].
159 D'Hoore W, Sicotte C, Tilquin C. Sex bias in the management of coronary artery disease in Quebec. Am J Public Health. 1994;84(6):1013-5. [pmid: 8203667].
160 Weaver W D, White H D, Wilcox R G, et al. Comparisons of characteristics and outcomes among women and men with acute myocardial infarction treated with thrombolytic therapy. GUSTO-I investigators. JAMA. 1996;275(10):777-82. [pmid: 8598594].
161 Miller T D, Roger V L, Hodge D O, et al. Gender differences and temporal trends in clinical characteristics, stress test results and use of invasive procedures in patients undergoing evaluation for coronary artery disease. J Am Coll Cardiol. 2001;38(3):690-7. [pmid: 11527619].
162 Jaglal S B, Goel V, Naylor C D. Sex differences in the use of invasive coronary procedures in Ontario. Can J Cardiol. 1994;10(2):239-44. [pmid: 8143225].
163 Bickell N A, Pieper K S, Lee K L, et al. Referral patterns for coronary artery disease treatment: gender bias or good clinical judgment?. Ann Intern Med. 1992;116(10):791-7. [pmid: 1567093].
164 Klungel O H, de Boer A, Paes A H, et al. Sex differences in the pharmacological treatment of hypertension: a review of population-based studies. J Hypertens. 1997;15(6):591-600. [pmid: 9218177].
165 Sketris I S, Kephart G C, Hicks V A, et al. Prescribing patterns of antilipemic drugs and prevalence of hypercholesterolemia in the Nova Scotia population more than 65 years old. Ann Pharmacother. 1995;29(6):576-81. [pmid: 7663028].
166 Magrini N, Einarson T, Vaccheri A, et al. Use of lipid-lowering drugs from 1990 to 1994: an international comparison among Australia, Finland, Italy (Emilia Romagna Region), Norway and Sweden. Eur J Clin Pharmacol. 1997;53(34):185-9. [pmid: 9476029].
167 Majeed A, Moser K, Maxwell R. Age, sex and practice variations in the use of statins in general practice in England and Wales. J Public Health Med. 2000;22(3):275-9. [pmid: 11077897].
168 Bernstein S J, Hilborne L H, Leape L L, et al. The appropriateness of use of cardiovascular procedures in women and men. Arch Intern Med. 1994;154(23):2759-65. [pmid: 7993162].
169 Saha S, Stettin G D, Redberg R F. Gender and willingness to undergo invasive cardiac procedures. J Gen Intern Med. 1999;14(2):122-5. [pmid: 10051783].