# Conclusions

## Summary and Recommendations by Key Question

Table 3 presents a summary of the findings of the evidence review for each key question. We have classified the evidence as none, weak, fair or good, defined as follows:

Classification | Evidence
None | no publications that address the key question in women
Weak | some evidence, but no systematic review or definitive evidence from randomized trials
Fair | at least one systematic review, but the review is only fair quality or outdated or evidence from randomized trials, but the trials are small or have inconsistent findings
Good | at least one recent, good quality systematic review or several major randomized trials with consistent findings

Table 3. Summary and Recommendations by Key Question

Key Question | Topic | Existing Evidence | Systematic Review Feasible? | Summary & Recommendations
1.01 | Exercise tolerance testing | fair | yes | Two good quality systematic reviews suggest that the accuracy of exercise EKG and exercise thallium in women appears to be low with positive likelihood ratios of 2 to 3 and negative likelihood ratios of .35 to .55.^19,^ ^22^ The accuracy of exercise echocardiography appears to be higher with a positive likelihood ratio of 4 and negative likelihood ratio of .2, but data are limited. However, one of the systematic reviews is outdated,^19^ the other does not provide accuracy estimates stratified by gender^22^ and neither addresses current myocardial perfusion imaging technology using thallium and/or technetium agents with SPECT or gated SPECT imaging in women. An updated systematic review including information on exercise SPECT is feasible and could provide important clinical information.
1.02 | Exercise echocardiogram | fair | yes
1.03 | Calcium score | weak | no | Two good quality studies of the accuracy of computed tomographic measures of coronary calcium suggest that a score of 0 has a high sensitivity and low negative likelihood ratio for angiographic coronary disease and might be useful for ruling out disease in both men and women.^25,^ ^26^
2.01 | Aspirin | | | There is evidence from a good systematic review that aspirin reduces risk of CHD events about 20% in women with coronary disease or at high risk for CHD. ^27^ The systematic review included only studies published until 1990 and provided few data on dose, duration of therapy or adverse effects in women. A more detailed and current systematic review of the data in women is feasible. A new review is unlikely to change overall conclusions, but might provide clinically important information on dose, duration and adverse effects.
| a. secondary prevention | good | yes
| b. primary prevention | weak | yes | Evidence from a randomized trial among persons with hypertension suggests that risk for cardiovascular events is reduced about 20% in women taking aspirin, but total mortality was not reduced.^30,^ ^31^ A systematic review of aspirin for primary prevention is feasible, assuming that data stratified by gender could be obtained. However, a systematic review should likely await the results of the ongoing Women's Health Study, a randomized trial of aspirin therapy in women that may be definitive.
2.02 | Beta-blockers | | | Two small meta-analyses that included data from 4 large randomized trials found that treatment with beta-blockers reduced the risk of mortality by about 30% in both men and women with CHF.^33,^ ^34^ There have been approximately 20 randomized trials of the effect of beta-blockers in persons with CHF. Many of these included a small proportion of women, but did not report results specific to women. A systematic review of the effect of beta-blockers in women with CHF is feasible and could provide a more accurate estimate of the effect on mortality, assess other outcomes such as hospitalizations and adverse effects, and evaluate outcomes in subgroups of women, such as those with severe CHF. Based on evidence from two fair quality systematic reviews, treatment with beta-blockers after MI in women appears to decrease mortality 20 to 25%.^35,^ ^36^ Both of these reviews are over 10 years old and they provide no data on long-term beta-blocker treatment after MI. It would be useful to update these systematic reviews using currently accepted methodologic standards
| a. secondary prevention | fair | yes
| b. Primary prevention | none | no | There is insufficient evidence in women to address this question.
2.03 | ACE inhibitors
| a. secondary prevention | good | yes | Among women with documented CHF, two good systematic reviews suggest that outpatient treatment with ACE inhibitors reduces the risk of mortality 15 to 20%.^37,^ ^38^
| | | | Results of the HOPE trial suggest that outpatient treatment of women with cardiovascular disease or with multiple risk factors results in about a 20% reduction in risk of cardiovascular events.^39–41^
| | | | A systematic review of the results of 4 large randomized trials, treatment with ACE inhibitors within 36 hours of acute MI is probably associated with about a 7% reduction in risk of mortality in the 30 days after MI, but this small benefit is associated with about a 2-fold increased risk of both hypotension and renal dysfunction.^42^
| | | | New systematic reviews of these topics are feasible, but are unlikely to provide additional information on use of ACE inhibitors in women.
| b. Primary prevention | none | no | There is insufficient evidence in women to address this question.
2.04 | Calcium channel blockers | none | no | There is insufficient evidence in women to address this question.
2.05 | Nitrates | good | no | Consistent evidence from 2 large randomized trials suggests that mortality in women is not reduced after MI by early treatment with nitrates.^43,^ ^44^ Further systematic review of the literature related to this question is unlikely to provide clinically useful information.
2.06 | Heparin | none | no | There is insufficient evidence in women to address this question.
2.07 | IIb/IIIa drugs | fair to good | yes | A recent fair quality systematic review found that among women undergoing percutaneous coronary interventions, treatment with abciximab for a maximum of 12 hours reduces risk of death, MI and urgent revascularization 40 to 50% at 6 weeks and at 6 months.^46^ Risk for mortality is reduced 40% at one year. There is no difference in the effect of these drugs in men and women who are undergoing percutaneous coronary intervention.
| | | | A recent good quality systematic review found that among women admitted to the hospital for acute coronary syndromes, the effect of glycoprotein IIb/IIIa inhibitor treatment may be harmful.^47^ While men with acute coronary syndromes benefited from 2 to 5 days of treatment with a variety of IIb/IIIa inhibitors, risk for MI or mortality was increased 15% at 30 days in treated women. In a subset of about 1/3 of participants in whom troponins were elevated, treatment appeared to reduce risk of mortality about 20 to 25% in both men and women. However, these findings were based on post-hoc subset analyses, the findings were not statistically significant and there does not appear to be a similar benefit in women with elevated CPKs.
| | | | New systematic reviews of these topics are feasible, but are unlikely to add important clinical information
2.08 | Thrombolysis | fair | yes | A good quality systematic review of 9 large randomized trials demonstrates that thrombolysis reduces the risk of 5-week mortality in women and men hospitalized for suspected acute MI about 15%.^48^
| | | | The systematic review, while large and well-conducted, was published in 1994. An updated systematic review might be useful by providing more complete estimates for the effects of thrombolysis in women, but is unlikely to alter the major findings.
2.09 | Ticlopidine | none | no | There is insufficient evidence in women to address this question.
2.10 | Clopidogrel | weak | no | Results from one large, good quality randomized trial suggest that 3 to 12 months of treatment with clopidogrel among women with acute coronary syndromes reduces risk of cardiovascular events and death about 20%.^51^
| | | | Prolonged treatment (3 to 12 months) with clopidogrel among women undergoing percutaneous coronary intervention reduced risk of cardiovascular events and death about 20% more than brief treatment (2 to 4 weeks).^50^
| | | | A systematic review of this topic is not feasible due to limited data.
2.11 | Angioplasty/stenting | weak | no | Evidence regarding the efficacy of PTCA to reduce the risk of CHD events in women is limited. Three available clinical trials included only 100 to 250 women.^49,^ ^52,^ ^53^ These trials suggest that PTCA relieves angina over the short term better than medical therapy, but there are few data regarding risk for CHD outcomes.
| | | | One small trial suggested that CABG is more effective than PTCA in relieving angina, but that CABG and PTCA have similar effects on risk for CHD events at one year after the procedure among women with symptomatic multi vessel coronary disease.^52^
| | | | No studies were identified that provided data on the efficacy of coronary stenting to reduce risk of CHD events in women.
| | | | Whether PTCA is superior to medical management or to CABG for management of CHD in women is very important and currently unanswered. However, there appears to be insufficient data to conduct a definitive systematic review of these questions.
2.12 | Coronary bypass surgery | weak | no | Evidence regarding the efficacy of CABG to reduce the risk of CHD events and death in women is limited. Observational evidence suggests that despite a high perioperative mortality rate (5.3%), 8-year survival is improved in women with double or triple vessel coronary disease who undergo CABG surgery compared to initial medical management.^60^
| | | | Randomized trials to compare the effectiveness of CABG and PTCA provide little evidence regarding the relative benefits of procedures in women. There is no clear evidence that either CABG or PTCA is superior with regard to mortality or CHD outcomes in women.^53^ CABG is associated with a higher peri-procedure mortality but appears more effective than PTCA in relieving angina and is less likely to be followed by additional revascularization procedures.
| | | | A systematic review of the findings of randomized trials regarding the efficacy of CABG for preventing CHD events in women is probably not feasible given the small numbers of trials and women participants.
3.01 | Hypertension | | | Results of four large cohort studies suggest that hypertension, especially diastolic hypertension, is associated with a 2 to 3-fold increased risk for coronary heart disease events in both men and women.^62–65^ A systematic review and meta-analysis would likely be feasible if additional data could be obtained from the placebo groups in large clinical trials of treatment for hypertension. Summary estimates of the effect of blood pressure on CHD risk could be important in helping identify women most likely to benefit from therapy.
| a. As a risk factor | weak | yes
| b. Treatment | good | yes | Two recent systematic reviews (one good- and one fair-quality) suggest that treatment of hypertension in women results in small reductions in risk of mortality (about 10%) and in CHD events (15–20%), but these benefits are primarily limited to women over age 55.^66,^ ^67^ African-American women seem to derive more marked benefit than white women with about 40% reduction in risk of death and CHD events.^67^ A large randomized trial in China suggests that Asian women derive marked benefit from treatment of hypertension.^69^ Repeating these two relatively recent systematic reviews is unlikely to add additional clinical information.
3.02 | Diabetes | | | Two recent systematic reviews (one good- and one fair-quality) found that risk of CHD events is increased in both men and women diabetics compared to non-diabetics.^70,^ ^71^ In women diabetics, the increased risk (RR = 2.6) appeared to be increased more markedly than in men diabetics (RR = 1.8).^71^ These summary risk estimates are based on findings that were not adjusted for differences in CHD risk factors between women and men. It is feasible to update these systematic reviews and to calculate comparable, risk factor-adjusted relative risks in men and women diabetics. An adjusted analysis may provide clinically and scientifically important evidence to determine if diabetes has more harmful effects on CHD risk or is more likely to be associated with other risk factors in women.
| a. As a risk factor | good | yes
| b. Treatment | none | no | There is insufficient evidence in women to address this question.
3.03 | Hyperlipidemia | | | Evidence regarding the association of abnormal lipoprotein levels and CHD risk in women is inconclusive. A fair quality systematic review suggests that the pattern of risk associated with hyperlipidemia in middle-aged women is similar to that for middle-aged men (increased risk for CHD mortality with higher total cholesterol, LDL-C and triglycerides, and with lower HDL-C).^79^ However, the pattern of risk among older women appears to be different than in men with increased risk for CHD mortality associated only with lower HDL-C and higher triglycerides. The meta-analysis is limited, however, because it is outdated, the literature search may not have been complete and unadjusted findings were summarized. An updated systematic review of the literature to address the association of lipoproteins and risk for CHD in women is feasible and would likely contribute important clinical information.
| a. As a risk factor | fair | yes
| b. Treatment | good | yes | A recent, good quality systematic review found that both women and men with hyperlipidemia and treated with statins had a 30% reduction in risk of major CHD events.^87^ Men also experienced a 20% reduction in total mortality. The effect on total mortality in women was not provided, perhaps due to the small number of women included in the trials. A recent large randomized trial among persons with CHD or at high risk for CHD found that treatment with simvastatin reduced risk of major vascular events about 25% in both men and women, regardless of pretreatment cholesterol level.^89^
| | | | The systematic review includes only clinical trials of statins for lipid-lowering, did not separately assess effectiveness for primary and secondary prevention, and provided only one outcome estimate specifically for women. An updated systematic review focused on the effects of lipid-lowering in women could provide important clinical information.
3.04 | Homocysteine | fair | yes | A fair quality systematic review of observational studies found that each 5 μmol/L increase in serum homocysteine level was associated with a 70% higher risk of CHD events among both men and women.^90^ This systematic review is relatively old and did not rate studies by degree of statistical adjustment for potential confounding variables. An updated systematic review of this topic is feasible and could provide important evidence.
| a. As a risk factor
| b. Treatment | none | no | There is insufficient evidence in women to address this question.
3.05 | C-reactive protein | weak | no | One large cohort study suggests that higher C-reactive protein levels are associated with increased risk for CVD events in women.^92,^ ^93^ A systematic review of this topic is not feasible due to lack of data.
| a. As a risk factor
| b. Treatment | none | no | There is insufficient evidence in women to address this question.
3.06 | Smoking | | | Based on the findings of 6 cohort studies, smoking appears to be associated with increased risk for CHD events in women, but no systematic review has quantified this increased risk or compared it to the increased risk among male smokers.^94–101^ A systematic review is feasible and could provide important information.
| a. As a risk factor | weak | yes
| b. Smoking cessation | fair | yes | A small systematic review of prospective cohort studies found that smoking cessation after MI was associated with about a 50% lower risk of death during 2 to 10 years of observation.^102^ This evidence is observational, and may be subject to the biases associated with this study design. Of particular concern, it is not clear that the results of the studies included in the systematic review were adjusted for differences in CHD risk factors between smokers who quit and those who continued to smoke. This systematic review, though published in 2000, included only studies published before 1996. Given this, and the fact that only 185 women are represented in the review, we rated the evidence as only fair and recommend an updated systematic review.
3.07 | Obesity | weak | yes | Based on the findings of five cohort studies, obesity appears to increase risk of CHD events in women, but the measure of obesity (weight, body mass index, skinfold thickness, or waist-hip ratio) that best predicts CHD risk in women is not clear.^59,^ ^105–112^ A systematic review of this topic is feasible and could be clinically useful.
| a. As a risk factor
| b. Weight reduction | none | no | There is insufficient evidence in women to address this question.
3.08 | Inactivity | | | It is not clear that inactivity is a risk factor for CHD events in women. Three cohort studies suggest that risk for mortality is increased with inactivity, but the evidence regarding the association of inactivity and risk for CHD events is mixed.^117–119^ The limited number of studies that provide data on women and variations in measurement of activity level limit the feasibility of a systemic review of this topic.
| a. As a risk factor | weak | maybe
| b. Exercise | none | no | There is insufficient evidence in women to address this question.
3.09 | Age as risk factor | weak | yes | Among men, cohort studies consistently show a 5% increase in risk of CHD events per year of age among white, African-American, Japanese-American, Hispanic and Native American men.^3,^ ^126^ Among women, increasing age seems to be a stronger risk factor for CHD events than among men, but the evidence is inconclusive due to the small number of women included in the studies. A systematic review of this topic is feasible and could provide important information regarding the effect of aging on CHD risk and on differences in this association between men and women.
3.10 | Age at menopause as a risk factor | weak | maybe | Evidence that earlier age at menopause is associated with increased risk for CHD events is weak because the number of studies identified was small and their results are not consistent.^127–129^ Several large community-based studies may provide sufficient data to perform a systematic review.
3.11 | Ethnicity as a risk factor | weak | maybe | Three cohort studies provide conflicting evidence regarding the association between race/ethnicity and coronary heart disease risk in women.^130–132^ Several large community-based studies may provide sufficient data to perform a systematic review.
3.12 | Socioeconomic status as a risk factor | weak | maybe | Three cohort studies suggest that socioeconomic status may be associated with CHD risk, but the evidence is weak due to the small number of studies identified and differences in the definition of socioeconomic status.^133–135^ Several large community-based studies may provide sufficient data to perform a systematic review.
4.0 | Utilization of tests, treatments and risk reduction | weak | yes | Cross-sectional studies suggest that men are more likely than women to undergo diagnostic testing^14,^ ^136–138^ and treatment for CHD,^12–14,^ ^60,^ ^139–163,^ ^163,^ ^165–167^ but that women are more likely to be treated for hypertension.^164^ Differences in utilization of tests and treatment might be explained by differences in severity of disease or comorbidities between men and women, or by overuse of tests and treatments in men. A systematic review of the literature is feasible and could provide clinically important information for treatment practice guidelines.
5.01 | Troponins | none | no | There is insufficient evidence in women to address this question.
5.02 | Creatine kinase | none | no | There is insufficient evidence in women to address this question.
5.03 | Myoglobin | none | no | There is insufficient evidence in women to address this question.

Note: Superscripted numbers correspond with citations on References, page 115.

As noted in Chapter 2, Methodology, Hierarchy of Evidence and Completeness of Searches, we are confident that we have identified all systematic reviews and major randomized trials, but some large cohort or cross-sectional studies may not have been identified. Importantly, we were only able to include the results of studies if the results were stratified by gender. Thus, many completed studies may have the potential to provide evidence on women if the study investigators are willing and able to produce stratified results.

A new systematic review was considered feasible when we identified at least 5 or more studies using similar methods that could likely be included in a systematic review. In some cases, even though a systematic review is feasible, it was not recommended if a recent, methodologically sound systematic review has already been completed or a definitive randomized trial has been completed or is under way.

### Findings by Level of Evidence and Key Question

Assuming that the strength of a risk factor is a different question from the effect of modifying the same risk factor, and that the effects of a treatment in primary prevention are different from the effect in secondary prevention, we reviewed the medical literature related to 42 questions pertaining to CHD in women. We found no data in women to address 13 of the questions, weak data to address 15, fair data for eight and good data to address six questions (Table 4).

Table 5. Findings by Level of Evidence and Recommendation for Systematic Review

| | Systematic Review Feasible
Level of Evidence | Number of Key Questions | no | yes | maybe
None | 13 | 13 | 0 | 0
Weak | 15 | 5 | 6 | 4
Fair | 8 | 0 | 8 | 0
Good | 6 | 1 | 5 | 0

Table 4. Findings by Level of Evidence and Key Question

[underlined: No Evidence] | | [underlined: Weak Evidence]
2.06 | heparin | 1.03 | calcium score
2.09 | ticlopidine | 2.01b | aspirin - primary prevention
2.02b | beta blockers - primary prevention | 2.10 | clopidogrel
2.03b | ace inhibitors - primary prevention | 2.11 | angioplasty/stenting
2.04 | calcium channel blockers | 2.12 | coronary artery bypass surgery
3.02b | diabetes - treatment | 3.01a | hypertension - risk factor
3.07b | obesity - weight reduction | 3.06a | smoking - risk factor
3.08b | inactivity - exercise | 3.07a | obesity - risk factor
3.04b | homocysteine - treatment | 3.08a | inactivity - risk factor
3.05b | C-reactive protein - treatment | 3.09 | age - risk factor
5.01 | troponins | 3.11 | ethnicity - risk factor
5.02 | creatine kinase | 3.12 | socioeconomic status - risk factor
5.03 | myoglobin | 3.10 | age at menopause - risk factor
| | 3.05a | C-reactive protein - risk factor
| | 4.0 | differences in utilization between men and women
[underlined: Fair Evidence] | | [underlined: Good Evidence]
1.01 | exercise tolerance testing | 2.01a | aspirin - secondary prevention
1.02 | exercise echocardiography | 2.03a | ACE inhibitors-secondary Prevention
2.02a | beta-blockers for secondary prevention | 2.05 | nitrates
2.07 | IIb/IIIa drugs | 3.01b | hypertension - treatment
2.08 | thrombolysis | 3.02a | diabetes - risk factor
3.03a | hyperlipidemia - risk factor | 3.03b | hyperlipidemia - treatment
3.06b | smoking cessation
3.04a | homocysteine - risk factor

### Summary of Major Findings

There was fair data suggesting that the accuracy of exercise EKG and exercise thallium testing (using either conventional or SPECT imaging) for CHD in women is poor and that exercise echocardiography might be more accurate.

While evidence for many treatments was lacking, we found fair or good data to suggest that beta-blockers, aspirin and angiotensin converting enzyme inhibitors reduce risk for CHD events in women with coronary disease. Good evidence suggests that nitrates do not reduce risk for CHD events in women with known heart disease. There was fair evidence to suggest that IIb/IIIa drugs given to women undergoing percutaneous revascularization result in a reduced risk of CHD events and need for repeat revascularization. Fair evidence also suggests that IIb/IIIa drugs given to women suffering acute coronary syndromes result in increased mortality. This was the only treatment for which there appeared to be an interaction by gender: men treated with IIb/IIIa drugs during acute coronary syndromes appear to benefit.

We found only weak evidence linking most of the risk factors of interest and CHD risk in women. For the most part, this is because all of the studies addressing the strength of risk factors are observational, and very few good quality systematic reviews have been completed. However, there was fair evidence to suggest that hyperlipidemia and hyperhomocysteinemia are risk factors for CHD in women and good evidence that diabetes is a risk factor. Risk factors seem to be equally strong in men and women with the possible exceptions of age, diabetes, and specific lipoproteins. Increasing age seems to be a stronger risk factor for CHD events in women than men, but the evidence is inconclusive due to the small number of women included in the studies. Diabetes may be a stronger risk factor for CHD in women than in men and patterns of risk associated with lipoprotein subfractions appear to differ in men and women.

There was fair or good evidence to suggest that smoking cessation after MI and treatment of hypertension and of hyperlipidemia lower the risk for CHD events in women. In contrast, we found no evidence for the effectiveness of other interventions to modify risk factors in women.

Available studies suggest that men are more likely than women to undergo diagnostic testing and treatment for CHD, but that women are more likely to be treated for hypertension. These observed differences may be due to inadequate control for differences in severity of disease and comorbidities in men and women or result from overtreatment in men.

We found no evidence to address the prognostic value of troponins, creatine kinase or myoglobin in women with ischemia.

In general, no evidence addressed differences in the accuracy of diagnostic tests, strength of risk factors, effects of treatment or prognostic value of markers for ischemia in women of different races or ethnicity. The only evidence regarding differences by ethnicity suggests that African American women may benefit more from treatment of hypertension than white women.