# Appendix H: Abbreviations and Acronyms

ACE | angiotensin converting enzyme
AHRQ | Agency for Healthcare Research and Quality
β-blockers | beta-blockers
CABG | coronary artery bypass grafting
CHD | coronary heart disease
CKMB | creatinine kinase myocardial bands
CHF | congestive heart failure
CVD | cardiovascular disease
CI | confidence interval
DTS | Duke Treadmill Score
ECHO | echocardiography
EKG | electrocardiogram
EPC | Evidence-based Practice Center
ETT | exercise treadmill test
HDL | high density lipoprotein
HDL-C | high density lipoprotein cholesterol
LDL | low density lipoprotein
LDL-C | low density lipoprotein cholesterol
Lp(a) | lipoprotein a
Mg | milligrams
MI | myocardial infarction
Mmol | millimole
MRC/BHF | Medical Research Council/British Heart Foundation
N | number
NA | not available
NHLBI | National Heart Lung and Blood Institute
OR | odds ratio
PCI | percutaneous coronary intervention
PTCA | percutaneous coronary angioplasty
SES | socioeconomic status
SPECT | single photon emission computed tomography
RR | relative risk

[underlined: Names of studies:]
4S | Scandinavian Simvastatin Survival Study
AFCAPS/TEXCAPS | Air Force/Texas Coronary Artherosclerosis Prevention Study
AIRE | Acute Infarction Ramipril Efficacy
ARIC | Atherosclerosis Risk in Communities
BARI | Bypass Angioplasty Revascularization Investigation
BENESTENT | Belgian Netherlands Stent study
BBPP | Beta Blocker Pooling Project
CABRI | Coronary Angioplasty versus Bypass Revascularisation Investigation
CARDIA | Coronary Artery Risk Development in Young Adults
CARE | Cholesterol and Recurrent Events trial
CCS | Chinese Cardiac Study
CHS | Cardiovascular Health Study
CIBIS, CIBIS II | Cardiac Insufficiency Bisoprolol Study
COPERNICUS | Carvedilol Prospective Randomized Cumulative Survival Study
CURE | Clopidogrel in Unstable Angina to Prevent Recurrent Events Study
Consensus | Cooperative New Scandinavian Enalapril Survival Study
DOM | Diagnostisch Onderzoek Mammacarcinoom (Diagnostic Investigation of Mammary Cancer) ???
EPIC | Evaluation of 7E3 for the Prevention of Ischemic Complications EPILOG
EPILOG | Evaluation of Percutaneous Transluminal Coronary Angioplasty to Improve Long-Term Outcome with Abciximab Glycoprotein IIb/IIIa Blockade
EPISTENT | Evaluation of Platelet IIb/IIIa Inhibitor for Stenting
FHS | Framingham Heart Study;
FTT | Fibrinolytic Therapy Trialists' Collaborative Group
GISSI | Gruppo Italiano per lo Studio della Sopravvivenza nell'Infarto Miocardico
GUSTO-I | Global Utilization of Strategies to Open Occluded Coronary Arteries Trial I
GUSTO-IV ACS | Global Utilization of Strategies to Open Occluded Coronary Arteries Trial IV in Acute Coronary Syndromes
HHP | Honolulu Heart Program
HOPE | Hypertension Optimal Treatment
INDANA | INdividual Data ANalysis of Antihypertensive Intervention Trials
ISIS-2 | Second International Study of Infarct Survival
ISIS-4 | Fourth International Study of Infarct Survival) Collaborative Group
LIPID | Long-term Intervention with Pravastatin in Ischaemic Disease
MERIT-HF | Metoprolol Extended-Release Randomized Intervention Trial in Heart Failure
MRFIT | Multiple Risk Factor Intervention Trial
MUSIC | Multicenter Ultrasound Stenting In Coronary study
NHANES | National Health and Examination Survey
NMRI | National Registry of Myocardial Infarction
OASIS | Organization to Assess Strategies for Ischemic Syndromes
PCI-CURE | Percutaneous Coronary Intervention Substudy of Clopidogrel in Unstable Angina to Prevent Recurrent Events Study
POSCH | Program on the Surgical Control of the Hyperlipidemias
PAMI | Primary Angioplasty in Myocardial Infarction
PARAGON | Platelet IIb/IIIa Antagonism for the Reduction of Acute Coronary Syndrome events in a Global Organization Network
PHS | Physicians' Health Study
PR | Puerto Rico Heart Health Program
PRISM | Platelet Receptor Inhibition in Ischemic Syndrome Management
PRISM-PLUS | Platelet Receptor Inhibition in Ischemic Syndrome Management in Patients Limited by Unstable Signs and Symptoms
PURSUIT | Platelet Glycoprotein IIb/IIIa in Unstable Angina: Receptor Suppression using Integrilin Therapy
RITA | Randomised Intervention Treatment of Angina
SAVE | Survival and Ventricular Enlargement
SHS | Strong Heart Study
SOLVD | Studies of Left Ventricular Dysfunction
Syst-China | Systolic Hypertension in China Study
TRACE | Trandolapril in Cardiac Evaluation
WOSCOPS | West of Scotland Coronary Prevention Study