# Appendix G: Evidence Reports (N = 9)

1. Moderately elevated blood pressure. A report from SBU, the Swedish Council on Technology Assessment in Health Care. J Intern Med Suppl 1995;737:1–225.
2. An evaluation of beta-blockers, calcium antagonists, nitrates, and alternative therapies for stable angina. Evid Rep Technol Assess (Summ) 1999(10):1–2.
3. Berry E, Kelly S, Hutton J, Harris KM, Roderick P, Boyce JC, et al. A systematic literature review of spiral and electron beam computed tomography: with particular reference to clinical applications in hepatic lesions, pulmonary embolus and coronary artery disease. Health Technol Assess 1999;3(18):i–iv, 1–118.
4. Berry E, Kelly S, Hutton J, Lindsay HS, Blaxill JM, Evans JA, et al. Intravascular ultrasound-guided interventions in coronary artery disease: a systematic literature review, with decision-analytic modelling, of outcomes and cost-effectiveness. Health Technol Assess 2000;4(35):1–117.
5. Heidenreich P, Go A, Melsop K, et al. Prediction of risk for patients with unstable angina. Evidence Report/Technology Assessment No. 31(prepared by the UCSF-Stanford Evidence-based practice Center under Contract No. 290-97-0013). AHRQ Publication No. 01-E001. Rockville, MD: Agency for Healthcare Research and Quality. December 2000.
6. Lau J, Ioannidis J, Balk E, et al. Evaluation of Technologies for Identifying Acute Cardiac Ischemia in Emergency Departments. Evidence Report/technology Assessment Number 26. (Prepared by the New England Medical Center Evidence-based Practice Center under Contract No. 290-97-0019) AHRQ Publication No. 01-Eoo6, Rockville, MD: Agency for Healthcare Research and Quality. May 2001.
7. McDonagh MS, Bachmann LM, Golder S, Kleijnen J, ter Riet G. A rapid and systematic review of the clinical effectiveness and cost-effectiveness of glycoprotein IIb/IIIa antagonists in the medical management of unstable angina. Health Technol Assess 2000;4(30):1–95.
8. Meads C, Cummins C, Jolly K, Stevens A, Burls A, Hyde C. Coronary artery stents in the treatment of ischaemic heart disease: a rapid and systematic review. Health Technol Assess 2000;4(23):1–153.
9. Pignone M, Phillips C, Lannon C, et al. Screening for Lipid Disorders. Systematic Evidence Review. Research Triangle Institute - University of North Carolina, Evidence-based Practice Center. September 13, 2000.