# Appendix B: Literature Search Terms

The following terms were used to define the outcome for all questions.

| Search Terms
[underlined: Outcome] | cardiovascular diseases or heart diseases or heart or cardiovas* or cardiac* or coronary or myocardial
[underlined: Publication Type] | meta-analysis or meta-analy* or metaanaly* or metanaly* or review or overview and systematic
or
| methodologic* or evidence* or Medline
[underlined: Limits] | publication date 1985 to 2002, English language, human

The following terms were used to define the predictor for each specific question.

Question
1.01 | exercise test* or stress test* or exercise electrocardio*
| or exercise tolerance test*
1.02 | exercise echocardio* or coronary disease, ultrasonography or dobutamine, diagnostic or exercise test* or stress test*
1.03 | coronary artery calcification or electron beam tomography or coronary arteriosclerosis, radiography or coronary disease, radionuclide imaging or heart radionuclide imaging or spect or tomography, x-ray computed
2.01 | aspirin
2.02 | adrenergic beta-antagonists or beta-blockers or beta blockers or B-blockers
2.03 | angiotensin converting enzyme inhibitors or angiotensin-converting enzyme inhibitors or angiotensin receptor blockers
2.04 | calcium channel blocker*
2.05 | nitrate* or isosorbide mononitrate or isosorbide dinitrate
2.06 | heparin or low molecular weight heparin
2.07 | glycoprotein IIb-IIIa or glycoprotein IIb/IIIa or abciximab or tirofiban or eptifibatide
2.08 | fibrinolytic agents or thrombolytics or thrombolysis or myocardial infarction, drug therapy or streptokinase or tissue plasminogen activator or myocardial reperfusion, methods
2.09 | ticlopidine
2.10 | clopidogrel
2.11 | angioplasty, transluminal, percutaneous coronary or stent
2.12 | coronary artery bypass graft surgery or CABG
3.01 | hypertension or antihypertensive agents or vascular resistance
3.02 | diabetes or diabetic*
3.03a | hyperlipidemia or cholesterol or LDL* or HDL* or VLDL or LPA or lipoprotein* or triglycerides or triglycerid*
3.03b | lipid lowering agents or anticholesteremic agents or antilipemic agents or hyperlipidemia, therapy
3.04 | homocysteine or folic acid or pyridoxine
3.05 | c-reactive
3.06 | tobacco or smoking or nicotine
3.07 | obesity or body weight or weight
3.08 | inactiv* or sedentary
3.09 | aging or age factors or age or ageing or aging
3.10 | menopause
3.11 | racial stocks or ethnic groups or race
3.12 | socioeconomic factors or income*
4.0 | comparative study, male and female, sex factors or sex characteristics
5.01 | troponin or troponin-t
5.02 | creatine kinase or ck or ck-mb
5.03 | myoglobin