# Appendix A: Technical Expert Advisory Group and Expert Consultants

Technical Expert Advisory Group
Noel Bairey-Merz, MD | Cedars-Sinai Medical Center
Elizabeth Barrett-Connor, MD | University of California, San Diego
Robert Califf, MD | Duke University
Curt Furberg, MD | Wake Forest University
Lee Goldman, MD | University of California, San Francisco
Paul Heidenreich, MD | Stanford University
Mark Hlatky, MD | Stanford University
JoAnn Manson , MD, DrPH | Harvard Medical School, Brigham and Women's Hospital
Sally Shumaker, PhD | Wake Forest University
Marcia Stefanick, PhD | Stanford University
Nanette Wenger, MD | Emory University
Expert Consultants
Roger S. Blumenthal, MD, FACC | Johns Hopkins University
Lori Mosca, MD, MPH, PhD | Columbia University

Advice was also solicited from representatives of Partner Organizations, including:

Robert Christenson, PhD | American Association for Clinical Chemistry
Sharonne N. Hayes, M.D., F.A.C.C. | American College of Cardiology
Rosalind Fabunmi, Ph.D. | American Heart Association
Rose Marie Robertson, MD | American Heart Association
Mary Norine Walsh, MD | American College of Cardiology
Mary Winston, Ed.D. | American Heart Association