# Appendixes

Appendix A: Technical Expert Advisory Group and Expert Consultants

Appendix B: Literature Search Terms

Appendix C: Full Text Article Abstraction Form

Appendix D: Articles Eligible for Full-Text Review by Key Question

Appendix E: Cost-effectiveness Analyses and Decision Analyses Articles (N = 21)

Appendix F: Clinical Practice Guidelines (N = 43)

Appendix G: Evidence Reports (N = 9)

Appendix H: Abbreviations and Acronyms