# Evidence Tables

Evidence Table 1. Epidemiology of Dysphagia in the USA

Study author | Study design | Number of subjects | Mean age | Population being studied | Diagnosed symptoms | Diagnostic method | Includes LTC population? | Diagnosed occurrence overall | Miscellaneous results
Layne, Losinski, Zenner et al., 1989 | CS | 513 | NR | Hospital patients: nursing home unit | Dysphagia | Fleming Index of Dysphagia: at least 10 of 18 questions positive | Yes 25.1% (129/513) | NR | All hospital patients: Definite dysphagia: 3.7% (19/513) Probable dysphagia: 12.9% (66/513) Possible dysphagia: 18.3% (94/113) Nursing home unit: Definite 3.1% (4/129) Probable: 31% (40/113) Possible: 31.8% (41/113)
Groher and Bukatman, 1986 | Survey | 1,072 | NR | Hospital population | Dysphagia | BSE+ and/or history of aspiration pneumonia with diagnosis of neuro disease | No | 12.5%
Siebens, Trupe, Siebens et al., 1986 | Questionnaire and exam | 240 | 81.7 | Nursing home residents | Dependent eating | Questionnaire (all pts) and BSE by physician and SLT (131 pts) | Yes 100% | NR | Dependent eaters: 46.7% (112/240) Abnormal pharyngeal function 29.9% (32/107) Abnormal oral-motor function 26.2% (33/126) 60.5% of dependent eaters have observed normal pharyngeal function 19.5% of independent eaters have abnormal observed pharyngeal function
Baum and Bodner, 1983 | Examination | 120 | NR | Community-dwelling elderly population | Swallowing problems | BSE requiring at least 3 of 6 symptoms | NR | 17 (14.2%) | Men: 13.4% (9/67) Women: 15.1% (8/53)

Evidence Table 2. Epidemiology of Stroke in the USA

Study author | Study design | Number of subjects | Mean age | Population being studied | Diagnostic method | Includes LTC population? | Annual incidence overall | Miscellaneous results
Sacco, Boden-Albala, Gan et al., 1998 | Mixed | 51,215 | NR | General | CT or MRI | NR | NR | Avg annual age-adj incidence: Whites: 93/100k Blacks: 223/100k Hispanics: 196/100k
Barker and Mullooly, 1997 | Historical cohort study | 291 (period 3: 1981-85) | NR | Elderly in community health plan | WHO criteria | NR | Men: 953/100,000 person-years Women: 736/100,000 person-years | Case fatalities: 6% (16/275) 1 week 18% (50/275) 1 mo 32% (87/275) 6 mo 36% (99/275) 1 year
Brown, Whisnant, Sicks et al., 1996 | RCS | NR | NR | General population | WHO criteria | NR | Age- and sex-adj. (1985-89): 145/100,000 Men: 174/100 k Women: 122/100 k
McGovern, Burke, Sprafka et al., 1992 | Hospital discharge survey | NR | NR | General population | WHO criteria | NR | Age-adj. (1985): Men: 828.3/100 k unvalidated 436.2/100 k validated Women: 551.3/100 k unvalidated 287.4/100 k validated
Modan and Wagener, 1992 | RCS | NR | NR | General population, USA | NR | NR | Unadjusted: 312.1/100,000 Age-adjusted: 289.7/100,000
Kittner, White, Losonczy et al., 1990 | RCS | 9,117 | NR | General | NR: Hospital or nursing home record or death certificate diagnosis. No TIA | Yes | NR | 10 yr stroke incidence for 65-74 yr olds: Men: Black: 14.6% White: 12.6% Women: Black: 12.1% White: 9.2%

Evidence Table 3. Epidemiology of Dysphagia in Stroke

Study author | Study design | n | Mean age | Diagnostic method | Population being studied | Disease/ disorder being studied | Time post-stroke | How disease confirmed | Includes LTC population? | Reported occurrence | Miscellaneous results
Daniels, Brailey, Priestly et al., 1998 | CS | 55 | 66 | BSE, VFSS within 5 days of admission | CVA in hospital | Dysphagia, aspiration | Within 5 days | CT or MRI | NA | Dysphagia: 65.5% (36/55) Aspiration: 38.2% (21/55) Silent aspiration: 25.5% (14/55)
Nilsson, Ekberg, Olsson et al., 1998 | CCS | 100 | 77 (med.) | Self-report of eating/drinking ability, feeling of food sticking, coughing during or after swallowing, within 24 hours of CVA | CVA in hospital | Dysphagia | Within 1 day | "Neurologic exam;" some CT and MRI (61) | NR | 19.4% (14/72)
Daniels, McAdam, Brailey et al., 1997 | CCS | 59 | 66 | BSE and VFSS | CVA in hospital | Dysphagia; aspiration | Within 5 days | CT or MRI | NA | Dysphagia: 74.6% (44/59) Aspiration: 32.2% (19/59) | 68.4% (13/19) of aspirators did so silently
Smithard, O'Neill, England et al., 1997 | CS | 121 | NR | BSE on admission by doctor; VFSS within 3 days (95 pts) | CVA in hospital | Dysphagia | Within 1 day | WHO criteria | NA | 50.4% (61/121) | Day 3 BSE: 1.5% (35/111) by doctor 30.8% (32/104) by SLT VFSS: 22.1% (21/95) aspirated
Gottlieb, Kipnis, Sister et al., 1996 | CCS | 180 | 74 | BSE with 50-ml water swallow; one cough = dysphagia | CVA in rehab | Dysphagia | NR | NR | NA | 28% (50/74) | 18% of dysphagics got pneumonia 15.9% of those on altered diet got pneumonia
DePippo, Holas, and Reding, 1994 | CCS | 139 | 71 | Burke Dysphagia Screening Test (BDST) on admission | CVA in hospital | Dysphagia | 5 wks (mean) | CT or MRI | NR | 59.0% (82/139)
Kidd, Lawson, Nesbitt et al., 1993 | CS | 60 | 72 | Water swallow, VFSS within 3 days of admission | CVA in hospital | Dysphagia, aspiration | Within 3 days | NR | NA | Dysphagia: 41.7% (25/60) on BSE 90% (54/60) on VFSS Aspiration: 41.7% (25/60) | At day 7: Dysphagia 19.6% (10/51) Aspiration 17.6% (9/51) At day 14: 10.8% (4/37) dysphagic and aspirating At 3 months: Dysphagia 7.1% (3/42) Aspiration 7.9% (3/38)
Axelsson, Asplund, Norberg et al., 1989 | CCS | 104 | NR | Structured observation form, 70 variables, filled out by 2 nurses | CVA in hospital | Dysphagia | 3 wk period | NR | NA | 30% | In pts staying longer than 21 days: 63% dysphagic
Barer, 1989 | CS | 357 | NR | BSE | CVA in hospital | Swallowing problems | Within 1 day | NR | NA | Day 1: 29.4% (105/357) | All patients: Week 1: 15.5% (48/309) Month 1: 2.2% (6/277) Month 6: 0.4% (1/248) >70 yrs only: Day 1: 35.5% (66/186) Week 1: 17.6% (28/159) Month 1: 3.8% (5/132) Month 6: 0.9% (1/112)
Gordon, Hewer, and Wade, 1987 | CCS | 91 | 70 (med.) | Water swallow test: 50-ml, twice; every 48 hrs for 2 wks after CVA, then twice a week until dysphagia disappeared. Most assessed within 4 days | CVA in hospital | Dysphagia | Within 13 days | "Basic neuro-logical exam;" some CTs | NR | 45.1% (41/91) | No significant interaction between hemisphere of CVA and incidence of dysphagia
Wade and Hewer, 1987 | CS | 452 | NR | Water swallow test, unspecified, within 7 days of CVA | CVA | Swallowing problems | Within 7 days | WHO criteria | NR | | 14.2% (64/452) choked 6.2% (28/452) abnormal swallow pattern 22.6% (102/452) abnormally slow swallow

Evidence Table 4. Epidemiology of Parkinson's Disease in the USA

Study author | Study design | Number of subjects | Mean age | Population being studied | Diagnostic method | Includes LTC population? | Point or range prevalence | Prevalence overall | Annual incidence | Comments
Mitchell, Kiely, Kiel et al., 1996 | Survey | 5,020 | NR | Nursing home residents | NR | Yes 100% | R? 1991-92 | 6,800/100k Primary PD only: 2,250/100k Secondary PD only: 4,520/100k | NR | 66.8% of these were a secondary diagnosis
Mayeux, Marder, Cote et al., 1995 | Survey, registry | NR | NR | General population | At least 1 of 3 basic symp-toms + L-dopa effects | Yes | P: 12/31/89 | All ages: 106.9/100k Age 65+: 790/100k | Crude: 13/100k person-years | Prevalence rates are not age- or sex-adjusted
Lilienfeld, Sprafka, Pham et al., 1991 | Retrospective case review | NR | NR | General population < 75 yrs | NR | NR | NA | Men: 65/100k Women: 45/100k | NR | Age-adjusted to 1970 population

Evidence Table 5. Epidemiology of Dysphagia in Parkinson's Disease

Study author | Study design | Number of subjects | Mean age | How disease confirmed | Disease severity, with measurement tool | Length of illness (mean) | Diagnosed symptoms | Diagnostic method | Includes LTC population? | Diagnosed occurrence | Miscellaneous results
Coates and Bakheit, 1997 | CS | 48 | 69.9 | NR | 1.4 mean UPDRS | 6.7 yrs | Dysphagia | Chicago Assessment Scale (BSE) | NR | NR | 81.1% scored <5 on at least 1 item on Chicago Assessment Scale. Mostly mild impairment. Significant correlation btwn severity of disease and severity of dysphagia
Fuh, Lee, Wang et al., 1997 | Random case series | 19 | 68.4 | At least 2 of 3 cardinal symptoms + levodopa response | 1.9 mean Hoehn and Yahr | 3.2 yrs | Swallowing problems | MBS with and without L-dopa | NR | NR | Without L-dopa: Abnormal MBS: 63.2% (12/19) Aspiration: 15.8% (3/19) With L-dopa: Abnormal MBS: 31.6% (6/19) Aspiration: 5.3% (1/19)
Edwards, Quigley, Harned et al., 1994 | Case-control | 20 (13, 7) | 66.6, 67.0 | NR | 22.2 mean UPDRS | 5.3 yrs | Dysphagia | GI survey; videoesophagram | NR | PD pts: 76.9% (10/13) Controls: 14.3% (1/7) | On video: Oral dysphagia 4 Pharyngeal dysphagia: 1 Esophageal dysphagia 8 No sign. Diffs from controls
Hartelius and Svensson, 1994 | Survey, self-report | 258 | NR | Not done | NR | NR | Swallowing problems | 25 questions, forced-choice | NR | NR | Swallowing problems often: 18% Swallowing liquids often a problem: 15% Choking often a problem: 21%
Wintzen, Badrising, Roos et al., 1994 | PCS | 22 | 62.7 | NR | 1.5-4 Hoehn and Yahr; 1.4 mean UPDRS | 6.7 yrs | Dysphagia | Swallowing Function Questionnaire; VFSS | NR | Questionnaire: 72.7% (16/22) VFSS: 81.1% (18/22) | No correlation between severity of disease and number of dysphagia symptoms
Singer, Weiner, and Sanchez-Ramos, 1992 | Interview | 48 | 65.9 | NR | 1-3 Hoehn and Yahr | 7.8 yrs | Dysphagia | Questionnaire | NR | 22.9% (11/48) | Significantly higher incidence of dysphagia in PDs than in control group (6.3%), p<0.05
Bushmann, Dobmeyer, Leeker et al., 1989 | CS | 20 | 65.7 | NR | NR | NR | Dysphagia | Questionnaire; MBS without L-dopa; MBS with L-dopa | NR | Subjective: 35% (7/20) MBS w/o L-dopa: Dysphagia: 75% (15/20) Aspiration: 15% (3/20) | MBS w/ L-dopa: 5/15 dysphagics demonstrated mild to marked improvement

Evidence Table 6. Epidemiology of Alzheimer's Disease in the USA

Study author | Study design | Number of subjects | Mean age | Population being studied | Diagnostic method | Includes LTC population? | Point or range prevalence | Prevalence overall(per 100,000) | Prevalence in LTC | Prevalence in community population | Annual incidence | Comments
Hendrie, Osuntokun, Hall et al., 1995 | Cross-sectional interview | 2318 | 65+ | African-American elderly | Criteria of Nat'l Institute of Neurological and Communicative Disorders and Stroke and the Alzheimers Disease and Related Disorders Assn. | Yes (NR) | R: 1992-93 | Age-adj: 6,240 Age 65-74: 1,580 Age 75-84: 8,020 Age 85+: 28,850 | 65-74: 25,000 75-84: 47,200 85+: 68,400 | 3,690 | NR | Comparison with Nigerians excluded for our purposes
Beard, Kokmen, Offord et al., 1991 | Retrospective clinical records | NR | NR | General | DSM-IIIR | Yes (NR) | P: 1/1/80 | All ages: Age-adj: 270.4 Age/sex-adj: 259.8 Age 65+: age-adj: 2741.5 age/sex-adj: 2634.1 | NR | NR | NR | Adjusted to 1980 U.S. white population

Evidence Table 7. Epidemiology of Dysphagia in Alzheimer's Disease

Study author | Study design | N | Mean age | How disease confirmed | Severity of disease | Length of illness (mean) | Includes LTC population? | Number LTC (%) | Number living at home (%) | Diagnosed symptom | Diagnostic method | Diagnosed occurrence
Horner, Alberts, Dawson et al., 1994 | CS | 25 | 74 | McKhann et al. 1984 criteria of "probable AD." | 16 moderate 9 severe | 3.6 yrs | Yes | 44% (11/25) | 56% (14/25) | Dysphagia Aspiration | VFSS | 84% (21/25) 24% (6/25)

Evidence Table 8. Epidemiology of Other Neurological Disorders in the USA

Study author | Study design | Number of subjects | Mean age | Population being studied | Disease/disorder being studied | Diagnostic method | Includes LTC population? | Point or range prevalence | Prevalence (per 100,000) | Incidence (per 100,000) | Comments
Bower, Maraganore, McDonnell et al., 1997 | RCS | 2,739 | NR | General | MSA | Consensus of Committee of the American Autonomic Society and the American Academy of Neurology (1996) | Yes | NA | NR | All ages: 0.6 Age 50+: 3.0 | Does not include MSA without symptoms of parkinsonism
Bower, Maraganore, McDonnell et al., 1997 | RCS | 2,739 | NR | General | PSP | Criteria of Collins et al. (1995) | Yes | NA | NR | All ages: 1.1 Age 50+: 5.3 | Subset of parkinsonism
McGuire, Longstreth, Koepsell et al., 1996 | C-C | ~2.5 million | NR | General | ALS | Progressive muscular atrophy or bulbar symptoms w/o other attributable diagnoses | NR | NA | NR | Crude overall: 1.8 Age-adjusted: men: 2.1 women: 1.9 | Age-specific rates given as well
Kokmen, Ozekmekci, Beard et al., 1994 | RCS | ~106,000 | NR | General | HD | Symptoms: progressive choreiform movement disorder, progression of cognitive, behavioral or emotional dysfunction + inheritance | Yes | P: 1/1/90 | Total: 1.9 Women: 1.8 Men: 2.0 | 1970-89 avg annual: Both sexes: 0.2 Women: 0.3 Men: 0.1 | Definite cases only. Mayo Clinic records linkage system
Annegers, Appel, Lee et al., 1991 | Record review | NR | NR | General | ALS | NR | NR | P: 1/1/89 | All ages: 3.12 Age 75+: 2.77 | All ages: 1.14 75+: 4.01 Women: 1.03 Men: 1.27 | A lot of neurologists declined to participate; therefore, these rates may be underestimated
Hopkins, Indian, Pinnow et al., 1991 | Survey Record review Exam | ~12,000 | NR | General | MS | Criteria of Poser et al. (1983) | NR | P: 6/1/87 | 112 | NR | "Probable" or "definite" MS only. Possible area of high prevalence
Lilienfeld, Sprafka, Pham et al., 1991 | RCS | NR | NR | General | MND | NR | NA | P: 1/1/85 | All ages: 170.8 Age 65+: 265.7 Men: 79.8 Women: 231.9 | 1975-84: 6.2 | Significantly higher prev for women than for men; 98% white
Wynn, Rodriguez, O'Fallon et al., 1990 | RCS | NR | NR | General | MS | Criteria of Poser et al. (1983) | NR | | Men: 6 Women: 6 | NR | Age-adjusted to 1970 population
Helmick, Wrigley, Zack et al., 1989 | Survey | ~24,400 | NR | General | MS | Criteria of Poser et al. (1983) | NR | P: 9/1/85 | 70.1 | NR | "Probable" or "definite" cases only. Possible cluster area. Mean age of onset = 29
Golbe, Davis, Schoenberg et al., 1988 | Survey/Exam | NR | NR | General | PSP | Authors' set of criteria | NR | P: 5/1/86 | All ages: 1.39 Aged 55+: 7.00 Women: 1.23 Men: 1.53 | NR | Counties included are 94.3% caucasian

Evidence Table 9. Epidemiology of Dysphagia in Other Neurological Disorders

Study author | Study design | N | Mean age | Population being studied | Diagnostic method | How disease confirmed | Disease Severity and measurement tool | Length of illness (mean) | Diagnosed symptoms | Includes LTC population? | Diagnosed occurrence overall | Miscellaneous results | Comments
Litvan, Sastry, and Sonies, 1997 | C-C | 27 cases 28 controls | 64.9 (cases) | PSP | NIH Swallow Questionnaire; ultrasound of swallow; MBS | NINDS-SPSP guidelines | 3.4 mean Hoehn and Yahr | 52 mos | Aspiration | NR | 55.6%(15/27 cases) 18.5%(5/27 cases) | PSP patients had a signif. greater no. of swallow com-plaints than controls
Hartelius and Svensson, 1994 | Survey, self-report | 203 | NR | MS | 25 questions, forced-choice | Not done | NR | NR | Swallowing problems | NR | NR | Swallowing problems often: 16%; Swallowing liquids often a problem: 13%; Choking often a problem: 27% | Not just elderly; self-selection bias
Leighton, Burton, Lund et al., 1994 | CCS | 92 | NR | MND | NR | NR | NR | NR | Swallowing problems | NR | 51.2% | Swallow status moderate or poor: BP 89% PMA 45% ALS 29% | Not exclusively elderly; Graded excellent/good/moderate/ poor
Kagel and Leopold, 1992 | CS | 35 | 45.5 | HD | VFSS: oral/pharyngeal/esophageal; variety of bolus vols and textures. | NR | Shoulson and Fahn scale II-IV | 6.6 yrs | Dysphagia | NR | 100% | Hyperkinetic dysphagia: 29/30 oral 27/30 pharyngeal Hypokinetic: 5/5 oral 5/5 pharyngeal. Supraglottic aspiration: 2 (hypo) Glottic aspira-tion: 2 (hyper) | Not exclusively elderly
Mayberry and Atkinson, 1986 | Question-naire sent to members of MND Assn. | 310 | NR | MND | Questionnaire, self-report | | NR | NR | Dysphagia | NR | | 73% report chewing or swallowing problems 71% report just swallowing problems 58.4% report aspiration into lungs | Self-report selection bias; self-report bias of recognition of symptoms; how recognize aspiration?

Evidence Table 10. Stroke Patients with Dysphagia who Become Malnourished

Study author | Study design | N | How chosen | Mean age | Care setting | Disease | How disease confirmed | Time post-stroke | Diagnostic method | Treatment | Reported outcome | Time frame | Result | Comments
Davalos, Ricart, Gonzalez-Huix et al., 1996) | CS | 104 | Consecutive strokes | 66 | Hospital | CVA | CT | <24 hrs | Water swallow | Enteral feeding | Malnutrition | 1 wk | 48.4% (15/31) | Spain

Evidence Table 11. Cases of Neurologic Dysphagia that Present with Aspiration

Study author | Study design | N | How chosen | Mean age | Care setting | Disease(s) | How disease confirmed | Time post-stroke | Diagnostic method | Reported outcome | Time frame | Result | Comments
Daniels, McAdam, Brailey et al., 1997 | CCS | 44 | Consecutive strokes | 66 | Hospital | CVA | CT or MRI | w/in 5 days | BSE and MBS | Aspiration | NA | 43.2%(19/44)
Croghan, Burke, Caplan et al., 1994 | RCS | 33 | Underwent VFSS | 68.6 | Nursing home | CVA, PD, CP, head injury, cleft palate | NR | NR | VFSS | Aspiration | Up to 1 yr. | 66.7%(22/33) | Pneumonia not specifically aspiration
Holas, DePippo, and Reding, 1994 | CCS | 114 | Stroke + dysphagia | 71.6 | Stroke rehab unit | CVA | CT or MRI | 4 wks | VFSS | Aspiration | NR | 53.5%(61/114) | 44 silent aspiration; diagnosed with VFSS
Bleach, 1993 | RCS | 120 | Neurologic with dysphagia | 63.8 | Dysphagia clinic | Neurologic | NR | NA | NR | Aspiration | NA | 48.3%(58/120) | CVA: 50% (23/46)
Kidd, Lawson, Nesbitt et al., 1993 | CCS | 54 | Consecutive stroke | 72 | Hospital | CVA | NR | w/in 3 days | VFSS | Aspiration | 3 days | 46.3%(25/54)
Chen, Peele, Donati et al., 1992 | CS | 41 | Neurologic dysphagia | 55 | NR | Neurologic: ALS, PD, other | NR | NA | VFSS | Aspiration | NA | 44.1%(15/34)

Evidence Table 12. Cases of Stroke that Present with Aspiration

Study authors | Study design | N | How chosen | Mean age | Care setting | How disease confirmed | Time post-stroke | Diagnostic method | Reported outcome | Result | Comments
Daniels, Brailey, Priestly et al., 1998 | CCS | 55 | Recruited | 66 | VA Medical Center | CT or MRI | w/in 5 days | VFSS | Aspiration | 38.2%(21/55) | 14 cases of aspiration silent on BSE; diag-nosed on VFSS
Daniels, McAdam, Brailey et al., 1997 | CCS | 59 | Consecutive strokes | 66 | Hospital | CT or MRI | w/in 5 days | BSE and MBS | Aspiration | 32.2%(19/59)
Smithard, O'Neill, Parks et al., 1996 | CCS | 94 | Had VFSS within 3 days of stroke | 79 (med) | Hospital | "Clinical assessment" | w/in 3 days | VFSS | Aspiration | 21.3%(20/94)
Kidd, Lawson, Nesbitt et al., 1993 | CCS | 60 | Consecutive stroke | 72 | Hospital | NR | w/in 3 days | VFSS | Aspiration | 34.7%(25/60)
Chen, Ott, Peele et al., 1990 | CCS | 46 | Consecutive stroke | 69 | NR | CT | <1 mo | VFSS | Aspiration | 32.6%(15/46)

Evidence Table 13. Cases of Stroke that Result in Pneumonia

Study authors | Study design | N | How chosen | Mean age | Care setting | How disease confirmed | Diagnostic method for pneumonia | Treatment | Reported outcome | Time frame | Result | Comments
Barker and Mullooly, 1997 | RCS | 196 247 275 | Strokes: 1967-71 1974-78 1981-1984 | >65 | Mostly hospital | NR | NR | NR | Pneumonia | 30 days | 10% 7% 9% | Kaiser-Permanente Health Care Plan records
Odderson and McKenna, 1993 | RCS | 90 | All non-hemorrhagic strokes admitted during 1990 | NR | Hospital | NR | NR | NR | Pneumonia | LOS (17.5 days mn) | 6.7% (6/90) | See also (Odderson, Keaton, and McKenna, 1995); year before organized dysphagia program
Young and Durant-Jones, 1990 | RCS | 216 | Randomly selected over 3 yrs | Circa. 65 | Hospital | NR | NR | NR | Aspiration pneumonia | LOS (up to 53 days) | 13.0% (28/216) | No organized dysphagia program
Haerer and Smith, 1974 | RCS | 475 | Consecutive strokes | NR | Hospital | NR | NR | NR | Severe pneumonia | LOS | 8.8%

Evidence Table 14. Cases of Aspiration that Result in Pneumonia

Study authors | Study design | Num patients | How chosen | Mean age | Care setting | Disease(s) | Condition | Diagnostic method | Treatment | Reported outcome | Time frame | Result | Comments
Langmore, Terpenning, Schork et al., 1998 | CS | 51 20 | Recruited | 60+ | Inpatient Nursing home | CVA, COPD, CHF, GI disease | Aspiration of liquids | MBS | NR | Asp. Pneumonia | Up to 4 years | 21.6% (11/51) 65%(13/20)
Langmore, Terpenning, Schork et al., 1998 | CS | 51 14 | Recruited | 60+ | Inpatient Nursing home | CVA, COPD, CHF, GI disease | Aspiration of secretions | FEES | NR | Asp. Pneumonia | Up to 4 years | 15.7% (8/51) 64.3% (9/14)
Smithard, O'Neill, Parks et al., 1996 | CS | 20 | Stroke + aspiration | 79 md | Acute-care hospital | CVA | Aspiration | MBS | NR | Chest infection | LOS (36.4 days mean) | 35.0% (7/20)
Teasell, McRae, Marchuk et al., 1996 | RCS | 84 | Stroke + suspected aspiration | NR | Stroke rehab unit | CVA | Aspiration | MBS | Some artificial feeding | Pneumonia | LOS in hospital | 11.9% (10/84) | 6 brain-stem strokes, 3 right hem, 1 left hem
Croghan, Burke, Caplan et al., 1994 | RCS | 22 | Underwent VFSS | 68.6 | Nursing home | CVA, PD, CP, head injury, cleft palate | Aspiration | VFSS | 15/22 feeding tube | Pneumonia | Up to 1 yr. | 50% (11/22) | Pneumonia not specifically aspiration
Holas, DePippo, and Reding, 1994 | CCS | 61 | Stroke + dysphagia | NR | Stroke rehab unit | CVA | Aspiration | VFSS | NR | Pneumonia | LOS in hospital | 13.1% (8/61)
Schmidt, Holas, Halvorson et al., 1994 | CS | 26 | Strokes | 73 | Stroke rehab unit | CVA | Aspiration | MBS | NR | Pneumonia | 16 mos mean | 19.2% (5/26)

Evidence Table 15. Comparison of Aspirators, Nonaspirators, and Dysphagics in Pneumonia Incidence

Study authors | Num patients | How chosen | Mean age | Care setting | Disease(s) | Condition | Diagnostic method | Treatment | Reported outcome | Time frame | % aspiration with pneumonia | % nonaspiration with pneumonia | % dysphagic with pneumonia | Comments
Langmore, Terpenning, Schork et al., 1998 | 51 20 | Recruited | 60+ | Inpatient Nursing home | CVA, COPD, CHF, GI disease | Aspiration of liquids | MBS | NR | Asp. Pneumonia | Up to 4 years | 21.6% (11/51) 65% (13/20) | 57.1%(4/7) 60% (3/5) Dysphagic, no aspiration | 24.2% (15/62) 64% (16/25) | Primarily GE reflux; time not reported; no usable stats
Lang-more, Terpenning, Schork et al., 1998 | | Recruited | 60+ | Inpatient Nursing home | CVA, COPD, CHF, GI disease | Aspiration of secretions | FEES | NR | Asp. Pneumonia | Up to 4 years | 15.7% (8/51) 64.3% (9/14) | 63.6% (7/11) 63.6% (7/11) Dysphagic, no asp | 24.2% (15/82) 64% (16/25) | Primarily GE reflux; time not reported; no usable stats
Smithard, O'Neill, Parks et al., 1996 | 20 | Stroke + aspiration | 79 md | Acute-care hospital | CVA | Aspiration | MBS | NR | Chest infection | LOS (36.4 days mean) | 35.0% (7/20) | 16.2% (12/74) Not nec. dysphagic | 66.7% (20/60) | Chest infection may have a broader definition than pneumonia; tested <24 hrs post-stroke; no signif. diffs
Teasell, McRae, Marchuk et al., 1996 | 84 | Stroke + suspected aspiration | NR | Stroke rehab unit | CVA | Aspiration | MBS | Some artificial feeding | Pneumonia | LOS in hospital | 11.9% (10/84) | 0.6% (2/357) All non-asp, not all tested 9.1% (2/22) dysphagic non-asp | 11.3% (12/106) | 6 brain-stem strokes, 3 right hem, 1 left hem.; only suspected aspirators got MBS; tested mean 39 days post-stroke; no stats
Croghan, Burke, Caplan et al., 1994 | 22 | Underwent VFSS | 68.6 | Nursing home | CVA, PD, CP, head injury, cleft palate | Aspiration | VFSS | 15/22 feeding tube | Pneumonia | Up to 1 yr. | 50% (11/22) | 33.3% (6/18) All non-asp 45.5% (5/11) dysphagic non-asp | 48.5%(16/33) | Pneumonia not specifically aspiration; time not reported; no sign. diffs
Holas, DePippo, and Reding, 1994 | 61 | Stroke + dysphagia | NR | Stroke rehab unit | CVA | Aspiration | VFSS | NR | Pneumonia | LOS in hospital | 13.1% (8/61) | 1.9% (1/53) | 7.9% (9/114) | Tested 4 weeks post-stroke; p = 0.012
Schmidt, Holas, Halvorson et al., 1994 | 26 | Strokes | 73 | Stroke rehab unit | CVA | Aspiration | MBS | NR | Pneumonia | 16 mos mean | 19.2% (5/26) | 3.0% (1/33) | NR | Tested mean 62 days post-stroke; p=0.05
Kidd, Lawson, Nesbitt et al., 1993 | 25 | Stroke | 72 | Hospital | CVA | Aspiration | VFSS | NR | LRTI | 2 weeks | 68% (17/25) | 5.7% (2/35) | 31.7% (19/60) Suspected dysphagic | Only suspected dysphagics underwent VFSS <72 hrs post-stroke; p<0.0001

Evidence Table 16. Cases of Dysphagia that Lead to Pneumonia

Study author | Study design | Num patients | How chosen | Mean age | Care setting | Disease(s) | How disease confirmed | Time post-stroke | Diagnostic method | Treatment | Reported outcome | Time frame | Result | Comments
Langmore, Terpenning, Schork et al., 1998 | Recruited | 25 | Recruited | 60+ | Inpatient Nursing home | CVA, other neurologic, GI disease, diabetes, COPD, CHF | NR | NR | NR | NR | Asp. Pneumonia | Up to 4 yrs. | 24.2% (15/62) 64% (16/25)
Nilsson, Ekberg, Olsson et al., 1998 | CCS | 14 | Dysphagic stroke | 76 | Hospital | CVA | CT or MRI | <1 day | Water swallow | No specific swallow treatment | Pneumonia | LOS (14 days) | 14.3% (2/14)
Smithard, O'Neill, Parks et al., 1996 | CS | 60 | Stroke + dysphagia | 79 md | Acute-care hospital | CVA | CT | Dysphagia | BSE | NR | Chest infection | LOS (44.8 days mean) | 33.3% (20/60)
Croghan, Burke, Caplan et al., 1994 | RCS | 33 | Underwent VFSS | 68.6 | Nursing home | CVA, PD, CP, head injury, cleft palate | NR | NR | VFSS | | Pneumonia | Up to 1 yr. | 48% (16/33) | Pneumonia not specifically aspiration
Holas, DePippo, and Reding, 1994 | CCS | 114 | Stroke + dysphagia | 71.6 | Stroke rehab unit | CVA | CT or MRI | 4 wks | VFSS | | Pneumonia | NR | 7.9% (9/114) | Most cases were in aspirators

Evidence Table 17. Cases of Nondysphagic Stroke that Result in Pneumonia

Study author | Study design | N | How chosen | Mean age | Care setting | Disease(s) | Diagnostic method | Treatment | Reported outcome | Time frame | Result
Reynolds, Gilbert, Good et al., 1998 | RCS | 33 | Consecutive stroke with BSE and MBS | 66 | Hospital | CVA | BSE BSE and MBS | | Pneumonia | LOS (circa 10-29 days) | 19.8% (9/46) 9.1% (3/33)
Gottlieb, Kipnis, Sister et al., 1996 | CCS | 130 | Consecutive strokes | 74 | Stroke rehab unit | CVA | BSE | None | Pneumonia | 53.5 days mean | 6.9% (9/74)

Evidence Table 18. Cases of Nonaspirating Dysphagia that Result in Pneumonia

Study author | Study design | N | How chosen | Mean age | Care setting | Disease(s) | Condition | Diagnostic method | Treatment | Reported outcome | Time frame | Result | Comments
Reynolds, Gilbert, Good et al., 1998 | RCS | 68 | Consecutive stroke with BSE and MBS | 66 | Hospital | CVA | Non-aspiration | MBS | NR | Pneumonia | LOS (circa 10-29 days) | 13.2% (9/68) | Statistically sig. Lower pneumonia rate than aspirators
Holas, DePippo, and Reding, 1994 | CCS | 53 | Stroke + dysphagia | NR | Stroke rehab unit | CVA | Non-aspiration | VFSS | NR | Pneumonia | LOS in hospital | 1.9% (1/53)
Schmidt, Holas, Halvorson et al., 1994 | CS | 33 | Strokes | 73 | Hospital | CVA | Non-aspiration | MBS | NR | Pneumonia | 16 mos mean | 3.0% (1/33)

Evidence Table 19. Cases of Aspiration that Lead to Pneumonia Death

Study author | Study design | N | How chosen | Mean age | Care setting | Disease(s) | Diagnostic method | Treatment | Reported outcome | Time frame | Result | Comments
Croghan, Burke, Caplan et al., 1994 | RCS | 22 | Underwent VFSS | 68.6 | Nursing home | CVA, PD, CP, head injury, cleft palate | VFSS | 15/22 feeding tube | Pneumonia death | Up to 1 yr | 7 (31.8%) | Pneumonia,not specifically aspiration
Feinberg, Knebl, and Tully, 1996 | PCS | 115 | Underwent VFSS | 86 | Nursing home | Dementia, stroke, PD, unknown | VFSS | 30/115 artificial feeding | Pneumonia death | Mean 28 months (3 yrs or death) | 24/115 (20.9%)
Pick, McDonald, Bennett et al., 1996 | PCS | 69 | Aspirators | 72.3 | Nursing home | NR | Nurse observation | NR | Pneumonia death | 1 yr | 13 (18.8%) | 3 yr overall mortality: 83%

Evidence Table 20. Patients with Pneumonia who Die of Pneumonia

Study author | Study design | N | How chosen | Mean age | Care setting | Disease(s) | Condition | Diagnostic method | Treatment | Reported outcome | Time frame | Result | Comments
Thompson, Hall, Szpiech et al., 1997 | RCS | 129 | Elderly with pneumonia 1993-94 | 83.6 | Nursing home; hospital | Various | Pneumonia | Presence of new chest infiltrates + symptoms | Antibiotics | Pneumonia death | 6 wks | Hospitalized: 39.5% (15/38) Not hosp: 18.7% (17/101) Total: 24.8% (32/129)
Riquelme, Torres, El-Ebiary et al., 1996 | CC-C | 101 | Pneumonia | 78.5 | Hospital | CVA, CHF, COPD, fever, neoplasia, anemia, jaundice | Pneumonia | Presence of new chest infiltrates + symptoms | Antibiotics | Pneumonia death | 30+ days | 19.8% (20/101) | Pneumonia not specifically aspiration
Venkatesan, Gladman, Macfarlane et al., 1990 | CCS | 73 | Consecutive admitted with pneumonia | 79 (med) | Hospital | NR | Pneumonia | New shadow on chest radiograph and LRTI | NR | Death by pneumonia | 6 wks | 13.7% (10/73)

Evidence Table 21. Cases of Pneumonia that Result in Death (all causes) in Elderly Patients

Study authors | Study design | N | How chosen | Mean age | Care setting | Disease(s) | Condition | Diagnostic method | Treatment | Reported outcome | Time frame | Result | Comments
Reynolds, Gilbert, Good et al., 1998 | RCS | 21 | Consecutive stroke with BSE and MBS | 66 | Hospital | CVA | Pneumonia | NR | NR | Death | LOS (mean 29 days) | 23.8% (5/21) | Death not specific to pneumonia
Marston, Plouffe, File et al., 1997 | CS | 1481 | Community-acquired pneumonia | >65 | Hospital | NR | Pneumonia | New infiltrates on radiograph + symptoms | NR | Death | LOS | 12.5% (185/1481) | Ohio
Thompson, Hall, Szpiech et al., 1997 | RCS | 129 | Pneumonia in nursing homes, 1993-94 | 83.6 | Nursing home; hospital | Various | Pneumonia | New infiltrates on radiograph + symptoms | Antibiotics | Death | 36.9 wks avg. | 53.5% (69/129) | Death not specific to pneumonia
Riquelme, Torres, El-Ebiary et al., 1996 | CC-C | 101 | Pneumonia | 78.5 | Hospital | CVA, CHF, COPD, Fever, neoplasia, anemia, jaundice | Pneumonia | Presence of new chest infiltrates + symptoms | Antibiotics | Death | 30+ days | 26.0% (26/100) | Pneumonia not specifically aspiration
Houston, Silverstein, and Suman, 1995 | RCS | 243 | Elderly with pneumonia 1987 | >65 | Community Nursing home Hospital | Various | Pneumonia | Presence of new infiltrates and/or symptoms | Antibiotics | Death | 30 days 1 yr 2 yrs 3 yrs | 30-day outcomes: Nursing home treated in nursing home: 46% (23/50) Nursing home treated in hospital: 35.5% (11/31) Elderly overall: 13.2% (31/235) 1 yr: 30% 2 yrs: 38% 3 yrs: 46% | Radiograph not necessary for study inclusion as case of pneumonia; Mayo Clinic.
Beck-Sague, Villarino, Giuliano et al., 1994 | PCS | 69 | Pneumonia | NR | Nursing home | NR | Pneumonia | NR | NR | Death | 6 mos | 5.8% (4/69) | Time frame unclear; only 12% treated in hospital
Jones, 1993 | RCS | 101 | Record review | 58 | Hospital | NR | Aspiration pneumonia | Not clear | NR | Death | NR (LOS?) | 47.5% (48/101) | Death not specific to pneumonia
Marrie, Durant, and Kwan, 1986 | CC-C | 74 | Nursing home acquired pneumonia | 74.4 | Hospital | CVA, dementia, other | Pneumonia | Opacity on chest radiograph | Antibiotics | Death | Mean 15.5 days (LOS) | 40.5% (30/74) | 13 suspected aspiration
Garb, Brown, Garb et al., 1978 | RCS | 35 | Suspected pneumonia, 1971-76 | 80.8 | Hospital | NR | Pneumonia | Roentgenographic evidence of pneumonia and + bacteria on sputum sample | Antibiotics; inhalation; steroids, etc. | Death | NR | 11.4% (4/35) | Death not specific to pneumonia

Evidence Table 22. Stroke Patients Without Pneumonia who Died

Study authors | Study design | N | How chosen | Mean age | Care setting | Disease(s) | Condition | Diagnostic method | Treatment | Reported outcome | Time frame | Result | Comments
Reynolds, Gilbert, Good et al., 1998 | RCS | 81 | Consecutive stroke with BSE and MBS | 66 | Hospital | CVA | Non-pneumonia | NR | NR | Death | LOS (mean 10 days) | 3.7% (3/81) | All-cause death

Evidence Table 23. Annual Incidence of Pneumonia in the Elderly

Study authors | Study design | How chosen | Mean age | Care setting | Condition | Diagnostic method | Time frame | Result | Comments
Marston, Plouffe, File et al., 1997 | RCS | Hospitalized cases of community-acquired pneumonia | 65+ | Hospital | Pneumonia | Radiograph + symptoms | 1 yr | 1,014/100,000 | Does not include nursing homes, 1991
Thompson, Hall, Szpiech et al., 1997 | RCS | Nursing homes, NY, 1993-4 | 83.6 | Nursing home | Pneumonia | Radiograph + symptoms | 1 yr | 18,500/100,000 | Not nec. hospitalized; annual incidence
Houston, Silverstein, and Suman, 1995 | RCS | Mayo Clinic records | NR | Various | Pneumonia | Radiograph and/or symptoms | 1 yr | 3,032/100,000 | Sex- and age-adjusted to 1990 US white population; not nec. hospitalized
Marrie, 1990 | RCS | Hospital cases of pneumonia | NR | Hospital | Pneumonia | Radiograph | 1 yr | 530/100,000; Nursing homes: 3,300/100,000 | Nova Scotia, 1986

Evidence Table 24. Studies of Dysphagia Diagnostic-treatment Programs for Prevention of Pneumonia in Consecutive Stroke Patients in Acute-care Settings

Author | N | Study design | Time period and setting | Selection | Test(s) | Treatment | Mean age | Characteristics | Followup | Cumulative pneumonia
Nilsson, Ekberg, Olsson et al., 1998 | 72 28 Total 100 | CS | University hospital stroke unit, Malmo, Sweden | Consecutive stroke patients evaluable by test Unevaluable (couldn't respond to questions) Consecutive stroke patients | Self-report Patients unable to respond to questions All patients | Diet consistency treatment only; IV drip but no tubes | 76 | All acute stroke within 24 hrs.; 19% (14/72) with self-reported difficulty swallowing All acute stroke within 24 hrs. unable to respond to questions All acute stroke within 24 hrs.; 42% (42/100) with self-reported difficulty swallowing or unable to respond to questions | 24 wks. | 2.8% (2/72) 11% (3/28) Overalll 5.0% (5/100)
Odderson, Keaton, and McKenna, 1995 | 90 121 124 | HPCS | 1993 Urban community hospital | Consecutive acute stroke | ? Patients failing preliminary water test (39%) given formal BSE; diet, SLP therapy, tubes as needed | Year before program 1^st^ program year 2^nd^ program year | 75 | All stroke; BSE within 24 hours | 9.8 days ±0.9 (SE) 7.3 days ±0.5 7.2 days ±0.5 | 6.7% (6/90) 4.1%(5/121) 0%(0/124)
Daniels, Brailey, Priestly et al., 1998 | 55 | CS | VA medical center | Consecutive patients admitted with new stroke; 2 patients excluded due to obtunded or agitated status or previous history of dysphagia | All got MBS; 65% were dysphagic; 38% aspirated | All patients with dysphagia treated with one or more of: swallow therapy, compensatory strategies, diet alteration, nonoral feeding | 66 | All new stroke patients | 3 mos. | 1.8% (1/55)

Evidence Table 25. Historical Prospective Case Series Study of BSE Dysphagia Program for Prevention of Pneumonia in Consecutive Acute Stroke Patients

Author | N | Study design | Time period and care setting | Selection | Program | Follow-up | Mean age | Patient characteristics | Cumulative pneumonia (95% CI) | Difference ^1^ from historical control (95% CI) | Relative risk reduction ^2^ (95% CI)
Odderson, Keaton, and McKenna, 1995 Year before program 1^st^ year 2^nd^ year 1^st^ & 2^nd^ Mean | 90 121 124 | HPCS | Urban community hospital 1990 1992 1993 | Consecutive acute nonhemorrhagic stroke; excluded terminal care patients and those with resolution within 24 hrs | ? BSE BSE | 9.8 ±0.9 (SE) 7.3 ±0.5 7.2 ±0.5 | 75 74 75 | All acute stroke | 6.7% (6/90) (3.1 to 14%) 4.1% (5/121) (1.8 to 9.3%) 0 (0/124) (0 to 3.0%) 2.0% (5/245) (0.9 to 4.7%) | 2.5% (-3.8 to 10%) 6.7% (2.0 to 11%) 4.6% (0.2 to 12%) | 39% (14 to 70%) 100% (68 to 100%) 70% (45 to 86%)
Adjusted to 7 days of followup
Year before program 1^st^ year 2^nd^ year 1^st^ & 2^nd^ Mean | 90 121 124 245 | | 1990 1992 1993 | | | 7 days (0.934) 7 days (0.990) 7 days (0.993) 7 days (0.992) | 75 74 75 | | 6.3% (2.8 to 13%) 4.1% (1.7 to 9.2%) 0 (0 to 3.0%) 2.0% (0.8 to 4.6%) | 2.2% (-4.0 to 9.6%) 6.3% (1.7 to 13%) 4.3% (-0.0003 to 11%) | 35% 100% 68%

Evidence Table 26. Historical Controls for no-program Pneumonia Incidence in Consecutive Stroke Patients in Acute-care Settings

Author | N | Study design | Time period and setting | Selection | Test(s) | Treatment | Mean age | Characteristics | Followup | Cumulative pneumonia (95% CI) | Adjustment factor | Adjusted to 2 week interval (95% CI)
Odderson, Keaton, and McKenna, 1995 | 90 | HPCS | 1993 Urban community hospital | Consecutive acute nonhemorrhagic stroke | ? | ? | 75 | All stroke | Mn LOS 9.3 days | 6.7% (6/90) (3.1 to 14%) | 1.105 | 7.4% (3.6 to 15%)
Young and Durant-Jones, 1990 | 216 | CS | 1987-89 Acute-care teaching hospital | Charts of randomly selected stroke patients over a 3-year period (4%, 9/225, excluded as comatose) | ? | ? | 65 | All stroke | 4.4 wks | 13% (28/216) (9.1 to 18%) | 0.848 | 11% (7.5 to 16%)
Barker and Mullooly, 1997 | 196 247 275 | RCS | Hospital 1967-71 1974-78 1981-84 | All new stroke patients (WHO standard) over age 65 in an HMO | | | >65 | All stroke | 30 days | 10% (20/196) 7% (17/247) 9% (25/275) Mean 8.6% | 0.848 | 8.5% (5.4 to 13%) 5.9% (3.6 to 9.6%) 7.6% (5.0 to 11%) Mean 7.3% (5.6 to 9.4%)
Haerer and Smith, 1974 | 475 | RCS | Hospital 1967-72 | Consecutive strokes | | | | | LOS Mn 17.5 days | 8.8% (42/475) | 0.951 | 8.4% (6.2 to 11%)
Range Unweighted Mean N-Weighted Mean | | | | | | | | | | 6.7 to 13% 9.1% 9.2% (138/1,499) (7.8 to 11%) | | 5.9 to 11% 8.1% 8.2% (6.9 to 9.7%)

Evidence Table 27. Dysphagia Programs for Prevention of Pneumonia in Consecutive Acute Stroke Patients Compared with Historical Controls

Author | N | Care setting | Program | Follow-up interval | Cumulative pneumonia (95% CI) | Difference ^1^ from no-program mean of 9.2% (95% CI) | Relative risk reduction ^1^ | Adjustment factor | Cumulative adjusted to 2- week interval | Difference ^2^ from adjusted no-program mean of 8.2% (95% CI) | Adjusted relative risk reduction ^2^
Nilsson, Ekberg, Olsson et al., 1998 | 72 | University hospital stroke unit, Malmo, Sweden | Self-reported difficulty swallowing; diet consistency treatment only; IV drip but no tubes | 26 wks | 2.8% (2/72) (0.8 to 9.6%) | 6.4%(-0.5 to 9.0%) | 74% | 0.800 | 2.2% (0.5 to 8.7) | 6.0% (-0.6 to 8.3%) | 73%
Odderson, Keaton, and McKenna, 1995 2^nd^ year | 124 | 1993, Urban community hospital | Patients failing preliminary water test (39%) given formal BSE; diet, SLP therapy, tubes as needed | 1.0 wk | 0 (0/124) (0 to 3.0%) | 9.2% (5.9 to 11%) | 100% | 1.183 | 0% (0 to 3.0%) | 8.2 (4.9 to 9.7%) | 100%
Daniels, Brailey, Priestly et al., 1998 | 55 | VA medical center | All got MBS (65% were dysphagic, 38% aspirated); dysphagics got diet, SLP therapy, tubes as needed | 13 wks | 1.8% (1/55) (0.3 to 9.6%) | 7.4% (-0.5 to 0.6%) | 80% | 1.018 | 1.8% (0.3 to 9.6%) | 6.4% (-1.5 to 8.5%) | 78%
Range Unweighted Mean N-weighted Mean | | | | | 0 to 2.8% 1.5% 1.2% (3/251) (0.4 to 3.5%) | 6.4 to 9.2% 7.7% 8.0% (5.4 to 9.8%) | 74 to 100% 85% 88% | | 0 to 2.2% 1.3% 1.3% (0.5 to 3.6%) | 6.0 to 8.2% 6.9% 6.9% (4.3 to 8.6%) | 73 to 100% 84% 87%

Evidence Table 28. Diagnosis-treatment Programs for Prevention of Pneumonia in the Rehabilitiation Center Setting

Author | N | Study design | Time period and care setting | Selection | Test | Treatment | Mean age | Characteristics | Follow-up | Pneumonia | Comments
BSE
Gottlieb, Kipnis, Sister et al., 1996 | 60 60 60 | CS | Hospital rehabilitation unit, Petach Tiqva, Israel | Consecutive stroke patients admitted to rehabilitation | 50-ml water test | Startup (1^st^ 60 pts.) 2^nd^ 60 pts. Ongoing (3^rd^ 60 pts.) | 74 75 73 | All stroke patients; Mean of 14 days in previous acute- care unit | Mn LOS 52 days Mn LOS 56 days Mn LOS 55 days | 16% (9/60) 12% (7/60) 3.3% (2/60)
VFSS
Teasell, McRae, Marchuk et al., 1996 | 441 | CS | University hospital rehabilitation unit, London, Ontario, Canada | Consecutive patients admitted to hospital rehabilitation unit less than 4 mos. post-stroke | 24% (106/441) got MBS due to clinical suspicion of aspiration | High-risk patients received one or more of: modified diet, compensatory swallowing techniques, nasogastric or gastro-jejunal tubes | | All stroke within 4 mos., MBS Mn >5 weeks post-stroke | LOS | 2.7% (12/441) (1.5 to 4.8%)
DePippo, Holas, and Reding, 1994 | 139 | CS | | Consecutive stroke patients admitted to a rehabilitation hospital | 59% (82/139) failed Burke Dysphagia Screening Test and got MBS | Patients with dysphagia at MBS got one or more of: modified diet or compensatory training | 71 | All stroke, mean of 5 (SD ± 3) weeks post-stroke | Rehab. LOS, mean 9 (SD± 5) weeks | 6.5% (9/139) (3.2 to 12%) | 13% (18/139) of patients had pneumonia in an acute-care hospital prior to admittance to rehab

Evidence Table 29. Fiberoptic Endoscopic Dysphagia Diagnosis-treatment Program for Prevention of Pneumonia in Nursing Home Patients of Mixed Etiology Clinically Suspected off Dysphagia

Author | N | Study design | Time period and care setting | Selection | Program | Followup | Mean age | Patient characteristics | Cumulative pneumonia (95% CI) | Difference ^2^ (95% CI) | Relative risk reduction ^3^ (95% CI)
Spiegel, Creed, Selber et al., unpub.(b) 6 mos. before program 1^st^ 6 mos. of program | 85 ^1^ 85 | HPCS | 2 Nursing homes | Referred for dysphagia evaluation | BSE FEES | 0 to 6 mos 0 to 6 mos | ? 81 | Mixed etiology ? 9% on tube | 13%^1^ (11/85^1^) (7.4 to 22%^1^) 0 (0/85) (0 to 4.3%) | 13%^1^ (5.9 to 22%^1^) | 100% ^1^ (74 to 100% ^1^ )

Evidence Table 30. Applied Diagnosis to Guide Treatment: Diet Modification

Study author | Study design | N | Mean age | Disease(s) | Condition | Diagnostic method | Treatment | Treatment results | Comments
Logemann, Pauloski, Colangelo et al., 1995 | PCS | 27: 19 stroke, 8 other neuro | NR | Stroke; other neuro | Dypshagia with delayed onset of oral stage or delayed pharyngeal swallow | VFSS | Sour bolus in 1 ml- and 3- ml volumes | Stroke: With sour bolus: decreased swallow delay; reduced pharyngeal delay time; reduced oral transit time and pharyngeal transit time; improved oropharyngeal swallow efficiency. With increased bolus volume: decreased pharyngeal delay time and oral transit time; prolongation of opening of cricopharyngeus and duration of laryngeal closure Other neuro: With sour bolus: aspiration eliminated on 3 ml; onset of oral swallow shortened; tongue function improved With increased bolus volume: reduced oral transit times; increased oral residue; Reduced pharyngeal transit time; Increased number of swallows | Patients didn't like sour bolus: tolerable but unpleasant
Bisch, Logemann, Rademaker et al., 1994 | C-C | 28: Group I: 10 first-time stroke Group II: 8 neuro pts Group III: 10 normal | 62; 69; 62 | CVA; meningioma | I: Mild dysphagia II: moderate-severe dysphagia | VFSS | Cold bolus in 2 volumes and 2 viscosities | Group I: Cold 1 ml: decreased pharyngeal response time and duration of laryngeal elevation; increased duration of laryngeal closure 5 ml: shorter pharyngeal delay time Pudding: shorter pharyngeal delay time. On all temps, stroke demonstrate longer pharyngeal delay time and shorter duration of laryngeal closure than controls Group II: No temp effects Volume effects: larger generally improved measures Viscosity: pudding improved measures compared with liquid | 1 ml liquid the most difficult for first-time stroke pts

Evidence Table 31. Applied Diagnosis to Guide Treatment: Postural Changes

Study author | Study design | N | Mean age | Disease(s) | Condition | Diagnostic method | Treatment | Treatment results | Comments
Logemann, Kahrilas, Kobara et al., 1989 | C-C | 11: 5 stroke 6 controls | NR | CVA | | VFSS | Head turn 90 degrees | In normal head position: All pts demonstrated unilateral pharyngeal weakness and reduced laryngeal elevation on liquid bolus 33% of bolus successfully swallowed With head turned to weaker side: 65% of bolus successfully swallowed
Ekberg, 1986 | PCS | 53 | 58 | NR | Dysphagia | VFSS | Head tilt backwards; Head tilt forward | In normal head position: 34% (18/53) demonstrated defective laryngeal vestibular closure Head tilt forward: 50% (9/18) normal Head tilt backward: 11.1% (2/18) normal In normal head position: 18.9% (10/53) demonstrated abnormal downward mvt of epiglottis Head tilt backward: 20% (2/10) became normal In normal head position: 11.3% (6/53) demonstrated defective relaxation of cricopharyngeus No changes with head posture
Rasley, Logemann, Kahrilas et al., 1993 | CCS | 165 | 59 | Cancer; CVA; head injury; other | Aspiration | VFSS, 5 volumes (1, 3, 5, 10 ml; drink from cup) | Various head repositions as recommended by SLP | All postural positions: Aspiration elimination for at least 1 volume: 77% (127/165) No effect of treatment: 23% (38/165) Aspiration eliminated on all volumes: 12.7% (21/165) Chin down position: Aspiration eliminated on all volumes: 25% (21/84) Head rotation: Elimination of asp on all volumes: 26% (20/77) | For those with no success, problem often that pt couldn't change position or maintain position consistently, or had language or communication problems (26/38)
Shanahan, Logemann, Rademaker et al., 1993 | CCS | 30 | 74.3 61.1 | CVA; MND; MS; head injury, etc. | Aspiration: 10 successful with chin tuck 10 no success with chin tuck | VFSS | Chin tuck | Those with no success showed significantly more aspiration from pyriform sinus (versus valleculae) when chin upright and epiglottic angle significantly increased with chin tuck, while successful pts showed no change | Clinicians can be reasonably sure that a chin tuck will not work if aspiration from pyriform sinus is viewed on VFSS

Evidence Table 32. Applied Diagnosis to Guide Treatment: Other Treatments

Study author | Year | Study design | N | Mean age | Disease(s) | Condition | Diagnostic method | Treatment | Treatment results | Comments
de Lama Lazzara, Lazarus, and Logemann, 1986 | 1986 | CCS | 25 | NR | CVA, PD, MS, head trauma, etc. | Dysphagia: delay in swallow reflex | VFSS | Thermal stimulation of anterior faucial arches | Pharyngeal transit time and total transit time reduced on swallow immediately after stimulation. This effect wears off after 2-3 swallows. 92% (23/25) pts improved on at least one bolus viscosity | No statistical analyses
Rosenbek, Robbins, Willford et al., 1998 | 1998 | RT | 45 | 65.2 | CVA, PD, MS, head trauma, etc. | Dysphagia diagnosed on BSE | VFSS | Tactile-thermal application (TTA) at one of four different intensities: 150, 300, 450, 600 trials per week | No effect of treatment intensity on duration of stage transition or penetration and aspiration | Thus, lesser treatment intensity can be used safely, using less person hours

Evidence Table 33. Clinical Oropharyngeal Signs and Symptoms for Prediction of Pneumonia

Author | N | Study design | Test | Selection | Age | Characteristics | Outcomes | Comments
Langmore, Terpenning, Schork et al., 1998 | 189 | CCS | "Dependent for oral care" (cut-off defining dependence on 4-point scale not stated) | Male, age 60 or older, no head or neck cancer; dysphagia not inclusionary or exclusionary criterion | Mn 70 | 42% stroke, 28% other neurologic disease, 14% other diseases, 16% none | Sens. 34% Spec. 90% PPV 48% NPV 83% | Patients recruited from outpatient clinics, inpatient acute care wards, and VA nursing home care center. Patients followed until aspiration pneumonia, death, or failure to return for further examination; some patients followed for up to 4 years.
Langmore, Terpenning, Schork et al., 1998 | 189 | CCS | "Dependent for feeding" (cut-off defining dependence on 4-point scale not stated) | Male, age 60 or older, no head or neck cancer; dysphagia not inclusionary or exclusionary criterion | Mn 70 | 42% stroke, 28% other neurologic disease, 14% other diseases, 16% none | Sens.41% Spec. 94% PPV 65% NPV 85% | Patients recruited from outpatient clinics, inpatient acute care wards, and VA nursing home care center. Patients followed until aspiration pneumonia, death, or failure to return for further examination; some patients followed for up to 4 years.
Langmore, Terpenning, Schork et al., 1998 | 189 | CCS | Brush teeth 3 times a week or less | Male, age 60 or older, no head or neck cancer; dysphagia not inclusionary or exclusionary criterion | Mn 70 | 42% stroke, 28% other neurologic disease, 14% other diseases, 16% none | Sens.39% Spec. 88% PPV 47% NPV 84% | Patients recruited from outpatient clinics, inpatient acute care wards, and VA nursing home care center. Patients followed until aspiration pneumonia, death, or failure to return for further examination; some patients followed for up to 4 years.
Harkness, Bentley, and Roghmann, 1990 | 99 | C-C | Dependent feeding | 33 cases of radiographically confirmed nosocomial pneumonia in patients 65 years or older; each case matched with 2 controls for age within 5 years, sex, hospital service or residential unit, and length of stay | 42% of patients were 75 years or older | 42% of cases and 17% of controls had neurologic disease; 18% of cases of 4% of controls had renal disease | Sens. 73% ^2^ Spec. 59% ^2^ PPV 47% ^2^ NPV 81% ^2^ | Patients recruited from university hospital for acute care setting; patients with nosocomial pneumonia identified during 18-week period
Harkness, Bentley, and Roghmann, 1990 | 99 | C-C | Aspiration | 33 cases of radiographically confirmed nosocomial pneumonia in patients 65 years or older; each case matched with 2 controls for age within 5 years, sex, hospital service or residential unit, and length of stay | 42% of patients were 75 years or older | 42% of cases and 17% of controls had neurologic disease; 18% of cases of 4% of controls had renal disease | Sens. 55% ^2^ Spec. 97% ^2^ PPV 90% ^2^ NPV 81% ^2^ | Patients recruited from university hospital for acute care setting; patients with nosocomial pneumonia identified during 18-week period
Harkness, Bentley, and Roghmann, 1990 | 99 | C-C | Difficulty with oropharyngeal secretions | 33 cases of radiographically confirmed nosocomial pneumonia in patients 65 years or older; each case matched with 2 controls for age within 5 years, sex, hospital service or residential unit, and length of stay | 42% of patients were 75 years or older | 42% of cases and 17% of controls had neurologic disease; 18% of cases of 4% of controls had renal disease | Sens. 48% ^2^ Spec. 91% ^2^ PPV 73% ^2^ NPV 78% ^2^ | Patients recruited from university hospital for acute care setting; patients with nosocomial pneumonia identified during 18-week period
Harkness, Bentley, and Roghmann, 1990 | 99 | C-C | Nasogastric feeding tube | 33 cases of radiographically confirmed nosocomial pneumonia in patients 65 years or older; each case matched with 2 controls for age within 5 years, sex, hospital service or residential unit, and length of stay | 42% of patients were 75 years or older | 42% of cases and 17% of controls had neurologic disease; 18% of cases of 4% of controls had renal disease | Sens. 64% ^2^ Spec. 58% ^2^ PPV 43% ^2^ NPV 76% ^2^ | Patients recruited from university hospital for acute care setting; patients with nosocomial pneumonia identified during 18-week period
Harkness, Bentley, and Roghmann, 1990 | 81 | C-C | Difficulty with oropharyngeal secretions | 27 cases of radiographically confirmed nosocomial pneumonia in patients 65 years or older; each case matched with 2 controls for age within 5 years, sex, hospital service or residential unit, and length of stay | 62% of residents were 75 years or older | Not reported | Sens. 44% ^2^ Spec.96% ^2^ PPV 86% ^2^ NPV 78% ^2^ | Patients recruited from chronic disease hospital for long-term care facility; patients with nosocomial pneumonia identified during 18-week period
Harkness, Bentley, and Roghmann, 1990 | 81 | C-C | Nasogastric feeding tube | 27 cases of radiographically confirmed nosocomial pneumonia in patients 65 years or older; each case matched with 2 controls for age within 5 years, sex, hospital service or residential unit, and length of stay | 62% of residents were 75 years or older | Not reported | Sens. 18% ^2^ Spec.100% ^2^ PPV 100% ^2^ NPV 71% ^2^ | Patients recruited from chronic disease hospital for long-term care facility; patients with nosocomial pneumonia identified during 18-week period

Evidence Table 34. Clinical Oropharyngeal Signs and Symptoms for Detection of Aspiration in Patients of Mixed Etiologies - Reference Standard Aspiration on MBS

Author | N | Study design | Time period and setting | Selection | Sign/symptom | Mean age | Patient characteristics | Results | Comments
Logemann, [unpub] | 200 | Consecutive tests; blinded | Medical school | Patients referred for suspected dysphagia | Abnormal wall contraction on gag | 65 | 25% single stroke, 9% multiple strokes, 23% cancer treatment, 10% injuries, 42% other | Sens. 33% Spec. 81%
Logemann, [unpub] | 200 | Consecutive tests; blinded | Medical school | Patients referred for suspected dysphagia | Cough/throat clear after swallow | 65 | 25% single stroke, 9% multiple strokes, 23% cancer treatment, 10% injuries, 42% other | Sens. 78% Spec. 58%
Logemann, [unpub] | 200 | Consecutive tests; blinded | Medical school | Patients referred for suspected dysphagia | Reduced laryngeal elevation on swallow | 65 | 25% single stroke, 9% multiple strokes, 23% cancer treatment, 10% injuries, 42% other | Sens. 66% Spec. 57%
Logemann, [unpub] | 200 | Consecutive tests; blinded | Medical school | Patients referred for suspected dysphagia | Gurgly voice after swallow | 65 | 25% single stroke, 9% multiple strokes, 23% cancer treatment, 10% injuries, 42% other | Sens. 41% Spec. 76%
Logemann, [unpub] | 200 | Consecutive tests; blinded | Medical school | Patients referred for suspected dysphagia | Multiple swallows per bolus | 65 | 25% single stroke, 9% multiple strokes, 23% cancer treatment, 10% injuries, 42% other | Sens. 48% Spec. 57%
Mari, Matei, Ceravolo et al., 1997 | 93 | Consecutive tests; blinded | Rehabilitation center | Neurological disorder with risk of dysphagia; cooperative; not bedridden, not unconscious or demented | Subjective difficulty swallowing currently or in past | 60 | 30% stroke, 8% brain injury, 29% Parkinson's, 29% NMD, 4% AD; 46% aspirated on MBS | Sens. 88% Spec. 30% PPV 52% NPV 75%
Mari, Matei, Ceravolo et al., 1997 | 93 | Consecutive tests; blinded | Rehabilitation center | Neurological disorder with risk of dysphagia; cooperative; not bedridden, not unconscious or demented | Cough | 60 | 30% stroke, 8% brain injury, 29% Parkinson's, 29% NMD, 4% AD; 46% aspirated on MBS | Sens. 75% Spec. 74% PPV 71% NPV 77%
Leder, 1997 | 100 | CS | 7-week period; urban academic medical center | Patients who underwent fluoroscopy; no surgery to soft palate, no surgery to areas that trigger gag reflex, no medications that could cause dysphagia or suppress gag reflex, adequate cognitive functioning to perform evaluation | Absence of gag reflex | 54.1 (not stated but calculated from grouped data) | All adults | Sens. 7% Spec. 78% PPV 5% NPV 82% | Presence of aspiration determined by both clinical examiner and radiologist; 72 patients had video-fluoroscopy with either esophagram, upper GI series, or small bowel series; 28 patients had MBS. Gag reflex measured by touching posterior tongue or posterior pharyngeal wall with a tongue blade, and assessing visually
Bleach, 1993 | 120 | RCS | Time period not stated; tertiary referral dysphagia clinic in London, England | Neurological patients only; others excluded | Absence of gag reflex | 63.8 | 46 CVA patients; 21 motor neuron disease; 13 Parkinson's; 5 head injury; 35 miscellaneous | "Absence of gag reflex not associated with aspiration" - Mann-Whitney U-test (2-tailed); p=.11, n.s. No other information available | Method of testing gag reflex not standardized; charts noting definite absence or presence were included; reduced or abnormal were excluded; aspiration assessed radiographically
Krefting, Norman, Hagel et al., 1990 | 17 | RCS | 2-year review at a geriatric rehabilitation hospital | | Referred for dysphagia assessment by medical and nursing staff | Not stated; these 17 pts were a subgroup from 85 pts of whom "the majority were over 70 years old" | 65% neurological; 46% stroke | Sens. 40% Spec. 58% PPV 29% NPV 70% | Duration of swallowing problems varied from less than 3 months to up to 5 years

Evidence Table 35. Clinical Oropharyngeal Signs and Symptoms for Detection of Aspiration in Stroke Patients - Reference Standard Aspiration on VFSS^1^

Author | N | Study design | Time period and setting | Selection | Sign/symptom | Mean age | Patient char-acteristics | Results | Comments
Daniels, Brailey, Priestly et al., 1998 | 55 | CS | Time period not stated; urban VA medical center | Consecutive admissions with acute stroke | Dysphonia | 66 | All patients were men | Sens. 76% Spec. 68% PPV 59% NPV 82% | 14 patients presented with unilateral right hemispheric damage; 24 with unilateral left hemispheric damage; 13 with bilateral hemispheric damage, 4 with brain stem infarcts
Daniels, Brailey, Priestly et al., 1998 | 55 | CS | Time period not stated; urban VA medical center | Consecutive admissions with acute stroke | Dysarthria | 66 | All patients were men | Sens. 76% Spec. 53% PPV 50% NPV 78% | 14 patients presented with unilateral right hemispheric damage; 24 with unilateral left hemispheric damage; 13 with bilateral hemispheric damage, 4 with brain stem infarcts
Daniels, Brailey, Priestly et al., 1998 | 55 | CS | Time period not stated; urban VA medical center | Consecutive admissions with acute stroke | Abnormal gag reflex | 66 | All patients were men | Sens. 62% Spec. 82% PPV 68% NPV 78% | 14 patients presented with unilateral right hemispheric damage; 24 with unilateral left hemispheric damage; 13 with bilateral hemispheric damage, 4 with brain stem infarcts
Daniels, Brailey, Priestly et al., 1998 | 55 | CS | Time period not stated; urban VA medical center | Consecutive admissions with acute stroke | Abnormal volitional cough | 66 | All patients were men | Sens. 48% Spec. 94% PPV 83% NPV 74% | 14 patients presented with unilateral right hemispheric damage; 24 with unilateral left hemispheric damage; 13 with bilateral hemispheric damage, 4 with brain stem infarcts
Daniels, Brailey, Priestly et al., 1998 | 55 | CS | Time period not stated; urban VA medical center | Consecutive admissions with acute stroke | Cough with swallow | 66 | All patients were men | Sens. 57% Spec. 85% PPV 71% NPV 76% | 14 patients presented with unilateral right hemispheric damage; 24 with unilateral left hemispheric damage; 13 with bilateral hemispheric damage, 4 with brain stem infarcts
Daniels, Brailey, Priestly et al., 1998 | 55 | CS | Time period not stated; urban VA medical center | Consecutive admissions with acute stroke | Voice change with swallow | 66 | All patients were men | Sens. 38% Spec.85% PPV 62% NPV 69% | 14 patients presented with unilateral right hemispheric damage; 24 with unilateral left hemispheric damage; 13 with bilateral hemispheric damage, 4 with brain stem infarcts
McCullough, 1997 | 54 | CS | Time period not stated; 2 VA hospitals and one academic medical center | Stroke within 6 weeks of exam; mental competence for informed consent; no structural anomaly that could interfere with swallowing; no presence or recent history of tracheostomy; no reported history of dysphagia before stroke; no patients judged medically unstable to participate | Dysphonia rating from patients' sustained "AHH;" raters used a 4-point scale collapsed into 2 categories "normal/ mild and moderate/ severe" | 68 | Average of 6 days post-onset of CVA; 55 subjects were men | Sens. 60% Spec. 69% | Aspiration detecting overall or thick liquid penetration rated on MBS using a 4-point scale that was then collapsed into 2 categories: normal/mild and moderate/severe
McCullough, 1997 | 58 | CS | Time period not stated; 2 VA hospitals and one academic medical center | Stroke within 6 weeks of exam; mental competence for informed consent; no structural anomaly that could interfere with swallowing; no presence or recent history of tracheostomy; no reported history of dysphagia before stroke; no patients judged medically unstable to participate | Spontaneous cough during trial swallows (thin and thick liquid, puree and cookie); raters dichotomized cough into "normal/ abnormal" | 68 | Average of 6 days post-onset of CVA; 92% of subjects were men | Sens. 76% Spec.78% | Aspiration detecting overall or thick liquid penetration rated on MBS using a 4-point scale that was then collapsed into 2 categories: normal/mild and moderate/severe
McCullough, 1997 | 58 | CS | Time period not stated; 2 VA hospitals and one academic medical center | Stroke within 6 weeks of exam; mental competence for informed consent; no structural anomaly that could interfere with swallowing; no presence or recent history of tracheostomy; no reported history of dysphagia before stroke; no patients judged medically unstable to participate | Estimate of presence of aspiration during trial swallows (thin and thick liquid, puree and cookie); raters dichotomized estimate of presence of aspiration into "normal/ abnormal" | 68 | Average of 6 days post-onset of CVA; 92% of subjects were men | Sens. 88% Spec. 63% | Aspiration detecting overall or thick liquid penetration rated on MBS using a 4-point scale that was then collapsed into 2 categories: normal/mild and moderate/severe
McCullough, 1997 | 56 | CS | Time period not stated; 2 VA hospitals and one academic medical center | Stroke within 6 weeks of exam; mental competence for informed consent; no structural anomaly that could interfere with swallowing; no presence or recent history of tracheostomy; no reported history of dysphagia before stroke; no patients judged medically unstable to participate | Dysarthria during clinical BSE; raters dichotomized dysarthria into "normal/abnormal" | 68 | Average of 6 days post-onset of CVA; 92% subjects were men | Sens. 65% Spec. 68% | Aspiration detecting overall or thick liquid penetration rated on MBS as either normal or abnormal
McCullough, 1997 | 57 | CS | Time period not stated; 2 VA hospitals and one academic medical center | Stroke within 6 weeks of exam; mental competence for informed consent; no structural anomaly that could interfere with swallowing; no presence or recent history of tracheostomy; no reported history of dysphagia before stroke; no patients judged medically unstable to participate | Intelligibility during clinical BSE; raters dichotomized intelligibility into "normal/ abnormal" | 68 | Average of 6 days post-onset of CVA; 92% of subjects were men | Sens. 60% Spec. 74% | Aspiration detecting overall or thick liquid penetration rated on MBS as either normal or abnormal
Kidd, Lawson, Nesbitt et al., 1993 | 60 | PCS | Time period not stated; urban hospital | Consecutive pts with first stroke who were conscious | Abnormal pharyngeal sensation; Abnormal tongue movement | 72 | Pts excluded with neurological disorder other than stroke that might give rise to dysphagia | Sens. 100% Spec. 60% PPV 64% NPV 100% Sens. 64% Spec. 71% PPV 62% NPV 74% | 27 right CVA; 28 left CVA; rest were brain-stem CVA
DePippo, Holas, and Reding, 1992 | 44 | CS | No time period listed; patients were resident on a stroke rehabil-itation unit | Consecutive stroke patients with 1 or more of 7 screening factors for dysphagia ^2^ | Cough and/or wet-hoarse voice quality in 3-oz water swallow test | 71 | 14 patients had right hemisphere strokes; 17 left hemisphere strokes; 3 bilateral strokes; 10 brainstem or other strokes | Sens. 80% Spec. 54% PPV 59% NPV 76% | Two raters determined presence/absence of aspiration
Horner, Buoyer, Alberts et al., 1991 | 22 | CS | October 1987- May 1990; academic medical center | Consecutive brain stem stroke referrals | Moderate to severe dysarthria | 57 | 12 patients had unilateral lesions and 10 had bilateral lesions | Sens 60% Spec. 57% PPV 75% NPV 40% | Mean interval between stroke and swallowing exam was 46 days; between radiologic and swallowing exam was 13 days
Horner, Massey, and Brazer, 1990 | 65 | RCS | Oct 1996-Dec 1998; academic medical center | Bilateral stroke patients who underwent swallowing examinations | Dysphonia | 64 | Definitive history of bilateral stroke; clinical signs assessed within 1-2 days of MBS | Sens. 97% Spec. 29% PPV 54% NPV 91% | 41% of patients restricted from all oral feeding at time of MBS
Horner, Massey, and Brazer, 1990 | 57 | RCS | Oct 1996-Dec 1998; academic medical center | Bilateral stroke patients who underwent swallowing examinations | Cough | 64 | Definitive history of bilateral stroke; clinical signs assessed within 1-2 days of MBS | Sens 84% Spec. 56% PPV 60% NPV 82% | 41% of patients restricted from all oral feeding at time of MBS
Horner, Massey, and Brazer, 1990 | 50 | RCS | Oct 1996-Dec 1998; academic medical center | Bilateral stroke patients who underwent swallowing examinations | Abnormal gag reflex | 64 | Definitive history of bilateral stroke; clinical signs assessed within 1-2 days of MBS | Sens. 67% Spec. 73% PPV 70% NPV 70% | 41% of patients restricted from all oral feeding at time of MBS
Horner, Massey, Riski et al., 1988 | 45 | CS | Time period not stated; academic medical center | Stroke patients referred for swallowing evaluations | Dysphonia | 64 | Mean time post-stroke 2.9 months; 70% underwent evaluation within the first month | Sens 91% Spec. 32% PPV 58% NPV 78% | Unilateral cerebral lesions in 11 patients; bilateral cerebral in 22; unilateral brainstem in 5; bilateral brainstem in 2; mixed lesion loci in 7
Horner, Massey, Riski et al., 1988 | 40 | CS | Time period not stated; academic medical center | Stroke patients referred for swallowing evaluations | Cough | 64 | Mean time post-stroke 2.9 months; 70% underwent evaluation within the first month | Sens. 68% Spec. 33% PPV 48% NPV 54% | Unilateral cerebral lesions in 11 patients; bilateral cerebral in 22; unilateral brainstem in 5; bilateral brainstem in 2; mixed lesion loci in 7
Horner, Massey, Riski et al., 1988 | 41 | CS | Time period not stated; academic medical center | Stroke patients referred for swallowing evaluations | Absent or diminished gag reflex | 64 | Mean time post-stroke 2.9 months; 70% underwent evaluation within the first month | Sens 60% Spec. 48% PPV 52% NPV 56% | Unilateral cerebral lesions in 11 patients; bilateral cerebral in 22; unilateral brainstem in 5; bilateral brainstem in 2; mixed lesion loci in 7

Evidence Table 36. Clinical (noninstrumented) Exam Detection of Aspiration in Patients with Mixed Etiology and Symptoms Indicating Dysphagia

Author | N | Study design | Test | Selection | Mean age | Characteristics | Outcomes | Comments
Logemann, [unpub] | 200 | Consecutive tests; blinded | At least 2 of cough/throat clear after swallow, reduced laryngeal elevation on swallow, history of recurrent pneumonia | Patients referred for suspected dysphagia | 65 | 25% single stroke, 9% multiple strokes, 23% cancer treatment, 10% injuries, 42% other | Sens. 69% Spec. 73% | Gold standard was aspiration at MBS; medical school
Mari, Matei, Ceravolo et al., 1997 | 93 | Consecutive tests; blinded | 3-oz water test | Neurological disorder with risk of dysphagia; cooperative; not bedridden, not unconscious or demented | 60 | 30% stroke, 8% brain injury, 29% Parkinson's, 29% NMD, 4% AD; 46% aspirated on MBS | Sens. 52% Spec. 86% PPV 76% NPV 68% | Gold standard was aspiration at MBS; rehabilitation center
Mari, Matei, Ceravolo et al., 1997 | 93 | Consecutive tests; blinded | Cough & 3-oz water test | Neurological disorder with risk of dysphagia; cooperative; not bedridden, not unconscious or demented | 60 | 30% stroke, 8% brain injury, 29% Parkinson's, 29% NMD, 4% AD; 46% aspirated on MBS | Sens. 50% Spec. 91% PPV 84% NPV 76% | Gold standard was aspiration at MBS; rehabilitation center
Leder, 1997; Ott, Hodge, Pikna et al., 1996 | 32 | Consecutive tests | BSE: various consistencies | Aspiration or pharyngeal problem indicated by BSE and patient capable of being evaluated by MBS (116 or 78% of patients with swallowing difficulties excluded) | | Mostly CVA or ND; 34% mod. to severe symptoms on MBS | Correlation coefficient 0.623, p<0.01
Garon, Engle, and Ormiston, 1996 | 100 | Consecutive tests | 3-oz water | Consecutive patients with observed or suspected dysphagia recommended for MBS | | 50% stroke, 14% dementia, 36% other | Sens. 35% Spec. 89% PPV 79% NPV 54% | Gold standard was aspiration at MBS; hospital and rehabilitation center
Linden, Kuhlemeier, and Patterson, 1993 | 238 | Consecutive tests | BSE: (battery of 9 signs) | Patients with dysphagia scheduled for MBS | 65 | 95% neurological etiologies | Sens. 64% Spec. 67% PPV 58% NPV 72% | Gold standard was aspiration at MBS; hospital department of rehabilitation medicine
Sorin, Somers, Austin et al., 1988 | 10 | Consecutive tests | BSE similar to Logemann, 1983b | Appropriate mentally and physically for MBS | 21-81 | 40% stroke, 20% head injury, 20% MS, 10% ALS, 10% other | Sens. 0% Spec. 75% PPV 0% NPV 33% | Gold standard was >5% aspiration at MBS
Splaingard, Hutchins, Sulton et al., 1988 | 107 | Consecutive tests; blinded | BSE: various consistencies | Possible swallowing dysfunction | | 81% stroke, 15% brain injury, 4% NMD, 14% children; 40% aspirated on MBS | Sens. 42% Spec. 91% PPV 75% NPV 70% Kappa 0.34 | Gold standard was aspiration at MBS; rehabilitation center
Mendelsohn, 1988 | 47 | Consecutive tests | Clinical assessment by referring team | Consecutive patients referred for swallowing difficulty | | 51% stroke, 17% other neurological, 15% surgical, 9% stroke and surgical, 15% other; 68% aspirated on MBS | Sens. 50% | Gold standard was aspiration at MBS; hospital swallowing clinic
Mendelsohn, 1988 | 47 | Consecutive tests | Clinical assessment by dysphagia team | Consecutive patients referred for swallowing difficulty | | 51% stroke, 17% other neurological, 15% surgical, 9% stroke and surgical, 15% other; 68% aspirated on MBS | Sens. 91% | Gold standard was aspiration at MBS; hospital swallowing clinic

Evidence Table 37. Clinical (noninstrumented) Exam Detection of Aspiration in Patients with Stroke and Symptoms Indicating Dysphagia

Author | N | Study design | Study design | Selection | Mean age | Characteristics | Outcomes | Comments
Kidd, Lawson, Nesbitt et al., 1993 | 60 | Consecutive tests | 50-ml water without coughing, choking or altered voice quality | Consecutive stroke patients able to undergo MBS | 72 | All acute stroke tested within 72 hrs | Sens. 60% Spec. 74% PPV 63% NPV 72% | Gold standard was aspiration without immediate expectoration; hospital, Belfast, UK
Biem and Laupacis, 1994; DePippo, Holas, and Reding, 1992 | 44 | Consecutive tests; MBS not blinded | 3-oz water | Consecutive stroke patients with dysphagia indications | 71 | All stroke | Sens. 80% Spec. 54% PPV 59% NPV 76% | Gold standard was aspiration at MBS; stroke rehabilitation unit

Evidence Table 38. Clinical (noninstrumented) Exam Detection of Aspiration in all Stroke Patients

Author | N | Study design | Test | Selection | Age | Characteristics | Results | Comments
Daniels, Brailey, Priestly et al., 1998 | 55 total 21 asp. | Consecutive tests, blinded | At least 1 clinical feature of aspiration | Consecutive patients with acute stroke | Mn 66 | All acute stroke (within 5 days); all males; 38% (21/55) aspirated at MBS | Sens. 100% | Gold standard was aspiration at MBS; VA medical center
Daniels, Brailey, Priestly et al., 1998 | 55 total 21 asp. | Consecutive tests, blinded | At least 2 clinical features of aspiration | Consecutive patients with acute stroke | Mn 66 | All acute stroke (within 5 days); all males; 38% (21/55) aspirated at MBS | Sens. 90% | Gold standard was aspiration at MBS; VA medical center
Daniels, Brailey, Priestly et al., 1998 | 55 total 21 asp. | Consecutive tests, blinded | Abnormal volitional cough & cough after swallow | Consecutive patients with acute stroke | Mn 66 | All acute stroke (within 5 days); all males; 38% (21/55) aspirated at MBS | Sens. 70% Spec. 84% PPV 78% | Gold standard was aspiration at MBS; VA medical center
Daniels, McAdam, Brailey et al., 1997 | 59 | Consecutive tests | Combination of any 2 of dysphonia, dysarthria, abnormal volitional cough, abnormal gag, cough after swallow, voice change after swallow | Consecutive acute stroke patients | Mn 66 | | Sens. 92% Spec. 67% PPV 69% NPV 92% | Gold standard was aspiration at MBS; VA medical center

Evidence Table 39. MBS Interobserver Variability of Diagnosis of Aspiration

Author | N | Study design | Selection | Mean age | Characteristics | Outcomes | Comments
Kuhlemeier, Yates, and Palmer, 1998 | 20 | All-way pairwise comparison of 9 raters (4 physicians, 5 SLPs) | Archival videotapes from 20 patients chosen to have institutional prevalence of aspiration, laryngeal penetration, and pharyngeal retention | | Majority were stroke patients in acute-care rehabilitation. | Positive agreement: Beef stew 0% Cookie <20% Spread <20% Nectar <20% Juice 85% Negative agreement: All >98% | University hospital; intraobserver agreement was similar to interobserver agreement
Perlman, Booth, and Grayhack, 1994 | 330 | Independent observations of 2 speech pathologists | Patients referred for MBS evaluation of swallowing dysfunction | | 31% stroke, 18% cancer, 17% neurological disease, 5% gastrointestinal disease | 100% agreement | VA medical center
Ekberg, Nylander, Fork et al., 1988 | 72 | Independent observations of 6 radiologists | Dysphagia patients with most common pharyngeal dysfunctions | 64 | Dysphagia patients with most common pharyngeal dysfunctions | Kappa 0.83 | Teaching hospital

Evidence Table 40. Comparison of BSE and VFSS for Prediction of Aspiration Pneumonia

Author | Study design | N | Patient characteristics | Mean age | Selection | Test | Treatment | Reported outcome | Followup | Pseudo test characteristics ^1^
Reynolds, Gilbert, Good et al., 1998 | RCS | 102 | All stroke pts who underwent both BSE and VFSS | 66 | Not silent aspirators; Dysfunction demonstrated on BSE | BSE VFSS Both | Dietary modification and "treatment recommendations" | Aspiration pneumonia | NR | Sens. 57% Spec. 46% PPV: 21% NPV: 80% Sens. 57% Spec. 73% PPV. 35% NPV. 87% Sens. 86% Spec. 37% PPV. 26% NPV. 91%
Smithard, O'Neill, Parks et al., 1996 | PCS | 121 | All stroke patients presenting within 24 hrs of event | NR | Consecutive within 24 hrs of event | BSE VFSS | NR | Chest infection | 34.9 days mean | Sens: 69% Spec. 55% PPV. 33% NPV. 84% Sens. 37% Spec. 83% PPV. 35% NPV. 84%
Smithard, O'Neill, Parks et al., 1996 | PCS | 121 | All stroke patients presenting within 24 hrs of event | NR | Consecutive within 24 hrs of event | BSE VFSS | NR | Death | 34.9 days mean | Sens: 86% Spec. 60% PPV. 37% NPV. 94% Sens. 40% Spec. 82% PPV. 22% NPV. 91%

Evidence Table 41. Pneumonia Predicted by Apparent Unsafe Swallow at BSE

Author | N | Study design | Test(s) | Selection | Age | Characteristics | Follow-up | Pneumonia | Pseudo outcomes ^1^ | Comments
Gordon, Hewer, and Wade, 1987 | 86: 37 dys 49 non-dys | Prospective case series with followup as gold standard | 50-ml water; cough more than once in two tests or unable to take test due to previous coughing, unconsciousness, or drowsiness | Consecutive stroke patients | Md 70 | All acute stroke; 90% within 4 days, 10% within 14 days; 45% (41/91) with dysphagia by test | Up to 40 days | 13%(12/91) | Sens. 64% Spec. 60% PPV. 19% NPV. 92% | General hospital, Bristol, England; treatment to prevent aspiration not specified; treatment not reported
DePippo, Holas, and Reding, 1994 | 139 | Prospective case series with followup as gold standard | BSE: Burke Dysphagia Screening Test (BDST) | Stroke patients admitted to rehabilitation center | 71 | All stroke; mean of 5 weeks post-stroke Rehab | Mean 9 weeks (SD ±5 weeks) | 7.2%(10/139) | Pneumonia (10), upper airway obstruction (1), death (2): Sens. 92% Spec. 44% PPV 13% NPV 98% | University hospital rehabilitation center Postural techniques and diet modification
DePippo, Holas, and Reding, 1994 | 139 | Prospective case series with followup as gold standard | 3-oz water | Stroke patients admitted to rehabilitation center | 71 | All stroke; mean of 5 weeks post-stroke Rehab | Mean 9 weeks (SD ±5 weeks) | 7.2% (10/139) | Pneumonia (10), upper airway obstruction (1), death (2): Sens. 92% Spec. 60% PPV 18% NPV 99% | University hospital rehabilitation center
Gottlieb, Kipnis, Sister et al., 1996 | 180 | Time series | 3-oz water | Consecutive stroke patients | 74 | Acute + rehab | 54 days | 18.3% (11/60) | Sens. 50% Spec. 75% PPV: 18% NPV. 93% | Postural and diet modification
Smithard, O'Neill, Parks et al., 1996 | 117 | Prospective case series with followup at gold standard | BSE (various quantities and consistencies of fluids) | Consecutive stroke patients presenting within 24 hours of stroke | Md 79 | All stroke; within 24 hours of stroke | 7 days | 25% (29/117) (80% also had MBS) | Sens. 69% Spec. 55% PPV 33% NPV 84% | University hospital, Manchester, England NGT then postural and diet

Evidence Table 42. Pneumonia Predicted by Aspiration at MBS

Author | N | Study design | Selection | Age | Characteristics | Follow-up | Pneumonia | Pseudo outcomes* | Comments
Johnson, McKenzie, and Sievers, 1993 | 60 | Retrospective case series | Suspected dysphagia | NR | All acute stroke | 6 mos to 1 year | 48.3% | Sens. 66% Spec. 71% PPV 68% NPV 69% | University medical center Treatment not reported
Croghan, Burke, Caplan et al., 1994 | 40 | Retrospective case series | Suspected dysphagia | Mn 69 | 90% stroke, 2% Parkinson's, 2% head injury, 2% cerebral palsy, 2% cleft palate | 1 year | 43% (17/40) | Sens. 65% Spec. 52% PPV 50% NPV 55% | Teaching nursing home; unspecified treatment following diagnosis
Holas, DePippo, and Reding, 1994 | 114 | Prospective case series | Suspected dysphagia | Mn 72 | stroke | 1 year | 7.9% (9/114) | PPV 13% NPV 98% | Inpatient stroke rehabilitation center; treated by dysphagia management program; Only those positive on MBS were reported, skewing test characteristics
Smithard, O'Neill, Parks et al., 1996 | 94 | Prospective case series with followup at gold standard | Consecutive stroke patients presenting within 24 hours of stroke | Md 79 | All stroke; within 24 hours of stroke | 7 days | 20% (19/94) | Sens. 37% Spec. 84% PPV 35% NPV 84% | University hospital, Manchester, England
Aviv, Sacco, Mohr et al., 1997 | 20 | Prospective series, MBS + sensory testing | Suspected dysphagia | Mn 65 | All strokes, tested within 4 weeks of stroke; 50% (10/20) aspirated at MBS; 30% (6/20) developed aspiration pneumonia | 2 years | 30% (6/20) | Sens. 33% Spec. 43% PPV 20% NPV 60% | Hospital; patients who aspirated at MBS were treated with PEG tube feeding; nonaspirators got noninvasive therapy
Reynolds, Gilbert, Good et al., 1998 | 102 | RCS | Suspected dysphagia | Mn 66 | All acute stroke | ~2 years | 21% (21/102) | Sens. 57% Spec. 73% PPV 35% NPV 87% | Hospital; gold standard was long-term followup for aspiration pneumonia Diet modification and "treatment"
Daniels, McAdam, Brailey et al., 1997 | 55 | RCS | Suspected dysphagia | Mn 66 | All acute stroke | LOS | 1.8% | Sens. 100% Spec. 54% PPV 3% NPV 100% | Treatment: swallow therapy and diet modification

Evidence Table 43. Pseudo-randomized Controlled Trial Comparing FEESST with MBS for Prevention of Pneumonia

Author | N | Study design | Time period and care setting | Selection | Followup | Mean age | Patient characteristics | Cumulative pneumonia (95% CI) | Difference (95% CI) | Relative reduction of risk (95% CI)
Aviv, [unpub.] | 75 51 | Pseudo-RCT: Mon. & Fri get FEESST; Wed.-Thurs. get MBS MBS FEESST | 1996-97; Outpatient otolaryngology department | Outpatient referrals | 1 year | 70 65 | 33% stroke, 38% chronic neuro. disease, 29% other 43% stroke, 10% chronic neuro. disease, 48% other | 19% (14/75) (11 to 29%) 12% (6/51) (5.5 to 23%) | 6.9% (-6.7 to 19%) (Not statistically signif.) | 36%

Evidence Table 44. Comparison of Fiberoptic Endoscopy to MBS for Prediction of Pneumonia in Stroke Patients Referred for Dysphagia Evaluation

Author | N | Study design | Test | Treatment | Selection | Age | Characteristics | Followup | Pseudo test Characteristics ^1^
Aviv, Sacco, Mohr et al., 1997 | 20 | Prospective controlled trial with blinded consecutive tests within subjects | MBS Both MBS & FEESST FEESST | Patients who aspirated at MBS were treated with PEG tube feeding | Consecutive stroke patients with dysphagia given MBS | Mn 65 | All strokes, tested within 4 weeks of stroke; 50% (10/20) aspirated at MBS; 30% (6/20) developed aspiration pneumonia All strokes, tested within 4 weeks of stroke; 70% (14/20) aspirated at MBS or had bilateral sensory deficit by FEESST; 30% (6/20) developed aspiration pneumonia All strokes, tested within 4 weeks of stroke; 60% (12/20) had bilateral sensory deficit by FEESST; 30% (6/20) developed aspiration pneumonia | 2 years | Sens. 33% Spec. 43% PPV 20% NPV 60% Sens. 83% Spec. 36% PPV 36% NPV 83% Sens. 83% Spec. 50% PPV 42% NPV 88%

Evidence Table 45. Comparison of Fiberoptic Endoscopy to MBS for Detection of Aspiration

Author | N | Study design | Selection | Mean age | Characteristics | Both positive | MBS pos. FEES neg. | MBS neg. FEES pos. | Both negative | Accuracy (pos. & neg. agree)
Leder, Sasaki, and Burrell, 1998 | 56 | Consecutive tests; blinded | Consecutive patients; referred for dysphagia evaluation | | | | | | | 96% (silent aspiration)
Kaye, Zorowitz, and Baredes, 1997 | 105 | Consecutive tests | Consecutive patients | 61 | 25% stroke, 21% primary dysphagia, 18% surgery, 18% brain injury, 18% other | 6.8% (7/103) | 24% (25/103) | 1.9% (2/103) | 67% (69/103) | 74% (76/103)
Wu, Hsiao, Chen et al., 1997 | 28 | Consecutive tests; blinded | Long-term dysphagia | 65 | 79% stroke, 14% cancer, 4% Parkinson's, 4% head injury | 54% (15/28) | 3.6% (1/28) | 11% (3/28) | 32% (9/28) | 86% (24/28)
Langmore, Schatz, and Olson, 1991 | 21 | Consecutive tests; blinded | | 63 | 43% stroke, 24% other neurologic | 38% (8/21) | 4.8% (1/21) | 4.8% (1/21) | 57% (12/21) | 95% (20/21)

Evidence Table 46. Noninvasive Swallow Therapy and Diet Modification. Outcome: Food Intake (Link T3 to O2)

Study author | Study design | Care setting | Total no. subjects | No. subjects in each arm (no. arms) | Mean age | Patient selection criteria | Diagnostic method | Primary disease(s) | Treatment(s) | Duration of treatment | Time frame of study | Outcome measures | Results
Martens, Cameron, and Simonsen, 1990 | HPCS | Acute hospital unit | 31 | 16 15 (2) | 49.3 46.1 | Glasgow coma scale score > 8 | MBS | Brain injury, tumor, CVA | Controls: no Spec. dysphagia treatment Cases: various: diet, exercise, counseling; individualized | 31.9 days 41.1 days | NR | Kilojoule intake relative to desired | Treatment: -407.31 kj Controls: -2044.86 kj

Evidence Table 47. Noninvasive Swallow Therapies. Outcome: Feeding Method (Link T1 to O3)

Study author | Study design | Care setting | Total no. subjects | No. subjects in each arm (no. arms) | Mean age | Primary disease(s) | Treatment(s) | Duration of treatment | Followup time | Outcome measures | Results
Neumann, Bartolome, Buchholz et al., 1995 | RCS | Neuro rehab facility | 58 | Various (3) | 57 (med) | CVA, brain damage, neoplasms | Indirect (29) or direct swallow therapy (1), or both (28) | 15 wks median | NR | Resumed exclusively oral feeding | Post-treatment: 67.2% (39/58)
Selley, Roche, Pearce et al., 1995 | RCS | Hospital | 30 | 30 (1) | 76 | CVA | Palatal training appliance (PTA) | Permanent? | 12 months | NG tube feeding | Pre-treatment: 26.7% (8/30) Post-treatment: 9.1% new (2/22)
Neumann, 1993 | CS | Neuro rehab facility | 66 | 66 (1) | 55 (med) | Neurologic | Indirect and direct swallow therapy | 17 weeks median | NR | Feeding method: Oral Tube Both Oral to tube Tube to oral | Pre-treatment: 33.3% (22/66) 60.6% (40/66) 6.1% (4/66) Post-treatment: 9.1% (2/22) 67.5% (27/40)
Selley, 1985 | CCS | Various | 170 | 170 (1) | NR | NR | Palatal training appliance (PTA) | NR | NR | Success rate (cessation of drooling, ability to swallow w/o choking) | Post-treatment: 96.5% (164/170)

Evidence Table 48. Noninvasive Swallow Therapy and Diet Modification. Outcome: Feeding Method (Link T3 to O3)

Study author | Study design | Care setting | Total no. subjects | No. subjects in each arm (no. arms) | Mean age | Primary disease(s) | Treatment(s) | Duration of treatment | Time frame of study | Outcome measures | Results
Odderson, Keaton, and McKenna, 1995 | HPCS | Hospital | 48 | 48 (1) | NR | CVA, non-hemorrhagic | Food texture modifications and "further intervention" | LOS | Circa. 1 week | Recovery of swallow function by discharge Placement of feeding tube after treatment | 21% (10/48) 19% (9/48)
DePippo, Holas, Reding et al., 1994 | RCT | Inpatient rehab unit | 115 | 38 (3) | 76 74.5 73 | CVA | Group I: diet and swallow technique recommended alone Group II: therapist-prescribed diet and technique recommendations Group III: therapist prescribed diet and techniques reinforced | circa. 2 months | 1 year | Independent eating (>75%) Feeding tube placement post-treatment | Group 3 used swallowing techniques independently by discharge more often than groups 1 and 2 0%

Evidence Table 49. Noninvasive Swallow Therapy and Diet Modification. Outcome: Weight Change (Link T3 to O4)

Study author | Study design | Care setting | N | N in each arm (no. arms) | Mean age | Primary disease(s) | Treatment(s) | Duration of treatment | Time frame of study | Outcome measures | Results
Martens, Cameron, and Simonsen, 1990 | HPCS | Acute hospital unit | 31 | 16 treatment 15 controls (2) | 49.3 46.1 | Brain injury, tumor, CVA | Cases: various (diet, exercise, counseling-individualized) Controls: no spec. dysphagia treatment | 31.9 days 41.1 days | NR | Weight change | Cases: +1.41 kg Controls: -2.82 kg

Evidence Table 50. Feeding Tubes. Outcome: Weight Change (Link T4 to O4)

Study Author | Study design | Care setting (after acute care) | Total no. subjects | No. subjects in each arm (no. arms) | Mean age | Primary disease(s) | Treatment(s) | Followup time | Outcome measures | Results
Golden, Beber, Weber et al., 1997 | RCS | Nursing home | 102 | NA | 89 (mean) 71-104 (range) | 99% neurological; 20% stroke | All had PEG, but had been admitted to nursing home without feeding tube. Inclusion criteria: probable survival of at least 1 month and dysphagia for a minimum of 4 weeks | 6 months, for 76% of sample who survived the interval | Amount of weight gain | 11.9 pounds (mean) [= 5.4 kg] -15 - 30 lbs (range) [= -6.75 - 13.5 kg]
Britton, Lipscomb, Mohr et al., 1997 | RCS | Various | 32 | NA | 49 (mean) 16-80 (range) | 100% neurological; 0% stroke 81.2% dysphagic | All had PEG | 6 months (median) 1-36 months (range) | Amount of weight gain | 9 kilograms (mean) 3.5-13.6 kilograms (range)
Norton, Homer-Ward, Donnelly et al., 1996 | RCT | NR | 30 | 16 (PEG) 14 (NGT) | 76 (mean) 79 (mean) ranges NR | All patients had acute dysphagic stroke; dysphagia persisting 8 or more days ^1^ | PEG tube placement NG tube placement | 1 - 6 weeks for 13 pts. surviving 1 - 6 weeks for 8 pts. surviving | Amount of weight change Amount of weight change | 2.2 kilograms (mean) -0.6 - 5.2 kilograms (range) -2.6 kilograms (mean) 0.38 - 5.1 kilograms (range)
Kaw and Sekas, 1994 | RCS | Nursing home | 46 | NA | 74 (mean) 19-96 (range) | 91% neurological; 24% stroke; nursing home patients | All had PEG | For subset of 43 patients, 1-6 months after PEG | Percent patients who gained weight: 1-6 mos post-PEG 13-16 mos post-PEG | 50% 36%
Sant, Gilvarry, Shannon et al., 1993 | RCS | Various | 29 | NA | 71 (med) 29-86 (range) | 100% neurological; 67% stroke | All had PEG | For subset of 22 patients who survived, 4 weeks | Amount of weight gain | 4.5 kilograms (mean) 3-7 kilograms (range)
Park, Allison, Lang et al., 1992 | RCT of PEG and NGT; only PEG reported here because of very large attrition from NGT group (95%) | NR | 20 | NA | 56 (mean) 4.8 (SE) | 100% neurological; 35% stroke | All had PEG | For subset of 18 patients who survived, 4 weeks | Amount of weight gain | 3.4 kilograms (mean) 0.6 kilograms (SE)
Llaneza, Menendez, Roberts et al., 1988 | RCS | Home, Nursing home | 73 | NA | 67 (mean) 30-96 (range) | 62% neurological; % stroke unknown; all male | All had PEG | 14 months (mean) 1.5-26 months (range) | Percent patients who gained weight | 18

Evidence Table 51. Noninvasive Swallow Therapies. Outcome: Aspiration (Link T1 to O5)

Study author | Study design | Care setting | Total no. subjects | No. subjects in each arm (no. arms) | Mean age | Primary disease(s) | Treatment(s) | Duration of treatment | Followup time | Outcome measures | Results
Rasley, Logemann, Kahrilas et al., 1993 | CCS | NR | 165 | 165 (1) | 59 | Cancer 39% CVA 29% Other 35% | Postural changes while swallowing liquid boluses (1, 3, 5, 10 ml): chin tuck, head turn, side lying | NR | NR | Aspiration elimination | Aspiration eliminated for at least one problematic volume in 77% (127/165) No success on any bolus volume in 23% (38/165) Eliminated on all problematic bolus volumes in 19.8% (21/165)

Evidence Table 52. Diet Modification. Outcome: Aspiration (Link T2 to O5)

Study author | Study design | Care setting | Total no. subjects | No. subjects in each arm (no. arms) | Mean age | Primary disease(s) | Treatment(s) | Duration of treatment | Time frame of study | Outcome measures | Results
Spiegel, Creed, Selber et al., unpub.(b) | CS | Nursing home | 122 | 24 13 59 26 (4) | 83 | NR | Feeding tube Puree Thick liquid Thin liquid | NR | 5.3 mos (m) | Aspiration | Pre-treatment: 43.4% (53/122) Post-treatment: 0% (0/122)

Evidence Table 53. Swallow Therapy and Diet Modification. Outcome: Aspiration (Link T3 to O5)

Study author | Study design | Care setting | Total no. subjects | No. subjects in each arm (no. arms) | Mean age | Primary disease(s) | Treatment(s) | Duration of treatment | Time frame of study | Outcome measures | Results
Odderson, Keaton, and McKenna, 1995 | CS | Hospital | 48 | 48 (1) | NR | CVA, non-hemorrhagic | Food texture modifications and "further intervention" | LOS | circa. 1 week | Aspiration | No. cases of aspiration before or after treatment

Evidence Table 54. Feeding Tubes. Outcome: Aspiration (Link T4 to O5)

Author | N | Study design | Setting (post-acute care) | Time period | Selection | Mean age (range/SE) | Pt. characteristics: %neur; %CVA | Mean followup days (range) | % Asp | Comments
Kadakia, Sullivan, and Starnes, 1992 | 72 | RCS | Various | July 1986 - July 1989 | Patients who underwent PEG | 60 (8-90) | 58; NR | acute care | 4
Wolfsen, Kozarek, Ball et al., 1990 | 116 75 | RCS | Various | March 1984 - Nov 1988 | Successful PEG placement Successful PEJ placement | NR; NR | 48; 25 | 30 (30-30) | 5 17 | Demographics not broken out by PEG/J
Stern, 1986 | 100 | PCS | NR | Oct 1983 - Dec 1985 | PEG performed by author | 76 (8-101) | 85; NR | Unclear: "post-op" aspiration | 1

Evidence Table 55. Feeding Tubes. Outcome: Tube Complications (Link T4 to O6)

Author | N | Study design | Setting (post-acute care) | Time period | Selection | Mean age (range/SE) | Pt characteristics: %neur; %CVA | Mean followup days (range) | % Tube block | % Infection | % Pain | % Tube pulled out | % Tube migration | % Cellulitis | % Tube leak | % Other
Golden, Beber, Weber et al., 1997 | 102 | RCS | Nursing home | Aug 1987 - March 1995 | Patients underwent successful PEG | 89 (71-104) | 99; 20 | NR (210-2,765) | | | | | 2 | | | 1 - bleeding
Kaw and Sekas, 1994 | 46 | RCS | Nursing home | Aug 1988 - Nov 1990 | Nursing home residents with PEG | 74 (19-96) | 91; 24 | 321 (2-520) | 30 | 4 | | | 21 | | 13
Grant, 1993 | 595 | CS | NR | Jan 1985 - March 1992 | Patients referred for PEG | 61 (16-91) | NR / NR most neur. | Acute care | | 1 | | | | | 2 | <1- bleed
Kadakia, Sullivan, and Starnes, 1992 | 79 | RCS | Various | July 1986 - July 1989 | Patients who underwent PEG or PEJ | 60 (8-90) | 58; NR | Acute care | | | | | 4 | 3 | 3 | 1- gastric ulcer
Jarnagin, Duh, Mulvihill et al., 1992 | 60 | RCS | NR | July 1986 - July 1990 | Patients who underwent PEG | 60 (20-93) | 47; NR (most) | Acute care | 3 | | | 5 | | 5
Taylor, Larson, Ballard et al., 1992 | 92 | RCS | Various | Jan 1982 - Dec 1988 | Referred for PEG | 76 ^1^ (1-97) | 80; 57 | 327 ^1^ (1-2,664) | 8 | 41 | 3 | 41 | 3 | | 8 | 3 - hematoma 7 - gastric hemorr 3 - dehydration 1 - gastric fistula
Stiegmann, Goff, Silas et al., 1990 ^ 2^ | 61 57 | RCT | NR | Dec 1984 - Oct 1988 | Succ. PEG placement Successful OG | 62 (12-92) | 81; NR | Acute care | | 3 9 | | | 7 5 | | 2 2 | 5 - bleeding 0 - bleeding
Wolfsen, Kozarek, Ball et al., 1990 | 116 75 | RCS | Various | March 1984 - Nov 1988 | Succ. PEG placement Succ PEJ placement | NR; NR | 48; 25 | 275 (NR-NR) | 9 23 | | | | 3 15 | | 9 11 | 3 - breakage 5 - breakage
Miller, Castlemain, Lacqua et al., 1989 | 302 | RCS | NR | Nov 1984 - Oct 1988 | Patients who underwent PEG | 75 (1-102) | 75; NR | 30 (30-30) | | 0 | | | 4
Llaneza, Menendez, Roberts et al., 1988 | 73 | RCS | Home, Nursing home | April 1984 - July 1986 | Patients who underwent PEG and had available followup information | 67 (30-96) | 62; NR | 420 (45-780) | 8 | | 7 | 4 | | 12 | 3
Larson, Burton, Schroeder et al., 1987 | 299 | RCS | Various | 1983 - NR (not stated) | Consecutive pts with PEG | ap 64; 3-92 ^2^ | 75; NR | 30 (30-30) | | 6 | | 2 | <1 | | 1 | 1 - ileus
Kirby, Craig, Tsang et al., 1986 | 51 | RCS | NR | 1983 - 1984 | All PEG patients | NR (18 - 90) | 87; NR | Up to 210 | 4 | | | 12 | | 10
Stern, 1986 | 100 | PCS | NR | Oct 1983 - Dec 1985 | PEG performed by author | 76 (8-101) | 85; NR | 30 (30-30) | | 1 | | | | | 4 | 1 - bleeding
Ponsky, Gauderer, and Stellato, 1983 | 150 | RCS | NR | June 1979 - May 1982 | Patients who underwent PEG | NR (3w - 97) | 79; NR | Acute care | | 5 | | | 2 | | | 1- pneumoperit

Evidence Table 56. Noninvasive Swallow Therapies. Outcome: Pneumonia (Link T1 to M1)

Study Author | Study design | Care setting | Total no. subjects | No. subjects in each arm (no. arms) | Mean age | Primary disease(s) | Treatment(s) | Duration of treatment | Time frame of study | Outcome measures | Results
Kasprisin, Clumeck, and Nino-Murcia, 1989 | Retro CT | VA medical center | 69 | 48 13 8 (3) | NR | Various | Swallow therapy | 1 to 36 weeks | NR | Incidence of aspiration pneumonia after therapy | Group 1 (no asp. Pneu.history): 6.3% (3/48) Group 2 (asp. Pneu. History): 15.4% (2/13) Group 3 (not treated): 100% (8/8)
Selley, Roche, Pearce et al., 1995 | RCS | Hospital, rehab | 30 | 30 (1) | 76 | CVA | Palatal training appliance (PTA) | Permanent? | 12 mos | Aspiration pneumonia | Pre-treatment: 36.7% (11/30) Post-treatment: 16.7% (5/30)

Evidence Table 57. Diet Modification. Outcome: Pneumonia (Link T2 to M1)

Study author | Study design | Care setting | Total no. subjects | No. subjects in each arm (no. arms) | Mean age | Primary disease(s) | Treatment(s) | Duration of treatment | Time frame of study | Outcome measures | Results
Groher, 1987 | RCT | Chronic care facility | 46 | 23 (2) | 71.8 74.2 | CVA with history of asp. Pneumonia | I: Pureed diet II: Mechanically altered diet | NR | 6 mos | Pneumonia incidence with treatment | I: 86.9% (20/23) II: 17.4% (4/23)

Evidence Table 58. Swallow Therapy and Diet Modification. Outcome: Pneumonia (Link T3 to M1)

Study author | Study design | Care setting | Total no. subjects | No. subjects in each arm (no. arms) | Mean age | Primary disease(s) | Treatment(s) | Duration of treatment | Time frame of study | Outcome measures | Results
Gottlieb, Kipnis, Sister et al., 1996 | CS | Stroke rehab unit | 180 | 50 (1) | 74 | CVA | Diet modification and swallow therapy | LOS | LOS (53.5 days mean) | Pneumonia incidence | 18% (9/50)
DePippo, Holas, Reding et al., 1994 | RT | Inpatient rehab unit | 115 | 38 (3) | 76 74.5 73 | CVA 100% | Group I: diet and swallow technique recommended alone Group II: therapist-prescribed diet and technique recommendations Group III: therapist prescribed diet and techniques reinforced | Circa. 2 months | 1 year | Pneumonia incidence | Pneumonia: I: 2.6% (1/38) II: 13.2% (5/38) III: 5.1% (2/38) Aspirators developed pneumonia sooner than nonaspirators (p= 0.02).
Martens, Cameron, and Simonsen, 1990 | HPCS | Acute hospital unit | 31 | 16 treatment 15 controls (2) | 49.3 46.1 | Brain injury, tumor, CVA | Cases: various (diet, exercise, counseling-individualized) Controls: no spec. dysphagia treatment | 31.9 days 41.1 days | NR | Aspiration pneumonia incidence | Treatment group: 0 Control group: 0

Evidence Table 59. Feeding tubes. Outcome: Pneumonia (Link T4 to M1)

Author | N | Study design | Setting (post-acute care) | Time period | Selection | Mean age (range/SE) | Pt. Characteristics: %neur; %CVA | Mean followup days (range) | % Pneum., asp pneum. | Comments
Golden, Beber, Weber et al., 1997 | 102 | RCS | Nursing home | Aug 1987 - March 1995 | Patients underwent successful PEG | 89 (71-104) | 99; 20 | NR (210-2765) | 51 | Referred from nursing home; 87% dementia
Kaw and Sekas, 1994 | 46 | RCS | Nursing home | Aug 1988 - Nov 1990 | Nursing home residents with PEG | 74 (19-96) | 91; 24 | 321 (2-520) | 20 | Nursing home pop; coma in 2/3 of CVA
Grant, 1993 | 595 | CS | NR | January 1985 - March 1992 | Patients who underwent PEG | 61 (16-91) | NR / NR most neur. | 75 (1 - 972) | <1 | 65% had altered mental status
Jarnagin, Duh, Mulvihill et al., 1992 | 60 | RCS | NR | July 1986 - July 1990 | Patients who underwent PEG | 60 (20-93) | 47; NR (most) | Acute care | 8
Taylor, Larson, Ballard et al., 1992 | 92 | RCS | Various | Jan 1982 - Dec 1988 | Referred for PEG | 76 ^1^ (1-97) | 80; 57 | 327 ^1^ (1-2,664) | 46 | Community-based; 55% not alert at PEG
Stiegmann, Goff, Silas et al., 1990 | 61 | RCT | NR | Dec 1984 - Oct 1988 | All patients over 18 years referred for PEG or operative gastrostomy | 62 (12-92) | 81; NR | Acute care | 3 | Demographics for 69 patients; 8 not followed
Miller, Castlemain, Lacqua et al., 1989 | 302 | RCS | NR | Nov 1984 - Oct 1988 | Patients who underwent PEG | 75 (1-102) | 75; NR | 30 (30-30) | 2
Cogen and Weinryb, 1989 | 109 | RCS | Nursing home | Jan 1985 - May 1988 | All available records of gastrostomy patients over age 60; hospice pts not included | 73 (61-103) | 43; 41 | 24 (2-142) | 17 | No terminally ill; 15% surgical gastrostomy
Llaneza, Menendez, Roberts et al., 1988 | 73 | RCS | Home, Nursing home | April 1984 - July 1986 | Patients who underwent PEG and had available followup information | 67 (30-96) | 62; NR | 420 (45-780) | 8 | All were men
Kirby, Craig, Tsang et al., 1986 | 51 | RCS | NR | 1983 - 1984 | All PEG patients | NR (18 - 90) | 87; NR | Up to 210 | 10

Evidence Table 60. Diet Modification. Outcome: Malnutrition/Wasting (Link T2 to M2)

Study Author | Study design | Care setting | Total no. subjects | No. subjects in each arm (no. arms) | Mean age | Primary disease(s) | Treatment(s) | Duration of treatment | Followup time | Outcome measures | Results
Keller, 1995 | PCS | Nursing home | 36 | 6 adequately nourished 30 malnourished | NR | Neurologic | Diet modification | 1 year | 1 year | Weight gain or loss in each group | Malnourished who remained malnourished: ~63.3% (19/30) Adequately nourished who became malnourished: ~33.3% (2/6)

Evidence Table 61. Feeding Tubes. Outcome: Major Tube Complications (Link T4 to M4)

Author | N | Study design | Setting (post-acute care) | Time period | Selection | Mean age (range/SE) | Pt. Characteristics: %neur; %CVA | Mean followup days (range) | Outcome | Results | Comments
Golden, Beber, Weber et al., 1997 | 102 | RCS | Nursing home | Aug 1987 - March 1995 | Patients underwent successful PEG | 89 (71-104) | 99; 20 | NR (210-2765) | Gastric fistula Bowel obstruction | 1.0 2.0 | Referred from nursing home; 87% dementia
Kaw and Sekas, 1994 | 46 | RCS | Nursing home | Aug 1988 - Nov 1990 | Nursing home residents with PEG | 74 (19-96) | 91; 24 | 321 (2-520) | Surgical repair following bowel obstruction Gastrointestinal bleeding | 4.3 4.3 | Nursing home population; coma in 2/3 of CVA
Grant, 1993 | 595 | CS | NR | January 1985 - March 1992 | Patients who underwent PEG | 61 (16-91) | NR / NR most neur. | 75 (1 - 972) | Peritonitis Severe infection | 0.8 0.2 | 65% had altered mental status
Kadakia, Sullivan, and Starnes, 1992 | 79 | RCS | Various | July 1986 - July 1989 | Patients who underwent PEG or PEJ | 60 (8-90) | 58; NR | Acute care | Closure failure | 1.3 | 7 received PEJ, not PEG
Jarnagin, Duh, Mulvihill et al., 1992 | 60 | RCS | NR | July 1986 - July 1990 | Patients who underwent PEG | 60 (20-93) | 47; NR (most) | Acute care | Gastric bleeding Necrotizing fasciitis | 1.6 1.6
Taylor, Larson, Ballard et al., 1992 | 92 | RCS | Various | Jan 1982 - Dec 1988 | Referred for PEG | 76* (1-97) | 80; 57 | 327* (1-2664) | Gastric hemmorhage Ileus | 2.2 4.3 | Community based; 55% not alert at PEG
Miller, Castlemain, Lacqua et al., 1989 | 302 | RCS | NR | Nov 1984 - Oct 1988 | Patients who underwent PEG | 75 (1-102) | 75; NR | 30 (30-30) | Gastric fistula Peritonitis | 0.3 1.7
Llaneza, Menendez, Roberts et al., 1988 | 73 | RCS | Home, Nursing home | April 1984 - July 1986 | Patients who underwent PEG and had available followup information | 67 (30-96) | 62; NR | 420 (45-780) | Septicemia | 1.4 | All were men
Larson, Burton, Schroeder et al., 1987 | 299 | RCS | Various | 1983 - ? (not stated) | Consecutive pts with PEG | ~64; 3-92 b | 75; NR | 30 (30-30) | Gastric bleeding Gastric perforation Hematoma | 1.3 0.7 0.3 | Used abdominal binder
Stern, 1986 | 100 | PCS | NR | Oct 1983 - Dec 1985 | PEG performed by author | 76 (8-101) | 85; NR | 30 (30-30) | Peritonitis | 1.0
Ponsky, Gauderer, and Stellato, 1983 | 150 | RCS | NR | June 1979 - May 1982 | Patients who underwent PEG | NR (3w - 97) | 79; NR | Acute care | Gastric fistula | 1.3 | Early report

Evidence Table 62. Feeding Tubes. Outcome: QOL (Link T4 to O7)

Study author | Study design | Care setting (post-acute care) | Total no. subjects | No. subjects in each arm (no. arms) | Mean age | Primary disease(s) | Treatment(s) | Duration of treatment | Followup time | Outcome measures | Results
McNabney, Beers, and Siebens, 1994 | PCS; Questionnaire | Hospitals | 58 | 58 (1) | 81.6 | 43% dementia 38% CVA | PEG | >1 month | 1 month | QOL as rated by surrogate caregiver: At tube placement One month later Scale: 1 to 5 (5 = very good) | 2.12 2.24 At followup, 19% rated QOL higher, 17% lower, 64% no change
Llaneza, Menendez, Roberts et al., 1988 | RCS | Home, Nursing home | 73 | NA | 67 (mean) 30-96 (range) | 62% neurological; % stroke unknown; all male | All had PEG | NA | 14 months (mean) 1.5-26 months (range) | Percent of cases for which "care for the PEG tube was deemed difficult" by telephone poll of family members and nursing personnel who cared for 42 patients who responded to followup call | 7%

Evidence Table 63. Noninvasive Swallow Therapy. Outcome: Mortality (Link T1 to O8, O9)

Study author | Study design | Care setting | Total no. subjects | No. subjects in each arm (no. arms) | Mean age | Primary disease(s) | Treatment(s) | Duration of treatment | Time frame of study | Outcome measures | Results
Selley, Roche, Pearce et al., 1995 | RCS | Hospital | 30 | 30 (1) | 76 | CVA | Palatal training appliance (PTA) | Permanent? | 12 months | 4 month mortality | 23.3% (8/30)

Evidence Table 64. Diet Modification. Outcome: Mortality (Link T2 to O8, O9)

Study author | Study design | Care setting | Total no. subjects | No. subjects in each arm (no. arms) | Mean age | Primary disease(s) | Treatment(s) | Duration of treatment | Followup time | Outcome measures | Results
Spiegel, Creed, Selber et al., unpub.(a) | CS | Nursing home | 122 | 24 13 59 26 (4) | 83 | NR | Feeding tube Puree Thick liquid Thin liquid | NR | 5.3 mos (m) | Mortality | 16.7% (4/24) 38.5% (5/13) 22.0% (13/59) 26.9% (7/26)

Evidence Table 65. Noninvasive Swallow Therapy and Diet Modification. Outcome: Mortality (Link T3 to O8, O9)

Study author | Year | Study design | Care setting | Total no. subjects | No. subjects in each arm (no. arms) | Mean age | Primary disease(s) | Treatment(s) | Duration of treatment | Followup time | Outcome measures | Results
DePippo, Holas, Reding et al., 1994 | 1994 | RT | Stroke rehab unit | 115 | 38 (3) | 76 74.5 73 | CVA | Group I: diet and swallow technique recomm. alone Group II: therapist-prescribed diet and technique recommendations Group III: therapist-prescribed diet and techniques reinforced | Circa. 2 months | 1 year | 2 month mortality | I: 0 II: 0 III: 0

Evidence Table 66. Feeding Tubes. Outcome: Mortality Resulting from Underlying Illness (not from aspiration, aspiration pneumonia, or tube-related complications) (Link T4 to O8)

Author | N | Study design | Setting (post-acute care) | Time period | Selection | Mean age (range/SE) | %Neur; %CVA | Followup in days (range) | % Died | Comments
Kaw and Sekas, 1994 | 46 | RCS | Nursing home | Aug 1988 - Nov 1990 | Nursing home residents with PEG | 74 (19-96) | 91; 24 | 321 (2-520) | 14 | Nursing home population; coma in 2/3 of CVA
Grant, 1993 | 595 | RCS | NR | Jan 1985 - March 1992 | Patients who underwent PEG | 61 (16-91) | NR;NR Most neur. | 75 (1-972) | 20 | 65% had altered mental status
Kadakia, Sullivan, and Starnes, 1992 | 79 | RCS | Various | July 1986 - July 1990 | Patients who underwent PEG | 60 (8-90) | 58; NR | 30 (30-30) | 9 | 7 with PEJ
Taylor, Larson, Ballard et al., 1992 | 97 | RCS | Various | July 1986 - July 1989 | Patients who underwent PEG or PEJ | 76 ^1^ (1-97) | 80; 57 | 30 (30-30) | 10 | Community-based; 55% not alert at PEG
Taylor, Larson, Ballard et al., 1992 | 97 | RCS | Various | Jan 1982 - Dec 1988 | Referred for PEG | 76 ^1^ (1-97) | 80; 57 | 365 (365-365) | 28 | Community-based; 55% not alert at PEG
Jarnagin, Duh, Mulvihill et al., 1992 | 60 | RCS | Various | Jan 1982 - Dec 1988 | Referred for PEG | 60 (20-93) | 47; NR (most) | 30 (30-30) | 5
Stiegmann, Goff, Silas et al., 1990 | 61 | RCT | NR | Dec 1984 - Oct 1988 | Successful PEG placement Successful operative gastrostomy | 62 (12-92) | 81; NR | 30 (30-30) | 13 9 | Related to underlying disorder
Miller, Castlemain, Lacqua et al., 1989 | 302 | RCS | NR | Nov 1984 - Oct 1988 | Patients who underwent PEG | 75 (1-102) | 75; NR | 30 (30-30) | 17
Cogen and Weinryb, 1989 | 109 | RCS | Nursing home | Jan 1985 - May 1988 | All available records of gastrostomy patients over age 60; hospice pts not included | 73 (61-103) | 43; 41 | 24 (2-142) | 18 | No terminally ill; 15% surgical gastrostomy
Larson, Burton, Schroeder et al., 1987 | 299 | RCS | Various | 1983 - ? (not stated) | Consecutive pts with PEG | ~64 (3-92) ^2^ | 75; NR | 30 (30-30) | 15 | (2% of 299 had asp pre-PEG; all died of respiratory failure)
Stern, 1986a | 100 | PCS | NR | Oct 1983 - Dec 1985 | PEG performed by author | 76 (8-101) | 85; NR | 30 (30-30) | 4 | Causes unrelated to PEG
Stern, 1986b | 100 | PCS | NR | Oct 1983 - Dec 1985 | PEG performed by author | 76 (8-101) | 85; NR | 100 (? - ?) | 24 | "Secondary to underlying disease"

Evidence Table 67. Feeding Tubes. Outcome: Mortality from Morbidity (pneumonia, aspiration) (Link T4 to O9)

Author | N | Study design | Setting (post-acute care) | Time period | Selection | Mean age (range/SE) | Pt. Characteristics: %neur; %CVA | Mean followup days (range) | % Pneum; asp pneum | % Asp | Comments
Ryan, Byrd, and Eleazer, 1995 | 19 | RCS | Nursing home | ? - 12 month period | Patients who underwent PEG | 76 (52-92) | NR; NR | 365 (365-365) | | 11 | Elderly referred from long-term care
Kaw and Sekas, 1994 | 46 | RCS | Nursing home | Aug 1988 - Nov 1990 | Nursing home residents with PEG | 74 (19-96) | 91;24 | 321 (2-520) | 15 | | Nursing home population; coma in 2/3 of CVA
Kadakia, Sullivan, and Starnes, 1992 | 79 | RCS | Various | July 1986 - July 1989 | Patients who underwent PEG or PEJ | 60 (8-90) | 58; NR | 30 (30-30) | | 4 | 7 with PEJ
Taylor, Larson, Ballard et al., 1992 | 97 | RCS | Various | Jan 1982 - Dec 1988 | Referred for PEG | 76* (1-97) | 80; 57 | 30 (30-30) | 12 | | Community-based; 55% not alert at PEG
Taylor, Larson, Ballard et al., 1992 | 97 | RCS | Various | Jan 1982 - Dec 1988 | Referred for PEG | 76* (1-97) | 80; 57 | 365 (365-365) | 25 | | Community-based; 55% not alert at PEG
Jarnagin, Duh, Mulvihill et al., 1992 | 60 | RCS | Various | July 1986 - July 1990 | Patients who underwent PEG | 60 (20-93) | 47; NR (most) | 30 (30-30) | | 7
Cogen and Weinryb, 1989 | 109 | RCS | Nursing home | Jan 1985 - May 1988 | All available records of gastrostomy patients over age 60; hospice pts not included | 73 (61-103) | 43; 41 | 24 (2-142) | 6 | | No terminally ill; 15% surgical gastrostomy
Miller, Castlemain, Lacqua et al., 1989 | 302 | RCS | NR | Nov 1984 - Oct 1988 | Patients who underwent PEG | 75 (1-102) | 75; NR | 30 (30-30) | 0.3
Larson, Burton, Schroeder et al., 1987 | 299 | RCS | Various | 1983 - ? (not stated) | Consecutive pts with PEG | ap 64 (3-92)a | 75; NR | 30 (30-30) | | 1 | Used abdominal binder
Kirby, Craig, Tsang et al., 1986 | 51 | RCS | NR | 1983 - 1984 | All PEG patients | NR (18 - 90) | 87; NR | Up to 210 | 6
Stern, 1986 | 100 | PCS | NR | Oct 1983 - Dec 1985 | PEG performed by author | 76 (8-101) | 85; NR | 30 (30-30) | 2

Evidence Table 68. Feeding Tubes. Outcome: Mortality from Treatment (Link T4 to O10)

Author | N | Study design | Setting (post-acute care) | Time period | Selection | Mean age (range/SE) | Pt. Characteristics: %neur; %CVA | Mean followup days (range) | Outcomes | Result (%) | Comments
Kaw and Sekas, 1994 | 46 | RCS | Nursing home | Aug 1988 - Nov 1990 | Nursing home residents with PEG | 74 (19-96) | 91;24 | 321 (2-520) | Sepsis | 13 | Nursing home pop; coma in 2/3 of CVA
Grant, 1993 | 595 | RCS | NR | Jan 1985 - March 1992 | Patients who underwent PEG | 61 (16-91) | NR; NR Most neur. | 75 (1 - 972) | Peritonitis | <1 | 65% had altered mental status
Kadakia, Sullivan, and Starnes, 1992 | 79 | RCS | Various | July 1986 - July 1989 | Patients who underwent PEG or PEJ | 60 (8-90) | 58; NR | 30 (30-30) | Peritonitis | 3 | 7 with PEJ
Miller, Castlemain, Lacqua et al., 1989 | 302 | RCS | NR | Nov 1984 - Oct 1988 | Patients who underwent PEG | 75 (1-102) | 75; NR | 30 (30-30) | Peritonitis | 0.3
Larson, Burton, Schroeder et al., 1987 | 299 | RCS | Various | 1983 - ? (not stated) | Consecutive pts with PEG | ap 64 (3-92)a | 75; NR | 30 (30-30) | Laryngosp. | <1 | Used abdominal binder
Stern, 1986 | 100 | PCS | NR | Oct 1983 - Dec 1985 | PEG performed by author | 76 (8-101) | 85; NR | 30 (30-30) | Peritonitis | 1
Ponsky, Gauderer, and Stellato, 1983 | 150 | RCS | NR | June 1979 - May 1982 | Patients who underwent PEG | NR (3 wks - 97) | 79; NR | acute care | Respiratory failure | 1 | Only assessed in acute care

Evidence Table 69. All Studies Reporting Aspiration Pneumonia or Pneumonia as Outcome with Either a Within-Study Control or a Historical Control

Author | N | Study design | Time period and care setting | Selection | Intervention | Followup | Mean age | Patient characteristics | Cumulative pneumonia (95% CI) | Difference (95% CI) | Relative reduction of risk | P value Fisher's exact test
Daniels, Brailey, Priestly et al., 1998 | 55 | CS CS | VA medical center | Consecutive patients admitted with new strokes | Historical control (Evidence Table) All got MBS; All patients with dysphagia treated with diet consistency, SLP therapy, tubes as needed | 2 wks ^1^ 2 wk ^1^ | 66 | Acute stroke Acute stroke | 8.2% (123/1499) (6.9 to 9.7%) 1.8% (1/55) (0.3 to 9.6%) | 6.4% (-1.5 to 8.5%) | 78% | 0.056
Nilsson, Ekberg, Olsson et al., 1998 | 72 | CS CS | University hospital stroke unit, Sweden | Consecutive stroke patients evaluable | Historical control (Evidence Table) Patient self-report of dysphagia; diet consistency, IV drips (no tube) | 2 wks ^1^ 2 wks ^1^ | 76 | Acute Stroke Acute stroke | 8.2% (123/1499) (6.9 to 9.7%) 2.2% (2/72) (0.5 to 8.7) | 6.0% (-0.6 to 8.3%) | 73% | 0.063
Spiegel, Creed, Selber et al., unpub.(a) 6 mos. Before program 1^st^ 6 mos. of program | 85 ^1^ 85 | HPCS | 2 Nursing homes | Referred for dysphagia evaluation | BSE with SLP therapy FEES with SLP therapy | 0 to 6 mos. 0 to 6 mos. | ? 81 | Mixed etiology ? 9% on tube | 13% ^1^ (11/85 ^1^ ) (7.4 to 22% ^1^ ) 0 (0/85) (0 to 4.3%) | 13% ^1^ (5.9 to 22% ^1^ ) | 100% ^1^ (74 to 100% ^1^ ) | 0.0003
Odderson, Keaton, and McKenna, 1995 | 90 124 | HPCS | 1990, Urban community hospital 1993 | Consecutive acute non-hemorrhagic stroke | Year before program BSE-stroke pathway 2^nd^ year | 7 days ^2^ (0.934) 7 days ^2^ (0.993) | 75 75 | Acute stroke | 6.3% (6/90) (2.8 to 13%) 0 (0/124) (0 to 3.0%) | 6.3% (1.7 to 13%) | 100% | 0.0050
Selley, Roche, Pearce et al., 1995 | 30 | PPT | Hospital, rehab | | Palatal training appliance (PTA) | | | Stroke | 75% (6/8) (41 to 93%) 27% (3/11) (9.7 to 57%) | 48% (2.8 to 73%) | 64% | 0.210
DePippo, Holas, Reding et al., 1994 | 38 38 38 | RCT | Inpatient rehab unit | | Diet and swallow technique only recommended Therapist-prescribed diet; technique only recommended Therapist-prescribed diet and techniques reinforced | circa 2 months | 76 75 73 | Stroke | 2.6% (1/38) (0.5 to 13%) 13.2% (5/38) (5.8 to 27%) 5.3% (2/38) (1.5 to 17%) | -11% (-25 to 2.6%) -7.9% (-23 to 6.2%) | -423% -304% | 0.880
Kasprisin, Clumeck, and Nino-Murcia, 1989 | 8 13 | Retro CT | VA medical center | | No swallow therapy (unknown history of pneumonia) Swallow therapy (with history of pneumonia) | 1 to 36 weeks | | Various | 100% (8/8) (68 to 100%) 15% (2/13) (4.3 to 42%) | 85% (43 to 96%) | 85% | 0.0002
Groher, 1987 | 23 23 | RCT | Chronic care facility | | Pureed diet Mechanically altered diet | 6 mos | 72 74 | Stroke | 87% (20/23) (68 to 95%) 17% (4/23) (7.0 to 37%) | 70% (42 to 83%) | 80% | <0.0001