# Supplemental Evidence Tables

Evidence Table S-1. Historical Controls for No-program Pneumonia Incidence in Consecutive Stroke Patients in Acute-care Settings

Author | N | Study design | Time period and setting | Selection | Test(s) | Treatment | Mean age | Characteristics | Followup | Cumulative pneumonia (95% CI) | Adjustment factor | Adjusted to 2 week interval (95% CI)
Odderson, Keaton, and McKenna, 1995 | 90 | HPCS | 1993 Urban community hospital | Consecutive acute nonhemorrhagic stroke | ? | ? | 75 | All stroke | Mn LOS 9.3 days | 6.7% (6/90) (3.1 to 14%) | 1.105 | 7.4% (3.6 to 15%)
Young and Durant-Jones, 1990 | 216 | CS | 1987-89 Acute-care teaching hospital | Charts of randomly selected stroke patients over a 3-year period (4%, 9/225, excluded as comatose) | ? | ? | 65 | All stroke | 4.4 wks | 13% (28/216) (9.1 to 18%) | 0.848 | 11% (7.5 to 16%)
Barker and Mullooly, 1997 | 196 247 275 | RCS | Hospital 1967-71 1974-78 1981-84 | All new stroke patients (WHO standard) over age 65 in an HMO | | | >65 | All stroke | 30 days | 10% (20/196) 7% (17/247) 9% (25/275) Mean 8.6% | 0.848 | 8.5% (5.4 to 13%) 5.9% (3.6 to 9.6%) 7.6% (5.0 to 11%) Mean 7.3% (5.6 to 9.4%)
Haerer and Smith, 1974 | 475 | RCS | Hospital 1967-72 | Consecutive strokes | | | | | LOS Mn 17.5 days | 8.8% (42/475) | 0.951 | 8.4% (6.2 to 11%)
Range Unweighted Mean Used in cost-effectiveness analysis: N-Weighted Adjusted Mean | | | | | | | | | | 6.7 to 13% 9.1% 9.2% (138/1,499) (7.8 to 11%) | | 5.9 to 11% 8.1% 8.2% (6.9 to 9.7%)

Evidence Table S-2. Proportion of Acute Stroke Patients Evaluated by Full BSE or VFSS in Ongoing Dysphagia Program

Author | N | Study design | Time period and care setting | Selection for program | Mean age | Patient characteristics | Selection for test | Proportion given SLP evaluation | Comments
Daniels, Brailey, Priestly et al., 1998 | 55 | Case series | VA medical center | Consecutive patients admitted with new strokes; 2 patients excluded due to obtunded or agitated status or previous history of dysphagia | 66 | All new stroke patients | Intention was to give test to all stroke patients; 4% (2/55) patients excluded due to obtunded or agitated status or previous history of dysphagia | 96% (53/55)
Akpunonu, Mutgi, Roberts et al., 1997 | 302 | Case series | Dept. of Internal Medicine, Medical College | Consecutive stroke patients (except transient < 24 hr ischemic attacks) (between 1989 and 1993) | 67 | | | 23% (69/302)
Teasell, McRae, Marchuk et al., 1996 | 441 | Case series | University hospital rehabilitation unit, Ontario, Canada | Consecutive patients admitted to hospital rehabilitation unit less than 4 mos post stroke | | All stroke within 4 mos., MBS Mn >5 weeks post-stroke | Those with clinical suspicion of aspiration | 24% (106/441)
Odderson, Keaton, and McKenna, 1995 | 124 | Historical prospective case series | 1993, Urban community hospital | Consecutive acute nonhemorrhagic stroke | 75 | All stroke; BSE within 24 hours | Preliminary BSE | 39% (49/124)
Odderson et al., 1995 (Odderson, Keaton, and McKenna, 1995) | | | | | | | Used in cost-effectiveness analysis | 39% (49/124)

Evidence Table S-3. Proportion of Acute Stroke Patients Treated for Dysphagia Following VFSS in Ongoing Dysphagia Program

Author | N | Study design | Time period and care setting | Selection for program | Mean age | Characteristics | Selection for treatment | Proportion dysphagic at SLP evaluation | Comments
Daniels, Brailey, Priestly et al., 1998 | 55 | Case series | VA medical center | Consecutive patients admitted with new strokes; 2 patients excluded due to obtunded or agitated status or previous history of dysphagia | 66 | All new stroke patients | Abnormal swallow at VFSS | 65% (36/55)
Akpunonu, Mutgi, Roberts et al., 1997 | 302 | Case series | Dept. of Internal Medicine, Medical College | Consecutive stroke patients (except transient < 24 hr ischemic attacks) (between 1989 and 1993) | 67 | All stroke patients (except transient <24 hr ischemic attacks) | Abnormal swallow at VFSS | 16% (49/302)
Teasell, McRae, Marchuk et al., 1996 | 441 | Case series | University hospital rehabilitation unit, Ontario, Canada | Consecutive patients admitted to hospital rehabilitation unit less than 4 mos post stroke | | All stroke within 4 mos, MBS Mn >5 weeks post-stroke | Suspected of dysphagia and given VFSS Aspirated thin liquids at VFSS | 24% (106/441) 19% (84/441)
Odderson, Keaton, and McKenna, 1995 | 124 | Historical prospective case series | 1993 Urban community hospital | Consecutive acute nonhemorrhagic stroke | 75 | All stroke; BSE within 24 hours | Preliminary BSE | 39% (49/124)
Odderson et al., 1995 (Odderson, Keaton, and McKenna, 1995) | | | | | | | Used in cost-effectiveness analysis | 39% (49/124)

Evidence Table S-4. Dysphagia Programs for Prevention of Pneumonia in Consecutive Acute Stroke Patients Compared with Historical Controls

Author | N | Care setting | Program | Follow-up interval | Cumulative pneumonia (95% CI) | Difference ^1^ from no-program mean of 9.2% (95% CI) | Relative risk reduction ^2^ | Adjustment factor | Cumulative adjusted to 2-week interval | Difference ^1^ from adjusted no-program Mean of 8.2% (95% CI) | Adjusted RRR ^2^
Nilsson, Ekberg, Olsson et al., 1998 | 72 | University hospital stroke unit, Sweden | Self-reported difficulty swallowing; diet consistency treatment only; IV drip but no tubes | 26 wks | 2.8% (2/72) (0.8 to 9.6%) | 6.4% (-0.5 to 9.0%) | 74% | 0.800 | 2.2% (0.5 to 8.7) | 6.0% (-0.6 to 8.3%) | 73%
Odderson, Keaton, and McKenna, 1995 2^nd^ year | 124 | 1993, Urban community hospital | Patients failing preliminary water test (39%) given formal BSE; diet, SLP therapy, tubes as needed | 1.0 wk | 0 (0/124) (0 to 3.0%) | 9.2% (5.9 to 11%) | 100% | 1.183 | 0% (0 to 3.0%) | 8.2 (4.9 to 9.7%) | 100%
Daniels, Brailey, Priestly et al., 1998 | 55 | VA medical center | All got MBS (65% were dysphagic, 38% aspirated); dysphagics got diet, SLP therapy, tubes as needed | 13 wks | 1.8% (1/55) (0.3 to 9.6%) | 7.4% (-0.5 to 9.6%) | 80% | 1.018 | 1.8% (0.3 to 9.6%) | 6.4% (-1.5 to 8.5%) | 78%
Range Used in cost-effectiveness analysis: Adjusted RRR Unweighted Mean N-weighted Mean | | | | | 0 to 2.8% 1.5% 1.2% (3/251) (0.4 to 3.5%) | 6.4 to 9.2% 7.7% 8.0% (5.4 to 9.8%) | 74 to 100% 85% 88% | | 0 to 2.2% 1.3% 1.3% (0.5 to 3.6%) | 6.0 to 8.2% 6.9% 6.9% (4.3 to 8.6%) | 73 to 100% 84% 87%

Evidence Table S-5. VFSS Costs

Author | Date | Setting | Patient characteristics | Components | Cost (charge or reimbursement) | Comments
Health Care Finanace Administration, 1997; American Speech-Language-Hearing Association (ASHA) and Health Care Financing Administration) (HCFA), 1998 | 1998 | Inpatient | | 74230 Cinema Xray throat/esoph., $77 92525 Oral function evaluation reimburse., $73 1.5 SLP billable hours reimburse., $68 | ($218)
CKMD101@aol.com, 1997 | 1998 | Medical center | | Speech dept. charge, $300 Radiology charge, $268 | ($568)
Kimark390@aol.com, 1997 | 1998 | Major hospital | | 1 hr. speech charge, $156 Radiology charge, $150 | ($306)
Aviv, 1997 | 1997 | Univ. hospital, New York City | | Medicare reimbursement including transportation from outside | ($700)
Used in cost-effectiveness analysis | | | | | ($218) | 1998 Medicare reimbursement

Evidence Table S-6. Swallow Therapy Cost

Author | Date | Setting | Patient characteristics | Components | Cost (charge or reimbursement) | Comments
Health Care Finance Administration, 1997; American Speech-Language-Hearing Association (ASHA) and Health Care Financing Administration (HCFA), 1998 | 1998 | Inpatient | | 1 hour session: 92526 Oral function therapy reimburse., $29 1 SLP billable hour reimburse., $45 1 month, 3X per week reimburse., $968 1 month, 5X per week reimburse., $1,291 1 month, 5X per week reimburse., $1,614 | ($74) ($968) ($1,291) ($1,614)
Odderson, Keaton, and McKenna, 1995 | 1998 | Acute-care hospital | Stroke | 6 daily sessions of 15 min. each: 92526 Oral function therapy reimburse., $29 15 min. SLP billable hour reimburse., $11.31 | ($242)
  $40.27
  X6
  $242
Gardner, 1998[unpub] | 1998 | | | 13.2 treatments (mean, not including evaluation) cost, $1,280 | $1,280
Used in cost-effectiveness analysis | | | | | $242 | 6 X 15 mins. per day, 1998 Medicare reimbursement

Evidence Table S-7. Aspiration Pneumonia Costs in Stroke Patients

Author | Date | Setting | Patient characteristics | Components | Cost (charge or reimbursement)] | Comments
Medicare, 1997 [table] | 1998 | Inpatient | | The difference between DRG 17 (nonspecific cerebrovascular disorder, $2,454) and DRG 16 (nonspecific cerebrovascular disorder with comorbid condition, $4,618), $2,164 | ($2,164)
Reynolds, Gilbert, Good et al., 1998 | 1991-95 | North Carolina Baptist Hospital | Stroke patients with aspiration pneumonia | Average extra cost for stroke/pneumonia patient versus stroke patient (29 day LOS vs. 10), $18,011 | $18,011
Aviv, 1997 | | University hospital, New York City | | Average medicare reimbursement for off-site transportation, 10-14 days LOS, antibiotics, ICU, intubation, ventilator, extubation; based on Boyce et al., 1991 (Boyce, Potter-Bynoe, Dziobek et al., 1991). McGarvey and Harper, 1993 (McGarvey and Harper, 1993), Paladino and Fell, 1994 (Paladino and Fell, 1994), ($19,000) | ($19,000)
Paladino and Fell, 1994 | 1992 | Fillmore Suburban Hospital, Williamsville, NY | Nosocomial pneumonia | Direct medical costs (including bed or hotel costs) for intermediate ICU for average case of nosocomial pneumonia, $10,660 | $10,660
McGarvey and Harper, 1993 | 1990 | Forbes Health System, a not-for-profit health care organization in southwestern Pennsylvania | Pneumonia clinical pathway | Average charge ($10,574) | ($10,574)
McGarvey and Harper, 1993 | 1990 | Forbes Health System, a not-for-profit health care organization in southwestern Pennsylvania | Pneumonia clinical pathway | As above but after implementation of quality improvement program ($9,629) | ($9,629)
Boyce, Potter-Bynoe, Dziobek et al., 1991 | 1986 | Miriam Hospital, Providence, RI | Medicare nosocomial pneumonia patients (mean age 77) | Hospital costs, $26,807
Boyce, Potter-Bynoe, Dziobek et al., 1991 | 1986 | Miriam Hospital, Providence, RI | Medicare nosocomial pneumonia patients (mean age 77) | As above but Medicare reimbursement ($13,066) | ($13,066)
Ahmad, Fergus, Stothard et al., 1988 | 1985 | Hospital ICU | Respiratory system cases | Average hospital costs, $14,326 | $14,326
Ibid | 1985 | Hospital ICU | Respiratory system cases | As above but Medicare reimbursement ($7,961) | ($7,961)
Used in cost-effectiveness analysis | | | | | ($2,164) | 1998 Medicare reimbursement