# References

Adams PF, Marano MA. Current estimates from the national health interview survey, 1994. Vital Health Stat 10. 1995 Dec;(193):12-13, 18-19.
Ahmad M, Fergus L, Stothard P, Harrington D, Sivak E, Farmer R. Impact of diagnosis-related groups' prospective payment on utilization of medical intensive care. Chest. 1988 Jan;93(1):176-9.
Akpunonu BE, Mutgi AB, Roberts C, Khuder SA, Federman DJ, Lee L. Modified barium swallow does not affect how often PEGs are placed after stroke. J Clin Gastroenterol Mar. 1997;24(2):74-8.
Ali GN, Wallace KL, Schwartz R, Decarle DJ, Zagami AS, Cook IJ. Mechanisms of oral-pharyngeal dysphagia in patients with Parkinson's disease. Gastroenterology. 1996 Feb;110(2):383-92.
American Speech-Language-Hearing Association (ASHA), Health Care Financing Administration. Salary equivalency per hour limits. Medicare in 1998-1999. Health Care Financing Administration; 1998 Mar 6. 7 p. Available from ASHA.
Annegers JF, Appel S, Lee JR, Perkins P. Incidence and prevalence of amyotrophic lateral sclerosis in Harris County, Texas, 1985-1988. Arch Neurol. 1991 Jun;48(6):589-93.
Armitage P, Berry G. Statistical methods in medical research. 3rd ed. Oxford: Blackwell Scientific; 1994. Chapter 16, Statistical methods in epidemiology.
Arrowsmith H. Nursing management of patients receiving gastrostomy feeding. Br J Nurs. 1996 Mar 14-27;5(5):268-73. [pmid: 8715740].
Aviv JE. Sensory discrimination in the larynx and hypopharynx. Otolaryngol Head Neck Surg. 1997 Mar;116(3):331-4. [pmid: 9121785].
Aviv JE, Kim T, Sacco RL, Kaplan S, Goodhart K, Diamond B, Close LG. FEESST: a new bedside endoscopic test of the motor and sensory components of swallowing. Ann Otol Rhinol Laryngol. 1998 May;107(5 Pt 1):378-87.
Aviv JE, Martin JH, Keen MS, Debell M, Blitzer A. Air pulse quantification of supraglottic and pharyngeal sensation: a new technique. Ann Otol Rhinol Laryngol. 1993 Oct;102(10):777-80.
Aviv JE, Sacco RL, Mohr JP, Thompson JL, Levin B, Sunshine S, Thomson J, Close LG. Laryngopharyngeal sensory testing with modified barium swallow as predictors of aspiration pneumonia after stroke. Laryngoscope. 1997 Sep;107(9):1254-60.
Aviv JE, Sacco RL, Thomson J, Tandon R, Diamond B, Martin JH, Close LG. Silent laryngopharyngeal sensory deficits after stroke. Ann Otol Rhinol Laryngol. 1997 Feb;106(2):87-93.
Awe WC, Fletcher WS, Jacob SW. The pathophysiology of aspiration pneumonitis. Surgery. 1966 Jul;60(1):232-9. [pmcid: 130048].
Axelsson K, Asplund K, Norberg A, Eriksson S. Eating problems and nutritional status during hospital stay of patients with severe stroke. J Am Diet Assoc. 1989 Aug;89(8):1092-6.
Barer DH. The natural history and functional consequences of dysphagia after hemispheric stroke. J Neurol Neurosurg Psychiatry. 1989 Feb;52(2):236-41. [pmid: 2564884].
Barker WH, Mullooly JP. Stroke in a defined elderly population, 1967-1985. A less lethal and disabling but no less common disease. Stroke. 1997 Feb;28(2):284-90.
Bartlett JG. The bacteriology of pulmonary infections following aspiration. West J Med. 1974;121:395-7.
Bartlett JG, Gorbach SL. The triple threat of aspiration pneumonia. Chest. 1975 Oct;68(4):560-6.
Bass NH, Morrell RM. The neurology of swallowing. In: Groher ME, editor(s). Dysphagia: diagnosis and management. 2nd ed. Boston: Butterworth-Heinemann; 1992. p.1-29.
Bastian RW. Videoendoscopic evaluation of patients with dysphagia: an adjunct to the modified barium swallow. Otolaryngol Head Neck Surg. 1991 Mar;104(3):339-50. [pmid: 1902935].
Bastian RW. The videoendoscopic swallowing study: an alternative and partner to the videofluoroscopic swallowing study. Dysphagia. 1993 Fall;8(4):359-67. [pmid: 8269732].
Baum BJ, Bodner L. Aging and oral motor function: evidence for altered performance among older persons. J Dent Res. 1983 Jan;62(1):2-6.
Beard CM, Kokmen E, Offord K, Kurland LT. Is the prevalence of dementia changing?. Neurology. 1991 Dec;41(12):1911-4.
Beck-Sague C, Villarino E, Giuliano D, Welbel S, Latts L, Manangan LM, Sinkowitz RL, Jarvis WR. Infectious diseases and death among nursing home residents: results of surveillance in 13 nursing homes. Infect Control Hosp Epidemiol. 1994 Jul;15(7):494-6.
Beck TJ, Gayler BW. Image quality and radiation levels in videofluoroscopy for swallowing studies: a review. Dysphagia. 1990;5(3):118-28. [pmid: 2249487].
Berg K, Mor V. Medicare nursing home residents with a stroke: characteristics and 90-day outcomes of care. J Aging Health. 1995 Aug;7(3):384-401.
Biem HJ, Laupacis A. Hard to swallow test [letter; comment]. Arch Neurol. 1994 Feb;51(2):119-20.
Bisch EM, Logemann JA, Rademaker AW, Kahrilas PJ, Lazarus CL. Pharyngeal effects of bolus volume, viscosity, and temperature in patients with dysphagia resulting from neurologic impairment and in normal subjects. J Speech Hear Res. 1994 Oct;37(5):1041-59.
Bleach NR. The gag reflex and aspiration: a retrospective analysis of 120 patients assessed by videofluoroscopy. Clin Otolaryngol. 1993 Aug;18(4):303-7. [pmid: 8877191].
Blonsky ER, Logemann JA, Boshes B, Fisher HB. Comparison of speech and swallowing function in patients with tremor disorders and in normal geriatric patients: a cinefluorographic study. J Gerontol. 1975 May;30(3):299-303.
Bower JH, Maraganore DM, McDonnell SK, Rocca WA. Incidence of progressive supranuclear palsy and multiple system atrophy in Olmsted County, Minnesota, 1976 to 1990. Neurology. 1997 Nov;49(5):1284-8.
Boyce HW Jr. Dysphagia: clinical update. St. Louis: Mosby; 1997 Nov 17 [cited1997 Nov 17]. [5 pages]. Available: http://www.asge.org/library/cu/cudysph.html.
Boyce JM, Potter-Bynoe G, Dziobek L, Solomon SL. Nosocomial pneumonia in Medicare patients. Hospital costs and reimbursement patterns under the prospective payment system. Arch Intern Med. 1991 Jun;151(6):1109-14.
Brenner H, Gefeller O. Variation of sensitivity, specificity, likelihood ratios and predictive values with disease prevalence. Stat Med. 1997 MAY 15;16(9):981-91.
Britton JE, Lipscomb G, Mohr PD, Rees WD, Young AC. The use of percutaneous endoscopic gastrostomy (PEG) feeding tubes in patients with neurological disease. J Neurol. 1997 Jul;244(7):431-4.
Broderick JP, Phillips SJ, Whisnant JP, O'Fallon WM, Bergstralh EJ. Incidence rates of stroke in the eighties: the end of the Decline in stroke?. Stroke. 1989 May;20(5):577-82.
Brown RD, Whisnant JP, Sicks JD, O'Fallon WM, Wiebers DO. Stroke incidence, prevalence, and survival: secular trends in Rochester, Minnesota, through 1989. Stroke. 1996 Mar;27(3):373-80.
Buchholz DW. What is dysphagia? [editorial; comment]. Dysphagia. 1996 Winter;11(1):23-4. [pmid: 8556874].
Bushmann M, Dobmeyer SM, Leeker L, Perlmutter JS. Swallowing abnormalities and their response to treatment in Parkinson's disease. Neurology. 1989 Oct;39(10):1309-14.
Bynum LJ, Pierce AK. Pulmonary aspiration of gastric contents. Am Rev Respir Dis. 1976 Dec;114(6):1129-36.
Campbell-Taylor I, Fisher RH. The clinical case against tube feeding in palliative care of the elderly. J Am Geriatr Soc. 1987 Dec;35(12):1100-4.
CDC Wonder [database online]. Atlanta (GA): Department of Health and Human Services; 1998; [cited 1998 Jul 26]. Population of 15 to 85+ years; All races; Both genders; By age (the United States);1996a; [1p].
CDC Wonder [database online]. Atlanta (GA): Department of Health and Human Services; 1998; [cited 1998 Jul 26]. Population of 65 to 85+ years; All races; Both genders; By age-gender (the United States);1996b; [1p].
CDC Wonder [database online]. Atlanta (GA): Department of Health and Human Services; 1998; [cited 1998 Jul 26]. Population of 65 to 85+ years; All races; Both genders; By age (the United States);1996c; [1p].
Centers for Disease Control and Prevention (CDC). Fastats A to Z. Pneumonia. 1998; [cited 1998 Jul 28]. [2]. Available: http://www.cdc.gov/nchswww/fastats/newmonia.htm.
Centers for Disease Control and Prevention (CDC). Table L. Number of deaths and fatality rate for discharges from short-stay hospitals, by age and selected first-listed diagnosis: United States, 1995. In: National Hospital Discharge Survey: Annual Summary, 1995. Washington D.C.: U.S. Government Printing Office; 1998 Jan. 1p. (Vital and Health Statistics; vol. 13, no. 133).
Chandra RK. Nutritional regulation of immunity and risk of infection in old age. Immunology. 1989 Jun;67(2):141-7. [pmid: 2666305].
Chandra RK. The relation between immunology, nutrition and disease in elderly people. Age Ageing. 1990 Jul;19(4):S25-31. [pmid: 2220476].
Chen MY, Ott DJ, Peele VN, Gelfand DW. Oropharynx in patients with cerebrovascular disease: evaluation with videofluoroscopy. Radiology. 1990 Sep;176(3):641-3.
Chen MY, Peele VN, Donati D, Ott DJ, Donofrio PD, Gelfand DW. Clinical and videofluoroscopic evaluation of swallowing in 41 patients with neurologic disease. Gastrointest Radiol. 1992;17(2):95-8. [pmid: 1551517].
Chua KS, Kong KH. Functional outcome in brain stem stroke patients after rehabilitation. Arch Phys Med Rehabil. 1996 Feb;77(2):194-7.
Ciocon JO. Indications for tube feedings in elderly patients. Dysphagia. 1990;5(1):1-5. [pmid: 2118023].
CKMD101@aol.com. Cost of videofluoroscopic swallow study. In: Dysphagia.com (Dysphagia discussion group) [online]. [cited 1997 Nov 16]. Available from Internet:dysphagia@cyberport.com.
Coates C, Bakheit AM. Dysphagia in Parkinson's disease. Eur Neurol. 1997;38(1):49-52. [pmid: 9252799].
Cogen R, Weinryb J. Aspiration pneumonia in nursing home patients fed via gastrostomy tubes. Am J Gastroenterol. 1989 Dec;84(12):1509-12.
Collins MJ, Bakheit AM. Does pulse oximetry reliably detect aspiration in dysphagic stroke patients?. Stroke. 1997 Sep;28(9):1773-5.
Cook TD, Campbell DT. Quasi-experimentation: design and analysis issues for field settings. Boston: Houghton Mifflin Company; 1979. 405p.
Croghan JE, Burke EM, Caplan S, Denman S. Pilot study of 12-month outcomes of nursing home patients with aspiration on videofluoroscopy. Dysphagia. 1994 Summer;9(3):141-6.
Daniels SK, Brailey K, Priestly DH, Herrington LR, Weisberg LA, Foundas AL. Aspiration in patients with acute stroke. Arch Phys Med Rehabil. 1998 Jan;79(1):14-9.
Daniels SK, McAdam CP, Brailey K, Foundas AL. Clinical assessment of swallowing and prediction of dysphagia severity. Am J Speech Lang Pathol. 1997 Nov;6(4):17-24.
Davalos A, Ricart W, Gonzalez-Huix F, Soler S, Marrugat J, Molins A, Suner R, Genis D. Effect of malnutrition after acute stroke on clinical outcome. Stroke. 1996 Jun;27(6):1028-32.
Davenport RJ, Dennis MS, Wellwood I, Warlow CP. Complications after acute stroke. Stroke. 1996 March;27(3):415-20.
de Lama Lazzara G, Lazarus C, Logemann JA. Impact of thermal stimulation on the triggering of the swallowing reflex. Dysphagia. 1986;1:73-7.
DeMeester TR, Bonavina L, Iascone C, Courtney JV, Skinner DB. Chronic respiratory symptoms and occult gastroesophageal reflux. A prospective clinical study and results of surgical therapy. Ann Surg. 1990 Mar;211(3):337-45.
Department of Health and Human Services, Centers for Disease Control and Prevention, National Center for Health Statistics. Health United States 1996-97 and injury chartbook. Washington D.C.: U.S. Government Printing Office; 1997 Jul. Table 34 (page 1 of 2). Leading causes of death and numbers of deaths, according to age: United States, 1980 and 1995.
Department of Health and Human Services, Centers for Disease Control and Prevention, National Center for Health Statistics. Health United States 1996-97 and injury chartbook. Washington D.C.: U.S. Government Printing Office; 1997 Jul. Table 89 (page 1 of 3). Discharges and average length of stay in non-Federal short-stay hospitals, according to sex, age, and selected first-listed diagnosis: United States, 1985, 1990, 1994, and 1995.
DePaso WJ. Aspiration pneumonia. Clin Chest Med. 1991 Jun;12(2):269-84. [pmid: 1855371].
DePippo KL, Holas MA, Reding MJ. The Burke dysphagia screening test: validation of its use in patients with stroke. Arch Phys Med Rehabil. 1994 Dec;75(12):1284-6.
DePippo KL, Holas MA, Reding MJ. Validation of the 3-oz water swallow test for aspiration following stroke. Arch Neurol. 1992 Dec;49(12):1259-61.
DePippo KL, Holas MA, Reding MJ, Mandel FS, Lesser ML. Dysphagia therapy following stroke: a controlled trial. Neurology. 1994 Sep;44(9):1655-60. [pmcid: 153508].
Dey AN. Characteristics of elderly nursing home residents: data from the 1995 National Nursing Home Survey. Adv Data. 1997 Jul 2;289.
Dobkin B. Neuromedical complications in stroke patients transferred for rehabilitation before and after diagnostic related groups. J Neurol Rehabil. 1987;1(1):3-7.
Dorland's illustrated medical dictionary. 28th ed. Philadelphia (PA): W.B. Saunders Company; 1994. 1940p.
Edwards LL, Quigley EM, Harned RK, Hofman R, Pfeiffer RF. Characterization of swallowing and defecation in Parkinson's disease. Am J Gastroenterol. 1994 Jan;89(1):15-25.
Eibling D. The efficacy of endoscopic swallowing evaluation in dysphagic population [dissertation]. 82 p.
Ekberg O. Defective closure of the laryngeal vestibule during deglutition. Acta Otolaryngol (Stockh). 1982 Mar-Apr;93(3-4):309-17. [pmid: 7064713].
Ekberg O. Posture of the head and pharyngeal swallowing. Acta Radiol Diagn (Stockh). 1986 Nov-Dec;27(6):691-6. [pmid: 3812018].
Ekberg O, Feinberg M. Clinical and demographic data in 75 patients with near-fatal choking episodes. Dysphagia. 1992;7(4):205-8. [pmid: 1424833].
Ekberg O, Nylander G, Fork FT, Sjoberg S, Birch-Iensen M, Hillarp B. Interobserver variability in cineradiographic assessment of pharyngeal function during swallow. Dysphagia. 1988;3(1):46-8. [pmid: 3248393].
Elmstahl S, Persson M, Andren M, Blabolil V. Malnutrition in geriatric patients: a neglected problem?. J Adv Nurs. 1997 Nov;26(5):851-5.
Emery JL. Two cases of lentil pneumonitis. Proc R Soc Med. 1960;53:952-3. [pmid: 13726622].
Ergun GA, Kahrilas PJ, Logemann JA. Interpretation of pharyngeal manometric recordings: limitations and variability. Dis Esophagus. 1993;6:11-6.
Feinberg MJ, Ekberg O, Segall L, Tully J. Deglutition in elderly patients with dementia: findings of videofluorographic evaluation and impact on staging and management. Radiology. 1992 Jun;183(3):811-4.
Feinberg MJ, Knebl J, Tully J. Prandial aspiration and pneumonia in an elderly population followed over 3 years. Dysphagia. 1996 Spring;11(2):104-9.
Fleming SM. Index of dysphagia: a tool for identifying deglutition problems. Dysphagia. 1987;1(4):206-8.
Fletcher RH, Fletcher SW, Wagner EH. Clinical epidemiology: the essentials. 2nd ed. Baltimore (MD): Williams and Wilkins; 1988. 246p.
Fryback DG, Thornbury JR. The efficacy of diagnostic imaging. Med Decis Making. 1991 Apr-Jun;11(2):88-94.
Fuh JL, Lee RC, Wang SJ, Lin CH, Wang PN, Chiang JH, Liu HC. Swallowing difficulty in Parkinson's disease. Clin Neurol Neurosurg. 1997 May;99(2):106-12.
Gann PH. Prostate-specific antigen screening for prostate cancer: issues involving test validity. Endocr Related Cancer. 1996 Fall;3(3):179-89.
Garb JL, Brown RB, Garb JR, Tuthill RW. Differences in etiology of pneumonias in nursing home and community patients. JAMA. 1978 Nov 10;240(20):2169-72.
Gardner Manzella, Inc. Cost [unpublished]. 1998. 1 p.
Garon BR, Engle M, Ormiston C. Silent aspiration: results of 1000 videofluoroscopic swallow evaluation. J Neurol Rehabil. 1996;10(2):121-6.
Gilbert RJ, Daftary S, Woo P, Seltzer S, Shapshay SM, Weisskoff RM. Echo-planar magnetic resonance imaging of deglutitive vocal fold closure: normal and pathologic patterns of displacement. Laryngoscope. 1996 May;106(5 Pt 1):568-72.
Gillum RF, Ingram DD. Relation between residence in the southeast region of the United States and stroke incidence.The NHANES I Epidemiologic Followup Study. Am J Epidemiol. 1996 Oct 1;144(7):665-73.
Golbe LI, Davis PH, Schoenberg BS, Duvoisin RC. Prevalence and natural history of progressive supranuclear palsy. Neurology. 1988 Jul;38(7):1031-4. [pmcid: 107739].
Golden A, Beber C, Weber R, KuMar V, Musson N, Silverman M. Long-term survival of elderly nursing home residents after percutaneous endoscopic gastrostomy for nutritional support. Nurs Home Med. 1997 Oct;5(11):382-9.
Gordon C, Hewer RL, Wade DT. Dysphagia in acute stroke. Br Med J (Clin Res Ed). 1987 Aug 15;295(6595):411-4.
Gottlieb D, Kipnis M, Sister E, Vardi Y, Brill S. Validation of the 50-ml 3 drinking test for evaluation of post-stroke dysphagia. Disabil Rehabil. 1996 Oct;18(10):529-32.
Grant JP. Percutaneous endoscopic gastrostomy. Initial placement by single endoscopic technique and long-term follow-up. Ann Surg. 1993 Feb;217(2):168-74. [pmid: 8439214].
Gray C, Sivaloganathan S, Simpkins KC. Aspiration of high-density barium contrast medium causing acute pulmonary inflammation-report of two fatal cases in elderly women with disordered swallowing. Clin Radiol. 1989 Jul;40(4):397-400.
Greenfield LJ, Singleton RP, McCaffree DR, Coalson JJ. Pulmonary effects of experimental graded aspiration of hydrochloric acid. Ann Surg. 1969 Jul;170(1):74-86.
Gresham SL. Clinical assessment and management of swallowing difficulties after stroke. Med J Aust. 1990 Oct 1;153(7):397-9. [pmid: 2215310].
Groher ME. Bolus management and aspiration pneumonia in patients with pseudobulbar dysphagia. Dysphagia. 1987;1:215-6.
Groher ME, Bukatman R. The prevalence of swallowing disorders in two teaching hospitals. Dysphagia. 1986;1:3-6.
Gustafsson B. The experiential meaning of eating, handicap, adaptedness, and confirmation in living with esophageal dysphagia. Dysphagia. 1995 Spring;10(2):68-85. [pmid: 7600857].
Gustafsson B, Tibbling L. Dysphagia, an unrecognized handicap. Dysphagia. 1991;6(4):193-9. [pmid: 1838076].
Haerer AF, Smith RR. Medical and surgical experiences in patients of a large southern stroke center. South Med J. 1974 Jun;67(6):667-71.
Hageman C. Feasibility of videofluoroscopy and piezoelectric technique: utilization for dysphagia in nursing homes [unpublished]. 11 p.
Hamdy S, Aziz Q, Rothwell JC, Crone R, Hughes D, Tallis RC, Thompson DG. Explaining oropharyngeal dysphagia after unilateral hemispheric stroke. Lancet. 1997 Sep 6;350(9079):686-92.
Hamlet S, Muz J, Farris R, Kumpuris T, Jones L. Scintigraphic quantification of pharyngeal retention following deglutition. Dysphagia. 1992;7(1):12-6. [pmid: 1424823].
Hanson P, Lawson G, Remacle M. Electromyography for swallowing disorders in the elderly. Eur J Phys Med Rehabil. 1995;5(3):76-9.
Hardy E, Robinson NM. Swallowing disorders treatment manual. Bisbee (AZ): Imaginart; 1993. Chapter 2, The normal swallow.
Harkness GA, Bentley DW, Roghmann KJ. Risk factors for nosocomial pneumonia in the elderly. Am J Med. 1990 Oct;89(4):457-63.
Hartelius L, Svensson P. Speech and swallowing symptoms associated with Parkinson's disease and multiple sclerosis: a survey. Folia Phoniatr Logop. 1994;46(1):9-17. [pmid: 8162135].
Health Care Financing Administration, Bureau of Data Management and Strategy. National physician fee schedule relative value file. Calendar year 1998. Rockville (MD): U.S. Department of Health and Human Services, Public Health Service, AHCPR; 1997 DEC 22. 17p. (Public Use Files;).
Hedges LV, Olkin I. Statistical method for meta-analysis. Academic Press, Inc., 1985. 369 p.
Helmick CG, Wrigley JM, Zack MM, Bigler WJ, Lehman JL, Janssen RS, Hartwig EC, Witte JJ. Multiple sclerosis in Key West, Florida. Am J Epidemiol. 1989 Nov;130(5):935-49.
Henderson CT. Safe and effective tube feeding of bedridden elderly. Geriatrics. 1991 Aug;46(8):56-8, 63-6. [pmid: 1907586].
Hendrie HC, Osuntokun BO, Hall KS, Ogunniyi AO, Hui SL, Unverzagt FW, Gureje O, Rodenberg CA, Baiyewu O, Musick BS. Prevalence of Alzheimer's disease and dementia in two communities: Nigerian Africans and African Americans. Am J Psychiatry. 1995 Oct;152(10):1485-92.
Hing E, Sekscenski E, Strahan G. The National Nursing Home Survey; 1985 summary for the United States. National Center for Health Statistics. Washington D.C.: Government Printing Office; 1989 Jan. 249p. (Vital and health statistics; vol. 13, no. 97).
Holas MA, DePippo KL, Reding MJ. Aspiration and relative risk of medical complications following stroke. Arch Neurol. 1994 Oct;51(10):1051-3.
Hopkins RS, Indian RW, Pinnow E, Conomy J. Multiple sclerosis in Galion, Ohio: prevalence and results of a case-control study. Neuroepidemiology. 1991;10(4):192-9. [pmid: 1745329].
Horner J, Alberts MJ, Dawson DV, Cook GM. Swallowing in Alzheimer's disease. 1994 Fall;8(3):177-89. [pmcid: 275183].
Horner J, Buoyer FG, Alberts MJ, Helms MJ. Dysphagia following brain-stem stroke.Clinical correlates and outcome. Arch Neurol. 1991 Nov;48(11):1170-3.
Horner J, Massey EW. Silent aspiration following stroke. Neurology. 1988 Feb;38(2):317-9. [pmcid: 107739].
Horner J, Massey EW, Brazer SR. Aspiration in bilateral stroke patients. Neurology. 1990 Nov;40(11):1686-8. [pmcid: 415551].
Horner J, Massey EW, Riski JE, Lathrop DL, Chase KN. Aspiration following stroke: clinical correlates and outcome. Neurology. 1988 Sep;38(9):1359-62. [pmcid: 107739].
Houston MS, Silverstein MD, Suman VJ. Community-acquired lower respiratory tract infection in the elderly: a community-based study of incidence and outcome. J Am Board Fam Pract. 1995 Sep-Oct;8(5):347-56.
Hull MA, Rawlings J, Murray FE, Field J, McIntyre AS, Mahida YR, Hawkey CJ, Allison SP. Audit of outcome of long-term enteral nutrition by percutaneous endoscopic gastrostomy. Lancet. 1993 Apr 3;341(8849):869-72.
Huxley EJ, Viroslav J, Gray WR, Pierce AK. Pharyngeal aspiration in normal adults and patients with depressed consciousness. Am J Med. 1978 Apr;64(4):564-8.
Jarnagin WR, Duh QY, Mulvihill SJ, Ridge JA, Schrock TR, Way LW. The efficacy and limitations of percutaneous endoscopic gastrostomy. Arch Surg. 1992 Mar;127(3):261-4.
Johnson ER, McKenzie SW, Rosenquist CJ, Lieberman JS, Sievers AE. Dysphagia following stroke: quantitative evaluation of pharyngeal transit times. Arch Phys Med Rehabil. 1992 May;73(5):419-23.
Johnson ER, McKenzie SW, Sievers A. Aspiration pneumonia in stroke. Arch Phys Med Rehabil. 1993 Sep;74(9):973-6.
Johnston BT, Collins JS, McFarland RJ, Blackwell JN, Love AH. A comparison of esophageal motility in response to bread swallows and water swallows. Am J Gastroenterol. 1993;88(3):351-5. [pmid: 8438839].
Jones J. Risk and outcome of aspiration pneumonia in a city hospital. J Natl Med Assoc. 1993 Jul;85(7):533-6. [pmid: 8350375].
Jorgensen NH, Byer DE, Gould AB Jr. Aspiration pneumonitis. Prevention and treatment. Minn Med. 1989 Sep;72(9):517-9, 530.
Kadakia SC, Sullivan HO, Starnes E. Percutaneous endoscopic gastrostomy or jejunostomy and the incidence of aspiration in 79 patients. Am J Surg. 1992 Aug;164(2):114-8.
Kagel MC, Leopold NA. Dysphagia in Huntington's disease: a 16-year retrospective. Dysphagia. 1992;7(2):106-14. [pmid: 1533361].
Kahrilas PJ. The anatomy and physiology of dysphagia. In: Gelfand DW, Richter JE, editor(s). Dysphagia: diagnosis and treatment. New York: Igaku-Shoin; 1989. p.11-28.
Kasprisin AT, Clumeck H, Nino-Murcia M. The efficacy of rehabilitative management of dysphagia. Dysphagia. 1989;4(1):48-52. [pmid: 2640178].
Kaw M, Sekas G. Long-term follow-up of consequences of percutaneous endoscopic gastrostomy (PEG) tubes in nursing home patients. Dig Dis Sci. 1994 Apr;39(4):738-43.
Kaye GM, Zorowitz RD, Baredes S. Role of flexible laryngoscopy in evaluating aspiration. Ann Otol Rhinol Laryngol. 1997 Aug;106(8):705-9.
Keller HH. Malnutrition in institutionalized elderly: how and why?. J Am Geriatr Soc. 1993 Nov;41(11):1212-8. [pmid: 8227896].
Keller HH. Weight gain impacts morbidity and mortality in institutionalized older persons. J Am Geriatr Soc. 1995 Feb;43(2):165-9. [pmid: 7836642].
Kidd D, Lawson J, Nesbitt R, MacMahon J. Aspiration in acute stroke: a clinical study with videofluoroscopy. Q J Med. 1993 Dec;86(12):825-9.
Kidder TM, Langmore SE, Martin BJ. Indications and techniques of endoscopy in evaluation of cervical dysphagia: comparison with radiographic techniques. Dysphagia. 1994 Fall;9(4):256-61.
Kim T, Goodhart K, Aviv JE, Sacco RL, Diamond B, Kaplan S, Close LG. FEESST: a new bedside endoscopic test of the motor and sensory components of swallowing. Ann Otol Rhinol Laryngol. 1998 May;107(5 Pt 1):378-87.
KiMark390@aol.com. Re: Cost of videofluoroscopic swallow study. In: Dysphagia.com (Dysphagia discussion group) [online]. [cited 1997 Nov 16]. Available from Internet: dysphagia@cyberport.com.
Kirby DF, Craig RM, Tsang TK, Plotnick BH. Percutaneous endoscopic gastrostomies: a prospective evaluation and review of the literature. JPEN J Parenter Enteral Nutr. 1986 Mar-Apr;10(2):155-9.
Kirshner HS. Causes of neurogenic dysphagia. Dysphagia. 1989;3(4):184-8. [pmid: 2639774].
Kirtley DW, Willis MJ, Thomas E. Reducing PEG wound problems [letter]. Gastrointest Endosc. 1987 Feb;33(1):51-2.
Kittner SJ, White LR, Losonczy KG, Wolf PA, Hebel JR. Black-white differences in stroke incidence in a national sample. The contribution of hypertension and diabetes mellitus. JAMA. 1990 Sep 12;264(10):1267-70.
Kokmen E, Ozekmekci FS, Beard CM, O'Brien PC, Kurland LT. Incidence and prevalence of Huntington's disease in Olmsted County, Minnesota (1950 through 1989). Arch Neurol. 1994 Jul;51(7):696-8.
Krefting L, Norman B, Hagel J, Wevik E, Elm D. A retrospective analysis of interdisciplinary dysphagia assessment data. Phys Occup Ther Geriatr. 1990;9(2):79-95.
Kuhlemeier KV, Yates P, Palmer JB. Intra- and interrater variation in the evaluation of videofluorographic swallowing studies. Dysphagia. 1998 Summer;13(3):142-7.
Langmore SE. Personal communication. 1998 Sep 19. 10 p.
Langmore SE, Schatz K, Olson N. Endoscopic and videofluoroscopic evaluations of swallowing and aspiration. Ann Otol Rhinol Laryngol. 1991 Aug;100(8):678-81.
Langmore SE, Terpenning MS, Schork A, Chen YM, Murray JT, Lopatin D, Loesche WJ. Predictors of aspiration pneumonia: how important is dysphagia?. Dysphagia. 1998 Spring;13(2):69-81.
Larson DE, Burton DD, Schroeder KW, DiMagno EP. Percutaneous endoscopic gastrostomy. Indications, success, complications, and mortality in 314 consecutive patients. Gastroenterology. 1987 Jul;93(1):48-52. [pmcid: 212298].
Larson DE, Fleming CR, Ott BJ, Schroeder KW. Percutaneous endoscopic gastrostomy. Simplified access for enteral nutrition. Mayo Clin Proc. 1983 Feb;58(2):103-7.
Layne KA, Losinski DS, Zenner PM, Ament JA. Using the Fleming index of dysphagia to establish prevalence. Dysphagia. 1989;4(1):39-42. [pmid: 2640175].
Lazarus BA, Murphy JB, Culpepper L. Aspiration associated with long-term gastric versus jejunal feeding: a critical analysis of the literature. Arch Phys Med Rehabil. 1990 Jan;71(1):46-53.
Lazarus CL, Logemann JA, Rademaker AW, Kahrilas PJ, Pajak T, Lazar R, Halper A. Effects of bolus volume, viscosity, and repeated swallows in nonstroke subjects and stroke patients. Arch Phys Med Rehabil. 1993 Oct;74(10):1066-70.
Leder SB. Videofluoroscopic evaluation of aspiration with visual examination of the gag reflex and velar movement. Dysphagia. 1997 Winter;12(1):21-3. [pmid: 8997829].
Leder SB, Sasaki CT, Burrell MI. Fiberoptic endoscopic evaluation of dysphagia to identify silent aspiration. Dysphagia. 1998 Winter;13(1):19-21.
Leighton SE, Burton MJ, Lund WS, Cochrane GM. Swallowing in motor neuron disease. J R Soc Med. 1994 Dec;87(12):801-5.
Leopold NA, Kagel MC. Dysphagia in Huntington's disease. Arch Neurol. 1985 Jan;42(1):57-60.
Liddle K, Yuill R. Making sense of percutaneous endoscopic gastrostomy. Nurs Times. 1995 May 3-9;91(18):32-3.
Lilienfeld DE, Sprafka JM, Pham DL, Baxter J. Parkinson's and motoneuron disease morbidity in the Twin Cities metropolitan area: 1979-1984. Neuroepidemiology. 1991;10(3):112-6. [pmid: 1922643].
Limeback H. Implications of oral infections on systemic diseases in the institutionalized elderly with a special focus on pneumonia. Ann Periodontol. 1998 Jul;3(1):262-75. [pmid: 9722710].
Linden P, Kuhlemeier KV, Patterson C. The probability of correctly predicting subglottic penetration from clinical observations. Dysphagia. 1993;8(3):170-9. [pmid: 8359036].
Linden P. Videofluoroscopy in the rehabilitation of swallowing dysfunction. Dysphagia. 1989;3(4):189-91. [pmid: 2639775].
Littenberg B, Moses LE. Estimating diagnostic accuracy from multiple conflicting reports: a new meta-analytic method. Med Decis Making. 1993 Oct-Dec;13(4):313-21.
Litvan I, Agid Y, Calne D, Campbell G, Dubois B, Duvoisin RC, Goetz CG, Golbe LI, Grafman J, Growdon JH, et al. Clinical research criteria for the diagnosis of progressive supranuclear palsy (Steele-Richardson-Olszewski syndrome): report of the NINDS-SPSP international workshop. Neurology. 1996 Jul;47(1):1-9. [pmcid: 116601].
Litvan I, Sastry N, Sonies BC. Characterizing swallowing abnormalities in progressive supranuclear palsy. Neurology. 1997 Jun;48(6):1654-62. [pmcid: 107739].
Llaneza PP, Menendez AM, Roberts R, Dunn GD. Percutaneous endoscopic gastrostomy: clinical experience and follow-up. South Med J. 1988 Mar;81(3):321-4.
LoCicero J 3rd. Bronchopulmonary aspiration. Surg Clin North Am. 1989 Feb;69(1):71-6. [pmid: 2643185].
Logemann JA. Approaches to management of disordered swallowing. Baillieres Clin Gastroenterol. 1991 Jun;5(2):269-80. [pmid: 1912652].
Logemann JA. Evaluation and treatment of swallowing disorders. 2nd ed. Austin (TX): Pro-Ed; 1998a. Chapter 2, Anatomy and physiology of normal deglutition.
Logemann JA. Evaluation and treatment of swallowing disorders. Austin (TX): PRO-ED; 1983a. Chapter 3, Disorders of deglutition.
Logemann JA. Evaluation and treatment of swallowing disorders. Austin (TX): PRO-ED; 1983b. Chapter 5, Management of the patient with disordered oral feeding.
Logemann JA. Evaluation and treatment of swallowing disorders. Austin (TX): PRO-ED; 1983c. Chapter 8, Swallowing disorders associated with neuromuscular disorders.
Logemann JA. The dysphagia diagnostic procedure as a treatment efficacy trial. Clin Commun Disord. 1993 Fall;3(4):1-10. [pmid: 8111359].
Logemann JA, editor(s). Evaluation and treatment of swallowing disorders. San Diego (CA): College-Hill Press, Inc.; 1983d. 249p.
Logemann JA. Personal communication. 1998a Aug 7. 2 p.
Logemann JA. Personal communication. 1998b Sep 21. 6 p.
Logemann JA. Rehabilitation of oropharyngeal swallowing disorders. Acta Otorhinolaryngol Belg. 1994;48(2):207-15. [pmid: 8209683].
Logemann JA, Kahrilas PJ. Relearning to swallow after stroke-application of maneuvers and indirect biofeedback: a case study. Neurology. 1990 Jul;40(7):1136-8. [pmcid: 415551].
Logemann JA, Kahrilas PJ, Kobara M, Vakil NB. The benefit of head rotation on pharyngoesophageal dysphagia. Arch Phys Med Rehabil. 1989 Oct;70(10):767-71.
Logemann JA, Pauloski BR, Colangelo L, Lazarus C, Fujiu M, Kahrilas PJ. Effects of a sour bolus on oropharyngeal swallowing measures in patients with neurogenic dysphagia. J Speech Hear Res. 1995 Jun;38(3):556-63.
Lugger KE. Dysphagia in the elderly stroke patient. J Neurosci Nurs. 1994 Apr;26(2):78-84. [pmid: 8077779].
Mari F, Matei M, Ceravolo MG, Pisani A, Montesi A, Provinciali L. Predictive value of clinical indices in detecting aspiration in patients with neurological disorders. J Neurol Neurosurg Psychiatry. 1997 Oct;63(4):456-60.
Marrie TJ. Epidemiology of community-acquired pneumonia in the elderly. Semin Respir Infect. 1990 Dec;5(4):260-8. [pmid: 2093971].
Marrie TJ, Durant H, Kwan C. Nursing home-acquired pneumonia. A case-control study. J Am Geriatr Soc. 1986 Oct;34(10):697-702.
Marston BJ, Plouffe JF, File TM Jr, Hackman BA, Salstrom SJ, Lipman HB, Kolczak MS, Breiman RF. Incidence of community-acquired pneumonia requiring hospitalization. Results of a population-based active surveillance Study in Ohio. The Community-Based Pneumonia Incidence Study Group. Arch Intern Med. 1997 Aug 11-25;157(15):1709-18.
Martens L, Cameron T, Simonsen M. Effects of a multidisciplinary management program on neurologically impaired patients with dysphagia. Dysphagia. 1990;5(3):147-51. [pmid: 2249491].
Martin CJ, Hunter S. Reduction of patient doses from barium meal and barium enema examinations through changes in equipment factors. Br J Radiol. 1994 Dec;67(804):1196-205.
Mayberry JF, Atkinson M. Swallowing problems in patients with motor neuron disease. J Clin Gastroenterol. 1986 Jun;8(3 Pt 1):233-4.
Mayeux R, Marder K, Cote LJ, Denaro J, Hemenegildo N, Mejia H, Tang MX, Lantigua R, Wilder D, Gurland B, et al. The frequency of idiopathic Parkinson's disease by age, ethnic group, and sex in northern Manhattan, 1988-1993. Am J Epidemiol. 1995 Oct 15;142(8):820-7.
McCullough GH. Sensitivity and specificity of a clinical/bedside examination of swallowing for detecting dysphagia in adults subsequent to stroke [dissertation]. Nashville (TN): Vanderbilt University Medical School; 1997. 208 p. Available from: UMI, Ann Arbor, MI.
McFarlin DE, McFarland HF. Multiple sclerosis (first of two parts). N Engl J Med. 1982a Nov 4;307(19):1183-8.
McFarlin DE, McFarland HF. Multiple sclerosis (second of two parts). N Engl J Med. 1982b Nov 11;307(20):1246-51.
McGarvey RN, Harper JJ. Pneumonia mortality reduction and quality improvement in a community hospital. QRB Qual Rev Bull. 1993 Apr;19(4):124-30.
McGovern PG, Burke GL, Sprafka JM, Xue S, Folsom AR, Blackburn H. Trends in mortality, morbidity, and risk factor levels for stroke from 1960 through 1990. The Minnesota Heart Survey. JAMA. 1992 Aug 12;268(6):753-9.
McGuire V, Longstreth WT Jr, Koepsell TD, van Belle G. Incidence of amyotrophic lateral sclerosis in three counties in western Washington state. Neurology. 1996 AUG;47(2):571-3. [pmcid: 116601].
McNabney MK, Beers MH, Siebens H. Surrogate decision-makers' satisfaction with the placement of feeding tubes in elderly patients. J Am Geriatr Soc. 1994 Feb;42(2):161-8.
Mendelsohn MS. The modified barium swallow in clinical practice. J Otolaryngol Soc Aust. 1988;6(2):97-100.
Mendez L, Friedman LS, Castell DO. Swallowing disorders in the elderly. Clin Geriatr Med. 1991 May;7(2):215-30.
Miller RE, Castlemain B, Lacqua FJ, Kotler DP. Percutaneous endoscopic gastrostomy. Results in 316 patients and review of literature. Surg Endosc. 1989;3(4):186-90. [pmid: 2516369].
Mitchell SL, Kiely DK, Kiel DP, Lipsitz LA. The epidemiology, clinical characteristics, and natural history of older nursing home residents with a diagnosis of Parkinson's disease. J Am Geriatr Soc. 1996 Apr;44(4):394-9.
Modan B, Wagener DK. Some epidemiological aspects of stroke: mortality/morbidity trends, age, sex, race, socioeconomic status. Stroke. 1992 Sep;23(9):1230-6.
Morrell RM. Neurologic disorders of swallowing. In: Groher ME, editor(s). Dysphagia: diagnosis and management. 2nd ed. Boston: Butterworth-Heinemann; 1992. p.31-51.
Murden RA, Ainslie NK. Recent weight loss is related to short-term mortality in nursing homes. J Gen Intern Med. 1994 Nov;9(11):648-50.
Muroi N, Nishibori M, Fujii T, Yamagata M, Hosoi S, Nakaya N, Saeki K, Henmi K. Anaphylaxis from the carboxymethylcellulose component of barium sulfate suspension. N Engl J Med. 1997 Oct 30;337(18):1275-7.
Muz J, Mathog RH, Miller PR, Rosen R, Borrero G. Detection and quantification of laryngotracheopulmonary aspiration with scintigraphy. Laryngoscope. 1987 Oct;97(10):1180-5.
Neumann S. Swallowing therapy with neurologic patients: results of direct and indirect therapy methods in 66 patients suffering from neurological disorders. Dysphagia. 1993;8(2):150-3. [pmid: 8467723].
Neumann S, Bartolome G, Buchholz D, Prosiegel M. Swallowing therapy of neurologic patients: correlation of outcome with pretreatment variables and therapeutic methods. Dysphagia. 1995 Winter;10(1):1-5.
Newcombe RG. Interval estimation for the difference between independent proportions: comparison of eleven methods. Stat Med. 1998 Apr 30;17(8):873-90. [pmid: 9595617].
Nilsson H, Ekberg O, Bulow M, Hindfelt B. Assessment of respiration during video fluoroscopy of dysphagic patients. Acad Radiol. 1997 Jul;4(7):503-7.
Nilsson H, Ekberg O, Hindfelt B. Oral function test for monitoring suction and swallowing in the neurologic patient. Dysphagia. 1995;10(2):93-100. [pmid: 7600859].
Nilsson H, Ekberg O, Olsson R, Hindfelt B. Dysphagia in stroke: a prospective study of quantitative aspects of swallowing in dysphagic patients. Dysphagia. 1998 Winter;13(1):32-8.
Nilsson H, Ekberg O, Olsson R, Hindfelt B. Quantitative assessment of oral and pharyngeal function in Parkinson's disease. Dysphagia. 1996 Spring;11(2):144-50.
Norton B, Homer-Ward M, Donnelly MT, Long RG, Holmes GK. A randomised prospective comparison of percutaneous endoscopic gastrostomy and nasogastric tube feeding after acute dysphagic stroke. BMJ. 1996 Jan 6;312(7022):13-6. [pmcid: 128944].
Odderson IR. (Medical director, rehabilitation services. Overlake Hospital Medical Center. Bellevue (WA)) Personal communication (telephone conversation). 1998 Aug 20. 1 p.
Odderson IR, Keaton JC, McKenna BS. Swallow management in patients on an acute stroke pathway: quality is cost effective. Arch Phys Med Rehabil. 1995 Dec;76(12):1130-3.
Odderson IR, McKenna BS. A model for management of patients with stroke during the acute phase. Outcome and economic implications. Stroke. 1993 Dec;24(12):1823-7.
Olsson R, Nilsson H, Ekberg O. Simultaneous videoradiography and computerized pharyngeal manometry-videomanometry. Acta Radiol. 1994 Jan;35(1):30-4.
Ott DJ, Hodge RG, Pikna LA, Chen MY, Gelfand DW. Modified barium swallow: clinical and radiographic correlation and relation to feeding recommendations. Dysphagia. 1996 Summer;11(3):187-90.
Paladino JA, Fell RE. Pharmacoeconomic analysis of cefmenoxime dual individualization in the treatment of nosocomial pneumonia. Ann Pharmacother. 1994 Mar;28(3):384-9.
Palmer LB. Bacterial colonization: pathogenesis and clinical significance. Clin Chest Med. 1987 Sep;8(3):455-66. [pmid: 3311586].
Park RH, Allison MC, Lang J, Spence E, Morris AJ, Danesh BJ, Russell RI, Mills PR. Randomised comparison of percutaneous endoscopic gastrostomy and nasogastric tube feeding in patients with persisting neurological dysphagia. BMJ. 1992 May 30;304(6839):1406-9. [pmcid: 121334].
Penington GR. Severe complications following a 'barium swallow' investigation for dysphagia. Med J Aust. 1993 Dec 6-20;159(11-12):764-5. [pmid: 8054001].
Perlman AL, Booth BM, Grayhack JP. Videofluoroscopic predictors of aspiration in patients with oropharyngeal dysphagia. Dysphagia. 1994 Spring;9(2):90-5.
Pick N, McDonald A, Bennett N, Litsche M, Dietsche L, Legerwood R, Spurgas R, LaForce FM. Pulmonary aspiration in a long-term care setting: clinical and laboratory observations and an analysis of risk factors. J Am Geriatr Soc. 1996 Jul;44(7):763-8.
Pinkerton H. The reaction to oils and fats in the lungs. Arch Pathol. 1928;5:380-401.
Ponsky JL, Gauderer MW, Stellato TA. Percutaneous endoscopic gastrostomy. Review of 150 cases. Arch Surg. 1983 Aug;118(8):913-4.
Potvin WJ, Kaur C, Williams G. Patient radiation doses associated with the modified barium swallow. Med Phys. 1991 May-Jun;18(3).
Priefer BA, Robbins J. Eating changes in mild-stage Alzheimer's disease: a pilot study. Dysphagia. 1997 Fall;12(4):212-21.
Ransohoff DF, Feinstein AR. Problems of spectrum and bias in evaluating the efficacy of diagnostic tests. N Engl J Med. 1978 Oct 26;299(17):926-30.
Rasley A, Logemann JA, Kahrilas PJ, Rademaker AW, Pauloski BR, Dodds WJ. Prevention of barium aspiration during videofluoroscopic swallowing studies: value of change in posture. AJR Am J Roentgenol. 1993;160(5):1005-9. [pmid: 8470567].
Reynolds PS, Gilbert L, Good DC, Knappertz VA, Crenshaw C, Wayne SL, Pillbury D, Tegeler CH. Pneumonia in dysphagic stroke patients: effect on outcomes and identification of high risk patients. J Neuro Rehab. 1998;12(1):15-21.
Riquelme R, Torres A, El-Ebiary M, de la Bellacasa JP, Estruch R, Mensa J, Fernandez-Sola J, Hernandez C, Rodriguez-Roisin R. Community-acquired pneumonia in the elderly: a multivariate analysis of risk and prognostic factors. Am J Respir Crit Care Med. 1996 Nov;154(5):1450-5.
Robbins J, Levine RL, Maser A, Rosenbek JC, Kempster GB. Swallowing after unilateral stroke of the cerebral cortex. Arch Phys Med Rehabil. 1993 Dec;74(12):1295-300.
Robbins JA, Logemann JA, Kirshner HS. Swallowing and speech production in Parkinson's disease. Ann Neurol. 1986 Mar;19(3):283-7.
Rogers B, Msall M, Shucard D. Hypoxemia during oral feedings in adults with dysphagia and severe neurological disabilities. Dysphagia. 1993;8(1):43-8. [pmid: 8436021].
Rosenbek JC, Robbins JA, Willford WO, Kirk G, Schiltz A, Sowell TW, Deutsch SE, Milanti FJ, Ashford J, Gramigna GD, et al. Comparing treatment intensities of tactile-thermal application. Dysphagia. 1998 Winter;13(1):1-9.
Rosenthal R. Meta-analytic procedures for social research. Revised ed. Newbury Park (CA): Sage Publications, Inc; 1991. 155 p. (Applied social research methods series; vol 6).
Ryan C, Bryant E, Eleazer P, Rhodes A, Guest K. Unintentional weight loss in long-term care: predictor of mortality in the elderly. South Med J. 1995 Jul;88(7):721-4.
Ryan C, Byrd J, Eleazer P. Percutaneous endoscopic gastrostomy tube placement in elderly patients from a South Carolina long-term care facility: outcomes. J Nutr Elder. 1995;14(2-3):89-96. [pmid: 7602462].
Sacco RL, Boden-Albala B, Gan R, Chen X, Kargman DE, Shea S, Paik MC, Hauser WA. Stroke incidence among white, black, and Hispanic residents of an urban community: the Northern Manhattan Stroke Study. Am J Epidemiol. 1998 Feb 1;147(3):259-68.
Sant SM, Gilvarry J, Shannon R, O'Morain C. Percutaneous endoscopic gastrostomy-its application in patients with neurological disease. Ir J Med Sci. 1993 Nov;162(11):450-1.
Schmidt J, Holas M, Halvorson K, Reding M. Videofluoroscopic evidence of aspiration predicts pneumonia and deaths but not dehydration following stroke. Dysphagia. 1994 Winter;9(1):7-11.
Schwartz P. Asylum pneumonitis. Gerontol Clin (Basel). 1973;15(5):281-351. [pmcid: 50586]. [pmid: 4794869].
Sekizawa K, Ujiie Y, Itabashi S, Sasaki H, Takishima T. Lack of cough reflex in aspiration pneumonia [letter]. Lancet. 1990 May 19;335(8699):1228-9.
Selkin SG. Kinelaryngoscopy for documentation of laryngeal pathophysiology. Laryngoscope. 1984 Jan;94(1):58-62. [pmid: 6690879].
Selley WG. Swallowing difficulties in stroke patients: a new treatment. Age Ageing. 1985 Nov;14(6):361-5. [pmid: 4072824].
Selley WG, Ellis RE, Flack FC, Bayliss CR, Pearce VR. The synchronization of respiration and swallow sounds with videofluoroscopy during swallowing. Dysphagia. 1994 Summer;9(3):162-7.
Selley WG, Flack FC, Ellis RE, Brooks WA. The Exeter dysphagia assessment technique. Dysphagia. 1990;4(4):227-35. [pmid: 2209098].
Selley WG, Flack FC, Ellis RE, Brooks WA. Respiratory patterns associated with swallowing: Part 1. The normal adult pattern and changes with age. Age Ageing. 1989a May;18(3):168-72.
Selley WG, Flack FC, Ellis RE, Brooks WA. Respiratory patterns associated with swallowing: Part 2. Neurologically impaired dysphagic patients. Age Ageing. 1989b May;18(3):173-6.
Selley WG, Roche MT, Pearce VR, Ellis RE, Flack FC. Dysphagia following strokes: clinical observations of swallowing rehabilitation employing palatal training appliances. Dysphagia. 1995 Winter;10(1):32-5.
Shaker R, Lang IM. Effect of aging on the deglutitive oral, pharyngeal, and esophageal motor function. Dysphagia. 1994 Fall;9(4):221-8.
Shanahan TK, Logemann JA, Rademaker AW, Pauloski BR, Kahrilas PJ. Chin-down posture effect on aspiration in dysphagic patients. Arch Phys Med Rehabil. 1993 Jul;74(7):736-9.
Shike M. Percutaneous endoscopic stomas for enteral feeding and drainage. Oncology (Huntingt). 1995 Jan;9(1):39-44; 44, 47. [pmcid: 419372]. [pmid: 7718440].
Siebens H, Trupe E, Siebens A, Cook F, Anshen S, Hanauer R, Oster G. Correlates and consequences of eating dependency in institutionalized elderly. J Am Geriatr Soc. 1986 Mar;34(3):192-8.
Singer C, Weiner WJ, Sanchez-Ramos JR. Autonomic dysfunction in men with Parkinson's disease. Eur Neurol. 1992;32(3):134-40. [pmid: 1592069].
Smith DT. Experimental aspiratory abscess. Arch Surg. 1927;14:231-9.
Smith DT. Fuso-spirochaetal diseases of the lungs. Tubercle. 1928 Jun;9:420-37.
Smithard DG, O'Neill PA, England RE, Park CL, Wyatt R, Martin DF, Morris J. The natural history of dysphagia following a stroke. Dysphagia. 1997 Fall;12(4):188-93.
Smithard DG, O'Neill PA, Parks C, Morris J. Complications and outcome after acute stroke. Does dysphagia matter?. Stroke. 1996 Jul;27(7):1200-4.
Sobin J, Nathanson A, Engstrom CF. Endoluminal ultrasonography: a new method to evaluate dysphagia. ORL J Otorhinolaryngol Relat Spec. 1996 Mar-Apr;58(2):105-9.
Sonies BC, Wang C, Sapper DJ. Evaluation of normal and abnormal hyoid bone movement during swallowing by use of ultrasound duplex-Doppler imaging. Ultrasound Med Biol. 1996;22(9):1169-75. [pmid: 9123641].
Sonies BC, Weiffenbach J, Atkinson JC, Brahim J, Macynski A, Fox PC. Clinical examination of motor and sensory functions of the adult oral cavity. Dysphagia. 1987;1:178-86.
Sorin R, Somers S, Austin W, Bester S. The influence of videofluoroscopy on the management of the dysphagic patient. Dysphagia. 1988;2(3):127-35. [pmid: 3251686].
Spiegel JR, Creed J, Selber JC. A functional diagnosis of dysphagia using videoendoscopy [unpublished]. 21 p.
Spiegel JR, Creed J, Selber JC, Sataloff R. Evaluation and management of swallowing disorders in long-term care settings: a program utilizing videoendoscopic assessment [unpublished]a. 15 p.
Spiegel JR, Creed J, Selber JC, Sataloff R. Evaluation of a protocol for dysphagia management using VESS in nursing homes [unpublished]b. 11 p.
Splaingard ML, Hutchins B, Sulton LD, Chaudhuri G. Aspiration in rehabilitation patients: videofluoroscopy vs bedside clinical assessment. Arch Phys Med Rehabil. 1988 Aug;69(8):637-40.
Stern JS. Comparison of percutaneous endoscopic gastrostomy with surgical gastrostomy at a community hospital. Am J Gastroenterol. 1986 Dec;81(12):1171-3. [pmid: 3788925].
Stiegmann GV, Goff JS, Silas D, Pearlman N, Sun J, Norton L. Endoscopic versus operative gastrostomy: final results of a prospective randomized trial. Gastrointest Endosc. 1990 Jan-Feb;36(1):1-5.
Taub NA, Wolfe CD, Richardson E, Burney PG. Predicting the disability of first-time stroke sufferers at 1 year. 12-month follow-up of a population-based cohort in southeast England. Stroke. 1994 Feb;25(2):352-7.
Taylor CA, Larson DE, Ballard DJ, Bergstrom LR, Silverstein MD, Zinsmeister AR, DiMagno EP. Predictors of outcome after percutaneous endoscopic gastrostomy: a community-based study. Mayo Clin Proc. 1992 Nov;67(11):1042-9.
Teasell RW, Bach D, McRae M. Prevalence and recovery of aspiration poststroke: a retrospective analysis. Dysphagia. 1994 Winter;9(1):35-9.
Teasell RW, McRae M, Marchuk Y, Finestone HM. Pneumonia associated with aspiration following stroke. Arch Phys Med Rehabil. 1996 Jul;77(7):707-9.
Thomas DR, Verdery RB, Gardner L, Kant A, Lindsay J. A prospective study of outcome from protein-energy malnutrition in nursing home residents. JPEN J Parenter Enteral Nutr. 1991 Jul-Aug;15(4):400-4.
Thompson RS, Hall NK, Szpiech M, Reisenberg LA. Treatments and outcomes of nursing-home-acquired pneumonia. J Am Board Fam Pract. 1997 Mar-Apr;10(2):82-7.
U.S. Department of Commerce, Economics and Statistics Administration, Bureau of the Census. Statistical Abstract of the United States 1997. 117ed. Springfield (VA): National Technical Information Service; 1997 Oct. No. 14 resident population, by age and sex: 1980 to 1996.
Valenti WM, Trudell RG, Bentley DW. Factors predisposing to oropharyngeal colonization with gram-negative bacilli in the aged. N Engl J Med. 1978 May 18;298(20):1108-11.
Veis SL, Logemann JA. Swallowing disorders in persons with cerebrovascular accident. Arch Phys Med Rehabil. 1985 Jun;66(6):372-5.
Venkatesan P, Gladman J, Macfarlane JT, Barer D, Berman P, Kinnear W, Finch RG. A hospital study of community acquired pneumonia in the elderly. Thorax. 1990 Apr;45(4):254-8.
Vidyarthi SC. Diffuse miliary granulomatosis of the lungs due to aspirated vegetable cells. Arch Pathol Lab Med. 1967 Feb;83(2):215-8.
Volicer L, Seltzer B, Rheaume Y, Karner J, Glennon M, Riley ME, Crino P. Eating difficulties in patients with probable dementia of the Alzheimer type. J Geriatr Psychiatry Neurol. 1989 Oct-Dec;2(4):188-95.
Wade DT, Hewer RL. Motor loss and swallowing difficulty after stroke: frequency, recovery, and prognosis. Acta Neurol Scand. 1987 Jul;76(1):50-4.
Wallace JI, Schwartz RS, LaCroix AZ, Uhlmann RF, Pearlman RA. Involuntary weight loss in older outpatients: incidence and clinical significance. J Am Geriatr Soc. 1995 Apr;43(4):329-37.
Webb DJ, Fayad PB, Wilbur C, Thomas A, Brass LM. Effects of a specialized team on stroke care. The first two years of the Yale Stroke Program. Stroke. 1995 Aug;26(8):1353-7.
Wein B, Bockler R, Klajman S. Temporal reconstruction of sonographic imaging of disturbed tongue movements. Dysphagia. 1991;6(3):135-9. [pmid: 1914541].
Winfield JB, Sande MA, Gwaltney JM Jr. Aspiration during sleep. JAMA. 1973 Mar 12;223(11).
Winstein CJ. Neurogenic dysphagia. Frequency, progression, and outcome in adults following head injury. Phys Ther. 1983 Dec;63(12):1992-7. [pmid: 6647555].
Winterbauer RH, Durning RB Jr, Barron E, McFadden MC. Aspirated nasogastric feeding solution detected by glucose strips. Ann Intern Med. 1981 Jul;95(1):67-8.
Wintzen AR, Badrising UA, Roos RA, Vielvoye J, Liauw L, Pauwels EK. Dysphagia in ambulant patients with Parkinson's disease: common, not dangerous. Can J Neurol Sci. 1994 Feb;21(1):53-6.
Wolfsen HC, Kozarek RA, Ball TJ, Patterson DJ, Botoman VA. Tube dysfunction following percutaneous endoscopic gastrostomy and jejunostomy. Gastrointest Endosc. 1990 May-Jun;36(3):261-3.
Wright RE, Boyd CS, Workman A. Radiation doses to patients during pharyngeal videofluoroscopy. Dysphagia. 1998 Spring;13(2):113-5.
Wu CH, Hsiao TY, Chen JC, Chang YC, Lee SY. Evaluation of swallowing safety with fiberoptic endoscope: comparison with videofluoroscopic technique. Laryngoscope. 1997 Mar;107(3):396-401.
Wynn DR, Rodriguez M, O'Fallon WM, Kurland LT. A reappraisal of the epidemiology of multiple sclerosis in Olmsted County, Minnesota. Neurology. 1990 May;40(5):780-6. [pmcid: 415551].
Wynne JW. Aspiration pneumonitis. Correlation of experimental models with clinical disease. Clin Chest Med. 1982 Jan;3(1):25-34. [pmid: 7075159].
Yorkston KM. (University of Washington School of Medicine; Rehabilitation Medicine) External review for: Diagnosis and Treatment of Dysphagia in the Elderly [letter]. 1998 Sep 9, p. 2.
Young EC, Durant-Jones L. Developing a dysphagia program in an acute care hospital: a needs assessment. Dysphagia. 1990;5(3):159-65. [pmid: 2123428].
Zaidi NH, Smith HA, King SC, Park C, O'Neill PA, Connolly MJ. Oxygen desaturation on swallowing as a potential marker of aspiration in acute stroke. Age Ageing. 1995 Jul;24(4):267-70.
Zenner PM, Losinski DS, Mills RH. Using cervical auscultation in the clinical dysphagia examination in long-term care. Dysphagia. 1995 Winter;10(1):27-31.