# Conclusions

Dysphagia (difficulty swallowing) is a cluster of symptoms that is commonly experienced by elderly patients with neurologic diseases. The incidence and prevalence of dysphagia cannot be exactly determined, precisely because it is a cluster of symptoms, implying that diagnostic technology as well as clinician judgment will affect the reported occurrence. With this in mind, it can be estimated that the greatest burden of illness of dysphagia occurs in stroke patients; approximately 160,000 to 573,000 stroke patients are affected by dysphagia each year; this is 42 to 75 percent of all stroke patients. The annual burden of illness created by other neurologic diseases is much smaller (approximately 51,000), due to the much lower incidence of these diseases.

This report addresses four main questions, but there are two interrelated themes that run throughout it. The first of these is that the treatment given to patients diagnosed with a swallowing disorder makes it impossible to accurately determine the sensitivities and specificities of the diagnostic test. The second is that the statistical power of many studies in this field is simply too low to find differences between groups, should such differences exist. The relatively low quality of the literature in this area is also worth noting. We recognize that our attempt to come to conclusions based on the limited evidence available to us is uncommon. However, it must also be recognized that many of today's pressing healthcare questions must be answered in the absence of strong evidence, and that failure to do so imposes serious limitations on the practical applications of an evidence-based medicine.

The first question we addressed in this report is perhaps the one most important to society. This question asks whether stroke patients fare better with a dysphagia diagnosis and treatment program than without. As such, the answer to this question depends on both the performances of the tests used to diagnose dysphagia and the efficacy of the treatments for this disorder. We conclude from our analysis of the evidence pertaining to this question that there is a correlation between use of a dysphagia program and a reduction in aspiration pneumonia rates. However, the available studies do not allow us to rule out the possibility that this reduction is due to other causes. This is because the designs of these studies do not rule out the possibility that other factors such as unspecified changes in physician practice, changes in hospital policy and procedures, or even some unknown factor may have caused the effect. This is why the efficacy of dysphagia diagnosis and treatment programs must be ascertained using randomized controlled trials. While it is probably unethical to perform a controlled trial that includes a patient group that does not receive treatment, it is ethical to compare the efficacy of different dysphagia programs. In this light, it is important to remember that the purpose of randomization is not to control for known confounds, it is to control for unknown confounds. Therefore, in the face of the current data that lack such control, we can only conclude that use of dysphagia programs is correlated with a reduction in aspiration pneumonia rates. We cannot technically conclude that these programs cause this reduction. However, it is also important to note that the effects observed in the better studies are large, so it would be imprudent to ignore them. Therefore, these results must be taken as evidence of the efficacy of dysphagia management programs.

We further address this first question in our supplemental analysis. The results of this analysis indicate that implementation of a dysphagia diagnosis and management program is cost-effective. However, the results of this supplemental analysis are subject to the same caveats as our analysis of the effectiveness of these programs, so they should not be regarded as absolute.

Our second question addressed the ability to predict or detect morbidity (in the form of aspiration, aspiration pneumonia, or malnutrition) from signs and symptoms detectable during a preliminary bedside exam (BSE). One aspect of this question concerns whether a preliminary BSE is sensitive enough to be used in isolation [without a full BSE or instrumented followup], or, alternatively, whether it can selectively identify patients who would benefit from more extensive diagnostic testing.

No single clinical sign or symptom appears to have satisfactory clinical utility for prediction of aspiration pneumonia or aspiration. The presence of a cough is probably the best detector of aspiration, but its detection of aspiration is not sufficiently reliable. However, there is no need to restrict clinicians to use of a single sign or symptom, and more research on the utility of combinations of signs and symptoms needs to be conducted.

Aspiration is not the only potential risk factor for aspiration pneumonia. While there were no clinical signs or symptoms directly related to dysphagia that predicted aspiration pneumonia well, it was found that dentition status and oral hygiene did show some predictive value for pneumonia. This is an area not yet well-explored, but worth further study.

No studies have examined signs and symptoms that may predict malnutrition, and it has not even been definitively established that dysphagia is associated with an increased incidence of malnutrition.

The third question addressed in this report compared the sensitivity and specificity of several dysphagia diagnostic tests. While there was a trend in one study that suggested that use of fiberoptic endoscopic examination of swallowing and sensory test (FEESST) in a dysphagia management program better prevented aspiration pneumonia than modified barium swallow (MBS), the difference was not statistically significant. Studies comparing MBS with fiberoptic endoscopic examination of swallowing (FEES) have generally found that MBS detects some cases of aspiration that FEES does not, while FEES detects some that MBS does not. There is no way to determine which diagnostic is correct because, in spite of common belief that MBS is a gold standard test, this has not been proven.

Full BSEs can have sensitivities for aspiration near 80 percent, and specificities near 70 percent. This, plus the fact that about half of the patients with aspiration do so silently (without a cough) and the very low pneumonia rates observed in dysphagia management programs that used full BSEs, indicates that these BSEs are capable of detecting most aspiration (even silent aspiration), or that any undetected aspiration does not contribute greatly to the pneumonia rate. In spite of these good results, the ability of the BSE to detect aspiration should be optimized in future research.

Currently available data do not allow one to determine the degree to which, or even whether, use of videofluoroscopy leads to lower pneumonia rates than the BSE. This is in spite of the fact that it is reasonable to believe that videofluoroscopy would be superior because of the additional information it provides. One reason that videofluoscopy has not been shown to be superior to the full BSE is that the results of the latter are difficult to improve upon. One result of this is that available studies do not have enough statistical power to detect the relatively small differences between diagnostic tests that one should expect.

Because of the lack of appropriate data, we compared videofluoroscopy and the full BSE in our supplemental cost-effectiveness analyses. These analyses, which are based on published protocols, assume that a preliminary test will be used to refer no more than 39 percent of all patients to a subsequent full BSE or videofluoroscopy. Under these conditions, our analysis suggests that a dysphagia diagnosis and treatment programs that employ the BSE would either save money or have very little net costs if they reduced pneumonia rates by amounts similar to those obtained in certain published studies. In addition, our results indicate that the slightly higher costs of videofluoroscopy would be offset if it provided an additional 10 percent reduction in pneumonia rates.

The fourth primary question in this report addressed the efficacy of different treatment interventions in preventing serious morbidity (pneumonia and malnutrition), their effect on short-term outcomes (weight change, energy intake, aspiration, prevention of a feeding tube, and minor feeding tube complications), and their effect on long-term outcomes [quality of life (QOL) and mortality]. Data provided by these studies are of very limited use because of poor study design. There is limited evidence from one randomized controlled trial (RCT) that a mechanically altered (soft solids and thickened liquids) diet is superior to a pureed diet for stroke patients with a history of aspiration pneumonia. Results of another randomized controlled trial on the intensity of swallow therapy on pneumonia incidence were inconclusive. Otherwise, the literature is exclusively case series, which were not comparable to one another because of differences in care settings, patient characteristics, or length of followup. Percutaneous endoscopic gastrostomy (PEG) tube literature generally indicates a superiority of PEG over nasogastric (NG) tubes, operative gastrostomy (OG), and percutaneous endoscopic jejunostomy (PEJ) tubes; these studies also report a higher rate of morbidity than do those studies of patients undergoing noninvasive therapy. This could be due either to the greater level of debilitation in patients needing a feeding tube or aspects of the treatment itself.

In conclusion, data to answer these four questions are sparse and not of the highest reliability. Determining the clinically prudent course of action in these circumstances raises ethical issues. This is because, while the superiority of any given dysphagia diagnosis and treatment has not been proved, such programs have the potential to benefit patients, and a minimal potential to harm them. They also have the potential to be cost-effective. Withholding such programs would deny these potential benefits to patients. It therefore seems prudent to conclude that active stroke management in acute care continue to include dysphagia-specific management with formal diagnosis and treatment (the specifics of which can be determined by the individual hospital) as part of standard protocol.

At the same time, current data prohibit us from specifying the precise components of these programs, and future research in this area is urgently needed. To this end, we detail in the Future Research section of this evidence report a recommended clinical trial that will answer many of the outstanding questions. We strongly suggest that this trial, or some version of it, be conducted in the near future.