# Results

In this section, we discuss and assess the evidence for each relevant link in the evidence model as it relates to each of our four primary questions.

## 1. How does the diagnosis of dysphagia or aspiration affect the subsequent course of treatment and outcomes?

We address the first question in two subsections. The first addresses whether use of an instrumented or noninstrumented diagnostic improves patient outcomes, particularly aspiration pneumonia. In the second subsection, we examine the evidence for whether these diagnostics change patient management. Nevertheless, we do not ignore outcomes in this second section, and we discuss, wherever possible, the outcomes associated with specific treatments. We more directly address the question of which treatments are most effective in the fourth question of this evidence report.

### Outcomes: Dysphagia Diagnosis Treatment Program for Prevention of Serious Morbidities

The primary reason to use any diagnostic test is to improve patient management and, thus, patient outcomes. Several dysphagia-related outcomes are important, including subjective patient quality of life (QOL) improvement, prevention of malnutrition, prevention of dehydration, prevention of pneumonia, and prevention of death.

We could not find sufficient suitable data for formal evaluation of QOL improvement due to dysphagia diagnosis, so this outcome is not evaluated in relation to our first question.

One of the most meaningful endpoints to patients is prevention of death. Again, there was little evidence on this in the literature, particularly on death due to malnutrition (if, despite the availability of feeding tubes, it occurs). We were, however, able to estimate potential death rates due to dysphagia, and these are addressed in the Epidemiology section of this report.

#### Malnutrition and Dehydration

Prevention of malnutrition and dehydration is also important, but the relationship between these outcomes and diagnosis of dysphagia is difficult to determine from available evidence. This is partly because the administration of parenteral or enteral nutrition is often introduced if there is even a threat of malnutrition. Similarly, intravenous fluids are commonly given to inpatients with any serious disease or illness that precludes ingestion of liquids. For these reasons, in acute care, malnutrition and dehydration are largely dealt with outside of the context of formal diagnosis and treatment of dysphagia. This could explain why few studies have attempted to determine the extent to which (or even whether) dysphagia causes malnutrition/dehydration. Because of the resulting lack of evidence, we do not examine this outcome in relation to this question. There is, however, the possibility that for some patients, diagnosis of dysphagia may lead to therapy that prevents malnutrition and/or dehydration, and therefore obviates the need for feeding tubes. Whether, in fact, dysphagia management does reduce the use of feeding tubes is addressed in our fourth question.

#### Pneumonia

For the purposes of this question, then, prevention of pneumonia is the primary endpoint, an endpoint that is reported relatively often in the literature. The advantage of this endpoint is that it allows us to ask whether use of any particular diagnostic leads to lower pneumonia rates. In addressing this question, we focused on stroke patients, either in acute care, rehabilitation units, or nursing homes, inasmuch as this reflects the emphasis of the literature.

Aspiration pneumonia, in particular, is the specific diagnosis of interest in a population with dysphagia, as these patients are at risk of aspirating food or liquid into their lungs. The definition of aspiration pneumonia is not clear in the medical literature, and it is often difficult to diagnose without the use of invasive procedures. It is therefore questionable in many studies whether patients diagnosed as having aspiration pneumonia were actually definitively diagnosed as such. Adding to this confusion is the fact that the causative relationship between aspiration and pneumonia has been demonstrated in the literature as somewhat tenuous (see the section entitled Burden of Illness). In addition to aspiration, the general debilitation, malnutrition, and dehydration that may accompany stroke and degenerative neurologic conditions could increase risk of pneumonia by weakening immune defenses. Also, poor oral hygiene might accompany these conditions and thus increase the presence of oral-pharyngeal bacteria or other microorganisms that cause increased risk of pneumonia. Nevertheless, in the presence of markedly increased dysphagia and aspiration in these neurologically impaired patients, aspiration remains the most plausible route into the lungs for microorganisms that might overwhelm a weakened immune system. Therefore, even though aspiration alone may not be sufficient to cause pneumonia in otherwise uncompromised people, aspiration does appear to participate in the etiology as the most plausible route of harmful microorganisms into the lungs. Thus, the term aspiration pneumonia is probably warranted in patients who are at such increased risk of both aspiration and pneumonia.

Because of the lack of uniformity in the criteria for distinguishing aspiration pneumonia from other pneumonia in dysphagia in published studies, we were forced to accept the terminology used by the authors of each study. This is unlikely to have had a major impact on the results of this report because there were no marked differences in the frequency of pneumonia in acute stroke patients, regardless of whether the authors stated they were studying aspiration pneumonia or just pneumonia. However, the term chest infection, which is common in the medical literature of the U.K., did appear to be a broader definition that was associated with markedly higher frequencies. For this reason, we generally did not use this type of data. Otherwise, we included and analyzed any dysphagia study that examined pneumonia, regardless of whether the authors stipulated that it was aspiration pneumonia. Because we must frequently refer to results from more than one study, we often use the generic term pneumonia, even though some of the studies being referred to may have used the term aspiration pneumonia. Under the circumstances, it does not appear practical to put too fine a point on the possible distinctions between these terms.

The links of the evidence model that are relevant to answering this first question are the links between each of the diagnostic techniques and aspiration pneumonia. Referring to the evidence model shown in Figure 1, these are the eight imaginary lines between each of the boxes labeled D1 through D8, and box M8. These links each ask whether there is a relationship between use of any of the diagnostic tests and pneumonia or, more specifically, does use of any of these tests prevent aspiration pneumonia? It is also possible to compare the results of one link with another to determine whether the use of one diagnostic leads to lower pneumonia rates than another. As such, these links presume that treatment intervened between diagnosis and the outcome and, therefore, these links address the efficacy of dysphagia diagnosis and treatment programs. To ensure that the meaning of each link is clear, we preface our discussion of these links by presenting in each heading the question posed by the link and parenthetically noting the codes for the specific boxes of the evidence model that comprise the link.

#### Does Use of Noninstrumented Exams in A Dysphagia Program Reduce Pneumonia Rates? (Links D1 through D4 to M1)

To address this link, we have combined history and physical examinations and the formal and informal bedside examinations (BSEs) into a single question. This is appropriate because we can assume that all patients receive some sort of history and physical as part of the routine examinations conducted on stroke patients.

We found no randomized controlled trials (RCTs) that were relevant to this question.

We found one study (Odderson, Keaton, and McKenna, 1995) of a dysphagia program that used aspiration pneumonia as an outcome and that included a control group. This study was a historical prospective case series that assessed the efficacy of a dysphagia program using a BSE followed by speech-language therapy. The assessment consisted of comparing pneumonia rates at the same institution immediately before, and after introduction of the program (see Evidence Table 25 for a description of this study and its results). This study was performed in an urban community hospital. A pneumonia frequency of 6.7 percent (95 percent CI of 3.1 to 14 percent) was reported in consecutively admitted stroke patients the year before instituting a dysphagia program (the historical control group). A frequency of 4.1 percent (and a CI of 1.8 to 9.3 percent) was reported in 121 patients during the first year of the program, and no cases of pneumonia out of 124 admissions (CI = 0 to 3.0 percent) during the second program year. Oral communication with the author indicated that there was one case of pneumonia in the third year and no cases in the fourth year (Odderson, 1998). In this program, a preliminary BSE, typically administered by a nurse, was used to determine whether patients had a safe swallow, defined by the following criteria: (1) the patient is alert, follows simple requests, has a clear, strong voice, and can produce a strong cough; (2) the patient can handle his or her own secretions without difficulty, and can swallow ice chips and sips of ice water briskly; and (3) the larynx elevates completely at the time of swallowing, the voice remains clear after swallow, and there is no coughing afterwards. If the patient met all of these criteria, trial meals were instituted starting with thin and thick liquids.

Patients not passing the preliminary test had oral intake restricted and were given a formal BSE by a speech-language pathologist (SLP). Dysphagia patients were followed by speech pathologists with 15-minute daily sessions for 6 days. The mean length of hospital stay for all stroke patients was 7 days during the program and 9 days in the pre-program period.

The authors did not determine whether the reported decrease in pneumonia after initiation of the program was statistically significant. The authors of this study also did not test statistically whether the results obtained in the second program year were different from those obtained in the first. We carried out such an analysis by calculating the 95 percent CI around the difference between the two proportions (6.7 percent pneumonia prior to the program, and 0 percent for the second year of the program) using the method of Wilson as described by Newcombe (Newcombe, 1998), which compensates for the fact that the commonly used methods of calculating CIs around proportions (or their differences) yields spurious results when the proportions are near zero. The absolute difference between the percentage of all stroke patients with pneumonia before the program and during the second year was 6.7 percent, with a 95 percent CI from 2.0 to 11 percent. The fact that the CI around the difference does not include zero indicates that the difference is statistically significant. Another way to analyze these data is to calculate the proportional reduction in relative risk (RRR).^1^ We calculated the RRR for the first program year was 39 percent, and for the second year, it was 100 percent.

1 RRR is calculated according to the formula: (percent of patients with pneumonia in the control group-percent of patients with pneumonia in the program group)/(the percent of patients in the control group with pneumonia).

This trial may represent one of the few ethical ways to compare the results of an explicit program that included diagnosis and treatment with a situation in which there was no diagnosis. Nevertheless, the pre-program data almost certainly underestimate a true no diagnosis situation, because according to oral communication with the author, some patients in the pre-program year were receiving whatever dysphagia diagnosis and treatment was requested by attending physicians (Odderson, 1998). Given this, it is tempting to speculate that greater pneumonia rates would be found in the true no diagnosis situation and that, therefore, this trial underestimates the effect of a dysphagia program. However, the study has weaknesses that preclude reaching such a conclusion. First, there was no in-depth comparison of the patient characteristics before the program and during the program, so the authors did not formally demonstrate that these patient groups were similar. Second, the data were not collected in the same way for the pre-program and program groups. The pre-program data were collected retrospectively, and the program data were collected prospectively. It would have been preferable if both were collected prospectively, because this would provide more confidence that there was no bias in the selection of comparison of the groups in this nonrandomized study. Finally, because the control and experimental group data were obtained at different time periods, there remains the formal possibility that, as with any time series-like study, improvements in patient outcomes were due to some unspecified change in physician practice, patient management, or hospital practice and policies. Because of these shortcomings, it is fair to conclude that an improvement with pneumonia rates was correlated with the presence of a dysphagia program that used a BSE as the diagnostic tool, but the evidence that this improvement was caused by this program is relatively weak. It is also imprudent to assume that the size of the effect measured by these authors (i.e., that their program was perfectly successful) is generalizable, but in the face of such a large apparent effect, it is similarly imprudent to entirely dismiss the results of this study because of its weaknesses.

Because this was the only relevant U.S. information we located, we searched the foreign literature for additional evidence. We found an uncontrolled study from a Swedish program (Nilsson, Ekberg, Olsson et al., 1998) that reported a pneumonia frequency of 2.8 percent (2/72) for consecutive stroke patients over a 6-month interval (see Evidence Table 27). This was the frequency for patients who were able to respond to the preliminary BSE, which was simply patient report of difficulty swallowing. Patients who thus self-reported dysphagia were treated with parenteral nutrition (IV drips) or diet modification as needed; no nasogastric (NG) or gastrostomy tubes were used. An additional 28 percent of stroke patients were not evaluable, and they had a pneumonia frequency of 11 percent (3/28).

##### Adjustment of published results to a common followup period

It is difficult to interpret or compare the results of the above studies because they used different followup periods. For example, the pre-program followup in the Odderson et al. study (Odderson, Keaton, and McKenna, 1995) averaged 9.8 days, and the followup during the second program year averaged 7.2 days. Further, the Nilsson et al. study (Nilsson, Ekberg, Olsson et al., 1998) used yet another followup, 6 months. The problem in comparing such data arises because the incidence of pneumonia may change as a function of the time since the stroke. We therefore sought to adjust these results to a standard time period after stroke.

In this effort (described more fully in Appendix A), we found no studies that specifically reported the change in the incidence of aspiration pneumonia with time following stroke. We did, however, find one study that reported the change in incidence of chest infection over the time following stroke. Davenport, Dennis, Wellwood et al. (1996) (Webb, Fayad, Wilbur et al., 1995) plotted the cumulative percent of chest infection out to 30 days following stroke. Chest infection is a broader definition than the usual aspiration pneumonia criterion of radiologically confirmed lower pulmonary evidence of pneumonia; however, the shape of this declining incidence curve should be approximately the same for both definitions. This means that at each weekly interval following stroke, the proportion of cases should be the same for both curves, although the absolute numbers might be different. Thus, we fitted a logarithmic curve (SPSS 7.5, Chicago, IL) to the Davenport et al. data, and from this curve, we were able to interpolate the proportion of pneumonia cases occurring at each weekly interval following stroke. We then applied the appropriate weekly interval adjustment factor to the frequency for any reported interval, and standardized the pneumonia frequencies to a single interval.

For the Odderson et al. study, we standardized to a 7-day interval, because that closely approximated the 7.3- and 7.2-day length-of-stay (LOS) intervals for their pneumonia frequencies for the first and second years of their program. The 9.8-day LOS interval for the pre-program year was likewise adjusted to a 7-day interval. The only effect of this adjustment was to change their historical control frequency of pneumonia from 6.7 to 6.3 percent (Evidence Table 25). The program frequencies did not change, and the difference in pneumonia frequency between the pre-program year and the second program year was still statistically significant.

##### Exploratory analysis using pooled historically controlled data

Because only the Odderson et al. study provided a historical control pneumonia frequency for a period without a structured dysphagia program, we searched for additional historical control data (Evidence Table 26) from studies that that did not have an evaluation of a dysphagia program, nor they attempt evaluation. We found one such contemporary U.S. study that reported the frequency of pneumonia in stroke patients in an acute-care facility (Young and Durant-Jones, 1990). The pneumonia frequency was 13 percent (28 of 216 patients; 95 percent CI were 9.1 to 18 percent). Four percent of the patients were excluded because they were comatose. They are likely to have had a high frequency of pneumonia that would increase the overall frequency slightly if they were included. However, on an intent-to-treat basis, these patients would not be eligible for modified barium swallow (MBS), fiberoptic endoscopic examination of swallowing (FEES), or interactive therapy, therefore, we can exclude them from analysis. The followup interval was a mean LOS of 31 days. In Evidence Table 26, we show the pre-program pneumonia frequency from Odderson, Keaton, and McKenna (1995) and the additional U.S. no-program frequency we located (Young and Durant-Jones, 1990).

We also found two older studies reporting pneumonia frequency after stroke, covering the years 1967 through 1984 (Barker and Mullooly, 1997; Haerer and Smith, 1974). These studies reported frequencies of 8.6 percent and 10 percent. Because these frequencies were within the range reported in the two more recent studies described above and did not appear to change over these years, we performed an exploratory analysis in which we averaged all of these reported frequencies to get a historical no-program pneumonia frequency of 9.2 percent (95 percent CI = 7.8 to 11 percent) to compare with the above dysphagia program case series pneumonia frequencies. Adjusted to a 2-week interval, this historical control frequency was 8.2 percent (CI = 6.9 to 9.7 percent; Evidence Table 27). This is an arbitrary interval, but it does approximate the typical LOS in the articles we examined.

We then performed an exploratory analysis in which the Odderson, Keaton, and McKenna (1995) and Nilsson, Ekberg, Olsson et al. (1998) data were compared with the historical controls. We refer to this as an exploratory analysis because it is subject to the same problems as other quasi-experimental designs. Among these problems are the inability to control for patient characteristics and the inability to control for different practices and policies that may exist at different institutions. These weaknesses exist not only in our comparison of the experimental and control groups but also in combining the historical data into a single number. Therefore, the results of this analysis should be considered circumstantial.

Stated in another way, although our comparison involves statistically combining results, it should not be confused with a formal meta-analysis. The latter is usually conducted on data from a homogeneous set of RCTs (all using the same treatment), whereas we have compared the results of heterogeneous case series studies (different diagnostic and treatment methods) with those of other case series that we used as historical controls. Our analysis does not have the internal validity of a meta-analysis of controlled trials, which would pool only the within study differences between experimental and control groups, because it cannot control for different treatment settings of patient populations.

Evidence Table 27, which displays the results of this exploratory analysis, shows the raw and adjusted frequencies for the program years for Odderson, Keaton, and McKenna (1995) and Nilsson, Ekberg, Olsson et al. (1998), along with the difference between each program year and the historical control frequency we calculated, both raw and adjusted to a 2-week interval. Reduction of relative risk, adjusted and unadjusted, are also shown. The 95 percent CIs around the differences indicate that, for the raw or adjusted frequencies, the second year of the Odderson, Keaton, and McKenna (1995) study achieves statistical significance at an alpha level of 0.05 (the 95 percent CIs for the differences do not include 0), but that the reported frequencies in the Nilsson, Ekberg, Olsson et al. (1998) study do not achieve statistical significance (the CIs around the differences include 0).

Because our analysis is exploratory, it should be considered a descriptive analysis, and not one that attempts to ascribe causation. Nevertheless, this analysis is consistent with the results obtained when the Odderson, Keaton, and McKenna (1995) data are considered by themselves and are consistent with the idea that there are lower pneumonia rates in the second year of this program than in historical controls.

It is tempting to speculate that the reason that the Odderson, Keaton, and McKenna (1995) data were different from historical controls and from the Nilsson, Ekberg, Olsson et al. (1998) data is that the latter investigators diagnosed dysphagia on the basis of patient self-report, and the former used a more structured exam. This, in turn, would imply the superiority of the more structured exam. Such an explanation, however, is not warranted because, although the results of the Nilsson et al. study were not significantly different from those of the controls, they were also not different from those of Odderson and colleagues.

We can also speculate that the reason that Odderson, Keaton, and McKenna (1995) found results that were significantly greater than our historical controls and Nilsson, Ekberg, Olsson et al. (1998) did not is because the latter had fewer patients (72 versus 124 in the Odderson et al. study). Stated in another way, the statistical power of the comparison of Nilsson, Ekberg, Olsson et al. (1998) data to the historical controls was too low. However, this argument cannot be proven, because we cannot demonstrate that the results of the comparison of the two studies would have been different if Nilsson et al. had used more patients.

Because of the issues related to statistical power that surround this comparison, we also calculated the proportional RRR brought about by incorporating a swallowing program into stroke patient management. For the raw numbers this ranged from 55 to 100 percent RRR, and for the frequencies adjusted to a 2-week interval this ranged from 44 to 100 percent reduction in risk. We did not conduct a significance test on these reductions, and provide them only to illustrate that the same trend exists in both the Odderson, Keaton, and McKenna (1995) and Nilsson, Ekberg, Olsson et al. (1998) data. Again, these data are suggestive that dysphagia management programs are efficacious, but cannot be conclusive.

For these reasons, the results of our exploratory analysis are equivocal. It is therefore prudent to rely more heavily on the results of the internally controlled analysis of the Odderson et al. data. This evidence indicates that a reduction in the frequency of aspiration pneumonia is correlated with the presence of a dysphagia diagnosis and treatment program.

#### Does Use of Videofluoroscopic Swallowing Studies (VFSS) in A Dysphagia Program Reduce Pneumonia Rates? (Link d5 to m1)

##### VFSS in acute-care settings

Next, we examined whether using VFSS (see Evidence Table 24 for study descriptions and Evidence Table 27 for results) in dysphagia programs reduces aspiration pneumonia rates. We found no relevant controlled trials or historical prospective case series. Rather, we found only one case series performed at an acute-care facility that enrolled consecutive stroke patients and diagnosed them using VFSS (Daniels, Brailey, Priestly et al., 1998). This study was conducted at a Veterans Administration medical center. All stroke patients were given a MBS exam, except for 4 percent (2/55) whose mental state did not permit the exam. Patients with dysphagia were treated using one or more of: swallowing therapy, compensatory strategies, diet alteration, or nonoral feeding. This study reported a pneumonia frequency of 1.8 percent (1/55; 95 percent CI = 0.3 to 9.6 percent) over an interval of 3 months.

##### Exploratory analyses using pooled historically controlled data

In another exploratory analysis, we compared the results of the study noted in the previous paragraph with the above historical no-program controls. The raw difference between the pneumonia frequency in this study and these controls (Evidence Table 26) was 7.4 percent (95 percent CI = 0.5 to 9.6 percent). The frequency adjusted to a 2-week interval (1.8 percent; CI = 0.3 to 9.6 percent) was nearly identical to the nonadjusted frequency. The adjusted difference was 6.4 percent (-1.5 to 8.5 percent), which was not statistically significant. The relative reduction of risk for the raw values was 80 percent, and the adjusted value was 78 percent.

As with the above study by Nilsson, Ekberg, Olsson et al. (1998), there is a possibility that the failure to achieve statistical significance in this VFSS study was due to its small size (55 patients) and consequent low statistical power. In view of the statistical significance of the more powerful (90 control year patients, 124 program year patients) results of Odderson, Keaton, and McKenna (1995) for their program using a BSE on only 39 percent of stroke patients and considering that VFSS apparently detects patients with silent aspiration who may not be detected by the BSE, it seems unlikely that a program using VFSS on all patients would do worse in preventing aspiration pneumonia than a BSE program. Thus, the interpretation most consistent with the Odderson et al. study and the ability of VFSS to detect more patients with aspiration is that the trend reported in the Daniels et al. VFSS study is real, but the study had statistical power too low to detect the effect with statistical significance (a type II error in statistical parlance). However, this argument is not conclusive, because it does not prove that the comparison involving the Daniels et al. study would have yielded different results had they enrolled more patients.

One way to compensate for the low power of the Nilsson et al. and Daniels et al. studies is to determine whether taking the results of all three dysphagia programs together, despite their obvious diagnostic and treatment differences, yields a result that is significantly different from the result obtained in the combined historical control group. We did this in a third exploratory analysis, in which we examined the CI around the difference between the mean of the three program groups and mean of the historical control group (see Evidence Tables 26 and 27). The differences, both unadjusted and adjusted to a 2-week interval, and the appropriate CIs are shown at the bottom of Evidence Table 27. The unadjusted difference is 8.0 percent (95 percent CI = 5.4 to 9.8 percent), and the difference adjusted to a 2-week interval is 6.9 percent (4.3 to 8.6 percent). Neither of the confidence intervals include 0, demonstrating statistical significance at an alpha level of < 0.05. This statistical significance is likely due to a real effect, either of the dysphagia programs or of any several possible confounding factors.

This statistically significant difference also strongly suggests that low statistical power is, indeed, a problem in these individual studies. Further, it supports the idea that reductions in aspiration pneumonia are correlated with the presence of a dysphagia diagnosis and treatment program. This difference, however, does not demonstrate that dysphagia management programs cause a reduction in aspiration pneumonia. This is because this exploratory analysis cannot compensate for possible confounding of results, for example, by differences in patient characteristics between the program studies and the historical controls or other unspecified differences in provider practice or hospital policy.

The results of one BSE program study were statistically different from those of historical controls but the results of the VFSS program study were not. However, it would be a mistake to conclude that the two tests were of equal efficacy from these data. This is for several reasons, the first of which is the experimental confounds that hamper reaching conclusions from our comparisons. Equally worthy of mention, however, is that the statistical power of these studies is too low to detect the apparently small difference between programs. If two of these three studies did not have sufficient power to detect the substantial apparent difference between the program results and the historical controls, then they must clearly have much less power to detect the much smaller apparent differences among the three program results. We have calculated in the Future Research section of this report that it would require tens of thousands of patients to detect a meaningful difference (25 percent reduction of relative risk) between two diagnostic programs. Therefore it would be wrong to interpret these data to indicate that the BSE is as good or better than VFSS, or vice versa, because these studies are too small to resolve the expected small difference between these methods.

##### VFSS in rehabilitation care settings

We found one relevant U.S. study conducted at a rehabilitation center (Evidence Table 29). This study, performed by DePippo, Holas, and Reding (1994), reported a frequency of pneumonia of 6.5 percent (9/139) over a mean LOS interval of 9 weeks. Patients judged clinically to have dysphagia were given an MBS exam followed by compensatory training and/or a modified diet. Prior to admission to the rehabilitation unit, 13 percent of these patients had pneumonia during acute care (mean LOS 5 weeks). It is not clear how many of them were exposed to a dysphagia program during acute care; however, pneumonia frequency during acute care is the same as the no-program frequency reported by Young and Durant-Jones (1990), but over a longer interval (5 weeks versus 31 days), and only for those patients who went into rehabilitation, not consecutive stroke patients.

We found a Canadian study (Teasell, McRae, Marchuk et al., 1996) reporting a pneumonia frequency of 2.7 percent (12/441) at a rehabilitation center, with an unreported LOS. Clinical suspicion of aspiration resulted in 24 percent of these consecutive stroke patients being given an MBS exam. High-risk patients received one or more of modified diet, compensatory swallowing techniques, or NG or gastrojejunal tubes. We also found an Israeli study (Gottlieb, Kipnis, Sister et al., 1996) that used a 50-ml water test BSE for a stroke dysphagia program. They reported a pneumonia frequency of 16 percent (8.1 to 27 percent) for their first 60 patients, 12 percent (5.8 to 22 percent) for the second 60, and 3.3 percent (0.9 to 11 percent) for the third 60 patients. Their overall mean was 10 percent (6.5 to 156 percent). Their followup intervals were between 7.4 and 8 weeks.

We could find no historical control data for aspiration pneumonia frequency for stroke patients in rehabilitation centers. Without either internal or historical controls, the results of these studies cannot be interpreted.

#### Does Use of FEES in A Dysphagia Program Reduce Pneumonia Rates? (Link D6 to M1)

We located one recent historical prospective case series, published in two articles, in which FEES was used to assess swallowing in patients referred to an otolaryngologist and SLPs in two nursing homes [Spiegel, Creed, Selber et al., unpub.(a); Spiegel, Creed, Selber et al., unpub (b)] (Evidence Table 29). The patients received individualized diet therapy depending on the FEES results. The authors found no cases of pneumonia during a 6-month period among the 85 referred patients; whereas, in the same 2 nursing homes there were 11 cases of aspiration pneumonia in the 6 months prior to instituting systematic use of FEES. The authors do not report the total number of patients for the pre-program period. If we assume that approximately the same number of patients were involved in the previous 6 months, the frequency of pneumonia would have been approximately 13 percent (95 percent CI = 7.4 to 22 percent), a statistically significant result. These frequencies are not directly comparable to the above frequencies for three reasons. First, these were nursing home patients. Second, these were not stroke patients, but rather patients with mixed etiology of dysphagia. Finally, these pneumonia frequencies were not for the whole cohort of patients, but only for those suspected of dysphagia and referred to dysphagia specialists. Nursing home stroke patients would be expected to have a lower frequency of stroke-induced aspiration pneumonia than do patients in acute-care or rehabilitation facilities because they are further from the event of the stroke. However, they do not comprise the whole stroke cohort, but only the most serious cases that cannot be rehabilitated to the point of home care. Also, within the nursing homes, the selected group of patients who are suspected of dysphagia and referred to swallowing specialists would be expected to have a much higher frequency of pneumonia than patients not referred.

As with the Odderson, Keaton, McKenna (1995) study, this study lacks information on the comparability of the patients before and after the FEES dysphagia program was introduced, and the lack of a control group makes it possible to ascribe the apparent effect of FEES to some unspecified change in physician practice, patient management, or nursing home practice and policies. Therefore, although it is possible to conclude that the introduction of FEES was correlated with a decrease in pneumonia rates, we cannot conclude that FEES was the cause of this decrease. In addition, the authors did not report the number of patients with clinically suspected dysphagia. Finally, there is no assurance that the tracking and determination of aspiration pneumonia cases were carried out in exactly the same way both years, preferably blinded to FEES diagnosis results and treatment. Nevertheless, and again as with the Odderson et al. study, the relative reduction in risk after introduction of FEES was 100 percent, a large apparent effect than cannot be dismissed lightly. This result is important because it was obtained in patients clinically suspected of dysphagia, a group known to have a high risk of aspiration pneumonia in any care setting (see Appendix B and Appendix C for further details).

Also similar to the Odderson et al. study is that our estimated absolute difference between the pre-program and program periods (13 percent; 95 percent CI of 5.9 to 22 percent) is statistically significant. Although these latter calculations are based on the assumption that the same number of patients were seen during the pre-program and program years, the statistical significance of this result is unlikely to be overturned by any reasonable imprecision in this assumption. Thus, we calculated that the pre-program year had to have 228 patients clinically suspected of dysphagia, or more than 2.6 times the number of clinically suspected dysphagia patients referred during the program year, for the difference between the pre-program year and the FEES program year to become nonsignificant at an alpha level of 0.05.

##### Unevaluable studies

We retrieved a number of studies that we did not further consider in our analysis. These were case series studies without historical controls that only reported the pneumonia frequency for patients clinically suspected of dysphagia and referred for dysphagia assessment by specialists. Because of differences in referral patterns and patient mixes, it was not possible to make comparisons between these studies. In addition, we could not devise any method for determining historical control pneumonia frequencies with which to compare these disparate studies. Some of these studies had two or more arms comparing different diagnostic methods or treatments, and these are presented below in sections dealing with treatment comparisons. However, none of them contained no-program arms that would allow assessment of the efficacy of whole diagnosis-treatment programs compared with no intervention.

### Conclusions

The conclusions in this subsection concern comparisons of pneumonia rates obtained with and without dysphagia diagnostic and treatment programs. The above-evaluated studies of Odderson, Keaton, and McKenna (1995), Daniels, Brailey, Priestly et al. (1998), and Spiegel, Creed, Selber et al. [unpub.(b)] have provided data (albeit data that are limited, and potentially confounded) that are consistent with, but do not prove, the idea that use of a BSE, VFSS, or FEES in a dysphagia diagnosis and treatment program may substantially reduce pneumonia rates in stroke patients with dysphagia. These data do not allow us to specify exactly how successful these programs are (i.e., how many cases of pneumonia they would prevent in a larger context), nor do they allow us to conclude definitively that these programs caused the reduction in pneumonia frequency (as noted above, that could have been caused by changes in hospital policy, physician practice, or some other unspecifiable factor). Nevertheless, it would be imprudent to dismiss the substantial effects observed in these studies, and thus they provide evidence about a question that is at the fifth level, near the top, in the hierarchy of the societal interest of the questions that we describe in the Evidence Model section of this evidence report.

The suggestion of apparently substantial efficacy of these dysphagia programs, while derived from historical prospective case series and case series compared with historical controls (which are typically not as reliable as RCTs), indicates that conducting a randomized controlled trial in which some patients were not allowed to participate in a dysphagia program would be unethical. Additional data from dysphagia programs and from historical controls or contemporary controls in institutions or geographic areas without dysphagia programs would be helpful in assessing the magnitude of the effect of dysphagia programs in preventing pneumonia.

Because of the lack of even a historically controlled study of a VF dysphagia program, because of a lack of studies of the long-term patient outcome of interest (prevention of aspiration pneumonia), and because of the small size of the one reported uncontrolled case series, there is no statistically significant efficacy demonstrated for VF studies in the prevention of aspiration pneumonia (although there is an apparent trend in the one study reported). Further, it has not been demonstrated that predictions of aspiration pneumonia derived from videofluoroscopy are superior to those derived from the BSE or FEES, although there are some studies demonstrating that VFSS can detect substantially more patients with the surrogate endpoint of aspiration than the BSE. This lack of statistically significant evidence does not mean VF swallowing diagnosis and treatment programs have no effect. Rather it reflects the lack of hard experimental evidence.

This section has only dealt with comparisons of diagnostic methods used in dysphagia programs compared with the no-program situation. Direct comparisons among BSEs and instrumented exams are discussed below in Questions 2 and 3.

### Diagnostic Test Guidance of Treatments

The results of a diagnostic test are typically used to determine the course of subsequent treatment. The diagnosis of aspiration or dysphagia per se will simply determine that treatment is necessary; more specific symptoms (such as the severity of aspiration) will determine the specific treatment applied. Clinicians may do this to different degrees- while some clinicians may simply determine treatment on the basis of gross manifestations (such as the presence or absence of aspiration), other clinicians may use a more specific technique, such as assessment of particular physiologic functions, as predictors of which treatment will be most effective.

One implication is that a description of the diagnosis that guided treatment is relatively uninformative unless the outcomes after the treatment are described as well. A study may report, for example, that detection of aspiration of more than 10 percent of bolus volume led to the placement of a feeding tube. If the study does not report the outcomes from these patients placed on feeding tubes, and compare them with other patients placed on feeding tubes using different diagnostic criteria, there is no way to determine if the influence of the diagnostic test on treatment helped the patient, had no beneficial effect, or harmed the patient.

Outcomes reported after the treatment should be clinically meaningful. It is not sufficient to report that the pharyngeal transit time as measured by videofluoroscopy was significantly reduced after tactile-thermal stimulation (TTA). Rather, the outcome measure must in some way directly measure the patient's well-being. Clinically meaningful outcomes are occurrence of pneumonia, dehydration, malnutrition, QOL, and mortality. Intermediate or surrogate measures that would fit these criteria would be occurrence of aspiration, coughing, or choking; these are all measurable outcomes that directly affect the patient.

Diagnostic technologies can be used to guide treatment in two ways: the diagnostic can detect signs that predict the success of future treatments, or the diagnostic can be used while treatments are being attempted. Videofluoroscopy has often been used in the latter way. However, while videofluoroscopy may indicate that a particular treatment is effective in the first 5 minutes, it cannot determine whether the patient is able to continue receiving benefit long term.

Many studies, most using videofluoroscopy, have used a diagnostic technology to guide or assess treatment. This has been done to assess the appropriateness of specific dietary characteristics (Bisch, Logemann, Rademaker et al., 1994; Logemann, Pauloski, Colangelo et al., 1995), postural changes (Ekberg, 1986; Logemann, Kahrilas, Kobara et al., 1989; Rasley, Logemann, Kahrilas et al., 1993; Shanahan, Logemann, Rademaker et al., 1993), and other applied treatments (de Lama Lazzara, Lazarus, and Logemann, 1986; Rosenbek, Robbins, Willford et al., 1998). Only one study used a diagnostic method other than videofluoroscopy to make treatment recommendations (Eibling, 1994). No studies have reported the use of symptoms detected using any other diagnostic method to guide the course of treatment.

#### Does Diagnosis-Directed Diet Modification Improve Swallow Function? (Links D1 - D8 to T2)

Evidence Table 30 shows two studies that used specific findings on videofluoroscopy to guide diet modification. Logemann, Pauloski, Colangelo et al. (1995) tested the use of a sour bolus at different volumes on several physiologic swallow measurements in 27 patients with neurogenic dysphagia (19 stroke, 8 other) who demonstrated delayed onset of oral stage or delayed pharyngeal swallow. The theory behind this test is that boluses providing a great deal of sensory information will be more easily swallowed, and that patients with dysphagia often have problems swallowing because the food they are given is very bland. The results indicated that for both stroke and other neurologic patients, the sour bolus did improve several physiologic swallow measures compared with an unflavored bolus. Bolus volume also had a significant effect, with the larger volume (3 ml versus 1 ml) causing improved swallow function. Aspiration was eliminated in three patients who demonstrated it on normal boluses. Stroke patients appeared to reap the most benefit from this treatment. However, only physiological measurements were provided as outcomes of this treatment; the only clinically meaningful outcome was an anecdotal remark that the patients did not like the sour bolus. This indicates that the use of this particular treatment may be impractical, as patients would be reluctant to continue it voluntarily. Otherwise, there was no indication of how this treatment would affect patient well-being; we can only infer indirectly that these improved swallow measures would lead to decreased morbidity and increased QOL.

Bisch, Logemann, Rademaker et al. (1994) tested the use of cold boluses in two volumes and two viscosities with 18 neurologic patients (10 stroke with mild dysphagia; 8 other patients with neurologic disorders and moderate to severe dysphagia) and 10 controls. Again, the theory of this test is that sensory stimulation will improve swallow function. On videofluoroscopy, the cold 1-ml bolus improved several swallow measures in the first-time stroke patients; increased volume and pudding viscosity resulted in shorter pharyngeal delay time. For patients with other neurologic conditions and with moderate to severe dysphagia, there were no temperature effects. Increased volume improved measures, and pudding improved measures compared with thin liquids. This study did not report any clinically relevant outcome measures, but does seem to indicate that cold bolus treatment is more useful for those with mild dysphagia than those with more severe problems. As found in Logemann et al. (above), 1-ml volume appears to be less safe than 3-ml.

One study (not tabled) reported anecdotally on eight patients who were examined using FEES to determine if their diet should be modified. Of eight patients who demonstrated significant swallow delay, it appeared that the longest delay was on the first swallow. Therefore, the researchers recommended that such patients be given a warmup swallow with ice or water to increase safety (Eibling, 1994).

Evidence from this field therefore suggests that boluses with high sensory information may help neurologic patients safely swallow, as does increased volume and thickened viscosity.

#### Do Diagnosis-Directed Postural Techniques Improve Swallow Function? (Links D1 - D8 to T1)

Evidence Table 31 shows four studies that used videofluoroscopy to assess different postural techniques. Logemann, Kahrilas, Kobara et al. (1989) found that a head turn 90 degrees to the weaker side in unilateral stroke patients caused swallow success to improve 33 to 65 percent. Rasley, Logemann, Kahrilas et al.(1993) also tested the head turn in a variety of neurogenic dysphagics with aspiration, and found that head rotation eliminated aspiration on five different volumes in 26 percent of those tested (20 out of 77).

The chin tuck is another frequently used postural technique. Ekberg (1986) tested 53 patients with dysphagia using a forward head tilt, and found that, of 18 patients who demonstrated defective laryngeal vestibular closure in the normal head position, 50 percent (nine patients) developed a normal swallow with the head tilt. Rasley et al. (1993) found that a chin tuck eliminated aspiration for 25 percent of patients (21 out of 84). Shanahan, Logemann, Rademaker et al. (1993), in a study to identify signs that would predict chin tuck success, found that those patients unsuccessful with chin tuck (50 percent in this study) were more likely to experience aspiration from the pyriform sinus, versus successful patients who experienced it from the valleculae.

Thus, in studies using VFSS to evaluate postural techniques, the only clinically meaningful measure that has been reported is the elimination of aspiration in two studies; these studies found that approximately 25 percent of patients were helped by postural techniques. From the other studies, we can again only infer that improvements in swallow measures would lead to a safer swallow and lower incidence of morbidities, but this has yet to be reported.

#### Do Other Diagnosis-Directed Treatments Improve Swallowing Function? (Links D1 - D8 to T1 - T4)

Two studies have used videofluoroscopy to assess thermal stimulation as a treatment for dysphagia (see Evidence Table 32). De Lama Lazzara et al. (1986) examined the efficacy of thermal stimulation of the anterior faucial arches in dysphagics with swallow reflex delay. Videofluoroscopy results indicated that pharyngeal transit time and total transit time were reduced immediately after treatment; however, this effect diminished within two to three swallows after the stimulation. This suggests that thermal stimulation is not a very practical treatment approach.

Rosenbek, Robbins, Willford et al. (1998) assessed TTA at four different intensities: 150, 300, 450, or 600 trials per week. Videofluoroscopy results indicated that there was no significant effect of treatment intensity on duration of stage transition, penetration, or aspiration. Results did not indicate the efficacy of this type of treatment; however, they indicate that if this treatment is at all efficacious, a lower intensity level is safe and might be used to lessen person-hours.

These two studies did not provide clinically meaningful outcome measures. However, the use of videofluoroscopy during these treatment trials did provide practical considerations for two types of treatment: the results of one indicated that the treatment provided no long-term effects and therefore may be impractical; the other allowed for lower intensity of treatment.

Other published studies have reported that the use of videofluoroscopy or fiberoptic endoscopy played a role in the determination of appropriate treatment (Aviv, Kim, Sacco et al., 1998 ; Eibling, 1994; Feinberg, Ekberg, Segall et al., 1992; Ott, Hodge, Pikna et al., 1996), but provide no indication as to what particular signs or symptoms led to the choice of treatment, or what the outcomes from treatment were. These studies therefore tell us little about the efficacy of the diagnostic.

### Conclusions Concerning Diagnostic Guidance of Treatment Management

Eight of nine studies discussed here used videofluoroscopy to assess treatment options. The most meaningful outcome, reported by three of these studies, was the occurrence of aspiration. All other measures reported were specific physiological swallow measures. These are considered a way of measuring the likelihood of having a safe swallow; however, they only imply changes in swallow safety. No studies have compared different diagnostic criteria in the determination of treatment to compare the relative predictive value of specific symptoms shown by the diagnostic tool. No diagnostic methodologies have been compared with one another as to their ability to guide treatment. In particular, no studies have assessed the ability to use specific symptomatology during a BSE to guide treatment.

## 2. What are the appropriate clinical indications or components of a preliminary BSE useful for referring patients for a full BSE or instrumented exams?

In this section, we address the question of determining the best clinical indications for referring patients for further diagnostic testing. This question is best answered by examining the signs and symptoms readily apparent during a history and physical or preliminary BSE that may predict future morbidity or mortality.

Noninstrumented diagnostic tests have been used to determine if a patient has dysphagia or if the patient has a special risk for dysphagia. But dysphagia is a poorly defined condition in which the patient's subjective experience, and hence QOL, plays a major role (see the section entitled Dysphagia Defined). While patient QOL issues are important, we could find no suitable QOL efficacy data by which to judge dysphagia diagnosis or treatment and therefore were unable to analyze this issue. Thus, in the first subsection below we consider the ability to predict pneumonia and in the second subsection the ability to predict aspiration resulting from dysphagia. However, because not all aspiration inevitably causes pneumonia, aspiration must be considered a surrogate endpoint for pneumonia and thus will be considered only as an outcome of secondary interest. In the third subsection, we consider any clinical signs or symptoms predictive of malnutrition that results from dysphagia.

### What Clinical Signs and Symptoms Predict Pneumonia? (Link D1 to M1)

Recent studies have not been able to determine the absolute test characteristics [sensitivity, specificity, positive predictive value (PPV), Negative predictive value (NPV); for definitions see Appendix E] for signs, symptoms or BSEs. This is because treatment intervenes between the test and the outcome of pneumonia (for further discussion of this issue, see the section entitled The Relationship between Diagnosis and Treatment of Swallowing Programs above). In this situation, the test characteristics indicate the ability of the test to detect or predict only the unpreventable cases of aspiration pneumonia; we have no idea how many cases would have occurred without treatment. To the extent that some cases were prevented and false positives are unknown, sensitivity, specificity, and PPV would be underestimated, while NPV would remain unaffected. Nevertheless, within the patient population of a single study, it is possible to determine the relative measures of diagnostic examination performance carried out on the same subjects, provided that treatment following each exam is chosen in exactly the same way, and caregivers are preferably blinded as to which test was used to prescribe treatment.

We are interested in detecting as many of the patients at high risk for pneumonia as possible; thus, sensitivity needs to be high, over 80 or 90 percent (fewer than 10 to 20 percent of the high-risk patients would be missed). At the same time we want to minimize the number of false positives referred for the more expensive instrumented exam; thus, specificity needs to be at least moderate, say over 70 or 80 percent (fewer than 20 percent or 30 percent of the low risk patients would be wrongly referred for the instrument exam). Because, as discussed above, intervening treatment will result in underestimates of sensitivity and underestimates of specificity, we should possibly require 90 percent sensitivity and accept 70 percent specificity.

Evidence Table 33 shows clinical signs and symptoms for prediction of pneumonia in patients with and without dysphagia that might possibly predict pneumonia. One of the better and most recent studies of signs and symptoms was carried out by Langmore, Terpenning, Schork et al. (1998) in a prospective case series that analyzed the data using a multivariate analysis. The signs and symptoms that they determined to be independently correlated with pneumonia on long-term followup of up to 4 years are presented in the table. Although there was some correlation for these, all of the signs and symptoms had sensitivities below 50 percent, and only dependent-for-feeding had a PPV over 50 percent; its PPV was 65 percent. The low sensitivities and PPVs are all the more noteworthy because, as explained above, any successful efforts to prevent pneumonia would have falsely decreased sensitivity values and PPVs.

The signs and symptoms data reported by Harkness, Bentley, and Roghmann (1990) in a matched-control study show higher sensitivity and specificity than those examined by Langmore et al. (1998), but the methods are problematic. The biases in matched-control diagnostic studies are such that they typically overestimate measures of test performance. For a given diagnostic test, PPV and NPV are not set, but PPV increases as prevalence increases and NPV decreases (Fletcher, Fletcher, and Wagner, 1988). Yet in matched-control studies, prevalence is usually set artificially high, which overestimates PPV and underestimates NPV (see Appendix E). For example, in this study, each case in the disease arm was matched with two nondiseased controls; thus, pneumonia prevalence was artificially set at 33 percent, artificially inflating PPV and NPV for any population with a lower prevalence.

Sensitivity for a given test is also not fixed, but depends on the spectrum of disease severity (Brenner and Gefeller, 1997; Fletcher, Fletcher, and Wagner, 1988; Gann, 1996; Ransohoff and Feinstein, 1978). Most tests are more sensitive for severe disease (or risk). Case-control and matched-control studies usually preselect disease cases so that the spectrum of disease severity is not typical, which overestimates sensitivity. In the Harkness et al. study, only radiographically confirmed cases with one or more signs or symptoms possibly associated with pneumonia that occurred within an 18-week period were chosen for cases. Atypical cases of pneumonia that were not radiographically confirmed or that were slow to develop and had not yet occurred in the 18-week period may have been more difficult to predict but were not included in the sensitivity count, thus possibly inflating sensitivity. Specificity is also not fixed but is dependent on the presence of comorbidities with symptoms that overlap those of the disease of interest. In case-control studies, controls are usually selected to have no confounding comorbidities, which overestimates specificity. Such was the case in this study, in which controls were selected who had no obvious signs or symptoms of respiratory infection. To the extent that signs and symptoms of respiratory infection and dysphagia overlap, some patients with these overlapping symptoms were excluded from the controls even though they may have been falsely predicted to get pneumonia by these very signs and symptoms, thus artificially inflating specificity. It is not surprising then that the test characteristics given by the Harkness, Bentley, and Roghmann (1990) data are generally higher values than Langmore, Terpenning, Schork et al. (1998) reported, given the potential biases described above, and therefore are probably unrealistically inflated.

### Conclusions

If there are any single clinical signs or symptoms that alone would be useful for referring patients for instrumented exams, they have apparently not been discovered, and more effort needs to be expended on this problem in future research. However, single signs and symptoms do not have to be used, and using combinations of them might better reflect clinical reality. If any one of several items is considered a positive test result for risk of pneumonia, then sensitivity will be increased, but at the expense of specificity. The low sensitivities and high specificities in Evidence Table 33 do indeed indicate that this would be a good strategy. The likely result of using such combinations would be to increase the sensitivity of these noninstrumented tests. Thus, the above studies and the data of Odderson, Keaton, and McKenna (1995) discussed above suggest that some clinical signs and symptoms can be combined into an algorithm that may achieve high enough sensitivity and specificity to be useful. This, in turn, suggests that future research should concentrate not on single signs and symptoms, but on combinations of them.

### What Clinical Signs and Symptoms are Indicative of Aspiration? (Link D1 to S1)

Because aspiration does not inevitably cause pneumonia, it must be considered a surrogate endpoint for pneumonia, and thus of secondary importance. Nevertheless, because of our inability to determine true test characteristics for prediction of pneumonia (as discussed in the previous subsection), we were forced to consider an intermediate portion of the overall link between test effectiveness and the outcome of pneumonia. Therefore we now consider the link between clinical signs and symptoms on a BSE (D1 through D4) and detection of aspiration (S1).

Evidence Table 34 shows oral-pharyngeal signs and symptoms for detecting aspiration from several studies that included patients with mixed etiologies, and Evidence Table 35 shows signs and symptoms from studies that included only stroke patients. The endpoint of aspiration was determined by VFSS in these studies. While VFSS is not a perfect gold standard, for the purposes of these tables we must assume that it is reasonably perfect compared with clinical symptoms, and that all VFSS studies have reasonably similar high sensitivity and specificity for aspiration. The studies included in our tables for signs and symptoms had too many items to practically present here; therefore, we only tabled and only discuss here those signs and symptoms that were indicated by the authors or the evidence they presented to be the most useful signs and symptoms (either sensitivity or specificity over 60 percent).

For detection of aspiration, we would want to have signs and symptoms that are almost as good as aspiration detected at a VFSS above 80 percent sensitivity (less than 20 percent of patients with aspiration detected by VFSS would be missed by the sign or symptom), and we would want specificity to be moderately high, above 70 percent (no more than 30 percent of patients referred for VFSS would be needlessly tested by VFSS for aspiration). In general it can be seen in Evidence Tables 34 and 35 that items with higher sensitivities have low specificities. This is expected because of the inevitable tradeoff between sensitivity and specificity as the diagnostic threshold for a positive test is changed, either intentionally or unintentionally. Because of this tradeoff, sensitivity and specificity values are best considered as sensitivity-specificity pairs, and the relationship of the pair values to the threshold chosen by the examiner, or enforced by the symptom, is best appreciated on a plot of sensitivity versus specificity. Such a plot is known as a receiver operating characteristic (ROC) plot, and the regression curve for a set of sensitivity-specificity points is the ROC curve (see Appendix E for more details of this statistical method).

We examined the available data for each of the other individual signs and symptoms of the BSE, to determine whether they could be combined meta-analytically. Combining all the points from the different subtests into a summary ROC curve would not be an appropriate way to determine the effectiveness of the BSE. Such a curve would underestimate the sensitivity and specificity of the BSE because: (1) it would not consider the effects of employing multiple tests (results of other tests could cancel out a false-positive or false-negative result of any given test, making the whole more effective than the parts), and (2) some of the less-effective subtests are unlikely to be used in an optimized BSE, and therefore should not be allowed to affect the results of the meta-analysis. Also, there are only a small number of trials for some of the individual signs and symptoms (e.g., only one trial reported "multiple swallows"). For these reasons, we chose not to perform a meta-analysis on the data for each individual subtest and simply present these data in ROC space.

A plot in ROC space of the individual signs and symptoms is shown in Figure 2. If an imaginary 45-degree diagonal line were drawn from lower left to upper right, it would represent points that are of no diagnostic value; such points would detect aspiration no better than chance. The top left corner represents a perfect test. The higher an ROC curve rises toward the top left corner, the more useful the test would be (both the sensitivity and specificity increase toward the top left).

Figure 2. Sensitivity and Specificity of Oral-Pharyngeal Symptoms for Detection of Aspiration Plotted in ROC Space

Thus, some of these signs and symptoms look more promising than others, but there needs to be more research on this topic before a conclusion can be reached. As noted above, more useful than the test characteristics for these items alone are the characteristics of various combinations of signs and symptoms, and some of these authors reported results of combinations that we present in the next two tables.

#### Silent aspiration

A number of studies have reported that VFSS detects a substantial number of patients who aspirate silently, and whose aspiration may thus be missed by some BSEs (Garon, Engle, and Ormiston, 1996; Holas, DePippo, and Reding, 1994 ; Horner, Massey, Riski et al., 1988; Kidd, Lawson, Nesbitt et al., 1993; Leder, Sasaki, and Burrell, 1998). In these studies, the proportion of aspirators who aspirated silently ranged from 20 to 73 percent. We found only one study (Holas, DePippo, and Reding, 1994 ) that reported on the pneumonia outcome for silent aspirators. For silent aspirators, 16 percent (7/44) contracted pneumonia, compared with 6 percent (1/17) for nonsilent aspirators. Thus, the relative risk of developing pneumonia within 1 year for silent aspirators was 2.7 compared with aspirators who coughed. This was not statistically significant (RR 95 percent CI was 0.36 to 20.4, which includes 1.0); however, the low power of the comparison prevents the conclusion of no difference.

Silent aspiration was generally defined as absent or weak cough upon aspiration. Such silent aspiration is indeed indicated by the sensitivity data we discussed above. Detection of aspiration by cough has a sensitivity ranging from 57 percent (Daniels, Brailey, Priestly et al., 1998) to 84 percent (Horner, Massey, and Brazer, 1990) in Evidence Tables 34 and 35. Thus, if cough upon aspiration were the only criterion for detecting aspiration, a BSE would be expected to miss from 16 to 43 percent of aspirators. However, BSE assessment of aspiration is not limited to cough alone, but other signs and symptoms are available. Thus, the well-documented existence of silent aspiration does not automatically imply that BSEs are inadequate for detecting aspiration. The overall assessment of aspiration danger by BSEs is considered in the next subsection.

#### Meta-analysis of the 3-ounce Water Test: Sensitivity and Specificity for Aspiration

Various versions of the BSE include some of the signs and symptoms discussed above along with other items. Evidence Table 36 shows the test characteristics obtained in several studies of BSEs for detecting aspiration confirmed by VFSS for patients with mixed etiologies. Evidence Table 37 shows BSE test characteristics for aspiration in stroke patients referred to VFSS with dysphagia symptoms. Evidence Table 38 is similar to Evidence Table 37, except that the former table presents results obtained from examining all stroke patients, not just those referred for VFSS. Sensitivities range from 0 to 91 percent. However, in general, specificity is high when sensitivity is low, and low when sensitivity is high. Four of the studies tabled used an abbreviated version of a full BSE, the 3-ounce (or 50-ml) water test. In Figure 3, these sensitivity-specificity points have been used to construct a summary ROC curve (Littenberg and Moses, 1993) (see Appendix E). The points of the individual signs and symptoms discussed above are also plotted. It can be seen that the 3-ounce water test summary ROC curve falls below our hypothetical curve passing through 80 percent sensitivity and 70 percent specificity. This indicates that, even if the threshold is somehow manipulated (which causes one to move along the curve as opposed to shifting the curve), this test is unlikely to achieve the necessary sensitivity without sacrificing too much specificity, and vice versa. Also, it can be seen that the 3-ounce water test curve is similar to the average ROC curve we would expect for the whole group of signs and symptoms (11 points are above and 12 points are below the 3-ounce water test curve). This indicates that the 3-ounce water test may not contain the best individual signs and symptoms available.

Figure 3. Sensitivity and Specificity of the 3-oz Water Test for Detection of Aspiration Plotted in ROC Space

#### Meta-analysis of the Characteristics of the BSE: Sensitivity and Specificity for Aspiration

In Figure 4, we plotted the summary ROC curve for the five studies that reported both sensitivity and specificity for a complete, formal BSE. These comprehensive BSEs produce a curve that is above both the 3-ounce water test curve and the average curve for all the individual signs and symptoms. Interestingly, the BSE curve falls very close to our hypothetical 80 percent sensitivity and 70 percent specificity curve. This reasonably high sensitivity of the BSE is one explanation for why the BSE dysphagia program reported by Odderson, Keaton, and McKenna (1995) (discussed under Question 1 above) had such a substantial apparent effect in reducing aspiration pneumonia spite of the likely existence of substantial silent aspiration (as defined by absence of cough). Full BSEs score several items that may increase their sensitivity for aspiration, and so are not limited to the single symptom of failure to cough.

Figure 4. Sensitivity and Specificity of BSEs for Detection of Aspiration Plotted in ROC Space

The data in the above-mentioned tables and figures indicate that only a BSE using more and/or better signs and symptoms than the 3-ounce water test would be appropriate for detection of aspiration and/or referral of patients to an instrumented exam. In fact, these data, along with the effectiveness of the BSE program reported by Odderson, Keaton, and McKenna (1995), call into question the need for instrumented exams to detect aspiration. The 80 percent sensitivity of the BSE for aspiration using VFSS as a gold standard indicates that VFSS would only detect an additional approximately 20 percent of patients who aspirate. Instrumented exams, particularly those providing imaging, seem likely to be more useful than a BSE for guiding treatment and therapy, because of the additional physiological and functional information they provide. However, the effect of this additional information on patient outcomes such as pneumonia, malnutrition, dehydration, and QOL has been poorly demonstrated. Also, as discussed above under Question 1, the approximately equal effectiveness of the Odderson BSE program (Odderson, Keaton, and McKenna, 1995) and the Daniels VFSS program (Daniels, Brailey, Priestly et al., 1998) in preventing pneumonia indicates that the added benefit of VFSS over BSE is likely to be small, and, in fact, too small to be detected by anything other than a study much larger than either of these.

The potentially small benefit that accrues to patients as a result of using VFSS, and its somewhat greater cost than the BSE, mean that a comparison of the BSE with VFSS is primarily a cost-effectiveness issue. We address cost-effectiveness in our supplemental analysis.

### Conclusions

Single symptoms detectable on clinical exam do not appear to reliably predict aspiration. It seems likely that there should be some combination of clinical oral-pharyngeal signs and symptoms that can predict aspiration with adequate sensitivity and at least moderate specificity. The approximately 80 percent sensitivity and 70 percent specificity for aspiration of full BSEs including several signs and symptoms bears this out, and could possibly be improved upon. Further research on this topic is of great interest, but it is important that researchers understand the tradeoff involved in the sensitivity-specificity relationship. They may be able to reach a consensus on some combination of these values that achieves both adequate sensitivity and specificity for prediction of aspiration or aspiration pneumonia. The reasonably high sensitivity and specificity of BSEs raises the issue of whether a BSE could entirely replace instrumented exams. The possibly small improvement of instrumented exams over BSEs and the increased cost of instrumented exams present a cost-effectiveness question that is discussed in our supplemental analysis. This question also raises the issue of the effect of diagnostic exam findings on subsequent treatment.

### What Clinical Signs and Symptoms Predict Malnutrition? (Link D1 to M2)

Malnutrition is a significant predictor of mortality in the elderly (Elmstahl, Persson, Andren et al., 1997; Keller, 1995; Murden and Ainslie, 1994; Ryan, Bryant, Eleazer et al., 1995; Wallace, Schwartz, LaCroix et al., 1995). It can also lead to other morbidities through a weakening of the immune system (Chandra, 1990). It is therefore important to enact measures to prevent malnutrition if it is determined to be prevalent in a population of patients with dysphagia. To do this, it would be helpful to identify any signs or symptoms that predict eventual malnutrition in these patients.

The relationship between malnutrition and diagnosis of dysphagia is difficult to determine from available evidence. This is partly because the administration of parenteral or enteral nutrition is often introduced if there is even a threat of malnutrition, so the number of patients whose dysphagia might lead to malnutrition may be at least partially obscured. In addition, diagnosis of dehydration and malnutrition does not require extensive diagnostic methods for detection. For these reasons, in acute care, malnutrition may be largely dealt with outside of the context of formal diagnosis and treatment of dysphagia. This could explain why few studies have attempted to determine the extent to which (or even whether) dysphagia causes malnutrition. There is, however, the possibility that for some patients diagnosis of dysphagia may lead to therapy that prevents malnutrition and therefore obviates the need for feeding tubes.

There is limited evidence about the prevalence of malnutrition in patients with dysphagia, and whether patients with dysphagia are at increased risk for malnutrition compared with individuals with normal swallows. Current evidence on this is equivocal, as two studies have reported a significant association (Davalos, Ricart, Gonzalez-Huix et al., 1996; Keller, 1995) and another found no association (Thomas, Verdery, Gardner et al., 1991). Only one of these studies was specifically about acute-care stroke patients, and it found that 1 week after stroke, patients with dysphagia were significantly more likely to be malnourished than those with a normal swallow (Davalos, Ricart, Gonzalez-Huix et al., 1996).

However, no published studies examine signs or symptoms that may predict malnutrition in patients with dysphagia. Given that an association between dysphagia and malnutrition has not been definitively made, there may be no reason for such studies to be conducted. Therefore researchers must definitively document a link (if one does exist) between dysphagia and malnutrition in specific patient populations to determine the burden of illness in this population; then clinicians can work on ways to detect potential malnutrition risk factors before malnutrition occurs.

### What Clinical Signs and Symptoms Predict Dehydration? (Link D1 to M2)

Dehydration may be a particularly important outcome in regard to neurologically disabled patients with dysphagia because they most often suffer from an inability to swallow thin liquids safely; less common is the inability to swallow thick liquids and solids. However, this is a logical inference, rather than one based on clinical studies. While clinicians recognize the importance of measuring dehydration (Langmore, 1998 ; Logemann, 1998b; Yorkston, 1998), few studies have yet been conducted on this outcome. Currently, no studies examine the predictive value of clinical signs and symptoms for development or presence of dehydration.

## 3. Is there any evidence that one diagnostic technology is preferable/is more effective/gives more information than any other diagnostic technology?

In addressing this question, we address whether any of the diagnostic exams is better than another. Better in this section refers to the ability of a diagnostic test to accurately detect or predict the presence or absence of important outcomes. In this section, we pay particular attention to videofluoroscopy because the MBS has been the reference standard for diagnosis of dysphagia, detection of aspiration, and prediction of patients at high risk for pneumonia (Logemann, 1983b). Thus, we begin this section by examining the evidence on the reliability of VFSS results. In the subsequent subsections, we then compare videofluoroscopy with certain of the instrumented tests that have been introduced in recent years. In making these comparisons, we included only articles that directly compared videofluoroscopy and another instrumented diagnostic exam.

The outcomes discussed here are pneumonia and aspiration (as a surrogate measure of pneumonia). Other outcomes are of clinical significance and interest; however, pneumonia is the only outcome on which researchers in this field have focused. Therefore, mortality, malnutrition, dehydration, and QOL will not be discussed here.

### How Reliably do Videofluoroscopic Studies Detect Aspiration? (Link D5 to S1)

#### Interobserver Variability of VFSS

While workers in the field have accepted the VFSS as the reference standard, there is no evidence showing that this is as a perfect gold standard, so this test likely yields some false-positive and false-negative results. It may also be the case that aspiration detected by one clinician will not be detected by another. In this case, it would be difficult to determine which clinician is correct. Evidence Table 39 shows the three studies we found that examined interobserver variability for detection of aspiration on several different bolus viscosities. The study by Ekberg, Nylander, Fork et al. (1988) reported a kappa value of 0.83 for independent observations of 6 radiologists on 72 patients. This is a moderately high kappa value.

The study by Perlman, Booth, and Grayhack (1994) reported 100 percent agreement between independent observations of 2 speech pathologists on 33 patients. The study was conducted by having the 2 SLPs retroactively review videotapes of 33 patients in slow motion, frame-by-frame. There were at least six swallows for each patient, presumably of different consistencies. While some SLPs may sometimes review tapes over and over, frame-by-frame, the more typical situation is that the SLP views the exam in real time and makes decisions and starts therapy measures on the spot. Although there may also be some post-exam review of the tapes before writing a report, it seems unlikely that most SLPs routinely carry out extensive post-exam frame-by-frame or slow motion review. Therefore, this study may not be generalizable.

The study by Kuhlemeier, Yates, and Palmer (1998) reported interobserver variability for each consistency of the bolus separately. They conducted an all-way pairwise comparison among nine raters (four physicians and five SLPs). Furthermore, they reported both positive and negative agreement. The negative agreement was very good, being above 98 percent for all consistencies. However, the positive agreement showed considerable interobserver variability. Juice had the most positive agreement with 85 percent. Beef stew had the lowest with 0 percent. The three other consistencies, cookie, spread, and nectar, all had positive agreement below 20 percent.

### Conclusions

These studies together indicate that there is fairly good interobserver agreement on aspiration of thin liquids, but that thicker liquids and solids present a problem of interobserver agreement. Unfortunately, the inter- and intraobserver variability of a diagnostic technology are used as the reference standard for judging all newer technologies, yet they have not been thoroughly studied. Potentially, the absence of interobserver agreement on aspiration of solids and thicker consistencies could present a risk to some patients, because in the standard procedure (Logemann, 1983b), these consistencies are tried first as indications of whether it is safe to proceed on to thin liquids. We were unable to find any evidence that addressed this issue, and there is likely to be little risk for stroke patients, who usually have more difficulties when swallowing thin liquids.

### Which is a Better Predictor of Pneumonia: BSE or Videofluoroscopy? (Links D4 and D5 to M1)

There is a general assumption in the field of dysphagia research that VFSS (or any instrumented exam for that matter) is better than any noninstrumented exam. This hypothesis needs to be tested in clinical trials. The sensitivity and specificity of the BSE for detection of aspiration using VFSS as a gold standard was discussed above in Question 2. However, the use of VFSS as a gold standard requires the assumption that VFSS is 100 percent accurate, which may not be the case. Thus, in order to compare the BSE with VFSS, a clinical outcome must be used as the gold standard. However, this is problematic because measuring effectiveness only in terms of the ability of the test to predict pneumonia is unreliable, because treatment intervenes and will bias the results. Examples of this will be presented below.

#### Within-study Comparisons of VFSS and BSEs

We located two trials that compared the abilities of VFSS and the BSE to predict clinical outcomes, in terms of test performance (Reynolds, Gilbert, Good et al., 1998; Smithard, O'Neill, Parks et al., 1996). They are described in Evidence Table 40. Some test characteristics, however, are not generalizable but apply only to patient populations with the same prevalence as the study population, thus limiting the generalizability of these results (see Appendix E). Also, as mentioned above, treatment biases the measurement of test performance by decreasing sensitivity, specificity, and PPV. Assuming treatment is given only to those who test positive, treatment will have no effect on NPV (this is further explained in Appendix G).

Smithard, O'Neill, Parks et al. (1996) followed 117 consecutive stroke patients who presented at an acute-care hospital within 24 hours of the stroke event. All patients received a BSE and 94 also received a VFSS; clinicians performing one test were blinded to the results of the other. If the BSE indicated that swallowing was unsafe, parenteral feeding was initiated; diet modification was subsequently instituted based on findings from both diagnostic tests. The abilities of BSE and VFSS to predict chest infection and death were compared in terms of measures of test performance.

Although Smithard and colleagues report that the BSE was superior to VFSS in its sensitivity, inferior in specificity, and similar in PPV (see Evidence Table 40 for details), these findings do not take into account the apparent spectrum bias in this study. Spectrum bias is introduced when the patients selected for one diagnostic or treatment differ from the patients selected for the other, and the difference is likely to affect the results. In this instance, this bias manifests itself because patients who received only the BSE were apparently sicker than those who received both the BSE and VFSS. Specifically, patients who did not receive the VFSS were those with reduced consciousness or medical unfitness for the test. The BSE, however, was administered to all patients, including these sicker individuals. The fact that some of the patients who received the BSE alone were sicker than those who received the VFSS is supported by the death statistics provided by the report. Twenty-one patients died over the course of the study; all of whom contributed data to the BSE results. Only 10 of these patients contributed data to the VFSS results. If 8 of the 11 patients not given VFSS would have aspirated during the exam (which is entirely reasonable because of their relatively ill health), the diagnostic effectiveness of the BSE and VFSS would not have been significantly different, as tested by the chi-square statistic.

Smithard and colleagues base their conclusion that VFSS did not appear to add greatly to this risk profile partly on the absence of a statistically significant correlation between the results of the VFSS examination and clinical outcomes of chest infection and mortality. In other words, patients that the VFSS predicted would have these outcomes did not significantly develop them. As a result, observed VFSS sensitivity was much lower than observed BSE sensitivity. As suggested in the previous paragraph, this finding may be the result of spectrum bias, and VFSS may actually be equal to or more effective than BSE. If Smithard et al. had published the data only for the subset of BSE patients who also had VFSS, this would have permitted a less biased comparison of the two diagnostic tests, even though their absolute sensitivity and specificity would still be affected by treatment intervention. Given the data that were reported, it is not possible to draw conclusions from this study about which test is more effective for identifying patients at elevated risk for pneumonia.

NPVs from the trial of Smithard et al. are not affected by treatment bias, and since the patients who died before they could undergo VFSS are not likely to have had negative results, the selection bias is unlikely to have affected NPV. For both outcomes (chest infection and death), the NPVs of both tests are high (84 percent NPV for chest infection, 91 to 94 percent NPV for death). This suggests that both the BSE and the VF examination would be reasonable tests for determining which patients need no further dysphagia followup.

The other direct comparison of VFSS and BSE was by Reynolds, Gilbert, Good et al. (1998). This was a retrospective case series, including 102 acute stroke patients who were given a BSE and then referred to videofluoroscopy if oropharyngeal dysfunction was suspected; those patients exhibiting no dysfunction on BSE were not followed; this patient selection bias has the result of inflating the sensitivity and lowering the NPV reported on this test. Silent aspirators (those who did not cough while aspirating on VFSS) were excluded from the study; this may reduce any advantage VFSS might have over BSE as a result of improved detection of these silent cases. Subsequent treatment included diet modification and treatment recommendations (Reynolds, Gilbert, Good et al., 1998).

Reynolds et al. properly limited their internal comparisons to the subset of patients who had both the barium swallow and the standardized BSE. However, treatment intervened between the diagnostic procedure and the outcome measurement (pneumonia) for those who tested positive by barium swallow. As we have shown in Appendix G, this causes a decrease in sensitivity, specificity, and PPV. Only NPV remains unchanged. The treatment bias will affect barium swallow results more than they affect BSE results since only half (6 out of 12) of the patients with positive BSE results also had a positive barium swallow. Data reported are insufficient to allow the magnitude of the bias to be determined.

In this trial, the treatment bias favoring the BSE (fewer patients treated) is offset (to an unknown degree) by spectrum bias against the BSE. Assuming the protocol described in the report was followed when the patients were diagnosed and treated, patients who had no dysfunction during the BSE and no complaints of cough or throat-clearing were not given a barium swallow. Also, patients exhibiting significant problems and overt signs of severe aspiration throughout the BSE were not given a barium swallow. The effect of these exclusions is to create a spectrum bias, because the cases that would be easiest to diagnose by BSE were excluded. This would cause decreases in both sensitivity and specificity. To the extent that BSE and barium swallow results are correlated, the spectrum bias would also extend to the barium swallow results. While we cannot determine the magnitude of the effect, we can be sure that the net effect of the spectrum bias is to favor barium swallow.

Omission of obvious positives should not affect the NPV results significantly. Results from the Reynolds et al. trial were similar to those in the Smithard et al. trial, although the VF examination had somewhat better results than the BSE. NPVs were 87 percent for VFSS and 80 percent for BSE. As expected, the NPV increased to 91 percent if both tests were negative.

#### Case Series Comparisons of VFSS and BSEs

Because of the scarcity of trials comparing BSE with VFSS within the same patient population, we turned to the case series literature. Obvious differences in study design and patient characteristics among these studies make comparisons among them of questionable reliability. For example, treatments may have differed in significant ways, although none of these studies provided in-depth description of the therapies. Study design issues, such as retrospective versus prospective case identification, may have resulted in different findings so that retrospective case review could not identify all diagnoses or occurrence of illness, therefore skewing results. We seek, however, only to roughly approximate a comparison of test characteristics for these two tests. Given the purported advantages of VFSS in detecting cases of silent aspiration missed by BSE that may ultimately lead to pneumonia, even with study differences, VFSS should appear to have increased sensitivity.

Several case series studies have been published that examined either the ability of BSE to diagnose an unsafe swallow (Evidence Table 41) or MBS detection of aspiration to predict pneumonia (Evidence Table 42). We have assumed for this discussion that care setting does not affect test characteristics in any significant way (though the differences in prevalence of disease in different care settings will obviously have some effect); therefore, acute-care and rehabilitation centers are analyzed together. We have limited the pool of studies to those reporting on 90 percent or more stroke patients. Because of a paucity of data, the formal BSE and water swallow test have been collapsed into a single category of noninstrumented exam. We are, therefore, disregarding many factors that may potentially confound results.

Evidence Table 41 includes trials that related pneumonia rates to results of the BSE or 3-ounce/50-ml water test. Key points regarding these trials and their suitability for between-studies comparison are presented below.

Gordon, Hewer, and Wade (1987), examining the 50-ml water test, excluded those patients known to have choked on fluids the day of the test. Since these patients likely would have choked during the 50-ml water test, this selection bias is likely to have excluded cases that would have been true positives, thus underestimating sensitivity and PPV of the test.

DePippo had very sensitive criteria for interpreting the Burke Dysphagia Screening Test (BDST). Failure on any of the seven elements was interpreted as failure of the test. Thus, sensitivity was high (92 percent) and specificity was low (45 percent). Patients who failed the BDST were referred for barium swallow. Patients failing the barium swallow were enrolled in a dysphagia program including diet modification and compensatory swallowing techniques. As a result, treatment probably intervened for most patients who had dysphagia.

Gottlieb, Kipnis, Sister et al. (1996) called their trial a validation of the 50-ml water test, but because it does not compare the 50-ml water test with a reference test for diagnosis of dysphagia, it is not truly a validation. It is, however, a trial measuring the ability of the 50-ml water test to predict pneumonia. More than that, this is a trial measuring the effect of a comprehensive swallowing program on pneumonia rates. Three consecutive groups of 60 patients were enrolled in the swallow program, using the 50-ml water test as the criterion for selecting patients for swallow therapy. Patients who failed the 50-ml water test were given a modified diet, along with three sessions per week of swallow therapy by a speech therapist. Pneumonia rates in patients with and without the modified diet were compared. The change in results is graphic evidence of the effect of treatment bias (Table 15).

Table 15. One Study's Results Illustrative of the Effects of Treatment Bias (Gottlieb, Kipnis, Sister et al., 1996)

| | 50-ml water test results in first group
| | Pneumonia outcome
| | Positive | Negative
| | 50-ml water test results in the third group
| | Pneumonia outcome
50-ml water test result | Positive | 6 TP | 7 FP | 46 percent PPV
50-ml water test result | Negative | 3 FN | 44 TN | 94 percent NPV
Pneumonia rate: 15 percent | | 67 percent sensitivity | 86 percent specificity
| | Positive | Negative
50-ml water test result | Positive | 0 TP | 13 FP | 0 percent PPV
50-ml water test result | Negative | 2 FN | 45 TN | 96 percent NPV
Pneumonia rate: 3 percent | | 0 percent sensitivity | 76 percent specificity

As the dysphagia program became established, true-positive results decreased while false-positive results increased. Sensitivity, specificity, and PPV all appeared to decrease as treatment became more successful at preventing pneumonia. (See Appendix G for further discussion of the effects of treatment bias.)

All of these trials found that the BSE had high NPV. Reported PPVs were very low; this could be the result of treatment bias as well as selection of a sensitive test threshold to minimize false-negative results. Smithard's trial found NPV to be 84 percent; all the others had NPV results over 90 percent. This demonstrates that BSE results can be used to identify patients who are unlikely to need swallow therapy.

Although Evidence Table 42 shows DePippo, Holas, and Reding (1994) twice, only the results for the BSE were graphed to avoid double counting of patients. Smithard et al. (1996) is included in both tables but not included in our graph, due to only a 1-week followup period that may affect its results relative to the results from other studies with longer followup times (it has, however, already been discussed above). Holas et al. (1994) is tabled but excluded from analysis because results were only reported for those patients who tested positive on VFSS, thus resulting in patient selection bias.

Johnson's group tested the ability of VF examination to predict pneumonia. Kinematic pharyngeal transit time (Em) was the primary measure of swallow function; pneumonia rates were stratified by group, with threshold Em times ranging from 2 to 5 seconds. This allows consideration of a range of thresholds and illustration of the tradeoff between sensitivity and specificity. At the lowest threshold (2 seconds), sensitivity was 100 percent and specificity was 42 percent; at 3 seconds, sensitivity was 86 percent and specificity was 68 percent; at 4 seconds, sensitivity was 76 percent and specificity was 81 percent; and at 5 seconds, sensitivity was 66 percent and specificity was 94 percent. Treatment was not reported, so it cannot be determined if treatment bias affected the results. The trial does not appear to have spectrum bias, because it was a retrospective review of consecutive cases referred for videofluoroscopy. The only exclusion criteria were dysphagia caused by disease other than stroke (two cases) and patient noncompliance causing an examination of poor quality (two cases, 3.2 percent). The latter exclusion causes a small bias against VFSS, but is appropriately conservative in design.

The Holas, DePippo, and Reding (1994) report on the correlation between MBS results and pneumonia showed that all patients selected for this trial had videofluoroscopy results that were positive for dysphagia. Patients also were given unspecified dysphagia treatment, so treatment bias probably affected the results.

Aviv, Sacco, Mohr et al. (1997) reported MBS results in 20 patients with known dysphagia. Although all patients got some treatment, treatment differed by group. The 10 patients whose barium swallow demonstrated aspiration were given a percutaneous endoscopic gastrostomy (PEG) tube, and the 10 that did not have aspiration were given swallow therapy and no PEG tube. Pneumonia risk was twice as great for those patients who had negative barium swallow results than for those who had positive results, a counterintuitive result. The reported barium swallow sensitivity of 33 percent and specificity of 43 percent are worse than would be obtained by random chance. This suggests that treatment bias affected the results.

Aviv et al. also tested laryngopharyngeal sensory discrimination testing (LPSDT) in a matched-control trial. Twenty patients with complaints of dysphagia and who were not taking food by mouth were paired with healthy age-matched controls. The controls had no dysphagia and no history of stroke. None of the controls contracted pneumonia or had abnormal LPSDT results. Six of the dysphagia patients (30 percent) contracted pneumonia, all of whom exhibited a bilateral sensory deficit on the LPSDT. Treatment bias affects these results too, though; since there were no false negatives, sensitivity remained at 100 percent. Specificity of the LPSDT was 57 percent while PPV was 43 percent.

Daniels et al. (1998) and Aviv et al. (1997) are interesting studies to discuss because of outlier VFSS test characteristic findings. Aviv reports a very low sensitivity of 33 percent from a very small pool of patients (20). Because all patients who tested positive for aspiration were put on a feeding tube (as opposed to noninvasive therapies reported in most other studies), we excluded these results from further analysis in an attempt to control for treatment effects. On the other hand, Daniels et al. (1998) reported a sensitivity rate of 100 percent; this was because only one case of pneumonia occurred in their patient population of 55; these results are thus rendered unreliable because of the low number of patients who developed pneumonia, resulting in low statistical power.

NPV is the parameter least affected by the known biases. For the barium swallow trials listed in Evidence Table 42, there was a wide range of NPV values, from 55 to 100 percent. The wide range of values could be explained by the possibility that some investigators used more sensitive thresholds than others. Summary ROC meta-analysis would be able to test this hypothesis, but meta-analysis of this evidence base is not appropriate because of treatment bias and selection bias previously described.

Because so many of the trials are confounded by treatment bias and/or spectrum bias, we could not use their results in a between-studies comparison or draw conclusions on the relative effectiveness of the 3-ounce water test, the barium swallow, and other tests based on these results. Trials measuring the effect of these diagnostic procedures on outcomes such as pneumonia rate are necessary to determine the value of these diagnostic tests.

### Which is the Better Predictor of Pneumonia: Videofluoroscopy or Fiberoptic Endoscopy? (Links D5 through D7 to M1)

We located two studies that addressed this question, a pseudo-randomized controlled trial and a nonrandomized controlled trial. We address these two studies in separate subsections below.

#### A Pseudo-randomized controlled trial comparing VFSS and FEESST for prevention of pneumonia in patients with mixed etiology of dysphagia

Evidence Table 43 shows the results of a trial using 1-year pneumonia incidence as the primary outcome for comparing the efficacy of VFSS and fiberoptic endoscopic examination of swallowing and sensory test (FEESST) (Aviv et al., 1997 ). We have called this a pseudo-randomized controlled trial because of the possible nonrandom manner in which the patients were directed to each diagnostic test. Patients referred to an otolaryngology department for outpatient diagnosis received FEESST if they were examined on Monday or Thursday, and VFSS if examined on Tuesday, Wednesday, or Friday. This apparently resulted in more patients being directed to VFSS (75 versus 51), which, by itself, is not a major concern. More problematic, however, is that the patient characteristics in terms of dysphagia etiology were unequally distributed between the comparison groups. Although patients and referring physicians were blinded as to which test would be used on each day of the week, it is a formal possibility that unknown factors could have influenced the selection of patients on particular days of the week. For example, Social Security or welfare checks might arrive on a particular day, or alcoholics might be less likely to show up on Mondays. It is recognized that it would be impractical for examiners to switch methods for randomized individual patients; however, the days of the week for each type of exam could be randomized. The same team of SLPs conducted both diagnostic tests, blinded to the comparison test results, and treated patients according to the same algorithm. Thus, while diagnosis and treatment were supposedly consistent, the treatment was not prescribed blinded to the test used. This would be considered a design omission in many studies, but in the present case, this limitation seems unavoidable, because for many patients treatment begins during the course of the diagnostic exam.

After 1 year of followup, 18 percent (14/75) of the VFSS patients developed pneumonia, compared with 9.8 percent (6/51) of FEESST patients. The difference between these two groups was not statistically significant (p = 0.176). Whereas these results fail to prove that the apparent trend of FEESST superiority is reliable, possibly because of low statistical power, the results also failed to prove that VFSS was superior (again with low power). The study is still ongoing, thus the issue of low power may ultimately be resolved.

The authors of this study suggest that the sensory testing provided by FEESST can identify patients who may aspirate intermittently but who do not necessarily aspirate during the test. They also suggest that the longer time over which FEES/FEESST can be used during a single session may detect aspiration that occurs with fatigue that is not observable on the shorter VFSS exam. However, there was no evidence presented that the sensory testing part of the exam per se was a predictive factor for aspiration pneumonia.

#### Studies of other designs comparing VFSS and FEESST for prediction of pneumonia

Because the ability of VFSS and fiberoptic endoscopic (FE) exam to assist in pneumonia prevention have been compared by only the single trial discussed in the preceding subsection (the results of which were inconclusive), we examined the other reported controlled trials. Evidence Table 44 presents the only other study we found that made this comparison (Aviv, Sacco, Mohr et al., 1997). This was a prospective trial controlled by giving VFSS and FEESST to the same patients, and blinding the readers of the results of one test to the results of the other test. This, plus the fact that this trial used the gold standard of long-term followup for pneumonia, can make the design of this trial quite strong but only if patients who test positive with either test receive the same treatment, which was not the case for this trial because the results of FEESST were not used in choosing treatment. Thus, any patient who aspirated on VFSS was given a PEG tube. After 2 years of followup, the number of cases of pneumonia were counted and compared with the test results. VFSS had a sensitivity of 33 percent (2/6) and a specificity of 43 percent (6/14); FEESST had a sensitivity of 83 percent (5/6) and a specificity of 50 percent (7/14). A combination requiring both tests to be positive had a sensitivity of 83 percent (5/6) and a specificity of 36 percent (5/14). The fact that some patients were treated, which likely prevented some cases of pneumonia, means that sensitivity and PPV may be underestimated for both tests. Furthermore, because only patients with a VFSS positive test were treated, the VFSS sensitivity and PPV were likely underestimated to a greater degree. This problem makes it impossible to use this trial to compare diagnostic methods.

### Which Better Detects Aspiration, VFSS or FEES? (Links D5 through D7 to S1)

Because of the inconclusive nature of the above studies, we looked beyond the preferred outcome of long-term followup for pneumonia and considered studies that compared VFSS and fiberoptic endoscopy for detecting aspiration. Although aspiration is only loosely correlated to pneumonia (not all patients who aspirate get pneumonia, and not all patients who get pneumonia aspirate) and thus cannot be considered a reliable surrogate measure for pneumonia, the limited correlation that appears to exist makes aspiration an interesting symptom for test comparisons. As with the preceding question, we included only controlled trials. We found four such studies, which are shown in Evidence Table 45. All of these studies compared the ability of VFSS and FEES to detect aspiration.

Although some studies used one diagnostic as a gold standard against which to compare the other diagnostic, this is not appropriate, because FEES may detect some cases of aspiration that VFSS does not, and VFSS may provide some false positives that FEES correctly identifies as negative, and vice versa. The Leder et al. (Leder, Sasaki, and Burrell, 1998) study only reported diagnostic accuracy, which is the combination of positive and negative agreement. Unfortunately, diagnostic accuracy does not tell one whether the disagreements were in the positive or negative direction, which is particularly important when the consequences of a false positive are different from those of a false negative. In the present case, the consequences of a false negative are pneumonia and, perhaps, death. On the other hand, the most serious possible consequences of a false positive are the complications caused by feeding tubes.

The remaining three studies all reported finding some apparent cases of aspiration detected by VFSS but not FEES, but they also reported that some cases detected by FEES were not detected by VFSS. Kaye, Zorowitz, and Baredes (1997) reported substantially more cases of aspiration detected by VFSS than by FEES. This was the largest study, but there was no indication that the readers of one test were blinded to the results of the other test. Also, the bolus volumes, consistencies, and number of boluses were not equivalent between the two exams, and it is difficult to detect aspiration of water by FE (milk or colored liquids are typically used). In the Wu, Hsiao, Chen et al. (1997) study, the readers were blinded, and more positives were reported for FEES than for VFSS. The remaining study by Langmore, Schatz, and Olson (1991) reported the same number of positives for each test that were missed by the other test; however, this was only 1 (out of 21 tests) in each case.

The important finding is that in all of these studies, each test detected some apparent positives that the other test did not. This means that neither test can be the reference standard for the other. The amount of disagreement over these positives is not reliable, because there was no outcomes-based gold standard for aspiration. Investigators on future studies should recognize these limitations of study design and they should also recognize that aspiration is a surrogate marker for the more useful endpoint of long-term pneumonia frequency.

### Conclusions Concerning the Comparability of Videofluoroscopy and Fiberoptic Endoscopy for Prevention of Pneumonia and Detection of Aspiration

A single pseudo-randomized controlled trial with low statistical power and moderately strong internal validity reported a trend that incidence of aspiration pneumonia in dysphagia patients with mixed etiologies was lower after FEESST than VFSS but failed to show that either test was statistically significantly superior. This study did not address whether either of these tests is superior to the BSE, and the reader is referred to Question 2 for a discussion of this latter issue.

We found no reliably interpretable evidence comparing the abilities of VFSS and FE to detect aspiration. This difficulty was primarily due to the fact that the trials that examined aspiration failed to incorporate an appropriate gold standard external to VFSS and FE. However, even were such an aspiration gold standard possible, it is important to remember that aspiration is a surrogate endpoint for the long-term followup of pneumonia frequency. Thus, at the present, aspiration pneumonia frequency is both the most desirable and the only available gold standard for any instrumented exam. However, intervening treatment biases diagnostic test detection and prediction results. Thus, without withholding treatment, the absolute test detection and prediction results cannot be known. If treatment is not identical after each test, the relative detection and prediction abilities also cannot be known.

### Summary

Measuring the performance of diagnostic tests for dysphagia is difficult because of the lack of a gold standard. While VFSS is the most widely used diagnostic imaging method, and therefore considered the gold standard, it does not demonstrate perfect sensitivity and specificity. As a result, it becomes difficult to interpret the results of studies that compare VFSS with other newer diagnostics, such as FEES and FEESST. This is because when one test yields a positive diagnosis and the other test yields a negative one, it is impossible to determine which test is correct. Similarly, if the two tests agree, they may both be wrong or they may both be right. The only way to assess test performance is to use clinical followup. In the studies we examined, however, followup was confounded by treatment intervention.

Because of these limitations, research thus far has been unable to demonstrate any significant advantage of one test over another. Comparisons have been made of the abilities of VFSS and FEESST for prevention or prediction of aspiration pneumonia and of the abilities of VFSS and FEES to detect aspiration. There was a statistically nonsignificant trend in one pseudo-randomized trial comparing VFSS and FEESST suggesting that incorporation of FEESST into a dysphagia diagnosis and treatment program results in lower aspiration pneumonia rates than in programs that employ VFSS. Further data are needed to determine whether this trend is reliable. Another within-subjects trial comparing the predictive value of these tests for aspiration pneumonia was flawed in that treatment decisions were made on the basis only of VFSS, and not on the basis of the FEESST results, thus leaving the results of each program noncomparable.

A comparison of VFSS and FEES for detection of aspiration in four studies showed that VFSS detects some aspiration that FEES does not, and that FEES detects some aspiration that VFSS does not. The ultimate gold standard, clinical outcome, was not used in any of these trials. Because of the above-mentioned limitations in studies of dysphagia diagnostic technologies, and because of the lack of a reliable gold standard, these trials provide no reliable information about relative efficacy of these two diagnostic tests.

A few studies have evaluated the interobserver reliability of videofluoroscopy. Two studies reported very high reliability overall when testing several different viscosities. These studies used retrospective viewing of tapes or film. As such, these results may not be generalizable to the more common procedure of viewing the test and making clinical decisions in real time. One study that analyzed each viscosity independently reported a high reliability only for thin liquids, and very low or nonexistent reliability for thick liquids and solids. While this low reliability is problematic because solids and thick liquids are the first substances tested on VFSS, the high reliability of thin liquids is reassuring because this is the viscosity most often problematic for patients with neurogenic dysphagia.

No studies have compared the test characteristics of FEES and FEESST. Such a comparison is warranted to determine if the quantitated sensory testing included as part of FEESST actually provides any clinically relevant information. Further within-subjects studies comparing VFSS and FE should make treatment determinations for patients tested positive by either test so that results, although confounded by the treatment, will be comparable between the two tests. Alternatively, a randomized controlled trial should be carried out in which the patients in each arm are diagnosed by only one method, and are treated solely based on that method. This would demonstrate the relative effect of each test on actual patient outcomes; however, the detection and prediction abilities of the tests in the absence of treatment would not be known.

In the absence of such a trial, and because current literature does not appropriately address the issue of differences between diagnostic tests, we further explored the answer to this third question in our supplemental analysis. This latter analysis, in turn, relies upon the data we discussed in our answer to Question 1.

## 4. When is noninvasive swallow therapy or diet modification appropriate? Do these therapies work particularly well in any particular patient population? What can the evidence tell us about these therapies? Is PEG useful as a primary therapy or is it a last resort?

In addressing this last question, we turn our attention to treatment of dysphagia. The primary question asks: Do these treatments prevent morbidity and/or mortality after dysphagic stroke, and if so, which treatments work the best? As we have noted in our discussions of the previous three questions, treatment is difficult to address in the absence of a discussion of diagnosis, so the discussion surrounding the present question cannot be viewed apart from our previous discussions. In the present section, however, we broaden our discussion to include specific outcomes (e.g., malnutrition) that we have not previously discussed in detail. We also expand our discussion to include feeding tubes and the benefits and risks associated with these tubes.

As with our previous discussions, we focus on stroke victims, which again is a reflection of the emphasis in the literature. Because of this, one must be cautious about extrapolating our results to patients with other neurologic conditions; dysphagia in stroke victims typically does not progress (in fact, it often spontaneously resolves) but in patients with neurodegenerative disorders (e.g., Parkinson's and Alzheimer's disease), the opposite is true.

Because stroke victims often spontaneously regain their ability to swallow (Barer, 1989; Smithard, O'Neill, England et al., 1997), the effects of treatment are difficult to separate from those of the recuperation that occurs after a stroke. Because of this, it is especially important that researchers who evaluate dysphagia treatments in stroke patients include control groups in their studies. Although the ethics of including a no-treatment control group in a prospective trial are questionable, it remains possible to compare different treatments. This has been done in only two published trials (DePippo, Holas, Reding et al., 1994; Groher, 1987). Alternatively, historically controlled trials or other quasi-experimental designs can be employed. A large literature exists on how such studies can be conducted and validly analyzed, and the interested reader is referred to Cook and Campbell's classic work on this subject (Cook and Campbell, 1979) for further discussion.

Many noninvasive dysphagia therapies have been developed, as discussed in the section entitled Treatment of Oropharyngeal Dysphagia. Treatments of interest in this section are: diet modification, noninvasive swallow therapy (postural maneuvers and exercises), a combined treatment including both diet modification and swallow therapy, and PEG tubes. While diet modification could be considered one part of noninvasive swallow therapy, we broke it out separately here because many of the published studies looked at these two approaches independently.

In considering this fourth question, we included studies of noninvasive treatments regardless of design if they contained 10 or more treated patients and quantitatively reported results. For our analyses of PEG tubes, we were able to limit the studies included to those with the following characteristics:

- 50 or more patients
- U.S. studies
- Quantitative results
- Reported followup time

More stringent limitations are applied to some specific PEG tube outcomes because of possible effects of patient characteristics on results.

### Outcomes Considered

As implied by the Evidence Model (see Figure 1), we considered a large number of outcomes for this evidence report. The most important are those that directly impact the long-term health or well-being of the patient. We divided these into short-term outcomes, major morbidities, and long-term outcomes. Short-term outcomes include energy intake, weight change, aspiration, prevention of feeding tube usage, and minor feeding tube complications. Major morbidities were pneumonia, malnutrition, and major feeding tube complications. Long-term outcomes are QOL, mortality resulting from underlying illness, mortality as a result of morbidity, and mortality resulting from treatment (feeding tube only).

Many studies have looked at the short-term effects that noninvasive swallow therapies (such as chin tuck, head turning, and palatal training appliances) and diet modification (such as changes in bolus volume, flavor, or temperature) have on the physiological process of swallowing, such as total swallow duration and pharyngeal transit time (Bisch, Logemann, Rademaker et al., 1994; Lazarus, Logemann, Rademaker et al., 1993). However, little evidence in the literature directly links changes in these physiological processes to changes in the overall swallowing-related health of the patient; for example, there is no evidence linking improved (decreased) pharyngeal transit time to reduced incidence of aspiration pneumonia. Because of this, we will not discuss these findings, and we limit our discussion to the clinically meaningful outcomes outlined above.

Many of these outcomes of interest were not reported in the treatment literature. These treatments and outcomes, along with the evidence model links that represent their relationship, are depicted in Table 16.

Table 16. Treatments for which Outcomes of Interest Were Not Reported

Swallow therapy | | Diet modification | | Combined swallow therapy and diet modification | | Feeding tube
Outcome | Link | Outcome | Link | Outcome | Link | Outcome | Link
Change in food intake | T1 to O2 | Change in food intake | T2 to O2 | Malnutrition | T3 to M2 | Malnutrition | T4 to M2
Weight change | T1 to O4 | Prevention of feeding tube | T2 to O3 | Dehydration | T3 to M2 | Dehydration | T4 to M2
Malnutrition | T1 to M2 | Weight change | T2 to O4 | QOL | T3 to O7 | QOL | T4 to O7
Dehydration | T1 to M2 | Dehydration | T2 to O7
QOL | T1 to O7 | QOL | T2 to M2

Because case series design provides little information on treatment efficacy in stroke patients, we looked for other case series that might provide comparative data (historical studies for control groups and contemporary studies for other treatments). In some cases potential comparison data were identified, but were unusable because of different care settings, patient populations, or ways of measuring the outcome of interest. In the case that no comparative data could be located, we could not analyze these case series. Those outcomes for which there were only case series studies and no comparative data were located are shown in Table 17 below, and are included in Evidence Tables 46 through 68 but are not discussed here.

Table 17. Outcomes of Interest for which No Comparison Groups Exist in the Published Literature

Swallow therapy | | Diet modification | | Combined swallow therapy and diet modification
Outcome | Link | Outcome | Link | Outcome | Link
Aspiration | T1 to O5 | Aspiration | T2 to O5 | Aspiration | T3 to O5
Prevention of feeding tube | T1 to O3 | Malnutrition | T2 to M2
Mortality | T1 to O8, O9 | Mortality | T2 to O8, O9

The exception to this exclusion of case series is the literature on feeding tube usage, which may provide useful information from case series because this treatment is more applicable to chronic stroke patients who may not spontaneously recuperate.

Therefore, we considered only the outcomes shown in Table 18 in our discussion of Question 4.

Table 18. Outcomes Available for Analysis by Treatment Category

Swallow therapy | | Diet modification | | Combined swallow therapy and diet modification | | Feeding tube
Outcome | Link | Outcome | Link | Outcome | Link | Outcome | Link
Pneumonia | T1 to M1 | Pneumonia | T2 to M1 | Pneumonia | T3 to M1 | Pneumonia | T4 to M1
| | | | Mortality | T3 to O8, O9 | Mortality | T4 to O8, O9, O10
| | | | Change in food intake | T3 to O2 | Aspiration | T4 to O5
| | | | Prevention of feeding tube | T3 to O3 | Weight change | T4 to O4
| | | | Weight change | T3 to O4 | Minor tube complications | T4 to O6
| | | | | | Major tube complications | T4 to M4

We discuss each of these outcomes for each of these treatments (and, hence, each appropriate link in the evidence model) in the following sections and subsections. We will first discuss pneumonia, the most commonly reported outcome, followed by any other morbidities for which there were data; short-term outcomes (weight change, feeding method, energy intake, aspiration, minor tube complications) are then discussed, followed by mortality.

### Noninvasive Therapies

Because of the inconvenience, discomfort, and cost of enteral feeding, it is important to patients, clinicians, caregivers, and payers that the patient be able to eat orally and independently whenever it is deemed safe to do so. This means that the patient must be able to ingest adequate amounts of food to maintain a healthy weight and not aspirate significant amounts of harmful substances. It must also be comfortable for the patient to eat; if they experience pain or the disquiet of coughing on every swallow, they will be reluctant to eat, and will ultimately lose weight and become susceptible to further illnesses.

Four published studies on noninvasive therapies in the dysphagia literature meet our inclusion criteria for size and study design in this section (DePippo, Holas, Reding et al., 1994; Groher, 1987; Kasprisin, Clumeck, and Nino-Murcia, 1989; Martens, Cameron, and Simonsen, 1990). Each of these studies used a different study design, patient population, care setting, or followup time that potentially affected results; these studies are therefore not comparable to one another. Table 19 displays the characteristics of each of these studies that render them noncomparable. We will therefore only perform within-study comparisons.

Table 19. Characteristics of Controlled Studies on Noninvasive Therapies for Dysphagia

Study | N | Study design | Care setting | Mean age | Primary disease(s) | Treatment | Time frame
Groher 1987 | 23 23 | RCT | Nursing home | 71.8 74.2 | CVA with history of aspiration pneumonia | Pureed diet Mechanically altered diet | 6 mos
Kasprisin 1989 | 48 13 8 | Retro CT | Hospital | NR | Various | Swallow therapy | NR
Martens 1990 | 16 15 | HPCS | Acute hospital unit | 49.3 46.1 | Brain injury, tumor, CVA | Various (diet, exercise, counseling) No specific dysphagia treatment | NR
DePippo 1994 | 38 38 38 | RCT | Rehab unit | 76 74.5 73 | CVA | Diet and swallow technique recommendations Therapist-prescribed diet and swallow techniques Therapist prescribed diet and techniques reinforced | 1 year

All of these studies suffer from the same limitation that makes it impossible to make conclusions based on their results, no matter how well designed they are. The problem is an issue of statistical power-if the outcome of interest (in this case, pneumonia or mortality) is one that has a low incidence rate, to obtain statistically significant group differences, the total number of patients in the study must be high enough that a type II error can be avoided. An example about how to calculate the necessary number of subjects needed is included in the Future Research section. Studies on patients with dysphagia interested in reporting pneumonia or death as an outcome would require several hundred patients to obtain reliable findings.

#### Pneumonia

Pneumonia has been the outcome most often reported in these studies. This, however, is not to say that pneumonia is the only important outcome after dysphagia-malnutrition, QOL, dehydration, and death are also important outcomes. Pneumonia is, however, the most common illness experienced by the elderly, and a common cause of death for these patients. It has thus been the primary focus of researchers in this field. There are no studies on the other major morbidities to discuss in this section, and we therefore recommend that researchers pay more attention to these outcomes when conducting future research.

Pneumonia as an outcome is shown in Evidence Tables 56 through 58. Pneumonia has been reported as an outcome in a retrospective controlled trial on noninvasive therapies (Kasprisin, Clumeck, and Nino-Murcia, 1989), a randomized controlled trial on diet modification (Groher, 1987), an RCT on combined therapy (DePippo, Holas, Reding et al., 1994), and a historical prospective case series on combined therapy (Martens, Cameron, and Simonsen, 1990). Only well-designed RCTs can be completely free of potential confounds. Controls in these studies were not patients who received no treatment at all, but a different treatment (Groher, 1987) or a different level of treatment (DePippo, Holas, Reding et al., 1994). Therefore, even in these relatively well-designed studies, no pure effects of treatment can be determined, only effects relative to the control treatment.

Groher (1987) compared the use of a pureed diet (control group) with the use of a mechanically altered diet (treatment group) for patients with a history of aspiration pneumonia. This study specifically challenged the notion that a pureed diet was safe for such patients. A mechanically altered diet was defined as one in which soft foods were allowed as well as altered fluids (thickened or frozen). The researchers reported that in the treatment group, 17.4 percent of patients developed pneumonia, while in the control group, 86.9 percent developed pneumonia; this difference was statistically significant (p<0.05). Although the number of subjects in this trial was relatively small, the large effect size made statistical significance possible. The results of this trial strongly indicate that a mechanically altered diet is safer for stroke patients with dysphagia than the conventional pureed diet; these results, however, are limited to those in a nursing home with a history of aspiration pneumonia. These results may not be generalizable to patients with higher functional status.

DePippo, Holas, Reding, et al. (1994) compared three different levels of intervention in a randomized controlled trial with 115 stroke patients in a rehabilitation center. Patients in Group I received diet and swallow technique recommendations without therapist followup or reinforcement, those in Group II received therapist-prescribed diet and special swallowing techniques, and those in Group III received therapist-prescribed diet and swallowing techniques with daily reinforcement from the therapist. The treatment lasted for about 2 months, and followup continued for 1 year. Those patients with the lowest intervention level had a pneumonia incidence of 2.6 percent; those on intermediate intervention experienced the highest pneumonia incidence at 13.2 percent. The most intense intervention group had an incidence rate of 5.1 percent. Pneumonia incidence did not correlate with the level of intervention, and the difference between the groups was not significant.

Because these two studies were well-controlled for patient population, treatment, and care setting, their results could, theoretically, be reliable. However, because of low statistical power (small number of patients and low incidence of pneumonia in these populations), conclusions cannot be drawn.

The results of DePippo et al. (1994) can be compared with those reported in a case series on the same type of treatment for a similar patient population. Gottlieb et al. (1996), in a case series of 50 stroke patients with dysphagia, reported a pneumonia incidence of 18 percent (9/50) after a mean 53.5 days. Gottlieb's pneumonia incidence rates are higher than DePippo's; DePippo's subjects received VFSS exams, while Gottlieb's were diagnosed using a water swallow test. It is conceivable that the water swallow test did not detect silent aspirators, and therefore the treatment applied in this study was not geared to prevent aspiration, thus resulting in more cases of pneumonia. However, it is also unclear how intensive the therapy was in Gottlieb's study. Thus, it is impossible to determine the exact cause of these differences.

Less well-controlled studies were also done on swallow therapy and combined therapy. Kasprisin et al. (1989) conducted a retrospective pseudo-controlled trial that compared three groups of patients with various diseases (both neurologic and nonneurologic) who received either swallow therapy (including thermal stimulation, supraglottic swallow, and bolus propulsion exercises) with those who did not. Group 1 (48 patients) received therapy and had no history of aspiration pneumonia; Group 2 (13 patients) received therapy and had a history of aspiration pneumonia; Group 3 (8 patients) did not receive treatment (for a variety of self-determined reasons) and their history of pneumonia was not reported. Incidence of aspiration pneumonia in each of these groups was 6.3 percent, 15.4 percent, and 100 percent, respectively, 1 to 36 weeks after treatment (mean not given). The differences between Groups 1 and 3, and Groups 2 and 3 were statistically significant. Although the results of this study suggest that swallow therapy helps prevent aspiration pneumonia both in patients with a history of it and those without such a history, few details were provided on the untreated group, and therefore potential biases may have been introduced. The control group consisted of a very small number of patients (eight) and could have differed from the treated groups in clinically significant ways. Their pneumonia rates were tracked immediately while the treatment group's pneumonia rates were not tracked until they had completed treatment (2-4 weeks after admission); this difference may be significant if pneumonia rates change over time (as discussed in Appendix D). It is also unclear how the control group patients were tracked after they transferred to a different hospital or moved out of the geographical area. It is possible that patients who stayed within the healthcare system because of health problems such as pneumonia were more easily followed, thus inflating the pneumonia rates in the untreated individuals. The difference between the pre- and post-treatment rates of pneumonia in Group II (100 to 15.4 percent) looks promising, but the meaning of this difference is difficult to evaluate without knowing the etiological makeup of the patient population; if there were many stroke patients, recovery could have occurred spontaneously.

Martens et al. (1990) conducted a historical prospective case series comparing 16 acute-care patients receiving individualized dysphagia treatment with 15 historical controls with no such individualized treatment. They reported no cases of aspiration pneumonia in either group during a 30- to 40-day acute-care stay (Martens, Cameron, and Simonsen, 1990), which suggests that a dysphagia program was not needed for these patients to prevent aspiration pneumonia. However, the etiologies of these patients were mixed (patients with head injuries and tumors were included), and the average age of these patients was in the upper 40s. Because this was the only study not reporting cases of pneumonia in the control group, it is possible that publication bias is playing a role, because investigators would not be likely to publish a study reporting no effect.

#### Short-Term Outcomes

There are several different ways of measuring the short-term efficacy of a treatment. In dysphagia treatment, whether noninvasive or invasive, the short-term goal is to safely increase a patient's food intake and/or weight. Only one study has thus far reported these results in a pseudo-controlled trial on dysphagia treatment (Martens, Cameron, and Simonsen, 1990) (see Evidence Tables 46 and 49). These researchers reported that patients of various etiologies who underwent a directed dysphagia treatment program fared better than those not treated, in terms of weight gain (+1.41 kg versus -2.82 kg) and kilocalorie intake (97.3 kilocalories fewer than desired versus 488.8 kilocalories fewer than desired); these differences were marginally significant (p = 0.05). Only limited information can be gleaned from this study because of design, patient characteristics, and nonspecific treatment descriptions (see Table 18); it suggests, but does not prove, that a directed dysphagia treatment program is better than no such program.

Another issue is whether patients who learn swallowing techniques can perform them independently after leaving the inpatient care setting; these techniques are useless (or, alternatively, very expensive) if they can only be performed under the direction of a clinician. DePippo et al.(1994) reported on three different levels of intervention in a stroke rehab unit (see Evidence Table 48). These researchers found that the patients undergoing the most intensive therapy were significantly more likely to be able to perform these techniques independently. However, this same study found no differences in pneumonia incidence among the three groups; this suggests that the ability to perform the techniques independently is not clinically significant. We do not, however, know the effect of independent performance on the QOL or nutritional status of the patient.

#### Mortality

Patients undergoing noninvasive therapy are not usually those patients expected to die; the more severely debilitated patients will likely be put on a feeding tube instead. As a result, very few studies have reported mortality as clinically important when examining noninvasive treatments. Indeed, the one analyzable study that did report this outcome found that no patients died in any of the treatment groups (DePippo, Holas, Reding et al., 1994) (see Evidence Table 65). Mortality is a significant outcome in patients with a PEG tube (as discussed below), suggesting that patients undergoing noninvasive therapy are characteristically different from those undergoing enteral feeding. Therefore, PEG tubes will be discussed below without comparison to the results of noninvasive treatment.

#### Summary

Only four studies in the published literature provided information suitable for analysis of the effectiveness of noninvasive therapy. Two of these studies provided data from well-designed and controlled RCTs that may, as a result, be considered reliable. In addition, these were also the only studies that exclusively examined stroke patients. These two studies suggest that soft mechanical diets lead to decreased pneumonia incidence over pureed diet in patients with a history of aspiration pneumonia, and that intensity of treatment intervention has no apparent effect on pneumonia incidence.

Less well-controlled studies have reported contradictory findings, one reporting that aspiration pneumonia does not occur in acute-care patients and therefore no treatment effects could be reported, and the other reporting that those without a directed dysphagia program experienced significantly higher incidence of pneumonia. Because these studies were of mixed etiology and flawed study design, no conclusions can be drawn.

There is also a suggestion from a case series with historical comparison group that dysphagia treatment leads to improved weight gain and calorie intake. Such short-term improvements may lead to reduced morbidities later, and therefore such outcomes are important to report.

DePippo et al. (1994) have also reported that greater intensity of treatment leads to better ability of patients to perform exercises independent of clinician assistance. However, they provided no evidence that such independent function leads to improved clinical outcomes.

In conclusion, there is limited information that some specific noninvasive treatments have significant effects on clinical outcome measures (pneumonia and weight gain) in certain care settings and specific patient populations. However, contradictory findings have been reported, and no two studies have examined identical patients in identical care settings, thus rendering these studies noncomparable.

### PEG Tubes

In many cases, as discussed previously in this report, stroke patients spontaneously regain their ability to swallow. These are recuperative stroke patients with mild to moderate dysfunction. If these patients have severe difficulty swallowing immediately after the event, they may be given an NG tube temporarily to help them ingest adequate amounts of food. They may also receive noninvasive swallow therapy and/or diet modification until the dysphagia resolves. However, there are also chronic stroke patients who recover more slowly, or never recover full swallow ability. These patients would most benefit from effective noninvasive or invasive treatments because of the long-term risks of unsafe swallowing.

While NG tubes are used short term, PEG tubes, because they are invasive, are generally reserved for those patients requiring long-term enteral feeding (Lazarus, 1990). However, acute-care stroke patients are sometimes given a PEG tube for sustenance while undergoing noninvasive swallow therapy or while receiving recreational oral feeding. Those patients with chronic stroke accompanied by severe dysphagia may receive a PEG tube if noninvasive therapies prove ineffective in eliminating aspiration or sustaining adequate energy intake. With the advent of more specialized noninvasive therapies, PEG tube placement may become a last resort. The patients placed on PEG tubes are thus likely to be sicker than those who continue with noninvasive therapy. Consequently, it is not appropriate to compare the outcomes of PEG tube patients with those undergoing noninvasive therapy. Tube patients are not only at increased risk of morbidity and mortality because of their debilitated status, but the insertion of the feeding tube also can cause many different minor and major complications. These additional factors make it all the more important to identify efficacious noninvasive measures whenever possible and reserve PEG for those patients with unresolvable dysphagia or other feeding-related functional problems. Most studies conducted thus far on PEG tubes have included a mixture of patients with widely varying etiology (from paralysis to Parkinson's) and varying levels of cognition. Many studies included patients in a comatose state, and these studies will not be discussed here except in reference to tube-related complications and tube-related mortality, for which we assume the condition of the patient plays no significant role. For our discussion of morbidities and nontube related mortalities, we limit our discussion to studies including 90 percent or more cognizant patients, with a largely neurologic etiology (>75 percent), because those are patients most relevant to this report and most likely to be suffering from dysphagia, and therefore potentially eligible for noninvasive therapy. This reduces our pool of eligible studies from 20 to 7 (all studies are recorded in the appropriate evidence table, however). Only two studies were located that reported patients with dysphagia as a major part of their patient pool (Britton, Lipscomb, Mohr et al., 1997; Norton, Homer-Ward, Donnelly et al., 1996): We will pay particular attention to these two studies in this discussion.

#### Major Tube Complications

Major complications are those that seriously affect the health of the patient, threaten mortality, or require major interventions (such as surgery) to repair. Major complications were reported by 11 studies and included:

- Gastric fistula
- Bowel obstruction
- Gastric bleeding
- Peritonitis
- Severe infection
- Wound closure failure
- Necrotizing fasciitis (extensive streptococcal cellulitis)
- Gastric perforation
- Hematoma
- Septicemia
- Ileus

Studies reporting these outcomes are shown in Evidence Table 61. If incidence rates of any of these complications were not reported in a given study, we did not automatically assume that this complication did not occur; instead, we do not discuss studies for which no data were reported. This may lead to overestimates of complication rates, if in fact the researcher found that none of the complication of interest occurred. This possible bias is unfortunately unavoidable.

All studies reporting major complications were case series. Studies on PEG tubes meeting our inclusion criteria reported that 1 to 2 percent of the patients experienced major complications during the acute-care stage or a 30-day followup interval. These complications included failure of the incision to heal at tube removal (Kadakia, Sullivan, and Starnes, 1992), gastric fistula (Miller, Castlemain, Lacqua et al., 1989; Ponsky, Gauderer, and Stellato, 1983), peritonitis (Grant, 1993; Miller, Castlemain, Lacqua et al., 1989; Stern, 1986), bowel obstruction (Golden, Beber, Weber et al., 1997), and bladder perforation (Larson, Burton, Schroeder et al., 1987). Higher percentages of complications were reported over longer periods of time by two studies (Kaw and Sekas, 1994; Taylor, Larson, Ballard et al., 1992). Three complications were reported in these two studies: bowel obstruction, gastric bleeding, and ileus. All had an incidence rate of 4.3 percent with a followup of about a year.

Because these complications were each only reported by a few studies, it is not possible to determine the precise risk of each of these, or trends based on age, patient characteristics, or time. Also, because these complications occur at such a low rate (often only occurring in a single patient in each study), a larger patient population is necessary to achieve sufficient statistical power to compare these numbers. We have assumed that neurogenic dysphagia would suffer the same risk of complications as other enterally fed patients; however, it is conceivable that a pool of patients with dysphagia who were alert and cognizant (the population of primary interest in this report) might experience fewer complications because of stronger physiology.

#### Minor Tube Complications

Minor complications are fairly common after PEG insertion, occurring in 4 to 40 percent of patients. For the purposes of this particular analysis, we modified the inclusion criteria of at least 50 patients that we adopted for studies of feeding tubes to include all studies with 10 or more patients with long-term followup, defined as greater than 30 days. We modified our inclusion criteria because such long-term studies were scarce.

The most commonly reported minor tube complications were:

- Tube blockage
- Wound infection
- Tube extrusion
- Tube migration
- Cellulitis
- Tube leakage

These complications are considered minor because they can usually be resolved with tube reinsertion, replacement, or antibiotics; invasive or extreme measures are rarely needed.

Those studies reporting minor tube complications are shown in Evidence Table 55. Dysphagia has not been broken out in any study reporting tube complications; we assume for the purposes of this discussion that disease etiology plays no significant role in the occurrence of tube complications. When studies did not report on individual complications, we do not automatically assume that they did not occur during that study, and therefore that cell of the relevant evidence table is left blank rather than filled with a 0.

##### Tube blockage

As shown in Evidence Table 55, tube blockage has been reported in 3 to 30 percent of patients with a PEG tube (Jarnagin, Duh, Mulvihill et al., 1992; Kaw and Sekas, 1994; Kirby, Craig, Tsang et al., 1986; Llaneza, Menendez, Roberts et al., 1988; Taylor, Larson, Ballard et al., 1992; Wolfsen, Kozarek, Ball et al., 1990). All studies were case series. The highest rate was found in a nursing home population (Kaw and Sekas, 1994); the lowest was in a mixed population followed only for the length of their acute-care stay (Jarnagin, Duh, Mulvihill et al., 1992). A tube blockage incidence rate of 8 to 9 percent was reported in three studies (Llaneza, Menendez, Roberts et al., 1988; Taylor, Larson, Ballard et al., 1992; Wolfsen, Kozarek, Ball et al., 1990); most were patients with neurologic disorders who were released to a variety of care settings. This may provide an estimate of an average occurrence rate for this complication.

One case series compared PEG with percutaneous endoscopic jejunostomy (PEJ) tubes, and found significantly more tube blockage in the latter (23 percent versus 9 percent) (Wolfsen, Kozarek, Ball et al., 1990). Given that PEJ also results in increased aspiration (as reported by the same study), as well as increased tube migration and tube leakage (reported below), it appears that PEG should be used instead of PEJ whenever possible.

##### Wound infection

Wound infection has been reported in 0 to 41 percent of PEG tube patients (Grant, 1993; Kaw and Sekas, 1994; Larson, Burton, Schroeder et al., 1987; Miller, Castlemain, Lacqua et al., 1989; Ponsky, Gauderer, and Stellato, 1983; Stern, 1986; Stiegmann, Goff, Silas et al., 1990; Taylor, Larson, Ballard et al., 1992). The lowest rate was reported in a case series of 302 patients followed for 30 days (Miller, Castlemain, Lacqua et al., 1989); the highest was reported in a similar study in which patients were followed for an average of 327 days. There were no apparent differences in patient mean age or proportion of patients having neurologic conditions. It therefore appears that the incidence of wound infection continues to increase over time for PEG tube patients; this again may be caused by patient selection bias, in which sicker patients remain on the tube and may be more susceptible to infections.

One randomized controlled trial (Stiegmann, Goff, Silas et al., 1990) compared the incidence of wound infection after PEG insertion with wound infection after operative gastrostomy (OG). While 3 percent of PEG tube patients experienced wound infection, 9 percent of OG patients did. No statistical analysis of this difference was reported.

##### Pain

Two studies reported that pain occurred in 3 percent (Taylor, Larson, Ballard et al., 1992) or 7 percent (Llaneza, Menendez, Roberts et al., 1988) of patients. The patients in these studies were similar in etiology and age. Given that pain is a subjective sensation that can be measured in many different ways, test methodology and time of measurement may account for this difference. Thus, limited evidence suggests that PEG tubes cause minimal pain for most patients.

##### Tube extrusion

Inadvertent tube extraction by the patient or caregiver was reported by five studies (all retrospective case series) as occurring in 4 to 41 percent of patients (Jarnagin, Duh, Mulvihill et al., 1992; Kirby, Craig, Tsang et al., 1986; Larson, Burton, Schroeder et al., 1987; Llaneza, Menendez, Roberts et al., 1988; Taylor, Larson, Ballard et al., 1992). The lowest incidence rate was reported by Kaw et al. (1994) who followed 46 nursing home residents for almost a year. The highest, from Taylor et al. (1992) (who also reported the highest infection rate) was in a group of 92 largely neurologic patients in various care settings. While nursing home patients in general have the highest rates of complications and morbidities, this is not the case here.

There appeared to be no correlation between time of followup or patient characteristics and the incidence of inadvertent tube extraction.

##### Tube migration

A feeding tube may slip from its position as a result of patient movement or improper anchoring. Given that reporting of complications was often not clear in these studies, it may be the case that tube migration and inadvertent tube extraction (above) were mixed together in some studies.

Tube migration has been reported by nine studies as occurring in less than 1 to 21 percent of PEG tube patients (Golden, Beber, Weber et al., 1997; Kadakia, Sullivan, and Starnes, 1992; Kaw and Sekas, 1994; Larson, Burton, Schroeder et al., 1987; Miller, Castlemain, Lacqua et al., 1989; Ponsky, Gauderer, and Stellato, 1983; Stiegmann, Goff, Silas et al., 1990; Taylor, Larson, Ballard et al., 1992; Wolfsen, Kozarek, Ball et al., 1990). The lowest number was reported by a case series of 87 consecutive patients in various care settings (Larson, Burton, Schroeder et al., 1987); the highest was reported by a study of 46 nursing home patients (Kaw and Sekas, 1994), again suggesting that nursing home residents suffer from more complications and morbidities. One randomized controlled trial compared PEG tubes with OG and found tube migration to occur slightly more often with PEG tubes (7 percent versus 5 percent), not a significant difference (Stiegmann, Goff, Silas et al., 1990). One case series compared PEG with PEJ and found that tube migration occurred more often with PEJ tubes (3 versus 15 percent, respectively) (Wolfsen, Kozarek, Ball et al., 1990) (statistical significance not reported).

There is no apparent effect of age or etiology on the incidence of tube migration.

##### Cellulitis

Four studies reported the incidence of tissue inflammation after infection (Jarnagin, Duh, Mulvihill et al., 1992; Kadakia, Sullivan, and Starnes, 1992; Kirby, Craig, Tsang et al., 1986; Llaneza, Menendez, Roberts et al., 1988), ranging from 3 to 12 percent. All were case series. The lowest incidence was found in a study of 79 patients who were followed during their acute-care stay (Jarnagin, Duh, Mulvihill et al., 1992). The highest rate was reported among 73 patients followed for an average 420 days and living at home or in a nursing home (Llaneza, Menendez, Roberts et al., 1988). These findings suggest that the incidence of cellulitis may increase over time; but again, patient attrition may have affected these rates. Interestingly, although cellulitis usually occurs after an infection, the rate of wound infections reported by these studies was lower than the rate of cellulitis.

##### Tube leakage

Nine studies reported tube leakage as a complication after PEG (Grant, 1993; Kadakia, Sullivan, and Starnes, 1992; Kaw and Sekas, 1994; Larson, Burton, Schroeder et al., 1987; Llaneza, Menendez, Roberts et al., 1988; Stern, 1986; Stiegmann, Goff, Silas et al., 1990; Taylor, Larson, Ballard et al., 1992; Wolfsen, Kozarek, Ball et al., 1990). Incidence ranged from 1 to 13 percent. The lowest rate, reported by Larson et al. (1987), was in a pool of 299 consecutive patients, 75 percent with neurologic disorders, mean age of 64, followed for 30 days. The highest rate, from Kaw and Sekas (1994), was in 46 nursing home patients, 91 percent of whom had neurologic disease, and who were followed for a mean of 321 days. Thus, duration of tube use, age, and debilitation may all play a role in the incidence of this complication. However, when all nine studies are examined, the incidence of tube leakage does not appear to change over time. On the other hand, there was a trend for age and incidence of tube leakage to correlate.

One randomized controlled trial reported tube leakage in PEG patients and OG patients. The incidence rate was 2 percent for both groups during their acute-care stay (Stiegmann, Goff, Silas et al., 1990). One nonrandomized trial comparing PEG with PEJ found a slightly lower rate of tube leakage in PEG patients followed over 275 days (9 percent versus 11 percent) (Wolfsen, Kozarek, Ball et al., 1990); statistical significance of this finding was not reported.

##### Other minor complications

Other complications reported by some studies included tube breakage, minor ileus, minor bleeding, gastric ulcer, hematoma, dehydration, and gastric fistula. Minor bleeding was reported as occurring in about 1 percent of patients in three case series (Golden, Beber, Weber et al., 1997; Grant, 1993; Stern, 1986), and in 5 percent of patients in a randomized controlled trial (Stiegmann, Goff, Silas et al., 1990). There is no clear reason for this discrepancy. One study reported a rate of 7 percent gastric hemorrhage (Taylor, Larson, Ballard et al., 1992); these patients were followed for an average of 327 days.

##### Summary of minor tube complications

Variations in rates of each minor complication suggest differences resulting from patient or care setting characteristics (nursing home residents experiencing more severe problems except with tube extraction), and in a few cases, length of followup time or age of patients. Two studies have reported the rates of complications broken out by care setting; Taylor et al. (1994) reported that 14 percent of all complications occurred while patients were in the hospital, 14 percent occurred when patients were released to go home, 62 percent occurred in a nursing home, and 9 percent occurred in other care settings. These findings suggest that nursing home patients experience substantially more complications than patients in other settings. On the other hand, another study (Hull, Rawlings, Murray et al., 1993) showed no significant differences in overall complication rates based on residential status; however, three out of four specific complications (tube blockage, tube migration, and cellulitis versus tube extraction) were found to occur more often in nursing home patients than in patients in other care settings. Overall, the evidence does suggest increased complications among nursing home patients, although because these are comparisons among case series, a lack of internal control makes these trends unclear.

Because patients suffering from severe dysphagia may require a feeding tube if they are unable to feed well enough orally to ingest adequate amounts of food safely, it is important to determine which enteral feeding method is the most effective and safest. One case series has suggested a superiority of PEG over PEJ in terms of incidence of complications (Wolfsen, Kozarek, Ball et al., 1990). One other randomized controlled trial found PEG to be far superior to OG in the rate of wound infection (Stiegmann, Goff, Silas et al., 1990). Such findings, if supported by further, well-controlled research, should be considered when placing these patients on enteral feeding.

#### Major Morbidities

The primary morbidity discussed in this report thus far has been pneumonia, primarily because it has been the only major outcome consistently reported in the literature. For patients with neurologic disease with a PEG tube, pneumonia has been reported in 3 percent during acute care (Stiegmann, Goff, Silas et al., 1990) and 10 percent when patients were followed for up to 210 days (Valenti, Trudell, and Bentley, 1978) (see Evidence Table 59). The number of stroke patients was not reported by either of these studies, but they were both over 80 percent neurologic etiology in these two studies. These results do suggest that for PEG tube patients, unlike patients orally feeding, the risk of pneumonia does not drop sharply after the first few weeks after the stroke event, further emphasizing that the patients placed on PEG tubes are patients suffering from chronic neurologic problems that do not clear up spontaneously.

However, when aspiration was measured as a surrogate for pneumonia immediately after the tube placement, one study reported an incidence rate of only 1 percent (Stern, 1986); few details were provided on patient characteristics or care setting. This raises the obvious question as to what kind of pneumonia these PEG patients are getting over the long term, if it is not the result of aspiration. Two other studies that did not meet our inclusion criteria because of mixed patient population and condition, reported that aspiration rates increased over time, from 4 percent during acute care (Kadakia, Sullivan, and Starnes, 1992) to 5 percent at 30 days (Wolfsen, Kozarek, Ball et al., 1990). Because these patient populations include many degenerating patients, this increasing rate could be a reflection of advancing disease. This is not necessarily applicable to stroke patients.

Malnutrition has not been reported as an outcome in any published PEG tube study.

#### Short-term Outcomes

The most immediate purpose of enteral feeding is to stabilize the patient nutritionally. Many patients put on a feeding tube have already lost significant amounts of weight by the time of insertion, thus necessitating the tube. If weight gain cannot be achieved, then there is no point to the feeding tube. One study reporting this outcome exclusively examined stroke patients with dysphagia who were randomized to receive either a PEG tube or an NG tube (see Evidence Table 50). These researchers found that while PEG tube patients gained a mean 2.2 kilograms over a 1- to 6-week period, the NG tube patients lost a mean 2.6 kilograms (Norton, Homer-Ward, Donnelly et al., 1996). However, these results are not reported on an intent-to-treat basis, only including surviving patients. Another study with 100 percent of patients with neurologic disorders, 86 percent of whom suffered from dysphagia, reported that after a 6-month mean period, patients on average had gained 9 kilograms (Britton, Lipscomb, Mohr et al., 1997). Two other similar studies not reporting on patients with dysphagia specifically reported similar mean weight gain at 4 weeks of 4.5 kilograms (Sant, Gilvarry, Shannon et al., 1993) and 3.4 kilograms (Park, Allison, Lang et al., 1992). These positive results may not be so much an indication of the effectiveness of tube feeding, but a reflection of how much weight patients have lost by the time they are on a feeding tube. These results in toto still suggest, however, that patients with neurologic disorders do benefit from PEG tubes in terms of nutritional status, and patients with dysphagia in particular may continue to gain weight for up to 6 months.

With such stabilization of nutritional status, it may be more likely for stroke patients to recover function and ultimately be removed from the feeding tube, and then become eligible for noninvasive therapies. Neumann (1993) reported that in a neurologic rehabilitation center during a 17-week period, patients on a feeding tube who were also given indirect and direct swallow therapy were able to be removed from tube feeding in 67.5 percent of cases (tube feeding method not specified) (Neumann, 1993) (see Evidence Table 47). This study suggests that the use of enteral feeding in addition to noninvasive therapy may help the patient regain exclusive oral feeding. However, because this study did not include a control group of tube-fed patients who did not receive therapy, it is unclear what exactly affected the feeding method outcome.

#### Mortality (Resulting from Morbidity, Underlying Illness, or Tube Complications)

If patients suffer from severe pneumonia, and are in a debilitated state, they may die from this illness. Such mortality has been reported in 2 percent (Stern, 1986) of patients after 30 days, and 6 percent of patients during a period of up to 210 days (Kirby, Craig, Tsang et al., 1986) (see Evidence Table 66). These findings were in populations of 85 percent or more neurologic etiology. They suggest that as the cumulative rate of pneumonia continues to rise over time (as discussed above), a substantial portion of these patients will die of the illness. If pneumonia incidence rates are 3 to 10 percent during a period of up to 210 days, and death rates are 2 to 6 percent during the same period, this suggests that approximately 60 percent of PEG tube patients with neurologic disorders will die of pneumonia if they contract it. The causal relationship between these morbidities and mortalities is unclear in PEG tube patients: Are they intubated because of severe illness, or do they become sicker because they are on a feeding tube?

Patients may also die of their underlying illness while receiving enteral feeding (see Evidence Table 66). In populations consisting largely of patients with neurologic disorders, this has been reported in 4 percent after 30 days up to 24 percent after a mean of 100 days (Stern, 1986). These findings suggest that many of these patients had neurodegenerative disease or recurring stroke, and thus are severely ill patients.

As discussed earlier in this section, the insertion of a PEG tube can lead to serious complications, such as gastric fistula, severe infections, and bowel obstruction. If the patient is frail and the complication is not detected soon enough, the patient may die (post-operative mortality). Complications may also occur peri-operatively, although these are more rare.

Data addressing this outcome were available in a single study (see Evidence Table 68), in which a single patient died as a result of peritonitis (1 percent death rate) (Stern, 1986). Peritonitis was the most often reported cause of tube-related death in all PEG studies. More information is needed in this area before making conclusions; when such mortality rates are so small, larger patient populations are needed for statistical power in order to compare these results with the results of other studies.

#### Summary: Mortality After a Feeding Tube

By far, most of the patients on feeding tubes die as a result of their underlying illness that necessitated the feeding tube in the first place; studies have reported this rate of mortality to be 4 to 24 percent, depending on the followup time and possible patient differences. The next most common cause of death appears to be serious comorbidity (pneumonia or aspiration), causing deaths in 2 to 6 percent of PEG tube patients with neurologic disease; the longer the PEG tube is retained, the greater the chance of dying of one of these morbidities. This may indicate that patients who retain the tube for longer periods of time are the frailest, perhaps most likely to have a terminal illness, and thus most likely to die. Deaths due to tube complications have been reported in only one study, with a single patient dying as a result of peritonitis.

#### Summary: Outcomes After Treatment for Dysphagia

Question 4 contained four separate (but interrelated) subquestions about the efficacy of different treatments for the prevention or elimination of complications and morbidities associated with dysphagia. The first subquestion asks when noninvasive swallow therapy or diet modification is appropriate. Answering this question requires the ability to identify patient populations who would most likely benefit (the second subquestion) as well as symptomatology and stage of disease at which noninvasive therapy has the greatest effect. No research to date has currently addressed these two questions; an answer would require a study that compared different patient populations in their response to particular therapies. Because the current literature is largely case series data on stroke patients, this information cannot be extrapolated.

The third question asks simply, What can the evidence tell us about these therapies? The simple answer to this is very little. To determine treatment efficacy in any patient group suffering from a recuperative or degenerative disease, a comparison group (whether an untreated control or another treatment) is necessary to adjust for the changing effects of disease over time. This has been done in only a few studies. It is also necessary to include enough patients in the groups so that statistical power can be achieved for the results; assuming that the rate of aspiration pneumonia in stroke patients with dysphagia who are treated noninvasively is approximately 9.2 percent (DePippo, Holas, Reding et al., 1994) and the aspiration pneumonia rate in untreated stroke patients with dysphagia is about 14.2 percent (Nilsson, Ekberg, Olsson et al., 1998), it would require about 1,296 patients to find a statistically significant difference.^2^ However, such a comparison between a treatment and a no-treatment group would not be ethical; smaller differences between different levels of intervention would require even more subjects.

2 For these calculations, we assumed that the test statics was and sought an 80 percent power level at an alpha level of 0.05.

One controlled trial has indicated that intensity of swallow therapy and diet modification affects how well stroke patients with dysphagia continue these exercises independently (DePippo, Holas, Reding et al., 1994); however, intensity of treatment appeared to have no impact on the incidence of pneumonia or mortality after treatment. Another study determined that the use of a mechanically altered thickened diet resulted in better outcomes (as measured by pneumonia incidence) than a pureed diet in stroke patients with dysphagia (Groher, 1987). Although these studies do not provide a no-treatment group to determine pure treatment efficacy, their use of a comparison group with different treatment does provide information on relative efficacy.

One study included a historical control group (Martens, Cameron, and Simonsen, 1990) and found no cases of pneumonia in either the historical controls or the treatment group; they did, however, report marginally significant improvements in nutritional intake and weight gain in the treatment group compared with the controls.

The only way to glean perspective from case series data is to compare their results with other studies reporting the same outcomes in patients with dysphagia without a treatment program. This was done for pneumonia outcomes in our discussion of main Question 1 above. Some relevant calculations are discussed in Appendix D, and there does appear to be evidence that pneumonia rates are lower in the presence of a dysphagia management program.

We found no specific research on those swallow therapies (as described in the section Treatment of Oropharyngeal Dysphagia) that use voluntary physiological maneuvers during a swallow to force the bolus to pass through the pharynx correctly (the Mendelsohn maneuver, the supraglottic swallow, and the super-supraglottic swallow). In fact, very little literature reported patient outcomes after specific therapies at all; there were a few studies on palatal training appliances and TTA, but the rest were on general swallow therapy and/or diet modification. We do understand that these treatments are individualized and can be applied in many combinations, thus making outcomes reporting difficult for each one; however, it is impossible to make evidence-based practice decisions solely on the basis of anecdotal clinical accounts that these treatments are effective.

The final subquestion asked, Is PEG useful as a primary therapy or is it a last resort? This may not be an appropriate question if patient populations directed to noninvasive therapy differ in clinically significant ways from those directed to PEG tubes. There are, however, scarce data reporting current practice patterns for directing patients to different treatment; we can only conjecture on the basis of anecdotal reports and personal communications. For one, stroke patients with mild to moderate dysfunction who are expected to recuperate will probably only receive a NG tube if enteral feeding is necessary. These patients are also most likely to receive diet modification or swallow techniques as temporary measures until their swallow function spontaneously improves with time. Patients likely to be recommended for a PEG tube are those whose swallow function does not appear to improve during the first few weeks after the stroke event, and therefore these may represent more debilitated, chronic stroke patients. However, these patients, if not severely debilitated, may be the most likely to benefit from long-term dietary modification and swallow techniques if they are functionally able to follow directions and perform the maneuvers; for these patients, a PEG tube as well as noninvasive therapy can be used simultaneously. It may then be possible, as suggested by a single study (Neumann, 1993), that tube-fed patients could potentially resume an oral diet.

Evidence from the literature thus far suggests that patients on PEG tubes fare worse than those undergoing noninvasive therapy. It is unclear whether this is caused by the tube or by the severity of illness. These findings suggest that there are clinically significant differences in current practice patterns between those patients referred for noninvasive therapy and those referred for a PEG tube.

We strongly recommend that researchers consider conducting controlled trials on dysphagia treatment in a defined patient population, including such outcomes as aspiration, aspiration pneumonia, malnutrition, wasting, weight change, caloric intake, mortality resulting from pneumonia and other morbidities, and overall mortality. We also strongly recommend that patients be followed for an extended period of time so that the long-term consequences of therapy can be explored.

### Synthesis of Results Common to the Four Questions

Although this evidence report has concentrated on four main questions, these questions are not entirely independent of one another. Therefore, at this point, we present related information in one section. Thus, we present here the results of all of the controlled studies addressing our main question: Does a dysphagia diagnosis and treatment program prevent aspiration pneumonia? This, as noted in the Methodology section of this report, may be the question of most interest to society.

The studies relevant to the present discussion are described in Evidence Table 69. There were four studies of diagnostic-treatment programs [Daniels, Brailey, Priestly et al., 1998; Nilsson, Ekberg, Olsson et al., 1998; Odderson, Keaton, and McKenna, 1995; Spiegel, Creed, Selber et al., unpub(b)]. The Odderson and Spiegel studies had their own historical controls, and we calculated historical control values for the other two. (The caution that must be exercised in interpreting the results of such exploratory analyses is discussed in our answer to Question 1). The two studies with their own controls had highly statistically significant results (p = 0.0050 and p = 0.0003, respectively, with the Fisher exact test, one-tailed, alpha = 0.05). These studies also had statistically significant results by the Wilson score method for 95 percent confidence limits around the difference between two proportions (two-tailed). The two studies for which we provided historical controls had near significant results (p = 0.056 and p = 0.063, respectively) with the Fisher exact test and also by the Wilson method. These latter two studies were of low statistical power, so their nonsignificant results do not convincingly demonstrate a lack of effect and can best be considered inconclusive. One study of palatal training devices by Selley, Roche, Pearce et al. (1995) found nonsignificant results (p = 0.210) by the Fisher exact test, but attained a statistically significant difference by the Wilson method (95 percent CI 2.8 to 73 percent). Because of the extremely low power of this study, this is also an inconclusive result, and it again is important not to confuse lack of evidence for an effect with evidence of no effect. Two studies of diet and/or swallow therapy comparisons (Groher, 1987; Kasprisin, Clumeck, and Nino-Murcia, 1989) had highly significant results by both tests (p<0.0001 and p = 0.0002, respectively, on the Fisher exact test); and one (DePippo, Holas, Reding et al., 1994) had a nonsignificant result by both tests (p = 0.88 on the Fisher exact test, and a nonsignificant difference on the Wilson test). As in the studies above, this was a low powered study, and it is again difficult to have confidence in the finding of no statistically significant effect.

Thus, for the eight controlled studies above, we found four with highly significant results, two with near significant results and low power, and two with nonsignificant results and low power. Because of the low power, none of the nonsignificant results convincingly demonstrated no effect. This puts the emphasis on the four trials that found statistical significance. The most unbiased appraisal of these results is that there is an apparent effect (regardless of the cause of that effect) demonstrated by the studies that is not caused by random error. We again caution that a statistical analysis such as ours cannot eliminate confounding differences between control and experimental groups resulting from differences in treatment, patient characteristics, or other factors that contribute partially or wholly to the apparent effect.

#### Effect of Increased Power: An Illustration

Expressed in its most simplistic terms, the preceding analysis found that four trials found a statistically significant result, and four did not. Were we to simply tally up the number of studies for and against an effect (i.e., were one to vote count) we would likely determine that the sum total of the results was inconclusive. However, such vote-counting procedures have low statistical power (Hedges and Olkin, 1985). To illustrate this point and to further illustrate the low statistical power of the individual studies, we provide below another example using the data from the above-mentioned studies. We caution, however, that this exercise is solely for the purposes of illustration; although it can be used to infer that a correlation exists between the presence of a dysphagia program and a decrease in aspiration pneumonia rates, this analysis cannot be used to conclude that the program is the sole cause of these decreases. We also note that we could have illustrated the point with hypothetical data, but chose not to do so because using available data provides a more direct example of how vote-counting is conservative in the present case. Finally, we note that we did not use the results of this illustration in deriving the conclusions of this report.

In this example, we combine the above one-tailed p-values of the individual studies obtained from the Fisher exact test to yield an overall level of statistical significance. We chose to meta-analytically combine p-values rather than to employ a statistic that provides an effect size (e.g., the odds ratio) because any effect size estimated by combining the results of these studies is likely to be imprecise. In effect, our present analysis nevertheless approximates combining the results of the individual studies into one larger study. We combined the p-values by first taking their natural logarithms, and multiplying the result by -2. These quantities were summed according to the Fisher method, described in Rosenthal (Rosenthal, 1991). The sum, 76.946, was compared with the critical value for a chi-square distribution with df =16 (number of studies multiplied by 2). The resulting probability was less than 0.0001, which is highly significant. We obtained a similarly significant p-value using the method proposed by Stouffer et al. and described in Rosenthal (Rosenthal, 1991). The z-scores corresponding to the p-values were summed and this quantity was divided by the square root of the number of studies. The obtained z-value, 5.984, was then compared with the standard normal distribution. Again, the resulting probability was less than 0.0001.

We also conducted a statistical test to determine whether the results of these trials were significantly different from one another using the heterogeneity test described by Rosenthal (Rosenthal, 1991). Briefly, the sum of the squared differences between each z-score and the mean z-score was compared with the chi-square value for df = 7 (number of studies minus one). The obtained value, 14.811, was statistically significant, p = 0.0385, suggesting that the p-values were heterogeneous. We did not extensively investigate the source of this heterogeneity but, given that in some of these studies a single case of pneumonia can make the difference between statistical significance or nonsignificance, this heterogeneity is not surprising. However, we chose to be extremely cautious about combining these heterogeneous data, and, partly for this reason, we did not use the results of this analysis in deriving the conclusions of this report. However, the present analysis serves the purposes of our illustration by showing that because of an increase in statistical power, the overall test is statistically significant even when the results of the nonsignificant trials are included in the analysis.