# Appendix C. Detailed Search Strategies for Data Collection

## Medlars

(Parallel strategies were constructed in Dialog, Ovid, and PubMed syntax.)

### To identify swallowing disorders not associated with cancer

1 explode deglutition disorders or deglutition
2 (tw) all swallow: or dysphagia
3 neoplasms(px) [(px) indicates a pre-explosion of a MeSH term]
4 1 or 2
5 4 and not 3
6 5 and aged(px)
7 6 and human
8 7 and not case report

### To identify documents related to barium swallow in stroke patients

1 barium sulfate or barium adj sulfate
2 explode deglutition disorders
3 explode cerebrovascular disorders or stroke(tw)
4 1 and 2 and 3

### To identify documents related to barium swallow in patients over 65

1 barium sulfate or barium adj sulfate
2 explode deglutition disorders
3 aged(px)
4 1 and 2 and 3

### To identify therapies

1 explode deglutition disorders or explode deglutition
2 (tw) all swallow: or dysphagia
3 1 and di&(px) [this is a pre-explosion of a subheading category]
4 1 and th&(px)
5 3 or 4
6 1 or 2
7 6 and <speech therapy or speech-language pathology>
8 6 and <barium sulfate or barium(tw) or fluoroscopy or cineradiography or all videofluoroscopy:(tw)>
9 5 or 7 or 8
10 9 and aged(px)
11 10 and human

### To identify complications associated with and costs of PEG tubes

1 gastrostomy
2 percutaneous(tw) and endoscopic(tw) and gastrostomy(tw) or <PEG(tw) and all tube:(tw)>
3 1 and instrumentation(sh)
4 2 and equipment a#d supplies(px)
5 3 or 4
6 1 or 2
7 6 and <fatal outcome or treatment outcome or mortality or survival or explode morbidity>
8 6 and explode economics
9 7 and aged(px)
10 5 or 7 or 8 or 9
11 10 and human
12 neoplasms(px)
13 11 and not 12
14 13 and not <infant(px) or child(px)>

### To assess issues related to enteral nutrition

1 enteral nutrition or intubation, gastrointestinal
2 1 and <nasogastric(tw) or nasointestinal(tw)>
3 1 contains NG
4 2 or 3
5 4 and <adverse effects(sh) or complications(sh) or mortality(sh) or hazard:(tw) or safe(tw) or safety(tw)>
6 5 and not child(px)
7 gastrostomy and <percutaneous(tw) or PEG(tw)>
8 6 and not 7
9 8 and human

### To assess epidemiology and economics of various disorders and their relation to dysphagia

#### Alzheimer's Disease

##### Strategy 1

1 Alzheimer disease or all Alzheimer:(tw)
2 (tw) dysphagia or all swallow:
3 explode deglutition disorders or deglutition
4 2 or 3
5 1 and 4
6 5 and not adult(px)

##### Strategy 2

1 Alzheimer disease or all Alzheimer:(tw)
2 1 and not <explode dementia or explode dementia, vascular>
3 2 and <explode economics or economics(sh)>
4 2 and <epidemiology(sh) or incidence or prevalence>
5 4 and human

#### Cervical Osteophytes

1 (tw) cervical and osteophyte:
2 swallow:(tw) or dysphagia(tw) or explode deglutition disorders
3 1 and 2
4 3 and human

#### Dementia

##### Strategy 1

1 explode dementia or explode dementia, vascular
2 explode deglutition disorders or deglutition
3 (tw) dysphagia or all swallow:
4 2 or 3
5 1 and 4

##### Strategy 2

1 explode dementia or explode dementia, vascular
2 1 and <explode economics or economics(sh)>
3 1 and <epidemiology(sh) or incidence or prevalence>
4 2 or 3
5 4 and human

#### Lou Gehrig's Disease (ALS)

1 explode myotrophic lateral sclerosis
2 ALS(tw) or gehrig(tw) or (lateral adj sclerosis)
3 swallow:(tw) or dysphagia(tw) or explode deglutition disorders
4 1 or 2
5 3 and 4
6 5 and human

#### Neurodegenerative Diseases

1 explode *neurodegenerative diseases/statistics and numbers
2 explode *neurodegenerative diseases/epidemiology
3 1 or 2
4 3 and aged(px)
5 4 and human

[Note: the category neurodegenerative diseases includes: alzheimer disease; demyelinating diseases; multiple sclerosis; spinal cord diseases (including amyotrophic lateral sclerosis).]

#### Parkinson's Disease

1 *Parkinson disease/epidemiology
2 1 and human

[Note: we originally included the terms incidence or prevalence in the search strategy for Parkinson's disease but excluded them to minimize extraneous retrieval.]

#### Pneumonia

1 pneumonia, aspiration or silent adj aspiration
2 1 and <incidence or prevalence>
3 pneumonia, aspiration/epidemiology or pneumonia, aspiration/statistics and numbers
4 2 or 3
5 4 and human

#### Raynaud's Disease

##### Strategy 1

1 Raynaud disease or all Raynaud:(tw)
2 tw) dysphagia or all swallow:
3 explode deglutition disorders or deglutition
4 2 or 3
5 1 and 4
6 5 and human

##### Strategy 2

1 Raynaud disease or all Raynaud:(tw)
2 1 and <explode economics or economics(sh)>
3 1 and <epidemiology(sh) or incidence or prevalence>
4 2 or 3
5 4 and human

#### Stroke

##### Strategy 1

1 *stroke
2 1 and <explode economics or economics(sh)>
3 1 and epidemiology(sh)
4 2 or 3

##### Strategy 2

1 stroke
2 explode deglutition disorders or deglutition
3 (tw) dysphagia or all swallow:
4 2 or 3
5 1 and 4
6 5 and not infant(px)
7 6 and not child(px)
8 7 and not adult(px)
9 8 and human

##### Strategy 3

1 explode cerebrovascular disorders
2 1 and not cerebral ischemia, transient
3 explode hospitals or explode nursing homes
4 clinical protocols or clinical pathways or outcome assessment (health care) or patient care team
5 2 and 3 and 4

##### Strategy 4

1 explode cerebrovascular disorders/complications and explode pneumonia/etiology

#### Supranuclear Palsy

1 supranuclear palsy, progressive
2 supranuclear adj palsy
3 swallow:(tw) or dysphagia(tw) or explode deglutition disorders
4 1 or 2
5 3 and 4
6 5 and human

#### Xerostomia

1 Xerostomia
2 swallow:(tw) or dysphagia(tw) or explode deglutition disorders
3 1 and 2
4 3 and human

### To assess weight loss

1 *weight loss or *cachexia or *wasting syndrome
2 aged(px)
3 1 and 2
4 neoplasms(px)
5 3 and not 4
6 5 and human

[Note: we considered but excluded the following terms: eating; eating disorders; nutritional requirements; nutritional status; energy intake; activities of daily living.]

### To assess the cost of VFSS mobile units

1 explode mobile health units and explode economics
2 1 and United States

## PsycINFO

### To identify material describing dysphagia in the elderly

1 s swallowing or sh=50920
2 s (aged or geriatrics or gerontology or elder care or geriatric patient) or sh=(16364 or 20950 or 01370 or 20970 or 21000)
3 s s1 and s2
4 s s3 not children
5 s s4/eng

### To assess quality of life in the elderly

1 s quality of life or life satisfaction or QOL or satisfaction
2 s aged or geriatrics or gerontology or elder care or geriatric patients or QOL
3 s s1 and s2
4 s s3 and literature review
5 s s3 and ((control? Or random?)(2n)(trial?)
6 s s4 or s5
7 s s6 not child?

### To identify controlled trials, the above strategies were combined with

1 randomized controlled trials or randomized controlled trial(pt) or <random:(tw) and controlled(tw) and trial#(tw)> or random allocation or double-blind method or single-blind method
2 controlled clinical trials or controlled clinical trial(pt)
3 <explode clinical trials or all clinical trial:(pt) > and controlled(tw)
4 meta-analysis or meta-analysis(pt) or <meta adj analysis>
5 1 or 2 or 3 or 4 (randomized controlled trials OR randomized controlled trial[pt] OR (random*[tw] AND controlled[tw] AND trial*[tw]) OR random allocation OR double-blind method OR single-blind method OR controlled clinical trials OR controlled clinical trial[pt] OR ((clinical trials OR clinical trial*[pt]) AND controlled[tw]) OR meta-analysis OR meta-analysis[pt] OR meta-analysis[tw] OR "meta analysis")