# Appendixes

Appendix A. Epidemiology

Appendix B. Burden of Illness of Dysphagia and Its Complications in Neurologic Diseases

Appendix C. Detailed Search Strategies for Data Collection

Appendix D. Time Distribution of Pneumonia Cases in Acute Stroke Patients

Appendix E. Methods for Evaluation of Diagnostic Tests

Appendix F. Extension and Cost-Effectiveness Analysis of Suggested Clinical Trial

Appendix G. The Effect of Treatment on Diagnostic Test Results

Appendix H. Original Calculations in This Report