# Bibliography

Abrahm J L. Management of pain and spinal cord compression in patients with advanced cancer. Ann Int Med. 1999;131(1):37-46. [pmid: 10391814].
Ackermann S P, Cheal N. Factors affecting physician adherence to breast cancer screening guidelines. J Cancer Educ. 1994;9(2):96-100. [pmid: 7917899].
Adriaanse H, Van Reek J, Zandbelt L, et al. Nurses' smoking worldwide: A review of 73 surveys on nurses' tobacco consumption in 21 countries in the period 1959-1988. Int J Nurs Stud. 1991;28(4):361-75. [pmid: 1761380].
Adriaanse H, Van Reek J. Tobacco prevention in hospitals needs prolonged and sustained effort. Br J Addiction. 1991;86(6):703-4.
Albright C L, Farquhar J W, Fortmann S P, et al. Impact of a clinical preventive medicine curriculum for primary care faculty: Results of a dissemination model. Prev Med. 1992;21(4):419-35. [pmid: 1409485].
Alcalay R, Alvarado M, Balcazar H, et al. Evaluation of a community-based Latino heart disease prevention program in metropolitan Washington D.C. Int Q Community Educ. 1999;19(3):191-204.
Alciati M H. Intervention research: a model from the National Cancer Institute's Smoking and Tobacco Control Program. Am J Ind Med. Apr. 1996;29(4):324-8. [pmid: 8728133].
Alexy B B, Elnitsky C. Rural mobile health unit: outcomes. Public Health Nurs. Feb. 1998;15(1):3-11. [pmid: 9503947].
Allard P, Maunsell E, Labbe J, et al. Educational interventions to improve cancer pain control: a systematic review. J Palliat Med. 2001;4(2):191-203. [pmid: 11441627].
Allen B Jr, Pederson L L, Leonard E H. Effectiveness of physicians-in-training counseling for smoking cessation in African Americans. J Natl Med Assoc. Oct. 1998;90(10):597-604. [pmid: 9803724].
Allen S S, Bland C J, Dawson S J. A mini-workshop to train medical students to use a patient-centered approach to smoking cessation. Am J Prev Med. Jan. 1990;6(1):28-33. [pmid: 2340189].
Altman D G, Bland J M. Statistics notes. Units of analysis. BMJ. Jun 28. 1997;314(7098):1874. [pmid: 9224131]. [pmcid: 2127005].
American Cancer Society. Cancer facts and figures-1999. Internet. http://www.cancer.org/downloads/STT/CancerFacts&Figures1999TM.pdf
American Cancer Society. Cancer facts and figures-2002. Internet. http://www.cancer.org/downloads/STT/CancerFacts&Figures2002TM.pdf
American Cancer Society. Cervical Cancer and Pap Test Information. Internet. http://www.cdc.gov/cancer/nbccedp/info-cc.htm
Ammerman A, Lindquist C, Hersey J et al. Efficacy of interventions to modify dietary behavior related to cancer risk. Evidence Report/Technology Assessment, No. 25. Rockville, MD: U.S. Department of Health and Human Services, Agency for Health Care Research and Quality; 2001. AHRQ Publication N. 01-E029.
Andersen S, Keller C, McGowan N. Smoking cessation: the state of the science: the utility of the Transtheoretical Model in guiding interventions in smoking cessation. Online J Knowledge Synthesis Nurs 1999 Oct 22;6(9):no pagination
Anderson C, Sengupta S, Coleman J. Implementing smoking policies within trusts: nurses' perceptions and views of effectiveness and implications. J Nurs Manage. Nov. 1999;7(6):349-54.
Anderson D M, Meissner H I, Portnoy B. Media use and the health information acquisition process: How callers learned about the NCI's Cancer Information Service. Health Educ Res. 1989;4:419-27.
Anderson J T, Watson M, Hilleman D. Cardiovascular risk factor screening and intervention in African American adults. J Health Care Poor Underserved. Aug. 1997;8(3):322-44. [pmid: 9253225].
Anderson L A, Janes G R, Jenkins C. Implementing preventive services: to what extent can we change provider performance in ambulatory care? A review of the screening, immunization, and counseling literature. Ann Behav Med. 1998;20(3):161-7. [pmid: 9989322].
Andrews J L Jr. Reducing smoking in the hospital. An effective model program. Chest. Aug. 1983;84(2):206-9. [pmid: 6872604].
Anonymous. Public health service implementation plans for attaining the objectives for the nation. Public Health Rep 1983;98(Suppl 5):1780
Anonymous. Update: National Breast and Cervical Cancer Early Detection Program, July 1991-July 1992. MMWR 1992 Oct 9;41(40):739–43.
Anonymous. Bridging research to action: a framework and decision-making process for cancer control. Advisory Committee on Cancer Control, National Cancer Institute of Canada. CMAJ 1994 Oct 15;151(8):1141–6.
Anonymous. Quality improvement guidelines for the treatment of acute pain and cancer pain. American Pain Society Quality of Care Committee. JAMA 1995 Dec;274(23):1874–80.
Anonymous. Quick reference guide for clinicians. Smoking cessation: information for specialists. U.S. Department of Health and Human Services. J Am Acad Nurse Pract 1996 Jul;8(7):317–22.
Anonymous. The Agency for Health Care Policy and Research Smoking Cessation Clinical Practice Guideline. JAMA 1996 Apr 24;275(16):1270–80.
Anonymous. Cigarette smoking before and after an excise tax increase and an antismoking campaign--Massachusetts, 1990-1996. MMWR 1996 Nov 8;45(44):966–70.
Anonymous. Tobacco control: reducing cancer incidence and saving lives. American Society of Clinical Oncology. J Clin Oncol 1996 Jun;14(6):1961–3.
Anonymous. Harvard Report on Cancer Prevention. Volume 1: Causes of human cancer. Cancer Causes Control 1996 Nov;7 Suppl 1:S3–S59.
Anonymous. Smoking cessation: information for specialists. AHCPR. Dermatol Nurs 1997 Feb;9(1):51–6.
Anonymous. Food, nutrition and the prevention of cancer, a global perspective. American Insititute for Cancer Reserach; 1997.
Anonymous. 1998 MQSA (Mammography Quality Standards Act) final rule released. American College of Radiology. Radiol Manage 1998 Jul;20(4):51–5.
Anonymous. The management of chronic pain in patients with breast cancer. The Steering Committee on Clinical Practice Guidelines for the Care and Treatment of Breast Cancer. Canadian Society of Palliative Care Physicians. Canadian Association of Radiation Oncologists. CMAJ 1998 Feb 10;158(Suppl 3):S71–S81
Anonymous. Decline in cigarette consumption following implementation of a comprehensive tobacco prevention and education program--Oregon, 1996-1998. MMWR 1999 Feb 26;48(7):140–3.
Anonymous. From the Centers for Disease Control and Prevention. Decline in cigarette consumption following implementation of a comprehensive tobacco prevention and education program--Oregon, 1996-1998. JAMA 1999 Apr 28;281(16):1483–4.
Anonymous. Getting evidence into practice. Eff Health Care Bull 1999;5(1):1–15.
Anonymous. Strategies for reducing exposure to environmental tobacco smoke, increasing tobacco-use cessation, and reducing initiation in communities and health-care systems. MMWR 2000 Nov 10;49(RR-12):1–11.
Anonymous. A clinical practice guideline for treating tobacco use and dependence: A US Public Health Service report. The Tobacco Use and Dependence Clinical Practice Guideline Panel, Staff, and Consortium Representatives. JAMA 2000 Jun 28;283(24):3244–54.
Anonymous. Smoking cessation interventions and strategies. Best Pract 2001;5(3):1–6.
Anonymous. Cochrane reviews. Nursing interventions for smoking cessation. Nurs Times 2001 Jul 19;97(29):44
Anonymous. State-specific prevalence of current cigarette smoking among adults, and policies and attitudes about secondhand smoke--United States, 2000. MMWR 2001 Dec 14;50(49):1101–6.
Anonymous. Fact Sheet: Translating Research Into Practice (TRIP): - II. Internet. http://www.ahcpr.gov/research/trip2fac.htm
Anonymous. Effective Public Health Practice Project. Internet. Last accessed May 29, 2002. http://www.city.hamilton.on.ca/sphs/EPHPP/
Anonymous. Effective Public Health Interventions Summaries/Reviews. Internet. Last accessed May 29, 2002. http://www.city.hamilton.on.ca/sphs/EPHPP/ephppSumRev.htm
Anonymous. Guide to Community Preventive Health Services. Internet. Last accessed May 29, 2002. http://www.thecommunityguide.org/home_f.html
Anonymous. Research on tobacco and tobacco-related cancers. In: National Insitutes of Health, editors. The Nation's Investment in Cancer Research: A plan and budget proposal for fiscal year 2003, 2002. p. 83–7. Chapter 5
Anonymous. Annual smoking-attributable mortality, years of potential life lost, and economic costs--United States, 1995-1999. MMWR 2002 Apr 12;51(14):300–3.
Anonymous. HHS News: HHS affirms value of mammography for detecting breast cancer. Internet. http://www.hhs.gov/news/press/2002pres/20020221.html
Anonymous. 5 A Day for Better Health Program: Monograph. National Institutes of Health; 2002.
Anonymous. Who has the power over tobacco control? Lancet 2002 Jul 27;360(9329):267
Anonymous. Cigarette smoking among adults--United States, 2000. MMWR 2002 Jul 26;51(29):642–5.
Ansell D, Lacey L, Whitman S, et al. A nurse-delivered intervention to reduce barriers to breast and cervical cancer screening in Chicago inner city clinics. Public Health Rep. Jan. 1994;109(1):104-11. [pmid: 8303003]. [pmcid: 1402249].
Arblaster L, Lambert M, Entwistle V, et al. A systematic review of the effectiveness of health service interventions aimed at reducing inequalities in health. J Health Serv Res Policy. Apr. 1996;1(2):93-103. [pmid: 10180855].
Arciti C, Pistone M, Persici P, et al. Ten years of anti-smoking programs in Italy: a review. Am J Health Promot. Jan. 1995;9(3):190-200. [pmid: 10150721].
Ashenden R, Silagy C, Weller D. A systematic review of the effectiveness of promoting lifestyle change in general practice. Fam Pract. Apr. 1997;14(2):160-76. [pmid: 9137956].
Austin SM, Balas EA, Mitchell JA, et al. Effect of physician reminders on preventive care: meta-analysis of randomized clinical trials. Proceedings - the Annual Symposium on Computer Applications in Medical Care 1994;121–4.
Austoker J. Organisation of a national screening programme. Br Med Bull. Apr. 1991;47(2):416-26. [pmid: 1933222].
Bailey S, Bennett P, Hicks J, et al. Cancer detection activities coordinated by nursing students in community health. Cancer Nurs. Oct. 1996;19(5):348-52. [pmid: 8885482].
Baillie A J, Mattick R P, Hall W. Quitting smoking: estimation by meta-analysis of the rate of unaided smoking cessation. Aust J Public Health. Apr. 1995;19(2):129-31. [pmid: 7786936].
Bains N, Pickett W, Hoey J. The use and impact of incentives in population-based smoking cessation programs: a review. Am J Health Promot. May. 1998;12(5):307-20. [pmid: 10181140].
Bains N, Pickett W, Laundry B, et al. Predictors of smoking cessation in an incentive-based community intervention. Chronic Dis Can. 2000;21(2):54-61. [pmid: 11007655].
Bal D G, Kizer K W, Felten P G, et al. Reducing tobacco consumption in California. Development of a statewide anti-tobacco use campaign. JAMA. Sep 26. 1990;264(12):1570-4. [pmid: 2395199].
Bal D G, Foerster S B. Dietary strategies for cancer prevention. Cancer. Aug 1. 1993;72(Suppl 3):1005-10. [pmid: 8155110].
Bal D G, Glynn T J, Woolam G L. Tobacco wars: The successes, the challenges, and some failures. Cancer. 2001;91(Suppl 1):247-51. [pmid: 11148588].
Balas E A, Weingarten S, Garb C T, et al. Improving preventive care by prompting physicians. Arch Intern Med. Feb 14. 2000;160(3):301-8. [pmid: 10668831].
Balbach E D, Traynor M P, Glantz S A. The implementation of California's tobacco tax initiative: the critical role of outsider strategies in protecting Proposition 99. J Health Politics Policy Law. Aug. 2000;25(4):689-715.
Ball M J. Dietary intervention trials - Effect on cardiovascular morbidity and mortality. Curr Opin Lipidol. 1993;4(1):7-12.
Bandura A. Social Learning Theory. Englewood Cliffs, NJ: Prentice Hall; 1989.
Barbour DM. Development and implementation of a tobacco consultation program for managed care pharmacists. Am J Health Syst Pharm 2001;58(3):210, 212–3.
Barker G J, Taylor T S, Barker B F. Implementation of a tobacco cessation program in the student clinics. J Dent Educ. Aug. 1995;59(8):850-5. [pmid: 7499604].
Bartosch W J, Pope G C. Local restaurant smoking policy enactment in Massachusetts. J Public Health Manage Practice. Jan. 1999;5(1):63-73.
Basen-Engquist K, O'Hara-Tompkins N, Lovato C Y, et al. The effect of two types of teacher training on implementation of Smart Choices: a tobacco prevention curriculum. J Sch Health. Oct. 1994;64(8):334-9. [pmid: 7844976].
Baskerville N B, Hogg W, Lemelin J. Process evaluation of a tailored multifaceted approach to changing family physician practice patterns improving preventive care. J Fam Pract. Mar. 2001;50(3):W242-W249. [pmid: 11252222].
Bauman K E, Brown J D, Bryan E S, et al. Three mass media campaigns to prevent adolescent cigarette smoking. Prev Med. Sep. 1988;17(5):510-30. [pmid: 3237655].
Bayer W H, Fiscella K. Patients and community together. A family medicine community-oriented primary care project in an urban private practice. Arch Fam Med. Nov. 1999;8(6):546-9. [pmid: 10575396].
Beardow R, Oerton J, Victor C. Evaluation of the cervical cytology screening programme in an inner city health district. BMJ. Jul 8. 1989;299(6691):98-100. [pmid: 2504348]. [pmcid: 1837137].
Beck S L. Health policy, health services, and cancer pain management in the New South Africa. J Pain Symptom Manage. Jan. 1999;17(1):16-26. [pmid: 9919862].
Becker D M, Conner H F, Waranch H R, et al. The impact of a total ban on smoking in the Johns Hopkins Children's Center. JAMA. Aug 11. 1989;262(6):799-802. [pmid: 2746836].
Becker M H. The Health Belief Model and sick-role behavior. Health Education Monographs. 1974;2:409-19.
Begay M E, Traynor M, Glantz S A. The tobacco industry, state politics, and tobacco education in California. Am J Public Health. Sep. 1993;83(9):1214-21. [pmid: 8362994]. [pmcid: 1694950].
Bell R A, Mayer-Davis E J, Jackson Y, et al. An epidemiologic review of dietary intake studies among American Indians and Alaska Natives: implications for heart disease and cancer risk. Ann Epidemiol. May. 1997;7(4):229-40. [pmid: 9177104].
Ben Sira Z. Latent fear-arousing potential of fear-moderating and fear-neutral health promoting information. Soc Sci Med. May. 1981;15(2):105-12.
Benowitz N L. Smoking cessation trials targeted to racial and economic minority groups. JAMA. Jul 24. 2002;288(4):497-9. [pmid: 12132983].
Bentz C J. Implementing tobacco tracking codes in an individual practice association or a network model health maintenance organisation. Tob Control. 2000;9(Suppl 1):i42-i45. [pmid: 10688931].
Beresford S A, Thompson B, Feng Z, et al. Seattle 5 a Day worksite program to increase fruit and vegetable consumption. Prev Med. Mar. 2001;32(3):230-8. [pmid: 11277680].
Berger S. The implementation of dietary guidelines - Ways and difficulties. Am J Clin Nutr. 1987;45(Suppl 5):1383-9. [pmid: 3578126].
Bergman J A, Falit J L. Non-smoking policies, tobacco education, and smoking cessation programmes in facilities serving the elderly in Michigan, United States. Tob Control. 1997;6(3):194-8. [pmid: 9396103].
Berlin J A. Does blinding of readers affect the results of meta-analyses? University of Pennsylvania Meta-analysis Blinding Study Group. Lancet. Jul 19. 1997;350(9072):185-6. [pmid: 9250191].
Berman B A, Gritz E R, Braxton-Owens H, et al. Targeting adult smokers through a multi-ethnic public school system. J Cancer Educ. 1995;10(2):91-101. [pmid: 7669541].
Berman B A, Yancey A K, Bastani R, et al. African-American physicians and smoking cessation counseling. J Natl Med Assoc. Aug. 1997;89(8):534-42. [pmid: 9264221].
Bero L A, Grilli R, Grimshaw J M, et al. Closing the gap between research and practice: an overview of systematic reviews of interventions to promote the implementation of research findings. The Cochrane Effective Practice and Organization of Care Review Group. BMJ. Aug 15. 1998;317(7156):465-8. [pmid: 9703533]. [pmcid: 1113716].
Berwick D M. Controlling variation in health care: a consultation from Walter Shewhart. Med Care. Dec. 1991;29(12):1212-25. [pmid: 1745079].
Bevvino C, Jacob M C. Implementing the Veterans Administration's no-smoking policy. Am J Public Health. 1992;82(10):1416-7. [pmid: 1415872].
Biener L, Abrams D B, Follick M J, et al. A comparative evaluation of a restrictive smoking policy in a general hospital. Am J Public Health. Feb. 1989;79(2):192-5. [pmid: 2913839]. [pmcid: 1349932].
Biener L, Harris J E, Hamilton W. Impact of the Massachusetts tobacco control programme: population based trend analysis. BMJ. Aug 5. 2000;321(7257):351-4. [pmcid: 27453]. [pmid: 10926595].
Bigaard J, Hariri J, Lynge E. Cervical cancer screening in Denmark. Eur J Cancer. Nov. 2000;36(17):2198-204. [pmid: 11072204].
Bjartveit K. Smoking control implementation. Legislation and political activity. IARC Scientific Publications (Lyon). 1986;74:285-98.
Black M, Yamada J, Mann V et al. Effectiveness of strategies to increase cervical cancer screening: a systematic review of the literature from 1989-1999. Effective Public Health Practice Project: Public Health Branch, Ontario Ministry of Health; 2000.
Bolliger C T. Practical experiences in smoking reduction and cessation. Addiction. Jan. 2000;95(Suppl 1):S19-S24. [pmid: 10723818].
Bonfill X, Marzo M, Pladevall M, et al. Strategies for increasing women participation in community breast cancer screening (Cochrane Review). In: The Cochrane Library, 2001. Issue 1. Oxford: Update Software.
Bonnekamp G M M, Gutierrez-Sigler M D, Colomer C, et al. Opportunities for Health Promotion: The Knowledge and Information System of the Valencian Food Sector, Spain. Health Promotion Int. Nov 4. 1996;11(4):309-19.
Bonner F B. Cancer among Black families: Diffusion as a strategy of prevention and intervention. J Comp Fam Stud. 1998;29(2):349-59.
Bonomi A E, Shikiar R, Legro M W. Quality-of-life assessment in acute, chronic, and cancer pain: a pharmacist's guide. J Am Pharm Assoc. May. 2000;40(3):402-16.
Bookbinder M, Coyle N, Kiss M, et al. Implementing national standards for cancer pain management: program model and evaluation. J Pain Symptom Manage. Dec. 1996;12(6):334-47. [pmid: 8973043].
Borbas C, Morris N, McLaughlin B, et al. The role of clinical opinion leaders in guideline implementation and quality improvement. Chest. Aug. 2000;118(2 Suppl):24S-32S. [pmid: 10939996].
Borland R, Owen N, Hocking B. Changes in smoking behaviour after a total workplace smoking ban. Aust J Public Health. Jun. 1991;15(2):130-4. [pmid: 1912055].
Borland R. Tobacco health warnings and smoking-related cognitions and behaviours. Addiction. Nov. 1997;92(11):1427-35. [pmid: 9519486].
Borland R, Owen N, Tooley G, et al. Promoting reduced smoking rates in the context of workplace smoking bans. Am J Health Promot. Sep. 1999;14(1):1-3. [pmid: 10621518].
Boyd N R, Sutton C, Orleans C T, et al. Quit Today! A targeted communications campaign to increase use of the cancer information service by African American smokers. Prev Med. Sep. 1998;27(5:Pt 2):S50-S60. [pmid: 9808824].
Brant J M, Fallsdown D, Iverson M L. The evolution of a breast health program for Plains Indian women. Oncol Nurs Forum. May. 1999;26(4):731-9. [pmid: 10337651].
Brazdova Z, Fiala J, Bauerova J, et al. Dietary guidelines in the Czech Republic II.: Nutritional profiles of food groups. Cent Eur J Public Health. 2000;8(4):216-20. [pmid: 11125974].
Breitbart W, Rosenfeld B, Passik S D. The Network Project: a multidisciplinary cancer education and training program in pain management, rehabilitation, and psychosocial issues. J Pain Symptom Manage. Jan. 1998;15(1):18-26. [pmid: 9436338].
Brigham J, Gross J, Stitzer M L, et al. Effects of a restricted work-site smoking policy on employees who smoke. Am J Public Health. May. 1994;84(5):773-8. [pmid: 8179047]. [pmcid: 1615061].
Briley M E, Montgomery D H, Blewett J. Dietary intakes of police department employees in a wellness program. J Am Diet Assoc. Jan. 1990;90(1):65-8. [pmid: 2295760].
Briley M E, Montgomery D H, Blewett J. Worksite nutrition education can lower total cholesterol levels and promote weight loss among police department employees. J Am Diet Assoc. Nov. 1992;92(11):1382-4. [pmid: 1430725].
Brink S G, Basen-Engquist K M, O'Hara-Tompkins N M, et al. Diffusion of an effective tobacco prevention program. Part I: Evaluation of the dissemination phase. Health Educ Res. Sep. 1995;10(3):283-95. [pmid: 10158026].
Briss P A, Zaza S, Pappaioanou M, et al. Developing an evidence-based Guide to Community Preventive Services-- methods. The Task Force on Community Preventive Services. Am J Prev Med. Jan. 2000;18(1 Suppl):35-43. [pmid: 10806978].
Britt J, Curry S J, McBride C, et al. Implementation and acceptance of outreach telephone counseling for smoking cessation with nonvolunteer smokers. Health Educ Q. 1994;21(1):55-68. [pmid: 8188493].
Brotons C, Iglesias M, Martin-Zurro A, et al. Evaluation of preventive and health promotion activities in 166 primary care practices in Spain. Fam Pract. 1996;13(2):144-51. [pmid: 8732325].
Browman GP, Snider A, Ellis P. The Healthcare Manager as Catalyst for Evidence-based Practice: Changing the Healthcare Environment and Sharing Experience. [In Press] 2002.
Brown K M, Bryant C A, Forthofer M S, et al. Florida Cares for Women social marketing campaign: A case study. Am J Health Behav. Jan. 2000;24(1):44-52.
Brown L, Rosner B, Willett W W, et al. Cholesterol-lowering effects of dietary fiber: A meta-analysis. Am J Clin Nutr. 1999;69(1):30-42. [pmid: 9925120].
Bruce A P E. The implementation of dietary guidelines. Am J Clin Nutr. 1987;45(Suppl 5):1378-82. [pmid: 3578125].
Brug J, Steenhuis I, van Assema P, et al. The impact of a computer-tailored nutrition intervention. Prev Med. May. 1996;25(3):236-42. [pmid: 8781000].
Brug J, Glanz K, van Assema P, et al. The impact of computer-tailored feedback and iterative feedback on fat, fruit, and vegetable intake. Health Educ Behav. Aug. 1998;25(4):517-31. [pmid: 9690108].
Brug J, Campbell M, van Assema P. The application and impact of computer-generated personalized nutrition education: A review of the literature. Patient Educ Couns. 1999;36(2):145-56. [pmid: 10223019].
Brunner E, White I, Thorogood M, et al. Can dietary interventions change diet and cardiovascular risk factors? A meta-analysis of randomized controlled trials. Am J Public Health. Sep. 1997;87(9):1415-22. [pmid: 9314790]. [pmcid: 1380963].
Bryant H. Breast cancer screening in Canada: climbing the diffusion curve. Can J Public Health. Nov. 1996;87(Suppl 2):S60-2. [pmid: 9002347].
Buller D, Buller M K, Larkey L, et al. Implementing a 5-a-day peer health educator program for public sector labor and trades employees. Health Educ Behav. Apr. 2000;27(2):232-40. [pmid: 10768804].
Buller D B, Morrill C, Taren D, et al. Randomized trial testing the effect of peer education at increasing fruit and vegetable intake (Study A). J Natl Cancer Inst. Sep 1. 1999;91(17):1491-500. [pmid: 10469751].
Buller D B, Morrill C, Taren D, et al. Randomized trial testing the effect of peer education at increasing fruit and vegetable intake (Study B). J Natl Cancer Inst. Sep 1. 1999;91(17):1491-500. [pmid: 10469751].
Buller D B, Woodall W G, Zimmerman D E, et al. Formative research activities to provide Web-based nutrition education to adults in the Upper Rio Grande Valley. Fam Community Health. Oct. 2001;24(3):1-12. [pmid: 11563940].
Bush N E, Wooldridge J, Foster V, et al. Web site design and development issues: the Washington State Breast and Cervical Health Program Web Site Demonstration Project. Oncol Nurs Forum. Jun. 1999;26(5):857-65. [pmid: 10382184].
Butrum R R, Clifford C K, Lanza E. NCI dietary guidelines: rationale. Am J Clin Nutr. Sep. 1988;48(Suppl 3):888-95. [pmid: 3046317].
Buxton T, Pfeffer J. The Healthy People Project: Reducing the risk of heart disease in Maryland. J Public Health Policy. 1987;8(4):475-91. [pmid: 3429666].
Cameron R, Brown K S, Best J A. The dissemination of chronic disease prevention programs: linking science and practice. Can J Public Health. Nov. 1996;87(Suppl 2):S50-S53. [pmid: 9002344].
Campbell H S, Macdonald J M. Tobacco counselling among Alberta dentists. J Can Dent Assoc. Mar. 1994;60(3):218-20. [pmid: 8156460].
Campbell H S, Sletten M, Petty T. Patient perceptions of tobacco cessation services in dental offices. J Am Dental Assoc. Feb. 1999;130(2):219-26.
Campbell M K, DeVellis B M, Strecher V J, et al. Improving dietary behavior: the effectiveness of tailored messages in primary care settings. Am J Public Health. May. 1994;84(5):783-7. [pmid: 8179049]. [pmcid: 1615043].
Campbell N R C, Burgess E, Choi B C K, et al. Methods and an overview of the Canadian recommendations. CMAJ. 1999;160(Suppl 9):S1-S6. [pmcid: 305325]. [pmid: 10333847].
Canadian Task Force on the Periodic Health Examination. The periodic health examination. Canadian Task Force on the Periodic Health Examination. CMAJ. Nov 3. 1979;121(9):1193-254. [pmid: 115569]. [pmcid: 1704686].
Carney J K, Ewing J F, Finley C A. Progress in breast cancer screening: Vermont's efforts. J Public Health Manage Practice. 1996;2(2):57-63.
Carney P A, Dietrich A J, Freeman D H Jr, et al. A standardized-patient assessment of a continuing medical education program to improve physicians' cancer-control clinical skills. Acad Med. Jan. 1995;70(1):52-8. [pmid: 7826445].
Carroll D, Seers K. Relaxation for the relief of chronic pain: a systematic review. J Adv Nurs. Mar. 1998;27(3):476-87. [pmid: 9543032].
Carter A P, Thompson R S, Bourdeau R V, et al. A clinically effective breast cancer screening program can be cost-effective, too. Prev Med. Jan. 1987;16(1):19-34. [pmid: 3103118].
Castro FG, Elder J, Coe K, et al. Mobilizing churches for health promotion in Latino communities: Companeros en la Salud. J Natl Cancer Inst Monographs 1995;(18):127–35.
Cavalcante A A, Pinheiro L M, Monte C, et al. Treatment of malnutrition in Brazil: simple solutions to common problems. Trop Doct. Apr. 1998;28(2):95-7. [pmid: 9594678].
Chalmers K, Bramadat I J, Cantin B, et al. A smoking reduction and cessation program with registered nurses: findings and implications for community health nursing. J Commun Health Nurs. 2001;18(2):115-34.
Chambers C V, Balaban D J, Carlson B L, et al. Microcomputer-generated reminders. Improving the compliance of primary care physicians with mammography screening guidelines. J Fam Pract. Sep. 1989;29(3):273-80. [pmid: 2769192].
Chapman S, Borland R, Scollo M, et al. The impact of smoke-free workplaces on declining cigarette consumption in Australia and the United States. Am J Public Health. Jul. 1999;89(7):1018-23. [pmid: 10394309]. [pmcid: 1508862].
Chelf J H, Agre P, Axelrod A, et al. Cancer-related patient education: an overview of the last decade of evaluation and research. Oncol Nurs Forum. Aug. 2001;28(7):1139-47. [pmid: 11517847].
Ciliska D, Hayward S, Thomas H, et al. A systematic overview of the effectiveness of home visiting as a delivery strategy for public health nursing interventions. Can J Public Health. 1996;87(3):193-8. [pmid: 8771925].
Ciliska D, Thompson O'Brien MA, Turl C et al. The effectiveness of community interventions to improve consumption of fruits and vegetables in people four years of age and older. Effective Public Health Practice Project: Public Health Branch, Ontario Ministry of Health; 1999.
Ciliska D, Miles E, Thompson O'Brien M A, et al. Effectiveness of community-based interventions to increase fruit and vegetable consumption. J Nutr Educ. Nov. 2000;32(6):341-52.
Clarke M, Oxman AD. Cochrane Reviewers' Handbook 4.1.5 [updated April 2002]. In: The Cochrane Library, 2002. Issue 2. Oxford: Update Software. Updated quarterly
Clarke, R. A Primer in Diffusion of Innovations Theory. Internet. http://www.anu.edu.au/people/Roger.Clarke/SOS/InnDiff.html
Cockburn J, Ruth D, Silagy C, et al. Randomised trial of three approaches for marketing smoking cessation programmes to Australian general practitioners. BMJ. Mar 14. 1992;304(6828):691-4. [pmid: 1571645]. [pmcid: 1881508].
Cohen M M, Roos N P, MacWilliam L, et al. Assessing physicians' compliance with guidelines for Papanicolaou testing. Med Care. Jun. 1992;30(6):514-28. [pmid: 1593917].
Cohen S J. Implementing smoking cessation protocols in medical and dental practices. Tob Control. 1997;6(Suppl 1):S24-S26. [pmid: 9396116].
Colditz G A, Atwood K A, Emmons K, et al. Harvard report on cancer prevention volume 4: Harvard Cancer Risk Index. Risk Index Working Group, Harvard Center for Cancer Prevention. Cancer Causes Control. Jul. 2000;11(6):477-88. [pmid: 10880030].
Colditz G A, Samplin-Salgado M, Ryan C T, et al. Harvard report on cancer prevention, volume 5: fulfilling the potential for cancer prevention: policy approaches. Cancer Causes Control. Apr. 2002;13(3):199-212. [pmid: 12020101].
Coleman E A, Lord J E, Bowie M, et al. A statewide breast cancer screening project. Cancer Nurs. Oct. 1993;16(5):347-53. [pmid: 8261382].
Coleman M P, Law M. Prevention of cancer: review of the evidence from intervention trials. IARC Scientific Publications (Lyon). 1990;103:113-22.
Comley A L, DeMeyer E. Assessing patient satisfaction with pain management through a continuous quality improvement effort. J Pain Symptom Manage. 2001;21(1):27-40. [pmid: 11223312].
Conte P M, Walco G A, Sterling C M, et al. Procedural pain management in pediatric oncology: A review of the literature. Cancer Invest. 1999;17(6):448-59. [pmid: 10434956].
Contento I, Balch G I, Bronner Y L, et al. The effectiveness of nutrition education and implications for nutrition education policy, programs and research: a review of research. J Nutr Educ. 1995;27(6):277-422.
Cooksey K, Kohlmeier M, Plaisted C, et al. Getting nutrition education into medical schools: A computer-based approach. Am J Clin Nutr. 2000;72(3):868S-76S. [pmid: 10966915].
Copeman R C, Swannell R J, Pincus D F, et al. Utilization of the “Smokescreen” smoking-cessation programme by general practitioners and their patients. Med J Aust. Jul 17. 1989;151(2):83-7. [pmid: 2739612].
Corbett K, Thompson B, White N, et al. Process Evaluation in the Community Intervention Trial for Smoking Cessation (COMMIT). Int Q Community Educ. 1990;11(3):291-309.
Costanza M E, Zapka J G, Harris D R, et al. Impact of a physician intervention program to increase breast cancer screening. Cancer Epidemiol Biomarkers Prev. Nov. 1992;1(7):581-9. [pmid: 1302571].
Crim C. Clinical practice guidelines vs actual clinical practice : the asthma paradigm. Chest. Aug. 2000;118(2 Suppl):62S-4S. [pmid: 10940002].
Crockett S J. The family team approach to fitness: a proposal. Public Health Rep. Sep. 1987;102(5):546-51. [pmid: 3116587]. [pmcid: 1477887].
Crockett S J, Mullis R M, Perry C L. Parent nutrition education: a conceptual model. J Sch Health. Feb. 1988;58(2):53-7. [pmid: 3352225].
Crockett S J, Mullis R, Perry C L, et al. Parent education in youth-directed nutrition interventions. Prev Med. Jul. 1989;18(4):475-91. [pmid: 2678093].
Croft J B, Temple S P, Lankenau B, et al. Community intervention and trends in dietary fat consumption among black and white adults. J Am Diet Assoc. Nov. 1994;94(11):1284-90. [pmid: 7963173].
Cromwell J, Bartosch W J, Fiore M C, et al. Cost-effectiveness of the clinical practice recommendations in the AHCPR guideline for smoking cessation. Agency for Health Care Policy and Research. JAMA. Dec 3. 1997;278(21):1759-66. [pmid: 9388153].
Crooks C E, Kenney E, Elder J P, et al. Tobacco control activities of primary care physicians in California: Results of the statewide independent evaluation of primary health care providers. Eval Health Prof. 1993;16(3):311-21.
Cuckle H S, Van Vunakis H. The effectiveness of a postal smoking cessation ‘kit’. Community Med. Aug. 1984;6(3):210-5. [pmid: 6478779].
Cummings K M, Sciandra R, Davis S, et al. Response to anti-smoking campaign aimed at mothers with young children. Health Educ Res. 1989;4(4):429-37.
Cummings KM, Sciandra R, Davis S, et al. Results of an antismoking media campaign utilizing the Cancer Information Service. J Natl Cancer Inst Monographs 1993;(14):113–8.
Cummings S R, Coates T J, Richard R J, et al. Training physicians in counseling about smoking cessation. A randomized trial of the “Quit for Life” program. Ann Int Med. Apr 15. 1989;110(8):640-7. [pmid: 2930094].
Curry R H, Moen J B, Morris S J, et al. Community-directed cancer screening program. Cancer Pract. Jul. 1994;2(4):256-63. [pmid: 7858652].
Curry S J. Organizational interventions to encourage guideline implementation. Chest. Aug. 2000;118(Suppl 2):40S-6S. [pmid: 10939998].
Cutter J, Tan B Y, Chew S K. Levels of cardiovascular disease risk factors in Singapore following a national intervention programme. World Health Organ. 2001;79(10):908-15.
Cuzick J, Sasieni P, Davies P, et al. A systematic review of the role of human papillomavirus testing within a cervical screening programme. Health Technology Assessment (Winchester, England) 1999;3(14):i-iv
Dacey S. Tobacco cessation program implementation-from plans to reality: skill building workshop-group model. Tob Control. 2000;9(Suppl 1):i30-i32. [pmid: 10688928].
Dalton J A, Bernard S, Blau W, et al. Managing cancer pain: Content and scope of an educational program for nurses who work in predominantly rural areas. J Pain Symptom Manage. 1995;10(3):214-23. [pmid: 7629416].
Dalton J A, Blau W, Lindley C, et al. Changing acute pain management to improve patient outcomes: an educational approach. J Pain Symptom Manage. Apr. 1999;17(4):277-87. [pmid: 10203880].
Daudt A W, Alberg A J, Prola J C, et al. A first step incorporating smoking education into a Brazilian medical school curriculum: results of a survey to assess the cigarette smoking knowledge, attitudes, behaviour, and clinical practices of medical students. J Addict Dis. 1999;18(1):19-29. [pmid: 10234560].
Daughton D M, Andrews C E, Orona C P, et al. Total indoor smoking ban and smoker behavior. Prev Med. Sep. 1992;21(5):670-6. [pmid: 1438113].
Davey C, Austoker J, Jansen C. Improving written information for women about cervical screening: evidence-based criteria for the content of letters and leaflets. Health Educ J. Sep. 1998;57(3):263-81.
Davis D A, Thomson M A, Oxman A D, et al. Evidence for the effectiveness of CME. A review of 50 randomized controlled trials. JAMA. Sep 2. 1992;268(9):1111-7. [pmid: 1501333].
Davis D A, Thomson M A, Oxman A D, et al. Changing physician performance. A systematic review of the effect of continuing medical education strategies. JAMA. 1995;274(9):700-5. [pmid: 7650822].
Davis D A, Taylor-Vaisey A. Translating guidelines into practice. A systematic review of theoretic concepts, practical experience and research evidence in the adoption of clinical practice guidelines. Can Med Assoc J. 1997;157(4):408-16. [pmid: 9275952]. [pmcid: 1227916].
De Grasse C E, O'Connor A M, Boulet J, et al. Changes in Canadian women's mammography rates since the implementation of mass screening programs. Am J Public Health. Jun. 1999;89(6):927-9. [pmid: 10358690]. [pmcid: 1508655].
De Rond M E J, De Wit R, Van Dam F S A M, et al. A Pain Monitoring Program for nurses: Effects on nurses' pain knowledge and attitude. J Pain Symptom Manage. 2000;19(6):457-67. [pmid: 11131261].
De Rond M E J, De Wit R, Van Dam F S A M, et al. A pain monitoring program for nurses: Effects on communication, assessment and documentation of patients' pain. J Pain Symptom Manage. 2000;20(6):424-39. [pmid: 11131261].
Deming WE. Out of the crisis. Cambridge, MA: MIT Centre for Applied Engineering Studies; 1986.
Derose K P, Fox S A, Reigadas E, et al. Church-based telephone mammography counseling with peer counselors. J Health Communication. Apr. 2000;5(2):175-88.
Devine E C. Effects of psychoeducational care for adult surgical patients: a meta-analysis of 191 studies. Patient Educ Couns. Apr. 1992;19(2):129-42. [pmid: 1299818].
Devine E C, Westlake S K. The effects of psychoeducational care provided to adults with cancer: meta-analysis of 116 studies. Oncol Nurs Forum. Oct. 1995;22(9):1369-81. [pmid: 8539178].
DeWeese J. Best practices for smoking cessation intervention for hospitalized patients. Indiana Med. Mar. 1996;89(2):181-3. [pmid: 8867419].
Dhesy-Thind S K, Goffin J R, Cook R J, et al. Use of bisphosphonates in breast cancer metastatic to bone: compliance with practice guidelines. Curr Oncol. 2002;9(1):7-12.
Dhote R, Pellicer-Coeuret M, Thiounn N, et al. Risk factors for adult renal cell carcinoma: A systematic review and implications for prevention. Bju Int. 2000;86(1):20-7. [pmid: 10886077].
Di Tullio M, Belli C, Resnicow K, et al. Smoking cessation after myocardial infarction: A critical review of intervention strategies. Eur J Intern Med. 1993;4(1):9-14.
Dickey L L, Gemson D H, Carney P. Office system interventions supporting primary care-based health behavior change counseling. Am J Prev Med. 1999;17(4):299-308. [pmid: 10606199].
Dietrich A J, O'Connor G T, Keller A, et al. Cancer: improving early detection and prevention. A community practice randomised trial. BMJ. Mar 14. 1992;304(6828):687-91. [pmid: 1571644]. [pmcid: 1881551].
Dietrich A J, Sox C H, Tosteson T D, et al. Durability of improved physician early detection of cancer after conclusion of intervention support. Cancer Epidemiol Biomarkers Prev. Jun. 1994;3(4):335-40. [pmid: 8061583].
Dignan M, Bahnson J, Sharp P, et al. Implementation of mass media community health education: the Forsyth County Cervical Cancer Prevention Project. Health Educ Res. Sep. 1991;6(3):259-66. [pmid: 10148691].
Dignan M, Michielutte R, Wells H B, et al. The Forsyth County Cervical Cancer Prevention Project--I. Cervical cancer screening for black women. Health Educ Res. Dec. 1994;9(4):411-20. [pmid: 10150457].
Dignan M B, Beal P E, Michielutte R, et al. Development of a direct education workshop for cervical cancer prevention in high risk women: the Forsyth County project. J Cancer Educ. 1990;5(4):217-23. [pmid: 2132805].
Dixon H, Borland R, Segan C, et al. Public reaction to Victoria's “2 Fruit ‘n’ 5 Veg Every Day” campaign and reported consumption of fruit and vegetables. Prev Med. Jul. 1998;27(4):572-82. [pmid: 9672951].
Dobbins M, Ciliska D, Cockerill R, et al. A framework for the dissemination and utilization of research for health care policy and practice. Online J Knowledge Synthesis Nurs 2002;9(in press):
Dodds M E, Dowd S L, Mitchell-Beren M, et al. A breast cancer screening program in a community hospital. J Community Health. Oct. 1991;16(5):241-9. [pmid: 1955575].
Doll R, Peto R. The causes of cancer: quantitative estimates of avoidable risks of cancer in the United States today. J Natl Cancer Inst. Jun. 1981;66(6):1191-308. [pmid: 7017215].
Donahue A H. Women's health: a national plan for action. J Dent Educ. Oct. 1993;57(10):738-41. [pmid: 8408889].
Dowse G K, Gareeboo H, Alberti K G M M, et al. Changes in population cholesterol concentrations and other cardiovascular risk factor levels after five years of the non-communicable disease intervention programme in Mauritius. BMJ. 1995;311(7015):1255-9. [pmid: 7496233].
Doxiadis S A, Trihopoulos D V, Phylactou H D. Impact of a nationwide anti-smoking campaign. Lancet. Sep 28. 1985;2(8457):712-3. [pmid: 2863689].
Du Pen A R, Du P S, Hansberry J, et al. An educational implementation of a cancer pain algorithm for ambulatory care. Pain Manage Nurs. Dec. 2000;1(4):116-28.
Du Pen S L, Du Pen A R, Polissar N, et al. Implementing guidelines for cancer pain management: results of a randomized controlled clinical trial. J Clin Oncol. Jan. 1999;17(1):361-70. [pmid: 10458255].
Dunbar J A, Vincent D S, Dunbar A P, et al. Implementing the North Karelia Project in Scotland. Scott Med J. Aug. 1998;43(4):99-101. [pmid: 9757494].
Dunn C, Deroo L, Rivara F P. The use of brief interventions adapted from motivational interviewing across behavioral domains: A systematic review. Addiction. 2001;96(12):1725-42. [pmid: 11784466].
Dusseldorp E, Van Elderen T, Maes S, et al. A meta-analysis of psychoeducational programs for coronary heart disease patients. Health Psychol. 1999;18(5):506-19. [pmid: 10519467].
Dwyer T, Pierce J P, Hannam C D, et al. Evaluation of the Sydney “Quit. For Life” anti-smoking campaign. Part 2. Changes in smoking prevalence. Med J Aust. Mar 31. 1986;144(7):344-7. [pmid: 3485760].
Eakin E G, Lichtenstein E, Severson H H, et al. Use of tailored videos in primary care smoking cessation interventions. Health Educ Res. 1998;13(4):519-27.
Earp J A, Altpeter M, Mayne L, et al. The North Carolina Breast Cancer Screening Program: foundations and design of a model for reaching older, minority, rural women. Breast Cancer Res Treat. Jul. 1995;35(1):7-22. [pmid: 7612907].
Ebrahim S, Smith G D. Systematic review of randomised controlled trials of multiple risk factor interventions for preventing coronary heart disease. BMJ. Jun 7. 1997;314(7095):1666-74. [pmid: 9193292]. [pmcid: 2126863].
Ebrahim S, Davey S G, Gulckman R. In people with no evidence of cardiovascular disease, how effective are interventions aimed at controlling risk factors in reducing all-cause and coronary artery disease mortality?. West J Med. 2000;173(3):185-6. [pmid: 10986185]. [pmcid: 1071062].
Edwards B K, Howe H L, Ries L A G, et al. Communication: Annual report to the Nation on the status of cancer, 1973-1999, featuring implications of age and ageing on U.S. cancer burden. Cancer. 2002;94(10):2766-92. [pmid: 12173348].
Egger G, Fitzgerald W, Frape G, et al. Results of large scale media antismoking campaign in Australia: North Coast “Quit for Life” programme. Br Med J (Clin Res Ed ). Oct 15. 1983;287(6399):1125-8. [pmid: 6414597].
Egsmose T. The tobacco problem in Denmark and the difficulties in implementing an organized plan of action. Tokai J Exp Clin Med. Aug. 1985;10(4):457-63. [pmid: 3836528].
Ehrich B, Clark M, Rakowski W, et al. Implementing a computer-based mammography education project in a managed care setting. Med Health R I. Mar. 1998;81(3):79-82. [pmid: 9560557].
Elder J P, Campbell N R, Mielchen S D, et al. Implementation and evaluation of a community-sponsored smoking cessation contest. Am J Health Promot. Jan. 1991;5(3):200-7. [pmid: 10148669].
Elder J P, Edwards C C, Conway T L, et al. Independent evaluation of the California Tobacco Education Program. Public Health Rep. Jul. 1996;111(4):353-8. [pmid: 8711104]. [pmcid: 1381881].
Elder J P, Ayala G X, Harris S. Theories and intervention approaches to health-behavior change in primary care. Am J Prev Med. Nov. 1999;17(4):275-84. [pmid: 10606196].
Elliott B A, Johnson K M, Elliott T E, et al. Enhancing Cancer Pain Control among American Indians (ECPCAI): a study of the Ojibwe of Minnesota. J Cancer Educ. 1999;14(1):28-33. [pmid: 10328321].
Emmons K M, Linnan L A, Shadel W G, et al. The Working Healthy Project: a worksite health-promotion trial targeting physical activity, diet, and smoking. J Occup Environ Med. Jul. 1999;41(7):545-55. [pmid: 10412096].
Emont S L, Cummings K M. Adoption of smoking policies by automobile dealerships. Public Health Rep. Sep. 1989;104(5):509-14. [pmid: 2508181]. [pmcid: 1579966].
Eng E. The Save Our Sisters Project: A social network strategy for reaching rural black women. Cancer. 1993;72(Suppl 3):1071-7. [pmid: 8334660].
Engstrom P F. A new era for cancer prevention and control research. Cancer Epidemiol Biomarkers Prev. Nov. 1999;8(11):955-6. [pmid: 10566548].
Epps R P, Manley M W, Husten C G, et al. Transfer of preventive health programs to physicians' practices through medical organizations. Am J Prev Med. Jan. 1998;14(1):25-30. [pmid: 9476833].
Erfurt J C, Foote A, Heirich M A, et al. Improving participation in worksite wellness programs: Comparing health education classes, a menu approach, and follow-up counseling. Am J Health Promot. 1990;4(4):270-8.
Eriksen M P, Gottlieb N H. A review of the health impact of smoking control at the workplace. Am J Health Promot. Nov. 1998;13(2):83-104. [pmid: 10346662].
Etter J F, Ronchi A, Perneger T. Short-term impact of a university based smoke free campaign. J Epidemiol Commun Health. Nov. 1999;53(11):710-5.
Evans S A, Henderson A. The smoke-free policies of Lanarkshire general practices. Health Bull. Mar. 1996;54(2):126-30.
Fahs M C, Plichta S B, Mandelblatt J S. Cost-effective policies for cervical cancer screening: An international review. Pharmacoeconomics. 1996;9(3):211-30. [pmid: 10160098].
Farquhar J W. The case for dissemination research in health promotion and disease prevention. Can J Public Health. Nov. 1996;87(Suppl 2):S44-S49. [pmid: 9002343].
Farrelly MC, Pechancek TF, Chaloupka FJ. The impact of tobacco control program expenditures on aggregate cigarette sales: 1981-1998. 8691. Cambridge, MA: National Bureau of Economic Research; 2001.
Fawzy F I, Fawzy N W, Arndt L A, et al. Critical review of psychosocial interventions in cancer care. Arch Gen Psychiatry. 1995;52(2):100-13. [pmid: 7848046].
Feldman E B, Kuske T T. Why, what, and how to implement reduction of cardiovascular risk factors by diet. J Am Coll Nutr. 1987;6(6):475-84. [pmid: 3320154].
Fernandez M E, Debor M, Candreia M J, et al. Evaluation of ENCOREplus. A community-based breast and cervical cancer screening program. Am J Prev Med. Apr. 1999;16(Suppl 3):35-49. [pmid: 10198679].
Ferrell B R, Rhiner M, Ferrell B A. Development and implementation of a pain education program. Cancer. 1993;72(Suppl 11):3426-32. [pmid: 8242574].
Ferrence R. Using diffusion theory in health promotion: the case of tobacco. Can J Public Health. Nov. 1996;87(Suppl 2):S24-S27. [pmid: 9002339].
Ferry L H, Grissino L M, Runfola P S. Tobacco dependence curricula in US undergraduate medical education. JAMA. Sep 1. 1999;282(9):825-9. [pmid: 10478687].
Fichtenberg C M, Glantz S A. Association of the California Tobacco Control Program with declines in cigarette consumption and mortality from heart disease. N Engl J Med. Dec 14. 2000;343(24):1772-7. [pmid: 11114317].
Fiore MC, Bayley WC, Cohen SJ et al. Smoking cessation: information for specialists. Agency for Health Care Policy and Research. No. 18. Rockville, MD: U.S. Department of Health and Human Services, Public Health Service, Agency for Health Care Policy and Research and Centers for Disease Control and Prevention; 1996 Apr. AHCPR Publication N. 96-0694.
Fiore MC, Bailey WC, Cohen SJ et al. Smoking Cessation: Clinical Practice Guideline. Clinical Practice Guideline, No. 18. Washington DC: U.S.Department of Health and Human Services, Agency for Health Care Policy and Research; 1996. 96-0692.
Fiore M C. AHCPR smoking cessation guideline: a fundamental review. Tob Control. 1997;6(Suppl):S4-S8. [pmid: 9396115].
Fiore M C, Jorenby D E, Baker T B. Smoking cessation: principles and practice based upon the AHCPR Guideline, 1996. Agency for Health Care Policy and Research. Ann Behav Med. 1997;19(3):213-9. [pmid: 9603696].
Fiore M C, Bailey W C, Cohen S J, et al. Quick Reference Guide for Smoking Cessation Specialists, Number 18, Smoking Cessation Information for Specialists. J Pharmacoepidemiol. 1999;7(1):11-41.
Fiore M C. US public health service clinical practice guideline: treating tobacco use and dependence. Respir Care. Oct. 2000;45(10):1200-62. [pmid: 11054899].
Fiore MC, Bailey WC, Cohen SJ, et al. Treating tobacco use and dependence. Clinical Practice Guideline. Rockville, MD: U.S.Department of Health and Human Services: Public Health Service; 2000.
Fischer L R, Solberg L I, Kottke T E, et al. A process IMPROVEment approach to preventive services: case studies of CQI demonstration projects in two primary care clinics. HMO Pract. Sep. 1997;11(3):123-9. [pmid: 10174521].
Fishbein M, Azjen I. Beliefs, attitudes, intention and behavior: an introduction to theory and research. Reading, MA: Addison-Wesley; 1975.
Fisher E B, Auslander W F, Munro J F, et al. Neighbors for a smoke free north side: evaluation of a community organization approach to promoting smoking cessation among African Americans. Am J Public Health. Nov. 1998;88(11):1658-63. [pmid: 9807532]. [pmcid: 1508568].
Fisher E B Jr, Bishop D B, Levitt-Gilmour T, et al. Social support in worksite smoking cessation: qualitative analysis of the EASE project. Am J Health Promot. Sep. 1994;9(1):39-47. [pmid: 10147494].
Fisher K J, Glasgow R E, Terborg J R. Work site smoking cessation: a meta-analysis of long-term quit rates from controlled studies. J Occup Med. May. 1990;32(5):429-39. [pmid: 2348259].
Fishman J A, Allison H, Knowles S B, et al. State laws on tobacco control--United States, 1998. MMWR - SS. Jun 25. 1999;48(3):21-40.
Flay B R. Efficacy and effectiveness trials (and other phases of research) in the development of health promotion programs. Prev Med. Sep. 1986;15(5):451-74. [pmid: 3534875].
Flay B R. Mass media and smoking cessation: a critical review. Am J Public Health. Feb. 1987;77(2):153-60. [pmid: 3541650]. [pmcid: 1646843].
Flay B R, Gruder C L, Warnecke R B, et al. One year follow-up of the Chicago televised smoking cessation program. Am J Public Health. Oct. 1989;79(10):1377-80. [pmid: 2782506]. [pmcid: 1350178].
Flay B R, McFall S, Burton D, et al. Health behavior changes through television: the roles of de facto and motivated selection processes. J Health Soc Behav. Dec. 1993;34(4):322-35. [pmid: 8034949].
Foerster S B, Kizer K W, Disogra L K, et al. California's “5 a day--for better health!” campaign: an innovative population-based effort to effect large-scale dietary change. Am J Prev Med. Mar. 1995;11(2):124-31. [pmid: 7632448].
Foley R M, Pollard C M. Food Cent$ - Implementing and evaluating a nutrition education project focusing on value for money. Aust N Z J Public Health. 1998;22(4):494-501. [pmid: 9659779].
Ford M, Martin R D, Hilton L W, et al. Outcomes study of a course in breast-cancer screening. J Cancer Educ. 1997;12(3):179-84. [pmid: 9376257].
Forster J L, McBride C, Jeffery R, et al. Support for restrictive tobacco policies among residents of selected Minnesota communities. Am J Health Promot. Nov. 1991;6(2):99-104. [pmid: 10148683].
Fowler G, Mant D, Fuller A, et al. The “Help Your Patient Stop” initiative. Evaluation of smoking prevalence and dissemination of WHO/UICC guidelines in UK general practice. Lancet. Jun 3. 1989;1(8649):1253-5. [pmid: 2566792].
Fox R, Mazmanian P, Putnam RW. Changing and learning in the lives of physicians. New York: Praeger; 1989.
Fox S A, Stein J A, Sockloskie R J, et al. Targeted mailed materials and the Medicare beneficiary: increasing mammogram screening among the elderly. Am J Public Health. Jan. 2001;91(1):55-61. [pmid: 11189826]. [pmcid: 1446510].
Fracheboud J, de Koning H J, Beemsterboer P M, et al. Nation-wide breast cancer screening in The Netherlands: results of initial and subsequent screening 1990-1995. National Evaluation Team for Breast Cancer Screening. Int J Cancer. Mar 2. 1998;75(5):694-8. [pmid: 9495236].
Frame P S, Zimmer J G, Werth P L, et al. Computer-based vs manual health maintenance tracking. A controlled trial. Arch Fam Med. Jul. 1994;3(7):581-8. [pmid: 7921293].
France E K, Glasgow R E, Marcus A C. Smoking cessation interventions among hospitalized patients: what have we learned?. Prev Med. Apr. 2001;32(4):376-88. [pmid: 11304099].
Freels S A, Warnecke R B, Parsons J A, et al. Characteristics associated with exposure to and participation in a televised smoking cessation intervention program for women with high school or less education. Prev Med. Jun. 1999;28(6):579-88. [pmid: 10404556].
Freels S A, Warnecke R B, Johnson T P, et al. Evaluation of the effects of a smoking cessation intervention using the multilevel thresholds of change model. Eval Rev. Feb. 2002;26(1):40-58. [pmid: 11840638].
Freemantle N, Watt I. Dissemination: implementing the findings of research. Health Libr Rev. Jun. 1994;11(2):133-7. [pmid: 10136651].
Freemantle N, Grilli R, Grimshaw J, et al. Implementing findings of medical research: the Cochrane Collaboration on Effective Professional Practice. Qual Health Care. Mar. 1995;4(1):45-7. [pmid: 10142035].
Freemantle N, Harvey EL, Wolf F, et al. Printed educational materials: effects on professional practice and health care outcomes (Cochrane Review). In: The Cochrane Library, 2001. Issue 3. Oxford: Update Software.
Friedell G H, Linville L H, Sorrell C L, et al. Breast cancer action plan for Kentucky. J Ky Med Assoc. Oct. 2001;99(10):437-44. [pmid: 11668903].
Friend K, Levy D T. Smoking treatment interventions and policies to promote their use: A critical review. Nicotine Tobacco Res. 2001;3(4):299-310.
Frost C. Implications of smoking bans in the workplace. A nursing perspective. AAOHN Journal. Jun. 1991;39(6):270-5. [pmid: 2031648].
Garner P, Kale R, Dickson R, et al. Getting research findings into practice: implementing research findings in developing countries. BMJ. Aug 22. 1998;317(7157):531-5. [pmid: 9712608].
Gaston M H, Moody L E. Improving utilization of breast and cervical cancer screening in your office practice. J Natl Med Assoc. Sep. 1995;87(9):700-4. [pmid: 9583967].
Gauen S E, Lee N L. Pharmacists' role in a smoking-cessation program at a managed health care organization. Am J Health Syst Pharm. Feb 1. 1995;52(3):294-6. [pmid: 7749957].
Gebhardt W A, Maes S. Integrating social-psychological frameworks for health behavior research. Am J Health Behav. Nov. 2001;25(6):528-36. [pmid: 11720300].
Gelskey S C. Tobacco-use cessation programs and policies at the University of Manitoba's faculty of dentistry. J Can Dent Assoc. Mar. 2001;67(3):145-8. [pmid: 11315393].
George S A. Barriers to breast cancer screening: an integrative review. Health Care Women Intern. Jan. 2000;21(1):53-65.
Gillis C R, Hole D J. Survival outcome of care by specialist surgeons in breast cancer: a study of 3786 patients in the west of Scotland. BMJ. Jan 20. 1996;312(7024):145-8. [pmid: 8563532].
Gingiss P L, Gottlieb N H, Brink S G. Increasing teacher receptivity toward use of tobacco prevention education programs. J Drug Educ. 1994;24(2):163-76. [pmid: 7931926].
Glajchen M. Chronic pain: treatment barriers and strategies for clinical practice. J Am Board Fam Pract. May. 2001;14(3):211-8. [pmid: 11355054].
Glanville J, Haines M, Auston I. Finding information on clinical effectiveness. BMJ. Jul 18. 1998;317(7152):200-3. [pmid: 9665910]. [pmcid: 28661].
Glanz K, Gilboy M B. Physicians, preventive care, and applied nutrition: selected literature. Acad Med. Nov. 1992;67(11):776-81. [pmid: 1418261].
Glanz K. Reducing breast cancer risk through changes in diet and alcohol intake: from clinic to community. Ann Behav Med. 1994;16(4):334-46.
Glanz K, Sorensen G, Farmer A. The health impact of worksite nutrition and cholesterol intervention programs. Am J Health Promot. Jul. 1996;10(6):453-70. [pmid: 10163311].
Glanz K. Behavioral research contributions and needs in cancer prevention and control: dietary change. Prev Med. Sep. 1997;26(5 Pt 2):S43-S55. [pmid: 9327492].
Glasgow R E, Hollis J F, McRae S G, et al. Providing an integrated program of low intensity tobacco cessation services in a health maintenance organization. Health Educ Res. Mar. 1991;6(1):87-9. [pmid: 10148728].
Glasgow R E, Hollis J F, Pettigrew L, et al. Implementing a year-long, worksite-based incentive program for smoking cessation. Am J Health Promot. Jan. 1991;5(3):192-9. [pmid: 10148668].
Glasgow R E, Treborg J R, Hollis J F, et al. Modifying dietary and tobacco use patterns in the worksite: The Take Heart Project. Health Educ Q. 1994;21(1):69-82. [pmid: 8188494].
Glasgow R E, Lichtenstein E, Wilder D, et al. The tribal tobacco policy project: working with Northwest Indian tribes on smoking policies. Prev Med. Sep. 1995;24(5):434-40. [pmid: 8524716].
Glasgow R E, Terborg J R, Hollis J F, et al. Take Heart: results from the initial phase of a work-site wellness program. Am J Public Health. Feb. 1995;85(2):209-16. [pmid: 7856780]. [pmcid: 1615302].
Glasgow R E, Vogt T M, Boles S M. Evaluating the public health impact of health promotion interventions: the RE-AIM framework. Am J Public Health. Sep. 1999;89(9):1322-7. [pmid: 10474547]. [pmcid: 1508772].
Glasgow R E, McKay H G, Piette J D, et al. The RE-AIM framework for evaluating interventions: what can it tell us about approaches to chronic illness management?. Patient Educ Couns. Aug. 2001;44(2):119-27. [pmid: 11479052].
Glasgow R E, Bull S S, Gillette C, et al. Behavior change intervention research in healthcare settings. A review of recent reports with emphasis on external validity. Am J Prev Med. Jul. 2002;23(1):62-9. [pmid: 12093425].
Gloth F M III. Pain management in older adults: Prevention and treatment. J Am Geriatr Soc. 2001;49(2):188-99. [pmid: 11207874].
Glynn T J, Cullen J W. Health promotion through smoking prevention and cessation - the need for a selective research agenda. Health Educ Res. 1989;4(1):5-11.
Glynn T J, Boyd G M, Gruman J C. Essential elements of self-help/minimal intervention strategies for smoking cessation. Health Educ Q. 1990;17(3):329-45. [pmid: 2228634].
Gold J A, Kloepfel E, Spurlin D. Nurse adoption campaign promotes mammography. WMJ. Nov. 1999;98(7):56-7. [pmid: 10638294].
Goldberg G, Robinson F, Kelly C. The dissemination and discussion of EU-funded food and nutrition research: Update on progress of FLAIR-FLOW 4. Nutr Bull. 2001;26(2):175-7.
Goldberg T H, Chavin S I. Preventive medicine and screening in older adults. J Am Geriatr Soc. Mar. 1997;45(3):344-54. [pmid: 9063282].
Goldstein A O, Westbrook W R, Howell R E, et al. Hospital efforts in smoking control: remaining barriers and challenges. J Fam Pract. Jun. 1992;34(6):729-34. [pmid: 1593247].
Gomel M, Oldenburg B, Simpson J M, et al. Work-site cardiovascular risk reduction: a randomized trial of health risk assessment, education, counseling, and incentives. Am J Public Health. Sep. 1993;83(9):1231-8. [pmid: 8362997]. [pmcid: 1694995].
Goodin M, McAllister I. Evaluating compliance with Australia's first smoke-free public places legislation. Tob Control. 1997;6(4):326-31. [pmid: 9583631].
Goodson P, Murphy S M, Evans A, et al. Maintaining prevention in practice: survival of PPIP in primary care settings. Put Prevention Into Practice. Am J Prev Med. Apr. 2001;20(3):184-9. [pmid: 11275444].
Goodwin M A, Zyzanski S J, Zronek S, et al. A clinical trial of tailored office systems for preventive service delivery. The Study to Enhance Prevention by Understanding Practice (STEP-UP). Am J Prev Med. Jul. 2001;21(1):20-8. [pmid: 11418253].
Gorelick P B, Sacco R L, Smith D B, et al. Prevention of a first stroke: A review of guidelines and a multidisciplinary consensus statement from the National Stroke Association. JAMA. 1999;281(12):1112-20. [pmid: 10188663].
Gottlieb N H, Huang P P, Blozis S A, et al. The impact of Put Prevention into Practice on selected clinical preventive services in five Texas sites. Am J Prev Med. 2001;21(1):35-40. [pmid: 11418255].
Gotzsche P C, Olsen O. Is screening for breast cancer with mammography justifiable?. Lancet. Jan 8. 2000;355(9198):129-34. [pmid: 10675181].
Granados A, Jonsson E, Banta H D, et al. EUR-ASSESS Project Subgroup Report on Dissemination and Impact. Int J Technol Assess Health Care. 1997;13(2):220-86. [pmid: 9194353].
Grant M, Rivera L M, Alisangco J, et al. Improving cancer pain management using a performance improvement framework. J Nurs Care Qual. Apr. 1999;13(4):60-72. [pmid: 10330791].
Grant M, Golant M, Rivera L, et al. Developing a community program on cancer pain and fatigue. Cancer Pract. 2000;8(4):187-94. [pmid: 11898258].
Gray C H, Colome J S, Curry-Daly J R. Elective cancer education: How effective from the public health viewpoint?. Am J Public Health. 1987;77(9):1207-9. [pmid: 3618856]. [pmcid: 1646997].
Gray R E, Greenberg M, Fitch M, et al. A strategy for informing patients and health professionals about unconventional cancer therapies. J Cancer Educ. 1998;13(1):31-8. [pmid: 9565859].
Gredler B, Kunze M. Impact of a national campaign on smoking attitudes and patterns in Austria. Int J Health Educ. 1981;24(4):271-9. [pmid: 7344374].
Green L, Kreuter M, Deeds S, et al. Health education planning: a diagnostic approach. Palo Alto: Mayfield, CA; 1980.
Green L W. What can we generalize from research on patient education and clinical health promotion to physician counseling on diet?. Eur J Clin Nutr. May. 1999;53(Suppl 2):S9-S18. [pmid: 10406430].
Greenwald P. New directions in cancer control. Johns Hopkins Med J. Nov. 1982;151(5):209-13. [pmid: 7143872].
Greenwald P, Cullen J W. The scientific approach to cancer control. CA Cancer J Clin. Nov. 1984;34(6):328-32. [pmid: 6437624].
Greer A L. The state of the art versus the state of the science. The diffusion of new medical technologies into practice. Int J Technol Assess Health Care. 1988;4(1):5-26. [pmid: 10287114].
Grilli R, Minozzi S, Tinazzi A, et al. Do specialists do it better? The impact of specialization on the processes and outcomes of care for cancer patients. Ann Oncol. 1998;9(4):365-74. [pmid: 9636826].
Grilli R, Freemantle N, Minozzi S, et al. Mass media interventions: effects on health services utilisation (Cochrane Review). In: The Cochrane Library, 2001. Issue 1. Oxford: Update Software.
Grimshaw J M, Shirran L, Thomas R, et al. Changing provider behavior: an overview of systematic reviews of interventions. Med Care. Aug. 2001;39 (8 Suppl 2):I12-45. [pmid: 11583120].
Gritz E R, Ward P H, Beumer J, et al. Increasing adherence to a provider-implemented smoking cessation intervention for head and neck cancer patients. Prog Clin Biol Res. 1990;339:83-93. [pmid: 2202999].
Grol R, Grimshaw J. Evidence-based implementation of evidence-based medicine. Jt Comm J Qual Improv. Oct. 1999;25(10):503-13. [pmid: 10522231].
Gross P A, Cataruozolo P, Mitofsky W, et al. Implementing preventive health measures: a pilot study. Clin Perform Qual Health Care. Apr. 1999;7(2):52-5. [pmid: 10747565].
Groth-Marnat G, Leslie S, Renneker M. Tobacco control in a traditional Fijian village: indigenous methods of smoking cessation and relapse prevention. Soc Sci Med. Aug. 1996;43(4):473-7. [pmid: 8844948].
Gruder C L, Warnecke R B, Jason L A, et al. A televised, self-help, cigarette smoking cessation intervention. Addict Behav. 1990;15(6):505-16. [pmid: 2075848].
Guadagnoli E, Weeks J C, Shapiro C L, et al. Use of breast-conserving surgery for treatment of stage I and stage II breast cancer. J Clin Oncol. Jan. 1998;16(1):101-6. [pmid: 9440729].
Guadagnoli E, Shapiro C L, Weeks J C, et al. The quality of care for treatment of early stage breast carcinoma: is it consistent with national guidelines?. Cancer. Jul 15. 1998;83(2):302-9. [pmid: 9669813].
Guest C, Griffith E, Lewis S Y, et al. Epidemiology and detection of cervical cancer. Implementing the national screening policy. Aust Fam Physician. Nov. 1996;25(11):1722-30. [pmid: 8952107].
Guthrie R M. The effects of postal and telephone reminders on compliance with pravastatin therapy in a national registry: results of the first myocardial infarction risk reduction program. Clin Ther. Jun. 2001;23(6):970-80. [pmid: 11440296].
Guzewich J J. Statewide implementation of a HACCP food service regulatory program. J Environ Health. 1986;49(3):148-52.
Hagen N, Young J, MacDonald N. Diffusion of standards of care for cancer pain. CMAJ. Apr 15. 1995;152(8):1205-9. [pmid: 7736371]. [pmcid: 1337808].
Haines A, Donald A. Making better use of research findings. BMJ. Jul 4. 1998;317(7150):72-5. [pmid: 9651281]. [pmcid: 28547].
Halpin S H, Mordavsky J K, McMenamin S. Adoption of the AHCPR Clinical Practice Guideline for Smoking Cessation: a survey of California's HMOs. Am J Prev Med. Oct. 2001;21(3):153-61. [pmid: 11567834].
Halverson P K, Mays G P, Rimer B K, et al. Adoption of a health education intervention for family members of breast cancer patients. Am J Prev Med. Apr. 2000;18(3):189-98. [pmid: 10722984].
Hancock L, Sanson-Fisher R W, Redman S, et al. Community action for health promotion: A review of methods and outcomes 1990-1995. Am J Prev Med. 1997;13(4):229-39. [pmid: 9236957].
Harrison R A, Waterbor J W. Understanding meta-analysis in cancer epidemiology: dietary fat and breast cancer. Cancer Detect Prev. 1999;23(2):97-106. [pmid: 10101590].
Harvey-Berino J, Ewing J F, Flynn B, et al. Statewide dissemination of a nutrition program: Show the Way to 5-a-Day. J Nutr Educ. Jan. 1998;30(1):29-36.
Harvey P W, Steele J, Bruggemann J N, et al. The development and evaluation of lighten up, an Australian community-based weight management program. Am J Health Promot. Sep. 1998;13(1):8-11. [pmid: 10186935].
Hasselblad V. Meta-analysis of multitreatment studies. Med Decis Making. Jan. 1998;18(1):37-43. [pmid: 9456207].
Havas S, Anliker J, Damron D, et al. Final results of the Maryland WIC 5-A-Day Promotion Program. Am J Public Health. Aug. 1998;88(8):1161-7. [pmid: 9702141]. [pmcid: 1508288].
Havas S, Treiman K, Langenberg P, et al. Factors associated with fruit and vegetable consumption among women participating in WIC. J Am Diet Assoc. Oct. 1998;98(10):1141-8. [pmid: 9787720].
Hawkins R J, Wang E E, Leake J L. Preventive health care, 1999 update: prevention of oral cancer mortality. The Canadian Task Force on Preventive Health Care. J Can Dent Assoc. Dec. 1999;65(11):617. [pmid: 10859725].
Haynes B, Haines A. Barriers and bridges to evidence based clinical practice. BMJ. Jul 25. 1998;317(7153):273-6. [pmid: 9677226]. [pmcid: 1113594].
Haynes RB, Haines A. Barriers and bridges to evidence-based practice. In: Haines A, Donald A, editors. Getting research into practice, London: BMJ Publisher; 1998. p. 78–85.
Hearn J, Higginson I J. Outcome measures in palliative care for advanced cancer patients: A review. J Public Health Med. 1997;19(2):193-9. [pmid: 9243435].
Hearn J, Higginson I J. Do specialist palliative care teams improve outcomes for cancer patients? A systematic literature review. Palliat Med. 1998;12(5):317-32. [pmid: 9924595].
Hebert J R, Harris D R, Sorensen G, et al. A work-site nutrition intervention: its effects on the consumption of cancer-related nutrients. Am J Public Health. Mar. 1993;83(3):391-4. [pmid: 8438978]. [pmcid: 1694669].
Heckler M M. Health promotion for older Americans. Public Health Rep. Mar. 1985;100(2):225-30. [pmid: 3920721]. [pmcid: 1424734].
Heffner J E. The overarching challenge. Chest. Aug. 2000;118(2 Suppl):1S-3S. [pmid: 10939992].
Heffner J E, Alberts W M, Irwin R, et al. Translating guidelines into clinical practice : recommendations to the American College of Chest Physicians. Chest. Aug. 2000;118(2 Suppl):70S-3S. [pmid: 10940004].
Henson R M, Wyatt S W, Lee N C. The National Breast and Cervical Cancer Early Detection Program: a comprehensive public health response to two major health issues for women. J Public Health Manage Practice. 1996;2(2):36-47.
Hermann J, Brown B, Heintz S. Impact of nutrition promotion program on dietary behaviors, dietary intake, and health measures in adults over fifty-five years of age. J Nutr Elderly. 2000;19(3):1-14.
Hewitt M, Simone JV. Ensuring quality cancer care. Washington, DC: National Institute of Medicine; 1999.
Hiatt R A, Rimer B K. A new strategy for cancer control research. Cancer Epidemiol Biomarkers Prev. Nov. 1999;8(11):957-64. [pmid: 10566549].
Hicks C, Robinson K. Cervical screening: the impact of the gender of the smear-taker on service uptake. Health Serv Manage Res. Aug. 1997;10(3):187-9. [pmid: 10173148].
Hiddink G J, Hautvast J G A J, Van Woerkum C M J, et al. Information sources and strategies of nutrition guidance used by primary care physicians. Am J Clin Nutr. 1997;65(Suppl 6):1996S-2003S. [pmid: 9174509].
Hill D, Fawkes S, Murphy M. Hospital-based group smoking cessation programs. Aust Health Rev. 1990;13(2):95-102. [pmid: 10109123].
Hirano Y, Ojima T. Analyses of factors influencing participation in the cervical cancer screening programme in the community in Japan. J Epidemiol. Sep. 1997;7(3):125-33. [pmid: 9337510].
Holden D J, Moore K S, Holliday J L. Health education for a breast and cervical cancer screening program: Using the ecological model to assess local initiatives. Health Educ Res. 1998;13(2):293-9. [pmid: 10181027].
Holdsworth M, Spalding D. The development, implementation, monitoring and evaluation of a food and nutrition policy within a local health plan. J Hum Nutr Diet. 1997;10(4):209-17.
Hollis J F, Bills R, Whitlock E, et al. Implementing tobacco interventions in the real world of managed care. Tob Control. 2000;9(Suppl 1):i18-i24. [pmid: 10688926].
Holtrop JS, Slonim A. Sticking to it: a multifactor cancer risk-reduction program for low-income clients. J Health Educ 2000;31(3):122–7, 136.
Hooper L. UK Heart Health and Thoracic Dietitians Interest Group (Specialist interest group of the British Dietetic Association). Dietetic guidelines: diet in secondary prevention of cardiovascular disease. J Hum Nutr Diet. Aug. 2001;14(4):297-305. [pmid: 11493388].
Hopkins D P, Briss P A, Ricard C J, et al. Reviews of evidence regarding interventions to reduce tobacco use and exposure to environmental tobacco smoke. Am J Prev Med. Feb. 2001;20(Suppl 2):16-66. [pmid: 11173215].
Hopkins D P, Husten C G, Fielding J E, et al. Evidence reviews and recommendations on interventions to reduce tobacco use and exposure to environmental tobacco smoke: a summary of selected guidelines. Am J Prev Med. Feb. 2001;20(Suppl 2):67-87. [pmid: 11173216].
Horton R. Screening mammography--an overview revisited. Lancet. Oct 20. 2001;358(9290):1284-5. [pmid: 11684203].
Hough S, Mahlati M P. Osteoporosis Clinical Guideline. S Afr Med J. 2000;90(9 II):907-44. [pmid: 11081144].
Hovell M F, Jones J A, Adams M A. The feasibility and efficacy of tobacco use prevention in orthodontics. J Dent Educ. Apr. 2001;65(4):348-53. [pmid: 11336120].
Howe H L, Lehnherr M, Katterhagen J G. Education of rural physicians about breast cancer through an oncology outreach program. Public Health Rep. Nov. 1994;109(6):804-8. [pmid: 7800790]. [pmcid: 1403583].
Hsu L K G, Holben B, West S. Nutritional counseling in bulimia nervosa. Int J Eating Disord. 1992;11(1):55-62.
Hughes J R. Combined psychological and nicotine gum treatment for smoking: a critical review. J Subst Abuse. 1991;3(3):337-50. [pmid: 1821290].
Hughes J R, Liguori A. Bibliographical analysis of research on smoking cessation therapy. Tob Control. 1997;6(2):111-4. [pmid: 9291219].
Hughes J R. Reduced smoking: an introduction and review of the evidence. Addiction. Jan. 2000;95(Suppl 1):S3-S7. [pmid: 10723815].
Hughes JR, Stead LF, Lancaster T. Antidepressants for smoking cessation (Cochrane Review). In: The Cochrane Library, 2002. Issue 1. Oxford: Update Software.
Hulscher M E, van Drenth B B, van der Wouden J C, et al. Changing preventive practice: a controlled trial on the effects of outreach visits to organise prevention of cardiovascular disease. Qual Health Care. Mar. 1997;6(1):19-24. [pmid: 10166597].
Hulscher MEJL, Wensing M, van d, et al. Interventions to implement prevention in primary care (Cochrane Review). In: The Cochrane Library, 2001. Issue 3. Oxford: Update Software.
Humair J P, Ward J. Smoking-cessation strategies observed in videotaped general practice consultations. Am J Prev Med. Jan. 1998;14(1):1-8. [pmid: 9476830].
Hunt M K, Lederman R, Potter S, et al. Results of employee involvement in planning and implementing the Treatwell 5-a-Day work-site study. Health Educ Behav. Apr. 2000;27(2):223-31. [pmid: 10768803].
Hunter C P, Bavier A R, Ford L G. Cancer control research for community programs: the National Cancer Institute initiative. Cancer Detect Prev. 1990;14(6):633-7. [pmid: 2257561].
Hurley S F, Jolley D J, Livingston P M, et al. Effectiveness, costs, and cost-effectiveness of recruitment strategies for a mammographic screening program to detect breast cancer. J Natl Cancer Inst. Jun 3. 1992;84(11):855-63. [pmid: 1593653].
Irvin C B, Wyer P C, Gerson L W. Preventive care in the emergency department, Part II: Clinical preventive services--an emergency medicine evidence-based review. Society for Academic Emergency Medicine Public Health and Education Task Force Preventive Services Work Group. Acad Emerg Med. Sep. 2000;7(9):1042-54. [pmid: 11044002].
Irvin J E, Bowers C A, Dunn M E, et al. Efficacy of relapse prevention: a meta-analytic review. J Consult Clin Psychol. Aug. 1999;67(4):563-70. [pmid: 10450627].
Isacsson A, Lindholm L H, Schersten B, et al. Community intervention against non-insulin dependent diabetes mellitus (NIDDM) and cardiovascular disease: A study based on Swedish health care. Cardiovasc Risk Factors. 1996;6(3):164-71.
Iversen A, Anderson P, Champion P. How many districts have food and health policies?. Community Med. 1985;7(3):190-2. [pmid: 4042608].
Jadad A R, Browman G P. The WHO analgesic ladder for cancer pain management. Stepping up the quality of its evaluation. JAMA. Dec. 1995;274(23):1870-3. [pmid: 7500538].
Jadad A R, Moore R A, Carroll D, et al. Assessing the quality of reports of randomized clinical trials: is blinding necessary?. Control Clin Trials. Feb. 1996;17(1):1-12. [pmid: 8721797].
Janjanin M. Program of oral health as a part of the public health program in Republic Serbia. Med Arch. 2001;55(1):29-30.
Jason L A, Gruder C L, Martino S, et al. Work site group meetings and the effectiveness of a televised smoking cessation intervention. Am J Community Psychol. Feb. 1987;15(1):57-72. [pmid: 3604994].
Jenkins C N, Mcphee S J, Bird J A, et al. Effect of a media-led education campaign on breast and cervical cancer screening among Vietnamese-American women. Prev Med. Apr. 1999;28(4):395-406. [pmid: 10090869].
Jenkins DJA. Diet and Chronic Disease: Potential Impact and Unanswered Questions: A Background Document. 1. Toronto; The Prevention Unit,Division of Preventive Oncology Cancer Care Ontario; 2001.
Jepson R, Clegg A, Forbes C, et al. The determinants of screening uptake and interventions for increasing uptake: a systematic review. Health Technology Assessment (Rockville, Md) 2000;4(14):i-415
Johnson J L, Green L W, Frankish C J, et al. A dissemination research agenda to strengthen health promotion and disease prevention. Can J Public Health. Nov. 1996;87(Suppl 2):S5-10. [pmid: 9002336].
Johnson J L, Budz B, Mackay M, et al. Evaluation of a nurse-delivered smoking cessation intervention for hospitalized patients with cardiac disease. Heart Lung. Jan. 1999;28(1):55-64. [pmid: 9915931].
Joki R A. Health education: program development and implementation. Health Educ. Oct. 1988;19(5):31-3. [pmid: 3152241].
Jonkers C F, Prins F, Van Kempen A, et al. Towards implementation of optimum nutrition and better clinical nutrition support. Clin Nutr. 2001;20(4):361-6. [pmid: 11478835].
Joossens L. Smoking policy in the workplace and other public places. Lung. 1990;168(Suppl):437-44. [pmid: 2117146].
Jorenby D E, Fiore M C. The Agency for Health Care Policy and Research Smoking Cessation Clinical Practice Guideline: Basics and beyond. Prim Care Clin Office Pract. 1999;26(3):513-28.
Joseph A M, Knapp J M, Nichol K L, et al. Determinants of compliance with a national smoke-free hospital standard. JAMA. Aug 9. 1995;274(6):491-4. [pmid: 7629960].
Jou D, Shane R. Meeting the JCAHO challenge for improving pain management: The Cedars-Sinai approach. J Pharm Care Pain Symptom Control. 2001;9(3):7-35.
Kafatos A, Codrington C A. Nutrition and diet for healthy lifestyles in Europe: The ‘Eurodiet’ project. Public Health Nutr. 1999;2(3 A):327-8. [pmid: 10610068].
Kales S N. Smoking restrictions at Boston-area hospitals, 1990-1992. A serial survey. Chest. Nov. 1993;104(5):1589-91. [pmid: 8222828].
Kanstrom L, Haglund B J, Holm L E. A food fair to promote dietary change in the Stockholm cancer prevention programme. Eur J Cancer Prev. Aug. 1992;1(5):355-9. [pmid: 1463987].
Keller S, Donner-Banzhoff N, Kaluza G, et al. Improving physician-delivered counseling in a primary care setting: Lessons from a failed attempt. Educ Health. 2000;13(3):387-97.
Kelly A, Blair N, Pechacek T F. Observations from the CDC. Women and Smoking: Issues and opportunities. J Womens Health Gend Based Med. 2001;10(6):515-8. [pmid: 11559447].
Kelsey K, Earp J A, Kirkley B G. Is Social Support Beneficial for Dietary Change? A Review of the Literature. Fam Community Health. Oct 20. 1997;20(3):70-82.
Kennedy L A. Community involvement at what cost?--local appraisal of a pan-European nutrition promotion programme in low-income neighbourhoods. Health Promotion Int. Mar. 2001;16(1):35-45.
Kerner J. Designing for dissemination. In the presentation: “Designing for Dissemination” Conference, September 19, Washington, DC: 2002.
Ketola E, Sipila R, Makela M. Effectiveness of individual lifestyle interventions in reducing cardiovascular disease and risk factors. Ann Med. May. 2000;32(4):239-51. [pmid: 10852140].
Khanna N, Phillips M D. Adherence to care plan in women with abnormal Papanicolaou smears: a review of barriers and interventions. J Am Board Fam Pract. Mar. 2001;14(2):123-30. [pmid: 11314919].
Kim H J. Healthy City Kwachon 21 Project: a community health promotion programme in Korea. Asia Pac J Public Health. 2000;12(Suppl):S67-S70. [pmid: 11338743].
King E, Rimer B K, Benincasa T, et al. Strategies to encourage mammography use among women in senior citizens' housing facilities. J Cancer Educ. 1998;13(2):108-15. [pmid: 9659630].
King G. The “race” concept in smoking: a review of the research on African Americans. Soc Sci Med. Oct. 1997;45(7):1075-87. [pmid: 9257399].
King T K, Borrelli B, Black C, et al. Minority women and tobacco: implications for smoking cessation interventions. Ann Behav Med. 1997;19(3):301-13. [pmid: 9603705].
Kinsinger L S, Harris R, Qaqish B, et al. Using an office system intervention to increase breast cancer screening. J Gen Intern Med. Aug. 1998;13(8):507-14. [pmid: 9734786]. [pmcid: 1497003].
Kirby R K, Chauncey K B, Jones B G. The effectiveness of a nutrition education program for family practice residents conducted by a family practice resident-dietitian. Fam Med. Oct. 1995;27(9):576-80. [pmid: 8829982].
Kirby S D, Baranowski T, Reynolds K D, et al. Children's fruit and vegetable intake: socioeconomic, adult-child, regional, and urban-rural influences. J Nutr Educ. Sep. 1995;27(5):261-71.
Kirk-Gardner R, Steven D. An analysis of the Ontario Health Survey from a cardiovascular perspective. Can J Cardiov Nurs. 1994;5(3):7-14.
Klepp K I, Forster J L. The Norwegian Nutrition and Food Policy: An Integrated Policy Approach to a Public Health Problem. J Public Health Policy. Jun 4. 1985;6(4):447-63. [pmid: 4093500].
Knapp J M, Kottke T E, Heitzig C. A controlled trial to implement smoke-free hospitals. Minn Med. Dec. 1989;72(12):713-6. [pmid: 2601669].
Knuiman M W, Cullen K J, Bulsara M K, et al. Mortality trends, 1965 to 1989, in Busselton, the site of repeated health surveys and interventions. Aust J Public Health. 1994;18(2):129-35. [pmid: 7948327].
Koh Y H, Voo Y O, Yong L S. Smoking restrictions in private workplaces in Singapore. Singapore Med J. Jun. 1994;35(3):250-6. [pmid: 7997897].
Kolasa K, Poehlman G, Jobe A. Virtual seminars for disseminating medical nutrition education curriculum ideas. Am J Clin Nutr. 2000;71(6):1403-4. [pmid: 10837278].
Korhonen T, McAlister A, Laaksonen M, et al. International quit and win 1996: standardized evaluation in selected campaign countries. Prev Med. Dec. 2000;31(6):742-51. [pmid: 11133342].
Kotler P. Social marketing of health behavior. In: Fredriksen LW, Solomon LJ, Brehony KA, editors. Marketing health behavior: Principles, techniques, and applications, New York: Plenum Press; 1984. p. 23–39.
Kottke T E, Battista R N, DeFriese G H, et al. Attributes of successful smoking cessation interventions in medical practice. A meta-analysis of 39 controlled trials. JAMA. May. 1988;259(19):2883-9. [pmid: 3367456].
Kottke T E, Solberg L I, Brekke M L. Initiation and maintenance of patient behavioral change: what is the role of the physician?. J Gen Intern Med. Sep. 1990;5(Suppl 5):S62-S67. [pmid: 2231068].
Kottke T E, Solberg L I, Brekke M L, et al. A controlled trial to integrate smoking cessation advice into primary care practice: Doctors Helping Smokers, round III. J Fam Pract. Jun. 1992;34(6):701-8. [pmid: 1593243].
Kottke T E, Brekke M L, Solberg L I. Making “time” for preventive services. Mayo Clin Proc. Aug. 1993;68(8):785-91. [pmid: 8331981].
Kottke T E, Trapp M A. Implementing nurse-based systems to provide American Indian women with breast and cervical cancer screening. Mayo Clin Proc. Sep. 1998;73(9):815-23. [pmid: 9737216].
Kottke T E, Solberg L I, Brekke M L, et al. Clinician satisfaction with a preventive services implementation trial. The IMPROVE project. Am J Prev Med. Apr. 2000;18(3):219-24. [pmid: 10722988].
Krejci R. Tobacco cessation program implementation-from plans to reality: skill building workshop-network model. Tob Control. 2000;9(Suppl 1):i33-i36. [pmid: 10688929].
Krumholz H M, Radford M J, Ellerbeck E F, et al. Aspirin in the treatment of acute myocardial infarction in elderly Medicare beneficiaries. Patterns of use and outcomes. Circulation. Nov 15. 1995;92(10):2841-7. [pmid: 7586250].
Krummel D A, Koffman D M, Bronner Y, et al. Cardiovascular health interventions in women: What works?. J Womens Health Gend Based Med. Mar. 2001;10(2):117-36. [pmid: 11268297].
Kuhn M, Doucet C, Edwards N. Effectiveness of coalitions in heart promotion, tobacco use reductions andinjury prevention: a systematic review of the literature from 1989-1999. Effective Public Health Practice Project: Public Health Branch, Ontario MInistry of Health; 1999.
Kunze M. Smoke-free Europe in the year 2000: nongovernmental action (smoking cessation treatment). Lung. 1990;168(Suppl):433-6. [pmid: 2117145].
Kupets R, Covens A. Strategies for the implementation of cervical and breast cancer screening of women by primary care physicians. Gynecol Oncol. 2001;83(2):186-97. [pmid: 11606071].
Kurtz M E, Given B, Given C W, et al. Relationships of barriers and facilitators to breast self-examination, mammography, and clinical breast examination in a worksite population. Cancer Nurs. Aug. 1993;16(4):251-9. [pmid: 8402601].
Kutner S E. Breast cancer genetics and managed care: The kaiser permanente experience. Cancer. 1999;86(Suppl 11):2570-4. [pmid: 10630183].
Kwekkeboom K L. A model for cognitive-behavioral interventions in cancer pain management. Image. 1999;31(2):151-6.
Lacey L P, Phillips C W, Ansell D, et al. An urban community-based cancer prevention screening and health education intervention in Chicago. Public Health Rep. Nov. 1989;104(6):536-41. [pmid: 2511585]. [pmcid: 1580137].
Lacey L P, Manfredi C, Balch G, et al. Social support in smoking cessation among black women in Chicago public housing. Public Health Rep. May. 1993;108(3):387-94. [pmid: 8497578]. [pmcid: 1403392].
Lancaster T, Stead L, Silagy C, et al. Effectiveness of interventions to help people stop smoking: findings from the Cochrane Library. BMJ. Aug 5. 2000;321(7257):355-8. [pmid: 10926597]. [pmcid: 1118332].
Lancaster T, Stead LF. Self-help interventions for smoking cessation (Cochrane Review). In: The Cochrane Library, 2001. Issue 3. Oxford: Update Software.
Lancaster T, Silagy C, Fowler G. Training health professionals in smoking cessation (Cochrane Review). In: The Cochrane Library, 2001. Issue 3. Oxford: Update Software.
Lancaster T, Stead LF. Individual behavioural counselling for smoking cessation (Cochrane Review). In: The Cochrane Library, 2001. Issue 3. Oxford: Update Software.
Lando H A. A factorial analysis of preparation, aversion, and maintenance in the elimination of smoking. Addict Behav. 1982;7(2):143-54. [pmid: 7102445].
Lando H A, Kalb E A, McGovern P G. Behavioral self-help materials as an adjunct to nicotine gum. Addict Behav. 1988;13(2):181-4. [pmid: 3369327].
Lang J E, Mercer N, Tran D, et al. Use of a supermarket shelf-labeling program to educate a predominately minority community about foods that promote heart health. J Am Diet Assoc. Jul. 2000;100(7):804-9. [pmid: 10916519].
Lantz P M, Stencil D, Lippert M T, et al. Implementation issues and costs associated with a proven strategy for increasing breast and cervical cancer screening among low-income women. J Public Health Manage Practice. 1996;2(3):54-9.
Lantz P M, Jacobson P D, Warner K E, et al. Investing in youth tobacco control: a review of smoking prevention and control strategies. Tob Control. Mar. 2000;9(1):47-63. [pmid: 10691758].
Larkey L K, Alatorre C, Buller D B, et al. Communication strategies for dietary change in a worksite peer educator intervention. Health Educ Res. Dec. 1999;14(6):777-90. [pmid: 10585385].
Laudico A V. Development of cancer pain relief and palliative care in the Philippines. Acad Med Singapore. Mar. 1994;23(2):292-5.
Law M, Tang J L. An analysis of the effectiveness of interventions intended to help people stop smoking. Arch Intern Med. Oct 9. 1995;155(18):1933-41. [pmid: 7575046].
Lawson H W, Henson R, Bobo J K, et al. Implementing recommendations for the early detection of breast and cervical cancer among low-income women. Oncology. Nov. 2000;14(11):1528-30. [pmid: 11125939].
Lechky O. Persuasion techniques can motivate patients to change eating behaviours, symposium told. CMAJ. 1995;152(4):583-5. [pmid: 7859207]. [pmcid: 1337730].
Lefebvre R C, Lasater T M, Carleton R A, et al. Theory and delivery of health programming in the community: the Pawtucket Heart Health Program. Prev Med. Jan. 1987;16(1):80-95. [pmid: 3823012].
Legler J, Meissner H I, Coyne C, et al. The effectiveness of interventions to promote mammography among women with historically lower rates of screening. Cancer Epidemiol Biomarkers Prev. Jan. 2002;11(1):59-71. [pmid: 11815402].
Leino-Kilpi H, Iire L, Suominen T, et al. Client and information: a literature review. J Clin Nurs. Nov. 1993;2(6):331-40.
Leitch A M, Dodd G D, Costanza M, et al. American Cancer Society guidelines for the early detection of breast cancer: Update 1997. CA Cancer J Clin. 1997;47(3):150-3. [pmid: 9152172].
Lekhraj R. A study on the anti-smoking measures adopted by the local authorities in Malaysia, 1982. Med J Malaysia. Sep. 1983;38(3):203-5. [pmid: 6672563].
Lemelin J, Hogg W, Baskerville N. Evidence to action: a tailored multifaceted approach to changing family physician practice patterns and improving preventive care. CMAJ. Mar 20. 2001;164(6):757-63. [pmcid: 80870]. [pmid: 11276541].
Lesmes G R. Corporate healthcare costs and smoke-free environments. Am J Med. Jul 15. 1992;93(1A):48S-54S. [pmid: 1497004].
Levesque L, Richard L, Potvin L. The ecological approach in tobacco-control practice: health promotion practitioner characteristics related to using the ecological approach. Am J Health Promot. Mar. 2000;14(4):244-52. [pmid: 10915536].
Lewit E M. Responses among New Jersey's largest employers to legislation restricting smoking at the worksite. Am J Ind Med. 1992;22(3):385-93. [pmid: 1519621].
Lewit E M, Botsko M, Shapiro S. Workplace smoking policies in New Jersey businesses. Am J Public Health. 1993;83(2):254-6. [pmid: 8427334]. [pmcid: 1694587].
Li F P. Cancer control in susceptible groups: opportunities and challenges. J Clin Oncol. Feb. 1999;17(2):719-25. [pmid: 10080618].
Lichtenstein E, Glasgow R E, Lopez K, et al. Promoting tobacco control policies in northwest Indian tribes. Am J Public Health. Jul. 1995;85(7):991-4. [pmid: 7604928]. [pmcid: 1615526].
Lichtenstein E, Glasgow R E, Lando H A, et al. Telephone counseling for smoking cessation: rationales and meta-analytic review of evidence. Health Educ Res. Jun. 1996;11(2):243-57. [pmid: 10163409].
Lichtenstein E, Lopez K, Glasgow R E, et al. Effectiveness of a consultation intervention to promote tobacco control policies in Northwest Indian tribes: integrating experimental evaluation and service delivery. Am J Community Psychol. Oct. 1996;24(5):639-55. [pmid: 9145495].
Lichtenstein E. Behavioral research contributions and needs in cancer prevention and control: Tobacco use prevention and cessation. Prev Med. 1997;26(5 II):S57-S63. [pmid: 9327493].
Lichtman J H, Roumanis S A, Radford M J, et al. Can practice guidelines be transported effectively to different settings? Results from a multicenter interventional study. Jt Comm J Qual Improv. Jan. 2001;27(1):42-53. [pmid: 11147239].
Liguori A, Hughes J R. Where is smoking research published?. Tob Control. 1996;5(1):37-8. [pmid: 8795857].
Lilford R J, Pauker S G, Braunholtz D A, et al. Decision analysis and the implementation of research findings. BMJ. Aug 8. 1998;317(7155):405-9. [pmid: 9694762]. [pmcid: 1113676].
Lindseth G. Evaluating rural nurses for preparation in implementing nutrition interventions. J Rural Health. 1990;6(3):231-45. [pmid: 10105936].
Little P, Margetts B. The importance of diet and physical activity in the treatment of conditions managed in general practice. Br J Gen Pract. Mar. 1996;46(404):187-92. [pmid: 8731628]. [pmcid: 1239582].
Little P, Margetts B. Dietary and exercise assessment in general practice. Fam Pract. 1996;13(5):477-82. [pmid: 8902518].
Little S J, Stevens V J. Dental hygiene's role in reducing tobacco use. A literature review and recommendations for action. J Dent Hyg. Sep. 1991;65(7):346-50. [pmid: 1819632].
Logan H, Levy S, Ferguson K, et al. Tobacco-related attitudes and counseling practices of Iowa dentists. Clin Prev Dentistry. Jan. 1992;14(1):19-22.
Lomas J, Haynes R B. A taxonomy and critical review of tested strategies for the application of clinical practice recommendations: from “official” to “individual” clinical policy. Am J Prev Med. 1988;4(Suppl 4):77-94. [pmid: 3079143].
Lomas J. Words without action? The production, dissemination, and impact of consensus recommendations. Annu Rev Public Health. 1991;12:41-65. [pmid: 2049143].
Lomas J. Diffusion, dissemination, and implementation: who should do what?. Ann N Y Acad Sci. Dec 31. 1993;703:226-35. [pmid: 8192299].
Longo D R, Brownson R C, Kruse R L. Smoking bans in US hospitals. Results of a national survey. JAMA. Aug 9. 1995;274(6):488-91. [pmid: 7629959].
Longo D R, Feldman M M, Kruse R L, et al. Implementing smoking bans in American hospitals: results of a national survey. Tob Control. 1998;7(1):47-55. [pmid: 9706754].
Loo R. Policies and procedures in the workplace: how health care organizations compare. Healthc Manage Forum. 1993;6(2):39-43. [pmid: 10126761].
Love M B, Davoli G W, Thurman Q C. Normative beliefs of health behavior professionals regarding the psychosocial and environmental factors that influence health behavior change related to smoking cessation, regular exercise, and weight loss. Am J Health Promot. May. 1996;10(5):371-9. [pmid: 10163307].
Love R R. Changing the health promotion behaviors of primary care physicians: lessons from two projects. Jt Comm J Qual Improv. Jul. 1995;21(7):339-43. [pmid: 7581737].
Lowe J B, Windsor R A, Valois R F. Quality assurance methods for managing employee health-promotion programs: a case study in smoking cessation. Health Values. Mar. 1989;13(2):17-23. [pmid: 10292141].
Lowik M R H, Hulshof K F A M, Brussaard J H. Food-based dietary guidelines: Some assumptions tested for the Netherlands. Br J Nutr. 1999;81(Suppl 2):S143-S149. [pmid: 10999040].
Ludman E J, Curry S J, Meyer D, et al. Implementation of outreach telephone counseling to promote mammography participation. Health Educ Behav. Oct. 1999;26(5):689-702. [pmid: 10533173].
Lunetta P, Rockwell H. Ready-for-reading ‘script kits’ useful for teaching nutrition to seniors. J Nutr Elderly. Jan. 1985;5(2):59-66.
Lynagh M, Schofield M J, Sanson-Fisher R W. School Health Promotion Programs over the Past Decade: A Review of the Smoking, Alcohol and Solar Protection Literature. Health Promotion Int. Dec 1. 1997;12(1):43-60.
Lynde B D. Nutrition promotion for mature adults: A case study in peer education. J Nutr Elderly. 1992;11(3):19-31.
Macdonald H R, Glantz S A. Political realities of statewide smoking legislation: the passage of California's Assembly Bill 13. Tob Control. 1997;6(1):41-54. [pmid: 9176985].
Maddux J E, Rogers R W. Protection motivation and self-efficacy: A revised theory of fear appeals and attitude change. J Exp Soc Psychol. 1983;19:469-79.
Madigan D, Chapman C R, Gavrin J R, et al. Repertory hypergrids for large-scale hypermedia linking. Int J Human Computer Studies. Sep. 1995;43(3):465-81.
Maguire T A, McElnay J C, Drummond A. A randomized controlled trial of a smoking cessation intervention based in community pharmacies. Addiction. Feb. 2001;96(2):325-31. [pmid: 11182878].
Magzamen S, Glantz S A. The new battleground: California's experience with smoke-free bars. Am J Public Health. Feb. 2001;91(2):245-52. [pmid: 11211633]. [pmcid: 1446527].
Magzamen S, Charlesworth A, Glantz S A. Print media coverage of California's smokefree bar law. Tob Control. Jun. 2001;10(2):154-60. [pmid: 11387536].
Mahloch J, Taylor V, Taplin S, et al. A breast cancer screening educational intervention targeting medical office staff. Health Educ Res. Dec. 1993;8(4):567-79. [pmid: 10146564].
Malott J M, Glasgow R E, O' Neill H K, et al. Co-worker social support in a worksite smoking control program. J Appl Behav Anal. 1984;17(4):485-95. [pmid: 6441794]. [pmcid: 1307970].
Mandelblatt J, Kanetsky P A. Effectiveness of interventions to enhance physician screening for breast cancer. J Fam Pract. Feb. 1995;40(2):162-71. [pmid: 7654272].
Mandelblatt J S, Yabroff K R. Effectiveness of interventions designed to increase mammography use: a meta-analysis of provider-targeted strategies. Cancer Epidemiol Biomarkers Prev. Sep. 1999;8(9):759-67. [pmid: 10498394].
Manfredi C, Crittenden K S, Warnecke R, et al. Evaluation of a motivational smoking cessation intervention for women in public health clinics. Prev Med. Jan. 1999;28(1):51-60. [pmid: 9973588].
Manfredi C, Crittenden K, Cho Y I, et al. Maintenance of a smoking cessation program in public health clinics beyond the experimental evaluation period. Public Health Rep. 2001;116(Suppl 1):120-35. [pmid: 11889280].
Manley M, Lynn W, Payne E R, et al. The American Stop Smoking Intervention Study for cancer prevention: an overview. Tob Control. 1997;6(Suppl 2):S5-S11. [pmid: 9583646].
Manley M W, Pierce J P, Gilpin E A, et al. Impact of the American Stop Smoking Intervention Study on cigarette consumption. Tob Control. 1997;6(Suppl 2):S12-S16. [pmid: 9583647].
Manske S R, Lovato C Y, Shoveller J, et al. Public health capacity and interest in using electronic communication for staff training and resource dissemination: a national survey. Can J Public Health. Jul. 2000;91(4):274-6. [pmid: 10986785].
Marcus A C, Crane L A. A review of cervical cancer screening intervention research: implications for public health programs and future research. Prev Med. Jan. 1998;27(1):13-31. [pmid: 9465350].
Marcus A C, Heimendinger J, Wolfe P, et al. Increasing fruit and vegetable consumption among callers to the CIS: results from a randomized trial. Prev Med. Sep. 1998;27(5 Pt 2):S16-S28. [pmid: 9808821].
Marcus B H, Pinto B M, Clark M M. Physician-delivered physical activity and nutrition interventions. Med Exerc Nutr Health. 1995;4:325-34.
Margetts B M, Little P, Warm D. Interaction between physical activity and diet: Implications for blood pressure management in primary care. Public Health Nutr. 1999;2(3 A):377-82. [pmid: 10610076].
Marin G, Marin B V, Perez-Stable E J, et al. Changes in information as a function of a culturally appropriate smoking cessation community intervention for Hispanics. Am J Community Psychol. Dec. 1990;18(6):847-64. [pmid: 2091458].
Marin G, Perez-Stable E J. Effectiveness of disseminating culturally appropriate smoking-cessation information: Programa Latino Para Dejar de Fumar. J Natl Cancer Inst Monographs. 1995;18:155-63. [pmid: 8562216].
Marks L. Policies and postures in smoking control. BMJ. 1982;284(6313):391-5. [pmid: 6800472]. [pmcid: 1495959].
Marrett LD, Theis B, Ashbury FD et al. Workshop Report: Physical Activity and Cancer Prevention. 21. 2000. 4.
Marshall A A, Smith S W, McKeon J K. Persuading low-income women to engage in mammography screening: Source, message, and channel preferences. Health Commun. 1995;7(4):283-99.
Martin C B, Beerline D, Breslow L. Getting key players to work together and defending against diversion--California. Cancer. Dec 15. 1998;83(Suppl 12):2697-701. [pmid: 9874380].
Martin K, Froelicher E S, Miller N H. Women's initiative for nonsmoking (WINS) II: the intervention. Heart Lung. Nov. 2000;29(6):438-45. [pmid: 11080325].
Martin L M, Bouquot J E, Wingo P A, et al. Cancer prevention in the dental practice: oral cancer screening and tobacco cessation advice. J Public Health Dent. 1996;56(6):336-40. [pmid: 9089529].
Martinek K, Thomas K, Berner B, et al. Development and implementation of a breast and cervical cancer screening program in urban and rural Alaska. Int J Circumpolar Health. 1998;57(Suppl 1):399-405. [pmid: 10093314].
Matson D M, Lee J W, Hopp J W. The impact of incentives and competitions on participation and quit rates in worksite smoking cessation programs. Am J Health Promot. Mar. 1993;7(4):270-80. [pmid: 10146850].
May S, West R. Do social support interventions (“buddy systems”) aid smoking cessation? A review. Tob Control. Dec. 2000;9(4):415-22. [pmid: 11106712].
Mayer J A, Kellogg M C. Promoting mammography appointment making. J Behav Med. Dec. 1989;12(6):605-11. [pmid: 2634113].
McAfee T. Waking the health plan giant: Group Health Cooperative stops counting sheep and starts counting key tobacco indicators. Tob Control. 1998;7:S41-S44. [pmid: 10093197].
McAlister A, Puska P, Koskela K, et al. Mass Communication and Community Organization for Public Health Education. Am Psychol. Apr 3. 1980;35(4):375-9. [pmid: 7386969].
McBride P, Schrott H G, Plane M B, et al. Primary care practice adherence to national cholesterol education program guidelines for patients with coronary heart disease. Arch Intern Med. 1998;158(11):1238-44. [pmid: 9625403].
McCann J, Wait S, Seradour B, et al. A comparison of the performance and impact of breast cancer screening programmes in East Anglia, U.K. and Bouches du Rhone, France. Eur J Cancer. Mar. 1997;33(3):429-35. [pmid: 9155528].
McCann J. Anti-smoking effort seeks global implementation. J Natl Cancer Inst. 2000;92(7):523-4. [pmid: 10749902].
McClure J B. Are biomarkers a useful aid in smoking cessation? A review and analysis of the literature. Behav Med. 2001;27(1):37-47. [pmid: 11575171].
McDonnell A, Crookes P, Davies S, et al. Practice nurses and the prevention of cardiovascular disease and stroke: a literature review to promote evidence-based practice. Part 1: rationale, review methods, effectiveness of practice nurses and smoking cessation. Clin Effectiveness Nurs. Dec. 1997;1(4):189-97.
McEwen A, West R. Smoking cessation activities by general practitioners and practice nurses. Tob Control. Mar. 2001;10(1):27-32. [pmid: 11226357].
McGhan W F, Smith M D. Pharmacoeconomic analysis of smoking-cessation interventions. Am J Health Syst Pharm. Jan 1. 1996;53(1):45-52. [pmid: 8719289].
McGinnis J M, Nestle M. The Surgeon General's Report on Nutrition and Health: Policy implications and implementation strategies. Am J Clin Nutr. 1989;49(1):23-8. [pmid: 2912006].
McGinnis J M, Foege W H. Actual causes of death in the United States. JAMA. Nov 10. 1993;270(18):2207-12. [pmid: 8411605].
McIlvain H E, Crabtree B F, Backer E L, et al. Use of office-based smoking cessation activities in family practices. J Fam Pract. Nov. 2000;49(11):1025-9. [pmid: 11093569].
McKinlay J J, Short A D. An audit of secondary prevention in patients with established coronary heart disease. Health Bull. Mar. 1998;56(2):592-602.
McMaugh K, Rissel C. Smoking restrictions in small businesses of inner west Sydney: A management perspective. J Occup Health Safety. 2000;16(1):37-45.
McMenamin E, McCorkle R, Barg F, et al. Implementing a multidisciplinary cancer pain education program. Cancer Pract. Sep. 1995;3(5):303-9. [pmid: 7663549].
Mcphee S J, Bird J A, Jenkins C N, et al. Promoting cancer screening. A randomized, controlled trial of three interventions. Arch Intern Med. Aug. 1989;149(8):1866-72. [pmid: 2764657].
Mcphee S J, Detmer W M. Office-based interventions to improve delivery of cancer prevention services by primary care physicians. Cancer. Aug 1. 1993;72(Suppl 3):1100-12. [pmid: 8334665].
Mcquay H J, Moore R A, Eccleston C, et al. Systematic review of outpatient services for chronic pain control. Health Technol Assess. 1997;1(6):i-iv. [pmid: 9483161].
Medder J, Susman J L, Gilbert C, et al. Dissemination and implementation of Put Prevention into Family Practice. Am J Prev Med. Sep. 1997;13(5):345-51. [pmid: 9315265].
Meissner H I, Bergner L, Marconi K M. Developing cancer control capacity in state and local public health agencies. Public Health Rep. Jan. 1992;107(1):15-23. [pmid: 1738803]. [pmcid: 1403596].
Meissner H I, Breen N, Coyne C, et al. Breast and cervical cancer screening interventions: an assessment of the literature. Cancer Epidemiol Biomarkers Prev. Oct. 1998;7(10):951-61. [pmid: 9796642].
Melnikow J, Kohatsu N D, Chan B K. Put prevention into practice: a controlled evaluation. Am J Public Health. Oct. 2000;90(10):1622-5. [pmid: 11030000]. [pmcid: 1446373].
Mensink R P, Katan M B. Effect of dietary fatty acids on serum lipids and lipoproteins. A meta-analysis of 27 trials. Arterioscler Thromb. Aug. 1992;12(8):911-9. [pmid: 1386252].
Metcalfe C, Lewin R, Wisher S, et al. Barriers to implementing the evidence base in four NHS therapies. Physiotherapy. 2001;87(8):433-41.
Meyer A J, Nash J D, McAlister A L, et al. Skills training in a cardiovascular health education campaign. J Consult Clin Psychol. Apr. 1980;48(2):129-42. [pmid: 7365050].
Meyer T J, Mark M M. Effects of psychosocial interventions with adult cancer patients: a meta-analysis of randomized experiments. Health Psychol. Mar. 1995;14(2):101-8. [pmid: 7789344].
Michels P J, Keisler D. Psychological, demographic and situational factors of family physicians which influence cigarette cessation interventions in office-based practice. Patient Educ Couns. Aug. 1994;24(1):63-71. [pmid: 7862596].
Michielutte R, Dignan M B, Wells H B, et al. Development of a community cancer education program: the Forsyth County, NC cervical cancer prevention project. Public Health Rep. Nov. 1989;104(6):542-51. [pmid: 2511586]. [pmcid: 1580155].
Mielke M M, Jorenby D E, Fiore M C. Achieving smoking cessation in nicotine-dependent individuals. Cns Drugs. 1997;8(1):12-20.
Milio N. Promoting Health through Structural Change: Analysis of the Origins and Implementation of Norway's Farm-Food-Nutrition Policy. Soc Sci Med. Sep 15. 1981;15A(5):721-34.
Miller E H, Belgrade M J, Cook M, et al. Institutionwide pain management improvement through the use of evidence-based content, strategies, resources, and outcomes. Qual Manage Health Care. 1999;7(2):28-40.
Mitchell J P. Guideline implementation in the department of defense. Chest. Aug. 2000;118(2 Suppl):65S-9S. [pmid: 10940003].
Mittman B S, Tonesk X, Jacobson P D. Implementing clinical practice guidelines: social influence strategies and practitioner behavior change. QRB Qual Rev Bull. Dec. 1992;18(12):413-22. [pmid: 1287523].
Moher D, Schulz K F, Altman D. The CONSORT statement: revised recommendations for improving the quality of reports of parallel-group randomized trials. JAMA. Apr 18. 2001;285(15):1987-91. [pmid: 11308435].
Moller A, Villebro N, Pedersen T. Interventions for preoperative smoking cessation (Protocol). In: The Cochrane Library, 2001. Issue 3. Oxford: Update Software.
Monk A, Barry B, McClain K, et al. Practice guidelines for medical nutrition therapy provided by dietitians for persons with non-insulin-dependent diabetes mellitus. J Am Diet Assoc. 1995;95(9):999-1006. [pmid: 7657915].
Monninkhof EM, van d, van d, et al. Self-management education for patients with chronic obstructive pulmonary disease [Protocol]. In: The Cochrane Library, 2001. Issue 3. Oxford: Update Software.
Moore S A, Larsen L C. Nutrition teaching for family practice residents. J Fam Pract. 1983;16(6):1149-53. [pmid: 6854246].
Moormeier J. Breast cancer in black women. Ann Int Med. May 15. 1996;124(10):897-905. [pmid: 8610920].
Mott S F, Feder G S, Griffiths C J, et al. Guidelines for coronary heart disease in general practice. Practice-based audit: Results from a dissemination and implementation programme. J Clin Effectiveness. 1998;3(4):161-5.
Mowat D L, Mecredy D, Lee F, et al. Family physicians and smoking cessation. Survey of practices, opinions, and barriers. Can Fam Physician. Oct. 1996;42:1946-51. [pmid: 8894241]. [pmcid: 2146953].
Moyer C A, Lennartz H, Moore A A, et al. Expanding the role of mammographers: A training strategy to enhance mammographer-patient interaction. Breast Dis. 2001;13:13-9. [pmid: 15687618].
Moynihan R. Tobacco giant undermined Nicorette campaign. BMJ. Aug 17. 2002;325(7360):353. [pmid: 12183295].
Mularski R A, Young E A, Zeisel S H, et al. Essentials of nutrition education in medical schools: A National Consensus. Acad Med. 1996;71(9):969-71. [pmid: 9125984].
Mularski R A, Young E A, Zeisel S H, et al. Essentials of nutrition education in medical schools: A national consensus. Am J Clin Nutr. 1997;65(5):1559-61. [pmid: 9157789].
Mullen P D, Ito J R, Carbonari J P, et al. Assessing the congruence between physician behavior and expert opinion in smoking cessation counseling. Addict Behav. 1991;16(5):203-10. [pmid: 1776538].
Mullen P D, Mains D A, Velez R. A meta-analysis of controlled trials of cardiac patient education. Patient Educ Couns. 1992;19(2):143-62. [pmid: 1299819].
Mullen P D, Simons-Morton D G, Ramirez G, et al. A meta-analysis of trials evaluating patient education and counseling for three groups of preventive health behaviors. Patient Educ Couns. 1997;32(3):157-73. [pmid: 9423498].
Mullins R, Livingston P, Borland R. A strategy for involving general practitioners in smoking control. Aust N Z J Public Health. Jun. 1999;23(3):249-51. [pmid: 10388167].
Mullis R M, Bowen P E. Process guides for nutrition care in community health. J Am Diet Assoc. 1985;85(1):73-6. [pmid: 3965545].
Mullis R M, Pirie P. Lean meats make the grade--a collaborative nutrition intervention program. J Am Diet Assoc. Feb. 1988;88(2):191-5. [pmid: 3339206].
Mullooly J P, Schuman K L, Stevens V J, et al. Smoking behavior and attitudes of employees of a large HMO before and after a work site ban on cigarette smoking. Public Health Rep. Nov. 1990;105(6):623-8. [pmid: 2124362]. [pmcid: 1580168].
Munafo M, Rigotti N, Lancaster T, et al. Interventions for smoking cessation in hospitalised patients: a systematic review. Thorax. Aug. 2001;56(8):656-63. [pmid: 11462070].
Muñoz de Chávez M, Chávez A. Diet that prevents cancer: recommendations from the American Institute for Cancer Research. Int J Cancer. 1998;11:85-9.
Muramoto M L, Connolly T, Strayer L J, et al. Tobacco cessation skills certification in Arizona: application of a state wide, community based model for diffusion of evidence based practice guidelines. Tob Control. Dec. 2000;9(4):408-14. [pmid: 11106711].
Murray D M. Dissemination of community health promotion programs: the Fargo-Moorhead Heart Health Program. J Sch Health. Nov. 1986;56(9):375-81. [pmid: 3640927].
Musaiger A O. Evaluation of a Nutrition Education Program in Oman: A Case Study. Int Q Community Educ. 1997;17(1):57-64.
Muto T, Hsieh S D, Sakurai Y. Status of health promotion programme implementation in small-scale enterprises in Japan. Occup Med. Feb. 1999;49(2):65-70.
Napoles-Springer A, Perez-Stable E J, Washington E. Risk factors for invasive cervical cancer in Latino women. J Med Syst. Oct. 1996;20(5):277-93. [pmid: 9001995].
National Center for Health Statistics (2002). Data file documentation, National Health Interview Survey, 2000 (machine readable data file and documentation). National Center for Health Statistics, Hyattsville, Maryland.
Nayfield S G, Bongiovanni G C, Alciati M H, et al. Statutory requirements for disclosure of breast cancer treatment alternatives. J Natl Cancer Inst. Aug 17. 1994;86(16):1202-8. [pmid: 8040887].
Naylor C D, Paterson J M. Cholesterol policy and the primary prevention of coronary disease: Reflections on clinical and population strategies. Annu Rev Nutr. 1996;16:349-82. [pmid: 8839931].
Neill K, Allensworth D D. A model to increase consumption of fruit and vegetables by implementing the “5-A-Day” initiative. J Sch Health. Apr. 1994;64(4):150-5. [pmid: 8035575].
Newell S A, Bowman J A, Cockburn J D. Can compliance with nonpharmacologic treatments for cardiovascular disease be improved?. Am J Prev Med. Apr. 2000;18(3):253-61. [pmid: 10722993].
Newman C F, Downes N J, Tseng R Y, et al. Nutrition-related backgrounds and counseling practices of doctors of chiropractic. J Am Diet Assoc. 1989;89(7):939-43. [pmid: 2745912].
Newman M. Review: counselling and education reduce cardiovascular risk factors but not mortality. EBN. Jan. 2000;3(1):22.
Ngo J. Social marketing and fat intake. Eur J Clin Nutr. Sep. 1993;47(Suppl 1):S91-S95. [pmid: 8269908].
Nguyen T V. Promoting early detection of breast cancer among Vietnamese-American women. Cancer. Jan 1. 2001;91(S1):267-73. [pmid: 11148592].
Nielsen B B. The nurse's role in mammography screening. Cancer Nurs. Oct. 1989;12(5):271-5. [pmid: 2804962].
Norman S A, Greenberg R, Marconi K, et al. A process evaluation of a two-year community cardiovascular risk reduction program: what was done and who knew about it?. Health Educ Res. 1990;5(1):87-97.
Norman S A, Talbott E O, Kuller L H, et al. Demographic, psychosocial, and medical correlates of Pap testing: a literature review. Am J Prev Med. Jul. 1991;7(4):219-26. [pmid: 1756058].
O'Loughlin J, Renaud L, Richard L, et al. Correlates of the sustainability of community-based heart health promotion interventions. Prev Med. Sep. 1998;27(5:Pt 1):702-12. [pmid: 9808802].
O'Loughlin J, Makni H, Tremblay M, et al. Smoking cessation counseling practices of general practitioners in Montreal. Prev Med. Dec. 2001;33(6):627-38. [pmid: 11716660].
Ockene I S, Hebert J R, Ockene J K, et al. Effect of physician-delivered nutrition counseling training and an office-support program on saturated fat intake, weight, and serum lipid measurements in a hyperlipidemic population: Worcester Area Trial for Counseling in Hyperlipidemia (WATCH). Arch Intern Med. Apr 12. 1999;159(7):725-31. [pmid: 10218753].
Ockene J K, Lindsay E, Berger L, et al. Health Care Providers as Key Change Agents in the Community Intervention Trial for Smoking Cessation (COMMIT). Int Q Community Educ. 1990;11(3):223-37.
Ockene J K, Lindsay E A, Hymowitz N, et al. Tobacco control activities of primary-care physicians in the Community Intervention Trial for Smoking Cessation. COMMIT Research Group. Tob Control. 1997;6(Suppl 2):S49-S56. [pmid: 9583653].
Ockene J K, Zapka J. Changing provider behaviour: provider education and training. Tob Control. 1997;6 Suppl 1:S63-S67. [pmid: 9396127].
Ockene J K, Emmons K M, Mermelstein R J, et al. Relapse and maintenance issues for smoking cessation. Health Psychol. Jan. 2000;19(Suppl 1):17-31. [pmid: 10709945].
Ockene J K, Zapka J G. Provider education to promote implementation of clinical practice guidelines. Chest. Aug. 2000;118(2 Suppl):33S-9S. [pmid: 10939997].
Offord K P, Hurt R D, Berge K G, et al. Effects of the implementation of a smoke-free policy in a medical center. Chest. Nov. 1992;102(5):1531-6. [pmid: 1424878].
Okuyemi K S, Ahluwalia J S, Wadland W C. The evaluation and treatment of tobacco use disorder. J Fam Pract. 2001;50(11):981-7. [pmid: 11711018].
Olive K E, Ballard J A. Changes in employee smoking behavior after implementation of restrictive smoking policies. South Med J. Jul. 1996;89(7):699-706. [pmid: 8685757].
Olsen O, Gotzsche PC. Screening for breast cancer with mammography. Cochrane Database Syst Rev 2001;(4):CD001877
Olsen O, Gotzsche P C. Cochrane review on screening for breast cancer with mammography. Lancet. Oct 20. 2001;358(9290):1340-2. [pmid: 11684218].
Olson K L, Chapman J A, Thurston W E, et al. Promotion of breast cancer screening in communities: a research agenda. Cancer Prev Control. Aug. 1997;1(3):213-21. [pmid: 9765746].
Olsson S, Andersson I, Karlberg I, et al. Implementation of service screening with mammography in Sweden: from pilot study to nationwide programme. J Med Screen. 2000;7(1):14-8. [pmid: 10807141].
Orleans C T, Gruman J, Ulmer C, et al. Rating our progress in population health promotion: Report card on six behaviors. Am J Health Promot. 1999;14(2):75-82. [pmid: 10724725].
Osler M, Jespersen N B. The effect of a community-based cardiovascular disease prevention project in a Danish municipality. Dan Med Bull. Sep. 1993;40(4):485-9. [pmid: 8222768].
Owen N, Borland R. Delayed compensatory cigarette consumption after a workplace smoking ban. Tob Control. 1997;6(2):131-5. [pmid: 9291223].
Oxman A D, Cook D J, Guyatt G H. Users' guides to the medical literature. VI. How to use an overview. Evidence-Based Medicine Working Group. JAMA. Nov 2. 1994;272(17):1367-71. [pmid: 7933399].
Oxman A D, Thomson M A, Davis D A, et al. No magic bullets: a systematic review of 102 trials of interventions to improve professional practice. CMAJ. Nov 15. 1995;153(10):1423-31. [pmid: 7585368]. [pmcid: 1487455].
Paradis G, O'Loughlin J, Elliott M, et al. Coeur en sante St-Henri--a heart health promotion programme in a low income, low education neighbourhood in Montreal, Canada: theoretical model and early field experience. J Epidemiol Commun Health. Oct. 1995;49(5):503-12.
Parcel G S. Diffusion research: The smart choices project. Health Educ Res. 1995;10(3):279-81. [pmid: 10158027].
Pargeon K L, Hailey B J. Barriers to effective cancer pain management: a review of the literature. J Pain Symptom Manage. Nov. 1999;18(5):358-68. [pmid: 10584460].
Park EW, Schultz JK, Tudiver F, et al. Partner support for smoking cessation [Protocol]. In: The Cochrane Library, 2001. Issue 3. Oxford: Update Software.
Parrott S, Godfrey C, Raw M, et al. Guidance for commissioners on the cost effectiveness of smoking cessation interventions. Health Educational Authority. Thorax. Dec. 1998;53(Suppl 5 Pt 2):S1-S38. [pmid: 10226676].
Pasacreta JV. Review: 5 community based recruitment strategies increase women's attendance at mammography screening appointments... commentary on Bonfill X, Marzo M, Pladevall M, et al. Strategies for increasing women participation in community breast cancer screening. Cochrane Database Syst Rev 2001;(1):CD002943 (latest version 18 Oct 2000). EBN 2001 Jul;4(3):87
Paskett E D, DeGraffinreid C, Tatum C M, et al. The recruitment of African-Americans to cancer prevention and control studies. Prev Med. Sep. 1996;25(5):547-53. [pmid: 8888322].
Paskett E D, Tatum C M, D'Agostino R Jr, et al. Community-based interventions to improve breast and cervical cancer screening: results of the Forsyth County Cancer Screening (FoCaS) Project. Cancer Epidemiol Biomarkers Prev. May. 1999;8(5):453-9. [pmid: 10350442].
Paskett E D, Masten K B, Phillips K C, et al. Receptivity of a worksite breast cancer screening education program. Health Educ Res. Oct. 1999;14(5):667-74. [pmid: 10510074].
Passanisi N, Prout M, Holm L J. The New England division Tell A Friend program implementation evaluation. Cancer Pract. 2001;9(Suppl 1):S64-S71. [pmid: 11912857].
Patten C A, Martin J E, Hofstetter C R, et al. Smoking cessation following treatment in a smoke-free Navy Alcohol Rehabilitation program. J Subst Abuse Treat. Jan. 1999;16(1):61-9. [pmid: 9888123].
Patterson R E, Kristal A R, Biener L, et al. Durability and diffusion of the nutrition intervention in the Working Well Trial. Prev Med. Sep. 1998;27(5:Pt 1):668-73. [pmid: 9808797].
Payne T H. Computer decision support systems. Chest. Aug. 2000;118(2 Suppl):47S-52S. [pmid: 10939999].
Pbert L, Adams A, Quirk M, et al. The patient exit interview as an assessment of physician-delivered smoking intervention: a validation study. Health Psychol. Mar. 1999;18(2):183-8. [pmid: 10194054].
Pearson T A, Stone E J, Grundy S M, et al. Translation of nutritional sciences into medical education: The Nutrition Academic Award Program. Am J Clin Nutr. 2001;74(2):164-70. [pmid: 11470716].
Pederson L L, Bull S B, Ashley M J, et al. An evaluation of the workplace smoking bylaw in the city of Toronto. Am J Public Health. Sep. 1993;83(9):1342-5. [pmid: 8363016]. [pmcid: 1694960].
Pederson LL, Brock J, McDonald J. Self-quitters and those who continue to smoke: a review of the litterature. Literature Reviews Series, No. 6. Toronto: The Ontario Tobacco Research Unit, Canada; 1996.
Pederson L L, Ahluwalia J S, Harris K J, et al. Smoking cessation among African Americans: what we know and do not know about interventions and self-quitting. Prev Med. Jul. 2000;31(1):23-38. [pmid: 10896841].
Perez-Stable E J, Marin B V, Marin G. A comprehensive smoking cessation program for the San Francisco Bay Area Latino community: Programa Latino Para Dejar de Fumar. Am J Health Promot. Jul. 1993;7(6):430-42. [pmid: 10146254].
Perkins K A, Levine M D, Marcus M D, et al. Addressing women's concerns about weight gain due to smoking cessation. J Subst Abuse Treat. Mar. 1997;14(2):173-82. [pmid: 9258862].
Person L. Implementing guidelines on acute pain management. Oncol Nurs Forum. Oct. 1995;22(9):1436-7. [pmid: 8539187].
Piasecki T M, Baker T B. Any further progress in smoking cessation treatment?. Nicotine Tobacco Res. 2001;3(4):311-23.
Pierce J P, Dwyer T, Frape G, et al. Evaluation of the Sydney “Quit. For Life” anti-smoking campaign. Part 1. Achievement of intermediate goals. Med J Aust. Mar 31. 1986;144(7):341-4. [pmid: 3959949].
Pierce J P, Anderson D M, Romano R M, et al. Promoting smoking cessation in the United States: effect of public service announcements on the Cancer Information Service telephone line. J Natl Cancer Inst. May 6. 1992;84(9):677-83. [pmid: 1569601].
Pinotti J A, Carvalho J P, Nisida A C T. Control of cervical cancer in Brazil. Arch Std/Hiv Res. 1994;8(3–4):199-207.
Pirkis J E, Jolley D, Dunt D R. Recruitment of women by GPs for Pap tests: a meta-analysis. Br J Gen Pract. Sep. 1998;48(434):1603-7. [pmid: 9830190]. [pmcid: 1313228].
Poland B, Boutilier M, Tobin S, et al. The policy context for community development practice in public health: A Canadian case study. J Public Health Policy. 2000;21(1):5-19. [pmid: 10754795].
Posavac E J, Kattapong K R, Dew D E J. Peer-based interventions to influence health-related behaviors and attitudes: A meta-analysis. Psychol Rep. Dec. 1999;85(3, Pt 2 [Spec Issue]):1179-94. [pmid: 10710973].
Potter JD, Finnegan JR, Guinard J-X et al. 5 A Day for Better Health Program Evaluation Report. NIH Publication No. 01-4904. Bethesda, MD: National Institutes of Health; 2000.
Potter S J, Mauldin P D, Hill H A. Access to and participation in breast cancer screening: a review of recent literature. Clin Perform Qual Health Care. Apr. 1996;4(2):74-85. [pmid: 10156946].
Powers T, Deckard M, Stark N, et al. A nutrition support team quality assurance plan. Nutr Clin Pract. Aug. 1991;6(4):151-5. [pmid: 1775109].
Prochaska JO. Systems of psychotherapy. Homewood, IL: Dorsey Press; 1979.
Prochaska J O, DiClemente C C, Norcross J C. In search of how people change. Applications to addictive behaviors. Am Psychol. Sep. 1992;47(9):1102-14. [pmid: 1329589].
Pucci L G, Haglund B. ‘Naturally Smoke Free’: A support program for facilitating worksite smoking control policy implementation in Sweden. Health Promotion Int. 1994;9(3):177-87.
Raffle A E. Information about screening - is it to achieve high uptake or to ensure informed choice?. Health Expectations. Jun. 2001;4(2):92-8. [pmid: 11359539].
Raja-Jones H. Breast screening and ethnic minority women: a literature review. Br J Nurs. Oct 28. 1999;8(19):1284-8. [pmid: 10887805].
Ramirez AG, McAlister A, Gallion KJ, et al. Community level cancer control in a Texas barrio: Part I--Theoretical basis, implementation, and process evaluation. J Natl Cancer Inst Monographs 1995;(18):117–22.
Ramirez A G, Villarreal R, McAlister A, et al. Advancing the role of participatory communication in the diffusion of cancer screening among Hispanics. J Health Communication. Jan. 1999;4(1):31-6.
Ratner P A, Bottorff J L, Johnson J L, et al. A meta-analysis of mammography screening promotion. Cancer Detect Prev. 2001;25(2):147-60. [pmid: 11341350].
Raw M, McNeill A, West R. Smoking cessation guidelines for health professionals. A guide to effective smoking cessation interventions for the health care system. Health Education Authority. Thorax. Dec. 1998;53(Suppl 5 Pt 1):S1-S19. [pmid: 10226676].
Razavi D, Vandecasteele H, Primo C, et al. Improving cancer prevention at the worksite: how are Belgian companies dealing with smoking regulations?. Psychooncology. Sep. 1997;6(3):204-11. [pmid: 9313286].
Reding D J, Huber J A, Lappe K A. Results of a rural breast health education demonstration project. Cancer Pract. Sep. 1995;3(5):295-302. [pmid: 7663548].
Reeder B, Ramsden V, Shuaib A, et al. The Saskatchewan Clinical Stroke Prevention Project: design. Health Rep. 1994;6(1):166-70. [pmid: 7919076].
Reid W M, Marshburn J, Siddharthan K. Managed care organizations and mammography: Opportunities to serve underserved women. Women Health. 1999;28(4):13-28. [pmid: 10378343].
Renneker M. An inner city cancer prevention clinic. Design, methods, and early results. Cancer. Mar 15. 1991;67(Suppl 6):1802-7. [pmid: 2001582].
Resnicow K, Wallace D C, Jackson A, et al. Dietary change through African American churches: baseline results and program description of the eat for life trial. J Cancer Educ. 2000;15(3):156-63. [pmid: 11019764].
Revere D, Dunbar P J. Review of computer-generated outpatient health behavior interventions: clinical encounters “in absentia”. JAMIA. Jan. 2001;8(1):62-79. [pmcid: 134592]. [pmid: 11141513].
Rhodes D J, Koshy R C, Waterfield W C, et al. Feasibility of quantitative pain assessment in outpatient oncology practice. J Clin Oncol. Jan 15. 2001;19(2):501-8. [pmid: 11208844].
Rice V H. Nursing intervention and smoking cessation: A meta-analysis. Heart Lung. Nov. 1999;28(6):438-54. [pmid: 10580218].
Rice VH, Stead LF. Nursing interventions for smoking cessation (Cochrane Review). In: The Cochrane Library, 2001. Issue 3. Oxford: Update Software.
Richmond R L, Anderson P. Research in general practice for smokers and excessive drinkers in Australia and the UK. III. Dissemination of interventions. Addiction. 1994;89(1):49-62. [pmid: 8148744].
Richmond R L, Anderson P. Research in general practice for smokers and excessive drinkers in Australia and the UK. II. Representativeness of the results. Addiction. 1994;89(1):41-7. [pmid: 8148743].
Richmond R L. Retracing the steps of Marco Polo: From clinical trials to diffusion of interventions for smokers. Addict Behav. 1996;21(6):683-97. [pmid: 8904935].
Ries LAG, Kosary CL, Hankey BF. SEER cancer statistics review, 1973-1994. Bethesda, MD; National Cancer Institute, National Institute of Health; 1997.
Rigotti N A, Bourne D, Rosen A, et al. Workplace compliance with a no-smoking law: a randomized community intervention trial. Am J Public Health. Feb. 1992;82(2):229-35. [pmid: 1739153]. [pmcid: 1694289].
Rigotti N A, Stoto M A, Bierer M F, et al. Retail stores compliance with a city no-smoking law. Am J Public Health. 1993;83(2):227-32. [pmid: 8427328]. [pmcid: 1694565].
Rigotti NA, Munafo MR, Murphy MFG, et al. Interventions for smoking cessation in hospitalised patients (Cochrane Review). In: The Cochrane Library, 2001. Issue 3. Oxford: Update Software.
Rimer B K. Mammography use in the U.S.: Trends and the impact of interventions. Ann Behav Med. 1994;16(4):317-26.
Rimer BK, Glassman B. Is there a use for tailored print communications in cancer risk communication? J Natl Cancer Inst Monographs 1999;(25):140–8.
Rinck G C, Van den Bos G A M, Kleijnen J, et al. Methodologic issues in effectiveness research on palliative cancer care: A systematic review. J Clin Oncol. 1997;15(4):1697-707. [pmid: 9193371].
Rischer J B, Childress S B. Cancer pain management: pilot implementation of the AHCPR guideline in Utah. Jt Comm J Qual Improv. Oct. 1996;22(10):683-700. [pmid: 8923168].
Rischer J B, Childress S B. Implementation of the AHCPR clinical practice guideline on the management of cancer pain. J Pharm Care Pain Symptom Control. 1998;6(1):79-90.
Ritvo P G, Irvine M J, Lindsay E A, et al. A critical review of research related to family physician-assisted smoking cessation interventions. Cancer Prev Control. Oct. 1997;1(4):289-303. [pmid: 9765753].
Roberts C, Turnbull D, Irwig L. The impact of a screening mammography program on Sydney general practitioners. Aust J Public Health. Mar. 1992;16(1):58-65. [pmid: 1627713].
Rogers EM. Diffusion of innovations. New York: The Free Press; 1962.
Rogers RW. Cognitive and psychological processes in fear appraisal and attitude change: a revised theory of protection motivation. In: Cacioppo JT, Petty RE, editors. Social psychophysiology, New York: Guilford Press; 1983. p. 153–76.
Rosen C S. Is the sequencing of change processes by stage consistent across health problems? A meta-analysis. Health Psychol. Nov. 2000;19(6):593-604. [pmid: 11129363].
Rosenstock I M, Stergachis A, Heaney C. Evaluation of smoking prohibition policy in a health maintenance organization. Am J Public Health. Aug. 1986;76(8):1014-5. [pmid: 3728757]. [pmcid: 1646636].
Rosenstock IM. The Health belief model: Explaining health behavior through expectancies. In: Glanz K, Lewis FM, Rimer BK, editors. Health behavior and health education: theory, research, and practice, 2nd Edition San Francisco: Jossey-Bass; 1990.
Roski J. Changing practice patterns as a result of implementing the Agency for Health Care Policy and Research guideline in 20 primary care clinics. Tob Control. 1998;7(Suppl 1):19S-20S. [pmid: 10093191].
Royce J M, Hymowitz N, Corbett K, et al. Smoking cessation factors among African Americans and Whites (COMMIT). Am J Public Health. 1990;83(2):220-6. [pmid: 8427327].
Ruck N F, Darwish O A. Motivating health workers through nutrition training: An example from Egypt. Health Policy Plann. 1991;6(2):130-40.
Rushton P, Nail L, Brown S. Impact of continuing education on rural cancer nursing care. J Pharm Care Pain Symptom Control. 1997;5(2):37-59.
Ruzicka D L, Daniels D. Implementing a pain management service at an Army Medical Center. Mil Med. Feb. 2001;166(2):146-51. [pmid: 11272713].
Sackett DL, Haynes BJ, Guyatt G, et al. How to read reviews. In: Clinical Epidemiology: A Basic Science for Clinical Medicine, 2nd edition Toronto: Little, Brown & Company; 1991. Chaper 13 p. 379–91.
Sackett D L, Rosenberg W M, Gray J A, et al. Evidence based medicine: what it is and what it isn't. BMJ. Jan 13. 1996;312(7023):71-2. [pmid: 8555924].
Sacks-Silver G, O'Loughlin J, Jacques M. Implementing smoking policies in the workplace: a pilot study. Can J Public Health. May. 1990;81(3):230-1. [pmid: 2361213].
Sadler G R, Thomas A G, Yen J Y, et al. Breast cancer education program based in Asian grocery stores. J Cancer Educ. 2000;15(3):173-7. [pmid: 11019767].
Sahay TB, Rootman I, Ashbury FD. Review of Nutrition Interventions for Cancer Prevention. Hamilton, ON: Cancer Care Ontario; 2000.
Saint-Pierre R G, Cook T D, Straw R B. An Evaluation of the Nutrition Education and Training Program: Findings from Nebraska. Eval Program Plan. Apr 3. 1981;4(3–4):335-44.
Samuels S E. Project LEAN--lessons learned from a national social marketing campaign. Public Health Rep. Jan. 1993;108(1):45-53. [pmid: 8434097]. [pmcid: 1403329].
Sanderson M E, Winkler J T. Nutrition: The changing scene. Implementing the NACNE report. 2. Strategies for implementing NACNE recommendations. Lancet. Dec 10. 1983;2(8363):1353-4. [pmid: 6139683].
Sawaya G F, Grimes D A. New technologies in cervical cytology screening: a word of caution. Obstet Gynecol. Aug. 1999;94(2):307-10. [pmid: 10432148].
Schauffler H H. Integrating smoking control policies into employee benefits: a survey of large California corporations. Am J Public Health. Sep. 1993;83(9):1226-30. [pmid: 8362996]. [pmcid: 1694986].
Scheer J C, Sims L S. Status of nutrition surveillance activities in 24 state and metropolitan health departments. Public Health Rep. 1983;98(4):349-55. [pmid: 6611821]. [pmcid: 1424466].
Schoenwald S K, Hoagwood K. Effectiveness, transportability, and dissemination of interventions: what matters when?. Psychiatr Serv. Sep. 2001;52(9):1190-7. [pmid: 11533392].
Schooler C, Farquhar J W, Fortmann S P, et al. Synthesis of findings and issues from community prevention trials. Ann Epidemiol. 1997;7(Suppl 7):S54-S68.
Scott C J, Gerberich S G. Analysis of a smoking policy in the workplace. AAOHN Journal. Jul. 1989;37(7):265-73. [pmid: 2735977].
Scott T L, Wong F L, Rimer B K. Dissemination of an evidence-based intervention manual to improve managed care mammography rates. Managed Care Interface. Feb. 1999;12(2):83-8. [pmid: 10346191].
Secker-Walker R. Community interventions for reducing smoking among adults [Protocol]. In: The Cochrane Library, 2001. Issue 3. Oxford: Update Software.
Secker-Walker R H, Flynn B S, Solomon L J, et al. Helping women quit smoking: results of a community intervention program. Am J Public Health. Jun. 2000;90(6):940-6. [pmid: 10846513]. [pmcid: 1446253].
Segnan N, Battista R N, Rosso S, et al. Preventive practices of general practitioners in Torino, Italy. Am J Prev Med. Nov. 1992;8(6):333-8. [pmid: 1482572].
Seow A, Straughan P T, Ng E H, et al. Factors determining acceptability of mammography in an Asian population: a study among women in Singapore. Cancer Causes Control. Sep. 1997;8(5):771-9. [pmid: 9328200].
Shanley M H, Laskey M, Decker R. Effectiveness of a physician reminder program for smoking cessation. J Contin Educ Health Prof. 1999;19(3):142-51.
Shea S, Basch C E, Wechsler H, et al. The Washington Heights-Inwood Healthy Heart Program: a 6-year report from a disadvantaged urban setting. Am J Public Health. Feb. 1996;86(2):166-71. [pmid: 8633731]. [pmcid: 1380323].
Shea S, DuMouchel W, Bahamonde L. A meta-analysis of 16 randomized controlled trials to evaluate computer-based clinical reminder systems for preventive care in the ambulatory setting. JAMIA. Nov. 1996;3(6):399-409. [pmcid: 116324]. [pmid: 8930856].
Shediac-Rizkallah M C, Cassady C E, Scheirer M A, et al. Linking Implementation to Outcomes: Evaluation of a Community-Based Breast and Cervical Cancer Screening Program. Int Q Community Educ. 1996;16(1):5-23.
Sheils J F, Rubin R, Stapleton D C. The estimated costs and savings of medical nutrition therapy: The medicare population. J Am Diet Assoc. 1999;99(4):428-35. [pmid: 10207394].
Shekelle PG, Stone EG, Maglione MA. Interventions that increase the utilization of Medicare funded preventive services for persons age 65 and older. Evidence Report/Technology assessment, U.S. Department of Health and Human Services: Health Care Financing Administration; 1999. Publication No. HCFA-02151.
Sheldon T A, Guyatt G H, Haines A. Getting research findings into practice. When to act on the evidence. BMJ. Jul 11. 1998;317(7151):139-42. [pmid: 9657797]. [pmcid: 1113499].
Shewart WA. Economic control of quality of manufactured product. New York: D Van Nostrand company Inc.; 1991.
Shoaf L R, Bishirjian K O. Standards of practice for gerontological nutritionists: A mandate for action. J Am Diet Assoc. 1995;95(12):1433-8. [pmid: 7594150].
Shojania K G, Bero L A. Taking advantage of the explosion of systematic reviews: an efficient MEDLINE search strategy. Eff Clin Pract. Jul. 2001;4(4):157-62. [pmid: 11525102].
Shopland D R, Gerlach K K, Burns D M, et al. State-specific trends in smoke-free workplace policy coverage: The current population survey tobacco use supplement, 1993 to 1999. J Occup Environ Med. 2001;43(8):680-6. [pmid: 11515250].
Shortell SM, Bennett CL, Byck GR. Assessing the impact of continuous quality improvement on clinical practice: what it will take to accelerate progress. Milbank Q 1998;76(4):593–624, 510.
Shovic A C, Harris P R. Nutrition components and assessment procedures of a university employee wellness program: a case study. J Am Diet Assoc. Jan. 1991;91(1):79-82. [pmid: 1869763].
Shuster G F III, Utz S W, Merwin E. Implementation and outcomes of a community-based self-help smoking cessation program. J Commun Health Nurs. 1996;13(3):187-98.
Silagy C, Lancaster T, Gray S, et al. Effectiveness of training health professionals to provide smoking cessation interventions: systematic review of randomised controlled trials. Qual Health Care. Dec. 1994;3(4):193-8. [pmid: 10140233].
Silagy C, Stead LF. Physician advice for smoking cessation (Cochrane Review). In: The Cochrane Library, 2001. Issue 3. Oxford: Update Software.
Simmer T. Implementing the AHCPR guideline in health management organisations. Tob Control. 1997;6(Suppl 1):S27-S28. [pmid: 9396117].
Simonds S K, Kanters H W. Comparative analysis of patient education by four professions in the Netherlands and the United States. Patient Educ Couns. 1990;15(2):151-67. [pmid: 2290748].
Simons-Morton D G, Mullen P D, Mains D A, et al. Characteristics of controlled studies of patient education and counseling for preventive health behaviors. Patient Educ Couns. 1992;19(2):175-204. [pmid: 1299821].
Sin J P, St Leger A S. Interventions to increase breast screening uptake: do they make any difference?. J Med Screen. 1999;6(4):170-81. [pmid: 10693060].
Skaar K L, Tsoh J Y, McClure J B, et al. Smoking cessation: 1. An overview of research. Behav Med. 1997;23(1):5-13. [pmid: 9201426].
Skinner C S, Strecher V J, Hospers H. Physicians' recommendations for mammography: do tailored messages make a difference?. Am J Public Health. Jan. 1994;84(1):43-9. [pmid: 8279610]. [pmcid: 1614921].
Skinner C S, Campbell M K, Rimer B K, et al. How effective is tailored print communication?. Ann Behav Med. 1999;21(4):290-8. [pmid: 10721435].
Skipper A, Young M, Rotman N, et al. Physicians' implementation of dietitians' recommendations: A study of the effectiveness of dietitians. J Am Diet Assoc. 1994;94(1):45-9. [pmid: 8270754].
Slotnick H B. Physicians' learning strategies. Chest. Aug. 2000;118(2 Suppl):18S-23S. [pmid: 10939995].
Smith M C, Holcombe J K, Stullenbarger E. A meta-analysis of intervention effectiveness for symptom management in oncology nursing research. Oncol Nurs Forum. Aug. 1994;21(7):1201-9. [pmid: 7971430].
Smith W R. Evidence for the effectiveness of techniques To change physician behavior. Chest. Aug. 2000;118(2 Suppl):8S-17S. [pmid: 10939994].
Snell J L, Buck E L. Increasing cancer screening: a meta-analysis. Prev Med. Nov. 1996;25(6):702-7. [pmid: 8936572].
Soebadi R D, Tejawinata S. Indonesia: status of cancer pain and palliative care. J Pain Symptom Manage. Aug. 1996;12(2):112-5. [pmid: 8754994].
Solberg L I, Kottke T E, Brekke M L, et al. Failure of a continuous quality improvement intervention to increase the delivery of preventive services. A randomized trial. Eff Clin Pract. May. 2000;3(3):105-15. [pmid: 11182958].
Sorensen G, Glasgow R E, Corbett K, et al. Compliance with worksite nonsmoking policies: baseline results from the COMMIT study of worksites. Am J Health Promot. Nov. 1992;7(2):103-9. [pmid: 10148714].
Sorensen G, Thompson B, Basen-Engquist K, et al. Durability, dissemination, and institutionalization of worksite tobacco control programs: Results from the working well trial. Int J Behav Med. 1998;5(4):335-51. [pmid: 16250700].
Sowden A, Arblaster L. Community interventions for preventing smoking in young people (Cochrane Review). In: The Cochrane Library, 2001. Issue 3. Oxford: Update Software.
Sowden AJ, Arblaster L. Mass media interventions for preventing smoking in young people (Cochrane Review). In: The Cochrane Library, 2001. Issue 3. Oxford: Update Software.
Spencer E, Swanson T, Hueston W J, et al. Tools to improve documentation of smoking status. Continuous quality improvement and electronic medical records. Arch Fam Med. Jan. 1999;8(1):18-22. [pmid: 9932067].
Stead LF, Lancaster T. Group behaviour therapy programmes for smoking cessation (Cochrane Review). In: The Cochrane Library, 2001. Issue 3. Oxford: Update Software.
Stead LF, Lancaster T. Interventions for preventing tobacco sales to minors (Cochrane Review). In: The Cochrane Library, 2001. Issue 3. Oxford: Update Software.
Stead LF, Lancaster T. Telephone counselling for smoking cessation (Cochrane Review). In: The Cochrane Library, 2001. Issue 3. Oxford: Update Software.
Steckler A, Goodman R M, McLeroy K R, et al. Measuring the diffusion of innovative health promotion programs. Am J Health Promot. Jan. 1992;6(3):214-24. [pmid: 10148679].
Steenhuis I H, van Assema P, Glanz K. Strengthening environmental and educational nutrition programmes in worksite cafeterias and supermarkets in The Netherlands. Health Promotion Int. Mar. 2001;16(1):21-33.
Stigler M H, Pirie P, Havlicek D, et al. Doing Our Part So Kids Don't Start: An evaluation of a statewide public awareness campaign. Cancer Pract. 2001;9(SUPPL. 1):S37-S42. [pmid: 11912852].
Stillman F A, Becker D M, Swank R T, et al. Ending smoking at the Johns Hopkins Medical Institutions. An evaluation of smoking prevalence and indoor air pollution. JAMA. Sep 26. 1990;264(12):1565-9. [pmid: 2395198].
Stillman F A, Bone L R, Rand C, et al. Heart, body, and soul: a church-based smoking-cessation program for Urban African Americans. Prev Med. May. 1993;22(3):335-49. [pmid: 8327417].
Stockdale S E, Keeler E, Duan N, et al. Costs and cost-effectiveness of a church-based intervention to promote mammography screening. Health Serv Res. Dec. 2000;35(5:Pt 1):1037-57. [pmid: 11130802].
Stockley L. Toward public health nutrition strategies in the European Union to implement food based dietary guidelines and to enhance healthier lifestyles. Public Health Nutr. Apr. 2001;4(2A):307-24. [pmid: 11688436].
Stoddard A M, Fox S A, Costanza M E, et al. Effectiveness of telephone counseling for mammography: results from five randomized trials. Prev Med. Jan. 2002;34(1):90-9. [pmid: 11749101].
Stone E G, Morton S C, Hulscher M E, et al. Interventions that increase use of adult immunization and cancer screening services: a meta-analysis. Ann Int Med. May 7. 2002;136(9):641-51. [pmid: 11992299].
Storey P. Hospice physician's current literature review: evaluation of the cancer patient in pain. Am J Hospice Palliat Care. Nov. 1991;8(6):7.
Storey P. Cancer pain management: how are we doing?... physician's current literature review. Am J Hospice Palliat Care. May. 1992;9(3):6-7.
Straus S E, Sackett D L. Using research findings in clinical practice. BMJ. Aug 1. 1998;317(7154):339-42. [pmid: 9685286]. [pmcid: 1113635].
Strecher V J, Kreuter M, Den Boer D J, et al. The effects of computer-tailored smoking cessation messages in family practice settings. J Fam Pract. Sep. 1994;39(3):262-70. [pmid: 8077905].
Stroup D F, Berlin J A, Morton S C, et al. Meta-analysis of observational studies in epidemiology: a proposal for reporting. Meta-analysis Of Observational Studies in Epidemiology (MOOSE) group. JAMA. Apr 19. 2000;283(15):2008-12. [pmid: 10789670].
Suarez L, Nichols D C, Pulley L, et al. Local health departments implement a theory-based model to increase breast and cervical cancer screening. Public Health Rep. Jul. 1993;108(4):477-82. [pmid: 8341783]. [pmcid: 1403412].
Suarez L, Nichols D C, Brady C A. Use of peer role models to increase Pap smear and mammogram screening in Mexican-American and black women. Am J Prev Med. Sep. 1993;9(5):290-6. [pmid: 8257618].
Suarez L, Lloyd L, Weiss N, et al. Effect of social networks on cancer-screening behavior of older Mexican-American women. J Natl Cancer Inst. May 18. 1994;86(10):775-9. [pmid: 8169975].
Suarez L, Pulley L. Comparing acculturation scales and their relationship to cancer screening among older Mexican-American women. J Natl Cancer Inst Monographs 1995;(18):41–7.
Sun S, Korhonen T, Uutela A, et al. International Quit and Win 1996: comparative evaluation study in China and Finland. Tob Control. Sep. 2000;9(3):303-9. [pmid: 10982574].
Sung H Y, Kearney K A, Miller M, et al. Papanicolaou smear history and diagnosis of invasive cervical carcinoma among members of a large prepaid health plan. Cancer. May 15. 2000;88(10):2283-9. [pmid: 10820350].
Sunseri A J, Alberti J M, Kent N D, et al. Ingredients in nutrition education: family involvement, reading and race. J Sch Health. May. 1984;54(5):193-6. [pmid: 6564304].
Surveillance Implementation Group. Cancer Surveillance Research. National Cancer Institute; 1999.
Tabak E R, Mullen P D, Simons-Morton D G, et al. Definition and yield of inclusion criteria for a meta-analysis of patient education studies in clinical preventive services. Eval Health Prof. Dec. 1991;14(4):388-411. [pmid: 10120958].
Takeda F, Uki J. Recent progress in cancer pain management and palliative care in Japan. Acad Med Singapore. Mar. 1994;23(2):296-9.
Tang J L, Armitage J M, Lancaster T, et al. Systematic review of dietary intervention trials to lower blood total cholesterol in free-living subjects. BMJ. Apr 18. 1998;316(7139):1213-20. [pmcid: 28525]. [pmid: 9552999].
Taplin S H, Anderman C, Grothaus L, et al. Using physician correspondence and postcard reminders to promote mammography use. Am J Public Health. Apr. 1994;84(4):571-4. [pmid: 8154558]. [pmcid: 1614799].
Taplin S H, Mandelson M T, Anderman C, et al. Mammography diffusion and trends in late-stage breast cancer: evaluating outcomes in a population. Cancer Epidemiol Biomarkers Prev. Aug. 1997;6(8):625-31. [pmid: 9264276].
Tatum C, Wilson A, Dignan M, et al. Development and implementation of outreach strategies for breast and cervical cancer prevention among African American women. FoCaS Project. Forsyth County Cancer Screening. J Cancer Educ. 1997;12(1):43-50. [pmid: 9095440].
Taylor T, Serrano E, Anderson J, et al. Knowledge, skills, and behavior improvements on peer educators and low- income Hispanic participants after a stage of change-based bilingual nutrition education program. J Community Health. 2000;25(3):241-62. [pmid: 10868817].
Taylor V M, Taplin S H, Urban N, et al. Community organization to promote breast cancer screening ordering by primary care physicians. J Community Health. Aug. 1996;21(4):277-91. [pmid: 8842890].
The American Cancer Society 1996, Advisory Committee on Diet Nutrition and Cancer Prevention. Guidelines on diet, nutrition, and cancer prevention: reducing the risk of cancer with healthy food choices and physical activity. CA Cancer J Clin. Nov. 1996;46(6):325-41. [pmid: 8917019].
Thomas H, Micucci S, Thompson O'Brien MA, and Briss P. Towards a reliable and valid instrument for quality assessment of primary studies in public health. 2001. Unpublished work.
Thomas L, Cullum N, McColl E, et al. Guidelines in professions allied to medicine (Cochrane Review). In: The Cochrane Library, 2001. Issue 4. Oxford: Update Software.
Thompson O'Brien MA, Oxman AD, Davis DA, et al. Audit and feedback versus alternative strategies: effects on professional practice and health care outcomes (Cochrane Review). In: The Cochrane Library, 2000. Issue 2. Oxford: Update Software.
Thompson O'Brien MA, Oxman AD, Haynes RB, et al. Local opinion leaders: effects on professional practice and health care outcomes (Cochrane Review). In: The Cochrane Library, 2000. Issue 2. Oxford: Update Software.
Thompson O'Brien MA, Oxman AD, Davis DA, et al. Educational outreach visits: effects on professional practice and health care outcomes (Cochrane Review). In: The Cochrane Library, 2001. Issue 3. Oxford: Update Software.
Thompson O'Brien MA, Freemantle N, Oxman AD, et al. Continuing education meetings and workshops: effects on professional practice and health care outcomes (Cochrane Review). In: The Cochrane Library, 2001. Issue 3. Oxford: Update Software.
Thompson O'Brien MA, Oxman AD, Davis DA, et al. Audit and feedback: effects on professional practice and health care outcomes. In: The Cochrane Library, 2002. Issue 1. Oxford: Update Software.
Thompson B, Corbett K, Bracht N, et al. Community mobilization for smoking cessation: Lessons learned from COMMIT. Health Promotion Int. 1993;8(2):69-83.
Thompson B L, Nelson D E, Caldwell B, et al. Assessment of health risk behaviors. A tool to inform consumers, providers, health care organizations, and purchasers. [see comments]. Am J Prev Med. Jan. 1999;16(1):48-59. [pmid: 9894556].
Thompson B, Wallack L, Lichtenstein E, et al. Principles of Community Organization and Partnership for Smoking Cessation in the Community Intervention Trial for Smoking Cessation (COMMIT). Int Q Community Educ. 1990;11(3):187-203.
Thomsen T F, Davidsen M, Ibsen H, et al. A new method for CHD prediction and prevention based on regional risk scores and randomized clinical trials; PRECARD(R) and the Copenhagen risk score. J Cardiovasc Risk. 2001;8(5):291-7. [pmid: 11702035].
Tillotson G S. Implementation and physician behavior change : an industry perspective. Chest. Aug. 2000;118(2 Suppl):59S-61S. [pmid: 10940001].
Tommasello T. Two pharmacy-practice models for implementing the AHCPR smoking cessation guideline. Tob Control. 1997;6(Suppl 1):S36-S38. [pmid: 9396120].
Toscani F, Carini M. The implementation of WHO guidelines for the treatment of advanced cancer pain at a district general hospital in Italy. Pain Clin. 1989;3(1):37-48.
Town G I, Fraser P, Graham S, et al. Establishment of a smoking cessation programme in primary and secondary care in Canterbury. N Z Med J. Apr 14. 2000;113(1107):117-9. [pmid: 10834278].
Tremblay M, Gervais A, Lacroix C, et al. Physicians Taking Action Against Smoking: an intervention program to optimize smoking cessation counselling by Montreal general practitioners. CMAJ. Sep 4. 2001;165(5):601-7. [pmcid: 81419]. [pmid: 11563213].
Trijsburg R W, van Knippenberg F C, Rijpma S E. Effects of psychological treatment on cancer patients: a critical review. Psychosom Med. Jul. 1992;54(4):489-517. [pmid: 1502290].
Truswell A S. Review of dietary intervention studies: effect on coronary events and on total mortality. Aust N Z J Med. Feb. 1994;24(1):98-106. [pmid: 8002875].
Tseng D S, Cox E, Plane M B, et al. Efficacy of patient letter reminders on cervical cancer screening: a meta-analysis. J Gen Intern Med. Aug. 2001;16(8):563-8. [pmid: 11556935]. [pmcid: 1495254].
Turnbull D, Irwig L, Simpson J M, et al. The psychosocial impact of implementing a mammography screening campaign in an Australian community. Soc Sci Med. Aug. 1994;39(4):543-51. [pmid: 7973854].
Tuttle M M, Jaeger B, Greenfield P H. Working well with Kaiser Permanente: an innovative approach to worksite health promotion. In HMOs and managed care: the measure of health care reform: proceedings of the 43rd Annual Group Health Institute, June 13–16, 1993, San Francisco, California 1993. p.85–96.
Tziraki C, Graubard B I, Manley M, et al. Effect of training on adoption of cancer prevention nutrition-related activities by primary care practices: results of a randomized, controlled study. J Gen Intern Med. Mar. 2000;15(3):155-62. [pmid: 10718895]. [pmcid: 1495352].
U.S.Department of Health and Human Services. Healthy people 2010: Understanding and improving health. 2nd ed. Washington, DC: U.S. Goverment Printing Office; 2000.
U.S.General Accounting Office. Mammography services: Impact of federal legislation on quality, access and health outcomes. Washington, DC: GAO; 1998.
Valdés-Ramos R, Mendoza I, Solomons N W. Concordance of dietary intake with the ‘Dietary Guidelines for Americans’ among adults in rural ‘Santa Rosa’ province, Guatemala. Nutr Res. 2001;21(1–2):81-91.
van Assema P, Kempers B, Brug J, et al. An exploratory study into Dutch consumers' experiences with implementing dietary recommendations to reduce fat intake. J Hum Nutr Diet. 1999;12(2):103-12.
van der Feen de Lille J C, Riedstra M, Hardeman W, et al. Fat Watch: a nationwide campaign in The Netherlands to reduce fat intake--process evaluations. Nutr Health. 1998;12(2):107-17. [pmid: 9502236].
Van DerWeijden T, Hutten J B F, Brandenburg B J, et al. Cholesterol management in Dutch general practice. A comparison with national guidelines. Scand J Prim Health Care. 1994;12(4):281-8. [pmid: 7863147].
Varner L M. Impact of combined weight-control and smoking-cessation interventions on body weight: review of the literature. J Am Diet Assoc. Oct. 1999;99(10):1272-5. [pmid: 10524395].
Vellozzi C J, Romans M, Rothenberg R B. Delivering breast and cervical cancer screening services to underserved women: Part I. Literature review and telephone survey. Womens Health Issues. Mar. 1996;6(2):65-73. [pmid: 8932459].
Vernon S W, Laville E A, Jackson G L. Participation in breast screening programs: a review. Soc Sci Med. 1990;30(10):1107-18. [pmid: 2194294].
Vicary J R, Doebler M K, Bridger J C, et al. A Community Systems Approach to Substance Abuse Prevention in a Rural Setting. J Prim Prev. 1996;16(3):303-18.
Viswesvaran C, Schmidt F L. A meta-analytic comparison of the effectiveness of smoking cessation methods. J Appl Psychol. Aug. 1992;77(4):554-61. [pmid: 1387394].
Vogt T M, Lichtenstein E, Ary D, et al. Integrating tobacco intervention into a health maintenance organization: the TRACC program. Health Educ Res. 1989;4(1):125-35.
Wagner T H. The effectiveness of mailed patient reminders on mammography screening: a meta-analysis. Am J Prev Med. Jan. 1998;14(1):64-70. [pmid: 9476837].
Ward J, Sanson-Fisher R. Does a 3-day workshop for family medicine trainees improve preventive care? A randomized control trial. Prev Med. Nov. 1996;25(6):741-7. [pmid: 8936577].
Ward J A, Anderson D M, Pundik C G, et al. Cancer Information Service utilization by selected U.S. ethnic groups. J Natl Cancer Inst. 1993;14:147-56.
Ward J A-D, Baum S, Maat J T, et al. The value and impact of the Cancer Information Service telephone service. Part 4. J Health Communication. 1998;3(Suppl 3):50-70.
Warnecke R B, Langenberg P, Wong S C, et al. The second Chicago televised smoking cessation program: a 24-month follow-up. Am J Public Health. Jun. 1992;82(6):835-40. [pmid: 1585964]. [pmcid: 1694195].
Warner K E. Cigarette smoking in the 1970's: the impact of the antismoking campaign on consumption. Science. Feb 13. 1981;211(4483):729-31. [pmid: 7455711].
Warner K E, Murt H A. Premature deaths avoided by the antismoking campaign. Am J Public Health. Jun. 1983;73(6):672-7. [pmid: 6846675]. [pmcid: 1650871].
Wears R L. Advanced statistics: statistical methods for analyzing cluster and cluster-randomized data. Acad Emerg Med. Apr. 2002;9(4):330-41. [pmid: 11927463].
Weingarten S. Translating practice guidelines into patient care : guidelines at the bedside. Chest. Aug. 2000;118(2 Suppl):4S-7S. [pmid: 10939993].
Weinstein N D, Rothman A J, Sutton S R. Stage theories of health behavior: conceptual and methodological issues. Health Psychol. May. 1998;17(3):290-9. [pmid: 9619480].
Weiss K B, Wagner R. Performance measurement through audit, feedback, and profiling as tools for improving clinical care. Chest. Aug. 2000;118(2 Suppl):53S-8S. [pmid: 10940000].
Weissman A M. Preventive health care and screening of Latin American immigrants in the United States. J Am Board Fam Pract. Jul. 1994;7(4):310-23. [pmid: 7942100].
Weissman D E, Gutmann M, Dahl J L. Physician cancer pain education: a report from the Wisconsin Cancer Pain Initiative. J Pain Symptom Manage. Oct. 1991;6(7):445-8. [pmid: 1940490].
Weissman D E, Dahl J L, Beasley J W. The Cancer Pain Role Model Program of the Wisconsin Cancer Pain Initiative. J Pain Symptom Manage. Jan. 1993;8(1):29-35. [pmid: 8482891].
Weissman D E, Dahl J L. Update on the cancer pain role model education program. J Pain Symptom Manage. May. 1995;10(4):292-7. [pmid: 7541436].
Weissman D E, Griffie J, Muchka S, et al. Building an institutional commitment to pain management in long-term care facilities. J Pain Symptom Manage. 2000;20(1):35-43. [pmid: 10946167].
West R, McNeill A, Raw M. Smoking cessation guidelines for health professionals: an update. Health Education Authority. Thorax. Dec. 2000;55(12):987-99. [pmid: 11083883].
White G E, Mcavoy B R, Gleisner S. Increasing the uptake of cervical smears: strategies implemented among general practitioners in Auckland. N Z Med J. Aug 25. 1993;106(962):357-60. [pmid: 8255562].
Whiteman J A, Snyder D A, Ragland J J. The value of leadership in implementing and maintaining a successful health promotion program in the Naval Surface Force, U.S. Pacific Fleet. Am J Health Promot. Jul. 2001;15(6):437-40. [pmid: 11523501].
Wiggers J, Considine R, Daly J, et al. Prevalence and acceptability of public health initiatives in licensed premises. Aust N Z J Public Health. Jun. 2000;24(3):320-2. [pmid: 10937412].
Wiggers J, Considine R, Hazell T, et al. Increasing the practice of health promotion initiatives by licensed premises. Health Educ Behav. Jun. 2001;28(3):331-40. [pmid: 11380053].
Wilcox S, Parra-Medina D, Thompson-Robinson M, et al. Nutrition and physical activity interventions to reduce cardiovascular disease risk in health care settings: a quantitative review with a focus on women. Nutr Rev. Jul. 2001;59(7):197-214. [pmid: 11475446].
Willemsen M C, Meijer A, Jannink M. Applying a contingency model of strategic decision making to the implementation of smoking bans: a case study. Health Educ Res. Aug. 1999;14(4):519-31. [pmid: 10557522].
Williams C. Dissemination of the Agency for Health Care Policy and Research guideline. Tob Control. 1998;7(Suppl 1):S17-S18. [pmid: 10093190].
Williams P T, Eckert G, Epstein A, et al. In-office cancer-screening education of primary care physicians. J Cancer Educ. 1994;9(2):90-5. [pmid: 7522508].
Wilson D H, Wakefield M A, Steven I D, et al. “Sick of Smoking”: evaluation of a targeted minimal smoking cessation intervention in general practice. Med J Aust. May 21. 1990;152(10):518-21. [pmid: 2338924].
Wilson E. Enhancing smoke-free behaviour: prevention of stroke. Health Rep. 1994;6(1):100-5. [pmid: 7919064].
Wilson E E, Tweed W A. Pharmacists' role in smoking cessation. Can Pharm J. Apr. 1984;117(4):156-7. [pmid: 10266366].
Wilson M G, Holman P B, Hammock A. A comprehensive review of the effects of worksite health promotion on health-related outcomes. [Review] [25 refs]. American Journal of Health Promotion. Jul. 1996;10(6):429-35. [pmid: 10163309].
Winett R A. A framework for health promotion and disease prevention programs. Am Psychol. May. 1995;50(5):341-50. [pmid: 7762887].
Winkler J D, Lohr K N, Brook R H. Persuasive communication and medical technology assessment. Arch Intern Med. Feb. 1985;145(2):314-7. [pmid: 3977492].
Woolf S H, Dickey L L. Differing perspectives on preventive care guidelines: A new look at the mammography controversy. Am J Prev Med. 1999;17(4):260-8. [pmid: 10606194].
Worden J K, Solomon L J, Flynn B S, et al. Community-based promotion of breast screening using small group education. J Public Health Manage Practice. May. 1999;5(3):54-62.
World Health Organization. Cancer Pain Relief. Geneva, Switzerland: World Health Organization; 1986.
Yabroff K R, Mandelblatt J S. Interventions targeted toward patients to increase mammography use. Cancer Epidemiol Biomarkers Prev. Sep. 1999;8(9):749-57. [pmid: 10498393].
Yabroff K R, Kerner J F, Mandelblatt J S. Effectiveness of interventions to improve follow-up after abnormal cervical cancer screening. Prev Med. Oct. 2000;31(4):429-39. [pmid: 11006069].
Yabroff K R, O'Malley A, Mangan P, et al. Inreach and outreach interventions to improve mammography use. J Am Med Womens Assoc. 2001;56(4):166-73. [pmid: 11759785].
Yajima S, Takano T, Nakamura K, et al. Effectiveness of a community leaders' programme to promote healthy lifestyles in Tokyo, Japan. Health Promotion Int. 2001;16(3):235-43.
Yarnall K S, Rimer B K, Hynes D, et al. Computerized prompts for cancer screening in a community health center. J Am Board Fam Pract. Mar. 1998;11(2):96-104. [pmid: 9542701].
Yeazel M W, Bunner S H, Kofron P M, et al. Put prevention into practice (PPIP): evaluating PPIP in two family practice residency sites. Fam Med. Jan. 2002;34(1):17-22. [pmid: 11838522].
Young J M, Ward J E. Implementing guidelines for smoking cessation advice in Australian general practice: opinions, current practices, readiness to change and perceived barriers. Fam Pract. Feb. 2001;18(1):14-20. [pmid: 11145622].
Yu-Poth S, Zhao G, Etherton T, et al. Effects of the National Cholesterol Education Program's Step I and Step II dietary intervention programs on cardiovascular disease risk factors: a meta-analysis. Am J Clin Nutr. Apr. 1999;69(4):632-46. [pmid: 10197564].
Zapata LB, Coreil J, Entrekin N. Evaluation of triple touch: An assessment of program delivery. Cancer Pract 2001;9(Suppl 1):S23–S3