# References

1 Haines A, Donald A. Making better use of research findings. BMJ. Jul 4. 1998;317(7150):72-5. [pmid: 9651281]. [pmcid: 28547].
2 Anonymous. Fact Sheet: Translating Research Into Practice (TRIP) - II. Internet. http://www.ahcpr.gov/research/trip2fac.htm
3 Kerner J. Designing for dissemination. In the presentation: “Designing for Dissemination” Conference, September 19, Washington, DC: 2002.
4 Rogers EM. Diffusion of innovations. New York: The Free Press; 1962.
5 Dobbins M, Ciliska D, Cockerill R, et al. A framework for the dissemination and utilization of research for health care policy and practice. Online J Knowledge Synthesis Nurs 2002;9(in press):
6 Lomas J, Haynes R B. A taxonomy and critical review of tested strategies for the application of clinical practice recommendations: from “official” to “individual” clinical policy. Am J Prev Med. 1988;4(Suppl 4):77-94. [pmid: 3079143].
7 Lomas J. Diffusion, dissemination, and implementation: who should do what?. Ann N Y Acad Sci. Dec 31. 1993;703:226-35. [pmid: 8192299].
8 Glasgow R E, Bull S S, Gillette C, et al. Behavior change intervention research in healthcare settings. A review of recent reports with emphasis on external validity. Am J Prev Med. Jul. 2002;23(1):62-9. [pmid: 12093425].
9 Glasgow R E, McKay H G, Piette J D, et al. The RE-AIM framework for evaluating interventions: what can it tell us about approaches to chronic illness management?. Patient Educ Couns. Aug. 2001;44(2):119-27. [pmid: 11479052].
10 Becker M H. The Health Belief Model and sick-role behavior. Health Education Monographs. 1974;2:409-19.
11 Bandura A. Social Learning Theory. Englewood Cliffs, NJ: Prentice Hall; 1989.
12 Fishbein M, Azjen I. Beliefs, attitudes, intention and behavior: an introduction to theory and research. Reading, MA: Addison-Wesley; 1975.
13 Prochaska JO. Systems of psychotherapy. Homewood, IL: Dorsey Press; 1979.
14 Prochaska J O, DiClemente C C, Norcross J C. In search of how people change. Applications to addictive behaviors. Am Psychol. Sep. 1992;47(9):1102-14. [pmid: 1329589].
15 Rimer B K. Mammography use in the U.S.: Trends and the impact of interventions. Ann Behav Med. 1994;16(4):317-26.
16 Granados A, Jonsson E, Banta H D, et al. EUR-ASSESS Project Subgroup Report on Dissemination and Impact. Int J Technol Assess Health Care. 1997;13(2):220-86. [pmid: 9194353].
17 Grimshaw J M, Shirran L, Thomas R, et al. Changing provider behavior: an overview of systematic reviews of interventions. Med Care. Aug. 2001;39(8 Suppl 2):112-45. [pmid: 11583120].
18 Li F P. Cancer control in susceptible groups: opportunities and challenges. J Clin Oncol. Feb. 1999;17(2):719-25. [pmid: 10080618].
19 American Cancer Society. Cancer facts and figures-1999. Internet. http://www.cancer.org/downloads/STT/CancerFacts&Figures1999TM.pdf
20 Ries LAG, Kosary CL, Hankey BF. SEER cancer statistics review, 1973-1994. Bethesda, MD; National Cancer Institute, National Institute of Health; 1997.
21 Hiatt R A, Rimer B K. A new strategy for cancer control research. Cancer Epidemiol Biomarkers Prev. Nov. 1999;8(11):957-64. [pmid: 10566549].
22 Anonymous. Bridging research to action: a framework and decision-making process for cancer control. Advisory Committee on Cancer Control, National Cancer Institute of Canada. CMAJ 1994 Oct 15;151(8):1141–6.
23 Anonymous. Effective Public Health Practice Project. Internet. Last accessed May 29, 2002. http://www.city.hamilton.on.ca/sphs/EPHPP/
24 Sackett DL, Haynes BJ, Guyatt G, et al. How to read reviews. In: Clinical Epidemiology: A Basic Science for Clinical Medicine, 2nd edition Toronto: Little, Brown & Company; 1991. Chaper 13 p. 379–91.
25 Oxman A D, Cook D J, Guyatt G H. Users' guides to the medical literature. VI. How to use an overview. Evidence-Based Medicine Working Group. JAMA. Nov 2. 1994;272(17):1367-71. [pmid: 7933399].
26 Anonymous. Effective Public Health Interventions Summaries/Reviews. Internet. Last accessed May 29, 2002. http://www.city.hamilton.on.ca/sphs/EPHPP/ephppSumRev.htm
27 Berlin J A. Does blinding of readers affect the results of meta-analyses? University of Pennsylvania Meta-analysis Blinding Study Group. Lancet. Jul 19. 1997;350(9072):185-6. [pmid: 9250191].
28 Clarke M, Oxman AD. Cochrane Reviewers' Handbook 4.1.5 [updated April 2002]. In: The Cochrane Library, 2002. Issue 2. Oxford: Update Software. Updated quarterly
29 Jadad A R, Moore R A, Carroll D, et al. Assessing the quality of reports of randomized clinical trials: is blinding necessary?. Control Clin Trials. Feb. 1996;17(1):1-12. [pmid: 8721797].
30 Thomas H, Micucci S, Thompson O'Brien MA, and Briss P. Towards a reliable and valid instrument for quality assessment of primary studies in public health. 2001. Unpublished work.
31 Anonymous. Guide to Community Preventive Health Services. Internet. Last accessed May 29, 2002. http://www.thecommunityguide.org/home_f.html
32 Anonymous. Annual smoking-attributable mortality, years of potential life lost, and economic costs--United States, 1995-1999. MMWR 2002 Apr 12;51(14):300–3.
33 Edwards B K, Howe H L, Ries L A G, et al. Communication: Annual report to the Nation on the status of cancer, 1973-1999, featuring implications of age and ageing on U.S. cancer burden. Cancer. 2002;94(10):2766-92. [pmid: 12173348].
34 Anonymous. Cigarette smoking among adults--United States, 2000. MMWR 2002 Jul 26;51(29):642–5.
35 Anonymous. State-specific prevalence of current cigarette smoking among adults, and policies and attitudes about secondhand smoke--United States, 2000. MMWR 2001 Dec 14;50(49):1101–6.
36 U.S.Department of Health and Human Services. Healthy people 2010: Understanding and improving health. 2nd ed. Washington, DC: U.S. Goverment Printing Office; 2000.
37 Anderson L A, Janes G R, Jenkins C. Implementing preventive services: to what extent can we change provider performance in ambulatory care? A review of the screening, immunization, and counseling literature. Ann Behav Med. 1998;20(3):161-7. [pmid: 9989322].
38 Davis D A, Thomson M A, Oxman A D, et al. Evidence for the effectiveness of CME. A review of 50 randomized controlled trials. JAMA. Sep 2. 1992;268(9):1111-7. [pmid: 1501333].
39 Davis D A, Thomson M A, Oxman A D, et al. Changing physician performance. A systematic review of the effect of continuing medical education strategies. JAMA. 1995;274(9):700-5. [pmid: 7650822].
40 Ebrahim S, Smith G D. Systematic review of randomised controlled trials of multiple risk factor interventions for preventing coronary heart disease. BMJ. Jun 7. 1997;314(7095):1666-74. [pmid: 9193292]. [pmcid: 2126863].
41 France E K, Glasgow R E, Marcus A C. Smoking cessation interventions among hospitalized patients: what have we learned?. Prev Med. Apr. 2001;32(4):376-88. [pmid: 11304099].
42 Freemantle N, Harvey EL, Wolf F, et al. Printed educational materials: effects on professional practice and health care outcomes (Cochrane Review). In: The Cochrane Library, 2001. Issue 3. Oxford: Update Software.
43 Grilli R, Freemantle N, Minozzi S, et al. Mass media interventions: effects on health services utilisation (Cochrane Review). In: The Cochrane Library, 2001. Issue 1. Oxford: Update Software.
44 Hulscher MEJL, Wensing M, van d, et al. Interventions to implement prevention in primary care (Cochrane Review). In: The Cochrane Library, 2001. Issue 3. Oxford: Update Software.
45 Ketola E, Sipila R, Makela M. Effectiveness of individual lifestyle interventions in reducing cardiovascular disease and risk factors. Ann Med. May. 2000;32(4):239-51. [pmid: 10852140].
46 Krummel D A, Koffman D M, Bronner Y, et al. Cardiovascular health interventions in women: What works?. J Womens Health Gend Based Med. Mar. 2001;10(2):117-36. [pmid: 11268297].
47 Law M, Tang J L. An analysis of the effectiveness of interventions intended to help people stop smoking. Arch Intern Med. Oct 9. 1995;155(18):1933-41. [pmid: 7575046].
48 McDonnell A, Crookes P, Davies S, et al. Practice nurses and the prevention of cardiovascular disease and stroke: a literature review to promote evidence-based practice. Part 1: rationale, review methods, effectiveness of practice nurses and smoking cessation. Clin Effectiveness Nurs. Dec. 1997;1(4):189-97.
49 Munafo M, Rigotti N, Lancaster T, et al. Interventions for smoking cessation in hospitalised patients: a systematic review. Thorax. Aug. 2001;56(8):656-63. [pmid: 11462070].
50 Oxman A D, Thomson M A, Davis D A, et al. No magic bullets: a systematic review of 102 trials of interventions to improve professional practice. CMAJ. Nov 15. 1995;153(10):1423-31. [pmid: 7585368]. [pmcid: 1487455].
51 Revere D, Dunbar P J. Review of computer-generated outpatient health behavior interventions: clinical encounters “in absentia”. JAMIA. Jan. 2001;8(1):62-79. [pmcid: 134592]. [pmid: 11141513].
52 Rigotti NA, Munafo MR, Murphy MFG, et al. Interventions for smoking cessation in hospitalised patients (Cochrane Review). In: The Cochrane Library, 2001. Issue 3. Oxford: Update Software.
53 Rimer BK, Glassman B. Is there a use for tailored print communications in cancer risk communication? J Natl Cancer Inst Monographs 1999;(25):140–8.
54 Skinner C S, Campbell M K, Rimer B K, et al. How effective is tailored print communication?. Ann Behav Med. 1999;21(4):290-8. [pmid: 10721435].
55 Thompson O'Brien MA, Oxman AD, Davis DA, et al. Educational outreach visits: effects on professional practice and health care outcomes (Cochrane Review). In: The Cochrane Library, 2001. Issue 3. Oxford: Update Software.
56 Thompson O'Brien MA, Freemantle N, Oxman AD, et al. Continuing education meetings and workshops: effects on professional practice and health care outcomes (Cochrane Review). In: The Cochrane Library, 2001. Issue 3. Oxford: Update Software.
57 Viswesvaran C, Schmidt F L. A meta-analytic comparison of the effectiveness of smoking cessation methods. J Appl Psychol. Aug. 1992;77(4):554-61. [pmid: 1387394].
58 Ashenden R, Silagy C, Weller D. A systematic review of the effectiveness of promoting lifestyle change in general practice. Fam Pract. Apr. 1997;14(2):160-76. [pmid: 9137956].
59 Bains N, Pickett W, Hoey J. The use and impact of incentives in population-based smoking cessation programs: a review. Am J Health Promot. May. 1998;12(5):307-20. [pmid: 10181140].
60 Fiore MC, Bailey WC, Cohen SJ, et al. Treating tobacco use and dependence. Clinical Practice Guideline. Rockville, MD: U.S.Department of Health and Human Services: Public Health Service; 2000.
61 Hopkins D P, Briss P A, Ricard C J, et al. Reviews of evidence regarding interventions to reduce tobacco use and exposure to environmental tobacco smoke. Am J Prev Med. Feb. 2001;20(Suppl 2):16-66. [pmid: 11173215].
62 Lancaster T, Stead LF. Individual behavioural counselling for smoking cessation (Cochrane Review). In: The Cochrane Library, 2001. Issue 3. Oxford: Update Software.
63 Lancaster T, Stead LF. Self-help interventions for smoking cessation (Cochrane Review). In: The Cochrane Library, 2001. Issue 3. Oxford: Update Software.
64 Lancaster T, Silagy C, Fowler G. Training health professionals in smoking cessation (Cochrane Review). In: The Cochrane Library, 2001. Issue 3. Oxford: Update Software.
65 Mullen P D, Simons-Morton D G, Ramirez G, et al. A meta-analysis of trials evaluating patient education and counseling for three groups of preventive health behaviors. Patient Educ Couns. 1997;32(3):157-73. [pmid: 9423498].
66 Rice VH, Stead LF. Nursing interventions for smoking cessation (Cochrane Review). In: The Cochrane Library, 2001. Issue 3. Oxford: Update Software.
67 Silagy C, Stead LF. Physician advice for smoking cessation (Cochrane Review). In: The Cochrane Library, 2001. Issue 3. Oxford: Update Software.
68 Stead LF, Lancaster T. Telephone counselling for smoking cessation (Cochrane Review). In: The Cochrane Library, 2001. Issue 3. Oxford: Update Software.
69 Lichtenstein E, Glasgow R E, Lando H A, et al. Telephone counseling for smoking cessation: rationales and meta-analytic review of evidence. Health Educ Res. Jun. 1996;11(2):243-57. [pmid: 10163409].
70 Matson D M, Lee J W, Hopp J W. The impact of incentives and competitions on participation and quit rates in worksite smoking cessation programs. Am J Health Promot. Mar. 1993;7(4):270-80. [pmid: 10146850].
71 Ritvo P G, Irvine M J, Lindsay E A, et al. A critical review of research related to family physician-assisted smoking cessation interventions. Cancer Prev Control. Oct. 1997;1(4):289-303. [pmid: 9765753].
72 Pederson L L, Ahluwalia J S, Harris K J, et al. Smoking cessation among African Americans: what we know and do not know about interventions and self-quitting. Prev Med. Jul. 2000;31(1):23-38. [pmid: 10896841].
73 Silagy C, Lancaster T, Gray S, et al. Effectiveness of training health professionals to provide smoking cessation interventions: systematic review of randomised controlled trials. Qual Health Care. Dec. 1994;3(4):193-8. [pmid: 10140233].
74 Rice V H. Nursing intervention and smoking cessation: A meta-analysis. Heart Lung. Nov. 1999;28(6):438-54. [pmid: 10580218].
75 Fiore M C. US public health service clinical practice guideline: treating tobacco use and dependence. Respir Care. Oct. 2000;45(10):1200-62. [pmid: 11054899].
76 Doll R, Peto R. The causes of cancer: quantitative estimates of avoidable risks of cancer in the United States today. J Natl Cancer Inst. Jun. 1981;66(6):1191-308. [pmid: 7017215].
77 Anonymous. Food, nutrition and the prevention of cancer, a global perspective. American Insititute for Cancer Reserach; 1997.
78 Muñoz de Chávez M, Chávez A. Diet that prevents cancer: recommendations from the American Institute for Cancer Research. Int J Cancer. 1998;11:85-9.
79 The American Cancer Society 1996 Advisory Committee on Diet Nutrition and Cancer Prevention. Guidelines on diet, nutrition, and cancer prevention: reducing the risk of cancer with healthy food choices and physical activity. CA Cancer J Clin 1996 Nov;46(6):325–41.
80 Butrum R R, Clifford C K, Lanza E. NCI dietary guidelines: rationale. Am J Clin Nutr. Sep. 1988;48(Suppl 3):888-95. [pmid: 3046317].
81 Kirby S D, Baranowski T, Reynolds K D, et al. Children's fruit and vegetable intake: socioeconomic, adult-child, regional, and urban-rural influences. J Nutr Educ. Sep. 1995;27(5):261-71.
82 Glanz K. Reducing breast cancer risk through changes in diet and alcohol intake: from clinic to community. Ann Behav Med. 1994;16(4):334-46.
83 Dunn C, Deroo L, Rivara F P. The use of brief interventions adapted from motivational interviewing across behavioral domains: A systematic review. Addiction. 2001;96(12):1725-42. [pmid: 11784466].
84 Simons-Morton D G, Mullen P D, Mains D A, et al. Characteristics of controlled studies of patient education and counseling for preventive health behaviors. Patient Educ Couns. 1992;19(2):175-204. [pmid: 1299821].
85 Ammerman A, Lindquist C, Hersey J et al. Efficacy of interventions to modify dietary behavior related to cancer risk. Evidence Report/Technology Assessment, No. 25. Rockville, MD: U.S. Department of Health and Human Services, Agency for Health Care Research and Quality; 2001. AHRQ Publication N. 01-E029.
86 Brunner E, White I, Thorogood M, et al. Can dietary interventions change diet and cardiovascular risk factors? A meta-analysis of randomized controlled trials. Am J Public Health. Sep. 1997;87(9):1415-22. [pmid: 9314790]. [pmcid: 1380963].
87 Ciliska D, Miles E, Thompson O'Brien M A, et al. Effectiveness of community-based interventions to increase fruit and vegetable consumption. J Nutr Educ. Nov. 2000;32(6):341-52.
88 Contento I, Balch G I, Bronner Y L, et al. The effectiveness of nutrition education and implications for nutrition education policy, programs and research: a review of research. J Nutr Educ. 1995;27(6):277-422.
89 Glanz K, Gilboy M B. Physicians, preventive care, and applied nutrition: selected literature. Acad Med. Nov. 1992;67(11):776-81. [pmid: 1418261].
90 Glanz K, Sorensen G, Farmer A. The health impact of worksite nutrition and cholesterol intervention programs. Am J Health Promot. Jul. 1996;10(6):453-70. [pmid: 10163311].
91 Wilcox S, Parra-Medina D, Thompson-Robinson M, et al. Nutrition and physical activity interventions to reduce cardiovascular disease risk in health care settings: a quantitative review with a focus on women. Nutr Rev. Jul. 2001;59(7):197-214. [pmid: 11475446].
92 Patterson R E, Kristal A R, Biener L, et al. Durability and diffusion of the nutrition intervention in the Working Well Trial. Prev Med. Sep. 1998;27(5:Pt 1):668-73. [pmid: 9808797].
93 Anonymous. HHS News: HHS affirms value of mammography for detecting breast cancer. Internet. http://www.hhs.gov/news/press/2002pres/20020221.html
94 Balas E A, Weingarten S, Garb C T, et al. Improving preventive care by prompting physicians. Arch Intern Med. Feb 14. 2000;160(3):301-8. [pmid: 10668831].
95 Bonfill X, Marzo M, Pladevall M, et al. Strategies for increasing women participation in community breast cancer screening (Cochrane Review). In: The Cochrane Library, 2001. Issue 1. Oxford: Update Software.
96 Jepson R, Clegg A, Forbes C, et al. The determinants of screening uptake and interventions for increasing uptake: a systematic review. Health Technology Assessment (Rockville, Md) 2000;4(14):i-415
97 Kupets R, Covens A. Strategies for the implementation of cervical and breast cancer screening of women by primary care physicians. Gynecol Oncol. 2001;83(2):186-97. [pmid: 11606071].
98 Legler J, Meissner H I, Coyne C, et al. The effectiveness of interventions to promote mammography among women with historically lower rates of screening. Cancer Epidemiol Biomarkers Prev. Jan. 2002;11(1):59-71. [pmid: 11815402].
99 Mandelblatt J, Kanetsky P A. Effectiveness of interventions to enhance physician screening for breast cancer. J Fam Pract. Feb. 1995;40(2):162-71. [pmid: 7654272].
100 Mandelblatt J S, Yabroff K R. Effectiveness of interventions designed to increase mammography use: a meta-analysis of provider-targeted strategies. Cancer Epidemiol Biomarkers Prev. Sep. 1999;8(9):759-67. [pmid: 10498394].
101 Ratner P A, Bottorff J L, Johnson J L, et al. A meta-analysis of mammography screening promotion. Cancer Detect Prev. 2001;25(2):147-60. [pmid: 11341350].
102 Shea S, DuMouchel W, Bahamonde L. A meta-analysis of 16 randomized controlled trials to evaluate computer-based clinical reminder systems for preventive care in the ambulatory setting. JAMIA. Nov. 1996;3(6):399-409. [pmcid: 116324]. [pmid: 8930856].
103 Shekelle PG, Stone EG, Maglione MA. Interventions that increase the utilization of Medicare funded preventive services for persons age 65 and older. Evidence Report/Technology assessment, U.S. Department of Health and Human Services: Health Care Financing Administration; 1999. Publication No. HCFA-02151.
104 Sin J P, St Leger A S. Interventions to increase breast screening uptake: do they make any difference?. J Med Screen. 1999;6(4):170-81. [pmid: 10693060].
105 Snell J L, Buck E L. Increasing cancer screening: a meta-analysis. Prev Med. Nov. 1996;25(6):702-7. [pmid: 8936572].
106 Wagner T H. The effectiveness of mailed patient reminders on mammography screening: a meta-analysis. Am J Prev Med. Jan. 1998;14(1):64-70. [pmid: 9476837].
107 Yabroff K R, Mandelblatt J S. Interventions targeted toward patients to increase mammography use. Cancer Epidemiol Biomarkers Prev. Sep. 1999;8(9):749-57. [pmid: 10498393].
108 Yabroff K R, O'Malley A, Mangan P, et al. Inreach and outreach interventions to improve mammography use. J Am Med Womens Assoc. 2001;56(4):166-73. [pmid: 11759785].
109 Meissner H I, Breen N, Coyne C, et al. Breast and cervical cancer screening interventions: an assessment of the literature. Cancer Epidemiol Biomarkers Prev. Oct. 1998;7(10):951-61. [pmid: 9796642].
110 American Cancer Society. Cervical Cancer and Pap Test Information. Internet. http://www.cdc.gov/cancer/nbccedp/info-cc.htm
111 Sawaya G F, Grimes D A. New technologies in cervical cytology screening: a word of caution. Obstet Gynecol. Aug. 1999;94(2):307-10. [pmid: 10432148].
112 Sung H Y, Kearney K A, Miller M, et al. Papanicolaou smear history and diagnosis of invasive cervical carcinoma among members of a large prepaid health plan. Cancer. May 15. 2000;88(10):2283-9. [pmid: 10820350].
113 Austin SM, Balas EA, Mitchell JA, et al. Effect of physician reminders on preventive care: meta-analysis of randomized clinical trials. Proceedings - the Annual Symposium on Computer Applications in Medical Care 1994;121–4.
114 Pirkis J E, Jolley D, Dunt D R. Recruitment of women by GPs for Pap tests: a meta-analysis. Br J Gen Pract. Sep. 1998;48(434):1603-7. [pmid: 9830190]. [pmcid: 1313228].
115 Tseng D S, Cox E, Plane M B, et al. Efficacy of patient letter reminders on cervical cancer screening: a meta-analysis. J Gen Intern Med. Aug. 2001;16(8):563-8. [pmid: 11556935]. [pmcid: 1495254].
116 Thompson O'Brien MA, Oxman AD, Davis DA, et al. Audit and feedback versus alternative strategies: effects on professional practice and health care outcomes (Cochrane Review). In: The Cochrane Library, 2000. Issue 2. Oxford: Update Software.
117 Thompson O'Brien MA, Oxman AD, Davis DA, et al. Audit and feedback: effects on professional practice and health care outcomes. In: The Cochrane Library, 2002. Issue 1. Oxford: Update Software.
118 Lynagh M, Schofield M J, Sanson-Fisher R W. School Health Promotion Programs over the Past Decade: A Review of the Smoking, Alcohol and Solar Protection Literature. Health Promotion Int. Dec 1. 1997;12(1):43-60.
119 Jadad A R, Browman G P. The WHO analgesic ladder for cancer pain management. Stepping up the quality of its evaluation. JAMA. Dec. 1995;274(23):1870-3. [pmid: 7500538].
120 Chelf J H, Agre P, Axelrod A, et al. Cancer-related patient education: an overview of the last decade of evaluation and research. Oncol Nurs Forum. Aug. 2001;28(7):1139-47. [pmid: 11517847].
121 Thompson O'Brien MA, Oxman AD, Haynes RB, et al. Local opinion leaders: effects on professional practice and health care outcomes (Cochrane Review). In: The Cochrane Library, 2000. Issue 2. Oxford: Update Software.
122 Allard P, Maunsell E, Labbe J, et al. Educational interventions to improve cancer pain control: a systematic review. J Palliat Med. 2001;4(2):191-203. [pmid: 11441627].
123 World Health Organization. Cancer Pain Relief. Geneva, Switzerland: World Health Organization; 1986.
124 Cockburn J, Ruth D, Silagy C, et al. Randomised trial of three approaches for marketing smoking cessation programmes to Australian general practitioners. BMJ. Mar 14. 1992;304(6828):691-4. [pmid: 1571645]. [pmcid: 1881508].
125 Mullins R, Livingston P, Borland R. A strategy for involving general practitioners in smoking control. Aust N Z J Public Health. Jun. 1999;23(3):249-51. [pmid: 10388167].
126 Boyd N R, Sutton C, Orleans C T, et al. Quit Today! A targeted communications campaign to increase use of the cancer information service by African American smokers. Prev Med. Sep. 1998;27(5:Pt 2):S50-S60. [pmid: 9808824].
127 Elder J P, Campbell N R, Mielchen S D, et al. Implementation and evaluation of a community-sponsored smoking cessation contest. Am J Health Promot. Jan. 1991;5(3):200-7. [pmid: 10148669].
128 Wilson E E, Tweed W A. Pharmacists' role in smoking cessation. Can Pharm J. Apr. 1984;117(4):156-7. [pmid: 10266366].
129 Epps R P, Manley M W, Husten C G, et al. Transfer of preventive health programs to physicians' practices through medical organizations. Am J Prev Med. Jan. 1998;14(1):25-30. [pmid: 9476833].
130 Marin G, Perez-Stable E J. Effectiveness of disseminating culturally appropriate smoking-cessation information: Programa Latino Para Dejar de Fumar. J Natl Cancer Inst Monographs. 1995;18:155-63. [pmid: 8562216].
131 Cummings KM, Sciandra R, Davis S, et al. Results of an antismoking media campaign utilizing the Cancer Information Service. J Natl Cancer Inst Monographs 1993;(14):113–8.
132 Marin G, Marin B V, Perez-Stable E J, et al. Changes in information as a function of a culturally appropriate smoking cessation community intervention for Hispanics. Am J Community Psychol. Dec. 1990;18(6):847-64. [pmid: 2091458].
133 Fowler G, Mant D, Fuller A, et al. The “Help Your Patient Stop” initiative. Evaluation of smoking prevalence and dissemination of WHO/UICC guidelines in UK general practice. Lancet. Jun 3. 1989;1(8649):1253-5. [pmid: 2566792].
134 Albright C L, Farquhar J W, Fortmann S P, et al. Impact of a clinical preventive medicine curriculum for primary care faculty: Results of a dissemination model. Prev Med. 1992;21(4):419-35. [pmid: 1409485].
135 Cummings K M, Sciandra R, Davis S, et al. Response to anti-smoking campaign aimed at mothers with young children. Health Educ Res. 1989;4(4):429-37.
136 Muramoto M L, Connolly T, Strayer L J, et al. Tobacco cessation skills certification in Arizona: application of a state wide, community based model for diffusion of evidence based practice guidelines. Tob Control. Dec. 2000;9(4):408-14. [pmid: 11106711].
137 Sorensen G, Thompson B, Basen-Engquist K, et al. Durability, dissemination, and institutionalization of worksite tobacco control programs: Results from the working well trial. Int J Behav Med. 1998;5(4):335-51. [pmid: 16250700].
138 Tremblay M, Gervais A, Lacroix C, et al. Physicians Taking Action Against Smoking: an intervention program to optimize smoking cessation counselling by Montreal general practitioners. CMAJ. Sep 4. 2001;165(5):601-7. [pmcid: 81419]. [pmid: 11563213].
139 Perez-Stable E J, Marin B V, Marin G. A comprehensive smoking cessation program for the San Francisco Bay Area Latino community: Programa Latino Para Dejar de Fumar. Am J Health Promot. Jul. 1993;7(6):430-42. [pmid: 10146254].
140 Anderson D M, Meissner H I, Portnoy B. Media use and the health information acquisition process: How callers learned about the NCI's Cancer Information Service. Health Educ Res. 1989;4:419-27.
141 Pierce J P, Anderson D M, Romano R M, et al. Promoting smoking cessation in the United States: effect of public service announcements on the Cancer Information Service telephone line. J Natl Cancer Inst. May 6. 1992;84(9):677-83. [pmid: 1569601].
142 O'Loughlin J, Makni H, Tremblay M, et al. Smoking cessation counseling practices of general practitioners in Montreal. Prev Med. Dec. 2001;33(6):627-38. [pmid: 11716660].
143 Lemelin J, Hogg W, Baskerville N. Evidence to action: a tailored multifaceted approach to changing family physician practice patterns and improving preventive care. CMAJ. Mar 20. 2001;164(6):757-63. [pmcid: 80870]. [pmid: 11276541].
144 Dietrich A J, O'Connor G T, Keller A, et al. Cancer: improving early detection and prevention. A community practice randomised trial. BMJ. Mar 14. 1992;304(6828):687-91. [pmid: 1571644]. [pmcid: 1881551].
145 Dwyer T, Pierce J P, Hannam C D, et al. Evaluation of the Sydney “Quit. For Life” anti-smoking campaign. Part 2. Changes in smoking prevalence. Med J Aust. Mar 31. 1986;144(7):344-7. [pmid: 3485760].
146 Pierce J P, Dwyer T, Frape G, et al. Evaluation of the Sydney “Quit. For Life” anti-smoking campaign. Part 1. Achievement of intermediate goals. Med J Aust. Mar 31. 1986;144(7):341-4. [pmid: 3959949].
147 Buller D B, Morrill C, Taren D, et al. Randomized trial testing the effect of peer education at increasing fruit and vegetable intake (Study A). J Natl Cancer Inst. Sep 1. 1999;91(17):1491-500. [pmid: 10469751].
148 Buller D, Buller M K, Larkey L, et al. Implementing a 5-a-day peer health educator program for public sector labor and trades employees. Health Educ Behav. Apr. 2000;27(2):232-40. [pmid: 10768804].
149 Larkey L K, Alatorre C, Buller D B, et al. Communication strategies for dietary change in a worksite peer educator intervention. Health Educ Res. Dec. 1999;14(6):777-90. [pmid: 10585385].
150 Samuels S E. Project LEAN--lessons learned from a national social marketing campaign. Public Health Rep. Jan. 1993;108(1):45-53. [pmid: 8434097]. [pmcid: 1403329].
151 Tziraki C, Graubard B I, Manley M, et al. Effect of training on adoption of cancer prevention nutrition-related activities by primary care practices: results of a randomized, controlled study. J Gen Intern Med. Mar. 2000;15(3):155-62. [pmid: 10718895]. [pmcid: 1495352].
152 Buller D B, Morrill C, Taren D, et al. Randomized trial testing the effect of peer education at increasing fruit and vegetable intake (Study B). J Natl Cancer Inst. Sep 1. 1999;91(17):1491-500. [pmid: 10469751].
153 Kinsinger L S, Harris R, Qaqish B, et al. Using an office system intervention to increase breast cancer screening. J Gen Intern Med. Aug. 1998;13(8):507-14. [pmid: 9734786]. [pmcid: 1497003].
154 Paskett E D, Masten K B, Phillips K C, et al. Receptivity of a worksite breast cancer screening education program. Health Educ Res. Oct. 1999;14(5):667-74. [pmid: 10510074].
155 Scott T L, Wong F L, Rimer B K. Dissemination of an evidence-based intervention manual to improve managed care mammography rates. Managed Care Interface. Feb. 1999;12(2):83-8. [pmid: 10346191].
156 Williams P T, Eckert G, Epstein A, et al. In-office cancer-screening education of primary care physicians. J Cancer Educ. 1994;9(2):90-5. [pmid: 7522508].
157 Breitbart W, Rosenfeld B, Passik S D. The Network Project: a multidisciplinary cancer education and training program in pain management, rehabilitation, and psychosocial issues. J Pain Symptom Manage. Jan. 1998;15(1):18-26. [pmid: 9436338].
158 Du Pen A R, Du P S, Hansberry J, et al. An educational implementation of a cancer pain algorithm for ambulatory care. Pain Manage Nurs. Dec. 2000;1(4):116-28.
159 Weissman D E, Dahl J L. Update on the cancer pain role model education program. J Pain Symptom Manage. May. 1995;10(4):292-7. [pmid: 7541436].
160 Altman D G, Bland J M. Statistics notes. Units of analysis. BMJ. Jun 28. 1997;314(7098):1874. [pmid: 9224131]. [pmcid: 2127005].
161 Wears R L. Advanced statistics: statistical methods for analyzing cluster and cluster-randomized data. Acad Emerg Med. Apr. 2002;9(4):330-41. [pmid: 11927463].
162 Moher D, Schulz K F, Altman D. The CONSORT statement: revised recommendations for improving the quality of reports of parallel-group randomized trials. JAMA. Apr 18. 2001;285(15):1987-91. [pmid: 11308435].
163 Stroup D F, Berlin J A, Morton S C, et al. Meta-analysis of observational studies in epidemiology: a proposal for reporting. Meta-analysis Of Observational Studies in Epidemiology (MOOSE) group. JAMA. Apr 19. 2000;283(15):2008-12. [pmid: 10789670].
164 Fiore MC, Bailey WC, Cohen SJ et al. Smoking Cessation: Clinical Practice Guideline. Clinical Practice Guideline, No. 18. Washington DC: U.S.Department of Health and Human Services, Agency for Health Care Policy and Research; 1996. 96-0692.
165 Anonymous. A clinical practice guideline for treating tobacco use and dependence: A US Public Health Service report. The Tobacco Use and Dependence Clinical Practice Guideline Panel, Staff, and Consortium Representatives. JAMA 2000 Jun 28;283(24):3244–54.
166 Briss P A, Zaza S, Pappaioanou M, et al. Developing an evidence-based Guide to Community Preventive Services-- methods. The Task Force on Community Preventive Services. Am J Prev Med. Jan. 2000;18(1 Suppl):35-43. [pmid: 10806978].
167 Wilson M G, Holman P B, Hammock A. A comprehensive review of the effects of worksite health promotion on health-related outcomes. [Review] [25 refs]. American Journal of Health Promotion. Jul. 1996;10(6):429-35. [pmid: 10163309].
168 Baskerville N B, Hogg W, Lemelin J. Process evaluation of a tailored multifaceted approach to changing family physician practice patterns improving preventive care. J Fam Pract. Mar. 2001;50(3):W242-W249. [pmid: 11252222].
169 Du Pen S L, Du Pen A R, Polissar N, et al. Implementing guidelines for cancer pain management: results of a randomized controlled clinical trial. J Clin Oncol. Jan. 1999;17(1):361-70. [pmid: 10458255].
170 Weissman D E, Dahl J L, Beasley J W. The Cancer Pain Role Model Program of the Wisconsin Cancer Pain Initiative. J Pain Symptom Manage. Jan. 1993;8(1):29-35. [pmid: 8482891].
171 Viswesvaran C, Schmidt F L. A meta-analytic comparison of the effectiveness of smoking cessation methods. J Appl Psychol. Aug. 1992;77(4):554-61. [pmid: 1387394].