# Acknowledgment

The authors of this report would like to thank and acknowledge the assistance of the following people:

Amy Steep and Tom Flemming of the McMaster University Health Sciences library for helping us with our searches, retrievals and the development of new methods to ‘work’ the library from off-site; Paul Ritvo, Linda Pederson, Annika Lillrank, Ann McDonnell, Elizabeth Kaegi, Helen Meissner, Cynthia Vinson and Diane van Abbe for providing us with documents we were otherwise unable to obtain; to Bridget Culhane for helping with the recruitment of peer reviewers; Dan Ellington from ISI Researchsoft for being so helpful in explaining how to manage our references and citations; to Rob Stevens and Lynda Booker for assistance with data abstraction; to Ann Fucic, Roxanne Cheeseman and Susan Hanna for taking the lead on the preparation of the manuscript and distribution of this report; and to Devon Christie, Erin Harvey, Carl Creatchman for their general assistance.