# Future Directions for Research

The transfer of new knowledge into practice remains a major issue in the delivery of healthcare today. While this review identifies a number of effective cancer control interventions to change provider or individual behavior, it also identifies a need for research into strategies to disseminate these interventions into practice.

Many of the primary studies identified by this report, which evaluated strategies used to disseminate cancer control interventions, demonstrated methodological limitations. The quality of these studies was generally weak and the study designs provided low levels of evidence to answer the questions that were posed. Therefore there are methodological issues that should be considered in future research:

- It is important that future dissemination research focuses on attempts to disseminate effective, evidence-based cancer control interventions
- Many of the studies identified in this review were primarily descriptive rather than evaluative. This raises questions about the most appropriate study designs for dissemination research. Issues for consideration include: what is the role of controlled trial designs in dissemination research? How can non-RCT types of studies make a stronger contribution to the field? What information can be provided from qualitative research (i.e., case studies)? Local barriers may be important factors that reduce the effectiveness of the interventions or the success of dissemination strategies
- What outcomes are important to consider in dissemination research? A number of outcomes can be considered in evaluating dissemination strategies. Much of the research has concentrated on process measures such as numbers of physicians educated, and numbers of individuals contacted. Behavioral outcomes including the delivery of interventions by healthcare professionals, or the uptake of behavioral change by individuals, should be evaluated in future research.
- Are cancer control interventions equally effective when they are more widely disseminated in the community?
- There is inconsistent use of terminology in the literature. Standardized criteria for reporting research findings have been developed in other areas including the CONSORT statement ^162^ for reporting RCTs and the MOOSE proposal ^163^ for observational studies in epidemiology. Would establishing criteria for reporting dissemination research help to clarify this field of research?

This report examined the strategies to disseminate cancer control interventions in the areas of adult smoking cessation, adult healthy diet, screening for breast and cervical cancer, plus control of cancer pain. However, other topics within the cancer control continuum were not addressed in this evidence report. As dissemination approaches may vary across topic areas, there is a need for further systematic reviews to synthesize available data in these areas too. Future systematic reviews should consider the following:

- What strategies have been used to disseminate cancer control interventions to promote other preventive behaviors such as increased physical activity or avoidance of exposure to ultraviolet radiation; screening activities including screening for colorectal cancer; and the therapeutic areas of cancer treatment and supportive care?
- What approaches have been undertaken to improve compliance/maintenance? Do the approaches to promote long-term behavioral change differ from those required to promote the uptake of behavioral change?
- What strategies are effective to improve recall following an abnormal screening examination? What strategies promote long-term adoption of screening behaviors?

Some suggestions for future research were common across several of the five topic areas examined in this evidence report. Those issues, along with several more general considerations that should be considered in future research examining diffusion and dissemination of cancer control interventions, include:

- How can theoretical models of behavior change inform future dissemination research?
- What approaches can be undertaken to make dissemination and dissemination research a routine component of intervention research?
- Do dissemination strategies along the cancer continuum differ from dissemination approaches in other areas of healthcare?
- What approaches can be undertaken to incorporate dissemination strategies into healthcare policy?
- What policy level interventions are effective at promoting dissemination of evidence-based cancer control interventions?
- What is the cost-effectiveness of different cancer control interventions and strategies to disseminate them? This may be an important local issue in determining approaches to dissemination.
- What is the role of new technologies in dissemination research? What is the potential of the Internet as a dissemination tool?
- Can audit and feedback, local opinion leaders, and educational outreach be used to effectively disseminate cancer control interventions? These approaches are effective interventions to change provider behavior in other situations, but have not been well evaluated in the topic areas examined in this evidence report.
- What characteristics of healthcare providers and individuals contribute to increased or decreased success of dissemination approaches?
- What is the most appropriate approach to combine provider and patient directed cancer control interventions?
- What is the importance of local barriers to effective dissemination of cancer control interventions?

Some additional issues were identified for future research that is specific to the individual topic areas in this evidence report. These are summarized below.

## Adult Smoking Cessation

Future research examining the dissemination of smoking cessation interventions should consider:

- What strategies are effective to disseminate office prompt/reminder systems to consistently identify smokers?
- What strategies are effective to disseminate the widespread use of physician advice to stop smoking?
- What are effective triage strategies amongst patients calling into Cancer Information Services to promote the use of effective smoking cessation interventions?

## Adult Healthy Diet

Future research examining the dissemination of interventions to promote healthy diet should consider:

- What is the effectiveness of reminder strategies for health professionals to give interventions in-patient encounters?
- Once media strategies have alerted the public to available services, can effective interventions then be disseminated to individuals in such a way that they will utilize them to change dietary habits? Or is there an effective combination or sequencing of strategies that will result in dietary change?

## Mammography

Future research examining the dissemination of interventions to promote mammographic screening for breast cancer should consider:

- Can worksites also be used to disseminate reminders and invitations for mammography to employees?
- What barriers exist for the dissemination and implementation of office system interventions?

## Screening for Cervical Cancer

Future research examining the dissemination of interventions to promote cervical cancer screening should consider:

- What strategies are effective to increase the use of physician-directed office system prompts?
- What strategies promote the use of reminder letters to patients?
- What are the barriers to successful dissemination of interventions proven to be effective to promote the uptake of cervical cancer screening?

## Control of Cancer Pain

There is a need for research into dissemination of interventions to promote control of cancer pain. Suggestions include:

- Strategies to disseminate treatment algorithms, or the transmission of patients pain scores to clinician
- Strategies to disseminate education or counseling of individuals with cancer pain

## Final Comments

Much of the focus of dissemination research in the cancer continuum to date has been evaluating interventions to promote behavior change. This evidence report highlights the lack of data on how to disseminate these findings into the community. There is a need to prioritize some of the suggestions above. Additionally there is a need for national agencies to provide leadership and funding for future dissemination research.