# Conclusions

There has been increased recognition in the healthcare arena of the need for processes to transfer new knowledge into routine practice. Traditional methods of knowledge transfer such as journals and conferences have not proven effective in changing behavior. ^17^ Emphasis has been placed on the importance of research examining the dissemination of evidence-based knowledge and its uptake by the targeted recipients. Target audiences include providers, policymakers and the general public.

The primary objective of this evidence report was to determine what strategies have been evaluated to more widely disseminate these interventions within five topic areas along the cancer control continuum. The five topic areas identified in conjunction with the nominating partner for this evidence report, the NCI were: adult smoking cessation, adult healthy diet, mammographic screening for breast cancer, screening for cervical cancer, and control of cancer pain.

A review of existing systematic reviews was undertaken to provide an overview of the state of evidence of cancer-control interventions to promote the uptake of behavior change. This review was limited to interventions addressing the five topics within prevention, screening strategies, and supportive care. A broader review of interventions to change provider behavior has been undertaken by Grimshaw et al. ^17^ Some of the findings of this review are in accord with those of Grimshaw et al. This overview identified various interventions that are effective in changing individual (consumer or patient) or healthcare provider behavior under certain circumstances. In general, interventions that were effective across many of the topic areas were reminder systems and/or advice by healthcare professionals. Furthermore, multicomponent interventions were more likely to be effective than single interventions. The number of reviews identified in this evidence report was limited, with the exception of the areas smoking cessation and mammography.

There was a paucity of research identified that examined policy level cancer control interventions in any of the five topic areas within the cancer control continuum. Furthermore, very few systematic reviews specifically evaluated the effectiveness of behavioral interventions that promote the uptake of cancer control behaviors in minority or socio-economically disadvantaged populations. The reviews that included subgroup populations in their analyses did show that interventions that were targeted and tailored could produce significant beneficial results.

The primary objective of this evidence report was accomplished by conducting a systematic review of primary studies that evaluated the dissemination of behavioral interventions (with or without evidence for their effectiveness). There was considerable amount of heterogeneity in the types of studies included in this review, which limited the interpretation of the evidence. The majority of the studies used descriptive, pre-test–post-test, and time-series designs to answer their questions.

Considerable variation in the outcomes assessed in these studies was observed. Outcomes ranged from process measures to behavioral outcomes. There was also a great deal of variation in the measurement methods. Some studies used self-reported methods of collecting data, whereas others used interviewer-assisted collection methods. The studies included in this review also lacked a consistent use of terminology related to diffusion, dissemination, and implementation. The lack of differentiation between studies evaluating the effectiveness of cancer control interventions and those evaluating strategies to disseminate such interventions was also evident. The reporting of the results was inconsistent, as some of the papers in this review did not provide adequate data for extraction. The studies included in this review used various time frames for data collection, further limiting the interpretation of the evidence.

Less intensive approaches such as mailing of materials to targeted populations were generally ineffective and were unlikely to result in behavior change when used alone. More active approaches to dissemination, such as train-the-trainer methods, media campaigns, and opinion leaders were more likely to be effective in inducing change in knowledge, attitudes, and behaviors when used alone or in combination.

## Summary of Findings of Primary Studies Focusing on Dissemination Strategies

### Adult Smoking Cessation

Eighteen primary studies were identified in the systematic review of dissemination strategies for smoking cessation interventions. A variety of study designs were employed. The majority of these studies used non-randomized designs to evaluate the dissemination strategy. Quality assessment of the studies was rated as “weak” quality except for three that were rated as “moderate”. None of the studies was rated as “strong”. The most common types of outcomes assessed in these studies were process or knowledge related.

The train-the-trainer approach was identified as a dissemination strategy that did improve the knowledge and awareness of the smoking cessation issues among health care providers, but none of these studies reported on the frequency of advice to quit smoking or smoking cessation rates. Recruitment of professional organizations as a strategy to promote the train-the-trainer model was also identified as a potentially effective dissemination strategy. There was some consistent evidence that media awareness campaigns, in particular television, are important strategies to disseminate information about Cancer Information Service (CIS) help lines. However, no information was provided about the type of smoking cessation interventions used subsequently. Several of the studies suggested that television is a more important source of media awareness for certain demographic groups, such as younger people and people from less educated and lower income groups. However, the studies generally did not provide information about the subsequent outcomes following the call to CIS.

### Adult Healthy Diet

The review of primary studies of dissemination strategies for dietary interventions identified seven studies. Overall, the quality of the evidence is not strong and is primarily descriptive rather than evaluative. Either process measures (numbers of calls, numbers of physicians educated, and number of education sessions held) were reported, or outcomes were often non-validated self-report measures. No clear conclusions can be drawn from these data. Controlled studies are needed to evaluate dissemination strategies, and to compare dissemination and diffusion strategies with different messages and different target audiences.

### Mammography

Six studies were identified that evaluated dissemination strategies for mammographic screening interventions. These data provide insufficient evidence to draw firm conclusions given both the small number of studies and the diversity in design and outcomes assessed. The studies identified by this systematic review serve more as a starting point to suggest what strategies may work and what factors could facilitate or impede successful dissemination and subsequent implementation of cancer control interventions that promote uptake of mammography.

### Cervical Cancer Screening

Four studies were identified that evaluated dissemination strategies for cervical cancer screening interventions. Three of these studies examined academic detailing as an approach to disseminate office system interventions. The fourth study evaluated the importance of different media sources for disseminating information about the CIS. None of the studies yielded promising results for disseminating interventions to increase cervical cancer screening. More research is required before conclusions can be made about the effectiveness of either of these strategies to disseminate interventions that promote cervical cancer screening.

### Control of Cancer Pain

Three studies were identified that evaluated dissemination strategies for control of cancer pain interventions. No studies evaluated the dissemination of the transmission of patients' self-reported pain scales to oncologists, and only one study evaluated the dissemination of treatment algorithms. This study reported a statistically significant improvement in healthcare professional overall adherence to the treatment algorithms. However, these differences were not maintained over the duration of the study. No dissemination studies directed at patients were located. Given the dearth of well-designed studies, it is difficult to come to any important conclusions about the effectiveness of any particular strategy to disseminate interventions to promote control of cancer pain.

## Summary Comments

In general, the majority of the evidence for strategies to disseminate cancer control interventions was identified for provider-directed interventions. There was a paucity of evidence related to the individual-directed interventions. The current evidence base in the area of dissemination is limited, but the findings of this evidence report provide valuable insight into the likely effectiveness of different strategies.

This evidence report did not evaluate the use of the different theoretical frameworks that have been proposed to elucidate the professional, patient, or public barriers and facilitators of behavior change. Evidence from other reviews by Grimshaw et al. ^17^ and Granados et al. ^16^ have described the potential usefulness of these models. More work is needed to validate the different theoretical frameworks. The most commonly identified barriers based on the results of this evidence report were related to the environment factors (e.g., financial incentives or administrative constraints), prevailing opinion (e.g., standards of practice or advocacy), and uncertainty (e.g., informational overload or sense of competence). These types of barriers have also been described by Grimshaw et al. ^17^ (2001) in their recent review of changing provider behavior.

Lastly, there is a need for agreement in the literature about the use of terminology. This review separates dissemination research into two categories. The first category is studies evaluating the effectiveness of interventions to change behavior. The second category of dissemination research is studies that more widely disseminate interventions of proven effectiveness. This distinction warrants further discussion in the literature, as the majority of papers do not make such an explicit distinction.

## Limitations of this Evidence Report

The results and conclusions of this evidence report are based on the information that was available in published English-language reports. Contact with authors could have resulted in identifying additional unpublished studies that may have reduced the likelihood of publication bias. Contact with the original authors of the report to supplement the missing information from the included studies could have compensated for many of the reporting difficulties described above. The budget and timelines available, however, were a limiting factor to achieving these tasks.

Another limitation of this report is that it does not include meta-analysis or some other quantitative synthesis of estimates of the relative effects of the interventions evaluated. However, quantitative synthesis was deemed inappropriate given the amount, heterogeneity, and quality of the data available. It is important to note that the systematic reviews that do not quantitatively synthesize the data can introduce other methodological challenges, such as biased narrative interpretation of the characteristics and the findings of the studies included. The inclusion of detailed evidence tables in this report is an attempt to allow consumers of this report to replicate findings and circumvent this problem of potentially biased interpretation.

The decision to conduct a review of systematic reviews of cancer control interventions was made with the knowledge that many systematic reviews had already been conducted in these areas. This reflected a desire to avoid replicating high quality work by other investigators. As there was no attempt to update any of these reviews, it is likely that recent research in these areas will not be incorporated in this review. Additionally, it is likely that less information was reported in the systematic reviews than in the primary studies concerning potential barriers, minority populations, and about the theoretical rationale behind the interventions. This limits our ability to comment on these areas.

A final limitation to the findings of this report is the potential for ‘unit of analysis’ errors ^160,^ ^161^ . This is particularly important where the effect sizes are not large. Many studies in this field of research utilize cluster randomization. However, the analyses of these studies may not use appropriate statistical methods to account for intra-cluster correlation. Therefore there is the potential to overestimate either the effect size or the precision with which it is measured. This issue is more pertinent for the review of systematic reviews, where it is generally unknown if unit of analysis errors in the primary studies has been considered. It was beyond the scope of this review to reanalyze the data for the systematic reviews. However, this issue needs to be considered in future studies or systematic reviews in this area.

Despite these limitations, this review provides valuable insight into the effectiveness of cancer control interventions and attempts to disseminate these interventions across a spectrum of areas of the cancer control continuum. It highlights the strengths of the existing research and, in particular, identifies a need to prioritize research into dissemination strategies for cancer control interventions (refer to Chapter 6 for further comments).