# Review of Reviews on the Effectiveness of Cancer Control Interventions

The purpose of this chapter is to provide an overview of cancer control interventions that are effective in promoting behavior change. This review of systematic reviews is focused on topics in the areas of cancer prevention, early detection, and supportive care. Five topics were selected based on NCI's cancer control priorities. These topics are: adult smoking cessation, adult healthy diet, mammography, cervical cancer screening, and control of cancer pain.

## Adult Smoking Cessation

### Key Question #1

What is the effectiveness of cancer control interventions that promote adult smoking cessation?

### Background

Tobacco-related health problems represent a large burden of illness and mortality to society and are the largest preventable cause of death. ^32^ Tobacco exposure is responsible for a spectrum of illness, including heart disease, cerebrovascular disease, chronic obstructive pulmonary disease, lung cancer, and a number of other malignancies. Over 80 percent of lung cancer cases can be attributed to smoking or exposure to cigarette smoke. ^32^ Lung cancer is the leading cause of death from cancer, with approximately 153,000 deaths annually. ^32,^ ^33^ The Center for Disease Control and Prevention (CDC) estimates that smoking caused approximately 440,000 deaths annually between 1995 and 1999 and approximately $157 billion in health related economic losses. ^32^ The median estimated prevalence of smoking in the US is 23.3 percent in men and 21 percent in women, ^34^ with considerable variation between regions. ^35^ Therefore, tobacco control represents a major public health issue. Reduction in consumption of tobacco products is an important goal of the US Department of Health and Human Services' Healthy People 2010. ^36^

A variety of cancer control interventions have been evaluated to promote uptake of adult smoking cessation. These interventions can be broadly classified as: interventions to increase the delivery of smoking cessation interventions by healthcare providers (healthcare provider-directed); interventions to promote uptake of smoking cessation by clients/consumers/general public (individual-directed); interventions to increase access by individuals to smoking cessation interventions (access enhancing interventions); media education campaigns; government/organization interventions to promote smoking cessation (policy level); and multicomponent interventions (combinations of the above).

This review examined systematic reviews of interventions to promote the uptake of smoking cessation behaviors among adult smokers. It did not address the areas of prenatal smoking cessation, pre-operative smoking cessation, exposure to environmental tobacco smoke, preventing initiation of primary tobacco use, or tobacco sales to minors. Additionally, reviews evaluating therapeutic interventions (e.g., nicotine replacement therapy [NRT], hypnosis, aversion therapy, or acupuncture) were not included following consultation with the NCI partners.

### Included Studies

The literature search identified 833 articles for title and abstract screening (Figure 3). Of these, 115 articles met the criteria and were eligible for full text screening. The remaining articles were either not systematic reviews, or did not address adult smoking cessation (see appendix D for guidelines for citation retrieval). Seventy-three articles did not meet eligibility criteria and were excluded. Fifteen unique reviews reported in 21 articles met the eligibility criteria for data to be extracted; 21 other articles also met the criteria for inclusion, but data on smoking cessation intervention approaches could not be extracted separately ^37–57,^ ^171^ (see General Table, Appendix G).

Figure 3. Adult Smoking Cessation: Search yield for studies evaluating the effectiveness of cancer control interventions (Key question #1)

The interventions addressed in these reviews are presented in Summary Table 1. These include healthcare provider-directed, individual patient-directed, access enhancing, media education campaigns, and multi-strategy intervention approaches.

Summary Table 1. Adult smoking cessation - Interventions addressed in systematic reviews of the effectiveness of cancer control interventions

Lead Author (year) | Healthcare provider directed interventions | | | | | Individual (patient)-directed interventions | | | | | | Accessenhancing interventions | | | Median education campaigns | Policy-level interventions | Multi-strategy interventions
| Healthcare provider training | Office systems (e.g., prompts) | Audit and feedback | Opinion Leaders | Other | Invitations or Reminders | Telephone counseling | Health-care provider advice | Educational materials | Social network | Other | Financial barriers | Access barriers | Other
Ashenden, R ^58^ (1997) | | | | | | | | ✓^ M ^
Bains, N ^59^ (1998) | | | | | | | | | | | ✓
Fiore, M ^75^ (2000) | | ✓^ M ^ | | | | | ✓^ M ^ | ✓^ M ^ | ✓^ M ^ | | ✓^ M ^
Hopkins, D ^61^ (2001) | ✓ | ✓ | ✓ | | | | ✓ | | ✓ | | ✓ | ✓ | | | ✓ | | ✓
Lancaster, T ^64^ (2001) | ✓
Lancaster, T ^62^ (2001) | | | | | | | | | | | ✓^ M ^
Lancaster, T ^63^ (2001) | | | | | | | | | ✓^M^
Lichtenstein, E ^69^ (1996) | | | | | | | ✓^M^
Matson, D ^70^ (1993) | | | | | | | | | | | ✓
Mullen, PD ^65^ (1997) | | | | | | | | | ✓^M^ | | ✓^M^
Pederson, LL ^72^ (2000) | ✓^ T ^ | ✓^ T ^ | | | | | | ✓^ T ^ | ✓^ T ^ | ✓^ T ^ | | | | | ✓^ T ^
Rice, V ^66^ (2001) | | | | | | | | ✓^ M ^ | | | ✓^ M ^
Ritvo, P ^71^ (1997) | ✓ | ✓ | | | | | ✓ | ✓ | ✓ | ✓ | ✓ | | | ✓
Silagy, C ^67^ (2001) | | | | | | | | ✓^ M ^
Stead, LF ^68^ (2001) | | | | | | | ✓ | | | | | | | | | | ✓

Legend: M=meta analysis performed; T=Target population specified

Quality assessment of the fifteen included systematic reviews was undertaken and the results are summarized in Summary Table 2. Eleven reviews ^58–68^ were rated as “strong”, three reviews ^69–71^ were rated as “moderate”, and one review ^72^ was rated as “weak” on the quality assessment tool for systematic reviews (see Appendix E for quality assessment tool). The most common weaknesses of the reviews were lack of quality assessment of the primary studies ^59,^ ^65,^ ^69–72^ followed by lack of integration of findings ^61,^ ^70–72^ and unclear or unstated search strategy ^69,^ ^71,^ ^72^ (Summary Table 2).

Summary Table 2. Quality assessment rating of included systematic reviews

Lead Author (Year) | Quality Assessment
| Qearch strategy stated | Comprehensive search | Level of evidence | Quality assessment | Integrate findings | Data support conclusions | Overall score (0–6) | Overall rating^a^
Ashenden, R ^58^ (1997) | ✓ | ✓ | ✓ | ✓ | ✓ | ✓ | 6 | STRONG
Bains, N ^59^ (1998) | ✓ | ✓ | ✓ | | ✓ | ✓ | 5 | STRONG
Fiore, M ^75^ (2000) | ✓^b^ | ✓^b^ | ✓ | | ✓ | ✓ | 5 | STRONG
Hopkins, D ^61^ (2001) | ✓ | ✓ | ✓ | ✓ | | ✓ | 5 | STRONG
Lancaster, T ^64^ (2001) | ✓ | ✓ | ✓ | ✓ | ✓ | ✓ | 6 | STRONG
Lancaster, T ^62^ (2001) | ✓ | ✓ | ✓ | ✓ | ✓ | ✓ | 6 | STRONG
Lancaster, T ^63^ (2001) | ✓ | ✓ | ✓ | ✓ | ✓ | ✓ | 6 | STRONG
Lichtenstein, E ^69^ (1996) | | ✓ | ✓ | | ✓ | ✓ | 4 | MODERATE
Matson, D ^70^ (1993) | ✓ | ✓ | ✓ | | | ✓ | 4 | MODERATE
Mullen, PD ^65^ (1997) | ✓ | ✓ | ✓ | | ✓ | ✓ | 5 | STRONG
Pederson, LL ^72^ (2000) | | | ✓ | | | ✓ | 2 | WEAK
Rice, V ^66^ (2001) | ✓ | ✓ | ✓ | ✓ | ✓ | ✓ | 6 | STRONG
Ritvo, P ^71^ (1997) | | ✓ | ✓ | | | ✓ | 3 | MODERATE
Silagy, C ^67^ (2001) | ✓ | ✓ | ✓ | ✓ | ✓ | ✓ | 6 | STRONG
Stead, LF ^68^ (2001) | ✓ | ✓ | ✓ | ✓ | ✓ | ✓ | 6 | STRONG

a Overall rating was based on overall score: ≤ 2=weak; 3–4=moderate; 5–6=strong

b This information was provided during a scheduled teleconference with NCI expert panel

Refer to Appendix E, Form 4 for full details on information collected for Quality Assessment

### Description of Systematic Reviews of Interventions to Promote Adult Smoking Cessation

Fifteen systematic reviews ^58–72^ from which data could be extracted on adult smoking cessation interventions met the eligibility criteria and were considered in this report (Evidence Table 1, Summary Tables 1 and 2).

#### Reviews of smoking cessation interventions as part of preventive healthcare services in family practice

Two reviews examined adult smoking cessation interventions as part of a larger review of the delivery of preventive healthcare services in family practice. ^58,^ ^65^ Ashenden et al. undertook a systematic review with meta-analysis of randomized controlled trials (RCTs) evaluating the effect of lifestyle advice provided by family practitioners, in changing patient behavior. ^58^ Lifestyle advice was defined as advice provided in the general practice setting to quit smoking, make dietary changes, reduce alcohol consumption, and exercise more. It was mainly verbal advice but could include written material. More intensive advice included additional followup by appointment, telephone, or letter. Data were analyzed separately for each topic.

The review by Mullen et al. included RCTs and non-RCTs evaluating patient education and counseling. ^65^ Education and counseling in this setting were advice on preventive health behavior to apparently healthy individuals seen in a clinical setting in a developed country. The analysis was broken down into three groups: smoking/alcohol, nutrition/weight, and other behaviors.

#### Reviews of multiple adult smoking cessation interventions

Four reviews of multiple adult smoking cessation interventions were identified. ^60,^ ^61,^ ^71,^ ^72^ Two comprehensive US public health reports on smoking cessation were identified. ^60,^ ^61^ These included systematic reviews of both single and multiple interventions. The Public Health Service (PHS) Clinical Practice Guideline is a comprehensive guideline that includes meta-analysis, addressing the broad issue of tobacco dependence treatments and practices. ^60^ These include a spectrum of cancer control interventions, along with pharmacologic interventions to assist patients attempting smoking cessation. A second report by Hopkins et al., presented a series of systematic reviews contained in the Task Force on Community Preventive Services (TFCPS) report on evidence regarding interventions to reduce tobacco use and exposure to environmental tobacco smoke. ^61^

A third review examined research related to family physician-assisted smoking cessation interventions. ^71^ This review analyzed biochemical measures of tobacco abstinence at six and 12 months. Pharmacologic interventions such as NRT were evaluated, as well as interventions to promote the uptake of smoking cessation. This makes comparison with the findings of other reviews more difficult. The fourth of these reviews examined the literature concerning smoking cessation interventions among African Americans. ^72^ Methodologically weak, the authors of this review specifically state they did not attempt to include all studies, but have included major studies to provide some indication of the patterns of results and comparisons of African American and Caucasian smokers and quitters. It has been discussed separately in a section on target populations.

#### Reviews of adult smoking cessation single interventions

Nine reviews evaluated adult smoking cessation single interventions. ^59,^ ^62–64^ ^66–70,^ ^73^ Bains et al. undertook a review of community- or population-based interventions that involved the use of financial incentives or competitions (e.g., vacation to Disney World) to promote participation in community-based smoking cessation programs. ^59^ The studies included in this review utilized pre—post-test comparisons, post-test measurements only, or quasi-experimental designs with comparison with state-wide or other population controls. Worksite incentive programs were specifically excluded from this review. However, the use of financial incentives and competitions to increase participation in worksite smoking cessation programs were the focus of another review by Matson et al. ^70^

One review by the Cochrane Tobacco Control Group focused primarily on the effectiveness of training healthcare professionals to provide smoking cessation interventions. ^64^ This review updated a prior systematic review by Silagy et al. ^73^ Training was generally provided in a group setting (e.g., workshop or tutorial), including lectures, videos, role plays, and discussion. Minimal contact strategies were emphasized. Meta-analysis was not utilized.

The remaining six systematic reviews in this category examined interventions directed at individuals. Two reviews examined healthcare provider advice to stop smoking: one directed to physicians ^67^ and one directed to nurses. ^66^ Advice was defined as verbal instructions from the healthcare professional with a “stop smoking” message. The review directed to nurses included brief interventions as well as higher-intensity interventions. ^66^ A second publication of this review was also identified. ^74^

Several reviews addressed some aspect of patient counseling. ^62,^ ^68,^ ^69^ Two reviews examined the effectiveness of telephone counseling for smoking cessation. ^68,^ ^69^ Stead and Lancaster ^68^ conducted a review with meta-analysis of 23 RCTs and quasi-randomized trials in which the primary question evaluated reactive or proactive telephone counseling. Proactive counseling includes studies in which a counselor initiates one or more calls to provide support in making an attempt to quit, whereas reactive counseling is provided by helplines that may offer information, recorded messages, personal counseling, or a mixture of components. Lichtenstein et al., ^69^ undertook a meta-analysis of 13 studies evaluating proactive telephone counseling. A third systematic review with meta-analysis examined RCTs and quasi-randomized trials of more intensive individual behavioral counseling by a smoking cessation counselor. ^62^ Counseling was defined broadly, based upon more than 10 minutes of face-to-face contact, rather than as the use of any specific behavioral approach.

The final paper in this category was a systematic review with meta-analysis examining studies in which the primary question addressed self-help interventions for smoking cessation. ^63^ Self-help interventions were any manual or program to be used by individuals to assist a quit attempt not aided by healthcare providers, counselors, or group support. Forty-five studies examined self-help interventions alone or in combination with NRT, additional educational materials or a video, provision of a helpline or telephone contact, or individualized materials.

The types of studies included in these 15 systematic reviews varied considerably. Some focused only on RCTs, whereas others included a variety of other study designs. Not all the systematic reviews used meta-analysis to combine the data. There was also variation in the outcomes assessed. Some reviews focused on process measures such as the proportion of patients in whom smoking cessation is discussed, whereas others looked at outcomes such as smoking cessation rates. Reviews reported point prevalence (percentage of smokers not smoking at time of assessment) and others reported on the proportion who had remained continuously abstinent. The time at which assessments were undertaken also varied (six months vs. 12 months). Some reviews relied on self-report of smoking cessation, while others utilized biochemical testing to confirm this. For these reasons, it was not possible to quantitatively combine the results of the systematic reviews. It also created difficulties in standardizing the reporting of findings of the systematic reviews in this report.

### Findings of Systematic Reviews

#### Healthcare provider-directed interventions

1. Physician training
  Three systematic reviews addressed the issue of training physicians to provide smoking cessation interventions. ^61,^ ^64,^ ^71^ Lancaster et al. ^64^ reported that training health professionals to provide smoking cessation interventions had a measurable effect on professional performance but there was no strong evidence that it changed smoking behavior. They reported that trained health professionals were 1.5 to 2.5 times more likely to counsel patients about smoking than controls. However, six of eight studies found no significant effect of practitioner training on smoking cessation rates. One other study reported sustained abstinence rates at 12 months of 8.8 percent for the trained group vs. 6.1 percent and 4.4 percent for control groups.
  The TFCPS Community Guide ^61^ evaluated 16 studies of provider education interventions. Determination of smoking status was increased by median of 8 percent (range 0.1 to 35 percent). Ten studies reported on provider delivery of advice to quit smoking. The median increase in provider advice to quit was 2.2 percent (range -5 to 73 percent) in comparison with control practitioners. Only two studies reported on smoking cessation rates. These studies reported a 1.7 percent and 5.3 percent increase in smoking cessation in comparison with controls. This review concluded there is insufficient evidence of the effectiveness of provider education alone as too few studies evaluate the effect on tobacco use cessation. Ritvo et al. ^71^ concluded that physician training has a modest effect on smoking cessation, but this effect is not quantified.
  PHS clinical practice guideline recommended that all clinicians and clinicians in training be trained in effective tobacco use treatments. ^60^ They stated that this recommendation was based on a review of the literature. However, data to support this recommendation were not included.
2. Office system prompts
  Two reviews addressed the issue of office prompts and reminders. ^60,^ ^61^ These reviews demonstrate that office reminder systems produce significant increases in tobacco use documentation and physician advice to quit. The PHS guideline ^60^ reported that tobacco use identification systems led to a significant increase in delivery of smoking cessation interventions by physicians. Among nine studies included, office systems led to an increase in the use of smoking cessation interventions (odds ratio [OR] 3.1, 95 percent CI 2.2 to 4.2). Smoking cessation rate increased (OR 2.0, 95 percent CI 0.8 to 4.8). However, this difference was not statistically significant.
  The TFCPS Community Guide ^61^ evaluated seven studies assessing provider reminder systems and concluded that provider reminder systems were effective at increasing delivery of advice to quit. These included efforts to identify patients using tobacco products and efforts to prompt physicians to discuss or advise patients about cessation. Provider reminder systems resulted in improved process measures. These included a median absolute increase in documentation of smoking status of 32.5 percent (range 26 to 57.6 percent) and a median absolute increase of 13 percent (range 7 to 31 percent) in delivery of advice to quit smoking were reported. Only one study evaluated abstinence (4 percent absolute increase).
3. Audit and feedback
  Hopkins et al. ^61^ reviewed three studies evaluating the effectiveness of provider assessment and feedback with tobacco-using patients. These studies utilized retrospective assessment of provider performance in the identification of tobacco use status, delivery of advice to quit, or a combination of both as an intervention to motivate providers. There was a median absolute increase in provider recognition of patient tobacco use of 21 percent (range 13 to 39 percent). No study evaluated provider advice to quit, or cessation rates. They concluded there was insufficient evidence to recommend provider feedback as an effective intervention to increase uptake of smoking cessation.

#### Individual-directed interventions

1. Telephone counseling
  Three systematic reviews were identified addressing some aspect of telephone counseling. ^60,^ ^68,^ ^69^ They concluded that proactive counseling was an effective intervention for smoking cessation. The PHS clinical practice guideline on smoking cessation examined the effectiveness of proactive telephone counseling as part of a systematic review of psychosocial treatments for tobacco dependence. ^60^ A meta-analysis of 26 studies found that proactive counseling significantly increased the smoking cessation rates (OR 1.2, 95 percent CI 1.1 to 1.4) in comparison with no intervention. Estimated abstinence rates were increased from 10.8 to 13.1 percent.
  Lichtenstein et al. ^69^ reported the results of a meta-analysis of 13 studies of proactive telephone counseling as part of a systematic review of telephone counseling services. Outcome data was reported as both short (three to eight months) and long-term (12 to 18 months) self-reported abstinence rates. Two studies were eliminated from the short-term meta-analysis because of significant heterogeneity. No sensitivity analysis was performed. There was a significant increase in short-term abstinence rates (OR 1.34, 95 percent CI 1.19 to 1.51). Two additional studies were removed from the analysis of long-term followup because of heterogeneity. The effect size appeared to decrease with longer-term followup (OR 1.20, 95 percent CI 1.06 to 1.37). No estimate of the absolute change in smoking rates was provided.
  Stead and Lancaster ^68^ undertook a systematic review with meta-analysis of RCTs and quasi-randomized trials of proactive and reactive telephone counseling. The authors concluded that proactive telephone counseling can be effective but the effect size is uncertain. There was significant heterogeneity among 10 trials of proactive counseling versus minimal intervention so the data were not pooled. In two trials the quit rate was lower in the intervention group than the control. Three trials observed significantly increased quit rates in comparison with controls (absolute increased quit rates 2 percent, 3.4 percent, 8 percent). Three trials observed increased quit rates between 1 to 2 percent, but these were not statistically significant, and two additional trials observed nearly identical quit rates. Four trials evaluated the addition of telephone counseling to a face-to-face intervention. There was no evidence that this increased quit rates (OR 1.08, 95 percent CI 0.87 to 1.34). Similarly, there was no evidence that the addition of telephone counseling to NRT improved quit rates (OR 1.08, 95 percent CI 0.82 to 1.43). Three trials evaluated the provision of a helpline to self-help materials. One trial observed a significant increase in quit rates from 4 to 6.6 percent. Two other trials showed no benefit. The review concluded there was uncertainty about the incremental benefit of telephone counseling in combination with a face-to-face intervention.
2. Healthcare provider advice to individuals to quit smoking
  Five reviews evaluated the impact of healthcare provider advice to quit smoking. ^58,^ ^60,^ ^66,^ ^67,^ ^71^ These reviews provide convincing evidence of the importance of health professional advice to stop smoking. At a minimum, health professionals should aim to advise all patients who smoke to stop. The PHS clinical practice guideline on tobacco use and dependence identified seven trials evaluating brief advice (modal length < 3 minutes) by a physician to quit smoking compared with controls. ^60^ Brief advice was associated with a significant increase in abstinence rates (OR 1.3, 95 percent CI 1.1 to1.6). This equates to an estimated increase in smoking abstinence from 7.9 to 10.2 percent. Separate analyses examined intensity of contact (43 studies), total contact time (35 studies), and number of contact treatment sessions (45 studies) strengthening the dose-response relationship. Abstinence rates increased significantly with intensity of contact: (OR 1.3, 95 percent CI 1.01 to1.6) for minimal counseling of less than three minutes, (OR 1.6, 95 percent CI 1.2 to 2.0) for low-intensity counseling of three to10 minutes, (OR 2.3, 95 percent CI 2.0 to 2.7) for high-intensity counseling of more than 10 minutes. Abstinence rates also increased significantly with total amount of contact time: (OR 1.4, 95 percent CI 1.1 to1.8) 1 to 3 minutes, (OR 1.9, 95 percent CI 1.5 to 2.3) 4 to 30 minutes, (OR 3.0, 95 percent CI 2.3 to 3.8) 31 to 90 minutes, (OR 3.2, 95 percent CI 2.3 to 4.6), and (OR 2.8, 95 percent CI 2.0 to 3.9) >300 minutes, and with increasing number of treatment sessions: (OR 1.4, 95 percent CI 1.1 to 1.7) 2 to 3 sessions, (OR 1.9, 95 percent CI 1.6 to 2.2) 4 to 8 sessions, and (OR 2.3, 95 percent CI 2.1 to 3.0) more than 8 sessions.
  Two reviews were undertaken by the Cochrane Tobacco Control Group. ^66,^ ^67^ Both reviews reported pooled ORs, but not abstinence rates. Silagy and Stead ^67^ undertook a systematic review with meta-analysis of RCTs evaluating physician advice to stop smoking. Sixteen studies evaluated brief advice to stop smoking (single consultation < 20 minutes duration). Brief advice was associated with a significant increase in smoking cessation compared with no advice (OR 1.69, 95 percent CI 1.45 to 1.98). They estimated that this equated to a 2.5 percent increase in absolute smoking cessation rates. Trials using direct comparisons of more intensive versus brief advice showed a benefit from more intensive advice (OR 1.44, 95 percent CI 1.23 to 1.68), although there was evidence of heterogeneity among trials and the results were not robust to sensitivity analysis. The effect size was greater for patients at high risk of smoking-related diseases and if followup visits were scheduled. Using indirect comparisons, there was insufficient evidence to show that more intensive interventions were significantly more effective than brief interventions.
  Rice et al. ^66^ examined the effectiveness of RCTs evaluating nursing interventions for smoking cessation. Interventions were grouped into low- (advice to stop smoking) and high-intensity (initial contact more than 10 minutes). Sixteen trials compared nurse interventions with usual care. Smokers offered advice by a nursing professional were significantly more likely to quit smoking than those who received usual care (OR 1.50, 95 percent CI 1.29 to 1.73). High- intensity interventions appeared no more effective than low-intensity interventions.
  Two additional systematic reviews examine the topic of healthcare provider advice to stop smoking. ^58,^ ^71^ Ashenden et al. ^58^ identified 23 studies of physician advice to quit smoking compared with no advice. Two studies were excluded because of heterogeneity. Brief advice was associated with an increase in abstinence rates compared with a no-advice control group (OR 1.32, 95 percent CI 1.18 to 1.48). The odds of quitting were greater with more intensive interventions than with brief interventions (OR 1.46 vs. 1.27). However, no statistical comparisons were made. Ashenden et al. ^58^ concluded it was necessary to provide advice to 35 smokers to produce one quitter. Meta-analysis was not performed in the systematic review by Ritvo et al. ^71^ They reached a similar conclusion that physician advice is an effective intervention to promote smoking cessation.
3. Self-help and educational materials
  Two systematic reviews examined patient self-help materials. ^60,^ ^63^ Lancaster and Stead ^63^ included forty-five trials in their review of self-help interventions. Pooled ORs were reported in the absence of absolute smoking cessation rates. In comparison with no intervention, self-help produced a small but significant increase in abstinence rates (OR 1.23, 95 percent CI 1.02 to 1.49). However, when self-help materials were added on to other interventions such as brief contact (self-help materials given directly to individuals but not in context of formal advice to stop smoking), healthcare provider advice to quit, or nicotine replacement therapy, there was no evidence of increased quit rates. Enhancements to self-help materials, such as additional written materials or a video, did not significantly increase quit rates. The individual tailoring of self-help materials on the basis of responses to baseline questionnaires or the addition of proactive telephone counseling to self-help were associated with increased quit rates. Similarly, Fiore et al. ^60^ reported a small increase in abstinence rates from self-help strategies compared to a control group (OR 1.2, 95 percent CI 1.02 to 1.3).
  Mullen et al. ^65^ conducted a systematic review of patient education and counseling for three groups of preventive behaviors. The analysis grouped studies concerning smoking and alcohol together. The overall weighted effect size for smoking and alcohol was 0.61 (95 percent CI 0.45 to 0.77) standard deviation units. It is not clear from the review what outcome measure this refers to, or the time point at which it was assessed.
4. Social network
  The PHS clinical practice guideline for tobacco use and dependence examined social support as part of a review of counseling and behavioral therapies. ^60^ They reported three main aspects of support: the training of patients in support solicitation skills; the prompting of support seeking; and clinician-arranged outside support. In comparison with no counseling, studies evaluating social supports were associated with modest increases in abstinence rates (OR 1.5, 95 percent CI 1.1 to 2.1).
5. Financial incentives
  Three systematic reviews evaluated the effectiveness of financial incentives or competitions on quit rates. ^59,^ ^61,^ ^70^ Bains et al. ^59^ undertook a systematic review of the impact of financial incentives in population-based smoking cessation programs. Seventeen studies of various methodological designs were included. There is no convincing evidence that incentive programs influenced participation or quit rates.
  Matson et al., ^70^ evaluated the impact of financial incentives and competitions on participation and quit rates in worksite smoking cessation programs. Fifteen studies were identified. Three of eight studies with appropriate controls demonstrated that incentives and competitions increased participation in the worksite program. Five studies showed increased quit rates, but the magnitude of this effect was not quantified. One study found that competitions increased quit rates in addition to incentives.
  The TFCPS community guide ^61^ included only one study on smoking cessation contests. This showed a 13 percent participation in the contest and a 3.3 percent cessation rate at six months compared with a group of smokers given general health education materials. The community guide concluded that there was insufficient evidence to assess the effectiveness of cessation contests given that there was only one study.
6. Other types of interventions
  Several reviews have examined the effect of patient counseling to stop smoking. ^60,^ ^62,^ ^71^ There is evidence to recommend the use of trained smoking cessation counselors and individual behavioral therapies as effective smoking cessation interventions. Lancaster and Stead ^62^ undertook a systematic review of smoking cessation counseling from a trained smoking cessation counselor not involved in routine clinical care. Individual counseling significantly increased the odds of quitting (OR 1.55, 95 percent CI 1.27 to1.90). This result was robust to a sensitivity analysis. There was no additional benefit observed from more intensive counseling in comparison with brief counseling.
  The PHS clinical practice guideline ^60^ examined counseling and behavioral therapies. They found that abstinence rates were significantly improved by five strategies in comparison with abstinence rates in a no-counseling group: (OR 1.5, 95 percent CI 1.3 to 1.8) general problem solving skills; (OR 1.3, 95 percent CI 1.1 to 1.6) intra-treatment support (providing support during a smokers direct contact with a clinician); (OR 1.5, 95 percent CI 1.1 to 2.1) extra-treatment support (intervening to increase social support); (OR 2.0, 95 percent CI 1.1 to 3.5) rapid smoking; and (OR 1.7, 95 percent CI 1.04 to 2.8) other aversive smoking procedures. The PHS guideline did not directly address the issue of brief versus more intensive behavioral counseling. ^60^ Ritvo et al. also concluded that cognitive-behavioral counseling was one of three key strategies in physician- assisted smoking cessation strategies, although there was no measure of effect size. ^71^

#### Access-enhancing interventions

1. Financial barriers
  The TFCPS community guide identified five studies evaluating the effectiveness of reducing out-of-pocket expenses for tobacco cessation therapies. ^61^ All five studies reduced or eliminated patient costs for NRT. All studies observed an increase in the use of cessation therapies (range 6.5 to 28 percent). Four of the studies observed increased smoking cessation (2 to 11 percent). Therefore, there is evidence to recommend reducing out-of-pocket expenses.
2. Media education campaigns
  The TFCPS community guide examined the evidence of effectiveness of media campaigns. ^61^ Fifteen studies were included in the systematic review. All of the studies evaluated a media campaign co-coordinated or concurrent with other interventions. There is strong evidence that media campaigns associated with other interventions are effective in reducing tobacco consumption. The median increase in cessation rate was 2.2 percent (range -2 to 35 percent). Three studies evaluated statewide tobacco consumption in response to media campaigns. Per capita consumption declined between 9 to 20.4 packets per capita per year (relative decrease 9.8 to 17.5 percent).
3. Policy level interventions
  One review on a policy level intervention to reduce tobacco consumption was identified. ^61^ Seventeen studies were included examining the impact of increasing the unit price of tobacco products. There was strong evidence that increasing price through taxation would reduce tobacco consumption. The median estimate from these studies was that a 10 percent increase in price would result in a 4.1 percent decrease in population consumption (range 2.7 to 7.6 percent).
4. Multicomponent interventions
  The TFCPS community guide ^61^ reported a review of multi-component interventions involving provider reminders and provider education with or without patient education. Twenty studies evaluated a provider reminder system and provider education. There was a median 20 percent (range 5.2 to 60 percent) increase in provider advice to quit and 4.7 percent (range -1 to 25.9 percent) increase in abstinence rates with followup between five weeks to 12 months (median 10 months). A subset analysis was performed of thirteen studies evaluating combinations of provider reminders and education, plus patient education. The median provider advice to quit was 22 percent, with a median cessation rate of 5.7 percent. The report recommended the use of these multicomponent interventions.
  The TFCPS Community Guide ^61^ also conducted a review of multicomponent interventions that included patient telephone support. Thirty-two studies were included. In all studies, telephone counseling was combined with additional interventions such as patient education, provider delivered counseling, NRT, or a smoking cessation clinic. Cessation rates from -3.4 to 23 percent (median 2.6 percent) are reported. The report concluded that there was strong evidence that telephone counseling was effective when implemented with other interventions. These conclusions are somewhat discordant with the meta-analysis of telephone counseling from Stead et al. ^68^ who found no increase in the odds of quitting in studies of telephone counseling in addition to face-to-face interventions or NRT. These differences may be explained in part by the fact that more studies were included in the TFCPS review and the data were not combined quantitatively. Therefore, there is uncertainty about the incremental benefit of telephone counseling in combination with a face-to-face intervention.
5. Target populations
  One review specifically addressed smoking cessation among African Americans. ^72^ Multiple literature sources were searched. However, only major studies were included in the review “to provide some indication of the patterns of results and comparisons with white smokers and quitters”. A wide range of health-related interventions were evaluated in African American church communities. These included less intensive interventions such as smoking cessation counseling and self-help materials, as well as more intensive interventions including sermons on smoking cessation, smoking cessation counseling, and spiritual stop-smoking tapes and guides. There was a trend to greater effectiveness from the more intensive interventions, but this did not reach statistical significance. Quit rates among church attendees appeared to be greater than among the non-attendees (10.6 percent vs. 5.9 percent). In community programs, Pederson et al. ^72^ concluded that there was no difference in quit rates between African and Caucasian Americans.
  The PHS clinical practice guideline also examined the evidence for smoking cessation interventions in ethnic minorities. ^60^ There was no consistent evidence that specific targeted cessation programs resulted in higher quit rates in these groups than did generic interventions of comparable intensity. A range of interventions were shown to be effective, including NRT, clinician advice, counseling, tailored self-help materials, and telephone counseling. There were differences in smoking prevalence between white and racial/ethnic minorities. In addition, some racial/ethnic groups had inadequate access to primary care. These factors may be more of a barrier to effective smoking cessation interventions.

## Adult Healthy Diet

### Key Question #2

What is the effectiveness of cancer control interventions that promote the uptake of adult healthy diet?

### Background

It has been estimated that one-third of all cancer mortality in the US is related to diet. ^76^ Reviews of dietary studies have led groups, such as the American Institute for Cancer Research, to recommend that diet should largely be based on plant products with 400 grams of vegetables and fruits to provide more than 10 percent of energy consumed daily. ^77,^ ^78^ The American Cancer Society (ACS) adds that intake of high-fat foods and alcohol should be limited. ^79^ The national objectives in both the US and Canada have been set at five or more servings per day of fruits and vegetables. ^80^ Average intake falls considerably short of this. In the US, intake is estimated to be 3.4 total servings of fruits and vegetables per day on average, but differs by age, ethnicity, and socioeconomic status. ^81^

Several reviews of interventions to promote dietary change exist and will be discussed in this section of the report (Evidence Table 3). While some of the interventions had the stated purpose of altering cardiovascular risk factors, the reviews were included here if the interventions were the same as those promoted to reduce cancer risks (e.g., increased fruit and vegetable or fiber consumption, or reduced fat consumption). The interventions can be broadly classified as: interventions to increase delivery of healthy diet interventions by healthcare providers (healthcare provider-directed); interventions to promote uptake of healthy diet by clients/consumers/general public (individual-directed); and media education campaigns.

The review was not intended to address the relationship between dietary intake and any illness, to assess the effectiveness of various clinically therapeutic diets, nor to assess interventions in children. The purpose is to relate what is known about the effectiveness of dietary change interventions for adult consumers and healthcare professionals.

### Included Studies

The search strategy resulted in 1651 unique articles that were subsequently screened by title and abstract (Figure 4). Forty-eight papers were retrieved for full text screening; 32 papers were excluded. Sixteen papers met the eligibility criteria for data extraction, however 5 of the 16 contained no data relevant to this review ^40,^ ^45,^ ^82–84^ . These are presented in the General Table found in Appendix G.

Figure 4. Adult Healthy Diet: Search yield for studies evaluation the effectiveness of cancer control interventions (Key question #2)

Full data extraction was conducted on nine articles ^58,^ ^65,^ ^85–91^ (Evidence Table 2). Five systematic reviews focused primarily on dietary interventions ^85–89^ , and four reviews included two or more interventions such as diet plus physical activity, ^91^ or smoking, diet, alcohol and physical activity. ^58^ The interventions addressed in these reviews are presented in Summary Table 3. These include healthcare provider-directed, individual patient-directed, access-enhancing, media education campaigns, and multi-strategy interventions.

Summary Table 3: Adult healthy diet - Interventions addressed in systematic reviews of the effectiveness of cancer control interventions

Lead Author (Year) | Healthcare provider-directed interventions | | | | | Individual (patient)-directed interventions | | | | | | Access-enhancing interventions | | | Media education campaigns | Policy-level interventions | Multi-strategy interventions
| Healthcare provider training | Office systems (e.g., prompts) | Audit and feedback | Opinion leaders | Other | Invitations or reminders | Telephone counseling | Healthcare provider advice | Educational materials | Social network | Other | Financial barriers | Access barriers | Other
Ammerman, A ^85^ (2001) | | | | | | | | ✓^ M ^ | ✓^ M ^ | | ✓^ M ^
Ashenden, R ^58^ (1997) | | | | | | | | ✓ | ✓
Brunner, E ^86^ (1997) | | | | | | | ✓^ M ^ | ✓^ M ^ | ✓^ M ^ | | ✓^ M ^
Ciliska, D ^87^ (2000) | | | | | | | | | ✓^ T ^ | ✓^ T ^ | | | | | ✓^ T ^
Contento, I ^88^ (1995) | ✓^ T ^ | | | | | | | | ✓^ T ^ | ✓^ T ^ | ✓^ T ^ | | | | ✓^ T ^
Glanz, K ^89^ (1992) | ✓^ T ^
Glanz, K ^90^ (1996) | | | | | | | | | ✓^ T ^ | | ✓^ T ^
Mullen, P ^65^ (1997) | | | | | | | | | ✓^ M ^ | | ✓^ M ^
Wilcox, S ^91^ (2001) | ✓^ MT ^ | | | | | ✓^ MT ^ | ✓^ MT ^ | ✓^ MT ^ | ✓^ MT ^

Legend: M=meta analysis performed; T=Target population specified

The populations in the nine reviews were broad, including varied ages, varied ethnic groups, and both genders, with the exception of one review that dealt exclusively with women. ^91^ Four of the reviews included meta-analysis of dietary interventions. ^65,^ ^85,^ ^86,^ ^91^ The quality of the reviews was high. Six studies were judged to be methodologically “strong” (rated 5 or 6), ^58,^ ^65,^ ^85,^ ^87,^ ^90,^ ^91^ three were rated “moderate” (rated 3 or 4), ^86,^ ^88,^ ^89^ and no review was rated as “weak”, achieving scores of <3 (Summary Table 4). The most common weaknesses of the reviews were lack of quality assessment of the primary studies ^65,^ ^86,^ ^88,^ ^91^ followed by unclear or unstated search strategy ^86,^ ^88,^ ^89^ and lack of integration of findings. ^87,^ ^88^ Three reviews were published in last two years, ^85,^ ^87,^ ^91^ while the others were published between 1992 ^88^ and 1997. ^58,^ ^65,^ ^86,^ ^89,^ ^90^ There was considerable variation in study designs of the primary studies included in the reviews, from RCTs only ^58,^ ^86^ to descriptive studies of process indicators. ^88^

Summary Table 4: Adult healthy diet - Quality assessment rating of included systematic reviews

Lead Author (year) | Quality Assessment
| Search Strategy Stated | Comprehensive search | Level of evidence | Quality assessment | Integrate findings | Data support conclusions | Overall Score (0–6) | Overall rating^a^
Ammerman, A ^85^ (2001) | ✓ | ✓ | ✓ | ✓ | ✓ | ✓ | 6 | STRONG
Ashenden, R ^58^ (1997) | ✓ | ✓ | ✓ | ✓ | ✓ | ✓ | 6 | STRONG
Brunner, E ^86^ (1997) | | | ✓ | | ✓ | ✓ | 3 | MODERATE
Ciliska, D ^87^ (2000) | ✓ | ✓ | ✓ | ✓ | | ✓ | 5 | STRONG
Contento, I ^88^ (1995) | | ✓ | ✓ | | | ✓ | 3 | MODERATE
Glanz, K ^89^ (1992) | | | ✓ | ✓ | ✓ | ✓ | 4 | MODERATE
Glanz, K ^90^ (1996) | ✓ | ✓ | ✓ | ✓ | ✓ | ✓ | 6 | STRONG
Mullen, P ^65^ (1997) | ✓ | ✓ | ✓ | | ✓ | ✓ | 5 | STRONG
Wilcox, S ^91^ (2001) | ✓ | ✓ | ✓ | | ✓ | ✓ | 5 | STRONG

a Overall rating was based on overall score: ≤2=weak; 3–4=moderate; 5–6=strong

Refer to Appendix E, Form 4 for full details on information collected for Quality Assessment

### Description of Systematic Reviews of Interventions to Promote Adult Healthy Diet

#### Reviews of healthy diet interventions as part of preventive healthcare services in family practice

Ashenden et al. ^58^ undertook a systematic review of RCTs evaluating the effect of lifestyle advice provided by family practitioners, in changing patient behavior. Lifestyle advice was defined as advice provided in the general practice setting to quit smoking, make dietary changes, reduce alcohol consumption and exercise more. Advice was mainly verbal but could include written material. More intensive advice included additional followup by appointment, telephone, or letter. Data were analyzed separately for each topic; meta-analysis was done only for smoking.

The review by Mullen ^65^ included RCTs and uncontrolled studies evaluating patient education and counseling. Education and counseling in this setting were advice on preventive health behavior to apparently healthy individuals seen in a clinical setting in a developed country. The analysis was broken down into three groups: smoking/alcohol, nutrition/weight, and other behaviors.

Glanz ^89^ reviewed twenty-five studies regarding medical school curricula and physician's knowledge, attitudes, and practices related to nutritional care, with a focus on prevention of coronary heart disease through cholesterol control.

#### Reviews of multiple healthy diet interventions

Ammerman et al. ^85^ conducted a comprehensive review for the US AHRQ on the efficacy and effectiveness of behavioral interventions in promoting dietary change. In particular, they attempted to find (1) evidence for one intervention, alone or in combination, that is more effective than another in modifying diet to increase fruits and vegetables and reduce fat; (2) evidence for the efficacy of dietary interventions by population subgroup (ethnicity and gender); and (3) conclusions about cost-effectiveness of these types of interventions. A total of 92 studies were included that were RCTs or non-randomized trials conducted in any setting, with any age group except infants, healthy or high-risk populations (non-institutionalized), and any intervention (education, counseling, support groups, classes, etc.), with consumption of fruit, vegetables, or dietary fat as outcomes. Outcomes were reported in meta-analysis, a “difference-in-deltas” approach, and “summary of significant findings” approach.

The purpose of the review by Brunner et al. ^86^ was to assess the effectiveness of dietary advice designed for primary prevention of chronic disease. They identified 17 suitable RCTs to include in a meta-analysis. The populations were often within primary care, but were also in specialty clinics or worksites. The dietary interventions included individual advice, phone and mail support, small group meetings, classes and demonstrations, and educational materials. Analysis was reported by dietary fat as a percentage of food energy, serum cholesterol, urinary sodium, and systolic blood pressure.

A review of the effectiveness of community-based interventions to increase fruit and vegetable intake in people four years of age and older found a total of 15 studies. ^87^ Only five studies were relevant to adults and these designs were RCTs, cohort analytic studies, and interrupted time series studies. No meta-analysis was done. The interventions consisted of worksite education, formation of community coalitions, and tailored, individual education.

In a series of reviews within one publication, Contento et al. ^88^ aimed to discover which elements across effective interventions (if any) were successful, and to make subsequent implications for nutrition education programming, research, and policy. Two-hundred and seventeen articles were included; 117 were on adult healthy diet, but the methods or quality were not reported. Interventions included individual education or counseling, in-service of healthcare professionals and food-industry workers, mass media campaigns, worksite programs, point-of-purchase interventions, and intensive nutrition education programs for low-income families. No meta-analyses were performed.

The final review in this section was specifically concerned with dietary interventions delivered within healthcare settings to women. ^91^ Forty-five studies were identified, of which 19 were on physical activity alone, 14 were dietary alone (10 RCTs), and 12 combined diet and physical activity (eight RCTs). A mean effect size was calculated for outcomes. This review attempted to look at differences by ethnicity.

### Findings of Systematic Reviews

#### Healthcare provider-directed interventions

The provision of interventions to change healthcare provider behavior has, as a final goal, improvement in patient behaviors. Education of providers and system supports, such as computerized reminder systems, or automatic recall of patients, are some of the interventions directed to healthcare providers. Three reviews included at least some primary studies of healthcare provider interventions; ^88,^ ^89,^ ^91^ however, none of these indicated the quality of the included primary studies within the report. In the Wilcox et al. ^91^ review, five of the 14 studies of dietary interventions involved resident-physician or physician education in addition to their usual training; improvements in patient knowledge were found, but without subsequent significant impact on patient weight reduction. The Wilcox et al. ^91^ review did not analyze comparisons of different types of interventions (e.g., provider- vs. patient-directed); only comparisons of single vs. multiple interventions were reported: diet-only and combined interventions were equally effective in reducing dietary fat (mean effect size 0.13, 95 percent CI 0.08 to 0.18, vs. 0.11, 95 percent CI 0.05 to 0.17, using the Pearson Product Moment Correlation r). Three primary studies that specifically included other ethnic groups were included; the review indicated that interventions that were targeted and tailored could produce significant effects, but that more research was needed.

Glanz and Gilboy ^89^ found that attention to nutrition in medical school curricula and to continuing education for practicing physicians had increased modestly, with some improvement in attitudes about dietary interventions. The review raised important awareness of other determinants of physician behavior beyond education: that of reduction of barriers, such as lack of time, payment issues, and co-ordination of care.

The Contento et al. ^88^ review considered education of paraprofessionals and professionals. They found that additional educational input of paraprofessionals resulted in increased knowledge in before-after studies. Expectations of program supervisors, positive attitudes towards work, and knowledge of teaching-learning strategies were identified as characteristics of paraprofessionals most closely associated with positive program outcomes. Continuing education of physicians was found to be effective in changing patient dietary behaviors, but only when physician perceptions were altered regarding patients desire for and ability to follow dietary advice, and when reimbursement issues were addressed.

#### Individual-directed interventions

All nine included reviews presented information about individual-, or consumer-directed interventions such as education, counseling, and healthcare provider advice to individuals or community groups. Ammerman et al. ^85^ found 92 primary studies focused on fruits, vegetables, and dietary fat intake in a wide variety of settings, age groups, and populations. Interventions included workplace, community and patient education, mass media campaigns, mailed interventions, peer education, and combined strategies. They concluded that dietary interventions were consistently associated with a decrease in dietary fat and saturated fat (estimated as 7.3 percent reduction in percentage of calories from fat in the intervention groups vs. control), and an increase in fruit and vegetable consumption (0.6 servings per day).

Similarly Brunner et al. ^86^ reviewed 17 trials of dietary interventions of at least three months duration in diverse participants (e.g., volunteers, employees, breast cancer patients). Those studies achieved a reduction of 2.5 percent in percentage of calories from fat (95 percent CI -3.9 to1.1).

Mullen et al.'s ^65^ review considered any patient education or counseling intervention of preventive behavior with healthy individuals in clinical settings. The review included alcohol, nutrition/weight, and other behaviors. The interventions more often targeted patients with elevated risk; included education, support, some behavioral approaches, and often included more than one contact; and they were less likely to involve self-monitoring, media channels or to include followup longer than 30 days. The overall weighted effect size for nutrition and weight studies in Mullen et al.'s review of 17 included studies was 0.51 standard deviation (SD) units (95 percent CI 0.20 to 0.82); 65 percent of the variance was accounted for in a regression model; followup of at least 30 days, higher score on behavior change support factor, and use of self-monitoring were all significantly associated with higher effects. ^65^ The combination of results regarding nutrition and weight probably underestimated the effect size, as weight is so difficult to change and maintaining the loss is even more difficult.

Four reviews reported on worksites as a channel for messages regarding individual behavior change. ^85,^ ^87,^ ^90,^ ^92^ Multiple interventions, compared with no intervention or usual employee programs, were common in these primary studies and included peer educators, printed educational materials, cafeteria posters, and food labeling. These interventions were associated with at least short-term increases in fruit and vegetable intake (servings per day) and reduction of dietary fat.

Lifestyle education (smoking, diet, alcohol and exercise) was the target of the review by Ashenden et al. ^58^ Ten RCTs were included about healthy diet and they tried to alter fat, fiber, lipid levels, blood pressure, and/or weight reduction. The meta-analysis and the results focused primarily on the smoking results. However, they concluded that brief or intensive advice, often with written materials and support, provided by general practitioners, had a modest and variable effect on lifestyle improvements. ^58^

The Wilcox et al. review ^91^ of all types of interventions in healthcare settings supports Ashenden et al.'s conclusion. In addition, that review was able to do further comparisons and concluded that intervention effects on dietary behaviors were generally larger for samples with a mean age over 50 years and for studies with less than six months followup.

Use of behavioral interventions, ^65,^ ^82,^ ^88,^ ^90^ tailored interventions, ^82,^ ^88^ multiple interventions, ^65,^ ^82,^ ^87,^ ^88,^ ^90^ provision of multiple contacts, ^82,^ ^87,^ ^88^ and environmental interventions ^82,^ ^87,^ ^88^ were more likely to be effective in producing dietary change. Interactions with food (community kitchens, community gardens, taste testing) were promising interventions to increase fruit and vegetable intake and reduce fat intake. ^85^

#### Media education campaigns

Mass media campaigns were the subject of parts of two of the reviews. ^87,^ ^88^ The primary studies included great variation in channels, media and intensity of the campaigns, and compared the outcomes with before-after samples or with outcomes in communities with no intervention. They resulted in increased knowledge and awareness of behaviors to reduce risks, particularly when the campaign was based on the audience planning of the campaign (such as social marketing). Behavior change has been associated with a highly targeted and focused message ^91^ and was often part of multiple intervention strategies. ^87^

## Screening Mammography

### Key Question #3

What is the effectiveness of cancer control interventions that promote screening mammography?

### Background

Other than skin cancer, breast cancer is the most common cancer among women in the US. In 2001, an estimated 192,200 women were diagnosed with breast cancer, and 40,600 women died from the disease. ^93^ Breast cancer has emerged as the most frequently occurring cancer among women aged 50 to 64 years, with nearly all cases occurring in women. ^33^

During the past two decades, several systematic reviews have examined the effectiveness of interventions to promote uptake of mammography screening and will be discussed in this section of the report. Overviews were included if they reported the effectiveness of interventions to promote uptake of cancer control behaviors (e.g., physician advice, counseling [telephone, emergency room, nurse], media campaigns, peer leaders) specific to promoting uptake of screening mammography. Studies that were not published in English, were published before 1990, or were exclusively focused on children or adolescents were excluded.

This review was not intended to address those studies which focused exclusively on increasing followup compliance after an abnormal mammogram, as well as those focused exclusively on increasing the use of breast self-exam or clinical breast examination.

### Included Studies

Electronic database searches yielded 190 titles and abstracts, 37 of which were selected using pre-established guidelines for full-text relevance screening (Figure 5). Fifteen ^94–108^ studies met the eligibility criteria for inclusion and data were extracted (see Evidence Table 5). Four ^15,^ ^37,^ ^53,^ ^109^ studies met the eligibility criteria for inclusion but data could not be extracted separately on interventions for screening mammography. These studies are included in a general table (see Appendix G).

Figure 5. Mammography: Search yield for studies evaluating the effectiveness of cancer control interventions (Key question #3)

Of the 15 systematic reviews included, nine focused exclusively on interventions to promote uptake of screening mammography; ^95,^ ^98–101,^ ^104,^ ^106–108^ two focused on breast and cervical cancer screening combined; ^97,^ ^102^ two included breast, cervical, and colorectal cancer screening; ^94,^ ^105^ and two reviews included other screening targets, such as colorectal cancer, influenza, tetanus, hypertension, and tuberculosis in addition to breast and cervical cancer. ^96,^ ^103^

The interventions addressed in these reviews are presented in Summary Table 5. These include healthcare provider-directed, individual patient-directed, access-enhancing, media education campaigns, and multi-strategy interventions.

Summary Table 5. Mammography - Interventions addressed in systematic reviews of the effectiveness of cancer control-interventions

Lead Author (Year) | Healthcare provider-directed interventions | | | | | Individual (patient)-directed interventions | | | | | | Access-enhancing interventions | | | Media education campaigns | Policy-level interventions | Multi-strategy interventions
| Healthcare provider training | Office systems (e.g., prompts) | Audit and feedback | Opinion leaders | Other | Invitations or reminders | Telephone counseling | Health-care provider advice | Educational materials | Social network | Other | Financial barriers | Access barriers | Other
Balas, EA ^94^ (2000) | | ✓^M^
Bonfill, X ^95^ (2001) | | | | | | ✓ | | | ✓ | | ✓
Jepson, R ^96^ (2000) | ✓ | ✓ | ✓ | | | ✓ | ✓ | | ✓ | | | ✓ | | | ✓ | | ✓
Kupets, R ^97^ (2001) | | ✓ | ✓ | | | ✓ | | | | | ✓ | | | | | | ✓
Legler, J ^98^ (2002) | | | | | | ✓^ MT ^ | | | | | | | ✓^ MT ^ | ✓^ MT ^ | ✓^ MT ^ | | ✓^ MT ^
Mandelblatt, JS ^99^ (1995) | ✓ | ✓ | ✓ | | | ✓ | | | ✓
Mandelblatt, JS ^100^ (1999) | ✓^ MT ^ | ✓^ MT ^ | | | | | | | | | | | | | | | ✓^ MT ^
Ratner, PA ^101^ (2001) | | ✓ | | | | ✓ | ✓ | | ✓ | ✓ | | | ✓
Shea, S ^102^ (1996) | | ✓ | | | | ✓ | | | | | | | | | | | ✓
Shekelle, PG ^103^ (1999) | ✓ | ✓ | ✓ | | ✓ | ✓ | | | ✓ | | | ✓ | | | | | ✓
Sin, JP ^104^ (1999) | | ✓ | | | | ✓ | | | ✓ | ✓ | | | ✓ | | | | ✓
Snell, JL ^105^ (1996) | | ✓ | ✓ | | ✓ | | | | | | | | | | | | ✓
Wagner, TH ^106^ (1998) | | | | | | ✓^M^
Yabroff, KP ^107^ (1999) | | | | | | ✓^ MT ^ | | | | ✓^ MT ^ | | ✓^ MT ^ | | | ✓^ MT ^
Yabroff, KP ^108^ (2001) | | | | | | ✓^M^ | | | ✓^M^

M=meta analysis performed; T=Target population specified

Quality assessment of these systematic reviews was undertaken (Summary Table 6). Five ^94,^ ^96,^ ^102–104^ reviews were rated as having “strong” methodological quality (refer to Chapter 2: Methods for details of the instrument). Ten received a rating of “moderate”. ^95,^ ^97–101,^ ^105–108^ . The most common weakness of the reviews was lack of formal quality assessment of the primary studies, ^95,^ ^97–103,^ ^105–108^ and comprehensiveness of the search conducted (i.e., databases used). ^98–101,^ ^105,^ ^107,^ ^108^

Summary Table 6. Mammography - Quality assessment rating of included systematic reviews

| Quality Assessment
Lead Author (Year) | Search Strategy Stated | Comprehensive search | Level of evidence | Quality assessment | Integrate findings | Data support conclusions | Overall Score (0–6) | Overall rating^a^
Balas, EA ^94^ (2000) | ✓ | ✓ | ✓ | ✓ | ✓ | ✓ | 6 | STRONG
Bonfill, X ^95^ (2001) | ✓ | ✓ | ✓ | | | ✓ | 4 | MODERATE
Jepson, R ^96^ (2000) | ✓ | ✓ | ✓ | ✓ | ✓ | ✓ | 6 | STRONG
Kupets, R ^97^ (2001) | ✓ | ✓ | ✓ | | | | 3 | MODERATE
Legler, J ^98^ (2002) | ✓ | | ✓ | | ✓ | ✓ | 4 | MODERATE
Mandelblatt, JS ^99^ (1995) | ✓ | | ✓ | | ✓ | ✓ | 4 | MODERATE
Mandelblatt, JS ^100^ (1999) | ✓ | | ✓ | | ✓ | ✓ | 4 | MODERATE
Ratner, PA ^101^ (2001) | ✓ | | ✓ | | | ✓ | 3 | MODERATE
Shea, S ^102^ (1996) | ✓ | ✓ | ✓ | | ✓ | ✓ | 5 | STRONG
Shekelle, PG ^103^ (1999) | ✓ | ✓ | ✓ | | ✓ | ✓ | 5 | STRONG
Sin, JP ^104^ (1999) | ✓ | ✓ | ✓ | ✓ | | ✓ | 5 | STRONG
Snell, JL ^105^ (1996) | ✓ | | | | ✓ | ✓ | 3 | MODERATE
Wagner, TR ^106^ (1998) | ✓ | ✓ | ✓ | | | ✓ | 4 | MODERATE
Yabroff, KP ^107^ (1999) | ✓ | | ✓ | | ✓ | ✓ | 4 | MODERATE
Yabroff, KP ^108^ (2001) | ✓ | | ✓ | | ✓ | ✓ | 4 | MODERATE

a Overall rating was based on overall score: ≤ 2=weak; 3–4=moderate; 5–6=strong

Refer to Appendix E, Form 4 for full details on information collected for Quality Assessment

### Description of Systematic Reviews to Promote Screening Mammography

#### Reviews of screening mammography as part of preventive health care services in family practice

Two reviews were found that addressed preventive health care services in family practice. ^94,^ ^102^ Balas et al. undertook a systematic review with the use of meta- analysis of RCTs evaluating the effect of prompting physicians to change clinical practice. ^94^ Prompting interventions were clinician prompt, alert, or reminder in the study group and no prompt in the control group and included such preventive services as Papanicolaou (Pap) testing, mammography, influenza vaccination, pneumococcal vaccination, tetanus vaccination, and fecal occult blood testing. The analysis was broken down by preventive care topic.

Shea et al. conducted a systematic review of RCTs using meta-analysis to assess the overall effectiveness of computer-based and manual reminder systems in ambulatory settings directed at preventive care. ^102^ The analysis was broken down into three categories: preventive practice generically and by prevention topic specifically.

#### Reviews of multiple screening mammography interventions

Nine reviews of multiple mammography screening interventions were identified. ^96–98,^ ^100,^ ^102,^ ^104,^ ^105,^ ^107,^ ^108^ Two of the nine systematic reviews used-meta analysis to combine data that addressed the use of multiple interventions (i.e., combined behavioral and cognitive interventions) to provide pooled estimates of effectiveness. ^98,^ ^100^

Bonfill et al. conducted a systematic review of interventions for increasing the participation of women in community breast-screening programs. ^95^ The review assessed the use of single interventions (invitations and reminders, education, and home visits) to recruit women as well as a combination of interventions to enhance recruitment (one or more of the above mentioned interventions). The main outcome measure for this overview was attendance for a mammogram among women in the intervention groups.

Yabroff et al., ^107^ Mandelblatt et al., ^100^ Yabroff et al., ^108^ and Sin et al. ^104^ , all conducted systematic reviews addressing the use of multiple interventions to promote the uptake of screening mammography. The results, however, are not presented by intervention type (i.e., mailed reminders, physician prompts, or audit and feedback); rather they are grouped into specific classification categories for the purpose of analysis. Both Yabroff et al. ^107^ and Mandelblatt et al. ^100^ used the following intervention classification scheme (1) behavioral interventions, (2) sociological interventions, and (3) cognitive interventions. Sin and St. Leger, ^104^ however, classified interventions into either (1) person-directed, (2) social-network-directed, or (3) multi-strategy for the purpose of analysis. All reviews included RCTs, ^100,^ ^104,^ ^107^ and one included descriptive studies. ^104^ Yabroff et al. ^108^ compared broad categories of inreach and outreach strategies and presented results under further classification within these categories as behavioral, sociological, and cognitive, making data extraction by specific intervention difficult.

A sixth review ^98^ addressed the effectiveness of combined intervention effects on women with historically lower mammography screening rates. These groups consisted of women who were disproportionately older, poorer, and of racial-ethnic minorities; had lower levels of formal education; and lived in rural areas. Combinations of access-enhancing and system-directed interventions were examined.

The Jepson report ^96^ included systematic reviews of multiple different interventions. No meta-analytic techniques were utilized and results are narratively presented by primary study. Results were synthesized broadly by intervention topic for a wide range of preventive services.

#### Reviews of single screening mammography interventions

Nine reviews evaluated single screening mammography interventions. ^94–96^ ^99,^ ^101–103,^ ^106,^ ^108^ Bonfill et al. conducted a systematic review of interventions for increasing the participation of women in community breast screening programs. ^95^ Interventions such as letters of invitation, mailed educational materials, and phone calls were all addressed. RCTs were included for this review.

Two reviews addressed interventions to promote screening mammography as part of a larger review of preventive services. ^94,^ ^102^ Balas et al. conducted a systematic review of prompting physicians to improve preventive care. ^94^ RCTs (n=33) that compared physician prompting in the study group with a control group with no intervention were included. The effects of prompting on selected procedures (i.e., fecal occult blood testing, mammography, Pap testing) were presented separately. Shea et al. ^102^ assessed the overall effectiveness of using computer- or manual- reminder systems in ambulatory settings directed at preventive care. RCTs or concurrent led control trials in which the control group received no intervention were included for analysis. Sixteen studies were included in the review.

Mandelblatt et al. ^99^ also addressed the use of interventions to enhance physician breast cancer screening delivery. In this review physician reminder, other office systems, audit with feedback, and physician education were all addressed.

One additional review addressed the use of mailed patient reminders on mammography screening. ^106^ Sixteen published studies were included for meta-analysis. Patient reminders included generic vs. tailored and letters with set appointments vs. no appointment.

The review by Yabroff et al. ^108^ classified interventions broadly under the following headings: behavioral, sociological, and cognitive interventions. Results are presented by these specific category types and not by single intervention (i.e., mailed reminders, physician advice) making it difficult to assess the effect size of a specific intervention.

The Jepson et al. report ^96^ and Ratner et al. review ^101^ included systematic reviews of several single interventions. No meta-analytic techniques were utilized for the Jepson et al. report, and results were narratively described by primary study. Results were synthesized broadly by intervention topic for a wide range of preventive services (i.e., mailed reminders seem to be effective overall). The Ratner et al. review incorporated meta-analysis to identify factors that influenced the effectiveness of interventions in increasing women's use of screening mammography programs. Included in this review were interventions such as mailed materials, physician reminders, telephone counseling, and patient education.

Finally, the review by Shekelle et al. ^103^ was a systematic review to determine the best strategies for early detection and prevention currently covered by Medicare and to asses interventions designed to improved screening in several prevention topics (mammography, Pap testing, colon cancer screening, immunization etc). Included in this review were interventions such as financial incentives, patient and provider reminders, organization changes, patient and provider education, and feedback.

### Findings of Systematic Reviews

#### Healthcare provider-directed interventions

1. Physician Training
  No systematic review exclusively addressing physician training on promoting uptake of screening mammography was identified. However, three systematic reviews, which were all rated highly methodologically, addressed physician training by including primary study data. ^96,^ ^99,^ ^100,^ ^103^ The Jepson et al. report (2001) ^96^ included four such studies (three RCTs and one controlled trial) that evaluated the impact of educational sessions, printed materials, and educational outreach visits targeted towards health care providers. The review suggests a small increase in the uptake of screening tests in the intervention group when compared with the control group. The report states that relative risks (RRs) were not calculated due to the lack of data. However, one RCT evaluating a day-long education session for eight screening procedures (Pap, mammography, breast self exam, cholesterol screening, etc.) reported that physician education intervention ultimately increased the proportion of women having a mammogram (p<0.01). ^96^
  Mandelblatt and Kanetsky concluded that there was a paucity of controlled trials addressing medical education strategies. ^99^ Within this review, six controlled trials included educational strategies, two used education as the major intervention, and the remainder included educational components with other concurrent interventions. One community-based study, which the review identified as having sufficient data to calculate confidence intervals, found a significant increase in mammography rates. The difficulty with much of the literature in this area is that reports focusing on educational strategies are limited by the inability to separate the impact of the education component exclusively from other strategies.
  In 1999, Mandelblatt and Yabroff reviewed provider-targeted interventions to increase screening mammography. ^100^ In this review, the author classified educational sessions as a cognitive intervention and did not report interventions separately. The review concluded that cognitive intervention strategies improved mammography rates by 18.6 percent (95 percent CI, 12.8 to 24.4). All types of interventions targeted at providers were effective in increasing mammography rates (behavioral, sociological, and cognitive).
  The review by Shekelle et al. reported effectiveness of provider education designed to improve the use of mammography screening (OR 2.26, 95 percent CI 1.81 to 2.82). The report found that the intervention with the greatest number of studies was patient reminders, followed by patient education.
2. Office System Prompts
  Ten reviews addressed the issue of office system prompts and reminders to promote uptake of screening mammography. ^94,^ ^96,^ ^97,^ ^99–105^ Four reviews combined all office-system prompts (chart reminder, and computer and manual reminders). ^96,^ ^100,^ ^104,^ ^105^ Three reviews addressed specific office-system prompts and included computer-generated, non-computerized, front-of-chart reminders, and those that had an alternative delivery method. ^94,^ ^97,^ ^99^ Only one review specifically evaluated office-system prompts involving computer-based clinical reminder systems. ^102^ All of the reviews were consistent in their findings and suggested a positive effect on screening utilization.
  Snell and Beck ^105^ state generally that office-system interventions increased compliance with cancer screening (d [the average amount of change in standard deviation units achieved by individuals in a treated group vs. the change achieved by members of a control/comparison group for a particular study] +0.1705, 95 percent CI +0.16 to +0.18). The results in this review were not presented separately by specific office-system intervention and also included other screening practices such as Pap smears, fecal occult blood tests, and rectal exams.
  Shea et al conducted a systematic review of RCTs to evaluate computer-based clinical reminder systems in preventive care. ^102^ The review found that computer-based reminder systems improved breast cancer screening (OR 1.88, 95 percent CI 1.44 to 2.45).
  The overview by Balas et al. ^94^ included 33 studies that looked at improving preventive care by prompting physicians. Fourteen studies pertained specifically to mammography and evaluated all types of office-system prompts combined. The results demonstrated the effect of prompting (presented as a rate difference) to be 11.5 percent, (95 percent CI 7.1 to 16.0).
  Kupets and Covens conducted a systematic review of interventions for improving both cervical and breast cancer screening and presented results separately by topic. ^97^ The review examined physician-based, patient-based, and the combination of the two strategies. The report concluded that the six studies that included computer-generated reminder systems suggest this to be an effective intervention. The delivery of mammography to patients improved by an absolute rate of 6 to 30 percent. The author noted that no benefit was seen from the use of an information sheet or reminder placed on the front of chart.
  Mandelblatt et al. ^99,^ ^100^ evaluated the use of interventions designed to increase physician screening for breast cancer. Provider-targeted interventions included reminder or office system prompts ^99,^ ^100^ or other physician-reminder systems. ^99^ Results for both reviews were similar. The review concluded that physician-based interventions can be effective in increasing screening use. In particular, behavioral interventions (reminders, office system prompts) increased screening by 13.2 percent (95 percent CI 7.8 to 18.4). ^100^
  As part of a larger review, Jepson et al. ^96^ identified five RCTs that evaluated the effectiveness of physician reminders in increasing uptake. All three reported an effect of the intervention, but one was only a small cluster RCT. Jepson et al. reports that one good-quality RCT reported the mean mammography completion rate was 47.9 percent vs. the control 34.6 percent, which was statistically significant (p value was not reported).
  The review by Sin and St Leger reported findings under the broad categories of person directed, social network directed, and multi-strategy. ^104^ There was mention of office system prompts; however, the results were reported narratively and did not provide enough data to make definitive conclusions regarding this intervention.
  The review by Shekelle et al. ^103^ addressed office-system prompts as part of a larger review of screening services. Office-system prompts specific to mammography were not presented separately; however, the authors reported that office-system prompts, in the form of physician reminders, were shown to be effective and calculated the OR to be 1.59 (95 percent CI 1.36 to 1.86).
3. Audit and Feedback
  No systematic review was identified which exclusively focused on audit and feedback as an intervention to promote the uptake of screening mammography. However, four reviews were identified that addressed the effectiveness of audit and feedback on mammographic screening practices ^96,^ ^97,^ ^99,^ ^103,^ ^105^ as part of a larger review.
  Snell and Buck conducted an overview, which combined cervical and breast cancer screening, that showed effect sizes for physician-directed intervention studies (n=4) for audit with feedback alone to be (d +0.2826, 95 percent CI +0.2155 to +0.3498) ^105^ . The results for audit and feedback combined with other physician-directed interventions are reported in the multi-strategy interventions section.
  Mandelblatt and Kanetsky ^99^ identified three trials, which demonstrated a 15 to 24 percent increase in rates of mammography. It was reported that long-term effects of audit and feedback were not evaluated in any of the research. Similarly, Kupets and Covens ^97^ reported that two studies identified by their search showed an improvement in the delivery of mammograms, with an absolute increase in uptake of 14 to 30 percent.
  The review by Shekelle et al. ^103^ addressed feedback as part of a larger review of screening services. The authors reported that feedback was shown to be effective and calculated the OR to be 1.49 (95 percent CI 1.24 to 1.80).
4. Opinion Leaders
  No studies utilizing opinion leaders exclusively to promote the uptake of mammographic screening interventions were identified.

#### Individual-directed interventions

1. Invitations or reminders
  The most widely investigated interventions to promote the uptake of mammographic screening are patient-directed interventions (mailed invitations, mailed reminders). Twelve reviews addressed invitations and/or reminders to promote the use of mammographic screening. ^95–99,^ ^101–104^ ^106–108^ Of the 12 systematic reviews, four ^98,^ ^106–108^ combined data to provide results from meta-analysis.
  Only one review identified by our search conducted a meta-analysis that looked specifically at mailed patient reminders for mammographic screening. ^106^ The review by Wagner evaluated the effectiveness of mailed reminders and included 16 published articles that were pooled for meta-analysis. The review reports that among studies in which controls did not receive any type of reminder, women who received reminders were approximately 50 percent more likely to attend a mammography (OR 1.48, p <0.001). In addition, the author stated that tailored letters were found to be more effective than generic reminders (OR 1.87, p <0.05). In a cost-effectiveness analysis that accompanied the main study, it was found that the cost per women screened ranged from $0.96 to $5.88.
  Sin and St Leger undertook a systematic review of studies that evaluated invitations or reminders under the broad categorization of “person-directed interventions” and used mammographic screening rates as the outcome measure. ^104^ Of the 20 studies focusing on the person-directed interventions that were included in the review, 14 were randomized trials. Appointments on the invitation letter increased uptake of screening mammography (86 percent) compared with open-ended invitations (76 percent). No additional benefit was observed from the addition of a letter from a general practitioner.
  Yabroff et al. conducted a systematic overview of patient-directed interventions to promote mammography use. ^107^ They found that 13.2 percent more women who received a behavioral intervention (i.e., telephone or mailed reminder) attended mammography compared with usual care.
  Bonfill et al. reported that a letter of invitation inviting women into a community breast-screening program was one of the most effective interventions (OR 1.66, 95 percent CI 1.43 to 1.92) in order of effect, of the interventions they examined ^95^ .
  Kupets and Covens ^97^ found conflicting results for the four studies identified in their review. The overview did not exclusively focus on mailed invitations or reminders; rather it included four studies that addressed this intervention. Three of the four studies identified in the overview did not show a statistically significant improvement for breast cancer screening. In fact, one study produced a negative effect of the intervention on screening in the study arm of 10 percent, although not statistically significant. One study showed a 10 percent increase in breast screening, indicating a number needed to intervene (NNI) of 10 patients, meaning one out of every 10 patients will respond to a screening reminder.
  Jepson et al. ^96^ included 57 studies in a qualitative systematic review that examined invitations or reminders for several screening topics. The results are presented across screening topics; however, specifically for mammography, some evidence was reported for the effectiveness of reminders for mammograms. Studies included in this report showed conflicting evidence. The Jepson et al. report also provided information narratively for telephone reminders vs. mailed reminders or physician advice.
  Like the Jepson et al. review, the Shekelle et al. review included patient reminders as an intervention as part of a larger review of screening topics. The authors reported an OR of 2.57 (95 percent CI 2.22 to 2.98).
2. Telephone counseling
  No systematic reviews were identified that addressed the use of telephone counseling exclusively for the uptake of mammographic screening. However, several reviews addressed this intervention as a component of a larger review or as part of a multicomponent intervention, and data was not extractable for this review.
3. Health care provider advice
  One review addressed the use of health care provider advice ^96^ and uptake of mammographic screening; however, the results were not provided separately from other interventions to promote uptake and were not extractable for this review.
4. Educational materials
  Seven studies addressed the use of educational materials as an intervention to promote the uptake of mammographic screening. ^95,^ ^96,^ ^99,^ ^101,^ ^103,^ ^104,^ ^108^ Three of the six studies identified by our search classified educational materials into a broader category of cognitive interventions (i.e., individually-tailored education as a component of a letter), ^108^ or patient-directed interventions, ^104^ or they combined the results with reminders, ^99^ making it difficult to summarize results for the effectiveness of educational materials alone as an intervention to promote uptake.
  The Health Technology Assessment Report by Jepson et al. in 2000 ^96^ did not focus exclusively on the use of educational materials to promote uptake. Within this report nine studies were identified. The report stated that there was no effect of printed materials versus an active control group in two RCTs in which RRs could be calculated. Jepson et al. also stated that four of five RCTs showed no increase in mammography uptake from educational telephone calls when compared with a control group.
  Bonfill et al.'s review ^95^ identified only one study that compared the effects of sending educational materials with no intervention as part of a much larger review. It was reported that there was evidence that mailed educational materials was an effective strategy (OR 2.81, 95 percent CI 1.96 to 4.02) for recruiting women into a community breast-screening program. The results from the review by Ratner et al. ^101^ were not presented individually by intervention topic. Rather, the individual studies were listed narratively in a table format and did not provide enough data to make conclusions regarding the effectiveness of mailed patient education as an intervention to promote the uptake of screening mammography. Within this review, the PRECEDE model was used as a framework to make distinctions among various interventions. These models revealed that more recent studies (those conducted from 1990 to 1996) were associated with higher screening rates, and those designed to target older women (minimum age 50 to 65 years) and set in clinics exhibited smaller screening rates.
  The Shekelle et al. review ^103^ found that patient education interventions were effective and reported an OR of 1.31 (95 percent CI 1.31 to1.52). The descriptions of studies are reported narratively and overall conclusions are done across screening topics.
5. Social network
  Of the 15 reviews included in the mammography chapter, only one review addressed and reported social network findings separately with some analysis. ^107^
  Yabroff and Mandelblatt identified nine studies that pertain to social-network interventions, however, they classified several types of social-network interventions (i.e., community peers, friends, lay health advisors or media representations) loosely under the heading “sociologic interventions” to increase mammographic screening. These patient-directed sociological interventions were grouped for analysis and showed an improved utilization of mammographic screening by 12.6 percent (95 percent CI 7.4 to 17.9).
  Within the Sin and St Leger review, social-network-directed interventions are addressed, but findings are presented in a narrative overview of the included studies and provides no extractable data. ^104^
6. Other types of inventories
  The Shekelle et al. review addressed organizational change as an intervention to promote screening mammography. ^103^ They reported that organizational change was consistently one of the most (or the most effective) interventions at increasing the use of preventive services. The OR for improving mammography was 2.26 (95 percent CI 1.81 to 2.83). Organizational change was the most heterogeneous intervention and was often combined with reminder letters.
  The overview conducted by Bonfill et al. ^95^ identified two studies evaluating the use of a home visits to promote the uptake of mammographic screening. No statistically significant differences between the use of home visit and control (no intervention) were found.
  The use of a patient-initiated touch-sensitive computer system was reviewed by Kupets and Covens ^97^ 2001. Only one study was included in the report. A computer was placed in the waiting area of the physician's office that was accessible to all patients. The review stated that this intervention was effective for improving mammography with an absolute increase of 9 percent, with an NNI of 11 patients.

#### Access-enhancing interventions

1. Financial barriers
  Four reviews were identified that addressed some aspect of removal of financial barriers to promote uptake of breast cancer screening, ^96,^ ^98,^ ^103,^ ^107^ Legler et al. undertook a systematic review to determine which types of mammography-enhancing interventions were most effective for diverse populations. ^98^ The results were presented under a broad topic of access-enhancing strategies, which included removal of financial barriers, mobile vans, vouchers, etc. Results from this meta-analysis showed the strongest categories of mammography-enhancing interventions were access-enhancing interventions (18.9 percent increase in mammography use). The author states that the most impressive effects were not for single-category approaches but for combinations of interventions with an effect size of 26.9 percent (95 percent CI 9.9 to 43.9; 9 studies) for the combination of access-enhancing and individual-directed interventions and 19.6 percent (95 percent CI 8.2 to 30.6; 5 studies) for the combination of access-enhancing and system-directed interventions ^98^ .
  Yabroff and Mandelblatt found two patient-targeted interventions that used financial incentives to try to increase the uptake of mammographic screening. Both studies showed an increase in mammography use, but a meta-analysis was not conducted due to the small number of studies available.
  In the overview conducted by Jepson et al., they identified three studies that focused on the removal of financial barriers and reported the results narratively by study (free or reduced-cost tests, transportation, or postage). Of the three studies, two were RCTs and one was a quasi-RCT. The author stated that one well-designed RCT was identified that examined the use of free screening by voucher, and showed it was very effective in increasing mammographic screening (RR 4.28, 95 percent CI 1.91 to 9.60). The other two studies also showed a significant effect of the intervention and were targeted at minority women; no other information was provided.
  The overview by Shekelle et al. includes meta-regression analysis for financial incentives as part of a much larger review of preventive services. The authors reported that this intervention was effective in promoting screening mammography with an OR of 3.57 (95 percent CI 2.36 to 5.40).
2. Access barriers
  The findings for access barriers are summarized under the removal of financial barriers heading. However, one review ^104^ highlighted one small before-and-after study that suggested that bus transport for Asian women (unpublished data) from the health center to the screening center could increase uptake (46 percent before intervention compared with 73 percent after intervention).
3. Media campaigns
  Three systematic reviews that addressed the use of media campaigns to promote the uptake of breast cancer screening were identified. ^96,^ ^98,^ ^107^ Two of the three reviews provided results separately by intervention and estimated the effect size of the intervention. ^96,^ ^107^ The systematic review by Legler et al included six studies that were specific media campaigns used to promote breast cancer screening. ^98^ They reported the pooled incremental benefit for media campaigns was 1.3 (95 percent CI 1.0 to 1.8).
  The overview conducted by Jepson et al. identified one RCT that assessed the effectiveness of mass media interventions compared with community interventions for increasing uptake of mammography and found that there was a significantly lower uptake of mammography by women in the media-promotion towns when compared with the community intervention towns (p<0.001). No details of baseline estimates were provided. They reported a controlled trial that compared a mass media campaign vs. a control to increase breast and cervical screening practices. The intervention had no effect on patients being up-to-date on any of the tests, but did increase knowledge of screening tests and the intention to have a mammographic screening test.
4. Policy level interventions
  No studies that addressed the use of policy level interventions to promote the uptake of mammographic screening exclusively were identified.
5. Multi-strategy interventions
  Eight overviews that addressed the use of multi-strategy interventions to promote the uptake of mammographic screening were identified. ^96–98,^ ^100,^ ^102–105^ Of the eight reviews, three included meta-analysis. ^98,^ ^100,^ ^103^ Combined interventions appeared to have an increased effect on increasing uptake of mammographic screening.
  Shea et al. ^102^ addressed the use of combining both manual and computer- generated reminders to improve physician delivery of breast cancer screening. The review included sixteen RCTs of which eleven were exclusively focused on mammography. When comparing the use of manual reminders to the combination of computer-generated and manual reminders, the adjusted OR was 1.42 (95 percent CI 1.02 to 1.97, p=0.04) when all preventive categories were combined for analysis. The review states that these findings suggest an additional benefit from combining the two interventions compared with manual reminders alone. The results for mammography were not presented separately.
  Mandelblatt and Yabroff ^100^ found that in interventions that combined cognitive (i.e., audit and feedback and educational sessions and materials) and behavioral strategies (i.e., reminder or office-system prompt) to reach providers, the combined effect was a 21.0 percent increase in mammography rates (95 percent CI 8.8 to 33.6) in contrast to usual care. When cognitive and behavioral strategies were combined and targeted to both patients and providers within communities, the analysis showed no improvement (1.1 percent increase, 95 percent CI -6.8 to 9.0).
  Legler et al. ^98^ also addressed the combination of interventions in the same fashion as Mandelblatt and Yabroff. The interventions were categorized according to Rimer's intervention typology (See Table 1, Chapter 1). The review stated that the strongest combination of approaches used were access-enhancing and individual-directed strategies and resulted in an estimated 27 percent increase in absolute mammography use (95 percent CI 9.9 to 43.9) and found that the combination of access-enhancing and system-directed combination showed a 20 percent increase (95 percent CI 8.2 to 30.6). Similarly, Snell and Buck ^105^ reported that greater success was found for interventions targeting the physician both during and outside the patient visit (d +0.1222 during visit, d +0.1849, both d +0.3375). Screening behavior improved when the physicians were the target of more than one, but not more than three interventions (d +0.1360, d +0.2495, d +0.6829, d -0.0058).
  Sin and St Leger ^104^ conducted a systematic review of interventions to increase breast screening uptake. Studies were included if uptake was the outcome measure of the intervention and if relevant to the United Kingdom (UK) screening program. Interventions were broadly categorized as “social-network-directed”, “person-directed”, or “multi-strategy”. Only one multi-strategy intervention was identified by their search. The use of clerical help to check addresses of non-attendees and a reminder letter in 93 inner city practices was evaluated. Results showed a subsequent uptake of 58.5 percent compared with 53.8 percent before the study. The author stated that the findings were circumstantial, and any real increase probably had a limited role in inner-city practices. ^104^
  The review by Kupets and Covens ^97^ addressed the use of multi-strategy interventions for mammography and cervical cancer screening, specifically audit and feedback combined with computer-generated reminders and physician computer-generated reminders combined with patient-reminder cards. One study for the use of audit and feedback combined with computer-generated reminders was identified by the review. The report stated that there was no difference in the delivery of breast screening between the arm of a physician-reminder letter alone and the combination of audit and feedback and reminder. Four studies looking at the combined effects of computer reminders for physicians and patient-reminder cards showed mixed results within the review. Two studies indicated an increased effect of the combined interventions for screening mammography (15 to 20 percent), while the other two studies showed no additive effect with the use of multiple interventions on screening practices.
  Jepson et al. ^96^ summarized combined interventions aimed at physicians and/or patients for several preventive services. For mammography, three studies were identified that evaluated the effect of physician reminders combined with individual letters, and all of the studies reported a statistically significant effect of the intervention when compared with control groups. Two controlled trials compared audit and feedback aimed at the physician with education and a request form for mammography. No statistically significant difference was seen in uptake rates between the intervention groups as compared with controls (45.9 to 49 percent vs. 47 to 56 percent).
  Finally, the Shekelle et al. review ^103^ presented narratively some of the studies that looked at multi-strategy interventions and based conclusions on multi-strategy interventions across several screening topics. For this reason, we could not extract enough data from the review to present results for mammography specifically.

## Cervical Cancer Screening

### Key Question #4

What is the effectiveness of cancer control interventions that promote cervical cancer screening?

### Background

In the recently released annual report from NCI, CDC, NAACCR and ACS on the status of cancer, cervical cancer was listed as one of the top 10 most frequent cancers for women aged 20 to 49 years. ^33^ It is estimated that in the US, 13,000 new cases of invasive cervical cancer will be diagnosed in 2002, and roughly 4,100 women will die of the disease. Although the incidence of invasive cervical cancer has decreased significantly over the past 40 years in general, the incidence among young white women has increased. ^110^

Much of this reduction in cervical cancer incidence can be attributed to the development of organized early detection programs. ^110^ The principal screening test for cervical dysplasia and cancer is the Pap test. The US Preventive Services Task Force (USPSTF) recommends routine screening for cervical cancer for all women who are or have been sexually active and who have a cervix; Pap tests should begin with the onset of sexual activity and be repeated at least once every three years. However, despite the apparent benefits of screening, nonadherence to screening recommendations remains a critical issue. Fifty percent of the 13,000 women developing cervical cancer annually in the US have never had a Pap test, and an additional 10 percent have not had a Pap test within five years of their diagnosis. ^111^ Although most of these women are uninsured, nonadherence has still been observed among women with comprehensive medical coverage. ^112^

Over the past two decades, several systematic reviews have been written which have examined the effectiveness of interventions to promote uptake of cervical screening. In light of these findings, effective interventions to promote cervical cancer screening and effective strategies to disseminate these interventions are needed.

Overviews were included if they reported the effectiveness of interventions to promote cervical cancer screening behaviors (e.g., office-system prompts to physicians, invitations or reminders to patients). Studies that were not published in English, were published before 1990.

### Included Studies

The search strategy yielded 95 citations, of which 26 met basic inclusion criteria at title and abstract screening. Of those, 13 met criteria for full text relevance screening (Figure 6). Nine reviews provided enough extractable data (either results presented narratively or in combination with other preventive services) specifically related to our report and provided enough evidence to be presented in the evidence tables ^94,^ ^96,^ ^97,^ ^102,^ ^103,^ ^105,^ ^113–115^ (Evidence Table 7). The remaining four studies did not have enough extractable data (i.e., cervix and immunization results intermixed) and were placed in a general table ^37,^ ^109,^ ^116,^ ^117^ (Appendix G).

Figure 6. Cervical Cancer Screening: Search yield for studies evaluating the effectiveness of cancer control interventions (Key question #4)

The interventions addressed in these reviews are presented in Summary Table 7. These include healthcare provider-directed, individual patient-directed, access-enhancing, media education campaigns, and multi-strategy interventions.

Summary Table 7. Cervical cancer screening - Interventions addressed in systematic reviews on the effectiveness of cancer control interventions

Lead Author (Year) | Healthcare provider-directed interventions | | | | | Individual (patient)-directed interventions | | | | | | Access-enhancing interventions | | | Media education campaigns | Policy-level interventions | Multi-strategy interventions
| Healthcare provider training | Office systems (e.g., prompts) | Audit and feedback | Opinion leaders | Other | Invitations or reminders | Telephone counseling | Healthcare provider advice | Educational materials | Social network | Other | Financial barriers | Access barriers | Other
Austin, SM ^113^ (1994) | | ✓^ M ^
Balas, EA ^94^ (2000) | | ✓^ M ^
Jepson,R ^96^ (2000) | ✓ | ✓ | | | | ✓ | | ✓ | ✓ | | ✓ | ✓ | | | ✓ | | ✓
Kupets, R ^97^ (2001) | | ✓ | ✓ | | | | | | | | | | | | | | ✓
Pirkis, JE ^114^ (1998) | | ✓^ M ^ | | | | ✓^ M ^
Shea, S ^102^ (1996) | | ✓ | | | | | | | | | | | | | | | ✓
Shekelle, PG ^103^ (1999) | ✓^ M ^ | ✓^ M ^ | ✓^ M ^ | | ✓^ M ^ | ✓^ M ^ | | | ✓^ M ^ | | | ✓^ M ^
Snell, JL ^105^ (1996) | ✓ | ✓ | ✓ | | ✓ | | | | | | | | | | | | ✓
Tseng, D ^115^ (2001) | | | | | | ✓^ M ^

Legend: M=meta analysis performed; T=Target population specified

The quality of reviews was high. Of the nine from which data was extracted, six received a rating of “strong” ^94,^ ^96,^ ^102,^ ^103,^ ^114,^ ^115^ (achieving a score of 5 or 6); and three were rated as “moderate” ^97,^ ^105,^ ^113^ (receiving a score of 3 or 4). No weak studies were identified. The most common weakness of the reviews was lack of formal quality assessment ^97,^ ^102,^ ^105,^ ^113,^ ^115^ (Summary Table 8).

Summary Table 8. Cervical cancer screening - Quality assessment rating of included systematic reviews

Lead Author (Year) | Quality Assessment
| Search strategy stated | Comprehensive search | Level of evidence | Quality assessment | Integrate findings | Data support conclusions | Overall score (0–6) | Overall rating^a^
Austin, SM ^113^ (1994) | | | ✓ | | ✓ | ✓ | 3 | MODERATE
Balas, EA ^94^ (2000) | ✓ | ✓ | ✓ | ✓ | ✓ | ✓ | 6 | STRONG
Jepson,R ^96^ (2000) | ✓ | ✓ | ✓ | ✓ | ✓ | ✓ | 6 | STRONG
Kupets, R ^97^ (2001) | ✓ | ✓ | ✓ | | | | 3 | MODERATE
Pirkis, JE ^114^ (1998) | ✓ | ✓ | ✓ | ✓ | ✓ | ✓ | 6 | STRONG
Shea, S ^102^ (1996) | ✓ | ✓ | ✓ | | ✓ | ✓ | 5 | STRONG
Shekelle, PG ^103^ (1999) | ✓ | ✓ | ✓ | ✓ | ✓ | ✓ | 6 | STRONG
Snell, JL ^105^ (1996) | ✓ | | | | ✓ | ✓ | 3 | MODERATE
Tseng, DS ^115^ (2001) | ✓ | ✓ | ✓ | | ✓ | ✓ | 5 | STRONG

a Overall rating was based on overall score: ≤ 2=weak; 3–4=moderate; 5–6=strong

Refer to Appendix E, Form 4 for full details on information collected for Quality Assessment

There were seven systematic reviews from the US, one from Canada, and one from Australia. Of the nine systematic reviews included, only two were entirely focused on cervical cancer screening, ^114,^ ^115^ while five focused on the topic of cervical cancer screening combined with other topics including mammography, ^97^ mammography and colorectal cancer screening ^105^ , colorectal and cardiovascular risk reduction, ^102^ influenza, ^94^ and tetanus ^113^ or a combination of several screening topics. ^103^ The ninth review ^96^ included a wide variety screening for both cancer and non-cancer related topics. For the purpose of this chapter, only the results pertaining specifically to the promotion of cervical cancer screening will be presented.

### Description of Systematic Reviews of Interventions to Promote Uptake of Cervical Cancer Screening

#### Reviews of interventions to promote uptake of cervical cancer screening

Several systematic reviews have been undertaken to determine which interventions are effective to promote the uptake and/or delivery of cervical cancer screening (Summary Table 7). A comprehensive systematic review by Jepson et al. ^96^ (2001) of the determinants of screening uptake and interventions for increasing uptake was identified. The review included RCTs, controlled trials, cohort studies, or case-control studies where there was a prospective time barrier between the measurement of determinants and the uptake of screening. They identified 190 studies that met inclusion criteria of which 130 were RCTs. For the purposes of this report, we consider only those studies included in the analysis of cervical cancer screening (n=12, eight of which were RCTs). Two systematic reviews addressed the interventions under the general headings of patient- vs. physician- directed interventions and present the results by grouping rather than by each specific intervention (i.e., reminder letter or telephone call). The remainder of the reviews addressed specific intervention topics. Three looked specifically at the effectiveness of office-system prompts (general practitioner [GP] reminders) on cervical cancer screening. ^102,^ ^113,^ ^118^ Within this subset, one addressed computer-generated reminders exclusively ^102^ . Two other overviews addressd the effectiveness of reminders aimed at both GPs and patients ^114^ or mailed reminders to patients. ^115^ Finally, the review by Shekelle et al. ^103^ is a systematic review to determine the best strategies for early detection and prevention currently covered by Medicare and to assess interventions designed to improved screening in several prevention topics (mammography, Pap testing, colon cancer screening, immunization, etc.). This review included interventions such as financial incentives, patient and provider reminders, organization changes, patient and provider education, and feedback.

#### Reviews of single interventions to promote the uptake of cervical cancer screening

The majority of evidence for interventions aimed at increasing cervical cancer screening uptake was in the intervention category of office-system prompts. The Austin, ^113^ Shea, ^94^ and Balas ^102^ systematic reviews addressed the effect of physician prompts for increasing cervical cancer screening as part of a larger systematic review addressing preventive healthcare services. Two of the reviews used meta-analytic techniques ^102,^ ^113^ and all of them included only RCTs.

Tseng et al. ^115^ undertook a systematic review, with meta-analysis, using RCTs that involved the use of patient letter reminders to promote cervical cancer screening. ^115^ A total of 10 randomized trials were included for meta-analysis. A second review also addressed the effectiveness of patient reminders ^114^ and included physician reminders as well. This review also included a total of 10 studies in the meta-analysis, with two studies on reminders for GPs alone, four studies on patient reminders, and four dealing with a combination of both.

#### Reviews of multiple interventions to promote uptake of cervical cancer screening

A comprehensive report by Jepson et al. ^96^ on the determinants of screening uptake and interventions for increasing uptake was identified. This report included a broad spectrum of interventions, including healthcare provider-directed interventions (office-system prompts such as a chart reminder and physician training), individual-directed (mailed reminders or invitations to patients for a mammogram, educational materials teaching patients about the benefits of mammography, and healthcare provider advice) and multi-strategy interventions (combination of two or more interventions). The report included 190 articles of which 130 were RCTs. Twelve studies related specifically to cervical cancer screening, and eight were RCTs. No meta-analysis was conducted.

### Findings of Systematic Reviews

#### Healthcare provider-directed interventions

1. Physician training
  Three systematic reviews address the use of physician training to promote physician uptake of cervical cancer screening. ^96,^ ^103,^ ^105^ The Jepson et al. review ^96^ identified four studies that addressed educational interventions to promote the uptake of screening tests. The review reported that two studies addressed Pap testing specifically. One evaluated a one-day seminar, four followup bulletins during the following year, and notes on Pap smear techniques. Only 43 percent of physicians randomized to the intervention attended the seminar, and the average number of Pap smears performed per practice was 40.5 percent in the intervention group and 46.1 percent in the control group. The review states that one other controlled trial reported that an educational outreach visit and educational session by a medical doctor resulted in an increase in uptake of cervical cancer screening (7 percent compared with 2.9 percent in the control group).
  Within the Snell and Buck ^105^ review, two controlled studies were found that a community intervention (which involved a mass media component) in combination with a GP workshop or educational session was effective in increasing uptake of Pap smears. Although this review addressed physician training, results were presented as a multi-component strategy. The results are outlined in the multi-strategy section of this chapter.
  Shekelle et al. ^103^ reviewed intervention strategies for early detection and prevention currently covered by Medicare to assess interventions and found that personalized reminders (which was the intervention with the greatest number of studies) are more effective than generic ones. The effectiveness of interventions to improve the use of clinical preventive and cervical cancer screening were: patient financial incentives OR 3.12 (95% CI 2.62–3.72); patient reminder OR 1.84(95% CI 1.67–2.02); organizational change OR 2.65 (95% CI 2.26–3.12); provider education OR 1.59 (95%CI 1.29–1.97); provider reminder OR 1.40 (95%CI 1.27–1.54); feedback OR 1.12 (95% CI 0.97–1.30), and patient education OR 1.53 (95% CI 1.30–1.82). This review also addressed interventions designed to approve influenza and pneumoicoccal immunization rates, mammography rates, cervical smear cytology (Pap Test), and colon cancer screening.
2. Office-system prompts
  The most abundant information regarding the effectiveness of interventions to promote uptake of cervical cancer screening is available in the area of office systems (i.e., prompts in the form of chart reminders directed at healthcare professionals). In total, eight systematic reviews addressed the use of office systems to promote uptake of cervical cancer screening. ^94,^ ^96,^ ^97,^ ^102,^ ^103,^ ^105,^ ^113,^ ^114^ Of the eight reviews, four used meta-analysis. ^94,^ ^103,^ ^113,^ ^114^
  In the reviews by Kupets and Covens ^97^ and Shea et al., ^102^ computer- generated reminders (either a computer generated reminder placed on the front of the chart compared with control arm of no intervention or a manual reminder placed on the front of the chart) were shown to be effective. The Kupets and Covens ^97^ review identified several studies addressing office-system prompts (i.e., computer-generated reminders, audit and feedback, manual reminder placed on chart) and determined that computer-generated reminders to physicians were proven effective for improving delivery of preventive healthcare to patients. The review stated that of the six studies included in the review, three studies showed significant improvements in cervical cancer screening (9 to 30 percent) with an NNI of 3 to 10 physicians. Conversely, Shea et al. ^102^ found that computer-generated reminders were not effective in increasing the delivery of cervical cancer screening (OR 1.15, 95 percent CI 0.89 to 1.49) when compared with results of six other forms of preventive care examined within the review (i.e., colorectal cancer screening, cardiovascular risk reduction, and breast cancer screening).
  Three other reviews specifically addressed the use of GP reminders/prompts to promote the delivery of Pap screening among their patients. In all three of the reviews, the use of reminders/prompts significantly increased cervical cancer screening practice. Pirkis et al. ^114^ reported that the women whose GPs had been prompted to remind them to have a Pap test were significantly more likely to do so than were control women (typical risk difference [TRD] 6.6 percent, 95 percent CI 5.2 to 8.0). Balas et al. ^94^ also found a significant increase in preventive care performance when prompting of physicians was utilized. It was determined that prompting can significantly increase Pap smear delivery by up to 18.3 percent (95 percent CI 11.6 to 25.1); this too was echoed by Austin et al. ^113^ who found the increase to be significant (OR 1.18, 95 percent CI 1.02 to 1.34). The review by Shekelle et al. ^103^ addressed office-system prompts as part of a larger review of screening services. Office-system prompts specific to cervical cancer screening were not presented separately; however, the authors reported that office-system prompts, in the form of physician reminders, were shown to be effective and calculated the OR to be 1.40 (95 percent CI 1.27 to 1.54).
3. Audit and feedback
  Three reviews were identified by our search that specifically addressed the use of audit and feedback to promote the delivery of cervical cancer screening by physicians. ^103,^ ^105,^ ^114^ One of the reviews ^105^ only addressed audit and feedback as a part of a multicomponent intervention and is referred to in the multicomponent interventions section of this chapter. The only review identified that included information regarding the use of audit and feedback was conducted by Kupets and Covens. ^97^ The review included 14 RCTs and all were related to cervical cancer screening (also tagged with mammography). Of the 14 studies, two specifically addressed the use of audit and feedback to promote delivery of Pap smears. The results indicate that when comparing a control arm of no intervention with audit and feedback, neither study showed improvement in cervical cancer screening rates. The review by Shekelle et al. ^103^ addressed feedback as part of a larger review of screening services. The authors reported that feedback was shown to be effective and calculated the OR to be 1.12 (95 percent CI 0.97 to 1.30).

#### Individual-directed interventions

1. Invitations or reminders
  Four systematic reviews identified were conducted to determine the effectiveness of the use of invitations or reminders directed at patients or individuals to promote the uptake of cervical cancer screening ^96,^ ^103,^ ^114,^ ^115^ of which three incorporated meta-analysis. ^103,^ ^114,^ ^115^
  In the review conducted by Tseng et al., ^115^ a meta-analysis was performed on 10 articles that specifically investigated the use of mailed letter reminders on cervical cancer screening. They reported patient reminder letters in the form of mailed letters increased the rate of cervical cancer screening. The authors reported that most notable within the results was that those studies evaluating lower socioeconomic groups had a smaller response (OR 1.16, 95 percent CI 0.99 to 1.35) than those studies using mixed populations (OR 2.02, 95 percent CI 1.79 to 2.28).
  Similarly, Pirkis et al. ^114^ found that the use of patient reminders would appear to be more effective than GP reminders when compared with normal care, in promoting cervical cancer screening. The authors reported that women whose GPs had been prompted to remind them to have a Pap test were more likely to do so than were control women (TRD 6.6 percent, 95 percent CI 5.2 to 8.0). They reported the estimate of the number of women needed to be involved in a GP reminder scheme in order to produce one additional screen (NNI) is 15.2 (95 percent CI 12.6 to 19.3). Sensitivity analysis revealed that one study stood out as exceptional, and when omitted, the TRD was 7.9 percent (95 percent CI 6.5 to 9.4). The TRD for the group of six patient reminder studies, after removal of one exceptional study to produce homogeneity, was 10.8 percent (95 percent CI 8.1 to 13.6). Jepson et al. ^96^ also found evidence that letters were effective in increasing uptake, with greater effects demonstrated for cervical cancer screening than mammography. However, the review stated that there was not enough evidence to detect whether GP letters suggesting a Pap smear were more effective than those from another source. In the Shekelle et al. review, ^103^ they reported patient reminders for cervical cancer screening as part of a larger review of screening. For cervical cancer screening, the authors reported an OR 1.84 (95 percent CI 1.67 to 2.02).
2. Healthcare provider advice
  Only one systematic review examined the use of health provider advice or counseling for promoting uptake of cervical cancer screening. The Jepson et al. ^96^ review identified five studies that evaluated the use of face-to-face counseling by a health professional in either the home or in a healthcare setting. The results indicated that there was no effect (numerical results not available) of the intervention for increasing the utilization of cervical cancer screening.
3. Educational materials
  The use of educational materials to promote the use of cervical cancer screening has not been widely investigated. Two systematic reviews were identified by our search which incorporated several interventions to promote the uptake of cervical cancer screening. ^96,^ ^103^
  The review by Jepson et al. ^96^ addressed several different types of educational interventions, which included the use of printed educational materials versus controls, audio/visual (videos, tape-slide shows, and computers) and group teaching (classes and workshops). For the three RCTs for which RRs could be calculated, no effect of printed materials was found compared with a control arm. RRs were not calculated for seven other studies. For these remaining studies, they report that results varied from no effect (n=6) to moderately effective (n=1). The information available for the use of audio/visual equipment was limited in this review. Four studies were identified (two RCTs and two quasi-RCTs); however, the results were grouped with other prevention topics. There was a brief mention of one study which found that tape-slide programme playing in a clinic waiting room had no effect on the uptake of Pap smears when compared with controls (author calculated OR 0.97, 95 percent CI 0.63 to 1.49). The Shekelle et al. review ^103^ found that patient-education interventions were effective and reported an OR of 1.53 (95 percent CI 1.30 to 1.82). The descriptions of studies were reported narratively and overall conclusions were done across screening topics.
4. Other types of interventions
  The Shekelle et al. ^103^ review addressed organizational change as an intervention to promote screening mammography. They reported that organizational change was consistently one of the most (or the most) effective interventions at increasing the use of preventive services. The OR for improving mammography was 2.65 (95 percent CI 2.26 to 3.12. Organizational change was the most heterogeneous intervention and was often combined with reminder letters.
  Within the Jepson et al. ^96^ review, they identified only one study: an RCT that evaluated the effectiveness of an organized programme of prevention that included the use of a health-promotion nurse. The intervention was so effective (Pap smear RR 1.56, 95 percent CI 1.44 to 1.69) that the trial was discontinued after two years (instead of three years) because GPs were no longer willing to exclude half of the participants from accessing the health-promotion nurse. Information regarding the specific outline of the study (other than study design description) was not provided by the authors.

#### Access-enhancing interventions

1. Financial barriers
  The information for removal of financial barriers to promote the uptake of cervical cancer screening is inadequate. The use of removal of financial barriers was not addressed systematically; however, one study mentioned within a much larger review by Jepson et al. ^96^ was identified. Jepson et al. reported that the RCT compared using a voucher for free preventive visits with a control group and the results for cervical cancer screening were part of a larger study that included tuberculosis screening and preventive visits. This study concluded that older individuals will respond to these programs, and such services will result in modest health gains. The overview by Shekelle et al. ^103^ included meta-regression analysis for financial incentives as part of a much larger review of preventive services, and the authors report that this intervention was effective in promoting cervical cancer screening with an OR of 3.12 (95 percent CI 2.62 to 3.72).
2. Access barriers
  None of the included reviews addressed access barriers for cervical screening.
3. Media campaigns
  The use of media campaigns to promote the uptake of cervical cancer screening has been understudied. The use of media campaigns was not addressed systematically; however, one controlled trial mentioned within a much larger review by Jepson et al. ^96^ was identified. The controlled trial compared the use of a media campaign with control (communities) to increase cervical (and breast) cancer screening and found that the intervention had no effect on being up to date for any of the tests compared with control.
4. Multi-strategy interventions
  Several systematic reviews addressd the use of multi-strategy or multicomponent interventions for uptake of cervical screening. ^96,^ ^97,^ ^102,^ ^105^ The interventions included were physician-directed, patient-directed and a combination of both physician- and patient-directed interventions (i.e., such as audit and feedback combined with physician education and the use of a flow chart to enhance delivery of Pap smears).
  Snell and Buck ^105^ conducted a systematic review of interventions to increase cancer screening. Within this review cervical, breast, or colorectal cancer screening were included. The effect size for Pap smear (n=35 cases) was d +0.0083 (95 percent CI -0.0174 to +0.0340. The results were also presented generally pertaining to cancer screening and determined that screening behavior improved when the physicians were the target of more than one intervention, but not more than three (d [the average amount of change in standard deviation units achieved by individuals in a treated group vs. the change achieved by members of a control/comparison group for a particular study] +0.1360, d +0.2495, d +0.6829, d -0.0058).
  The Shea et al. ^102^ review examined the use of computer versus manual reminders for improving preventive services and calculated the effect of the combined intervention versus control groups and found only a small benefit (OR 1.12, 95 percent CI 0.82 to 1.51). Similarly, Kupets and Covens ^97^ found that in the three studies identified by their search, one study indicated an additive effect of the combined intervention (patient letter combined with computer-generated reminder) of cervical cancer screening of 15 percent, while the two other studies (patient reminder letter combined with computer-generated reminder, and physician reminder combined with patient-carried health maintenance prompt card) did not show an additive effect.
  The Jepson et al. ^96^ review also addressed the use of combined interventions on the uptake of cervical cancer screening. Fifteen studies (10 RCTs, two quasi-RCTs, and three controlled trials) evaluated a combination of interventions to increase uptake of screening. The following combinations were shown to be effective at increasing uptake when compared with control: invitation letter from GP plus education, an invitation letter plus followup call from a health educator, and physician reminder combined with invitations to individuals. Finally, the Shekelle et al review ^103^ presents narratively some of the studies that look at multi-strategy interventions and based conclusions on multi-strategy interventions across several screening topics. For this reason, we could not extract enough data from the review to present results for cervical cancer screening specifically.

## Control of Cancer Pain

### Key question #5

What is the effectiveness of cancer control interventions that promote the control of cancer pain?

### Background

A recent Evidence Report produced by the AHRQ suggests that one-third to one-half of all patients undergoing active cancer treatment experience pain as do about three-quarters of individuals with advanced cancer. ^85^ The prevalence or incidence estimates of cancer pain, defined as “pain caused by the disease or its treatment, such as surgery, radiation therapy or chemotherapy”, depend on the type and stage of cancer and setting. The authors of the report indicate that “cancer pain adds substantially to the already considerable national burden of cancer”. Special populations such as minorities, the elderly, and women may be at risk for the under-treatment of pain. The review concluded that many treatments are effective for managing cancer pain, but there are impediments to optimal pain management, such as inconsistent assessment of pain, patient and provider barriers, regulatory constraints, and reimbursement issues.

This review examines systematic reviews to promote the uptake of cancer pain control interventions among patients with cancer pain. It specifically excludes systematic reviews that focus entirely on control of non-cancer pain.

### Included Studies

There were 2,432 unique citations identified for title and abstract screening (Figure 7). Of these, 27 articles met the criteria and were eligible for full text screening. One review met the inclusion criteria and was specific to cancer pain (Evidence Table 5).

Figure 7. Control of Cancer Pain: Search yield for studies evaluating the effectiveness of cancer control interventions (Key question #5)

#### Inverventions to promote evidence of cancer pain

One systematic review examining the World Health Organization (WHO) Analgesic Ladder was excluded as the studies did not evaluate the effectiveness of the intervention. ^119^ Two reports ^120,^ ^121^ met the inclusion criteria, but did not have extractable data and are included in the general table (Appendix G).

The objective of the review by Allard et al. ^122^ was to identify and describe educational interventions conducted to improve pain control in patients with advanced cancer. Outcomes were participants' attitudes and knowledge, pain management, patients' quality of life, and pain levels. Thirty-three studies targeting either health professionals (HPs) (25 studies) or patients with advanced cancer (seven studies) or their family caregivers (one study) were included. Across all studies, the format and duration of the interventions varied (Summary Table 9). Of the 25 studies targeting HPs, the most frequently studied interventions were educational courses or workshops (16 studies). Some of these interventions targeted opinion leaders (one study) or other types of role models (five studies). Other interventions included the use of pain assessment tools (three studies), provision of guidelines or a treatment algorithm (three studies), provision of patient pain scores to clinicians (two studies), and a combination of education and the creation of a supportive care service (one study).

Summary Table 9. Control of cancer pain - Interventions addressed in systematic reviews of the effectiveness of cancer control interventions

Author (Year) | Healthcare provider-directed interventions | | | | | Individual (patient)-directed interventions | | | | | | Access-enhancing interventions | | | Media education campaigns | Policy-level interventions | Multi-strategy interventions
| Healthcare provider training | Office systems (e.g., prompts) | Audit and feedback | Opinion Leaders | Other | Invitations or Reminders | Telephone counseling | Health-care provider advice | Educational materials | Social network | Other | Financial barriers | Access barriers | Other
Allard, P{9} (2001) | ✓ | | | ✓ | ✓ | | | | ✓

The methodological quality of the review was scored as “moderate” (Summary Table 10).

Summary Table 10. Control of cancer pain - Quality assessment rating of included systematic reviews

Lead Author (Year) | Quality Assessment
| Search strategy stated | Comprehensive search | Level of evidence | Quality assessment | Integrate findings | Data support conclusions | Overall score (0–6) | Overall rating^a^
Allard, P{9} (2001) | ✓ | ✓ | ✓ | | | ✓ | 4 | MODERATE

a Overall rating was based on overall score: ≤ 2=weak; 3–4=moderate; 5–6=strong

Refer to Appendix E, Form 4 for full details on information collected for Quality Assessment

Of the eight studies targeting patients or families, all the interventions included education with or without the provision of a booklet or diary. Six studies were RCTs (four targeting HPs and two targeting patients/family caregivers) and three were quasi-experimental designs (QEDs) with a non-equivalent control group (two targeting HPs and one directed to patients/family caregivers). Of the nine RCTs and QEDs, only four studies enrolled over 100 patients.

### Findings of the Systematic Review

#### Healthcare provider-directed interventions

Across all 25 studies, knowledge or attitude was improved to a variable degree in all 13 studies in which this outcome was measured. When only the studies with stronger designs (four RCTs and two QEDs) were considered, knowledge was increased in the only two studies in which it was measured. Pain management strategies such as compliance with guidelines were improved in seven of 10 studies. In the six studies with stronger designs, only two of four studies showed an improvement in adherence to guidelines or analgesic prescription. Patients' pain relief was measured in seven studies with at least some improvement noted in four. In the stronger studies, pain was assessed in all six studies and was improved in three.

Promising interventions in an outpatient setting appeared to be the transmission of patients' self-reported pain scales to oncologists and the use of treatment algorithms for improving prescribing and reducing pain. Interventions involving role modeling or nursing pain assessments and use of a flow sheet may reduce pain, but these studies were relatively small and employed less rigorous designs.

#### Individual-directed interventions

Patient knowledge or attitude was measured in six of eight studies and was improved in all six including those with stronger designs. In contrast, pain management was measured in only three of eight studies and was improved in all three including one of the strong studies. Pain relief was improved in five of eight studies, including three of the stronger studies. The authors of the review reported that promising interventions for pain control in ambulatory settings appeared to be brief nursing interventions to patients combined with a daily pain diary.

In summary, a nursing pain education program coupled with a daily pain diary can increase pain relief. A brief nursing counseling intervention combined with a pain management booklet is also promising. There are too few studies of interventions of the education of family caregivers to comment on their effectiveness.

### Gaps in the Evidence

Despite convincing evidence of both the burden imposed by cancer-related pain and the effectiveness of some strategies to reduce such pain, few rigorous evaluations of interventions to promote the uptake of effective pain assessment and management have been undertaken. One widely known intervention designed to promote effective control of cancer pain that has not been well evaluated is the WHO analgesic ladder. ^123^ A systematic review of studies describing patients treated according to the WHO analgesic ladder concluded there was insufficient evidence to assess the effectiveness of the ladder. There is a need for controlled trials to assess the importance of the WHO analgesic ladder as an intervention for control of cancer pain.

Most of the studies identified by Allard et al. (2001) were pre-post designs. There were only six RCTs and three QED studies. Only four of these studies enrolled more than 100 patients. ^122^ Future studies should include randomized allocation to experimental or control groups with sufficient power to detect important changes. Multtfaceted interventions that target clinicians as well as patients and their caregivers should be tested. Meaningful outcomes should be included, such as actual clinician behavior change (e.g., use of standardized pain assessments, and prescribing rates) and patient outcomes such as pain frequency and intensity, rather than relying on changes in knowledge and attitudes only.