# Appendix H: Acronyms and Abbreviations

A$ | Australian Dollars
ACOCC | Advisory Commission on Cancer Control
ACS | American Cancer Society
AHRQ | Agency for Healthcare Research and Quality
approx. | approximately
AzTEPP | Arizona Department of Health Service Tobacco Education and Prevention Program
BMI | Body Mass Index
BSE | Breast Self Exam
CBE | Clinical Breast Exam
CDC | Center for Disease Control and Prevention
CEB | Clinical Epidemiology and Biostatistics
chisq | Chi-Square Test
chisq _M-H_ | Mantel-Haenszel Chi-Square Test
CI | Confidence interval
CIS | Cancer Information Service
CME | Continuing Medical Education
CONSORT | Consolidated Standards of Reporting Trials
CPM | Clinical Preventive Medicine
CQI | Continuous Quality Improvement
CT | Controlled Trial
CVD | Cardiovascular Disease
d | Effect Size Value - (d) is the average amount of change in standard deviation units achieved by individuals in a treated group versus the change achieved by members of a control/comparison group for a particular study
df | Degrees of Freedom
e.g., | example
ERV | Education Representative Volunteers
ETS | Environmental Tobacco Smoke
GPs | General Practitioners
HP | Health Professional
LDL | Low Density Lipoprotein
MOOSE | Meta-Analysis of Observation Studies of Epidemiology
MU-EPC | McMaster University Evidence-based Practice Center
n | number included in study
NAACCR | North American Association of Central Cancer Registries
NCI | National Cancer Institute
NCIC | National Cancer Institute of Canada
NHS | National Health Services
NIH | National Institutes of Health
NNI | Number Needed to Intervene
NRT | Nicotine Replacement Therapy
OR | Odds Ratio
p | p value
PA | Physical Activity
Pap | Papanicolaou
PHS | Public Health Services
PSAs | Public Service Announcements
R | Correlation Coefficient
RA | Research Assistant
RCT | Randomized Controlled Trial
RefMan | Reference Manager Version 9®
RR | Relative Risk
SCCR | Supportive Cancer Care Research
SD | Standard Deviation
TFCPS | Task Force on Community Preventive Services
TOO | Task Order Officer
TPC | tailored print communication
TRD | Typical Risk Difference
TRIP | Translating Research Into Practice
UK | United Kingdom
US | United States
USPSTF | United States Preventive Services Task Force
WHO | World Health Organization
vs. | versus
x^2^ | chi-square