# Appendix G

Studies meeting the inclusion criteria for the review of systematic reviews that did not have relevant extractable data

Primary Author (Year) | Topic | Purpose & objective(s) of systematic review
Anderson,LA ^37^ 1998 | Implementing preventive services | “To determine the extent of change that can be expected from office-based interventions and the need to assess these effects across different types of preventive outcomes.…to determine their impact on three domains of preventive care: screening, immunization, and counselling.”
Chelf, J ^120^ (2001) | Cancer-related patient education | “To provide an overview of cancer-related patient-education research to determine future research needs.”
Davis, D ^38^ (1992) | Professional practice improvements and patient outcomes | “To assess the impact of diverse continuing medical education (CME) interventions on physician performance and health care outcomes.”
Davis, D ^39^ (1995) | Professional practice and health care outcomes | “To review the literature relating to the effectiveness of education strategies designed to change physician performance and health care outcomes”
Dunn, C ^83^ (2001) | Health behavior interventions and outcomes | “To examine the effectiveness of brief behavioral interventions adapting the principles and techniques of Motivational Interviewing to four behavioral domains: substance abuse, smoking, HIV risk and diet/exercise.”
Ebrahim, S ^40^ (1997) | Multiple risk factor intervention and coronary heart disease | “To assess the effectiveness of multiple risk factor intervention in reducing cardiovascular risk factors, total mortality, and mortality from coronary heart disease among adults.”
France, E ^41^ (2001) | Smoking cessation | “To review the literature on inpatient hospital-based smoking cessation interventions.”
Freemantle, N ^42^ (2001) | Professional practice improvements and patient outcomes | “To assess the effects of printed educational materials in improving the behavior of health care professionals and patient outcomes.”
Grilli, R ^43^ (2001) | Mass media interventions and health service utilization outcomes | “To assess the effects of mass media on the utilization of health services.”
Glanz, K ^82^ (1994) | Clinical interventions and community-based interventions using combinations of educational and environmental strategies | “To review and summarize evidence regarding the association of dietary factors, including alcohol intake, with breast cancer risk and survival, and review investigations of strategies for dietary behavior change for breast cancer prevention.”
Rimer, B ^53^ (1999) | Tailored print communications (TPCs) | “Examines the nature of TPCs, assesses the use and potential of TPCs for the purpose of cancer risk communication (CRC), and highlights new directions in CRC.”
Simons-Morton, D ^84^ (1992) | Health behavior interventions and outcomes | “To determine the characteristics of controlled studies (quasi-experimental and randomized) of clinical patient education/counselling for behavior change to prevent disease.”
Skinner, C ^54^ (1999) | Tailored print communications (TPC) | “Reviews the ‘first generation’ of tailored print communications studies in the published literature, describing the purpose, theoretical framework, sample, research design, message type and source, outcomes measured, and findings of each.”
Thompson O'Brien, M ^121^ (2000) | Professional practice improvements and patient outcomes; includes cancer pain | “To assess the effects of using local opinion leaders on the practice of health professionals or patient outcomes.”
Thompson O'Brien, M ^56^ (2001) | Professional practice improvements and patient outcomes | “To assess the effects of educational meetings on professional practice and health care outcomes.”
Thompson O'Brien, M ^116^ (2001) | Professional practice improvements | “To assess the effects of audit and feedback compared with other interventions in changing health professional practice and to assess whether the effectiveness of audit and feedback can be improved by modifying how it is done.”
Thompson O'Brien, M ^55^ (2001) | Professional practice improvements and patient outcomes | “To assess the effects of outreach visits on improving health professional practice and patient outcomes.”
Thompson O'Brien, M ^117^ (2002) | Professional practice improvements and patient outcomes | “To assess the effects of audit and feedback on the practice of health professionals and patient outcomes.”
Viswesvaran, C ^171^ (1992) | Smoking cessation | “To cumulate the results from 633 studies of smoking cessation, involving 71,806 subjects, that reported the proportion of successful quits.”
Hulscher, M ^44^ (2001) | Professional practice improvements for delivery of preventive services | “To assess the effects of interventions to improve the delivery of preventive services in primary care.”
Ketola, E ^45^ (2000) | Lifestyle interventions and health care outcomes | “To assess the effectiveness of lifestyle interventions in reducing cardiovascular disease risk factors, morbidity, and mortality among working-age adults.”
Krummel, D ^46^ (2001) | Cardiovascular health interventions in women - includes smoking and diet interventions | “To review the literature focused on improving women's cardiovascular health through behavior change for tobacco use, physical inactivity, or diet.”
Law, M ^47^ (1995) | Smoking cessation | “To review the efficacy of a variety of interventions intended to help people stop smoking.”
McDonnell, A ^48^ (1997) | Smoking cessation | “To review current literature to identify a range of research-based activities which practice nurses might employ in the primary and secondary prevention of CVD and stroke.”
Meissner, H ^109^ (1998) | Breast and cervical cancer screening interventions | “To evaluate published reports of breast and cervical cancer screening interventions, and to propose a framework of critical elements for authors and researchers to use when contributing to this literature.”
Munafo, M ^49^ (2001) | Smoking cessation | “To determine if providing smoking cessation services during hospitalization helps more people to attempt and sustain an attempt to quit smoking.”
Oxman, A ^50^ (1995) | Professional practice improvements and health care outcomes | “To determine the effectiveness of different types of interventions in improving health professional performance and health outcomes.”
Revere, D ^51^ (2001) | Health behavior interventions and outcomes | “To evaluate the evidence of effectiveness of computer-generated outpatient health behavior interventions - clinical encounters “in absentia” - as extensions of face-to-face patient care in an ambulatory setting.”
Rigotti, N ^52^ (2001) | Smoking cessation | “To determine the effectiveness of interventions for smoking cessation in hospitalized patients.”
Rimer, B ^15^ (1994) | Mammography use | “To provide an overview of trends in mammography use and review the effectiveness of interventions for increasing use of mammography.”