# Appendix F: Peer Reviewers

We gratefully acknowledge the participation of the following individuals in providing comments on the initial draft of this document. Acknowledgements are made with the explicit statement that this does not constitute endorsement of the report.

[underlined: Criticism Editor:]

Huston, Patricia - McMaster EPC consultant, Ottawa, ON, Canada

[underlined: Peer Reviewers:]

Ammerman, Alice - UNC Lineberger Comprehensive Cancer Center, University of North Carolina at Chapel Hill, NC

Anderson, Lois – Oncology Nursing Society – consumer advocate, York, PA

Black, Bruce – Cancer Control Planning, American Cancer Society, Atlanta, GA

Breslau, Erica S. – Applied Cancer Screening Research Branch, Division of Cancer Control and Population Sciences, National Cancer Institute, Bethesda, MD

Buhle, E. Loren - Oncology Nursing Society, Media, PA

Curry, Susan - University of Illinois at Chicago, Chicago, IL

Fox, Brion - University of Wisconsin Comprehensive Cancer Center, Madison, WI

Freemantle, Nick - Clinical Epidemiology & Biostatistics, University of Birmingham, United Kingdom

Glanz, Karen - Cancer Research Center of Hawaii, University of Hawaii, HI

Goldstein, Michael - Society of Behavioral Medicine, West Haven, CT

Grilli, Roberto - Regional Health Care Agency of Emilia-Romagna, Bologna (Italy)

Grimshaw, Jeremy - Cochrane Effective Practice and Organisation of Care Group; Centre for Best Practice, University of Ottawa, Ottawa, ON, Canada

Krebs, Linda - University of Colorado, School of Nursing, Lakewood, CO

Mahon, Suzanne - Oncology Nursing Society, Sunset Hills, MO

Mercer, Shawna - Public Health Practice Program Office, Center for Disease Control, Atlanta, GA

Myers, Brad - Community Guide Branch, Division of Prevention Research and Analytic Methods, Centers for Disease Control, Atlanta, GA

Somerfield, Mark - Health Services Research, American Society of Clinical Oncology, Alexandria, VA

Stead, Lindsay - Cochrane Review Group on Tobacco, Department of Public Health and Primary Health Care, Oxford, United Kingdom

Stoddard, Jackie - National Cancer Institute, Tobacco Control Research Branch, Rockville, MD

Sullivan, Terry - Division of Preventive Oncology, Cancer Care Ontario, Toronto, ON, Canada

Teschendorf, Bonnie - QOL Science Cancer Control, American Cancer Society, Atlanta, GA

Thornton, Hazel - Department of Epidemiology and Public Health, University of Leicester, United Kingdom

Wathen, Nadine - Canadian Task Force on Preventive Health Care, London, ON, Canada

Weyhenmeyer, Diana - Nurse oncologist, Springfield, IL

## Structured Format for Referee Comments

(Please refer to page and paragraph number when making very specific comments.)

Question Formulation

Are evidence report questions well formulated and easily understandable?

Study Identification

Is there a thorough search for relevant data using appropriate resources?

Are there unbiased, explicit searching strategies that are appropriately matched to the question?

Study Selection

Are appropriate inclusion and exclusion criteria used to select articles?

Are selection criteria applied in a manner that limits bias?

Are efforts made to identify unpublished data, if this is appropriate?

Are reasons for excluding studies from the report stated?

Appraisal of Studies

Is the validity of individual studies addressed in a reliable manner?

Are important parameters (e.g. setting, study population, study design) that could affect study results systematically addressed?

Data Collection

Is there a minimal amount of missing information regarding outcomes and other variables considered key to the interpretation of results?

Are efforts made to reduce bias in the data collection process?

Data Synthesis

Are important parameters, such as study designs, considered in the synthesis?

Are reasonable decisions made concerning whether and how to combine the data?

Are results sensitive to changes in the way the analysis was done?

Is precision of results reported?

Research

Are limitations and inconsistencies of studies stated?

Are limitations of the review process stated?

Are implications for research discussed?

Conclusions (stated throughout the report)

Are conclusions supported by the data reviewed?

Is evidence appropriately interpreted as inconclusive (no evidence of effect) or as showing a particular strategy did not work (evidence of no effect)?

Is a summary of pertinent findings provided?

Format

Does the Executive Summary adequately summarize the report?

Is the evidence report presented in a clear readable manner? If not, your suggestions are:

Other

What are the major strengths of this report?

What are the major limitations of this report?