# Appendix D: Guidelines for citation retrieval

## REVIEW OF SYSTEMATIC REVIEWS OF CANCER CONTROL INTERVENTIONS

General exclusion criteria:

- not published in English
- published before 1990
- exclusively focused on children or adolescents

Topic specific exclusion criteria:

1. Smoking cessation
  - exclusively focused on prenatal smoking cessation, environmental tobacco smoke, or primary tobacco use
  - exclusively focused on evaluating treatment/therapy interventions (for example: nicotine replacement, hypnosis, aversion therapy, acupuncture)
2. Healthy Diet
  - exclusively focused on vitamin or mineral supplements, prenatal/antenatal diets, weight-reduction diets, diabetic diets, or diets for secondary prevention of heart disease.
3. Mammography
  - exclusively focused on increasing follow-up compliance after an abnormal mammography finding
  - exclusively focused on increasing use of breast self-examination or clinical breast examination
4. Cervical cancer screening
  - exclusively focused on increasing follow-up compliance after an abnormal PAP test result
5. Control of Cancer Pain
  - exclusively focused on control of non-cancer related pain

Inclusion criteria:

- the article refers to itself as a systematic review or meta-analysis (or calls itself a review AND makes reference to databases searched or makes references to number of studies included) in one or more of the specific topic areas or a systematic review or meta-analysis in a more general area of prevention, screening, or supportive care that includes one or more of the topic areas covered by this evidence report
  AND
- assesses the effectiveness and/or efficacy of interventions that promote uptake of cancer control behaviors^*^ (for example: physician advice; counseling (telephone, emergency room, nurse); media campaigns; peer leaders). [underlined: Note]: for the purpose of title and abstract screening, we will retrieve all systematic reviews of policy-level, workplace, self-help, and incentive-based interventions
  * The term “behaviors” is being used in a broad context and encompasses a spectrum of outcomes from change in knowledge and attitudes to influencing practices and behaviors.

### Background Articles

We will retrieve any article for background that meets the following criteria:

1. Any review on diffusion theory or dissemination research, which would potentially be useful for the introductory narrative review.
2. Any systematic review of factors or determinants associated with the uptake of any of the prevention, early detection, or supportive care interventions or behaviors covered by this evidence report.
3. Guideline policies for each of the general areas of prevention, screening, or supportive care that includes one or more of the specific topic areas to be covered by this evidence report

## REVIEW OF PRIMARY STUDIES OF DISSEMINATION STRATEGIES

General exclusion criteria:

- not published in English
- published before 1980
- narrative review, editorial, letter or opinion paper

Topic specific exclusion criteria:

1. Adult smoking cessation
  - exclusively focused on children or adolescents, prenatal smoking cessation, environmental tobacco smoke, preventing initiation of primary tobacco use or tobacco sales to minors
2. Adult healthy diet
  - exclusively focused on children or adolescents, vitamin supplements, prenatal/antenatal diets
3. Mammography
  - exclusively focused on increasing follow-up compliance after an abnormal mammography finding
  - exclusively focused on increasing use of breast self-examination or clinical breast examination
4. Cervical cancer screening
  - exclusively focused on increasing follow-up compliance after an abnormal PAP test result
5. Control of Cancer Pain
  - exclusively focused on control of non-cancer related pain

Inclusion criteria:

- is a primary study (or a systematic review) involving one or more of the above specified topic areas that evaluates the diffusion or dissemination of a cancer control intervention(s).

### Background articles

We will retrieve any article for background that meets the following criteria:

1. Any article on diffusion theory or dissemination research, which would potentially be useful for the introductory narrative review
2. Any systematic review of factors or determinants associated with the uptake of any of the prevention, early detection, or supportive care interventions or behaviors covered by this evidence report
3. Any systematic review of barriers to adoption or uptake of cancer control interventions
4. Any article about non-cancer related dissemination strategies