# Appendix C: Search Strategies

Field definitions and abbreviations in electronic databases
PsychINFO and Sociological Abstracts
DE | Descriptors
SU | Subject
TI | Title
LA | Language
PY | Publication year
NLM Databases, Embase, Cinahl
.tw. | Textword
.ti. | Title
.pt. | Publication type
.sh. | Subject heading
yr | Year
Adj5 | Adjunct within 5 words
exp | Explode
Truncation Terms
Medline | :
PsychINFO, Sociological Abstracts | *

## Efficacy and/or Effectiveness of Cancer Control Interventions To Promote Uptake

### Adult Smoking Cessation

Search Strategy Using NLM Databases ^a^ (Search Performed on November 12 ^ th ^ , 2001)

a 5 Medline (1966-2002), PreMedline, Cochrane Database of Systematic Reviews, CancerLIT.

1. smoking cessation/
2. ((smoking or smoke) adj5 (quit: or stop: or cessation or cease)).tw.
3. (giv: adj5 smoking).tw.
4. “tobacco use disorder”/
5. smoking/
6. or/1–5
7. meta-analysis.sh,pt. or meta-analy:.tw. or metaanaly:.tw.
8. ((systematic: or quantitativ:) adj (review: or overview:)).tw.
9. (cochrane or medline or cinahl or embase or scisearch or psychinfo or psycinfo or psychlit or psyclit or (national and library)).tw.
10. ((handsearch: or search:) and (cochrane or medline or cinahl or embase or scisearch or psychinfo or psycinfo or psychlit or psyclit or (national and library) or (hand: or manual: or electronic: or bibligraph: or database:))).tw.
11. ((review or guideline).pt. or consensus.ti. or guideline:.ti. or literature.ti. or overview.ti. or review.ti.) and (9 or 10)
12. ((synthesis or overview or review or survey) and (systematic or critical or methodologic or quantitative or qualitative or literature or evidence or evidence-based)).ti.
13. 7 or 8 or 10 or 11 or 12
14. 13 not ((case: or report:).ti. or editorial.pt. or comment.pt. or letter.pt.)
15. 6 and 14
16. human.sh. not (animal.sh. and human.sh.)
17. 15 and 16
18. limit 17 to yr=1990-2002
19. limit 18 to English language

Search Strategy Using PsychINFO Database (Search Performed on November 12 ^ th ^ , 2001)

Limits set for: English Language, Publication Year 1990-2001; Adulthood; Aged; Middle-Age; Thirties; Very-Old; Young-Adulthood.

1. (Tobacco smoking) in DE,SU
2. Smoking cessation
3. Nicotine in DE,SU
4. (smoking or smoke) near (quit or stop or cessation or cease or give)
5. ‘Nicotine-Withdrawal’ in DE
6. 1 or 2 or 3 or 4 or 5
7. (meta-analysis) in DE,SU
8. meta-analy* or metaanaly* or meta analy*
9. (systematic* or quantitativ*) adj (review* or overview*)
10. (review* or overview*) adj (systematic* or quantitative*)
11. cochrane or medline or cinahl or embase or scisearch or psychinfo or psycinfo or psychlit or psyclit or (national and library)
12. hand* or manual* or electronic* or bibliograph* or database*
13. 11 or 12
14. handsearch* or search*
15. 13 and 14
16. (literature review ) in DE,SU
17. (consensus or guideline or literature or overview or review) in TI
18. 11 or 15
19. 17 and 18
20. (synthesis or overview or review or survey) in TI
21. (systematic or critical or methodologic or quantitative or qualitative or literature or evidence or evidence-based) in TI
22. 20 and 21
23. 7 or 8 or 9 or 10 or 15 or 19 or 22
24. 6 and 23

Search Strategy Using Sociological Abstracts Database (Search Performed on November 12 ^ th ^ , 2001)

Limits set for: English Language and Publication Year 1990-2001.

1. (smoking in de)
2. ((addiction in de) or (abstinence in de)) and smoking
3. ((smoking or smoke) near (quit or stop or cessation or cease or give))
4. 1 or 2 or 3
5. (meta-analy* or metaanaly* or meta analy*)
6. ((systematic* or quantitativ*) adj (review* or overview*))
7. ((review* or overview*) adj (systematic* or quantitative*))
8. (cochrane or medline or cinahl or embase or scisearch or psychinfo or psycinfo or psychlit or psyclit or (national and library))
9. (hand* or manual* or electronic* or bibliograph* or database*)
10. 8 or 9
11. (handsearch* or search*)
12. 10 and 11
13. ((literature reviews ) in DE)
14. (consensus or guideline or literature or overview or review)
15. 8 or 12
16. 14 and 15
17. ((synthesis or overview or review or survey) in TI)
18. ((systematic or critical or methodologic or quantitative or qualitative or literature or evidence or evidence-based) in TI)
19. 17 and 18
20. 5 or 6 or 7 or 12 or 16 or 19
21. 4 and 20

Search Strategy Using Embase Database (Search Performed on February 12 ^ th ^ , 2002)

1. smoking cessation/
2. cigarette smoking/
3. ((smoking or smoke:) adj5 (quit: or stop: or cessation or cease: or giv:)).tw.
4. smoking/
5. smoking habit/
6. or/1–5
7. meta-analysis.sh. or meta-analy:.tw. or metaanaly:.tw.
8. ((systematic: or quantitativ:) adj (review: or overview:)).tw.
9. (cochrane or medline or cinahl or embase or scisearch or psychinfo or psycinfo or psychlit or psyclit or (national and library)).tw.
10. ((handsearch: or search:) and (cochrane or medline or cinahl or embase or scisearch or psychinfo or psycinfo or psychlit or psyclit or (national and library) or (hand: or manual: or electronic: or bibliograph: or database:))).tw.
11. ((review or guideline).pt. or consensus.ti. or guideline:.ti. or literature.ti. or overview.ti. or review.ti.) and (9 or 10)
12. ((synthesis or overview or review or survey) and (systematic or critical or methodologic or quantitative or qualitative or literature or evidence or evidence-based)).ti.
13. 7 or 8 or 10 or 11 or 12
14. 13 not ((case: or report:).ti. or editorial.pt. or letter.pt. or proceeding.pt.)
15. 6 and 14
16. human.sh. not (animal.sh. and human.sh.)
17. 15 and 16
18. exp child or exp infant or embryo/ or fetus/ or exp newborn or exp childhood or newborn period/ or perinatal period/
19. 17 not 18
20. limit 19 to yr=1990-2002
21. limit 20 to English language

Search Strategy Using Cinahl Database (Search Performed on March 4 ^ th ^ , 2002)

1. Smoking Cessation/
2. SMOKING/ or “SMOKING CESSATION ASSISTANCE (IOWA NIC)”/ or SMOKING CESSATION PROGRAMS/
3. ((smoking or smoke:) adj5 (quit: or stop: or cessation or cease: or giv:)).tw.
4. or/1–3
5. meta-analysis.sh. or meta-analy:.tw. or metaanaly:.tw. or systematic review.pt.
6. ((systematic: or quantitativ:) adj (review: or overview:)).tw.
7. (cochrane or medline or cinahl or embase or scisearch or psychinfo or psycinfo or psychlit or psyclit or (national and library)).tw.
8. ((handsearch: or search:) and (cochrane or medline or cinahl or embase or scisearch or psychinfo or psycinfo or psychlit or psyclit or (national and library) or (hand: or manual: or electronic: or bibliograph: or database:))).tw.
9. ((review or guideline).pt. or consensus.ti. or guideline:.ti. or literature.ti. or overview.ti. or review.ti.) and (7 or 8)
10. ((synthesis or overview or review or survey) and (systematic or critical or methodologic or quantitative or qualitative or literature or evidence or evidence-based)).ti.
11. 5 or 6 or 8 or 9 or 10
12. 11 not ((case: or report:).ti. or editorial.pt. or comment.pt. or letter.pt or proceedings.pt.)
13. 4 and 12
14. limit 13 to yr=1990-2002
15. limit 14 to English language

### Adult Healthy Diet

Search Strategy Using NLM Databases ^a^ (Search Performed on December 17 ^ th ^ , 2001)

1. exp diet/
2. exp food/ or exp candy/ or exp cereals/ or exp condiments/ or exp dairy products/ or exp milk/ or dietary fats/ or exp dietary fats, unsaturated/ or dietary fiber/ or dietary supplements/ or exp eggs/ or flour/ or exp food additives/ or exp sweetening agents/ or exp foods, specialized/ or exp fruit/ or honey/ or exp meat/ or exp poultry/ or exp seafood/ or exp molasses/ or exp nuts/ or exp vegetables/ or exp allium/ or exp legumes/
3. exp nutrition/
4. or/1–3
5. meta-analysis.sh,pt. or meta-analy:.tw. or metaanaly:.tw.
6. ((systematic: or quantitativ:) adj (review: or overview:)).tw.
7. (cochrane or medline or cinahl or embase or scisearch or psychinfo or psycinfo or psychlit or psyclit or (national and library)).tw.
8. ((handsearch: or search:) and (cochrane or medline or cinahl or embase or scisearch or psychinfo or psycinfo or psychlit or psyclit or (national and library) or (hand: or manual: or electronic: or bibliograph: or database:))).tw.
9. ((review or guideline).pt. or consensus.ti. or guideline:.ti. or literature.ti. or overview.ti. or review.ti.) and (7 or 8)
10. ((synthesis or overview or review or survey) and (systematic or critical or methodologic or quantitative or qualitative or literature or evidence or evidence-based)).ti.
11. 5 or 6 or 8 or 9 or 10
12. 11 not ((case: or report:).ti. or editorial.pt. or comment.pt. or letter.pt.)
13. animal.sh.
14. human.sh.
15. 14 not (13 and 14)
16. diet:.tw.
17. (fruit or vegetabl: or saturated fat: or unsaturated fat: or fiber or fibre or supplements or supplementation or food).tw.
18. 4 or 17
19. 12 and 15 and 18
20. limit 19 to english language [Limit not valid in: Cochrane Database; records were retained]
21. pc.fs.
22. primary prevention/
23. health promotion/
24. (primary prevention or prevent: or promote).tw.
25. exp neoplasms/ or cancer.tw.
26. or/21–25
27. 20 and 26
28. limit 27 to yr=1990-2002
29. remove duplicates from 28

Search Strategy Using PsychINFO Database (Search Performed on December 17 ^ th ^ , 2001)

Limits set for: English Language, Publication Year 1990-2001; Adulthood; Aged; Middle-Age; Thirties; Very-Old; Young-Adulthood.

1. ‘Dietary-Supplements’ in DE
2. explode ‘Nutritional-Deficiencies’ in DE
3. ‘Vitamin-Therapy’ in DE
4. ‘Food-’ in DE
5. ‘Food-Preferences’ in DE
6. ‘Nutrition-’ in DE
7. (fruit or vegetabl* or saturated fat* or unsaturated fat* or fiber or fibre or supplements or supplementation or food) search in “words anywhere”
8. 1 or 2 or 3 or 4 or 5 or 6 or 7
9. ‘Preventive-Medicine’ in DE
10. prevention in DE,SU
11. ‘Health-Promotion’ in DE
12. ‘Lifestyle-Changes’ in DE
13. 11 or 12
14. explode ‘Neoplasms-’ in DE
15. cancer in ‘words anywhere’
16. 14 or 15
17. 13 and 16
18. 8 or 17
19. (meta-analysis) in DE,SU
20. meta-analy* or metaanaly* or meta analy*
21. (systematic* or quantitativ*) adj (review* or overview*)
22. (review* or overview*) adj (systematic* or quantitative*)
23. cochrane or medline or cinahl or embase or scisearch or psychinfo or psycinfo or psychlit or Psyclit or (national and library)
24. hand* or manual* or electronic* or bibliograph* or database*
25. 23 or 24
26. handsearch* or search*
27. 25 and 26
28. (literature review ) in DE,SU
29. (consensus or guideline or literature or overview or review) in TI
30. 23 or 27
31. 29 and 30
32. (synthesis or overview or review or survey) in TI
33. (systematic or critical or methodologic or quantitative or qualitative or literature or evidence or Evidence-based) in TI
34. 32 and 33
35. 19 or 20 or 21 or 22 or 27 or 31 or 34
36. 18 and 35

Search Strategy Using Sociological Abstracts Database (Search Performed on January 11 ^ th ^ , 2002)

Limits set for: English Language, and Publication Year 1990-2001.

1. explode ‘Nutrition-’ in DE
2. ‘Feeding-Practices’ in DE or ‘Food-’ in DE or ‘Diet-’ in DE
3. (fruit or vegetabl* or saturated fat* or unsaturated fat* or fiber or fibre or supplements or supplementation or food)
4. 1 or 2 or 3
5. (meta-analy* or metaanaly* or meta analy*)
6. ((systematic* or quantitativ*) adj (review* or overview*))
7. ((review* or overview*) adj (systematic* or quantitative*))
8. (cochrane or medline or cinahl or embase or scisearch or psychinfo or psycinfo or psychlit or psyclit or (national and library))
9. (hand* or manual* or electronic* or bibliograph* or database*)
10. 8 or 9
11. (handsearch* or search*)
12. 10 and 11
13. ((literature reviews ) in DE)
14. (consensus or guideline or literature or overview or review)
15. 8 or 12
16. 14 and 15
17. ((synthesis or overview or review or survey) in TI)
18. ((systematic or critical or methodologic or quantitative or qualitative or literature or evidence or evidence-based) in TI)
19. 17 and 18
20. 5 or 6 or 7 or 12 or 16 or 19
21. 4 and 20

Search Strategy Using Embase Database (Search Performed on February 21 ^ st ^ , 2002)

1. nutrition/
2. exp food/ or exp beverage/ or exp bran/ or exp cereal/ or exp dairy product/ or exp edible oil/ or exp egg/ or exp fruit/ or exp vegetable/
3. diet:.tw.
4. (fruit or vegetabl: or saturated fat: or unsaturated fat: or fiber or fibre or supplements or supplementation or food).tw.
5. nutritional health/
6. or/1–5
7. meta-analysis.sh. or meta-analy:.tw. or metaanaly:.tw.
8. ((systematic: or quantitativ:) adj (review: or overview:)).tw.
9. (cochrane or medline or cinahl or embase or scisearch or psychinfo or psycinfo or psychlit or psyclit or (national and library)).tw.
10. ((handsearch: or search:) and (cochrane or medline or cinahl or embase or scisearch or psychinfo or psycinfo or psychlit or psyclit or (national and library) or (hand: or manual: or electronic: or bibliograph: or database:))).tw.
11. ((review or guideline).pt. or consensus.ti. or guideline:.ti. or literature.ti. or overview.ti. or review.ti.) and (9 or 10)
12. ((synthesis or overview or review or survey) and (systematic or critical or methodologic or quantitative or qualitative or literature or evidence or evidence-based)).ti.
13. 7 or 8 or 10 or 11 or 12
14. 13 not ((case: or report:).ti. or editorial.pt. or letter.pt. or proceeding.pt.)
15. 6 and 14
16. human.sh. not (animal.sh. and human.sh.)
17. 15 and 16
18. exp child or exp infant or embryo/ or fetus/ or exp newborn or exp childhood or newborn period/ or perinatal period/
19. 17 not 18
20. limit 19 to yr=1990-2002
21. limit 20 to English language

Search Strategy Using Cinahl Database (Search Performed on March 4 ^ th ^ , 2002)

1. (fruit or vegetabl: or saturated fat: or unsaturated fat: or fiber or fibre or supplements or supplementation or food or diet:).tw.
2. exp diet/ or nutrition.sh.
3. exp food/ or exp cereals/ or exp chewing gum/ or exp condiments/ or exp dairy products/ or exp dietary carbohydrates/ or exp dietary fats/ or exp fruit/ or exp meat/ or exp nutrients/ or exp seafood/ or exp vegetables/
4. or/1–3
5. meta-analysis.sh. or meta-analy:.tw. or metaanaly:.tw. or systematic review.pt.
6. ((systematic: or quantitativ:) adj (review: or overview:)).tw.
7. (cochrane or medline or cinahl or embase or scisearch or psychinfo or psycinfo or psychlit or psyclit or (national and library)).tw.
8. ((handsearch: or search:) and (cochrane or medline or cinahl or embase or scisearch or psychinfo or psycinfo or psychlit or psyclit or (national and library) or (hand: or manual: or electronic: or bibliograph: or database:))).tw.
9. ((review or guideline).pt. or consensus.ti. or guideline:.ti. or literature.ti. or overview.ti. or review.ti.) and (7 or 8)
10. ((synthesis or overview or review or survey) and (systematic or critical or methodologic or quantitative or qualitative or literature or evidence or evidence-based)).ti.
11. 5 or 6 or 8 or 9 or 10
12. 11 not ((case: or report:).ti. or editorial.pt. or comment.pt. or letter.pt. or proceedings.pt.)
13. 4 and 12
14. limit 13 to yr=1990-2002
15. limit 14 to English language

### Mammography

Search Strategy Using NLM Databases ^a^ (Search Performed on January 7 ^ th ^ , 2002)

1. mammogra:.tw. or mammography/
2. (breast cancer adj5 screen:).tw.
3. mass screening/ and exp breast neoplasms/
4. meta-analysis.sh,pt. or meta-analy:.tw. or metaanaly:.tw.
5. ((systematic: or quantitativ:) adj (review: or overview:)).tw.
6. (cochrane or medline or cinahl or embase or scisearch or psychinfo or psycinfo or psychlit or psyclit or (national and library)).tw.
7. ((handsearch: or search:) and (cochrane or medline or cinahl or embase or scisearch or psychinfo or psycinfo or psychlit or psyclit or (national and library) or (hand: or manual: or electronic: or bibliograph: or database:))).tw.
8. ((review or guideline).pt. or consensus.ti. or guideline:.ti. or literature.ti. or overview.ti. or review.ti.) and (6 or 7)
9. ((synthesis or overview or review or survey) and (systematic or critical or methodologic or quantitative or qualitative or literature or evidence or evidence-based)).ti.
10. 4 or 5 or 7 or 8 or 9
11. 10 not ((case: or report:).ti. or editorial.pt. or comment.pt. or letter.pt.)
12. or/1–3
13. 11 and 12
14. (human not (animal and human)).sh.
15. 13 and 14
16. limit 15 to yr=1990-2002
17. limit 16 to english language [Limit not valid in: Cochrane Database; records were retained]
18. remove duplicates from 17

Search Strategy Using PsychINFO Database (Search Performed on January 9 ^ th ^ , 2002)

Limits set for: English Language, Publication Year 1990-2001; Adulthood; Aged; Middle-Age; Thirties; Very-Old; Young-Adulthood.

1. mammography in DE
2. ‘cancer screening’ in DE and breast
3. ‘health screening’ in DE and ‘breast neoplasms’ in DE
4. ‘breast cancer’ and screen*
5. mammogra*
6. 1 or 2 or 3 or 4 or 5
7. (meta-analysis) in DE,SU
8. meta-analy* or metaanaly* or meta analy*
9. (systematic* or quantitativ*) adj (review* or overview*)
10. (review* or overview*) adj (systematic* or quantitative*)
11. cochrane or medline or cinahl or embase or scisearch or psychinfo or psycinfo or psychlit or psyclit or (national and library)
12. hand* or manual* or electronic* or bibliograph* or database*
13. 11 or 12
14. handsearch* or search*
15. 13 and 14
16. (literature review ) in DE,SU
17. (consensus or guideline or literature or overview or review) in TI
18. 11 or 15
19. 17 and 18
20. (synthesis or overview or review or survey) in TI
21. (systematic or critical or methodologic or quantitative or qualitative or literature or evidence or evidence-based) in TI
22. 20 and 21
23. 7 or 8 or 9 or 10 or 15 or 19 or 22
24. 6 and 23

Search Strategy Using Sociological Abstracts Database (Search Performed on January 9 ^ th ^ , 2002)

Limits set for: English Language, and Publication Year 1990-2001.

1. ‘breast cancer’ and screen*
2. mammogra*
3. (tests in de) and (cancer in de) and breast
4. 1 or 2 or 3
5. (meta-analy* or metaanaly* or meta analy*)
6. ((systematic* or quantitativ*) adj (review* or overview*))
7. ((review* or overview*) adj (systematic* or quantitative*))
8. (cochrane or medline or cinahl or embase or scisearch or psychinfo or psycinfo or psychlit or psyclit or (national and library))
9. (hand* or manual* or electronic* or bibliograph* or database*)
10. 8 or 9
11. (handsearch* or search*) and (LA=ENGLISH) and (PY=1990-2001)
12. 10 and 11
13. ((literature reviews) in DE)
14. (consensus or guideline or literature or overview or review)
15. 8 or 12
16. 14 and 15
17. ((synthesis or overview or review or survey) in TI)
18. ((systematic or critical or methodologic or quantitative or qualitative or literature or evidence or evidence-based) in TI)
19. 17 and 18
20. 5 or 6 or 7 or 12 or 16 or 19
21. 4 and 20

Search Strategy Using Embase Database (Search Performed on February 21 ^ st ^ , 2002)

1. exp mammography
2. cancer screening/ and (exp breast or breast.tw.)
3. (exp breast cancer) and (screening/ or mass screening/ or screening test/)
4. (breast cancer adj5 screen:).tw.
5. mammogra:.tw.
6. or/1–5
7. meta-analysis.sh. or meta-analy:.tw. or metaanaly:.tw.
8. ((systematic: or quantitativ:) adj (review: or overview:)).tw.
9. (cochrane or medline or cinahl or embase or scisearch or psychinfo or psycinfo or psychlit or psyclit or (national and library)).tw.
10. ((handsearch: or search:) and (cochrane or medline or cinahl or embase or scisearch or psychinfo or psycinfo or psychlit or psyclit or (national and library) or (hand: or manual: or electronic: or bibliograph: or database:))).tw.
11. ((review or guideline).pt. or consensus.ti. or guideline:.ti. or literature.ti. or overview.ti. or review.ti.) and (9 or 10)
12. ((synthesis or overview or review or survey) and (systematic or critical or methodologic or quantitative or qualitative or literature or evidence or evidence-based)).ti.
13. 7 or 8 or 10 or 11 or 12
14. 13 not ((case: or report:).ti. or editorial.pt. or letter.pt. or proceeding.pt.)
15. 6 and 14
16. human.sh. not (animal.sh. and human.sh.)
17. 15 and 16
18. exp child or exp infant or embryo/ or fetus/ or exp newborn or exp childhood or newborn period/ or perinatal period/
19. 17 not 18
20. limit 19 to yr=1990-2002
21. limit 20 to English language

Search Strategy Using Cinahl Database (Search Performed on April 3 ^ rd ^ , 2002)

1. mammography/ or mammogra:.tw.
2. cancer screening/ and (breast.tw. or exp breast)
3. (breast cancer adj5 screen:).tw.
4. or/1–3
5. meta-analysis.sh. or meta-analy:.tw. or metaanaly:.tw. or systematic review.pt.
6. ((systematic: or quantitativ:) adj (review: or overview:)).tw.
7. (cochrane or medline or cinahl or embase or scisearch or psychinfo or psycinfo or psychlit or psyclit or (national and library)).tw.
8. ((handsearch: or search:) and (cochrane or medline or cinahl or embase or scisearch or psychinfo or psycinfo or psychlit or psyclit or (national and library) or (hand: or manual: or electronic: or bibliograph: or database:))).tw.
9. ((review or guideline).pt. or consensus.ti. or guideline:.ti. or literature.ti. or overview.ti. or review.ti.) and (7 or 8)
10. ((synthesis or overview or review or survey) and (systematic or critical or methodologic or quantitative or qualitative or literature or evidence or evidence-based)).ti.
11. 5 or 6 or 8 or 9 or 10
12. 11 not ((case: or report:).ti. or editorial.pt. or comment.pt. or letter.pt. or proceedings.pt.)
13. 4 and 12
14. limit 13 to yr=1990-2002
15. limit 14 to English language

### Cervical Cancer Screening

Search Strategy Using NLM Databases ^a^ (Search Performed on January 8 ^ th ^ , 2002)

1. cervix neoplasms/ and mass screening/
2. vaginal smears/
3. vagina: smear:.tw.
4. pap test:.tw.
5. (papanicolaou adj2 (smear: or test:)).tw.
6. (cervical adj2 (smear: or test:)).tw.
7. (cervical adj2 (smear: or screen:)).tw.
8. pap smear:.tw.
9. or/1–8
10. meta-analysis.sh,pt. or meta-analy:.tw. or metaanaly:.tw.
11. ((systematic: or quantitativ:) adj (review: or overview:)).tw.
12. (cochrane or medline or cinahl or embase or scisearch or psychinfo or psycinfo or psychlit or psyclit or (national and library)).tw.
13. ((handsearch: or search:) and (cochrane or medline or cinahl or embase or scisearch or psychinfo or psycinfo or psychlit or psyclit or (national and library) or (hand: or manual: or electronic: or bibliograph: or database:))).tw.
14. ((review or guideline).pt. or consensus.ti. or guideline:.ti. or literature.ti. or overview.ti. or review.ti.) and (12 or 13)
15. ((synthesis or overview or review or survey) and (systematic or critical or methodologic or quantitative or qualitative or literature or evidence or evidence-based)).ti.
16. 10 or 11 or 13 or 14 or 15
17. 16 not ((case: or report:).ti. or editorial.pt. or comment.pt. or letter.pt.)
18. 9 and 17
19. (human not (animal and human)).sh.
20. 18 and 19
21. limit 20 to (english language and year=1990-2002) [Limit not valid in: Cochrane Database,CancerLIT,Pre-MEDLINE,MEDLINE; records were retained]

Search Strategy Using PsychINFO Database (Search Performed on January 9 ^ th ^ , 2002)

Limits set for: English Language, Publication Year 1990-2001; Adulthood; Aged; Middle-Age; Thirties; Very-Old; Young-Adulthood.

1. (cervix in de) and ((health screening in de) or (cancer screening in de))
2. vagina* smear*
3. papanicolaou and (smear* or test*)
4. cervical and (smear* or test* or screen*).
5. pap smear* or pap test*
6. 1 or 2 or 3 or 4 or 5
7. (meta-analysis) in DE,SU
8. meta-analy* or metaanaly* or meta analy*
9. (systematic* or quantitativ*) adj (review* or overview*)
10. (review* or overview*) adj (systematic* or quantitative*)
11. cochrane or medline or cinahl or embase or scisearch or psychinfo or psycinfo or psychlit or psyclit or (national and library)
12. hand* or manual* or electronic* or bibliograph* or database*
13. 11 or 12
14. handsearch* or search*
15. 13 and 14
16. (literature review ) in DE,SU
17. (consensus or guideline or literature or overview or review) in TI
18. 11 or 15
19. 17 and 18
20. (synthesis or overview or review or survey) in TI
21. (systematic or critical or methodologic or quantitative or qualitative or literature or evidence or evidence-based) in TI
22. 20 and 21
23. 7 or 8 or 9 or 10 or 15 or 19 or 22
24. 6 and 23

Search Strategy Using Sociological Abstracts Database (Search Performed on January 9 ^ th ^ , 2002)

Limits set for: English Language, and Publication Year 1990-2001.

1. vagina* smear* or pap smear* or pap test*
2. ((cervical or papanicolaou) and (smear* or test* or screen*))
3. (tests in de) and (cancer in de) and (cervix or cervical)
4. 1 or 2 or 3
5. (meta-analy* or metaanaly* or meta analy*)
6. ((systematic* or quantitativ*) adj (review* or overview*))
7. ((review* or overview*) adj (systematic* or quantitative*))
8. (cochrane or medline or cinahl or embase or scisearch or psychinfo or psycinfo or psychlit or psyclit or (national and library))
9. (hand* or manual* or electronic* or bibliograph* or database*)
10. 8 or 9
11. (handsearch* or search*) and (LA=ENGLISH) and (PY=1990-2001)
12. 10 and 11
13. ((literature reviews) in DE)
14. (consensus or guideline or literature or overview or review)
15. 8 or 12
16. 14 and 15
17. ((synthesis or overview or review or survey) in TI)
18. ((systematic or critical or methodologic or quantitative or qualitative or literature or evidence or evidence-based) in TI)
19. 17 and 18
20. 5 or 6 or 7 or 12 or 16 or 19
21. 4 and 20

Search Strategy Using Embase Database (Search Performed on February 12 ^ th ^ , 2002)

1. Papanicolaou Test/ or Vagina Smear/ or vagina: smear:.tw. or pap test:.tw.
2. exp Uterine Cervix Cancer and (screening/ or screening test/ or mass screening/)
3. cancer screening and (exp uterine cervix or cervical.tw. or cervix.tw.)
4. (papanicolaou adj2 (smear: or test:)).tw.
5. (cervical adj2 (smear: or test:)).tw. or (cervical adj2 (smear: or screen:)).tw.
6. or/1–5
7. meta-analysis.sh. or meta-analy:.tw. or metaanaly:.tw.
8. ((systematic: or quantitativ:) adj (review: or overview:)).tw.
9. (cochrane or medline or cinahl or embase or scisearch or psychinfo or psycinfo or psychlit or psyclit or (national and library)).tw.
10. ((handsearch: or search:) and (cochrane or medline or cinahl or embase or scisearch or psychinfo or psycinfo or psychlit or psyclit or (national and library) or (hand: or manual: or electronic: or bibliograph: or database:))).tw.
11. ((review or guideline).pt. or consensus.ti. or guideline:.ti. or literature.ti. or overview.ti. or review.ti.) and (9 or 10)
12. ((synthesis or overview or review or survey) and (systematic or critical or methodologic or quantitative or qualitative or literature or evidence or evidence-based)).ti.
13. 7 or 8 or 10 or 11 or 12
14. 13 not ((case: or report:).ti. or editorial.pt. or letter.pt. or proceeding.pt.)
15. 6 and 14
16. human.sh. not (animal.sh. and human.sh.)
17. 15 and 16
18. exp child or exp infant or embryo/ or fetus/ or exp newborn or exp childhood or newborn period/ or perinatal period/
19. 17 not 18
20. limit 19 to yr=1990-2002
21. limit 20 to English language

Search Strategy Using Cinahl Database (Search Performed on April 3 ^ rd ^ , 2002)

1. Cervical Smears/
2. vagina: smear:.tw.
3. pap test:.tw.
4. (papanicolaou adj2 (smear: or test:)).tw.
5. (cervical adj2 (smear: or test:)).tw.
6. (cervical adj2 (smear: or screen:)).tw.
7. cancer screening/ and (cervix/ or cervix.tw. or cervical.tw.)
8. or/1–7
9. meta-analysis.sh. or meta-analy:.tw. or metaanaly:.tw. or systematic review.pt.
10. ((systematic: or quantitativ:) adj (review: or overview:)).tw.
11. (cochrane or medline or cinahl or embase or scisearch or psychinfo or psycinfo or psychlit or psyclit or (national and library)).tw.
12. ((handsearch: or search:) and (cochrane or medline or cinahl or embase or scisearch or psychinfo or psycinfo or psychlit or psyclit or (national and library) or (hand: or manual: or electronic: or bibliograph: or database:))).tw.
13. ((review or guideline).pt. or consensus.ti. or guideline:.ti. or literature.ti. or overview.ti. or review.ti.) and (11 or 12)
14. ((synthesis or overview or review or survey) and (systematic or critical or methodologic or quantitative or qualitative or literature or evidence or evidence-based)).ti.
15. 9 or 10 or 12 or 13 or 14
16. 15 not ((case: or report:).ti. or editorial.pt. or comment.pt. or letter.pt. or proceedings.pt.)
17. 8 and 16
18. limit 17 to yr=1990-2002
19. limit 18 to English language

### Control of Cancer Pain

Search Strategy Using NLM Databases ^a^ (Search Performed on February 5 ^ th ^ , 2002)

1. exp neoplasms/ or neoplasms.mp. or cancer.tw exp analgesia/ or analgesia.mp.
2. exp analgesia/ or analgesia.mp.
3. exp analgesics/ or analgesics.mp. or exp pain/ or pain.mp.
4. 2 or 3
5. 1 and 4
6. meta-analysis.sh,pt. or meta-analy:.tw. or metaanaly:.tw.
7. ((systematic: or quantitativ:) adj (review: or overview:)).tw.
8. (cochrane or medline or cinahl or embase or scisearch or psychinfo or psycinfo or psychlit or psyclit or (national and library)).tw.
9. ((handsearch: or search:) and (cochrane or medline or cinahl or embase or scisearch or psychinfo or psycinfo or psychlit or psyclit or (national and library) or (hand: or manual: or electronic: or bibliograph: or database:))).tw.
10. ((review or guideline).pt. or consensus.ti. or guideline:.ti. or literature.ti. or overview.ti. or review.ti.) and (8 or 9)
11. ((synthesis or overview or review or survey) and (systematic or critical or methodologic or quantitative or qualitative or literature or evidence or evidence-based)).ti.
12. 6 or 7 or 9 or 10 or 11
13. 12 not (case: report:.ti. or editorial.pt. or comment.pt. or letter.pt.)
14. 5 and 13
15. (human not (animal and human)).sh.
16. 14 and 15
17. limit 16 to yr=1990-2002
18. limit 17 to english language [Limit not valid in: Cochrane Database; records were retained]
19. remove duplicates from 18

Search Strategy Using PsychINFO Database (Search Performed on February 28 ^ th ^ , 2002)

Limits set for: English Language, Publication Year 1990-2001; Adulthood; Aged; Middle-Age; Thirties; Very-Old; Young-Adulthood.

1. (explode ‘Neoplasms-’ in DE) or cancer
2. (‘Analgesia-’ in DE) or analges*
3. explode ‘Analgesic-Drugs’ in DE
4. (‘pain management’ in de) or (explode pain in de) or pain
5. 2 or 3 or 4
6. 1 and 5
7. (meta-analysis) in DE,SU
8. meta-analy* or metaanaly* or meta analy*
9. (systematic* or quantitativ*) adj (review* or overview*)
10. (review* or overview*) adj (systematic* or quantitative*)
11. cochrane or medline or cinahl or embase or scisearch or psychinfo or psycinfo or psychlit or psyclit or (national and library)
12. hand* or manual* or electronic* or bibliograph* or database*
13. 11 or 12
14. handsearch* or search*
15. 13 and 14
16. (literature review ) in DE,SU
17. (consensus or guideline or literature or overview or review) in TI
18. 11 or 15
19. 17 and 18
20. (synthesis or overview or review or survey) in TI
21. (systematic or critical or methodologic or quantitative or qualitative or literature or evidence or evidence-based) in TI
22. 20 and 21
23. 7 or 8 or 9 or 10 or 15 or 19 or 22
24. 6 and 23

Search Strategy Using Sociological Abstracts Database (Search Performed on March 7 ^ th ^ , 2002)

Limits set for: English Language, and Publication Year 1990-2001.

1. (explode ‘cancer’ in de) or cancer
2. (pain in de) or pain
3. 1 and 2
4. (meta-analy* or metaanaly* or meta analy*)
5. ((systematic* or quantitativ*) adj (review* or overview*))
6. ((review* or overview*) adj (systematic* or quantitative*))
7. (cochrane or medline or cinahl or embase or scisearch or psychinfo or psycinfo or psychlit or psyclit or (national and library))
8. (hand* or manual* or electronic* or bibliograph* or database*)
9. 7 or 8
10. (handsearch* or search*)
11. 9 and 10
12. ((literature reviews ) in DE)
13. (consensus or guideline or literature or overview or review)
14. 7 or 11
15. 13 and 14
16. ((synthesis or overview or review or survey) in TI)
17. ((systematic or critical or methodologic or quantitative or qualitative or literature or evidence or evidence-based) in TI)
18. 16 and 17
19. 4 or 5 or 6 or 11or 15 or 18
20. 3 and 19

Search Strategy Using Embase Database (Search Performed on February 28 ^ th ^ , 2002)

1. exp neoplasm/
2. exp analgesia/ or analgesia.mp. or exp analgesic agent/ or analgesic:.mp.
3. exp pain/ or pain.mp.
4. cancer.mp. or neoplasm.mp.
5. or/2–4
6. 1 and 5
7. meta-analysis.sh. or meta-analy:.tw. or metaanaly:.tw.
8. ((systematic: or quantitativ:) adj (review: or overview:)).tw.
9. (cochrane or medline or cinahl or embase or scisearch or psychinfo or psycinfo or psychlit or psyclit or (national and library)).tw.
10. ((handsearch: or search:) and (cochrane or medline or cinahl or embase or scisearch or psychinfo or psycinfo or psychlit or psyclit or (national and library) or (hand: or manual: or electronic: or bibliograph: or database:))).tw.
11. ((review or guideline).pt. or consensus.ti. or guideline:.ti. or literature.ti. or overview.ti. or review.ti.) and (9 or 10)
12. ((synthesis or overview or review or survey) and (systematic or critical or methodologic or quantitative or qualitative or literature or evidence or evidence-based)).ti.
13. 7 or 8 or 10 or 11 or 12
14. not ((case: or report:).ti. or editorial.pt. or letter.pt. or proceeding.pt.)
15. 6 and 14
16. human.sh. not (animal.sh. and human.sh.)
17. and 16
18. exp child or exp infant or embryo/ or fetus/ or exp newborn or exp childhood or newborn period/ or perinatal period/
19. not 18
20. limit 19 to yr=1990-2002
21. limit 20 to English language

Search Strategy Using Cinahl Database (Search Performed on April 3 ^ rd ^ , 2002)

1. exp neoplams/ or cancer.tw. or neoplasm.mp.
2. exp analgesia or analges:.tw.
3. exp analgesics
4. exp pain/ or pain.tw
5. or/2–4
6. 1 and 5
7. cancer pain/
8. 6 or 7
9. meta-analysis.sh. or meta-analy:.tw. or metaanaly:.tw. or systematic review.pt.
10. ((systematic: or quantitativ:) adj (review: or overview:)).tw.
11. (cochrane or medline or cinahl or embase or scisearch or psychinfo or psycinfo or psychlit or psyclit or (national and library)).tw.
12. ((handsearch: or search:) and (cochrane or medline or cinahl or embase or scisearch or psychinfo or psycinfo or psychlit or psyclit or (national and library) or (hand: or manual: or electronic: or bibliograph: or database:))).tw.
13. ((review or guideline).pt. or consensus.ti. or guideline:.ti. or literature.ti. or overview.ti. or review.ti.) and (11 or 12)
14. ((synthesis or overview or review or survey) and (systematic or critical or methodologic or quantitative or qualitative or literature or evidence or evidence-based)).ti.
15. 9 or 10 or 12 or 13 or 14
16. 15 not ((case: or report:).ti. or editorial.pt. or comment.pt. or letter.pt. or proceedings.pt.)
17. 8 and 16
18. limit 17 to yr=1990-2002
19. limit 18 to English language

## Strategies for the Diffusion or Dissemination of Cancer Control Interventions

### Adult Smoking Cessation

Search Strategy Using NLM Databases ^b^ (Search Performed on November 16 ^ th ^ , 2001)

b Medline, PreMedline, HealthSTAR, CancerLIT

1. exp smoking cessation/
2. ((smoking or smoke) adj5 (quit: or stop: or cessation or cease)).tw.
3. (giv: adj5 smoking).tw.
4. “tobacco use disorder”/
5. smoking/
6. or/1–5
7. (disseminat: or implement: or adopt:).tw.
8. diffusion of innovation/
9. diffusion.tw.
10. or/7–9
11. 6 and 10
12. limit 11 to english language
13. limit 12 to human [Limit not valid in: Pre-MEDLINE; records were retained]
14. limit 13 to yr=1980-2002
15. drug screening/
16. work capacity evaluation/
17. postoperative complications/
18. blood donor/
19. tissue donor/
20. exp DNA/
21. amino acid sequence/
22. (drug adj2 screening).tw.
23. (work adj2 capacity).tw.
24. postoperative complication:.tw.
25. blood donor:.tw.
26. tissue donor:.tw.
27. DNA:.tw.
28. amino acid sequence:.tw.
29. or/15–28
30. 14 not 29
31. (addresses or analytic or bibliography or biography or classical article or comment or consensus development conference or consensus development conference nih or current biog obit or dictionary or directory or duplicate publication or editorial or festschrift or historical article or interview or lectures or legal cases or letter or news or newspaper article or review of reported cases or review tutorial or meeting abstracts or meeting report or meeting paper).pt.
32. 30 not 31
33. remove duplicates from 32

Search Strategy Using Embase Database (Search Performed on November 19 ^ th ^ , 2001)

1. smoking cessation/
2. cigarette smoking/ or smoking/ or smoking habit/
3. ((smoking or smoke:) adj5 (quit: or stop: or cessation or cease: or giv:)).tw.
4. or/1–3
5. (disseminat: or implement: or adopt or diffusion).tw.
6. 4 and 5
7. limit 6 to (human and english language)
8. Drug Screening/
9. Work Capacity/
10. Postoperative Complication/
11. Blood Donor/
12. Donor/
13. exp dna/
14. Amino Acid Sequence/
15. (Drug adj2 screening).tw.
16. (work adj2 capacity).tw.
17. postoperative complication:.tw.
18. blood donor:.tw.
19. tissue donor:.tw.
20. dna.tw.
21. amino acid sequence:.tw.
22. or/8–21
23. 7 not 22
24. (editorial or letter or proceeding).pt.
25. 23 not 24

Search Strategy Using PsychINFO Database (Search Performed on November 22 ^ nd ^ , 2001)

Limits set for: English Language, Publication Year 1980-2001; Adulthood; Aged; Middle-Age; Thirties; Very-Old; Young-Adulthood.

1. (Tobacco smoking) in DE,SU
2. Smoking cessation
3. Nicotine in DE,SU
4. (smoking or smoke) near (quit* or stop* or cessation or cease or giv*)
5. ‘Nicotine-Withdrawal’ in DE
6. 1 or 2 or 3 or 4 or 5
7. disseminat* or implement* or adopt* or diffusion
8. 6 and 7

Search Strategy Using Sociological Abstracts Database (Search Performed on November 19 ^ th ^ , 2001)

Limits set for: English Language, and Publication Year 1980-2001.

1. (smoking in de)
2. (((addiction in de) or (abstinence in de)) and smoking
3. ((smoking or smoke) near (quit or stop or cessation or cease or give))
4. 1 or 2 or 3
5. ‘Diffusion-’ in DE
6. ‘Information-Dissemination’ in DE
7. (disseminat* or implement* or adopt* or diffusion)
8. 5 or 6 or 7
9. 4 and 8

Search Strategy Using Cinahl Database (Search Performed on November 19 ^ th ^ , 2001)

1. Smoking Cessation/
2. SMOKING/ or “SMOKING CESSATION ASSISTANCE (IOWA NIC)”/ or SMOKING CESSATION PROGRAMS/
3. ((smoking or smoke:) adj5 (quit: or stop: or cessation or cease: or giv:)).tw.
4. or/1–3
5. Diffusion of Innovation/
6. (disseminat: or implement: or adopt: or diffusion).tw.
7. 5 or 6
8. 4 and 7
9. Work Capacity Evaluation/
10. Postoperative Complications/
11. Blood Donor/
12. Transplant Donors/
13. exp dna/
14. Amino Acid Sequence/
15. (Drug adj2 screening).tw.
16. (work adj2 capacity).tw.
17. postoperative complication:.tw.
18. blood donor:.tw.
19. tissue donor:.tw.
20. dna.tw.
21. amino acid sequence:.tw.
22. or/9–21
23. 8 not 22
24. limit 23 to (english and (adult <19 to 44 years> or middle age <45 to 64 years> or aged <65 to 79 years> or “aged, 80 and over”))
25. (editorial or letter or proceedings).pt.
26. 24 not 25

### Adult Healthy Diet

Search Strategy Using NLM Databases ^b^ (Search Performed on January 17 ^ th ^ , 2002)

1. exp Diet/ or exp nutrition/
2. exp food/ or exp candy/ or exp cereals/ or exp condiments/ or exp dairy products/ or exp milk/ or exp dietary fats/ or exp dietary fats, unsaturated/ or dietary fiber/ or dietary supplements/ or exp eggs/ or flour/ or exp food additives/ or exp sweetening agents/ or exp foods, specialized/ or exp fruit/ or honey/ or exp meat/ or exp poultry/ or exp seafood/ or exp molasses/ or exp nuts/ or exp vegetables/ or exp allium/ or exp legumes/
3. (fruit or vegetabl: or saturated fat: or unsaturated fat: or fiber or fibre or supplements or supplementation or food or diet:).tw.
4. or/1–3
5. (disseminat: or implement: or adopt:).tw.
6. diffusion of innovation/
7. diffusion.tw.
8. or/5–7
9. 4 and 8
10. limit 9 to english language
11. limit 10 to human [Limit not valid in: Pre-MEDLINE; records were retained]
12. limit 11 to yr=1980-2002
13. drug screening/
14. work capacity evaluation/
15. postoperative complications/
16. blood donor/
17. tissue donor/
18. exp DNA/
19. amino acid sequence/
20. (drug adj2 screening).tw.
21. (work adj2 capacity).tw.
22. postoperative complication:.tw.
23. blood donor:.tw.
24. tissue donor:.tw.
25. DNA:.tw.
26. amino acid sequence:.tw.
27. or/13–26
28. 12 not 27
29. (addresses or analytic or bibliography or biography or classical article or comment or consensus development conference or consensus development conference nih or current biog obit or dictionary or directory or duplicate publication or editorial or festschrift or historical article or interview or lectures or legal cases or letter or news or newspaper article or review of reported cases or review tutorial or meeting abstracts or meeting report or meeting paper).pt.
30. 28 not 29
31. pc.fs.
32. Primary Prevention/
33. Health Promotion/
34. (primary prevention or prevent: or promote).tw.
35. exp neoplasms/ or cancer.tw.
36. or/31–35
37. 30 and 36

Search Strategy Using Embase Database (Search Performed on January 18 ^ th ^ , 2002)

1. nutrition/ or nutritional health/
2. exp food/ or exp beverage/ or exp bran/ or exp cereal/ or exp dairy product/ or exp edible oil/ or exp egg/ or exp fruit/ or exp vegetable/
3. diet:.tw.
4. (fruit or vegetabl: or saturated fat: or unsaturated fat: or fiber or fibre or supplements or supplementation or food).tw.
5. or/1–4
6. (disseminat: or implement: or adopt or diffusion).tw.
7. 5 and 6
8. limit 7 to (human and english language)
9. Drug Screening/
10. Work Capacity/
11. Postoperative Complication/
12. Blood Donor/
13. Donor/
14. exp dna/
15. Amino Acid Sequence/
16. (Drug adj2 screening).tw.
17. (work adj2 capacity).tw.
18. postoperative complication:.tw.
19. blood donor:.tw.
20. tissue donor:.tw.
21. dna.tw.
22. amino acid sequence:.tw.
23. or/9–22
24. 8 not 23
25. (editorial or letter or proceeding).pt.
26. 24 not 25
27. pc.fs.
28. Primary Prevention/
29. Health Promotion/
30. (primary prevention or prevent: or promote).tw.
31. exp neoplasm/ or cancer.tw.
32. or/27–31
33. 26 and 32

Search Strategy Using PsychINFO Database (Search Performed on February 11 ^ th ^ , 2002)

Limits set for: English Language, Publication Year 1980-2001; Adulthood; Aged; Middle-Age; Thirties; Very-Old; Young-Adulthood.

1. ‘Dietary-Supplements’ in DE
2. explode ‘Nutritional-Deficiencies’ in DE
3. ‘Vitamin-Therapy’ in DE
4. ‘Food-’ in DE
5. ‘Food-Preferences’ in DE
6. ‘Nutrition-’ in DE
7. (fruit or vegetabl* or saturated fat* or unsaturated fat* or fiber or fibre or supplements or supplementation or food) search in “words anywhere”
8. 1 or 2 or 3 or 4 or 5 or 6 or 7
9. ‘Preventive-Medicine’ in DE
10. prevention in DE,SU
11. ‘Health-Promotion’ in DE
12. ‘Lifestyle-Changes’ in DE
13. 9 or 10 or 11 or 12
14. explode ‘Neoplasms-’ in DE
15. cancer in ‘words anywhere’
16. 14 or 15
17. 13 and 16
18. 8 or 17
19. disseminat* or implement* or adopt* or diffusion
20. 18 and 19

Search Strategy Using Sociological Abstracts Database (Search Performed on February 11 ^ th ^ , 2002)

Limits set for: English Language, and Publication Year 1980-2001.

1. explode ‘Nutrition-’ in DE
2. ‘Feeding-Practices’ in DE or ‘Food-’ in DE or ‘Diet-’ in DE
3. (fruit or vegetabl* or saturated fat* or unsaturated fat* or fiber or fibre or supplements or supplementation or food)
4. 1 or 2 or 3
5. ‘Diffusion-’ in DE
6. ‘Information-Dissemination’ in DE
7. (disseminat* or implement* or adopt* or diffusion)
8. 5 or 6 or 7
9. 4 and 8

Search Strategy Using Cinahl Database (Search Performed on February 11 ^ th ^ , 2002)

1. (fruit or vegetabl: or saturated fat: or unsaturated fat: or fiber or fibre or supplements or supplementation or food or diet:).tw.
2. exp diet/ or nutrition.sh.
3. exp food/ or exp cereals/ or exp chewing gum/ or exp condiments/ or exp dairy products/ or exp dietary carbohydrates/ or exp dietary fats/ or exp fruit/ or exp meat/ or exp nutrients/ or exp seafood/ or exp vegetables/
4. or/1–3
5. Diffusion of Innovation/
6. (disseminat: or implement: or adopt: or diffusion).tw.
7. 5 or 6
8. 4 and 7
9. Work Capacity Evaluation/
10. Postoperative Complications/
11. Blood Donor/
12. Transplant Donors/
13. exp dna/
14. Amino Acid Sequence/
15. (Drug adj2 screening).tw.
16. (work adj2 capacity).tw.
17. postoperative complication:.tw.
18. blood donor:.tw.
19. tissue donor:.tw.
20. dna.tw.
21. amino acid sequence:.tw.
22. or/9–21
23. 8 not 22
24. limit 23 to (english and (adult <19 to 44 years> or middle age <45 to 64 years> or aged <65 to 79 years> or “aged, 80 and over”))
25. (editorial or letter or proceedings).pt.
26. 24 not 25
27. Health promotion.sh.
28. pc.fs.
29. exp neoplasms/ or cancer.tw.
30. or/27–29
31. 26 and 30

### Mammography

Search Strategy Using NLM Databases ^b^ (Search Performed on January 11 ^ th ^ , 2002)

1. (breast cancer adj5 screen:).tw.
2. mammogra:.tw,sh.
3. mass screening/ and exp breast neoplasms/
4. or/1–3
5. (disseminat: or implement: or adopt:).tw.
6. diffusion of innovation/
7. Diffusion.tw.
8. or/5–7
9. 4 and 8
10. limit 9 to english language
11. limit 10 to human [Limit not valid in: Pre-MEDLINE; records were retained]
12. limit 11 to yr=1980-2002
13. drug screening/
14. work capacity evaluation/
15. postoperative complications/
16. blood donor/
17. tissue donor/
18. exp DNA/
19. amino acid sequence/
20. (drug adj2 screening).tw.
21. (work adj2 capacity).tw.
22. postoperative complication:.tw.
23. blood donor:.tw.
24. tissue donor:.tw.
25. DNA:.tw.
26. amino acid sequence:.tw.
27. or/13–26
28. 12 not 27
29. (addresses or analytic or bibliography or biography or classical article or comment or consensus development conference or consensus development conference nih or current biog obit or dictionary or directory or duplicate publication or editorial or festschrift or historical article or interview or lectures or legal cases or letter or news or newspaper article or review of reported cases or review tutorial or meeting abstracts or meeting report or meeting paper).pt.
30. 28 not 29

Search Strategy Using Embase Database (Search Performed on January 11 ^ th ^ , 2002)

1. exp mammography or mammogra:.tw.
2. cancer screening/ and (exp breast or breast.tw.)
3. (exp breast cancer) and (screening/ or mass screening/ or screening test/)
4. (breast cancer adj5 screen:).tw.
5. or/1–4
6. (disseminat: or implement: or adopt or diffusion).tw.
7. 5 and 6
8. limit 7 to (human and english language)
9. Drug Screening/
10. Work Capacity/
11. Postoperative Complication/
12. Blood Donor/
13. Donor/
14. exp dna/
15. Amino Acid Sequence/
16. (Drug adj2 screening).tw.
17. (work adj2 capacity).tw.
18. postoperative complication:.tw.
19. blood donor:.tw.
20. tissue donor:.tw.
21. dna.tw.
22. amino acid sequence:.tw.
23. or/9–22
24. 8 not 23
25. (editorial or letter or proceeding).pt.
26. 24 not 25

Search Strategy Using PsychINFO Database (Search Performed on January 11 ^ th ^ , 2002)

Limits set for: English Language, Publication Year 1980-2001; Adulthood; Aged; Middle-Age; Thirties; Very-Old; Young-Adulthood.

1. mammography in DE
2. ‘cancer screening’ in DE and breast
3. ‘health screening’ in DE and ‘breast neoplasms’ in DE
4. ‘breast cancer’ and screen*
5. mammogra*
6. 1 or 2 or 3 or 4 or 5
7. disseminat* or implement* or adopt* or diffusion
8. 6 and 7

Search Strategy Using Sociological Abstracts Database (Search Performed on January 11 ^ th ^ , 2002)

Limits set for: English Language, and Publication Year 1980-2001.

1. ‘breast cancer’ and screen*
2. mammogra*
3. (tests in de) and (cancer in de) and breast
4. 1 or 2 or 3
5. ‘Diffusion-’ in DE
6. ‘Information-Dissemination’ in DE
7. (disseminat* or implement* or adopt* or diffusion)
8. 5 or 6 or 7
9. 4 and 8

Search Strategy Using Cinahl Database (Search Performed on January 11 ^ th ^ , 2002)

1. mammography/ or mammogra:.tw.
2. cancer screening/ and (breast.tw. or exp breast)
3. (breast cancer adj5 screen:).tw.
4. or/1–3
5. Diffusion of Innovation/
6. (disseminat: or implement: or adopt: or diffusion).tw.
7. 5 or 6
8. 4 and 7
9. Work Capacity Evaluation/
10. Postoperative Complications/
11. Blood Donor/
12. Transplant Donors/
13. exp dna/
14. Amino Acid Sequence/
15. (Drug adj2 screening).tw.
16. (work adj2 capacity).tw.
17. postoperative complication:.tw.
18. blood donor:.tw.
19. tissue donor:.tw.
20. dna.tw.
21. amino acid sequence:.tw.
22. or/9–21
23. 8 not 22
24. limit 23 to (english and (adult <19 to 44 years> or middle age <45 to 64 years> or aged <65 to 79 years> or “aged, 80 and over”))
25. (editorial or letter or proceedings).pt.
26. 24 not 25

### Cervical Cancer Screening

Search Strategy Using NLM Databases ^b^ (Search Performed on January 15 ^ th ^ , 2002)

1. cervix neoplasms/ and mass screening/
2. Vaginal Smears/
3. vagina: smear:.tw.
4. pap test:.tw.
5. (papanicolaou adj2 (smear: or test:)).tw.
6. (cervical adj2 (smear: or test:)).tw.
7. (cervical adj2 (smear: or screen:)).tw.
8. pap smear:.tw.
9. or/1–8
10. (disseminat: or implement: or adopt:).tw.
11. diffusion of innovation/
12. diffusion.tw.
13. or/10–12
14. 9 and 13
15. limit 14 to english language
16. limit 15 to human [Limit not valid in: Pre-MEDLINE; records were retained]
17. limit 16to yr=1980-2002
18. drug screening/
19. work capacity evaluation/
20. postoperative complications/
21. blood donor/
22. tissue donor/
23. exp DNA/
24. amino acid sequence/
25. (drug adj2 screening).tw.
26. (work adj2 capacity).tw.
27. postoperative complication:.tw.
28. blood donor:.tw.
29. tissue donor:.tw.
30. DNA:.tw.
31. amino acid sequence:.tw.
32. or/18–31
33. 17 not 32
34. (addresses or analytic or bibliography or biography or classical article or comment or consensus development conference or consensus development conference nih or current biog obit or dictionary or directory or duplicate publication or editorial or festschrift or historical article or interview or lectures or legal cases or letter or news or newspaper article or review of reported cases or review tutorial or meeting abstracts or meeting report or meeting paper).pt.
35. 33 not 34

Search Strategy Using Embase Database (Search Performed on January 15 ^ th ^ , 2002)

1. Papanicolaou Test/ or Vagina Smear/
2. exp Uterine Cervix Cancer and (screening/ or screening test/ or mass screening/
3. cancer screening and (exp uterine cervix or cervical.tw. or cervix.tw.)
4. vagina: smear:.tw.
5. pap test:.tw.
6. (papanicolaou adj2 (smear: or test:)).tw.
7. (cervical adj2 (smear: or test:)).tw.
8. (cervical adj2 (smear: or screen:)).tw.
9. or/1–8
10. (disseminat: or implement: or adopt or diffusion).tw.
11. 9 and 10
12. limit 11 to (human and english language)
13. Drug Screening/
14. Work Capacity/
15. Postoperative Complication/
16. Blood Donor/
17. Donor/
18. exp dna/
19. Amino Acid Sequence/
20. (Drug adj2 screening).tw.
21. (work adj2 capacity).tw.
22. postoperative complication:.tw.
23. blood donor:.tw.
24. tissue donor:.tw.
25. dna.tw.
26. amino acid sequence:.tw.
27. or/13–26
28. 12 not 27
29. (editorial or letter or proceeding).pt.
30. 28 not 29

Search Strategy Using PsychINFO Database (Search Performed on January 15 ^ th ^ , 2002)

Limits set for: English Language, Publication Year 1980-2001; Adulthood; Aged; Middle-Age; Thirties; Very-Old; Young-Adulthood.

1. (cervix in de) and ((health screening in de) or (cancer screening in de))
2. vagina* smear*
3. papanicolaou and (smear* or test*)
4. cervical and (smear* or test* or screen*).
5. pap smear* or pap test*
6. 1 or 2 or 3 or 4 or 5
7. disseminat* or implement* or adopt* or diffusion
8. 6 and 7

Search Strategy Using Sociological Abstracts Database (Search Performed on January 15 ^ th ^ , 2002)

Limits set for: English Language, and Publication Year 1980-2001.

1. vagina* smear* or pap smear* or pap test*
2. ((cervical or papanicolaou) and (smear* or test* or screen*))
3. (tests in de) and (cancer in de) and (cervix or cervical)
4. 1 or 2 or 3
5. ‘Diffusion-’ in DE
6. ‘Information-Dissemination’ in DE
7. (disseminat* or implement* or adopt* or diffusion)
8. 5 or 6 or 7
9. 4 and 8

Search Strategy Using Cinahl Database (Search Performed on January 15 ^ th ^ , 2002)

1. Cervical Smears/
2. vagina: smear:.tw.
3. pap test:.tw.
4. (papanicolaou adj2 (smear: or test:)).tw.
5. (cervical adj2 (smear: or test:)).tw.
6. (cervical adj2 (smear: or screen:)).tw.
7. cancer screening/ and (cervix/ or cervix.tw. or cervical.tw.)
8. or/1–7
9. Diffusion of Innovation/
10. (disseminat: or implement: or adopt: or diffusion).tw.
11. 9 or 10
12. 8 and 11
13. Work Capacity Evaluation/
14. Postoperative Complications/
15. Blood Donor/
16. Transplant Donors/
17. exp dna/
18. Amino Acid Sequence/
19. (Drug adj2 screening).tw.
20. (work adj2 capacity).tw.
21. postoperative complication:.tw.
22. blood donor:.tw.
23. tissue donor:.tw.
24. dna.tw.
25. amino acid sequence:.tw.
26. or/13–25
27. 12 not 26
28. limit 27 to (english and (adult <19 to 44 years> or middle age <45 to 64 years> or aged <65 to 79 years> or “aged, 80 and over”))
29. (editorial or letter or proceedings).pt.
30. 28 not 29

### Control of Cancer Pain

Search Strategy Using NLM Databases ^b^ (Search Performed on February 26 ^ th ^ , 2002)

1. exp neoplasms/ or neoplasms.mp
2. cancer.tw.
3. 1 or 2
4. exp analgesia/
5. exp analgesics/ or analgesics.mp
6. exp pain or pain.mp
7. analgesia.mp.
8. or/4–7
9. 3 and 8
10. (disseminat: or implement: or adopt:).tw.
11. diffusion of innovation/
12. diffusion.tw.
13. or/10–12
14. 9 and 13
15. limit 14 to english language
16. limit 15 to human [Limit not valid in: Pre-MEDLINE; records were retained]
17. limit 16 to yr=1980-2002
18. drug screening/
19. work capacity evaluation/
20. postoperative complications/
21. blood donor/
22. tissue donor/
23. exp DNA/
24. amino acid sequence/
25. (drug adj2 screening).tw.
26. (work adj2 capacity).tw.
27. postoperative complication:.tw.
28. blood donor:.tw.
29. tissue donor:.tw.
30. DNA:.tw.
31. amino acid sequence:.tw.
32. or/18–31
33. 17 not 32
34. (addresses or analytic or bibliography or biography or classical article or comment or consensus development conference or consensus development conference nih or current biog obit or dictionary or directory or duplicate publication or editorial or festschrift or historical article or interview or lectures or legal cases or letter or news or newspaper article or review of reported cases or review tutorial or meeting abstracts or meeting report or meeting paper).pt.
35. 33 not 34

Search Strategy Using Embase Database (Search Performed on February 25 ^ th ^ , 2002)

1. exp neoplasm/ or cancer.tw. or neoplasm.mp.
2. exp analgesia/ or analgesia.mp. or exp analgesic agent/ or analgesic:.mp.
3. exp pain/ or pain.mp.
4. 2 or 3
5. 1 and 4
6. (disseminat: or implement: or adopt or diffusion).tw.
7. 5 and 6
8. limit 7 to (human and english language)
9. Drug Screening/
10. Work Capacity/
11. Postoperative Complication/
12. Blood Donor/
13. Donor/
14. exp dna/
15. Amino Acid Sequence/
16. (Drug adj2 screening).tw.
17. (work adj2 capacity).tw.
18. postoperative complication:.tw.
19. blood donor:.tw.
20. tissue donor:.tw.
21. dna.tw.
22. amino acid sequence:.tw.
23. or/9–22
24. 8 not 23
25. (editorial or letter or proceeding).pt.
26. 24 not 25

Search Strategy Using PsychINFO Database (Search Performed on February 27 ^ th ^ , 2002)

Limits set for: English Language, Publication Year 1980-2001; Adulthood; Aged; Middle-Age; Thirties; Very-Old; Young-Adulthood.

1. (explode ‘Neoplasms-’ in DE) or cancer
2. (‘Analgesia-’ in DE)
3. explode ‘Analgesic-Drugs’ in DE
4. (‘pain management’ in de)
5. (explode pain in de)
6. analges* or pain
7. 2 or 3 or 4 or 5 or 6
8. 1 and 7
9. disseminat* or implement* or adopt* or diffusion
10. 8 and 9

Search Strategy Using Sociological Abstracts Database (Search Performed on February 27 ^ th ^ , 2002)

Limits set for: English Language, and Publication Year 1980-2001.

1. (explode ‘cancer’ in de) or cancer
2. (pain in de) or pain
3. 1 and 2
4. ‘Diffusion-’ in DE
5. ‘Information-Dissemination’ in DE
6. (disseminat* or implement* or adopt* or diffusion)
7. 4 or 5 or 6
8. 3 and 7

Search Strategy Using Cinahl Database (Search Performed on February 27 ^ th ^ , 2002)

1. exp neoplams/ or cancer.tw. or neoplasm.mp.
2. exp analgesia or analges:.tw. .
3. exp analgesics
4. exp pain/ or pain.tw
5. or/2–4
6. 1 and 5
7. cancer pain/
8. 6 or 7
9. Diffusion of Innovation/
10. (disseminat: or implement: or adopt: or diffusion).tw.
11. 9 or 10
12. 8 and 11
13. Work Capacity Evaluation/
14. Postoperative Complications/
15. Blood Donor/
16. Transplant Donors/
17. exp dna/
18. Amino Acid Sequence/
19. (Drug adj2 screening).tw.
20. (work adj2 capacity).tw.
21. postoperative complication:.tw.
22. blood donor:.tw.
23. tissue donor:.tw.
24. dna.tw.
25. amino acid sequence:.tw.
26. or/13–25
27. 12 not 26
28. limit 27 to (english and (adult <19 to 44 years> or middle age <45 to 64 years> or aged <65 to 79 years> or “aged, 80 and over”))
29. (editorial or letter or proceedings).pt.
30. 28 not 29