# Appendix A: The Collaborative team

The collaborative team that has developed this Task Order included a local research team, representatives from the Division of Cancer Control and Population Sciences at NCI and the Task Order Officer (TOO). The local research team consisted of investigators directly related to the MU-EPC. Input from the Division of Cancer Control and Population Sciences included individuals that complemented and enhanced the array of skills and backgrounds included in the McMaster team.

Evidence-based Practice Center Personnel:

[underlined: Investigators:]

Parminder Raina PhD - EPC Director, Co-Task Order Leader

Peter Ellis MBBS MMed(Clin Epi) PhD FRACP, Co-Task Order Leader

Donna Ciliska, PhD

[underlined: Staff:]

Tanya Armour, PhD

Fulvia Baldassarre, MSc

Roxanne Cheeseman

Angela Eady, MLS

Ann Fucic

Mary Gauld, BA

Paula Robinson, MD, MSc

[underlined: Local Advisors:]

George Browman MD, MSc, FRCP(C)

Melissa Brouwers, PhD

Brian Haynes MD, PhD

John Lavis MD, MSc, PhD

Mary Ann O'Brien, MSc, BHSc (PT)

Anne Snider, MEd

Jonathan Sussman, MD, MSc, FRCP (c)

Timothy Whelan, BM, BCh, MSc

[underlined: AHRQ:]

Jacqueline Besteman, EPC Program Director

Margaret Coopey, Task Order Officer

Mary Haines, Contracts Officer

[underlined: NCI Partners:]

Jon Kerner

Barbara Rimer

[underlined: Technical Expert Panel - Conference Call Participants]

Alice Ammerman, Allan Best, Charmaine Cummings, Andrea Denicoff, Tanisha Denny, Alicia Eberl-Lefko, Brion Fox, Tom Glynn, Sue Krebs-Smith, Scott Leischow, Helen Meissner, Margo Michaels, Brad Myers, Linda Nebeling, Ann O'Mara, Julia Rowland, Gloria Stables, Bonnie Teschendorf, Cynthia Vinson.

[underlined: Others]

The authors of this report would like to thank and acknowledge the assistance of the following people:

Amy Steep and Tom Flemming of the McMaster University Health Sciences library for helping us with our searches, retrievals and the development of new methods to ‘work’ the library from off-site; Paul Ritvo, Linda Pederson, Annika Lillrank, Ann McDonnell, Elizabeth Kaegi, Helen Meissner, Cynthia Vinson and Diane van Abbe for providing us with documents we were otherwise unable to obtain; to Bridget Culhane for helping with the recruitment of peer reviewers; Dan Ellington from ISI Researchsoft for being so helpful in explaining how to manage our references and citations; to Rob Stevens and Lynda Booker for assistance with data abstraction; to Ann Fucic, Roxanne Cheeseman and Susan Hanna for taking the lead on the preparation of the manuscript and distribution of this report; and to Devon Christie, Erin Harvey, Carl Creatchman for their general assistance.