# Appendixes

Appendix A: The Collaborative team

Appendix B: Original key questions

Appendix C: Search Strategies

Appendix D: Guidelines for citation retrieval

Appendix E - Forms

Appendix F: Peer Reviewers

Appendix G

Appendix H: Acronyms and Abbreviations