# Acknowledgments

We wish to thank the medical directors and staff of the two clinics identified in this report for their invaluable help in identifying appropriate cases. Without their assistance, this project would have not been possible.

We would also like to thank the expert reviewers who helped us abstract the data at these clinics. Thank you Adelaide Coulter, Dr. Jim Gagne, and Dr. Jay Udani.