# Future Research

This review was based on the assumption that a proactive approach to creating a best-case series might be more productive than relying on practitioners to create their own best-case series. While our work demonstrates that a best-case series can be constructed for CAM therapy, it also demonstrates that to do so requires considerable resources, time, and effort. Assembling documentary evidence through retrospective case analysis is difficult, even with a trained research staff. For a CAM provider without a trained research staff, such an undertaking is probably not feasible. An alternative approach might be to establish a prospective case series where the protocol for treatment and the documentation can be established prior to the treatment.