# Results

## Overview of Case Review

For IAT, we reviewed, in depth, 30 cases (of the possible 60 cases) that had the potential to be included in a best-case series. Of those, nine cases are presented that we consider the most complete or appropriate in terms of the NCI criteria for a best-case series. They included the following types of cancer: Hodgkin's lymphoma, non - small cell carcinoma of the lung, nodular lymphoma (poorly differentiated), abdominal mesothelioma (two cases), ovarian adenocarcinoma, squamous cell carcinoma of vocal cord (two cases), and colon cancer.

For Naltrexone only three cases of the 21 we reviewed in depth approximated the NCI criteria. These included the following cancers: melanoma, pancreatic cancer, and endometrial adenocarcinoma with breast adenocarcinoma (single case).

However, the extent to which these cases meet the NCI criteria varied considerably. The most difficult criteria to meet are the histological/imaging confirmations, for two reasons; 1) inadequate information was provided by the file or the patient, or 2) the case was so old that the providers no longer had the specimens or files.

Whereas no institution refused to provide us with the material we requested, we had to rely in some cases on biopsy reports, radiological reports, and other such interpretations of the original material instead of the actual slides and images. Any case older than five years was unlikely to be able to meet the strict criteria of providing actual biopsy material and/or original images. However, we are still actively seeking much of this material for the cases included in this review. The status reports of the requested materials are shown below in Tables 1 and 2.

Table 1. Status report of requested materials (IAT)

ID# | Authorization Received | Reports Requested | Status of Reports
1-1 | Yes | 6 requested | 1 pending
| | | 5 not available
1-3 | Yes | 1 requested | 1 not available
1-4 | Yes | 6 requested | 6 pending
1-6 | Yes | 7 requested | 7 not available
1-7 | Yes | 9 requested | 7 received
| | | 1 pending
| | | 1 not available
1-9 | Yes | 6 requested | 2 received
| | | 4 not available
1-11 | Yes | 1 requested | 1 not available
1-19 | Yes | 5 requested | 2 pending
| | | 3 not available
1-22 | Yes | 6 requested | 6 pending

Table 2. Status report of requested materials (Naltrexone)

ID# | Authorization Received | Reports Requested | Status of Reports
2-10 | Yes | 2 requested | 2 pending
2-21 | Yes | 4 requested | 4 pending
2-22 | Yes | 9 requested | 9 pending

## Cancer Best-Case Series

### Patient #1-1 Nodular Sclerosing Lymphoma Stage 1B

#### Case 1-1

The patient in case 1-1 is a 46-year-old male diagnosed on 12/2/83 with nodular sclerosing lymphoma stage 1B after presenting with superior vena caval obstruction. Palliative radiation therapy was completed on 12/7/83 with a total of 800 RADS delivered to his vena cava. Chemotherapy (MOPP) was started on 12/00/83 and stopped early on 6/00/84. Four cycles of full-dose chemotherapy and two additional courses of a 25% reduced dose were given. On 7/19/94, it was recommended that the patient receive full mantle radiation, which he declined. At the termination of conventional therapy, the patient had no palpable peripheral lymphadenopathy but still had a superior mediastinal mass (CXR 7/10/84). IAT was started on 8/2/84, and 22 courses were completed as of 12/8/00 (the data of chart abstraction). The patient had sporadically taken a variety of dietary supplements in the past. Serial chest x-rays performed during IAT therapy showed a decrease in tumor mass. The most recent MRI for which we have a report (11/4/86) showed inactive disease. The most recent MRI of the chest (1995) revealed no tumor according to the patient. At the last patient contact (interview, 9/26/01), the patient reported that his overall physical condition was excellent.

Pathology

12/2/83 | Biopsy: anterior mediastinal Hodgkin's lymphoma (nodular sclerosing type)
12/7/83 | Biopsy: bone marrow: normal

Imaging

4/17/84 | X-ray chest: further improvement of mediastinal mass
7/10/84 | X-ray chest: mass in chest, no change
11/4/86 | MRI chest: complete obstruction of superior vena cava. Unchanged anteromediastinal mass suggests inactive disease at this time
1995 | MRI chest: no evidence of disease per patient

Conventional therapy

12/7/83 | Radiation: palliative to superior vena cava: 800 RADS: decrease in size of mass
12/83–6/84 | Chemotherapy: MOPP: 4 cycles: followed by 2 cycles reduced by 25%: Did not complete chemotherapy due to patient preference and low blood counts.
7/19/84 | Radiation (mantle) recommended; patient declined

Complementary therapy

8/2/84–12/8/00 | IAT 22 courses
11/1/84 | Benzaine E, calcium orotate, molybdenum, S.O.D., beta-carotene, glutathione, kyolic, Vitamin C, Vitamin E, lithumorate, Wobenzym, inzellonal, transmutase forte, thymus pills & injections, asterile injections, beriglobin, Vitamin D oil, selenium, carnitine (treatment recorded as provided by patient)
Date unknown | Live cell therapy in Germany; did not proceed with entire treatment

Patient # 1-1
EVENT | PERIOD 1 | | | | PERIOD 2 | | | | PERIOD 3 | | | | PERIOD 4 | | | | PERIOD 5 | | | | PERIOD 6
| 1^st^ qtr 1983 – 4^th^ qtr 1983 | | | | 1^st^ qtr 1984 – 4^th^ qtr 1984 | | | | 1^st^ qtr 1985 – 4^th^ qtr 1985 | | | | 1^st^ qtr 1986 – 4^th^ qtr 1986 | | | | 1^st^ qtr 1995 – 4^th^ qtr 1995 | | | | 1^st^ qtr 2000 – 4^th^ qtr 2000
Biopsy/diagnosis | | | | 12/83
Surgery
Radiation | | | | 12/83
Chemotherapy | | | | 12/83 | | 6/84
IAT | | | | | | | 8/84 | | | | | | | | | | | | | | | | | 12/00
CAM other | | | | | | | | 11/84
Imaging CXR | | | | | 3/84 | 4/84 | 7/84
Imaging MRI | | | | | | | | | | | | | | | | 11/86 | 1995

Date | Description of Events | Requested | Status of requests
| Family history of lymphoma in brother
12/2/83 | Biopsy: anterior mediastinal: Hodgkin's disease (nodular sclerosing) | Slides | Not avail.
12/7/83 | Biopsy: bone marrow; normal | Slides | Not avail.
12/7/83 | Radiation: palliative to superior vena cava: 800 RADS: decrease in size of mass
12/83–6-84 | Chemotherapy: MOPP: 4 cycles: followed by 2 cycles reduced by 25%: Did not complete chemotherapy due to patient preference.
4/17/84 | X-ray chest: further improvement of mediastinal mass | Films | Not avail.
7/10/84 | X-ray chest: mass in chest, no change | Films | Not avail.
8/2/84–12/8/00 | IAT 22 courses
11/1/84 | Benzaine E, calcium ortate, molybenum, S.O.D., beta-carotene, glutathione, kyolic, Vitamin C, Vitamin E, lithumorate, wobenzym, inzellonal, tranmusase forte, thymus pills & injections, astenile injections, beriglobin, Vitamin D oil, selenium, carnitine
11/4/86 | MRI chest: complete obstruction of superior vena cava. Inactive disease at this time | Films | Not avail.
1995 | MRI chest: no evidence of disease per patient | Films | Pending

### Patient #1-3 Squamous Cell Carcinoma of the Right Vocal Cord and Anterior Commissure

#### Case 1-3

The patient in case 1-3 is a 68-year-old male who was diagnosed with squamous cell carcinoma of the right vocal cord and anterior commissure on 9/3/81. An excisional biopsy was performed at that time, but the resection was not complete. The patient was referred for radiation therapy, which he refused due to patient preference. Thus, the patient received no definitive conventional therapy. He completed 15 courses of IAT from 9/22/81 to 5/19/89. Serial examinations by his otolaryngologist revealed the persistent presence of disease without progression through 2/23/82. An otolaryngologist performed an indirect laryngoscopy on 7/20/94, which did not reveal any abnormal findings. At the last contact (interview, 9/24/01), the patient reported that his overall physical condition was very good to excellent.

Pathology

9/3/81 | Biopsy: squamous cell carcinoma, well differentiated, infiltrating: right vocal cord and anterior commissure: stage T:1 1/2 N:0 M:0

Imaging

9/22/81 | X-ray chest: normal
7/20/94 | ENT evaluation visual inspection via indirect laryngoscopy: normal exam

Conventional therapy

9/3/81 | Surgery: biopsy with debulking; 80–90% bulky tumor mass removed; residual cancer remained
9/16/81 | Referred for radiation: patient refused

Complementary therapy

9/22/81–5/19/89 | IAT 15 courses

Patient # 1-3
EVENT | PERIOD 1 | | | | PERIOD 2 | | | | PERIOD 3 | | | | PERIOD 4 | | | | PERIOD 5 | | | | PERIOD 6
| 1^st^ qtr 1981 – 4^th^ qtr 1981 | | | | 1^st^ qtr 1984 – 4^th^ qtr 1984 | | | | 1^st^ qtr 1985 – 4^th^ qtr 1985 | | | | 1^st^ qtr 1986 – 4^th^ qtr 1986 | | | | 1^st^ qtr 1989 – 4^th^ qtr 1989 | | | | 1^st^ qtr 1994 – 4^th^ qtr 1994
Diagnosis/biopsy | | | 9/81
Diagnostic procedure | | | | | | | | | | | | | | | | | | | | | | | 7/94
Surgery | | | 9/81
Radiation
Chemotherapy
IAT | | | 9/81 | | | | | | | | | | | | | | | 5/89
CAM other
Imaging CXR | | | 9/81

Date | Description of Events | Requested | Status of requests
| Family history of gastric cancer in mother
9/3/81 | Biopsy: squamous cell carcinoma, well-differentiated, infiltrating: right vocal cord and anterior commisure: stage T:1 1/2 N:0 M:0 | Slides | Not avail.
9/3/81 | Surgery: biopsy with debulking- residual cancer remained
9/3/81 | Referred for radiation: patient refused
9/22/81 | X-ray chest: normal
9/22/81–5/19/89 | IAT: 15 courses
7/20/94 | ENT evaluation visual inspection via indirect laryngoscopy

### Patient #1-4 Metastatic Non - Small Cell Carcinoma of the Lung

#### Case 1-4

The patient in case 1-4 is a 67-year-old woman with a family history of cancer, diagnosed with metastatic non - small cell carcinoma of the lung in July 1992. She initially presented with swelling in the neck, an enlarged supraclavicular lymph node, and a chest mass demonstrated by CT in the area of the aortic notch. A mini-thoracotomy was performed to obtain tissue for diagnosis. Initially, the mass was identified as an anaplastic mediastinal tumor, which subsequent review at the Canadian Reference Lab for Pathology determined to be non - small cell poorly differentiated lung cancer. Subsequently, she was referred for palliative chemotherapy and radiation, which she completed. No response was demonstrated to these treatments, and no further conventional therapy was advised. She initiated IAT in February 1993 and continues on maintenance therapy today. Serial CT scans beginning in September 1994 revealed resolution of the tumor. At the last contact (interview, 12/4/01), the patient reported that her overall physical condition was good.

Pathology

7/31/92 | Surgical biopsy: mediastinum (multiple bite biopsy via mediastinotomy): discrepancy of pathological diagnosis: first diagnosis lymphoma, second diagnosis metastatic giant cell carcinoma, third diagnosis lung carcinoma poorly differentiated (9/4/92)
7/31/92 | Biopsy: left supraclavicular lymph node final pathology revealed lung carcinoma poorly differentiated
8/12/92 | Biopsy: bone marrow: negative for malignancy

Imaging

July, 92 | CT scan thorax: tumor 5cm mass in the area of the aortic notch
7/31/92 | X-ray chest: no change compared with prior
8/4/92 | Bone scan whole body: no metastatic bone disease
9/9/93 | CT scan thoracic: tumor decreased in size, residual tumor or post treatment fibrosis
11/30/93 | X-ray chest/ left shoulder: right lung clear; no tumor; increase left hemi-diaphragm
4/13/94 | X-ray chest: no significant changes compared with previous
9/26/94 | X-ray chest: lungs clear
9/26/94 | CT scan thoracic: no evidence of tumor; Remission based on CT scan of thorax revealing no evidence of tumor
6/24/93 | Ultrasound abdomen: normal
11/11/96 | CT scan thoracic: no evidence of tumor; post radiation changes in left thorax
11/25/97 | CT scan thoracic: no evidence of tumor
12/7/98 | CT scan thoracic: no evidence of tumor
12/15/00 | CT scan thoracic: no evidence of tumor; no change compared with 12/7/98

Conventional therapy

7/31/92 | Left anterior mediastinotomy; mediastinal mass biopsy
8/00/92 | Chemotherapy: cytoxan, adriamycin, vincristine, prednisone; stopped early due to change in tissue diagnosis
9/00/92 | Chemotherapy: VP16 190mg, cisplatinum 48 mg : 3 days every 3 weeks: completed recommended course: no tumor response
10/21/92 | Radiation: palliative: mediastinum/ left perihilar/ supraclavicular: 4,000cGy; no tumor response
11/92–12/92 | Chemotherapy: VP16 190mg, cisplatinum 48 mg: 3 days every 3 weeks: completed recommended course: no tumor response

Complementary therapy

2/8/93-present | IAT; still on maintenance therapy

Patient # 1-4
EVENT | PERIOD 1 | | | | PERIOD 2 | | | | PERIOD 3 | | | | PERIOD 4 | | | | PERIOD 5 | | | | PERIOD 6 | | | | PERIOD 7 | | | | PERIOD 8 | | | | PERIOD 9 | | | | PERIOD 10
| 1^st^ qtr 1992 – 4^th^ qtr 1992 | | | | 1^st^ qtr 1993 – 4^th^ qtr 1993 | | | | 1^st^ qtr 1994 – 4^th^ qtr 1994 | | | | 1^st^ qtr 1995 – 4^th^ qtr 1995 | | | | 1^st^ qtr 1996 – 4^th^ qtr 1996 | | | | 1^st^ qtr 1997 – 4^th^ qtr 1997 | | | | 1^st^ qtr 1998– 4^th^ qtr 1998 | | | | 1^st^ qtr 1999 – 4^th^ qtr 1999 | | | | 1^st^ qtr 2000 – 4^th^ qtr 2000 | | | | 1^st^ qtr 2001 – 4^th^ qtr 2001
Diagnosis/biopsy | | | 7/92, 8/92
Surgery | | | 7/92
Radiation | | | | 10/92
Chemotherapy | | | 7/92–9/92 | 12/92
IAT | | | | | 2/93
CAM other
Imaging CXR | | | 7/92 | | | | | 11/93 | | 4/94 | 9/94
Imaging CT | | | 7/92 | | | | 9/93 | | | | 9/94 | | | | | | | | | 11/96 | | | | 11/97 | | | | 12/98 | | | | | | | | 12/00
Imaging bone scan | | | 8/92

Date | Description of Events | Requested
no date | Family history: sister lung cancer, maternal aunt breast cancer, mother urinary cancer
7/31/92 | Surgical biopsy: mediastinum (multiple bite biopsy via mediastinotomy): discrepancy of pathological diagnosis: first diagnosis lymphoma, second diagnosis metastatic giant cell carcinoma, third diagnosis lung carcinoma poorly differentiated (9/4/92) | Slides
7/31/92 | Biopsy: left supraclavicular lymph node final pathology revealed lung carcinoma poorly differentiated | Slides
7/31/92 | X-ray chest: no mass
8/4/92 | Bone scan whole body: no metastatic bone disease
8/12/92 | Biopsy: bone marrow: negative for malignancy
8/00/92 | Chemotherapy: cytoxan, adriamycin, vincristine, prednisone; stopped early due to change in tissue diagnosis
9/00/92 | Chemotherapy: VP16 190mg, cisplatinum 48 mg : 3 days every 3 weeks: completed recommended course: no tumor response
10/21/92 | Radiation: palliative: mediastinum/ left perihilar/ supraclavicular: 4,000cGy; no tumor response
1/6/93 | Chemotherapy: VP16 190mg, cisplatinum 48 mg : 3 days every 3 weeks: completed recommended course: no tumor response
2/8/93-present | IAT; still on maintenance therapy
6/24/93 | Ultrasound abdomen: normal
9/9/93 | CT scan thoracic: tumor decreased in size, residual tumor or post treatment fibrosis | Films
11/30/93 | X-ray chest/ left shoulder: right lung clear; no tumor; increase left hemi-diaphragm
4/13/94 | X-ray chest: no significant changes compared with previous

Date | Description of Events | Requested | Status of requests
9/26/94 | X-ray chest: lungs clear | Films | Pend.
9/26/94 | CT scan thoracic: no evidence of tumor
11/11/96 | CT scan thoracic: no evidence of tumor; post radiation changes in left thorax
11/25/97 | CT scan thoracic: no evidence of tumor
7/12/98 | CT scan thoracic: no evidence of tumor | Films | Pend.
12/15/00 | CT scan thoracic: no evidence of tumor; no change compared with 12/7/98 | Films | Pend.

### Patient #1-6 Poorly Differentiated Nodular Lymphoma

#### Case 1-6

The patient in case 1-6 is a 49-year-old male who was diagnosed in 1983 with poorly differentiated nodular lymphoma after presenting with an enlarged node on his chin, fever, night sweats, and generalized pruritus. Although the patient was not found to have significant demonstrable adenopathy outside of the neck at diagnosis, he was felt to represent stage II disease. Local radiation was not recommended, and chemotherapy was deferred awaiting progression of disease. By 2/1/84, he had palpable adenopathy in both axillae and demonstrated anergy in skin testing. The patient elected to try unconventional therapy. He started IAT on 2/14/84 and had completed twelve courses by 7/19/90. He is currently in remission. At last contact (interview, 11/07/01), the patient reported that is overall physical condition was excellent.

Pathology

12/5/83 | Biopsy: pathology: lymph node: poorly differentiated lymphocytic nodular lymphoma
12/21/83 | Biopsy: bone marrow: negative for malignancy

Imaging

12/4/83 | Chest x-ray: within normal limits
12/21/83 | Chest x-ray: within normal limits
12/21/83 | Ultrasound abdomen: within normal limits
2/14/84 | Ultrasound abdomen: within normal limits
2/14/84 | Chest x-ray: within normal limits
3/23/88 | Ultrasound abdomen: within normal limits

Complementary therapy

2/14/84–7/19/90 | IAT: 12 courses

Conventional therapy

| None

Patient # 1-6
EVENT | PERIOD 1 | | | | PERIOD 2 | | | | PERIOD 3 | | | | PERIOD 4 | | | | PERIOD 5 | | | | PERIOD 6
| 1^st^ qtr 1983 – 4^th^ qtr 1983 | | | | 1^st^ qtr 1984 – 4^th^ qtr 1984 | | | | 1^st^ qtr 1985 – 4^th^ qtr 1985 | | | | 1^st^ qtr 1986 – 4^th^ qtr 1986 | | | | 1^st^ qtr 1988 – 4^th^ qtr 1988 | | | | 1^st^ qtr 1990 – 4^th^ qtr 1990
Diagnosis/biopsy | | | | 12/83
Surgery
Radiation
Chemotherapy
IAT | | | | | 2/84 | | | | | | | | | | | | | | | | | | 7/90
CAM other
Imaging CXR | | | | 12/83, 12/83 | 2/84
Imaging ultrasound | | | | 12/83 | 2/84 | | | | | | | | | | | | 3/88

Date | Description of Events | Requested | Status of requests
no date | Family history of cancer: mother died age 32 melanoma; father died age 57 of lung cancer
12/5/83 | Biopsy: diagnostic excisional biopsy: poorly differentiated lymphocytic nodular lymphoma | Slides | Not avail.
12/21/83 | Bone marrow: negative for malignancy
12/21/83 | Ultrasound abdomen: within normal limits | Films | Not avail.
12/4/83 | Chest x-ray: within normal limits | Films | Not avail.
12/21/83 | Chest x-ray: within normal limits | Films | Not avail.
2/14/84 | Chest x-ray: within normal limits | Films | Not avail.
2/14/84–7/19/90 | IAT: 12 courses
3/23/88 | Ultrasound abdomen: within normal limits | Films | Not avail.
6/20/98 | Physical exam: peripheral lymphadenopathy resolved by 1988: negative radiological studies

### Patient #1-7 Peritoneal Mesothelioma

#### Case 1-7

The patient in case 1-7 is a 50-year-old Caucasian female with a history of peritoneal mesothelioma. She was initially misdiagnosed with ovarian cancer on 7/1/99 after peritoneal biopsies were obtained from an exploratory laparoscopy with excision of left pelvic mass, left colectomy, colostomy, and omentectomy. Given the diagnosis of ovarian cancer, chemotherapy was initiated with taxol and carboplatin on 7/28/99. She had an anaphylactic reaction to taxol, and chemotherapy was stopped. On 8/5/99, the biopsies were again reviewed at the Armed Forces Institute of Pathology, and a diagnosis of peritoneal mesothelioma was made. No other conventional therapy was pursued due to patient preference. IAT was started on 12/1/99 and continued, with her most recent treatment on 6/6/01. Serial pelvic CT scans reveal a gradual diminution of pelvic densities, with the most recent pelvic CT scan on 5/24/01 revealing no evidence of progressive tumor or other abnormality. On 10/24/01, an attempt was made to reverse the patient's colostomy. Reversal was not possible due to adhesions, and the patient's small bowel was nicked, leading to a complicated post-operative course. However, according to the patient, the surgeon reported a decrease in the tumor bulk based on visual inspection. At last contact (interview, 9/26/01), the patient reported that her overall physical health is good.

Pathology

7/1/99 | Pathology: ovarian carcinoma vs. mesothelioma melanoma
8/5/99 | Pathology: final diagnosis: malignant mesothelioma (same tissue specimen)

Imaging

2/29/00 | CT scan of abdomen and pelvis: no associated definitive soft tissue mass to suggest progression or recurrence of disease, no evidence of lymphadenopathy
5/19/00 | CT scan of abdomen and pelvis: abdomen-no recurrent mass, no definite associated soft tissue mass effect, pelvis-increase in fluid collection L>R c/w 2/29/00.
8/10/00 | X-ray chest: normal
8/30/99 | CT scan of pelvis: decrease in soft tissue density and fluid c/w 6/28/99
9/12/00 | CT scan of abdomen and pelvis: small nodular densities adjacent to the spleen, fluid collection right side of pelvis not decreased, left side extension no longer identified
11/14/00 | Bone scan whole body: prominent activity in right renal pelvis similar to 2/98
12/15/00 | US RUQ: no abnormality, no change from prior
1/16/01 | CT scan of abdomen and pelvis with contrast: no bowel abnormalities, fluid collection on right side has increased to 4.5x3cm, now fluid to lower pelvis left side, findings nonspecific but recurrence possible
1/23/01 | CT scan of pelvis: increased size of 2 rounded densities in pelvis, right lateral pelvic wall 4.5x3x0.15cm
1/23/01 | CT scan of abdomen: mild prominence of left adrenal unchanged
3/9/01 | CT scan of abdomen and pelvis with contrast: abdomen unremarkable, pelvis with loculated fluid collection in inferior pelvis in midline and on right, slight reduction in size
5/24/01 | CT scan of abdomen: no pathologically enlarged lymph nodes or free fluid
5/24/01 | CT scan of pelvis: no evidence of progressive tumor or abnormality; significant interval reduction of irregularly loculated fluid collections compared with 3/9/01 consistent with response of mesothelioma
8/15/01 | CT scan of abdomen: no upper abdominal mass compared with 5/24/01
8/15/01 | CT scan of pelvis; further reduction in small amounts of fluid. No evidence of progressive neoplasm compared with 5/24/01

Tumor markers

7/23/99 | CA^a^ 125 = 22 (<35)
5/16/00 | CA 125 = 13 (<35)

a Cancer Antigen.

Conventional therapy

7/1/99 | Exploratory laparoscopy with excision of left pelvic mass, left colectomy, colostomy, omentectomy, and multiple peritoneal biopsies
7/28/99 | Taxol, carboplatin (initially thought to be ovarian cancer) stopped due to anaphalaxis
10/24/01 | Surgery: attempted reversal of colostomy: decrease of tumor bulk based on visual inspection

Complementary therapy

12/1/99–6/6/01 | IAT 6 courses over this time interval
12/1/99-present (intermittent) | MGn3, noni juice, colostrum, vitamin E, green tea, vitamin C, beta carotene, cat's claw, homeopathic miasms
1/30/01-present (intermittent) | Homeopathic -Haelan (fermented soy product), cat's claw, lyperinol
2/2/01-present (intermittent) | Illumination: multiherbal combo, Universal Complex (echinacea mix), Circu-Plus (gingko, ginseng), Mg/K aspartate, alpha-oxzyme, LSK Plus (granular liver, spleen, kidney)

Patient # 1-7
EVENT | PERIOD 1 | | | | PERIOD 2 | | | | PERIOD 3
| 1^st^ qtr 1999 – 4^th^ qtr 1999 | | | | 1^st^ qtr 2000 – 4^th^ qtr 2000 | | | | 1^st^ qtr 2001 – 4^th^ qtr 2001
Diagnosis/biopsy | | | 7/99
Surgery | | | 7/99 | | | | | | | | | 10/01
Radiation
Chemotherapy | | | 7/99
IAT | | | | 12/99 | | | | | | 6/01
CAM other | | | | 12/99 | | | | | 1/01, 2/01
Imaging CT scan | | | | | 2/00 | 5/00 | 9/00 | | 1/01, 3/01 | 5/01 | 8/01
Imaging CXR | | | | | | | 8/00
Imaging ultrasound | | | | | | | | 12/00
Tumor marker | | | | | | 5/00

Date | Description of Events | Requested | Status of request
6/28/99 | CT scan of pelvis: 3.5cm cystic left adnexal mass | Films | Rcvd.
7/1/99 | Exploratory laparoscopy with excision of left pelvic mass, left colectomy, colostomy, omentectomy, multiple peritoneal biopsies.
7/1/99 | Pathology: Ovarian carcinoma vs. malignant melanoma
7/23/99 | CA 125 = 22 (<35)
7/28/99 | Taxol, carboplatin (initially diagnosed with ovarian cancer)
7/28/99 | Adverse event: anaphylaxis from taxol
8/5/99 | Pathology: final diagnosis: malignant mesothelioma (same tissue sample) | Slides | Pend.
8/30/99 | CT scan of pelvis: decrease in soft tissue density and fluid c/w 6/28/99 | Films | Rcvd.
9/24/99 | PET scan of whole body: no specific findings to suggest residual tumor in torso, increased activity small area in neck
2/29/00 | CT scan of abdomen and pelvis: no associated definitive soft tissue mass to suggest progression or recurrence of disease, no evidence of lymphadenopathy
5/16/00 | CA 125 = 13 (<35)
5/19/00 | CT scan of abdomen and pelvis: abdomen-no recurrent mass, no definite associated soft tissue mass effect, pelvis-increase in fluid collection L>R c/w 2/29/00.
8/10/00 | X-ray chest: normal
9/12/00 | CT scan of abdomen and pelvis: small nodular densities adj. to spleen, fluid collection right side pelvis not decr., left side extension no longer identified | Films | Not avail.
11/14/00 | Bone scan of whole body: no change c/w 2/98
11/14/00 | X-ray chest: within normal limits
12/15/00 | US RUQ: no abnormality, no change from 6/29/99
1/16/01 | CT scan of abdomen and pelvis with contrast: no bowel abnormalities, fluid collection on right side has increased to 4.5x3cm, now fluid to lower pelvis left side, findings nonspecific but recurrence possible
1/23/01 | CT scan of pelvis: increased size of 2 rounded densities in pelvis, right lateral pelvic wall 4.5x3x0.15cm
3/9/01 | CT scan of abdomen and pelvis with contrast: abdomen unremarkable, pelvis with loculated fluid collection in inferior pelvis in midline and on right, slight reduction in size
5/24/01 | CT scan of abdomen: no pathologically enlarged lymph nodes or free fluid | Films | Rcvd.
5/24/01 | CT scan of pelvis: no evidence of progressive tumor or abnormality
12/1/1999 6/6/01 | IAT 5 courses
12/1/1999-present (intermittent) | Mgn3, noni juice, colostrum, vitamin E, green tea, vitamin C, beta carotene, cat's claw, homeopathic miasms
1/30/2001-present (intermittent) | Homeopathic - not specified, Haelan (fermented soy product), cat's claw, lyperinol
2/2/2001- present (intermittent) | Illumination: multiherbal combo, Universal Complex (echinacea mix), Circu-Plus (ginko, ginseng), Mg/K aspartate, alpha-oxzyme, LSK Plus (granular liver, spleen, kidney)
8/15/01 | CT scan abdomen: no upper abdominal mass compared to 5/24/01. | Films | Rcvd.
8/15/01 | CT scan of pelvis; further reduction in small amounts of fluid. No evidence of progressive neoplasm compared with 5/24/01 | Films | Rcvd.
10/12/01 | CT scan of abdomen and CT scan of pelvis with contrast: high grade partial small bower obstruction. No discrete mass is visualized, however, there is free intraperitoneal air with an air fluid level. | Films | Rcvd.
10/17/01 | CT scan of abdomen and CT scan of pelvis with contrast: small bowel dilation slightly less prominent than previously seen, otherwise basically unchanged compared to previous examination. | Films | Rcvd.
10/24/01 | Surgery: attempted reversal of colostomy: decrease of tumor bulk based on visual inspection

### Patient #1-9 Ovarian Cyst Adenocarcinoma

#### Case 1-9

The patient in case 1-9 is a 54-year-old woman with ovarian cyst adenocarcinoma diagnosed on 5/3/80. She had a total abdominal hysterectomy with bilateral salpingo-oophorectomy with debulking at that time. Subsequently, she was referred for chemotherapy but refused due to patient preference. Her only therapy has been 34 courses of IAT from 6/3/80 to 6/12/99. In June 1987, a CT scan revealed lesions in her liver suspicious for metastatic disease. A liver biopsy was recommended, but since a needle biopsy was not possible due to adhesions, none was performed. Subsequent followup did not reveal progression of disease. A pelvic mass was noted on 8/6/00 and found to be increasing over the next year to a maximal dimension of 2.8cm × 2.8cm. An exploratory laparotomy with resection of left pelvis mass and biopsy of right pelvis was performed on 6/29/81. Pathology from the surgery was negative. Tumor markers have also been negative. Routine gynecologic care has not revealed any abnormalities. At last contact (interview, 10/09/01), the patient reported that her overall physical health was good.

Pathology

5/3/80 | Biopsy: right ovary: papillary cyst adenocarcinoma, left ovary: same diagnosis
6/29/81 | Biopsy: excision of pelvic mass—no tumor
6/14/90 | Pap smear cytology: negative for malignancy
6/12/91 | Pap smear cytology: negative for malignancy

Imaging

5/1/80 | Ultrasound: pelvis mass 9cm × 7cm
5/21/80 | Liver scan: normal
5/23/80 | Bone scan whole body: normal
8/6/80 | Ultrasound: pelvis cystic left adnexal mass 2cm × 2.5cm, no fluid in pelvis
9/24/80 | Ultrasound: pelvis cystic left adnexal mass present since 8/6/80 unchanged
12/10/80 | Ultrasound: pelvis cystic left adnexal mass present since 8/6/80 slightly smaller
1/28/81 | Bone scan whole body: new area of increased uptake left iliac crest since 5/23/80
4/20/81 | Ultrasound: pelvis cystic left adnexal mass 2.3cm unchanged c/w 12/10/80
4/22/81 | Bone scan whole body: diffuse uptake in skull; increased uptake lumbar spine consistent with osteoarthritis: no evidence of metastases
6/8/81 | Ultrasound: pelvis cystic left adnexal mass 2.8cm × 2.8cm, increased since 4/20/81
9/8/81 | Ultrasound: pelvis no adnexal mass present, no fluid present
6/1/83 | Ultrasound: pelvis no adnexal mass present, no fluid present
1/15/86 | Ultrasound: pelvis no adnexal mass present, no fluid present
6/10/87 | CT scan abdomen: suspicious for liver metastases; focal areas of low attenuation throughout liver
3/4/91 | X-ray chest no change c/w 8/9/89
5/31/91 | Mammogram breast: normal
5/27/92 | Mammogram breast: normal
8/6/1993 | MRI thoracic spine: osteoporosis

Tumor markers

5/30/90 | CA^a^-125: <7.5 (normal 0–35)
5/29/91 | CA-125: 6.3 (normal 0–35)
5/6/94 | CA-125: <8.0 (normal 0–35)
6/10/97 | CA-125 = 5.0 (0–35); CEA^b^ = 0.3 (0–3)
6/11/01 | CA-125 = 6.0 (0–35)

a CA: Cancer Antigen.

b CEA: Carcinoembrionic Antigen.

Conventional therapy

5/1/80 | Surgery: TAH/BSO with appendectomy
5/3/80 | Chemotherapy recommended: never started
6/29/81 | Surgery: exploratory laparotomy with resection of left pelvic mass and biopsy

Complementary therapy

6/3/80–6/12/99 | IAT: 34 courses over this time period; no home maintenance after 16 courses

Patient # 1-9
EVENT | PERIOD 1 | | | | PERIOD 2 | | | | PERIOD 3 | | | | PERIOD 4 | | | | PERIOD 5 | | | | PERIOD 6 | | | | PERIOD 7 | | | | PERIOD 8 | | | | PERIOD 9 | | | | PERIOD 10 | | | | PERIOD 11 | | | | PERIOD 12
| 1^st^ qtr 1980 – 4^th^ qtr 1980 | | | | 1^st^ qtr 1981 – 4^th^ qtr 1981 | | | | 1^st^ qtr 1983 – 4^th^ qtr 1983 | | | | 1^st^ qtr 1986 – 4^th^ qtr 1986 | | | | 1^st^ qtr 1987 – 4^th^ qtr 1987 | | | | 1^st^ qtr 1989 – 4^th^ qtr 1989 | | | | 1^st^ qtr 1990– 4^th^ qtr 1980 | | | | 1^st^ qtr 1991 – 4^th^ qtr 1991 | | | | 1^st^ qtr 1994 – 4^th^ qtr 1994 | | | | 1^st^ qtr 1997 – 4^th^ qtr 1997 | | | | 1^st^ qtr 1999 – 4^th^ qtr 1999 | | | | 1^st^ qtr 2001 – 4^th^ qtr 2001
Diagnosis/biopsy | | 5/80 | | | | 6/81
Surgery | | 5/80 | | | | 6/81
Radiation
Chemotherapy
IAT | | 6/80 | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | 6/99
CAM other
Imaging CXR | | | | | | | | | | | | | | | | | | | | | | | | | | | | | 3/91
Imaging ultrasound | | 5/80 | 8/80, 9/80 | 12/80 | | 4/81, 6/81 | 9/81 | | | 6/83 | | | 1/86
Imaging CT | | | | | | | | | | | | | | | | | | 6/87
Tumor markers | | | | | | | | | | | | | | | | | | | | | | | | | | 5/90 | | | | 5/91 | | | | 5/94 | | | | 6/97 | | | | | | | | 6/01
Bone scan | | 5/80 | | | 1/81 | 4/81
Pap smear | | | | | | | | | | | | | | | | | | | | | | | | | | 6/90 | | | | 6/91

Date | Description of Events | Requested | Status of requests
| Mother-carcinoma of the uterus, grandmother-lung cancer, grandfather-cancer of tongue, brother-leukemia
5/1/80 | Ultrasound: mass in pelvis 9cm × 7cm | Films | Not avail.
5/3/80 | Surgery: TAH/BSO with appendectomy
5/3/80 | Biopsy:right ovary: papillary cystadenocarcinoma ; left ovary same diagnosis | Slides | Not avail.
5/3/80 | Chemotherapy recommended: never started
5/21/80 | Liver scan: normal
5/23/80 | Bone scan whole body: normal
6/3/80–6/12/1999 | IAT: 34 courses over this time period; no home maintenance after 16 courses
8/6/80 | Ultrasound: pelvis cystic left adnexal mass 2cm × 2.5cm, no fluid in pelvis | Films | Not avail.
9/24/80 | Ultrasound: pelvis cystic left adnexal mass present since 8/6/80 unchanged
12/10/80 | Ultrasound: pelvis cystic left adnexal mass present since 8/6/80 slightly smaller
1/28/81 | Bone scan whole body: new area of increased uptake left iliac crest since 5/23/80
4/20/81 | Ultrasound: pelvis cystic left adnexal mass 2.3cm unchanged c/w 12/10/80 | Films | Not avail.
4/22/81 | Bone scan whole body: diffuse uptake in skull; increased uptake lumbar spine consistent with osteoarthritis: no evidence mets
6/8/81 | Ultrasound: pelvis cystic left adnexal mass 2.8cm × 2.8cm, increased since 4/20/81
6/29/81 | Surgery: exploratory laparotomy with resection of left pelvic mass and biopsy | Slides | Rcvd.
6/29/81 | Biopsy: excision of pelvic mass- no tumor
9/8/81 | Ultrasound: pelvis no adnexal mass present, no fluid present
6/1/83 | Ultrasound: pelvis no adnexal mass present, no fluid present
1/15/86 | Ultrasound: pelvis no adnexal mass present, no fluid present | Films | Not avail.
6/10/87 | CT scan abdomen: suspicious for liver mets; focal areas of low attenuation throughout liver | Films | Not avail.
Jun-87 | Biopsy of liver lesions recommended but not performed; needle biopsy not possible due to adhesions
5/30/90 | CA-125: <7.5 (normal 0–35)
6/14/90 | Pap smear cytology: negative for malignancy
3/4/91 | X-ray chest no change c/w 8/9/89
5/29/91 | CA-125: 6.3 (normal 0–35)
5/31/91 | Mammogram breast: normal
6/12/91 | Pap smear cytology: negative for malignancy
5/27/92 | Mammogram breast: normal
8/6/93 | MRI thoracic spine: osteoperosis
5/4/94 | CA-125: <8.0 (normal 0–35)
6/10/97 | CA-125 = 5.0 (0–35); CEA = 0.3 (0–3)
6/11/01 | CA-125 = 6.0 (0–35)
present | Routine physical exams/ serial CA-125 normal per patient during interview

### Patient #1-11 Peritoneal Mesothelioma

#### Case 1-11

The patient in case 1-11 is a 59-year-old male with a family history of breast cancer, diagnosed in May, 1980 with peritoneal mesothelioma after presenting with a history of right lower quadrant abdominal pain and dyspepsia. His work-up included a cholangiogram, upper GI series with a small bowel follow-through, and an intravenous pyelogram of the GU tract. After these tests returned normal, a small bowel obstruction was the leading diagnosis until an exploratory laparotomy revealed peritoneal mesothelioma. According to the operative report (5/8/80), there was widespread disease throughout the pelvic and abdominal cavities. A partial omentectomy was performed, and as much bulk disease was removed as possible. A second opinion was obtained at MD Anderson (6/16/80 – 6/23/80), and it was recommended that additional tissue be obtained to confirm the diagnosis of mesothelioma via electron microscopy, which was done on 6/25/80. Due to the lack of a definitive curative therapy, no specific recommendations for chemotherapy, radiation, or future surgery were made. The patient started IAT therapy on 7/22/80 and completed the course in 5/84. At last contact (interview, 9/19/01), the patient reported that his overall physical condition is very good.

Pathology

5/8/80 | Pathology of cysts on peritoneum: mesothelioma of peritoneum, multiple sites
6/25/80 | Pathology: electron microscopy: multiple cystic mesothelioma of peritoneum

Imaging

4/11/80 | IVP of GU tract: within normal limits
4/12/80 | IV cholangiogram: within normal limits
4/12/80 | UGI with SBF: within normal limits
4/14/80 | Barium enema: within normal limits
4/16/80 | CT scan of abdomen: within normal limits
4/20/80 | X-ray chest: collapse of portion LLL, air containing structure posterior to sternum; nodular density adj. to left hilum
4/22/80 | Tomogram of left lung: possible mass adjacent to hilum is “distorted branch of pulmonary artery”
5/10/80 | X-ray chest: left ventricular enlargement
5/16/80 | Bone scan of total body: within normal limits
5/17/80 | Liver and spleen scan: within normal limits

Conventional therapy

5/8/80 | Surgery: exploratory laparoscopy, excision of multiple cysts, subtotal omentectomy for palliative: most of peritoneal cavity lined with cysts. Debulking done. Tumor is cystic, grape-like, no ascites.

Complementary therapy

7/22/80–7/20/84 | IAT 16 courses

Patient # 1-11
EVENT | PERIOD 1 | | | | PERIOD 2 | | | | PERIOD 3 | | | | PERIOD 4 | | | | PERIOD 5 | | | | PERIOD 6
| 1^st^ qtr 1980 – 4^th^ qtr 1980 | | | | 1^st^ qtr 1981 – 4^th^ qtr 1981 | | | | 1^st^ qtr 1982 – 4^th^ qtr 1982 | | | | 1^st^ qtr 1983 – 4^th^ qtr 1983 | | | | 1^st^ qtr 1984 – 4^th^ qtr 1984 | | | | 1^st^ qtr 1985 – 4^th^ qtr 1985
Diagnosis/biopsy | | 5/80
Surgery | | 5/80
Radiation
Chemotherapy
IAT | | | 7/80 | | | | | | | | | | | | | | | | 7/84
CAM other
Imaging CXR | | 4/80
Imaging tomogram | | 4/80
Imaging CT scan abdomen | | 4/80
Imaging liver spleen scan | | 4/80
Imaging bone scan | | 5/80

Date | Description of Events | Requested | Status of requests
4/11/80 | IVP of GU tract: within normal limits
4/12/80 | IV cholangiogram: within normal limits
4/12/80 | UGI with SBF: within normal limits
4/14/80 | Barium enema: within normal limits
4/16/80 | CT scan of abdomen: within normal limits
4/20/80 | X-ray chest: collapse of portion LLL, air containing structure posterior to sternum; nodular density adj. to left hilum
4/22/80 | Tomogram of left lung: possible mass adjacent to hilum is “distorted branch of pulmonary artery”
5/8/80 | Exploratory laparoscopy, excision of multiple cysts, subtotal omentectomy for palliative: most of peritoneal cavity lined with cysts. Debulking done. Tumor is cystic, grape-like, no ascites.
5/8/80 | Pathology of cysts on peritoneum: mesothelioma of peritoneum, multiple sites | Slides | Not avail.
5/10/80 | X-ray chest: left ventricular enlargement
5/16/80 | Tomogram of chest: volume loss LLL, unknown etiology
5/16/80 | Bone scan of total body: within normal limits
5/17/80 | Liver and spleen scan: within normal limits
6/25/80 | Pathology: electron microscopy: multiple cystic mesothelioma of peritoneum
7/22/80–7/20/84 | IAT 16 courses

### Patient #1-19 Sigmoid Carcinoma (Dukes Stage C2)

#### Case 1-19

The patient in case 1-19 is a 50-year-old male with a family history of colon cancer. He was diagnosed with sigmoid carcinoma (Dukes stage C2) in March1985 after presenting with hematochezia, lower-left quadrant abdominal pain, and a normal CEA. Biopsies obtained during colonoscopy verified the diagnosis. He underwent a sigmoid resection, and 6 of 14 nodes were positive for metastases, but no gross residual disease was left in the abdomen. No other conventional therapy was pursued. He started IAT on 5/85 and completed 11 courses by 5/91. Serial colonoscopies have remained normal, with the last exam conducted on 9/8/00. At the last contact (interview, 10/12/01), the patient reported that his overall physical condition was excellent.

Pathology

3/18/85 | Biopsy: mucinous producing adenocarcinoma, mod well diff, associated with adenomatous polyp, sigmoid colon, 6/14 nodes positive for mets, mesocolon and mesentery of colon.
9/8/00 | Biopsy: colon polyp: no evidence of malignancy

Imaging

3/22/85 | Liver spleen scan: normal
1/8/1987 | CT abdomen pelvis: no evidence of recurrent tumor
3/27/87 | Sigmoidoscopy: normal to 25cm
9/26/88 | Colonoscopy: colon fully visualized to the cecum
4/13/89 | CT scan abdomen; normal exam, no change compared with 1/8/87
10/5/89 | Colonoscopy: normal exam
11/13/92 | Colonoscopy: no evidence of recurrent colorectal polyps or cancer
12/2/94 | Colonoscopy: normal exam
2/10/98 | Sigmoidoscopy: normal to 40cm, normal anastamosis
5/7/98 | Colonoscopy: normal exam
7/27/99 | Sigmoidoscopy: normal to 70cm
9/8/00 | Colonoscopy: sessile polyp (3mm) near anastamotic site

Tumor markers

3/17/85 | CEA^a^ <1.0 (normal)
2/25/86 | CEA <2.5 (normal)
7/8/1986 | CEA 1.9 (normal<2.5)
2/1/1987 | CEA 1.8 (normal)
7/14/87 | CEA 1.1 (normal <2.5)
3/9/88 | CEA 1.9 (normal<2.5)
4/24/89 | CEA 1.2 (normal)
10/4/89 | CEA 2.0 (normal)
9/26/90 | CEA 1.4 (normal)

a Carcinoembryonic Antigen.

Conventional therapy

3/18/85 | Surgery: sigmoid resection

Complementary therapy

5/21/85–5/7/91 | IAT 11 courses

Patient # 1-19
EVENT | PERIOD 1 | | | | PERIOD 2 | | | | PERIOD 3 | | | | PERIOD 4 | | | | PERIOD 5 | | | | PERIOD 6 | | | | PERIOD 7 | | | | PERIOD 8 | | | | PERIOD 9 | | | | PERIOD 10 | | | | PERIOD 11 | | | | PERIOD 12
| 1^st^ qtr 1985 – 4^th^ qtr 1985 | | | | 1^st^ qtr 1986 – 4^th^ qtr 1986 | | | | 1^st^ qtr 1987 – 4^th^ qtr 1987 | | | | 1^st^ qtr 1988 – 4^th^ qtr 1988 | | | | 1^st^ qtr 1989 – 4^th^ qtr 1989 | | | | 1^st^ qtr 1990 – 4^th^ qtr 1990 | | | | 1^st^ qtr 1991– 4^th^ qtr 1991 | | | | 1^st^ qtr 1992 – 4^th^ qtr 1992 | | | | 1^st^ qtr 1994 – 4^th^ qtr 1994 | | | | 1^st^ qtr 1998 – 4^th^ qtr 1998 | | | | 1^st^ qtr 1999 – 4^th^ qtr 1999 | | | | 1^st^ qtr 2000 – 4^th^ qtr 2000
Diagnosis/biopsy | 3/85 | | | | | | | | | | | | | | | | | | | | | | 9/90
Surgery | 3/85
Radiation
Chemotherapy
IAT | | 5/85 | | | | | | | | | | | | | | | | | | | | | | | | 5/91
CAM other
Imaging CT scan | | | | | | | | | 1/87 | | | | | | | | | 4/89
Colonoscopy | | | | | | | | | | | | | | | 9/88 | | | | | 10/89 | | | | | | | | | | | | 11/92 | | | | 12/94 | | 5/98 | | | | | | | | | 9/00
Sigmoidoscopy | | | | | | | | | 3/87 | | | | | | | | | | | | | | | | | | | | | | | | | | | | 2/98 | | | | | | 7/99
Tumor markers | 3/85 | | | | 2/86 | | 7/86 | | 2/87 | | 7/87 | | 3/88 | | | | | 4/89 | | 10/89 | | | 9/90
Liver spleen scan | 3/85

Date | Description of Events | Requested | Status of requests
| Family history of colon cancer in uncle
3/17/85 | CEA <1.0 (normal)
3/18/85 | Biopsy: mucinous producing adenocarcinoma, mod well diff, associated with adenomatous polyp, sigmoid colon, 6/14 nodes positive for mets, mesocolon and mesentery of colon. | Slides | Rcvd.
3/18/85 | Surgery: sigmoid resection | Oper. Rpt. | Not avail.
3/22/85 | Liver spleen scan: normal
5/21/85–5/7/91 | IAT 11 courses
2/25/86 | CEA <2.5 (normal)
7/8/86 | CEA 1.9 (normal<2.5)
1/8/87 | CT abdomen pelvis: no evidence of recurrent tumor | Films | Not avail.
2/1/87 | CEA 1.8 (normal)
3/27/87 | Sigmoidoscopy: normal to 25cm
7/14/87 | CEA 1.1 (normal <2.5)
3/9/88 | CEA 1.9 (normal<2.5)
9/26/88 | Colonoscopy: colon fully visualized to the cecum
4/13/89 | CT scan abdomen; normal exam, no change compared with 1/8/87 | Films | Not avail.
4/24/89 | CEA 1.2 (normal)
10/4/89 | CEA 2.0 (normal)
10/5/89 | Colonoscopy: normal exam
9/26/90 | CEA 1.4 (normal)
11/13/92 | Colonoscopy: no evidence of recurrent colorectal polyps or cancer
12/2/94 | Colonoscopy: normal exam
2/10/98 | Sigmoidoscopy: normal to 40cm, normal anastamosis
5/7/98 | Colonoscopy: normal exam
7/27/99 | Sigmoidoscopy: normal to 70cm
9/8/00 | Colonoscopy: sessile polyp (3mm) near anastamotic site
9/8/00 | Biopsy: colon polyp: no evidence of malignancy | Slides | Rcvd.

### Patient #1-22 Squamous Cell Carcinoma of the Tongue

#### Case 1-22

The patient in case 1-22 is an 80-year-old male who was diagnosed in February 1999 with squamous cell carcinoma of the tongue accompanied by a benign parotid cyst. He subsequently completed the recommended course of radiation. Definitive surgery was recommended, but the patient refused, due to personal preference. IAT was initiated in June 1999, and he continues on maintenance therapy today. An MRI in October 2001 revealed no evidence of a discrete mass in the oropharynx and a decrease in right cervical lymph node. At the last contact (interview, 9/26/01), the patient reports that his overall physical condition is good.

Pathology

2/12/99 | Biopsy left side tongue: squamous cell carcinoma, invasive, moderately differentiated
2/18/99 | Biopsy (fine needle) right parotid lymph node: cystic contents; inconclusive
4/20/99 | Biopsy (fine needle) right parotid lymph node: abscess with Strep species, acute suppurative inflammation with cocci
5/6/99 | Biopsy aspiration of cyst in right parotid lymph node: cyst contents; acute inflammation

Imaging

2/17/99 | CT scan left neck and tongue: invasive carcinoma of tongue extends to tonsillar fossa, parapharyngeal space, and beyond inferior margin of mandible into cervical subcutaneous tissue: large contralateral node metastasis
2/25/99 | MRI of neck: ill-defined enhancing mass at base of tongue with extension into left piriformis sinus, highly suspicious for squamous cell carcinoma; cystic structure in submandibular space/ jugulodiagastric space
3/4/99 | MRI neck: 2.26cm × 3.60cm × 3.50cm enhancing mass base of left tongue extending into hypopharynx, to level of epiglottis piriformis sinus; no extension past midline; cystic structure 3.2cm × 6.5cm × 7.80cm in jugulodiagastric region
12/8/99 | CT scan neck: Resolution of left tongue base/lateral pharyngeal mass; pleomorphic adenoma or necrotic lymph node (right parotid cystic mass)
4/7/00 | X-ray chest: emphysematous changes, otherwise normal
4/7/00 | MRI of brain: normal
6/14/00 | CT scan abdomen: bilateral lower lobe fibrosis consistent with UIP; possible nephrolithiasis involving left kidney
7/11/00 | CT scan thorax: linear interstitial fibrosis consistent with UIP; bilateral apical fibrosis
7/23/00 | CT scan neck: low attenuation of lesion on along right anterior border of right parotid gland; 2.2cm × 2.3cm; suspicious for metastatic necrotic lymph node
10/3/01 | CT scan chest: bilateral interstitial lung disease
10/3/01 | MRI neck: no evidence of discrete mass in oropharynx or oral cavity. Diffuse enhancement in dorsal aspect of hypopharynx could represent post-radiation changes. Interval decrease in right lymph node now measures 1.2cm

Conventional therapy

3/5/99–4/15/99 | Radiation: upper neck, total rads 7200: 30 fractions over 41 days: completed full course: residual disease present after radiation

Complementary therapy

6/22/99-present | IAT (5 courses); still on maintenance therapy

Patient # 1-22
| PERIOD 1 | | | | PERIOD 2 | | | | PERIOD 3
EVENT | 1^st^ qtr 1999 – 4^th^ qtr 1999 | | | | 1^st^ qtr 2000 – 4^th^ qtr 2000 | | | | 1^st^ qtr 2001 – 4^th^ qtr 2001
Diagnosis/biopsy | 2/99, 2/99 | 4/99, 5/99
Surgery
Radiation | | 3/99
Chemotherapy
IAT | | | 6/99
CAM other
Imaging CT scan | 2/99 | | | 12/99 | | | 6/00, 7/00 | | | | | 10/01
Imaging CXR
Imaging MRI | 2/99, 3/99 | 4/99 | | | | | | | | | | 10/01

Date | Description of Events | Requested | Status of requests
2/12/99 | Biopsy left side tongue: squamous cell carcinoma, invasive, moderately differentiated | Slides | Pend.
2/17/99 | CT scan left neck and tongue: invasive carcinoma of tongue extends to tonsillar fossa, parapharyngeal space, and beyond inferior margin of mandible into cervical subcutaneous tissue: large contralateral node | Films | Pend.
2/18/99 | Biopsy (fine needle) right parotid lymph node: cystic contents; inconclusive
2/25/99 | MRI of neck: ill-defined enhancing mass at base of tongue with extension into left piriformis sinus, highly suspicious for squamous cell carcinoma; cystic structure in submandibular space/ juglodiagastric space
2/25/99 | MRI of brain: normal
3/4/99 | MRI neck: 2.26cm × 3.60cm × 3.50cm enhancing mass base of left tongue extending into hypopharynx, to level of epiglottis piriformis sinus; no extension past midline; cystic structure 3.2cm × 6.5cm × 7.80cm in juglodiagastric region
2/18/99 | Definitive surgery recommended: patient refused
3/4/99 | MRI neck: 2.26cm × 3.60cm × 3.50cm enhancing mass base of left tongue extending into hypopharynx, to level of epiglottis piriformis sinus; no extension past midline; cystic structure 3.2cm × 6.5cm × 7.80cm in
4/20/99 | Biopsy (fine needle) right parotid lymph node: abscess with Strep species, acute suppurative inflammation with cocci
5/6/99 | Biopsy aspiration of cyst in right parotid lymph node: cyst contents; acute inflammation
3/5/99–4/15/99 | Radiation: upper neck total rads 7200: 30 fractions over 41 days: completed full course: residual disease present after radiation | Rpt. After treatment | Pend.
12/8/99 | CT scan neck: Resolution of left tongue base/lateral pharyngeal mass.pleomorphic adenoma or necrotic lymph node (right parotid cystic mass) | Films | Pend.
4/7/00 | X-ray chest: emphysematous changes, otherwise normal
4/7/00 | MRI of brain: normal
6/14/00 | CT scan abdomen: bilateral lower lobe fibrosis consistent with UIP; possible nephroliathiasis involving left kidney
7/11/00 | CT scan thorax: linear interstitial fibrosis consistent with UIP; bilat apical fibrosis
7/23/00 | CT scan neck: low attenuation of lesion on along right anterior border of right parotid gland; 2.2cm × 2.3cm; suspicious for metastatic necrotic lymph node
10/3/01 | CT scan chest: bilateral interstitial lung disease | Films | Pend.
10/3/01 | MRI neck: no evidence of discrete mass in oropharynx or oral cavity. Diffuse enhancement in dorsal aspect of hypopharynx could represent post-radiation changes. Interval decrease in right lymph node now measures 1.2cm | Films | Pend.

### Patient #2-10 Pancreatic Cancer Involving the Bile Duct

#### Case 2-10

The patient in case 2-10 was a 55 year-old female with pancreatic cancer involving the bile duct. Her diagnosis was made in July 1999, after presenting with low back pain and a gastrointestinal bleed. No conventional therapy was pursued, as she was considered terminally ill at the time of her diagnosis and palliative drainage. Naltrexone was initiated on 11/11/99, and by July 2000, a CT scan showed a 90% reduction of her tumor mass. On August 8, 2000, she died from overwhelming septicemia, after three episodes of gram-negative sepsis secondary to loosening of her biliary stent. According to next of kin, no autopsy was performed.

Pathology

7/1/99 | Biopsy of body of pancreas; carcinoma of pancreas (per physician's notes)

Imaging

Jul-00 | CT scan abdomen: residual pancreatic lesions <1cm: 90% reduction of tumor mass; per physician's notes

Liver enzymes

10/22/99 | Alk Phos- 1646; ALT 93; AST 159
10/23/99 | Alk Phos- 1471; ALT 74; AST 108
11/21/99 | Alk Phos- 2262; ALT 126; AST 180

Conventional therapy

7/1/99 | Laparoscopy
Dec-99 | Metenkephalin IV

Complementary therapy

11/11/99 | Naltrexone 3mg qHS

Outcome

8/5/00 | Death—due to septicemia secondary to loosened stent in bile duct

Patient # 2-10
| PERIOD 1 | | | | PERIOD 2
EVENT | 1^st^ qtr 1999 – 4^th^ qtr 1999 | | | | 1^st^ qtr 2000 – 4^th^ qtr 2000
Biopsy/diagnosis | | 7/99
Surgery | | 7/99
Radiation
Chemotherapy
Naltrexone
Imaging CT scan | | | | | | | 7/00
Liver enzymes | | | | 10/99, 10/99, 11/99
Death | | | | | | | 8/00

Date | Description of Events | Requested | Status of requests
7/1/99 | Laparoscopy; diagnosis of pancreatic cancer per physician's notes | Slides | Pend.
10/22/99 | Alk Phos- 1646; ALT 93; AST 159
10/23/99 | Alk Phos- 1471; ALT 74; AST 108
11/21/99 | Alk Phos- 2262; ALT 126; AST 180
11/11/99 | Naltrexone 3mg qHS
Dec-99 | Metenkephalin IV
Jul-00 | CT scan abdomen: residual pancreatic lesions <1cm: 90% reduction of tumor mass; per physician's notes | Films | Pend.
8/5/00 | Death--due to septecemia secondary to loosened stent in bile duct

### Patient #2-21 Melanoma

#### Case 2-21

The patient in case 2-21 is a 67-year-old male who was diagnosed with melanoma in July 1996. The melanoma was resected from his right shoulder at that time, and no further therapy, other than close surveillance, was recommended. In April 1998, a lymph node dissection of his right axilla revealed metastatic disease in 1 of 15 lymph nodes. No conventional therapy was pursued. After presenting in August 1999 with proprioceptive changes in his left lower extremity, he had an MRI that showed a small brain lesion. This proved in fact to be a small bleed. During the course of 1999, the patient reported trying but not sustaining treatment with a variety of alternative therapies (see below). Also, he reported participating in a vaccine trial. Naltrexone was initiated in January 2000. At the last contact (interview, 10/10/2000), the patient reported that his overall physical condition was very good.

Pathology

7/23/96 | Pathology from excision: malignant melanoma focally filling to papillary dermis (level III), vertical thickness 0.78mm. No abnormal melanocytes at margins of specimen
9/10/99 | Biopsy brain: revealed no evidence of malignancy (per patient report)

Imaging

4/15/98 | CT scan brain, chest, abdomen, and pelvis: no evidence of metastasis
8/1/99 | MRI brain: proprioceptive changes in left lower calf and foot: diagnosed with cranial metastasis (per patient report) (this proved to be incorrect as the patient was later diagnosed to have had a small bleed

Conventional therapy

7/23/96 | Surgical excision of pigmented skin lesion on right shoulder
8/13/96 | Surgical excision after melanoma diagnosis confirmed
4/1/98 | Surgery: lymph nodes: 1 of 15 nodes positive for malignancy
1999 | Clinical trial: vaccinia melanoma cell lysates (VMCL) (per patient report)

Complementary therapy

1/00-present | Started Naltrexone 4.5mg
1999 | Melatonin 3mg q.d. MVI q.d.; antioxidant q.d.; green tea; ginseng; vegetarian diet; selenium; milk thistle; pancreatic enzymes

Patient # 2-21
EVENT | PERIOD 1 | | | | PERIOD 2 | | | | PERIOD 3 | | | | PERIOD 4 | | | | PERIOD 5 | | | | PERIOD 6
| 1^st^ qtr 1996 – 4^th^ qtr 1996 | | | | 1^st^ qtr 1997 – 4^th^ qtr 1997 | | | | 1^st^ qtr 1998 – 4^th^ qtr 1998 | | | | 1^st^ qtr 1999 – 4^th^ qtr 1999 | | | | 1^st^ qtr 2000 – 4^th^ qtr 2000 | | | | 1^st^ qtr 2001 – 4^th^ qtr 2001
Biopsy/diagnosis | | | 7/96 | | | | | | | | | | | | 9/99
Surgery | | | | 7/96, 8/96 | | | | | | 4/98
Radiation
Chemotherapy
Clinical trial | | | | | | | | | | | | | 1999
Naltrexone | | | | | | | | | | | | | | | | | 1/00
CAM other | | | | | | | | | | | | | 1999
Imaging-MRI brain
Imaging-CT scan abdomen | | | | | | | | | | 4/98 | | | | | 8/99

Date | Description of Events | Requested | Status of requests
7/23/96 | Surgical excision of pigmented skin lesion on right shoulder
7/23/96 | Pathology from excision: malignant melanoma focally filling to papillary dermis (level III), vertical thickness 0.78mm. No abnormal melanocytes at margins of specimen | Slides | Pend.
8/13/96 | Surgical excision after melanoma diagnosis confirmed
4/1/98 | Melanoma metastasized to right axilla with lymph node involvement (per patient report) | Slides | Pend.
4/15/98 | CT scan brain, chest, abdomen, and pelvis: no evidence of metastasis (per patient report) | Films | Pend.
4/1/98 | Surgery: lymph nodes: 1 of 15 nodes positive for malignancy
year '99 | melatonin 3mg qd; MVI qd; antioxidant qd; green tea; ginseng; vegetarian diet; selenium; milk thistle; pancreatic enzymes
year '99 | Clinical trial: vacinia melanoma cell lysates(VMCL) (per patient report)
8/1/99 | Proprioceptive changes in left lower calf and foot (per patient report)
8/1/99 | MRI brain: diagnosed with cranial metastasis (per patient report) | Films | Pend.
9/10/99 | Biopsy brain: revealed no evidence of malignancy (per patient report)
1/00-present | Started Naltrexone 4.5mg

### Patient #2-22 Adenocarcinoma of the Endometrium With Extension into the Peritoneum

#### Case 2-22

The patient in case 2-22 is a 58-year-old female diagnosed in May 1998 with adenocarcinoma of the endometrium with extension into the peritoneum. She completed four cycles of chemotherapy with adriamycin, cytoxan, and cisplatin. After her initial round of chemotherapy, adriamycin was withheld due to an equivocal multigated radionuclide (MUGA) scan and a past history of pericarditis. A course of radiation was completed. A CT scan (1/22/99) after chemotherapy and radiation showed a decrease in the pelvic mass. In July 1999, she was diagnosed with a second primary malignancy, intraductal carcinoma of the right breast with negative axillary nodes. Subsequent CT scans of her thorax revealed bilateral pulmonary nodules consistent with metastatic disease. She was referred to a thoracic surgeon, but a biopsy was not performed because the procedure was felt to be too difficult. She initiated Naltrexone in January 2001. In March 2001, a CT scan showed fewer abdominal and intrathoracic nodules compared to 1/3/01. A subsequent CT scan in June 2001 revealed a further reduction in peritoneal carcinomatosis. Her oncologist continues to follow her with serial CT scans. Currently, she reports her overall condition over the past week as excellent.

Pathology

5/8/98 | Biopsy endometrium: pathology- adenocarcinoma, endometroid moderately to well-differentiated with 33% invasion of the myometrium: extension into peritoneum and left pelvic sidewall
7/29/99 | Biopsy breast (right) pathology intraductal carcinoma well differentiated

Imaging

10/30/98 | CT scan 2.5cm mass in lymph nodes on left side of pelvis (MD's notes only-no full report)
1/22/99 | CT scan abdomen and pelvis: improvement in pelvic mass
4/9/99 | CT scan abdomen and pelvis: improvement in pelvic mass
5/10/00 | CT scan chest, abdomen, and pelvis: no abdominal or pelvic lesion. No evidence of metastatic disease. 1cm inguinal node unchanged
8/2/00 | CT scan chest compared to 5/10/00 upper lobe anterior segment nodule 10mm; 3 new nodules 5mm left apex, 5mm lingula, 7mm right middle lobe. Progression of metastatic disease
9/29/00 | CT scan chest: no adenopathy (mediastinal)-multiple small nodules; no change c/w 8/2/00
11/9/00 | CT scan chest, abdomen, and pelvis: bilateral pulmonary nodules some cavitated. New peritoneal carcinomatosis
3/14/01 | CT scan chest, abdomen, and pelvis: compared to 1/3/01; abdominal and intrathoracic nodules decrease in number
6/11/01 | CT scan chest, abdomen, and pelvis: compared to 3/14/01; no new adenopathy, interval decrease in peritoneal carcinomatosis. Small superior mediastinal lymph node unchanged

Conventional therapy

7/15/98–9/24/98 | Chemotherapy: cisplatin and AC; adriamycin held due to equivocal MUGA scan; four cycles
11/9/98–12/24/98 | Radiation: 5400 cGy to para-aortic lymph nodes; CT scan on 1/22/99 showed improvement of pelvic mass
9/1/1999 | Surgery: lumpectomy with sentinel node dissection: 1.7cm with clear margins and lymph nodes: ER + PR positive

Complementary therapy

1/9/01 | Naltrexone 4.5mg daily

Patient # 2-22
| PERIOD 1 | | | | PERIOD 2 | | | | PERIOD 3 | | | | PERIOD 4
EVENT | 1^st^ qtr 1998 – 4^th^ qtr 1998 | | | | 1^st^ qtr 1999 – 4^th^ qtr 1999 | | | | 1^st^ qtr 2000 – 4^th^ qtr 2000 | | | | 1^st^ qtr 2001 – 4^th^ qtr 2001
Diagnosis/biopsy | | 5/98 | | | | | 7/99
Surgery | | | | | | | 9/99
Radiation | | | | 11/98–12/98
Chemotherapy | | 7/98 | 9/98
Naltrexone | | | | | | | | | | | | | 1/01
CAM other
Imaging CXR
Imaging tomogram
Imaging CT scan | | | | 10/98 | 1/99 | 4/99 | | | | 5/00 | 8/00. 9/00 | 11/00 | 3/01 | 6/01

Date | Description of Events | Requested | Status of Requests
5/8/98 | Biopsy endometrium: pathology- adenocarcinoma, endometroid moderately to well-differentiated with 33% invasion of the myometrium: extension into peritoneum and left pelvic sidewall | Slides | Pend.
7/15/98–9/24/98 | Chemotherapy: cisplatin and AC; adriamycin held due to equivocal MUGA scan
10/30/98 | CT scan 2.5cm mass in lymph nodes on on left side of pelvis (MD's notes only--no full report) | Films | Pend.
11/9/98–12/24/98 | Radiation: 5400 cGy to para-artic lymph nodes; CT scan on 1/22/99 showed improvement of pelvic mass
1/22/99 | CT scan abdomen and pelvis: improvement in pelvic mass | Films | Pend.
4/9/99 | CT scan abdomen and pelvis: improvement in pelvic mass | Films | Pend.
7/29/99 | Biopsy breast (right) pathology intraductal carcinoma well differentiated | Slides | Pend.
9/1/99 | Surgery: lumpectomy with sentinel node dissection: 1.7cm with clear margins and lymph nodes: ER + PR positive
5/10/00 | CT scan chest, abdomen, and pelvis: no abdominal or pelvic lesion. No evidence of metastatic disease. 1cm inguinal node unchanged. | Films | Pend.
8/2/00 | CT scan chest compared to 5/10/00 upper lobe anterior segment nodule 10mm; 3 new nodules 5mm left apex, 5mm lingula, 7mm right middle lobe. Progression of metastatic disease
9/29/00 | CT chest: no adenopathy (mediastinal)-multiple small nodules; no change c/w 8/2/00
11/9/00 | CT chest, abdomen, and pelvis: bilateral pulmonary nodules, some cavitated. New peritoneal carcinomatosis | Films | Pend.
1/9/01 | Naltrexone 4.5mg daily
3/14/01 | CT scan chest, abdomen, and pelvis: compared to 1/3/01; abdominal and intrathoracic nodules decrease in number | Films | Pend.
6/11/01 | CT scan chest, abdomen, and pelvis: compared to 3/14/01; no new adenopathy, interval decrease in peritoneal carcinomatosis. Small superior mediastinal lymph node unchanged | Films | Pend.