# Appendix E: Additional Cases Reviewed

## Rejected IAT Cases (E-1)

Rejected IAT Cases

NAME | DIAGNOSIS | REASON FOR REJECTION
1-R | Adenocarcinoma of the rectum | Definitive surgery
2-R | Carcinoma of the bladder | Care not received in North America (France)
3-R | Breast carcinoma right and left | Multiple recurrences; more than IAT for chemotherapy
4-R | Ductal carcinoma of breast | No records
5-R | Bladder cancer | Incomplete record
6-R | Large-cell lymphoma | Incomplete record
7-R | Squamous cell carcinoma, metastatic-primary unknown; possibly tongue | Poor response to therapy
8-R | Squamous cell carcinoma of chest | Progression of disease on IAT treatment
9-R | Ductal carcinoma of breast, 1 of 12 nodes positive | Probable definitive therapy (surgical excision)
10-R | Carcinoma of the right breast | Definitive surgery 1979; metastases on IAT
11-R | Carcinoma of the bladder | Definitive surgery
12-R | Adenocarcinoma of the prostate | Inadequate documentation - possible
13-R | Ductal carcinoma of breast | Long survival but possible curative surgery
14-R | Gastroesophageal cancer | Current patient; insufficient followup
15-R | Ductal carcinoma of both breasts '87, recurrence on left 5/00 | Definitive therapy (surgical), relapse, other CAM
16-R | Squamous cell carcinoma, floor of mouth | Incomplete record
17-R | Malignant sarcoma | Long survivor; eventually died of the disease
18-R | Squamous cell carcinoma of lung | Progression of disease on IAT treatment
19-R | Astrocytoma | Prolonged survival but poor functional outcome
20-R | Endometrial adenocarcinoma | Recurrence on IAT
21-R | Malignant mesothelioma of the chest | Care not received in North America (Austria)
22-R | Adenocarcinoma of the breast | Definitive surgery—node negative
23-R | Poorly differentiated squamous cell carcinoma of nasopharanyx | Recent start on IAT; insufficient time for followup
24-R | Adenocarcinoma of unknown primary | Lived longer than expected time, but progressed on treatment
25-R | Adenocarcinoma of the prostate | Incomplete record
26-R | Bronchsarcoma protruberans of face | Multiple recurrences; surgery and local excision
27-R | Adenocarcinoma of the pancreas | Progression of disease on IAT treatment
28-R | Adenocarcinoma of the caecum | Progression of disease on IAT treatment
29-R | Breast carinoma, left | Possible curative resection; no measurable disease to follow
30-R | Carcinoma of the left breast | Confounding conventional therapy
31-R | Lymphocytic lymphoma | Progression of disease on IAT treatment
32-R | Sq. cell carcinoma left vocal cord 5/80, rectal carcinoma 10/90, liver angiosarcoma 9/00 | Incomplete record
33-R | Ductal carcinoma of breast | Progression of disease on IAT treatment
34-R | Carcinoma of colon to local nodes | Long survival but possible curative surgery
35-R | Adenocarcinoma of breast | Long survival but extensive conventional therapy
36-R | Squamous cell carcinoma of anum | Definitive surgery
32-R | Small cell carcinoma of the lung | Second primary (adenocarcinoma of breast) on treatment; confounding conventional and unconventional therapy
33-R | Adenocarcinoma of the colon | Long survivor, but questionable documentation of liver metastases; second primary (prostate) developed on treatment
34-R | Metastatic malignant melanoma | Progression of disease on IAT treatment
35-R | Clear cell carcinoma of the kidney | Stabilization of metastatic disease—variable by report. Confounding CAM therapy

## Other IAT Cases Reviewed E-2 Patient #1-2

Date | Description of Events
4/19/89 | Biopsy rectum (colonoscopy): infiltrating adenocarcinoma
5/3/89 | Surgery: transphincter local excision: tumor margin not clear
5/8/89 | Biopsy rectum (surgery): in situ and infiltrating adenocarcinoma moderately differentiated - tumor at margin
5/22/89 | Chemotherapy: 5-FU, leucovorin
6/5/89 | Selenium, bioflavinoid, vitamin C, vitamin A, vitamin E
8/18/89 | CT scan abdomen: thickening distal rectal wall: bilateral hydronephrosis: lucent mass 3.8cm × 2cm
8/28/89 | Surgery: Abdomino-peritoneal resection with permanent colostomy
8/30/89 | Biopsy ano-rectum (surgery): no residual carcinoma; margins clear; negative lymph node
11/12/89 | X-ray chest: normal
11/28/89 | CT scan abdomen/pelvis: irregular soft tissue mass 4.4cm; resolution of hydronephrosis
12/6/89 | Biopsy: needle aspirate: malignant adenocarcinoma
3/22/90 | CT scan abdomen/pelvis: mass 4.56cm × 3.35cm in rectal fossa: no change since 11/28/89
3/22/90 | CEA 1.1 ( normal < 5)
3/28/90 | Bone scan: whole body: normal
| Radiation: stopped early due to radiation cystitis (written in report 9/29/89)
9/25/90 | CT scan abdomen/pelvis: decrease in sacral mass (slight) 4.2 cm × 2.7cm)
11/8/90 | AMAS 213mg/ml (normal < 134)
3/6/91 | AMAS 219mg/ml (normal < 134)
4/30/91 | X-ray chest: normal
4/30/91 | CT scan abdomen/pelvis: increase in size of mass from 9/90, tumor vs. inflammation
8/6/91 | MRI pelvis: thickening of left levator ani muscle
9/17/91 | AMAS 116mg/ml (normal < 134)
12/18/91 | MRI pelvis: no recurrence of tumor
12/19/91 | MRI abdomen: normal
3/11/92 | AMAS 162mg/ml (normal < 134)
3/19/92 | X-ray chest: no evidence of metastatic disease
8/18/92 | AMAS 130mg/ml (normal < 134)
1/5/93 | MRI pelvis: no recurrence or spread of tumor
1/5/93 | MRI abdomen: no adenopathy
11/11/93 | AMAS normal
11/19/93 | MRI pelvis: no interval change
11/19/93 | MRI abdomen: no change; unremarkable MRI
12/12/94 | MRI abdomen: no change
5/24/95 | AMAS 137 mg/ml (normal < 134)
6/8/95 | MRI abdomen: bilateral renal cysts
6/8/95 | MRI pelvis: no interval change; normal study
6/22/95 | CEA 0.8 ( normal < 5.0)
10/17/95 | AMAS 104 mg/ml (normal < 134)
12/26/95 | MRI abdomen: no change
12/26/95 | MRI pelvis: no change
7/2/96 | AMAS normal
9/30/96 | X-ray c-spine: spondylotic changes
6/28/96 | MRI pelvis: no tumor recurrence
6/28/96 | MRI abdomen: no adenopathy
9/17/96 | MRI brain lacunar infarcts; periatrial ischemic changes
5/13/97 | CEA 0.9 ( normal < 5.0)
5/30/97 | AMAS normal
12/30/97 | AMAS 104 mg/ml (normal < 134)
10/8/97–5/11/01 | IAT 8 courses

## Additional Case Reviewed Patient #1-5

Date | Description of Events
04/30/79 | Renal IVP: duplicate left collecting system, dilated right upper pole collecting system, irregular bladder wall
05/09/79 | Renal US: large solid mass in right kidney
05/10/79 | Renal arteriogram: mass lesion at lower pole of right kidney
05/11/79 | Bone scan of whole body: within normal limits
05/17/79 | Right kidney biopsy: well-differentiated adenocarcinoma with focal extension through the renal capsule
05/17/79 | Surgery: right nephrectomy
10/01/79 | Bone scan of whole body: right kidney absent
12/07/79 | CT scan of abdomen: 3.5cm low density area at posterior right lobe of liver
01/18/80 | CT scan of abdomen with contrast: no change in low density area in posterior right hepatic lobe
01/18/80 | X-ray chest: within normal limits
06/25/80 | Bone scan of whole body: right nephrectomy
06/25/80 | Renal arteriogram: s/p nephrectomy, no evidence of residual tumor at excision site
06/27/80 | CT scan of abdomen: enhancing lesion in right lobe, second area seen
09/29/80 | X-ray chest: within normal limits
09/29/80 | Liver US: 3 solid lesions in right lobe of liver 3.6cm largest, 2cm other 2 lesions
10/13/80 | CT scan of abdomen: retroperitoneal mass in area of right pedicle, low density areas in liver
01/08/82 | CT scan of abdomen with contrast: mass at posterior of right lobe of liver decreased 3-2.4cm, 4.9cm mass in right renal pedicle decreased to 4cm
03/21/83 | CT scan of abdomen with contrast: enhancing hypodense masses in liver, no change
04/09/84 | CT scan of abdomen: multiple hypodense areas in right lobe of liver 2–3.5cm, recurrent mass medial and inferior to site of nephrectomy
10/24/84 | CT scan of abdomen: absent right kidney
10/25/84 | Bone scan of whole body: within normal limits
05/01/89 | CT scan of abdomen: double collecting system on left, 3 low density lesions in right lobe of liver, no change since 1984
06/19/92 | CT scan of abdomen with contrast: metastatic disease to liver, multiple masses (5–6), largest at right lobe of liver 2cm
07/13/94 | CT scan of abdomen and pelvis with contrast: 4 lesions at right lobe of liver, largest 3cm presumed not metastatic
06/19/97 | CT scan of abdomen 5–6 low attenuation foci within liver most consistent with metastatic disease
10/28/80-present | IAT 15 courses, then yearly injections

## Additional Case Reviewed Patient #1-12

Date | Description of Events
12/28/84 | Biopsy: Left breast pathology: 8 mm well-differentiated ductal cell carcinoma with microcalcification and stromal infiltration with comedo-carcinoma features
12/28/84 | Surgery: left partial mastectomy for diagnosis and palliation.
12/28/84 | X-ray chest: within normal limits
4/18/85 | X-ray chest: within normal limits
4/19/85 | Surgery left axilla: moderately differentiated ductal cell carcinoma, 29/30 nodes positive
4/22/85 | ERA binding sites: 13.9 fmol/mg, Estradiol receptor cytosol protein 2 mg/ml; PRA binding sites 219.3 fmol/mg; Progesterone receptor cytosol protein 4 mg/ml
4/22/85 | Radiation recommended for palliation; patient refused due to personal preference
4/22/85 | Liver scan: borderline hepatomegaly
4/23/85 | Bone scan: within normal limits
7/8/86 | Bone scan: within normal limits
7/8/86 | X-ray chest: within normal limits
3/6/87 | X-ray chest
12/2/87 | Bone scan: within normal limits
12/2/87 | X-ray chest: within normal limits
5/14/85 | Vitamin C, beta carotene, vitamin E, selenium, multivitamin
5/14/85–3/3/94 | IAT 18 courses

## Additional Case Reviewed Patient #1-15A

Date | Description of Events
10/2/87 | Biopsy: vocal cord pathology: moderately differentiated squamous cell carcinoma
10/10/87 | CT scan of thorax: within normal limits
10/27/87 | CT scan of neck: thickening of the right aryepiglottic fold compatible with exophytic mass, extends posteriorly to the pharyngeal wall
10/27/87 | X-ray head and neck: single lymph node measuring <1 cm of level of vocal cords on the right
10/28/87 | Anterior laryngoscopy, tracheostomy, partial laryngectomy for palliation: cancer involving posterior and superior margins;
10/28/87 | Biopsy pathology: surgical excision larynx, posterior and superior margins have infiltrating squamous cell cancer; clean margins
11/5/87 | X-ray chest: left pleural effusion
12/30/87 | Laryngoscopy for diagnostic: no exophytic lesion inviting biopsy, but biopsy done of glandular appearing tissue near junction of right true cord and epiglottis
12/30/87 | Biopsy pathology: direct laryngoscopy of right supraglottic larynx: dysplastic changes focally present
8/23/95 | X-ray chest: within normal limits except mild atelectasis
5/28/97 | Pelvic US: no pelvic adnexal masses nor fluid collection
2/24/98 | Exploratory laparotomy with right hemicolectomy and excision of right lateral abdominal wall for diagnosis and palliation: perforation of cecal carcinoma with abscess. Intention of surgery was appendectomy. Incidentally found cancer
2/24/98 | Biopsy cecum: pathology: invasive moderately differentiated adenocarcinoma arising in association with tubulovillous adenoma, invades muscularis with perforation of colonicwall, margins clear: all 12 nodes negative
2/15/99 | Colonoscopy: anastomic right side of colon stable
3/2/99 | X-ray lumbar spine: mild osteopenia
3/3/99 | CT scan of abdomen and pelvis: no significant evidence of mass lesion
4/26/88–7/3/98 | IAT; 13 courses

## Additional Case Reviewed Patient #1-16

Date | Description of Events
1/9/81 | Surgery: tonsillectomy
1/9/81 | Biopsy: tonsil : Hodgkin's lymphoma: initially, diffuse histiocytic lymphoma after reviewed at Yale felt to be Hodgkin's disease,lymphocytic and histiocystic predominant type
1/14/81 | Biopsy: bone marrow: negative for Hodgkin's disease
1/14/81 | Chemotherapy recommended:patient refused due to patient preference; was not followed by oncologist
1/19/81–11/30/99 | IAT 19 courses

## Additional Case Reviewed Patient #1-20

Date | Description of Events
| Smoking quit at age 28
6/8/87 | Sigmoidoscopy rigid: confirm tumor presence of tumor @20–30cm
6/9/87 | Surgery: resection of colon: margins free of tumor
6/9/87 | Biopsy colon and nodes: moderately well differentiated adenocarcinoma of sigmoid colon: 3/8 pericolic nodes positive: 1/2 inferior mesenteric nodes positive
6/9/87 | No conventional therapy offered by physician; physicians chose to follow serial markers instead
9/18/87 | CEA 1 .9 ng/ml (normal < 5.0)
6/7/88–5/22/01 | IAT: 35 courses
6/9/89 | CEA 0.8 ng/ml (normal < 5.0)
10/11/89 | CEA 2.0 ng/ml (normal < 5.0)
2/8/90 | CEA 3.3 ng/ml (normal < 5.0)
10/1/90 | CEA 1.8ng/ml (normal < 5.0)
2/1/91 | CEA 1 .4 ng/ml (normal < 5.0)
7/9/92 | CEA 3.5 ng/ml (normal < 5.0)
11/19/92 | CEA 3.6 ng/ml (normal < 5.0)
3/21/93 | CEA 4.0 ng/ml (normal < 5.0)
7/21/93 | CEA 1 .9 ng/ml (normal < 5.0)
11/1/93 | CEA 3.0 ng/ml (normal < 5.0)
3/11/94 | CEA 5.3 ng/ml (normal < 5.0)
7/27/94 | CEA 4. 9 ng/ml (normal < 5.0)
3/22/95 | CEA 6.3 ng/ml (normal < 5.0)
7/26/95 | CEA 4. 8 ng/ml (normal < 5.0)
10/1/95 | CEA 7.7 ng/ml (normal < 5.0)
4/1/96 | CEA 9.5 ng/ml (normal < 5.0)
5/7/97 | CEA 8.7ng/ml (normal < 5.0)
7/1/97 | CEA 12 ng/ml (normal < 5.0)
5/3/90 | Colonscopy: normal
5/23/96 | Colonscopy: benign polyp
5/23/96 | CT scan abdomen/pelvis normal
11/18/99 | Colonscopy: normal

## Additional Case Reviewed Patient #1-21

Date | Description of Event I
1/12/78 | Biopsy stomach; normal gastric mucosa
5/16/85 | X-ray chest : right upper lobe amorphous area of increased density not well delineated on lateral view
5/28/85 | X-ray chest : changes consistent with a mass lesion right upper lobe; mild fibrotic changes
6/11/85 | Biopsy pathology: bronchial brushings: no cancer cells
6/11/85 | Bone scan full body: normal
6/11/85 | CT scan mediastinum: previously noted mass: 4–5cm against mediastinum; 1 cm lymph node and several 15mm lymph nodes present
6/12/85 | Surgery: fine needle aspiration right upper lung
6/12/85 | Biopsy pathology: lung (fine needle aspiration) large malignant cells present
6/17/85 | X-ray chest : compared to 6/12/85 right upper lung mass unchanged
6/18/85 | Surgery: right minithoracotomy
6/18/85 | Biopsy mediastinal lymph node: 2 parts: part 1-no evidence of malignancy: part 2-metastatic grade IV carcinoma
6/18/85 | X-ray chest : no pneumothorax; slight atelectasis
6/24/85–7/8/85 | Radiation right lung: 6000 RADS in 30 fractions
7/19/85 | X-ray of ankle and wrist : periosteal thickening otherwise normal
12/17/85 | X-ray chest : questionable nodule behind the heart on the left
1/5/86 | X-ray chest : irregular 3cm mass behind the heart on the right side, only change compared with 4/10/86
4/30/86 | X-ray chest : post-broncosopy - no evidence of pneumothorax
5/13/86–4/23/93 | IAT: 14 courses
6/13/86 | X-ray chest : post-radiation reduction in size of right hilar mass since 4/30/86. Large right apical mass also smaller
11/4/86 | X-ray chest : mass-like density recurrence in right hilum cannot be excluded
3/10/87 | X-ray chest : compared to 1/5/87 small density behind left border is no longer seen
4/30/88 | Biopsy pathology: bronchial brushings: no cancer cells
1/23/89 | X-ray chest : no evidence of associated bone erosion to suggest bone invasion of residual tumor
2/6/89 | X-ray chest : no suggestion of mets
7/28/89 | X-ray chest : compared with 7/26/88 significant radiation changes in apical pleural thickening
10/23/90 | X-ray chest: stable chest; no recurrence
11/25/91 | X-ray chest : unchanged from 4/9/91
4/24/92 | X-ray chest : stable exam
9/22/92 | X-ray chest : no signs of recurrence or metastasis
3/19/93 | X-ray chest : unchanged from 9/22/92
4/22/99 | Deceased from acute MI

## Additional Case Reviewed Patient #1-24

Date | Description of Events
6/3/93 | Surgery wedge biopsy of mass at right scapula for diagnosis and palliation
6/3/93 | Biopsy pathology: 18×15×5 cm pleomorphic rhabdomyosarcoma with margins free of tumor
8/93–10/93 | Radiation: 6560 cGy to right medial posterior thorax
7/24/95 | Surgery wedge biopsy of RUL of lung
7/24/95 | Biopsy pathology wedge biopsy of right upper lobe lung: metastatic pleomorphic rhabdomyosarcoma 3 cm, margins clear
2/16/96 | Biopsy pathology: rhabdomyosarcoma: 3rd interspace, posterior chest wall; RUL lung with chest wall. Multiple biopsies of chest wall and nodes negative
3/96–8/96 | Chemotherapy completed 6 cycles
1/3/97 | CT scan of chest, abdomen, pelvis: since 10/8/96, internal resection of duodenal mass, otherwise no significant change, no new disease
1/3/97 | CT scan of chest
2/19/97 | Surgery duodenectomy of 2nd and 3rd portions for palliation
4/2/97 | Surgery pancreaticoduodenectomy (pylorus sparing)--Whipple
4/14/97 | CT scan of abdomen: 1 cm simple cyst unchanged, low attenuation areas in left kidney unchanged, 2.5 cm enhancing mass in duodenum
4/14/97 | CT scan of chest, abdomen, pelvis: no evidence of local recurrence of tumor in right chest; new 2 cm enhancing intraluminal mass within the duodenum
4/14/97 | CT scan of chest: post-surgical changes, irregular soft tissue area (post-surgical) no enlarged lymph node
4/14/97 | CT scan of pelvis: unchanged
4/17/97 | Biopsy pathology: recurrent pleomorphic rhabdomyosarcoma extending into peripancreatic soft tissue, all 19 nodes negative
4/21/97 | X-ray chest: consistent with prior right lung surgery
4/22/97 | X-ray chest: post surgical changes
4/22/97 | Surgery Whipple procedure for palliation
4/22/97 | Biopsy pathology: gall bladder within normal limits
4/22/97 | X-ray abdomen: post surgical drains
4/27/97 | X-ray chest
4/27/97 | X-ray chest: new LLL opacification, right pleural effusion may be bigger
7/7/97 | CT scan of chest, abdomen, pelvis: no evidence of metastatic disease or recurrence within the chest abdomen or pelvis
9/21/98 | CT scan of chest, abdomen, pelvis: compared to 3/31/98, no new lung nodules, no significant change in abdomen and pelvis
4/19/99 | CT scan of chest, abdomen, pelvis: compared to 9/21/98, no abnormally enlarged lymph nodes in abdomen and pelvis, no recurrence or metastasis in chest or pelvis
4/19/99 | CT scan: post-operative changes right chest and abdomen, no evidence of recurrence or metastasis
4/19/99 | CEA 2.2 (<5)
4/19/99 | PSA 0.8 (<4)
3/3/97–2/23/01 | IAT
| Quality of life measure: Kavaioncy 95

## Additional Case Reviewed Patient #1-28

Date | Description of Events
| Concurrently has multiple sclerosis
| Family history of cancer: father died of acute leukemia at age 45
9/22/75 | Myelogram of posterior fossa: questionable mass in right cerebellum
9/23/75 | Scan brain: abnormal lesion in brain stem
9/23/75 | X-ray of clavus and sella turcica: no definite abnormality
9/23/75 | Arteriogram cerebral: mass in right cerebellum
9/24/75 | Surgery: right suboccipital craniotomy: discovered posterior fossa tumor
9/24/75 | Biopsy: pathology chondromatous tumor
10/6/75 | Pathology (2nd opinion on same tissue sample 9/24/75): cellular chondroma
6/24/80–4/14/89 | IAT: 14 courses
6/12/89 | Deceased

## Other Naltrexone Cases Reviewed E-3 Patient #2-1

### Case 2-1

The patient in case 2-1 is a 71-year-old female with a history of chronic lymphocytic leukemia. She was initially diagnosed in 1988, per patient report. She started chemotherapy with chlorambucil and prednisone in August 1988 and stopped early in January 1989, secondary to bone marrow suppression. The following year she was diagnosed with pulmonary histoplasmosis and was treated with five months of amphotericin B. In the fall of 1991, she was diagnosed with a recurrence of CLL and the same chemotherapy was initiated. The chemotherapy was stopped after it was determined to have no effect, and five rounds of fludarabine (a full course) was completed by June 1992. In October 1997, she was diagnosed with a recurrence and fludarabine was started and stopped after it was determined to have no effect. In March 1998, Naltrexone was initiated. In August 1998, a bone marrow biopsy revealed histoplasmosis of the bone marrow and itraconazole was initiated. Since that time she has had intravenous immune globulin and rituxan treatments. In July 2001, her physician told her there has been no improvement in her condition. At last contact (patient interview 10/10/010, the patient reports that her general health is good.

Pathology

1988 | Diagnosed with CLL (per patient report)

Imaging

None

Conventional therapy

8/88–1/89 | Chemotherapy: chlorambucil and prednisone; stopped early due to bone marrow suppression
Jan-90 | Diagnosed with pulmonary histoplasmosis: amphotericin B (5 month treatment)
fall/91 | Diagnosed with CLL recurrence
fall/91 | Chemotherapy: chlorambucil and prednisone; stopped early due to no effect
fall/91-6/92 | Chemotherapy: fludarabine completed 5 courses
Oct-97 | Diagnosed with CLL recurrence
Oct-97 | Chemotherapy: fludarabine; stopped early due to no effect
Aug-98 | Bone marrow biopsy: positive for CLL and histoplasmosis
Sep-98 | Started traconazole
9/1/1998–9/1/00 | Started rituxan weekly for four weeks over 2 years: completed treatment
2/00-present | Intravenous immune globulin treatments monthly
March 1,2001-present | Rituxan restarted
2001, July | No improvement in disease per patient's physician

Complementary therapy

1998, March | Started Natrexone 3mg qhs

Patient # 2-1
EVENT | PERIOD 1 | | | | PERIOD 2 | | | | PERIOD 3 | | | | PERIOD 4 | | | | PERIOD 5 | | | | PERIOD 6
| 1^st^ qtr 1988 – 4^th^ qtr 1988 | | | | 1^st^ qtr 1991 – 4^th^ qtr 1992 | | | | 1^st^ qtr 1997 – 4^th^ qtr 1997 | | | | 1^st^ qtr 1998 – 4^th^ qtr 1998 | | | | 1^st^ qtr 2000 – 4^th^ qtr 2000 | | | | 1^st^ qtr 2001 – 4^th^ qtr 2001
Diagnosis/biopsy | 1998
Surgery
Radiation
Chemotherapy | | | 8/88 | | | | 6/92 | | | | 10/97
Rituxan | | | | | | | | | | | | | 1998
IvIg | | | | | | | | | | | | | 1998
Naltrexone | | 3/98

Date | Description of Events
| Comorbitities: hepatitis
1998 | Diagnosed with CLL
8/88–1/89 | Chemotherapy: chlorambucil and prednisone; stopped early due to bone marrow suppression
Jan-90 | Diagnised with pulmonary histoplasmosis: amphotericin B (5 month treatment)
fall/91 | Diagnosed with CLL recurrence
fall/91 | Chemotherapy: chlorambucil and prednisone; stopped early due to no effect
fall/91-6/92 | Chemotherapy: fludarabine completed 5 courses
Oct-97 | Diagnosed with CLL recurrence
Oct-97 | Chemotherapy: fludarabine; stopped early due to no effect
Aug-98 | Bone marrow biopsy: positive for CLL and histoplasmosis
Sep-98 | Started traconazole
9/1/98–9/1/00 | Started rituxan weekly for four weeks over 2 years: completed treatment
2/00-present | IvIg threatments monthly
Mar-98 | Started Natrexone 3mg qhs
Mar 01-present | Rituxan
Jul-98 | No improvement in disease per patient's physician

## Additional Case Reviewed Patient #2-6

### Case 2-6

The patient in case 2-6 is a 56-year-old female with a history of ovarian carcinoma. She was initially diagnosed in August 1995 after a total abdominal hysterectomy with a bilateral salpingo-oopherectomy. She started chemotherapy with taxol, cysplatin, and asplax in August 1995 and six rounds were completed by December 1995. The cancer persisted and by 1998 or 1999 chemotherapy was started with doxil and topotecan, and a full course was completed. Naltrexone was initiated in September 2000. Since that time, chemotherapy was again started after metastatic disease was found in her liver. Throughout the course of her treatment, she has tried several unconventional therapies to treat her cancer, including full body hyperthermia and mistletoe. At last contact (interview on 10/09/01), the patient reports that her overall condition is very good.

Pathology

Aug-95 | Biopsy: Diagnosis of ovarian cancer in pelvis (patient reports)

Imaging

8/28/00 | CT scan abdomen compared with 9/11/98: 3.5cm cyst in posterior medial left hepatic lobe anterior to portal vein, unchanged, no sign of metastatic disease
8/28/00 | CT scan pelvis: no sign of recurrent metastatic disease
4/19/01 | CT scan chest abdomen pelvis: few tiny nodual densities bilateral axilla, 1cm nodularity right lower lobe lung (new); few tiny cysts in liver; multiple soft tissue densities in liver; pelvic cyst 3.8cm

Conventional therapy

Aug-95 | Surgery: ovarectomy and hysterectomy
8/95–12/95 | Chemotherapy: Taxol, cysplatin; and asplax 6 rounds completed
1998 or 1999 | Chemotherapy: Doxil, topotecan:11 months - completed therapy; followed by doxil 12 months-completed therapy
10/3/00 | Chemotherapy: erythrotecan and low dose taxol
2/1/01 | Surgery: laporascopy: reportedly did not reveal anything
4/19/01 | Chemotherapy: initiated due to lesions on liver presumably metastatic disease: campthzar/cysplatin

Tumor markers

Aug-95 | CA-125: 65
Aug-95 | CA-125: <35
1998 | CA-125: 200
1998 | CA-125: 110
Aug-99 | CA-125: 100
Aug-99 | CA-125: 30
7/20/01 | CA-125: 765
8/14/01 | CA-125: 135

Complementary therapy

10/97–5/98 | Acupuncture
1998 | Vitamin C and mistletoe, full body hyperthermia
9/19/00 | Naltrexone 3mg qhs up to 6.5mg qhs
12/00–4/01 | Went to Mexico had alternative cancer treatment with vaccine

Patient # 2-6
EVENT | PERIOD 1 | | | | PERIOD 2 | | | | PERIOD 3 | | | | PERIOD 4 | | | | PERIOD 5
| 1^st^ qtr 1995 – 4^th^ qtr 1995 | | | | 1^st^ qtr 1998 – 4^th^ qtr 1998 | | | | 1^st^ qtr 1999 – 4^th^ qtr 1999 | | | | 1^st^ qtr 2000 – 4^th^ qtr 2000 | | | | 1^st^ qtr 2001 – 4^th^ qtr 2001
Diagnosis/biopsy | | | 8/95
Surgery | | | 8/95 | | | | | | | | | | | | | | 2/01
Radiation
Chemotherapy | | | 8/95 | 12/95 | | | 1998 | | | | | | | | | 10/01 | 1/01 | 4/01
Naltrexone | | | | | | | | | | | | | | | 9/00
CT scan | | | | | | | | | | | | | | | 8/00 | | | 4/01
Tumor markers | | | 8/95 | | | | 1998 | | | | 8/99 | | 2000 | | | | | | 7/01
| | | | | | | | | | | | | | | | | | | 8/01
CAM other | | | | | 1998 | | | | | | | | | | | 12/00 | | 4/01

Date | Description of Events
| History of migraines, GERD
Aug-95 | Surgery: ovarectomy and hysterectomy
Aug-95 | Biopsy: Diagnosis of ovarian cancer in pelvis
Aug-95 | CA-125: 65
Aug-95 | CA-125: <35
8/95–12/95 | Chemotherapy: taxol, cysplatin; 6 rounds completed
10/97–5/98 | Acupuncture
1998 | Vitamin C and mistletoe, full body hyperthermia
1998 | CA-125: 200
1998 | CA-125: 110
1998 or 1999 | Chemotherapy: doxil, topotecan:11month- completed therapy; followed by doxil 12 months-completed therapy
Aug-99 | CA-125: 100
Aug-99 | CA-125: 30
8/28/00 | CT scan abdomen compared with 9/11/98: 3.5cm cyst in posterior medial left hepatic lobe anterior to portal vein, unchanged, no sign of metastatic disease
8/28/00 | CT scan pelvis: no sign of recurrent metastatic disease
9/19/00 | Naltrexone 3mg qhs up to 6.5mg qhs
10/3/00 | Chemotherapy: erythrotecan and low dose taxol
12/00–4/01 | Went to Mexico had alternative cancer treatment with vaccine
2/1/01 | Surgery: laporascopy: reportedly did not reveal anything
4/19/01 | CT scan chest abdomen pelvis: few tiny nodual densities bilateral axilla, 1cm nodularity right lower lobe lung (new); few tiny cysts in liver; multiple soft tissue densities in liver; pelvic cyst 3.8cm
4/19/01 | Chemotherapy: initiated due to lesions on liver presumably metastatic disease : campthzar/cysplatin
7/20/01 | CA-125: 765
8/14/01 | CA-125: 135

## Additional Case Reviewed Patient #2-14

### Case 2-14

The patient in case 2-14 is an 11-year-old female with a history of metastatic neuroblastoma of the right adrenal gland. She was initially diagnosed in February 1996. She had surgery and palliative chemotherapy from March 1996 to December 1996. Response was inadequate and the patient had a stem cell transplant in February 1997. She also received one year of therapy at the Burzinski Clinic starting in August 1997. Recurrent disease was identified in the bone marrow in February 1999. [Naltrexone was initiated in July 1999.] A second course of chemotherapy (topotecan) was initiated in August 1999 but stopped early (February 2000) due to side effects. Currently, she is paralyzed in both lower extremities due to metastatic disease and her prognosis is poor according to the next of kin (interview 10/9/01).

Pathology

11/1/97 | Biopsy: bone marrow- partial replacement of hematopoetic elements with sheets of aggregate malignant cells consistent with recurrent neuroblastoma
2/22/99 | Biopsy: bone marrow- neuroblastoma
4/5/99 | Biopsy: bone marrow- neuroblastoma
8/5/99 | Biopsy: bone marrow- partial replacement by malignant cells
8/30/99 | Biopsy: bone marrow-neuroblastoma
8/30/99 | Biopsy: bone marrow- residual, recurrent neuroblastoma
11/16/99 | Biopsy: bone marrow- residual, recurrent neuroblastoma
12/16/99 | Biopsy: bone marrow- marked decrease of platelets, trilineage hematopoesis with maturation, clusters of aggregates of malignant cells were not identified, but clot sections showed some irregular areas of fibrosis with aggregates of malignant cells consistent with metastatic neuroblastoma
2/23/00 | Biopsy: bone marrow- hypercellular for patient's age

Imaging

7/29/97 | CT scan: abdomen
3/12/99 | CT scan: chest abdomen pelvis: lesions in L2 suspicious for metastatic disease
4/5/99 | Bone scan: multiple foci of abnormal accumulation of the tracer in the sternum, thoracic spine, lumbar spine, both sacroiliac joints, and the left superior acetabular region and left anterior 11th rib
6/21/99 | Bone scan: increased uptake in right humerus, sternum, T/L spine, left SI joint
6/24/99 | CT scan abdomen/pelvis: new crural lymph node 1cm; 13mc paracaval lymph node minimally change in size with necrosis; 12mm × 11mm soft tissue density in gastric antrum which may represent a lymph node or lesion; new sclerotic lesion at T7
8/30/99 | Bone scan: whole body- stable osseous lesions
11/18/99 | Bone scans: no new lesions: T10 lesion improved: resolution of left tibial lesions
1/12/00 | CT scan: eyes: normal
1/14/00 | CT scan: abdomen/pelvis: no interval change T7, L2 vertebral lesions
2/22/00 | Bone scans: no new lesions: improved but persistent bony changes

Conventional therapy

3/1/96 | Surgery: s/p right adrenalectomy
3/1/96 | Chemotherapy- topotecan, anti-neoplasmen
2/97 | Stem cell transplant
Jun-99 | Platelet infusions-weekly
8/13/99 | Surgery: central catheter placement
8/99 – 2/00 | Chemotherapy - topotecan, stopped early due to side effects

Complementary therapy

8/97 – 98 | Burzinski clinic - anti-neoplastin therapy
7/21/99 | Naltrexone 1.5mg qhs

Patient # 2-14
EVENT | PERIOD 1 | | | | PERIOD 2 | | | | PERIOD 3 | | | | PERIOD 4 | | | | PERIOD 5 | | | | PERIOD 6
| 1^st^ qtr 1996 – 4^th^ qtr 1996 | | | | 1^st^ qtr 1997 – 4^th^ qtr 1997 | | | | 1^st^ qtr 1998 – 4^th^ qtr 1998 | | | | 1^st^ qtr 1999 – 4^th^ qtr 1999 | | | | 1^st^ qtr 2000 – 4^th^ qtr 2000 | | | | 1^st^ qtr 2001 – 4^th^ qtr 2001
Diagnosis/biopsy | | 3/96 | | | | | | 11/97 | | | | | 2/99 | 4/99 | 8/99 | 11/99,12/99 | 2/00
Surgery | | 3/96
Radiation
Chemotherapy | | 3/96
CT scan | | | | | | | 7/97 | | | | | | 3/99 | 4/99 | 6/99, 8/99 | 11/99 | 1/00, 2/00
Naltrexone | | | | | | | | | | | | | | | 7/99

Date | Description of Events
3/1/96 | Surgery: s/p right adrenalectomy
3/1/96 | Chemotherapy- topotecan, anti-neoplasmen
7/29/97 | CT scan: abdomen
11/1/97 | Biopsy: bone marrow- partial replacement of hematopoetic elements with sheets of aggregate malignant cells consistent with recurrent neuroblastoma
2/22/99 | Biopsy: bone marrow- (results ?)
3/12/99 | CT scan:chest abdome pelvis: lesions in L2 suspicious for metastatic disease
4/5/99 | Biopsy: bone marrow- (results ?)
4/5/99 | Bone scan: multiple foci of abnormal accumulation of the tracer in the sternum, thoracic spine, lumbar spine, both sacroiliac joints, and the left superior acetabular region and left anterior 11th rib
Jun-99 | Platelet infusions-weekly
6/21/99 | Bone scan: increased uptake in right humerus, sternum, T/L spine, left SI joint
6/24/99 | CT scan abdomen/pelvis: new crural lymph node 1cm ; 13mc paracaval lymph node minimally change in size with necrosis; 12mm × 11mm soft tissue density in gastric antrum which may represent a lymph node or lesion; new sclerotic lesion at T7
7/21/99 | Naltrexone 1.5mg qhs
8/5/99 | X-ray: chest- no acute cardio-pulmonary process
8/5/99 | Biopsy: bone marrow- partial replacement by malignant cells
8/13/99 | Surgery: central catheter placement
8/13/99 | X-ray: chest- no complications evident for previously described antral and porta hepatis lymph nodes
8/30/99 | Biopsy: bone marrow-neuroblastoma
8/30/99 | Bone scan: whole body- stable osseous lesions
8/30/99 | Biopsy: bone marrow- residual, recurrent neuroblastoma
11/16/99 | Biopsy: bone marrow- residual, recurrent neuroblastoma
11/18/99 | Bone scans: no new lesions: T10 lesion improved: resolution of left tibial lesions
12/16/99 | Biopsy: bone marrow- marked decrease of platelets, trilineage hematopoesis with maturation, clusters of aggregates of malignant cells were not identified, but clot sections showed some irregular areas of fibrosis with aggregates of malignant cells consistent with metastatic neuroblastoma
1/12/00 | CT scan: eyes: normal
1/14/00 | CT scan: abdomen/pelvis: no interval change T7, L2 vertebral lesions
2/22/00 | Bone scans: no new lesions: improved but persistent bony changes
2/23/00 | Biopsy: bone marrow- hypercellular for patient's age
2/17/00–7/11/2000 | Serial CBC's: improving

## Additional Case Reviewed Patient #2-16

### Case 2-16

The patient in case 2-16 is a 62-year-old male with a history of squamous cell carcinoma of the lung with level 4 cervical lymph node involvement. He was diagnosed on 3/00. He declined conventional therapy. In June 2001, he was diagnosed with ascend primary melanoma. Naltrexone was initiated in June 2001. The cancer has continued to spread, and currently the patient has left-sided hemiparesis. His prognosis is poor but the patient reported at his interview (10/16/01) that his physical condition is very good.

Pathology

3/00 | Chest biopsy: fine needle aspiration: squamous cell carcinoma
5/5/00 | Lymph node biopsy: right neck non-small cell carcinoma
5/15/00 | Chest biopsy aspiration: pathology: metastatic non-small cell carcinoma
6/15/00 | Physical exam: 3cm ×4cm hard node in right neck
10/27/00 | Physical exam: 1.75cm × 2.5cm hard node in right neck
6/14/01 | Biopsy, mid-back: pathology: melanoma in situ, closely approaching the margins
6/26/01 | Physical exam: 3cm ×4cm hard node in right neck
| Bronchoscopy: pathology: washings and brushing; negative for tumor

Imaging

2/29/00 | CT scan chest: primary tumor in RML of lung; increased hilar/peritracheal nodes
3/15/00 | CT scan: abdomen/pelvis: enlarged prostate: no evidence of metastatic disease
4/26/00 | PET scan: whole body: right-sided cervical and right mediastinal malignant adenopathy
7/28/00 | CT scan chest: extensive mediastinal lymphadenopathy: nodular densities in both lungs
11/10/00 | CT scan chest: primary tumor in RML of lung (no change); hilar/peritracheal nodes (no change)

Conventional therapy

none

Complementary therapy

6/1/01 | Naltrexone 4.5 mg QHs
| Supplements: multiple nutritional supplements, MGN3, shitake mushroom, wheat grass

Patient # 2-16
EVENT | | | | | | | | | | | | | PERIOD 1 | | | | PERIOD 2 | | | | PERIOD 3
| | | | | | | | | | | | | 1^st^ qtr 1999 – 4^th^ qtr 1999 | | | | 1^st^ qtr 2000 – 4^th^ qtr 2000 | | | | 1^st^ qtr 2001 – 4^th^ qtr 2001
Diagnosis/biopsy | | | | | | | | | | | | | | | | | 3/00 | 5/00 | | | | 6/01
Surgery
Radiation
Chemotherapy
CT scan | | | | | | | | | | | | | | | | | 2/00, 3/00 | 4/00 | 7/00 | 11/00
Naltrexone | | | | | | | | | | | | | | | | | | | | | | 6/01

Date | Description of Events
| Brother died of stomach cancer
2/29/00 | CT scan of lungs: reveals tumor and enlarged lymph nodes
| Biopsy done: results unknown
3/15/00 | CT scan of abdomen (belly) and pelvis reveals enlarged prostate
4/26/00 | PET scan reveals enlarged lymph nodes in chest
5/5/00 | Biopsy done: reveals lung cancer
5/15/00 | Biopsy done: reveals lung cancer
6/15/00 | Physical exam: hard lymph node in right neck
6/15/00 | Started Naltrexone
7/28/00 | CT scan of lungs: reveals tumor and enlarged lymph nodes
| Started supplements: multiple nutritional supplements, MGN3, shitake mushroom, wheat grass
10/27/00 | Physical exam: hard lymph node in right neck smaller compared with prior exam
11/10/00 | CT scan of lungs: reveals tumor and enlarged lymph nodes, unchanged
6/1/01 | Increased dose of Naltrexone
6/14/01 | Biopsy done on mid-back: reveals melanoma
6/26/01 | Physical exam: hard lymph node in right neck
| Exam whereby a small camera inserted into airway: Cells from exam do not reveal any cancer

## Additional Case Reviewed Patient #2-17

### Case 2-17

The patient in case 2-17 is a 68-year-old male with a history of multiple myeloma. He was diagnosed in September 1998. He has completed his first course of chemotherapy from August 1998 to October 1999. He initiated Naltrexone in January 1999. His immune globulin levels were followed closely, and showed an increase in June 2001. At that time he resumed chemotherapy with biaxin, thalidomide, and decadron. Since that time his IgG levels have decreased and at his interview (10/8/01), the patient rated his overall physical condition as good.

Pathology

9/2/98 | Biopsy bone marrow: marrow infiltrated by plasma cell c/w plasma cell myeloma

Imaging

2/15/99 | MRI: lumbar spine: nodule within cauda equina at L2; presumed to be small neuroma; chronic compression fractures in L1 and L5
6/1/99 | X-ray: pathological fracture in 4 vertebrae in 2 ribs
1/3/00 | MRI: lumbar spine: nodule at L2 unchanged: numerous punctate focal bony lesions throughout lumbar spine; presumed to represent tiny multiple myeloma deposits
6/22/00 | Bone scan: whole body: increase uptake in regions T6, T8–T10

IgG levels

12/2/98 | IgG 9290
4/14/99 | IgG 5310
5/6/99 | IgG 4130
6/3/99 | IgG 4130
6/4/99 | IgG 4180
7/14/99 | IgG 2780
8/4/99 | IgG 3100
8/30/99 | IgG 2290
10/22/99 | IgG 1260
12/5/99 | IgG 1260
1/20/00 | IgG 1400
2/17/00 | IgG 1380
3/16/00 | IgG 1500
4/11/00 | IgG 1320
5/9/00 | IgG 1280
6/8/00 | IgG 1230
7/5/00 | IgG 1240
8/2/00 | IgG 1030
9/27/00 | IgG 1550
10/26/00 | IgG 1840
11/30/00 | IgG 2030
1/2/01 | IgG 2290
1/30/01 | IgG 3110
2/21/01 | IgG 3200
3/29/01 | IgG 4520
8/1/01 | IgG 649

Conventional therapy

9/98–10/99 | Chemotherapy: AB/CM
2/99–10/99 | Chemotherapy: cytoxan, melphalan, decadron, zofran q 3weeks
6/1/01 | Chemotherapy: thalodimide, biaxin, decradron

Complementary therapy

1/29/99 | Naltrexone 4.5 mg QHs

Patient # 2-17
EVENT | PERIOD 1 | | | | PERIOD 2 | | | | PERIOD 3 | | | | PERIOD 4 | | | | PERIOD 5
| 1^st^ qtr 1995 – 4^th^ qtr 1995 | | | | 1^st^ qtr 1998 – 4^th^ qtr 1998 | | | | 1^st^ qtr 1999 – 4^th^ qtr 1999 | | | | 1^st^ qtr 2000 – 4^th^ qtr 2000 | | | | 1^st^ qtr 2001 – 4^th^ qtr 2001
Diagnosis/biopsy
Surgery
Radiation
Chemotherapy | | | | | | | 9/98 | | | | | 10/99 | | | | | | | 6/01
Naltrexone | | | | | | | | | 1/99
Imaging | | | | | | | | | 2/99 | 6/99 | | | 1/00 | 6/00
CAM other

Date | Description of Events
9/2/98 | Biopsy bone marrow: marrow infiltrated by plasma cell c/w plasma cell myeloma
9/98–10/99 | Chemotherapy: AB/CM
12/2/98 | IgG 9290
2/15/99 | MRI: lumbar spine: nodule within cauda equina at L2; presumed to be small neuroma; chronic compression fractures in L1 and L5
2/99–10/99 | Chemotherapy: cytoxan, melphalan, decadron, zofran q 3weeks
4/14/99 | IgG 5310
5/6/99 | IgG 4130
6/1/99 | X-ray: pathological fracture in 4 vertebrae in 2 ribs
6/3/99 | IgG 4130
6/4/99 | IgG 4180
7/14/99 | IgG 2780
8/4/99 | IgG 3100
8/30/99 | IgG 2290
10/22/99 | IgG 1260
12/5/99 | IgG 1260
1/3/00 | MRI: lumbar spine: nodule at L2 unchanged: numerous punctate focal bony lesions throughout lumbar spine; presumed to represent tiny multiple myeloma deposits
1/20/00 | IgG 1400
2/17/00 | IgG 1380
3/16/00 | IgG 1500
4/11/00 | IgG 1320
5/9/00 | IgG 1280
6/8/00 | IgG 1230
6/22/00 | Bone scan: whole body: increase uptake in regions T6, T8–T10
7/5/00 | IgG 1240
8/2/00 | IgG 1030
9/27/00 | IgG 1550
10/26/00 | IgG 1840
11/30/00 | IgG 2030
1/2/01 | IgG 2290
1/30/01 | IgG 3110
2/21/01 | IgG 3200
3/29/01 | IgG 4520
6/1/01 | Chemotherapy: thalodimide, biaxin, decradron
8/1/01 | IgG 649

## Additional Case Reviewed Patient #2-18

### Case 2-18

The patient in case 2-18 is a 43-year-old woman with a history of breast cancer in her mother, who was diagnosed with breast cancer in November 1997. Axillary lymph nodes at the time of diagnosis were negative. She subsequently underwent a lumpectomy and radiation. In March 2000, an MRI of the right hip revealed bone metastases. Radiation to the affected hip was completed. She was started on tamoxifen and aridia in March 2000. Naltrexone was initiated in May 2000. During her interview (10/10/01), she rated her overall condition as very good, although results of a followup scan are mixed.

Pathology

11/1/97 | Biopsy: breast cancer estrogen sensitive, nodes negative

Imaging

12/1/99 | X-ray right hip: normal
3/1/00 | MRI: brain: questionable abnormality-repeated in 8 weeks
3/1/00 | MRI hip—right femoral neck and mid-femur; right acetabulum; scattered throughout osseous of pelvis
May-00 | CT chest: normal
5/1/00 | MRI: brain: normal
9/1/00 | CT chest: negative
9/6/00 | MRI: hip - extensive metastatic involvement of right femur; patchy metastatic involvement of left femur head and neck
6/1/01 | CT scan liver had small lesions
6/1/2001–8/01 | Chemotherapy: AC completed
8/1/01 | Liver lesions remain: oncologist monitoring
10/22/01 | CT scan of chest abdomen and pelvis. Decrease nodularity at anterior mediastinum. Probable improvement in hepatic lesions, probable healing and improvement in some bony metastases with exacerbation of others

Tumor markers

Mar-00 | CA 2729: 650
5/11/00 | CEA 3.6 (0–5)
12/1/00 | CA 2729: 79

Conventional therapy

11/1/97 | Surgery: lumpectomy breast
6/1/98 | Radiation: right breast and right axilla: adverse effects—radiation edema
Mar-00 | Radiation: pelvis: adverse effects—on crutches since 4/1/00
3/15/00 | Started tamoxifen 10mg bid and aridia

Complementary therapy

5/13/2000-present | Naltrexone

Patient # 2-18
EVENT | PERIOD 1 | | | | PERIOD 2 | | | | PERIOD 3 | | | | PERIOD 4 | | | | PERIOD 5
| 1^st^ qtr 1997 – 4^th^ qtr 1997 | | | | 1^st^ qtr 1998 – 4^th^ qtr 1998 | | | | 1^st^ qtr 1999 – 4^th^ qtr 1999 | | | | 1^st^ qtr 2000 – 4^th^ qtr 2000 | | | | 1^st^ qtr 2001 – 4^th^ qtr 2001
Biopsy/diagnosis | | | | 11/97
Surgery | | | | 11/97
Radiation | | | | | | 6/98 | | | | | | | 4/00
Chemotherapy
Tamoxifen | | | | | | | | | | | | | 3/00
Naltrexone | | | | | | | | | | | | | | 5/00
CAM other
X-ray | | | | | | | | | | | | 12/99
Imaging-MRI | | | | | | | | | | | | | 3/00 | 5/00 | 9/00
Imaging-CT scan | | | | | | | | | | | | | | 5/00 | 9/00 | | | 6/01 | 8/01
Tumor markers | | | | | | | | | | | | | 3/00 | 5/00

Date | Description of Events
| History of breast cancer in mother-currently in remission
11/1/97 | Surgery: lumpectomy breast
11/1/97 | Biopsy: breast cancer estrogen sensitive, nodes negative
6/1/98 | Radiation: right breast and right axilla: adverse effects- radiation edema
12/1/99 | X-ray right hip: no tumor present
3/1/00 | X-ray right pelvis: positive for mets to pelvis/spine
3/1/00 | MRI: brain: questionable abnormality-repeated in 8 weeks
3/1/00 | MRI hip--right femoral neck and mid-femur; right acetabulum; scattered throughout osseous of pelvis
Mar-00 | Radiation: pelvis: adverse effects- on crutches since 4/1/00
3/15/00 | Started tamoxifen 10mg bid and aridia
Mar-00 | CA 2729: 650
May-00 | CT chest: normal
5/1/00 | MRI: brain: normal
5/11/00 | CEA 3.6 (0–5)
5/13/00-present | Naltrexone
9/1/00 | CT chest: negative
9/6/00 | MRI: hip - extensive metastatic involvement of right femur; patchy metastatic involvement of left femur head and neck
12/1/00 | CA 2729: 79
6/1/01 | CT scan liver had small lesions
6/1/2001–8/01 | Chemotherapy: AC completed
8/1/01 | Liver lesions remain: oncologist monitoring

## Additional Case Reviewed Patient #2-19

### Case 2-19

The patient in case 2-19 is a 51-year-old male diagnosed with non-Hodgkin's lymphoma, small-cleaved cell type on 9/13/99. He declined conventional therapy and has pursued various unconventional therapies for cancer treatment, including Naltrexone (11/99). He has not been followed by any allopathic physician for over a year. While no recent imaging scans have been performed, he reports a submandibular lymph node that has grown to greater than 3cm over the past year. At his interview (10/18/01), the patient reported that his overall physical condition was good to very good.

Pathology

9/13/99 | Biopsy: lymph node (iliac): Malignant lymphoma non-Hodgkin's, small cleaved cell type predominately follicular and focally infiltrative: working formulation low grade

Imaging/labs

5/14/99 | CT scan abdomen: significant mesenteric adenopathy with multiple enlarged nodes 6cm. Multiple retroperitoneal prominent lymph nodes 2cm
1/5/00 | CT scan abdomen: nodes are generally smaller, less dense c/w 5/14/99. Largest retro-peritoneal node 1.5cm instead of 2cm. No additional adenopathy
7/10/00 | CT scan abdomen: mesenteric adenopathy, smaller nodes and less dense/w prior exam. Scattered, small retroperitoneal also appear smaller measuring 1cm or less. No additional adenopathy. Improved mesenteric and retropertoneal nodes.
1/19/01 | NK cell function 79 (43–100)
1/19/01 | Heavy metal screen: Mercury: 8.2 Nickel:11 Aluminum:12 Arsenic:53

Conventional therapy

None

Complementary therapy

11/22/99 | Naltrexone 3mg Qhs
10/00–3/01 | Removed mercury amalgam fillings; chelation therapy to remove mercury in blood, high dose vitamin C IV therapy
10/00–3/01 | CoQ10; pancreatic enzymes, essential fatty acids; vitamin E; milk thistle; turmeric; DHEA; selenium; N-acetyl cysteine, pro biotics
4/01–8/01 | PolyMVA
8/01-present | thymic protein; cereal grass (wheat, barley), digestive enzymes

Patient # 2-19
EVENT | | | | | | | | | PERIOD 1 | | | | PERIOD 2 | | | | PERIOD 3
| | | | | | | | | 1^st^ qtr 1999 – 4^th^ qtr 1999 | | | | 1^st^ qtr 2000 – 4^th^ qtr 2000 | | | | 1^st^ qtr 2001 – 4^th^ qtr 2001
Diagnosis/biopsy | | | | | | | | | | | 9/99
Surgery
Radiation
Chemotherapy
Naltrexone | | | | | | | | | | | | 11/99
Imaging | | | | | | | | | | 5/99 | | | 1/00 | | 7/00
CAM other | | | | | | | | | | | 8/99

Date | Description of Events
5/14/99 | CT scan abdomen: significant mesenteric adenopathy with multiple enlarged nodes 6cm. Multiple retroperitoneal prominent lymph nodes 2cm
9/13/99 | Biopsy: lymph node (iliac): Malignant lymphoma non-Hodgkin's, small cleaved cell type predominately follicular and focally infiltrative: working formulation low grade
9/13/99 | Radation recommended: patient refused due to pateint preference
11/22/99 | Naltrexone 3mg Qhs
1/5/00 | CT scan abdomen: nodes are generally smaller, less dense c/w 5/14/99. Largest retro-peritoneal node 1.5cm instead of 2cm. No additional adenopathy
7/10/00 | CT scan abdomen: mesenteric adenopathy, smaller nodes and less dense/w prior exam. Scattered, small retroperitoneal also appear smaller measuring 1cm or less. No additional adenopathy. Improved mesenteric and retropertoneal nodes
1/19/01 | NK cell function 79 (43–100)
1/19/01 | Heavy metal screen: Mercury: 8.2 Nickel:11 Aluminum:12 Arsenic:53
10/00–3/01 | Removed mercury amalgam fillings; chelation therapy to remove mercury in blood, high dose vitamin C IV therapy
10/00–3/01 | CoQ10; pancreatic enzymes, essential fatty acids; vitamin E; milk thistle; turmeric; DHEA; selenium; N-acetyl cysteine, probiotics
4/01–8/01 | PolyMVA
8/01-present | Thymic protein; cereal grass (wheat, barley), digestive enzymes
10/1/00-present | Submandibular node>3cm on physical exam (progressive); patient not followed by physician >1year