# Evidence Tables

## Abbreviations Used in the Evidence Tables

AED | Antiepileptic drugs
CI | 95% Confidence Interval
NES | Nonepileptic seizures
ES | Epileptic seizures
NA | Not applicable
NR | Not reported
SD | Standard deviation

## Question 1

What are the definitions of treatment-resistant epilepsy used in the literature?

Evidence Table 1. Definitions of treatment resistance in clinical studies

Reference | Definition
Question 2: Which methods of rediagnosing or reevaluating treatment-resistant epilepsy lead to, or can be expected to lead to improved patient outcomes?
Ben-Menachem (1999) | All patients refractory to available antiepileptic drugs
Handforth (1998) | Not Reported
Freeman (1998) | Not Reported
Vining (1998) | Not Reported
Salinski (1996) | Medically intractable seizures defined as a seizure frequency of ≥6 per month
(Followup of Clinical Trial EO3]
Tiancai (1996) | All cases used phenytoin sodium, carbamazepine and sodium valproate to no avail.
Question 3: Is there evidence that patients with treatment-resistant epilepsy are not optimized at their current level of treatment?
Sachdeo (2001) | Not reported
Sigler (2001) | Epilepsies which are not controlled by treatment with standard AED.
Garg (2000) | Not reported
Jozwiak (2000) | Not reported
Morrell (2000) | Not reported
El Desoky (1999) | Failure to meet their definition of “controlled cases of epilepsy” (defined as having no history of seizures for >1 year while still maintained on AEDs).
McLean (1999) | Not reported
Bruni (1998) | Not reported
Welty (1998) | Uncontrolled by standard AED therapy.
Hermanns (1996) | Seizure control not obtained despite maximum tolerable doses of at least one of the following drugs: carbamazapine (CBZ), phenytoin (PHT), or either phenobarbital (PB) or primidone (PRM).
Question 4: Which drug treatment strategies lead to improved outcomes for patients with treatment-resistant epilepsy?
Faught (2001) | Not reported
Sachdeo (2001) | Uncontrolled partial seizures while receiving carbamazepine monotherapy
Ben-Menachem (2000) | Seizures despite treatment with one AED
Betts (2000) | Not reported
Beydoun (2000) | Not reported
Cereghino (2000) | Not reported
Glauser (2000) | Partial seizures (with or without secondary generalization) that were inadequately controlled with one or two concomitant AEDs
Appleton (1999) | Not reported
Biton (1999) | Not reported
Duchowny (1999) | Epilepsy, incompletely controlled by existing therapy
Elterman (1999) | Not reported
KTSG (1999) | Not reported
Sachdeo (1999) | Not reported
Schachter (1999) | Not reported
Gilliam (1998) | Seizures, with or without secondary generalization, not adequately controlled by either carbamazepine or phenytoin monotherapy
Uthman (1998) | Not reported
Bergey (1997) | Not reported
Beydoun (1997b) | Not reported
Beydoun (1997a) | Not reported
Sachdeo (1997b) | Not reported
Ben-Menachem (1996) | Not reported
Chadwick (1996) | Medically uncontrolled generalized seizures despite treatment with one or two standard AEDs
Faught (1996) | Not reported
Privitera (1996) | Not reported
Tassinari (1996) | Not reported
Willmore (1996) | Complex partial seizures incompletely controlled by either phenytoin or carbamazepine
Question 5: Which methods of nondrug treatment for epilepsy after initial treatment failure lead to improved outcomes for patients with treatment-resistant epilepsy?
Bauer (2001) | Chronic focal epilepsy resistant to treatment with AEDs. Treatment strategy was with AED monotherapy if possible, otherwise, co-medication with two or three AEDs was established. Serum levels of AEDs were available for control of efficacy of treatment. These patients were not being considered for surgery and were selected because they had continuously documented their seizures in seizure charts.
Hennessy (2001) | Not reported
Hennessy (2001) | Not reported
Kanemoto (2001) | Not reported
Kohler (2001) | Not reported
Kwan (2001) | Not reported
Maehara (2001) | Not reported
Miranda (2001) | Not reported
Nees (2001) | Not reported
Orbach (2001) | Not reported
Schramm (2001) | A minimum one-year history of drug-resistant epilepsy and adequate trials of at least two first-line AEDs.
Wilson (2001) | Not reported
Anhoury (2000) | Not reported
Fandino-Franky (2000) | Not reported
Foldvary (2000) | Not reported
Markand (2000) | Medically refractory, all patients met the selection criteria of the presurgical evaluation set forth by the Indiana University Epilepsy Surgery Program
| Previous pharmacological management must have been adequate in view of the latest standards over a period of several years before medical treatment can be considered a failure. After being maintained on optimum anticonvulsant medication that does not produce unacceptable side effects, the residual seizures must be sufficiently significant to seriously disrupt normal life.
Mosewich (2000) | Not reported
Rao (2000) | Patients with 2 or more disabling complex partial seizures per month for 2 years or more and who received at least 2 trials with monotherapy and one trial with polytherapy were considered for presurgical evaluation
Westerveld (2000) | Not reported
Assaf (1999) | Not reported
Chassoux (1999) | Not reported
Eriksson (1999) | Not reported
Salanova (1999) | Medically refractory, all patients had frequent disabling seizures several times a month for years, despite treatment with several AEDs
Son (1999) | Not reported
Maher (1998) | Seizures refractory to at least 3 AEDs for at least 3 years
Radhakrishnan (1998) | Not reported
Ring (1998) | Not reported
Smith (1998) | Not reported
Wyllie (1998) | All of the patients had daily or weekly seizures despite multiple trials of AEDs
Ho (1997) | Not reported
McLachlan (1997) | Each patient had uncontrolled seizures for at least 3 years despite the use of three or more AEDs
Reeves (1997) | Not reported
Silander (1997) | Not reported
Smith (1997) | Not reported
Vining (1997) | Not reported
Hermanns (1996) | Resistance to an AED exists when it does not control seizures at the maximal individually tolerated dose. Prerequisite for focal epilepsy surgery is the resistance of disabling seizures to 3 major AEDs (carbamazepine, phenytoin, and either phenobarbital or primidone).
Peacock (1996) | Not reported
Rose (1996) | Not reported
Sirven (1996) | Not reported
Question 6: Which social, psychological or psychiatric services for treatment-resistant epilepsy lead to, or can be expected to lead to improved patient outcomes?
Sidorenko (2000) | Attacks persevered despite comprehensive drug treatments

Evidence Table 2. Definitions of treatment resistance in clinical guidelines

Reference | Definition
Tanenbaum (2000) | Not defined
French (1999) | Inadequately controlled seizures or significant side effects for whom no options had been available
Quality Standards Subcommittee of the American Academy of Neurology (1998) | Not defined

Evidence Table 3. Definitions of treatment resistance in review articles

Reference | Definition
Aldenkamp (2001) | Not defined
Benbadis (2001) | Medical intractability is a relative concept rather than an absolute one. The number of antiepileptic drugs that should be tried before a patient is deemed medically intractable is a matter of judgment.
| In practice, a usual medical trial may include two to four major drugs, with some used as monotherapy and at maximal tolerated dosages.
Blume (2001) | Not defined
Castillo (2001) | There is no universally accepted definition of drug-resistant, but for the purpose of this review, seizures will be considered drug-resistant if they have failed to respond to a minimum of two AEDs as monotherapy.
DeToledo (2001) | Not defined
Dlugos (2001) | Many adult epilepsy centers define medical intractability as persistent seizures despite 2 years and 2 maximally tolerated AED trials.
| Medical intractability is more challenging to define in children because of the tendency of many forms of pediatric epilepsy to remit with time.
Genton (2001) | Not defined
Kennedy (2001) | Not defined
Nordi (2001) | Failure to respond to three well-chosen antiepileptic medications, used alone or in combination.
Olsen (2001) | Medical intractability is established by assuring that antiepileptic medications appropriate for the child's particular epilepsy syndrome have been used and have been titrated to maximum tolerance before being deemed ineffective…There are no absolute criteria for determining when a patient has tried sufficient antiepileptic medications… There is no precisely determined time epilepsy must be present for seizures to be considered intractable.
Perucca (2001) | Not defined
Perucca (2001) | Not defined
Wisniewski (2001) | Not defined
Aarli (2000) | Not defined
Aiken (2000) | Not defined
Culy (2000) | Not defined
Davis (2000) | Not defined
Dooley (2000) | Seizures are considered refractory when they limit the patient's ability to live fully because of their frequency or severity or if they necessitate the use of medication which is effective but produces adverse effects.
Duchowny (2000) | Not defined
Glauser (2000) | Not defined
Juhasz (2000) | Not defined
Keene (2000) | Not defined
Leppik (2000) | Seizures only partially controlled at maximum tolerated doses.
Levisohn (2000) | Not defined
McLachlan (2000) | Not defined
Nordli (2000) | Intractability should not be considered until there is a failure of three first-line antiepileptic medications.
Palmini (2000) | Not defined
Provini (2000) | Not defined
Scharfman (2000) | Not defined
Schmidt (2000) | Not satisfactorily controlled with other antiepileptic drugs
Sisodiya (2000) | Not defined
Stafstrom (2000) | Not defined
Uthman (2000) | Continue to have seizures or their seizures are controlled at the expense of intolerable side effects
Yamamoto (2000) | Not defined
Annegers (1999) | Not defined
Beydoun (1999) | Not defined
Blumcke (1999) | Not defined
Chugani (1999) | Not defined
DeFelipe (1999) | Not defined
DeToledo (1999) | Seizures are so frequent or severe that they limit the patients ability to live fully according to his or her wishes or necessitate the use of medications that, although effective, produce adverse effects.
Devinsky (1999) | Do not become completely free of seizure
Haafiz (1999) | Not defined
Lewis (1999) | Not defined
Loiseau (1999) | Not defined
Mohan (1999) | Not defined
Moran (1999) | Not defined
Regis (1999) | Not defined
Rey (1999) | Not defined
Rho (1999) | Not defined
Snodgrass (1999) | Not defined
Tamer (1999)
Vinters (1999) | Not defined
Baxendale (1998) | Not defined
Bazil (1998) | A definition is implied by the diagnostic and treatment guidelines: “Each drug should be pushed to the highest tolerated dose regardless of serum concentrations. Should seizures persist at this dose, or if seizure control is achieved only with unacceptable adverse effects, a second drug should be substituted as monotherapy. Should this fail, then another drug should be added that compliments the first in terms of mechanism of action and side effect profile…patients who fail two first-line anticonvulsants at maximum tolerated doses should be considered for video-EEG monitoring to rule out nonepileptic events…”
Brown (1998) | Not defined
Bruni (1998) | Not defined
Corradetti (1998) | Not defined
Emilien (1998) | Not defined
Friis (1998) | Not defined
Lalviainen (1998) | Not defined
Lesser (1998) | Not defined
Novotny (1998) | Not defined
Ozuna (1998) | Not defined
Pellock (1998) | Not defined
Sachdev (1998) | Not defined
Tallian (1998) | Unresponsive to or experience adverse effects from medications
White (1998) | Uncontrolled seizure disorders and/or experiencing significant side effects
Yagi (1998) | Not defined
Acharya (1997) | Not defined
Benbadis (1997) | Not defined
Berg (1997) | Not defined
Blume (1997) | Not defined
Chadwick (1997) | Not defined
Duncan (1997) | Not defined
Eller (1997) | Not defined
Ho (1997) | Not defined
Jallon (1997) | Persistence of true epileptic seizures with a sufficient frequency or severity in a compliant patient despite optimal therapy for a minimum of 2 years
Kaufman (1997) | Not defined
Langtry (1997) | Not defined
Meador (1977) | Not defined
Mikati (1997) | Not defined
Ojemann (1997) | Not defined
Pellock (1997) | Not defined
Walker (1997) | Not defined
Zupane (1997) | Not defined
Duse (1996) | Not controlled after an adequate trial of first-line conventional anti-epileptic treatment
Henry (1996) | Not defined
Holmes (1996) | Seizures that either do not respond to conventional antiepileptic drugs (AEDs) or have significant adverse reactions to AEDs.
Leppik (1996) | Seizures are not controlled after usually effective levels have been attained and adverse effects are developing.
Nashef (1996) | Not defined
Neufeld (1996) | Not defined
Peacock (1996) | Patients evaluated for surgery had frequent medically intractable seizures that significantly interfered with their psychological and/or neurological development. Patients with infantile spasms had failed to respond to trials of ACTH and several antiepileptic drugs, including carbamazepine, phenytoin, Phenobarbital and valproate. As a general principle, children who were having many seizures each day required only a few months of medical therapy to determine medical intractability.
Perucca (1996) | Not defined
Reiss (1996) | Not defined
Roberts (1996) | Not defined
Trimble (1996) | Not defined
Villemure (1996) | Seizure intractability is defined as an epileptic disorder present for more than 2 years and unsuccessfully controlled with at least three anticonvulsants medications at therapeutic levels.
Wyllie (1996) | Not defined

Evidence Table 4. Inclusion/exclusion criteria implying a definition of treatment resistance

Reference | Minimum Number of AEDs Tried | Side Effects or Maximum Tolerated Dose Considered | Minimum Baseline Monthly Seizure Frequency | Minimum Duration of Symptoms | Study Purpose | Special Groups
Faught (2001) | 1 | No | 4 | Not Reported | FDA Approval | None
Sachdeo (2001) | 1 | No | 2 | Not Reported | FDA Approval | None
Beydoun (2000) | 1 | No | 2 | Not Reported | FDA Approval | None
Cereghino (2000) | 2 | No | 4 | 2 years | FDA Approval | None
Glauser (2000) | 1 | No | 4 | Not Reported | FDA Approval | Pediatric
Biton (1999) | 1 | No | 1.5 | Not Reported | FDA Approval | None
Duchowny (1999) | 1 | No | 4 | Not Reported | FDA Approval | Pediatric
Elterman (1999) | 1 | No | 3 | Not Reported | FDA Approval | Pediatric
Sachdeo (1999) | 1 | No | 60 | Not Reported | FDA Approval | Lennox-Gastaut syndrome
Schachter (1999) | 1 | No | 30 | Not Reported | FDA Approval | None
Gilliam (1998) | 1 | No | 4 | Not Reported | FDA Approval | None
Uthman (1998) | 1 | No | 2.67 | Not Reported | FDA Approval | None
Bergey (1997) | 1 | No | 3 | Not Reported | FDA Approval | None
Beydoun (1997b) | 1 | No | 2 | Not Reported | FDA Approval | None
Beydoun (1997a) | 1 | No | 2 | Not Reported | FDA Approval | None
Sachdeo (1997b) | 1 | No | 3 | Not Reported | FDA Approval | None
Faught (1996) | 1 | Yes | 4 | Not Reported | FDA Approval | None
Privitera (1996) | 1 | No | 4 | Not Reported | FDA Approval | None
Willmore (1996) | 1 | No | 4 | Not Reported | FDA Approval | None
Sachdeo (2001) | 1 | No | 2 | Not Reported | Drug study | None
Sigler (2001) | NR | Yes | NR | 1 year | Drug study | Pediatric (some had Lennox-Gastaut syndrome or West syndrome)
Ben-Menachem (2000) | 1 | No | 2 | 1 year | Drug Study | None
Betts (2000) | 1 | No | 0.67 | Not Reported | Drug Study | None
Garg (2000) | NR | Yes | NR | Not Reported | Drug study | None
Jozwiak (2000) | 1 | No | 1 | Not Reported | Drug study | None
Morrell (2000) | 1 | Yes (for some but not all patients) | 2 | Not Reported | Drug study | None
Appleton (1999) | 1 | No | 2.67 | Not Reported | Drug Study | Pediatric
El Desoky (1999) | 1 | No | 0.083 | Not Reported | Drug study | None
KTSG (1999) | 1 | Yes | 2 | Not Reported | Drug Study | None
McLean (1999) | 1 | Yes (for some but not all patients) | 2 | Not Reported | Drug study | None
Bruni (1998) | 1 | No | 1 | 1 year | Drug study | None
Welty (1998) | Not Reported | No | Not Reported | Not Reported | Drug Study | None
Ben-Menachem (1996) | 1 | No | 4 | Not Reported | Drug Study | None
Chadwick (1996) | 1 | No | 4 | Not Reported | Drug Study | None
Hermanns (1996) | 1 | Yes | 2 | 6 months | Drug study | None
Tassinari (1996) | 1 | No | 4 | Not Reported | Drug Study | None
Bauer (2001) | 3 | No | Not Reported | Not Reported | Surgery - control patients | None
Hermanns (1996) | 3 | Yes | Not Reported | Not Reported | Surgery - control patients | None
Hennessy (2001) | Not Reported | No | Not Reported | Not Reported | Surgery -Temporal lobe | Mesial temporal sclerosis
Hennessy (2001) | Not Reported | No | Not Reported | Not Reported | Surgery -Temporal lobe | Non-MTS focal lesions
Kanemoto (2001) | Not Reported | No | Not Reported | Not Reported | Surgery -Temporal lobe | None
Kohler (2001) | Not Reported | No | Not Reported | Not Reported | Surgery -Temporal lobe | None
Miranda (2001) | Not Reported | No | Not Reported | Not Reported | Surgery -Temporal lobe | None
Nees (2001) | Not Reported | No | Not Reported | Not Reported | Surgery -Temporal lobe | None
Schramm (2001) | 2 | No | Not Reported | 1 | Surgery -Temporal lobe | None
Wilson (2001) | Not Reported | No | Not Reported | Not Reported | Surgery -Temporal lobe | None
Anhoury (2000) | Not Reported | No | Not Reported | Not Reported | Surgery -Temporal lobe | None
Foldvary (2000) | Not Reported | No | Not Reported | Not Reported | Surgery -Temporal lobe | None
Markand (2000) | Not Reported | Yes | Not Reported | “Several Years” | Surgery -Temporal lobe | None
Rao (2000) | 2 | No | 2 | 2 | Surgery -Temporal lobe | None
Westerveld (2000) | Not Reported | No | Not Reported | Not Reported | Surgery -Temporal lobe | Pediatric
Assaf (1999) | Not Reported | No | Not Reported | Not Reported | Surgery -Temporal lobe | None
Eriksson (1999) | Not Reported | No | Not Reported | Not Reported | Surgery -Temporal lobe | None
Salanova (1999) | “Several” | No | “Several per month” | “Years” | Surgery -Temporal lobe | None
Son (1999) | Not Reported | No | Not Reported | Not Reported | Surgery -Temporal lobe | Mesial temporal sclerosis
Maher (1998) | 3 | No | Not Reported | 3 | Surgery -Temporal lobe | None
Radhakrishnan (1998) | Not Reported | No | Not Reported | Not reported | Surgery -Temporal lobe | None
Ring (1998) | Not Reported | No | Not Reported | Not Reported | Surgery -Temporal lobe | None
Wyllie (1998) | Multiple | No | “Daily or weekly” | Not Reported | Surgery -Temporal lobe | None
Ho (1997) | Not Reported | No | Not Reported | Not Reported | Surgery -Temporal lobe | None
McLachlan (1997) | 3 | No | Not Reported | 3 | Surgery -Temporal lobe | None
Reeves (1997) | Not Reported | No | Not Reported | Not Reported | Surgery -Temporal lobe | None
Silander (1997) | Not Reported | No | Not Reported | Not Reported | Surgery -Temporal lobe | None
Rose (1996) | Not Reported | No | Not Reported | Not Reported | Surgery -Temporal lobe | None
Sirven (1996) | Not Reported | No | Not Reported | Not Reported | Surgery -Temporal lobe | None
Peacock (1996) | Not Reported | No | Not Reported | Not Reported | Surgery -Hemispherectomy | None
Mosewich (2000) | Not Reported | No | Not Reported | Not Reported | Surgery -Frontal lobe resection | None
Chassoux (1999) | Not Reported | No | Not Reported | Not Reported | Surgery -Frontal lobe resection | None
Smith (1997) | Not Reported | No | Not Reported | Not Reported | Surgery -Frontal lobe resection | None
Vining (1997) | Not Reported | No | Not Reported | Not Reported | Surgery - Hemispherectomy | None
Orbach (2001) | Not Reported | No | Not Reported | Not Reported | Surgery -Multiple subpial transection | None
Smith (1998) | Not Reported | No | Not Reported | Not reported | Surgery -Multiple subpial transection | None
Fandino-Franky (2000) | Not Reported | No | Not Reported | Not Reported | Surgery -Callosotomy | None
Kwan (2001) | Not Reported | No | Not Reported | Not Reported | Surgery -Callosotomy | Lennox-Gastaut
Maehara (2001) | Not Reported | No | Not Reported | Not Reported | Surgery -Callosotomy | None
Sidorenko (2000) | 2 | No | Not Reported | Not Reported | Nondrug | None
Ben-Menachem (1999) | NR | No | 1 | Not Reported | Nondrug | None
Handforth (1998) | Not Reported | No | 6 | 2 years | Nondrug | None
Freeman (1998) | Not Reported | No | 8 | Not Reported | Nondrug | Pediatric
Vining (1998) | Not Reported | No | 32 | Not Reported | Nondrug | Pediatric
Salinski (1996) | Not Reported | No | 6 | Not Reported | Nondrug | None
Tiancai (1996) | 3 | No | NR | 2 Months | Nondrug | None

Evidence Table 5. Implied definitions from inclusion/exclusion criteria

Type of Study | Number of Studies | Number Requiring a Minimum Number of AEDs | Number Mentioning Side Effects of MTD | Number Requiring a Minimum Baseline Seizure Frequency | Number Requiring a Minimum Duration of Illness
Patients Selected
Pediatric | 8 | 5 (63%) | 1 (13%) | 6 (75%) | 1 (13%)
Lennox-Gastaut Syndrome | 2 | 1 (50%) | 0 | 1 (50%) | 0
Mesial temporal sclerosis | 2 | 0 | 0 | 0 | 0
Nonmesial temporal sclerosis lesions | 1 | 0 | 0 | 0 | 0
No Special Group | 69 | 38 (55%) | 8 (12%) | 33 (48%) | 12 (17%)
Purpose of Study
FDA drug study | 19 | 19 (100%) | 1 (5%) | 19 (100%) | 1 (5%)
Non-FDA drug study | 17 | 14 (82%) | 6 (35%) | 14 (82%) | 4 (24%)
Nondrug treatment | 7 | 3 (43%) | 0 | 5 (71%) | 2 (29%)
Surgery- Control patients | 2 | 2 (100%) | 1 (50%) | 0 | 0
Surgery- Temporal lobe | 27 | 6 (22%) | 1 (4%) | 2 (7%) | 6 (22%)
Surgery- Hemispherectomy | 2 | 0 | 0 | 0 | 0
Surgery- Frontal lobe resection | 3 | 0 | 0 | 0 | 0
Surgery- Multiple subpial transection | 2 | 0 | 0 | 0 | 0
Surgery- Callostomy | 3 | 0 | 0 | 0 | 0
Totals
All surgery studies | 39 | 8 (21%) | 2 (5%) | 2 (5%) | 6 (15%)
All studies | 82 | 44 (54%) | 9 (11%) | 40 (49%) | 13 (16%)

MTD Maximum tolerated dose

## Question 2

Which methods of rediagnosing or re-evaluating treatment-resistant epilepsy lead to, or can be expected to lead to improved patient outcomes?

Evidence Table 6. Evidence base and important study design characteristics for Question 2A

Reference | Country | Site of Study | Total Study Size | Multicenter | Study Design | Examined Consecutive Patients | Reason For Referral (N ) | Source of Referrals | Method of Original-Diagnosis | Diagnostic Reevaluation Battery | Patients Followed Up | Mean Followup Time (SD) | Who Was Followed Up
Zaidi (2000) | United Kingdom | Specialist epilepsy unit | 74 | Yes | Case series | Yes | Refractory epilepsy (36) | NR | NR | Tilt Table | Yes | 10.3 (6.7) months | Only patients with NES
| | | | | | | | | | Carotid sinus massage
| | | | | | | Diagnostic uncertainty (38)
| | | | | | | | | | Continuous ECG monitoring
| | | | | | | | | | Continuous EEG monitoring
| | | | | | | | | | Continuous BP monitoring
Holmes (1998) | United States | Specialist neuro-electrophysiology unit | 379 | No | Case series | Yes | Refractory epilepsy (379) | NR | NR | Clinical reevaluation | No | NA | NA
| | | | | | | | | | vEEG
Henry (1997) | United States | Specialist neurosurgery unit | 145 | No | Case series | Yes | Refractory epilepsy (141) | Treating neurologist | NR | Clinical reevaluation | Yes | 2.5 (0.9) years | Only patients with NES
| | | | | | | | | | MRI (all patients)
| | | | | | | | | | rEEG
| | | | | | | | | | vEEG
Arnold (1996) | United States | Specialist video/EEG monitoring unit | 45 | No | Case series | Yes | Refractory epilepsy (45) | NR | NR | Clinical reevaluation | Yes | NR | Only patients with confirmed epilepsy
| | | | | | | | | | vEEG
Slater (1995) | United States | Specialist video/EEG monitoring unit | 101 | No | Case series | Yes | Refractory epilepsy (101) | NR | NR | Clinical reevaluation | No | NA | NA
| | | | | | | | | | vEEG (minimum 24 hours)

BP Blood Pressure

ECG Electrocardiogram

EEG Electroencephalogram

MRI Magnetic resonance imaging

NA Not applicable

NES Nonepileptic seizure

rEEG Routine EEG

vEEG Video EEG

Evidence Table 7. Study characteristics: Inclusion/exclusion criteria

Reference | Inclusion Criteria | Exclusion Criteria
Zaidi (2000) | Patients with clinical diagnosis of epilepsy | Patients with suspected psychogenic seizures
Holmes (1998) | Patients with intractable epilepsy | NR
| Age ≥16 years
Henry (1997) | Medically refractory seizures >2 years | NR
| Candidates for temporal lobectomy and were referred for pre-surgical evaluation
| Absence of moderate or severe encephalopathy on neurologic exam
| EEG studies consistent with focal epilepsy
| Absence of generalized or extratemporal epiletiform EEG abnormality
| Recorded seizures considered consistent with ES
Arnold (1996) | Patients with seizures refractory to AED's | NR
| Age > 18 years
| Informed consent
Slater (1995) | Patients with seizures believed to be epilepsy refractory to AEDs | Refused induction procedure
| | Mental retardation (IQ <70)
| | Undergoing repeat hospitalization
| | Had know psychiatric illness
| | Incomplete medical records

NA Not applicable

Evidence Table 8. Patient characteristics for Question 2A

Reference | Total Number of Patients (N) | Number of Patients Suspected of Nonepileptic Seizures at Enrollment (%) | Mean Age (SD): Years | Age Range: Years | Mean Duration of Disease (SD): Years | Duration Range: Years | Percent Male | Seizure Frequency | Reported Seizure Types at Enrollment (N) | Percentage of Patients With Cognitive Deficits | Percentage of Patients With Developmental Delay | Number of AED's at Entry (Number of Patients)
Zaidi (2000) | 74 | 38 (51.4) | 38.9 (18) | 16 to 77 | NR | NR | NR | NR | NR | NR | NR | 1 AED (21)
| | | | | | | | | | | | 2 AED's (8)
| | | | | | | | | | | | >3 AED's (7)
| | | | | | | | | | | | (See footnote^b^)
Holmes (1998) | 379 | 0 | 24.2 (10.9) | ≥16 | NR | NR | 40.0 | NR | NR | NR | NR | NR
Henry (1997) | 145 | 0 | NR | NR | 20 (NR) | NR | NR | NR | Partial seizures (145)^a^ | NR | NR | NR
Arnold (1996) | 41 | 0 | NR | ≥18 | NR | NR | NR | NR | NR | NR | NR | NR
Slater (1995) | 101 | 0 | NR | ≥18 | NR | NR | NR | NR | NR | 0.0 | 0.0 | NR

a All patients were considered to have temporal lobe epilepsy. No details of the type of partial seizures was reported

b Only 36 of the 74 patients were taking AED's at time of investigation. These patients are the patients of interest in this section of the report.

Evidence Table 9. Rediagnosis data

Reference | Patients With Refractory Seizures | For Whom a Firm Diagnosis Could Be Made | Diagnostic Yield ( %) | Patients With NES (%) | Patients With NES Only (%) | Patients With NES Plus ES (%) | Post Rediagnosis Treatment Strategies | Were Patients Followed Up? | Mean Followup Time(SD) | Patients Followed Up | Reported Outcomes
Zaidi (2000) | 36^b^ | 36 | 100.0 | 13 (36.1) | 13 (36.1) | 0 (0.0) | 11/13 patients with NES stopped AED's and were treated for underlying cause of syncope. New treatments not reported | Yes | 10.3 (6.7) months | 13 | 11/13 patients seizure free
| | | | | | | | | | All NES
Holmes (1998) | 379 | 338 | 89.2 | 114 (33.7) | 111 (32.8) | 3 (0.9) | Not reported | No | Not applicable | Not applicable | Not applicable
Henry (1997) | 145 | 145 | 100.0 | 12 (8.3) | 0 (0.0) | 12 (8.3) | Psychotherapy (n = 5) | Yes | 2.48 (0.86) years | 11/12 All NES | Frequency of NES:
| | | | | | | Refused psychotherapy (n = 6)
| | | | | | | Lost-to-followup (n = 1) | | | | Ceased: 3/12 patients
| | | | | | | | | | | Reduced >75%: 1/12 patients
| | | | | | | | | | | No change: 6/12
| | | | | | | | | | | Unknown 1/12^a^
| | | | | | | | | | | Lost-to-followup: 1/12
Arnold (1996) | 45 | 41 | 91.0 | 14 (34.1) | 14 (34.1) | 0 (0.0) | ES Group: Resection of epileptic focus (n = 20) Medical treatment only (n = 7) | Yes | Not reported | 27 | Not reported
| | | | | | | NES Group: Not reported
Slater (1995) | 101 | 101 | 100.0 | 38 (37.6) | 37 (36.7) | 1 (1.0) | Not reported | No | Not applicable | Not applicable | Not applicable

a Patient and observers were unable to distinguish true epileptic seizures from nonepileptic seizures

b Consists of only those patients still on antiepileptic drugs on entry to study who were not suspected of misdiagnosis (see text)

Evidence Table 10. Meta-analysis of non-epileptic seizure prevalence data

Reference | N | Effect Size (Cohen's h and CI) | P-Value | Standard Residual | Outlier by Standard Residual? | Q^a^if Study Removed | P (Q) = | Greatest Outlier By Q?
Zaidi (2000) | 36 | 1.29 (0.83 to 1.75) | 0.000000 | 0.13 | No | 0.259181 | 0.967513 | No
Holmes (1998) | 338 | 1.24 (1.09 t0 1.39) | 0.000000 | -0.45 | No | 0.078236 | 0.994315 | No
Arnold (1996) | 41 | 1.25 (0.82 to 1.68) | 0.000000 | -0.05 | No | 0.273632 | 0.964909 | No
Slater (1995) | 101 | 1.32 (1.04 to 1.60) | 0.000000 | 0.49 | No | 0.040969 | 0.997821 | No
| | | | | Summary Effect Size (CI) | | 1.26 (1.14 to 1.38)
| | | | | Transformed ES (CI) | | 35% (29% to 41%).
Fixed Effects
| | | | | Q^b^= | | 0.28
| | | | | p = | | 0.964393
| | | | | Summary Effect Size (CI) | | 1.26 (1.14 to 1.38)
Random Effects
| | | | | Transformed ES (CI) | | 35% (29% to 41%).

a Critical Q_e_(p = 0.1, 2 degrees of freedom) = 4.605

b Critical Q _e_(p = 0.1, 3 degrees of freedom )= 6.250

Evidence Table 11. Number of studies addressing each diagnostic

Reference | Country | Routine EEG | Ambulaotry EEG | Video EEG | CT | MRI | Prolactin | Creatinine kinase | Tilt table | Tongue biting | Hypnotic recall | Provocation | MMPI | SPECT | Auditory Evoked Potentials
Jedrzejczak (2001) | Poland | | | | | | | | | | | | ✓
Shah (2001) | United States | | | | | | ✓
Barry (2000) | United States | | | | | | | | | | | ✓
Foley (2000) | United States | | ✓
Srikumar (2000) | India | | | ✓
Storzbach (2000) | United States | ✓ | | | | | | | | | | | ✓
zaidi (2000) | United Kingdom | | | | | | | | ✓
Drury (1999) | United States | | | ✓
Kuyk (1999) | Holland | | | | | | | | | | ✓
Lusic (1999) | Croatia | | | | | | ✓
Shihabuddin (1999) | United States | | ✓ | ✓
Alving (1998) | Denmark | | | | | | ✓
Ettinger (1998) | United States | | | | | | | | | | | | | ✓
Holmes (1998) | United States | | | | | | | | | | | | ✓
Neufeld (1997) | Israel | | | | | | | ✓
Derry (1996) | Canada | | | | | | | | | | | | ✓
Devinski (1996) | United States | ✓ | ✓
Benbadis (1995) | United States | | | | | | | | | ✓
Slater (1995) | United States | | | | | | | | | | | ✓
Boon (1994) | Belgium | | | ✓
Lancman (1994) | United States | | | | | | | | | | | ✓
Walczak (1994) | United States | | | | | | | | | | | ✓
Anzola (1993) | Italy | | | | | | ✓
Chayasirisobhon (1993) | United States | | | ✓
Drake (1993) | United States | | | | | | | | | | | | | | ✓
Nousiainen (1992) | Finland | ✓ | ✓ | ✓
Saygi (1992) | United States | | | | | ✓
Brown (1991) | United States | | | | | | | | | | | | ✓
Grubb (1991) | United States | | | | | | | | ✓
Zelnick (1991) | Israel | | | | | | ✓
Mishra (1990) | India | | | | | | ✓
Libman (1989) | Canada | | | | | | | ✓
Wroe (1989) | United Kingdom | | | | | | ✓
Vandervant (1986) | United States | | | | | | | | | | | | ✓
Laxter (1985) | United States | | | | | | ✓
Goodin (1984) | United States | ✓
Sivenius (1984) | Finland | | ✓
Chesson (1983) | United States | | | | | | | ✓
Size of Evidence Base For Each Modality | | 4 | 5 | 6 | 0 | 1 | 8 | 3 | 2 | 1 | 1 | 4 | 6 | 1 | 1

✓ Study assessed the ability of this diagnostic technology to differentiate between epileptic and nonepilpetic seizures

a This article was published prior to 1985. Included because evidence base for diagnostic modality of interest was <5 when only articles published during or after 1985 were considered (See inclusion criteria in Volume 1)

EEG Electroencephalogram

CT Computed tomography

MRI Magnetic resonance imaging

MMPI Minnesota Multiphasic Personality Inventory

SPECT Single photon emission computed tomography

Evidence Table 12. Articles addressing blood prolactin level measurement excluded for quality reasons

Reference | Country | Reason(s) for Exclusion
Shah (2001) | United States | Independence of data violation. Mean blood prolactin levels calculated from same patients multiple times if they had multiple seizures (340 events from 89 patients). Data does not allow one to determine which patients are represented multiple times.
Alving (1998) | Denmark | Independence of data violation. All values (means, dispersions, sensitivity, specificity, positive predictive value, negative predictive value) were based on number of seizure events and not on number of patients. Data does not allow one to determine which patients are represented multiple times.
Laxer (1985) | United States | Independence of data violation. Mean blood prolactin levels calculated from blood prolactin levels taken from same pt multiple times if they had multiple seizures (85 seizures from 70 patients). Data does not allow one to determine which patients are represented multiple times.
| | Inconsistencies in data presentation. Diagnostic performance data incorrectly presented. Authors report on data from 79 patients (37 men: 42 women) yet according to methods only 70 patients were recruited into study.

Evidence Table 13. Quality of reporting: articles describing studies of blood prolactin level measurement

Reference | Country | Refering Source of Included Patients Identified | Sampling Methodology Described | All Patients Subjected to Reference Standard | Clinical Setting in Which Diagnostic Test Evaluated Clearly Described | Inclusion/Exclusion Criteria Stated | Demographic Data For Patients Presented | Information on Comorbidities Presented | Information on Method of Data Collection Presented | Analytic Methods Clearly Described | Information on Sample Size Requirements Presented | Outcome Data Clearly Presented | Data Presented in Sufficient Detail For ECRI to Confirm Findings
Lusic (1999) | Croatia | No | No | No | Yes | Yes | No | No | Yes | Yes | No | Yes | Yes
Anzola (1993) | Italy | No | Yes | Yes | Yes | Yes | No | No | Yes | Yes | No | Yes | Yes
Zelnick (1991) | Israel | No | No | Yes | Yes | No | No | No | Yes | Yes | No | Yes | Yes
Mishra (1990) | India | No | No | Yes | Yes | No | No | No | Yes | Yes | No | Yes | Yes
Wroe (1989) | United Kingdom | No | No | Yes | Yes | No | No | No | Yes | Yes | No | Yes | Yes

Evidence Table 14. Study design characteristics in studies of blood prolactin level measurement

Reference | Setting | Study Design | Total Study Size (N)^a^ | Differntial Diagnosis | Consecutive Patients | Multicenter | Reference Standards | Blinded | Patients Followed Up | Reason Patients Referred
Lusic (1999) | Hospital Inpatient | Diagnostic case-control | 33 | CPS (n = 18) from syncopal seizures (n = 15) | Not reported | No | ES group: Not reported | No | No | Patients admitted to emergency department seeking treatment for either syncopal attack or epilpetic seizure
| | | | | | | Syncope group: Not reported
Anzola (1993) | Hospital Inpatient | Diagnostic case-control | 59 | GTCS (n = 40) from nonconvulsive syncope (n = 19) | No | No | ES group: Clinical opinion with EEG support | Yes | No | Patients admitted to neurological clinic due to loss of consciousness or epileptic seizure
| | | | | | | Syncope group: Clinical opinion with EEG support and in addition, cardiac
Zelnick (1991) | Hospital Inpatient | Diagnostic case-control | 27 | Mix of epileptic seizure types (n = 17) from syncope (n = 10) | Not reported | No | ES group: Clinical opinion with EEG support | No | No | Evaluation of various seizure types
| | | | | | | | Syncope group: Not reported
Mishra (1990) | Hospital Inpatient | Diagnostic case-control | 77 | GTCS (n = 15), CPS (n = 11), and SPS (n = 9) from PsyS (n = 20) | Not reported | No | ES group: Not reported | No | No | Not reported
| | | | | | | PsyS group: Not reported
Wroe (1989) | Hospital-Inpatient | ? | 33 | GTCS (n = 8), CPS (n = 11), and atypical seizures (n = 4) from PsyS (n = 10) | Not reported | No | ES group: Clinical opinion with video-EEG support | No | No | Patients admitted to epilepsy unit for vEEG monitoring and evaluation of severe or intractable epilepsy
| | | | | | | PsyS group: Clinical opinion with video-EEG support

a This is the total number of patients entered into the study that suffered seizures and this number may not include all patients included in the study, some of whom are not of interest in this section of the report

PsyS Psychogenic seizures

CPS Complex partial seizures

GTCS Generalized tonic-clonic seizures

SPS Simple partial seizures

Evidence Table 15. Definitions of diagnostic groups used in studies of blood prolactin level measurement

Reference | Reference Standard Used | Criteria For Diagnosis of Epileptic Seizure | Criteria For Diagnosis of Psychogenic Seizure | Criteria For Diagnosis of Syncope
Lusic (1999) | ES group: Not reported | Not reported | Not applicable | Not reported
| Syncope group: Not reported
Anzola (1993) | ES group: Clinical opinion with EEG support | Description of witnessed seizure consistent with ES. | Not applicable | Loss of consciousness not accompanied by convulsions
| Syncope group: Clinical opinion with EEG support and in addition, cardiac function tests
| | Patient must have shown postictal confusion. | | Normal EEG
| | | | Negative for birth injury, cranial injury, brain infection
| | Pt must have showed interictal or postictal EEG abnormalities.
| | | | Normal ECG
| | | | Normal 24 hour ECG holter monitoring
| | Corollary but non-crucial elements such as:
| | | | Plain chest radiograph
| | Tongue biting
| | Urinary incontinence
| | Increase in serum kinase level
| | Previous history of epilepsy
Zelnick (1991) | ES group: Clinical opinion with EEG support | Observation of seizure by clinical staff | Not applicable | Loss of tone and consciousness due to vasovagal mechisms (No more details given)
| Syncope group: Not reported | Patients with nonfebrile seizures and abnormal EEG with epileptiform features
Mishra (1990) | ES group: Not reported | Not reported | Not reported | Not applicable
| PsyS group: Not reported
Wroe (1989) | ES group: Clinical opinion with video-EEG support | Not reported | Not reported | Not applicable
| PsyS group: Clinical opinion with video-EEG support

ECG Electrocardiogram

EEG Electroencephalogram

ES Epileptic seizure

GTCS Generalized tonic-clonic seizures

PsyS Psychogenic seizure

EEG Electroencephalogram

Evidence Table 16. Protocols for measurement of blood prolactin levels

Reference | Serum or Plasma | Number of Measurments | Sampling Times | Method of Measurement | Normal/Abnormal Threshold
Lusic (1999) | Serum | 3 | T1 = Within 60 minutes of seizure | Comercial radioimmunoassay method (Prolactin-IRMA, manufactured by IBL, Hamburg, Germany) | Normal range for lab <630 mIU/L (26 ng/ml)
| | | T2 = Within 60 minutes after T1
| | | T3 = 24 hours after T1
Anzola (1993) | Plasma | 4 | T1 = Within 60 minutes of seizure | Commercial radioimmunoassay method (no more detail given) | >2 SD of mean of T2, T3, and T4 values
| | | | | >3 SD of mean of T2, T3, and T4 values
| | | T2 = 60 minutes after T1
| | | T3 = 1 day after T1 (in morning)
| | | T4 = 2 days after T1 (in morning)
Zelnick (1991) | Serum | 1 | T1 = Within 90 minutes of seizure | Commercial radioimmunoassay method (no more detail given) | Normal ref. range for lab >15 ng/ml
Mishra (1990) | Serum | 2 | T1 = 15 Within 20 minutes of seizure | Commercial radioimmunoassay method (no more detail given) | Mean: 278 (SD: 120.0) μIU/ml
| | | T2 = 6-8 hours following seizure
Wroe (1989) | Serum | 8 | T0 = Baseline | Commercial radioimmunoassay method using rabbit antibody | >1000mU/l
| | | T1 = Immediately following seizure
| | | T2 = 5 minutes following seizure
| | | T3 = 10 minutes following seizure
| | | T4 = 20 minutes following seizure
| | | T5 = 30 minutes following seizure
| | | T6 = 60 minutes following seizure
| | | T7 = 90 minutes following seizure

Evidence Table 17. Inclusion / exclusion criteria in studies of blood prolactin level measurement

Reference | Inclusion Criteria | Exclusion Criteria
Lusic (1999) | Epilepsy group: | Patients with suspected or proven cardiac aetiology for syncope, or autoimmune failure, were excluded from the study
| Patients with an established diagnosis of epilepsy who had experienced a complex partial seizure
| Syncope group:
| Patients examined immediately after a typical postural vaso-vagal syncope attack
Anzola (1993) | Patients who fulfilled criteria for either generalized tonic clonic or complex partial seizure due to epilepsy | Not reported
| Patients with noncardiac syncope
Zelnick (1991) | Not reported | Not reported
Mishra (1990) | Not reported | Not reported
Wroe (1989) | Not reported | Not reported

Evidence Table 18. Patient characteristics in studies of blood prolactin level measurement

Reference | Study Arm | N | Age:Mean (SD) | Age Range | Percent Male | Comorbidities | Mean Prediagnostic Seizure Rate (SD) | Mean Duration of Disease (SD) | AED Usage
Lusic (1999) | ES | 18 | 28.2 (5.8) | NR | 0 (0.0) | NR | NR | NR | Carbamazepine (n = 14)
| | | | | | | | | Valproic acid (n = 6)
| | | | | | | | | Metilphenobarbitone (n = 3)
| | | | | | | | | Lamotrigine (n = 1)
| | | | | | | | | Vigabatrin (n = 1)
| Syncope | 15 | 32.4 (5.5) | NR | 0.(0.0) | NR | NR | NR | Nil
Anzola (1993) | ES | 40 | 43.6 (17) | NR | 62.5 | NR | NR | NR | NR
| Syncope | 19 | 34.8 (20) | NR | 52.6 | NR | NR | NR | NR
Zelnick (1991) | ES | 17 | 7.2 (3.8) | 1 to 11 | 76.5 | NR | NR | NR | NR
| Syncope | 10 | 6.1 (NR) | NR | NR | NR | NR | NR | NR
Mishra (1990) | GTCS | 15 | NR | NR | NR | NR | NR | NR | NR
| CPS | 11 | NR | NR | NR | NR | NR | NR | NR
| SPS | 9 | NR | NR | NR | NR | NR | NR | NR
| PsyS | 20 | NR | NR | NR | NR | NR | NR | NR
Wroe (1989) | ES | 20 | 34.0 (NR) | NR | 55.0 | NR | 1.7 (3.0) / day | 17.4 (12.0) | NR
| PsyS | 40 | 33.9 (NR) | NR | 10.0 | NR | 0.6 (0.51) | 6.3 (7.9) | NR
| PsyS + ES | 8 | NR | NR | NR | NR | NR | NR | NR

ES Epileptic seizure

GTCS Generalized tonic clonic seizure

PsyS Psychogenic seizure

SPS Simple partial seizure

Evidence Table 19. Dichotomous diagnostic performance data: definitions

Reported Outcome | Definition
Prevalence | The proportion of subjects in the sample of interest who suffer from epileptic seizures alone
True Positive (TP) | A subject who suffers from true epileptic seizures (alone) who was correctly identified by the test of interest as suffering from epileptic seizures (alone)
False Positive (FP) | A subject who suffers from non-epileptic seizures (either alone or in combination with true epileptic seizures) who was incorrectly identified by the test of interest as suffering from true epileptic seizures (alone) by the test
True Negative (TN) | A subject who suffers from non- epileptic seizures (alone or in combination with true epileptic seizures) who was correctly identified by the test of interest as having nonepileptic seizures (either alone or in combination with true epileptic seizures)
False Negative (FN) | A subject who suffers from true epileptic seizures (alone) who was incorrectly identified by the test of interest as having nonepileptic seizures by the test.
Sensitivity | The proportion of individuals suffering from true epileptic seizures (alone) who were correctly identified by the test of interest as having true epileptic seizures (alone)
| Sensitivity = TP/(TP + FN)
Specificity | The proportion of individuals suffering from nonepileptic seizures (either alone or in combination with true epileptic seizures) who were correctly identified by the test of interest as not having true epileptic seizures (alone)
| Specificity = TN/(TN + FP)
Positive Predictive Value (PPV) | The proportion of individuals identified by the test of interest as suffering from true epileptic seizures (alone) who actually suffered from true epileptic seizures (alone)
| PPV = TP/(TP + FP)
Negative Predictive Value (NPV) | The proportion of individuals identified by the test of interest as suffering from non-epileptic seizures (either alone or in combination with true-epileptic seizures) who actually did suffer from nonepileptic seizures (either alone or in combination with true epileptic seizures)
| NPV = TN/(TN + FN)

Evidence Table 20. Dichotomous diagnostic performance data in studies of blood prolactin level measurement

| | | | | | | | | | | | | ECRI Calculated Data
Reference | Differentiation | Time | Threshold | Prevalence of Epileptic Seizures (%) | True Positive^a^ | False Positive^b^ | True Negative^c^ | False Negative^d^ | Sensitivity (CI) | Specificity (CI) | PPV (CI) | NPV (CI) | S^e^ | D^d^ | Standardized Effect Size, d (CI)f | Cohen's h (CI)
Lusic (1999) | Complex partial seizure from syncopal seizures | <60 minutes after seizure | ≥630 mIU/ml | 54.5 | 14 | 9 | 6 | 4 | 77.8 (54.7 to 90.8) | 40.0 (20.0 to 64.2) | 69.0 (40.8 to 77.7) | 60.0 (31.3 to 83.0) | 1.658 | 0.847 | 0.47 (-0.37 to 1.30) | 0.39 (-0.30 to 1.07)
Anzola (1993) | Epileptic seizure from syncopal seizures | <60 minutes after seizure | ≥2 SD above mean of next three readings | 64.9 | 17 | 4 | 9 | 7 | 70.8 (50.8 to 84.9) | 69.2 (42.3 to 87.1) | 81.0 (59.9 to 92.1) | 56.3 (33.3 to 76.8) | 0.076 | 1.698 | 0.94 (0.13 to 1.75) | 0.79 (0.14 to 1.44)
| Epileptic seizure from syncopal seizures | <60 minutes after seizure | ≥3 SD above mean of next three readings | 64.9 | 17 | 2 | 11 | 7 | 70.8 (50.8 to 84.9) | 84.6 (57.6 to 95.4) | 89.5 (68.4 to 76.8) | 61.1 (38.6 to 79.6) | -0.817 | 2.592 | 1.43 (0.47 to 2.39) | 1.13 (0.49 to 1.78)
Wroe (1989) | Generalized tonic clonic seizure and complex partial seizure from psychogenic seizure | 10 minutes after seizure | >1000 mU/l | 65.5 | 11 | 0 | 10 | 8 | 57.9 (36.3 to 76.7) | 100.0 (71.7 to 100.0) | 100.0 (73.6 to 100.0) | 55.6 (33.8 to 75.3) | -2.742 | 3.347 | 1.85 (0.21 to 3.48) | 1.68 (0.93 to 2.43)

Prevalence based on findings of Question 2A

a True Positive = Number of patients with ES correctly identified by test as having ES

b False Positive = Number of patients with NES incorrectly identified by test as having ES

c True Negative = Number of patients with NES correctly identified by test as having NES

d False Negative = Number of patients with ES incorrectly identified by test as having NES

Bolded effect size data indicate a statistically significant difference.

e Calculated using methodology of Littenburg and Moses

f Calculated using methodology of Hasselblad and Hedges (NB. D, which is the Ln of the odds ratio, can be converted to d by multiplying D by √3/π)

Evidence Table 21. Continuous diagnostic performance data in studies of blood prolactin level measurement

| Serum Prolactin Levels | | | | | | Calculated By ECRI
| Normal Range For Lab
Reference | Sample Time(s) | Study Arm | N | Mean (SD) | P = (Author Reported) | Prevalence of ES (%) | Power to Detect Difference | Between Groups Effect Size Hedges'd (CI) | P
Zelnick (1991) | >15 ng/ml | ES (Mixed) | 17 | 26.5 (SE: 3.3) | <0.01 | 62.9 | 0.9989 | 1.69 (0.79 to 2.59) | 0.000240
| T1 = Within 90 mins of seizure
| | Syncope | 10 | 7.3 (SE: 0.9)
Mishra (1990) | Mean: 278 (SD: 120.0) μIU/ml | ES (combined) | 35 | 1584 (876) | NR | 63.6 | 1.0000 | 1.66 (1.03 to 2.29) | 0.000000
| | PsyS | 20 | 405 (19)
| T1 = Within 20 mins of seizure
| | GTCS | 15 | 2230 (966) | <0.001 | 42.8 | 0.9999 | 2.83 (1.89 to 3.78) | 0.000000
| | PsyS | 20 | 405 (19)
| | CPS | 11 | 1757 (1044) | <0.01 | 35.5 | 0.9699 | 2.15 (1.24 to 3.06) | 0.000000
| | PsyS | 20 | 405 (19)
| | SPS | 9 | 400 (28) | NS | 45.0 | 0.0686 | -0.22 (-1.01 to 0.57) | 0.583966
| | PsyS | 20 | 405 (19)
| T2 = Approx. 6 to 8 hours post-seizure | ES (combined) | 35 | 332 (84) | NR | 63.6 | 0.8645 | -0.69 (-1.25 to -0.25) | 0.017282
| | PsyS | 20 | 380 (26)
| | GTCS | 15 | 291 (68.0) | <0.01 | 42.8 | 0.9928 | -1.79 (-2.58 to -1.00) | 0.000009
| | PsyS | 20 | 380 (26)
| | CPS | 11 | 360 (119) | NS | 35.5 | 0.0729 | -0.27 (-1.01 to 0.47) | 0.478861
| | PsyS | 20 | 380 (26)
| | SPS | 9 | 365 (47) | NS | 31.0 | 0.1146 | -0.43 (-1.23 to 0.36) | 0.284746
| | PsyS | 20 | 380 (26)

ES Epileptic seizures

CPS Complex partial seizures

GTCS Generalized tonic clonic seizures

PsyS Psychogenic seizure

Evidence Table 22. Articles addressing Minnesota Multiphasic Personality Inventory excluded for quality reasons

Reference | Country | Reason(s) for Exclusion
Holmes (1998) | United States | Study in which MMPI data were collected from a total of 347 patients. Authors presented data in graphical form only. These data did not include dispersion (i.e SD, SEM) data. Nor did they present the results of a statistical analysis of the data beyond indicating that significant differnces existed across four diagnostic groups. Data from this study do not allow one to draw independent conclusions about the clinical utility of the MMPI in differentiating patients with epileptic seizures from patients with nonepileptic seizures.
Brown (1991) | United States | Diagnostic case-control study in which MMPI (and other neuropsychological) data were collected from 23 patients with confirmed nonepileptic seizures and 25 patients with EEG confirmed epileptic seizures. Authors presented MMPI data in graphical form only. These data did not include dispersion (i.e. SD, SEM) data. Presentation of findings of statistical analysis of data was incomplete. Data from this study do not allow one to draw independent conclusions about the clinical utility of the MMPI in differentiating patients with epileptic seizures from patients with nonepileptic seizures.

Evidence Table 23. Articles addressing video EEG excluded for quality reasons

Reference | Country | Reason(s) for Exclusion
Drury (1999) | United States | Case series in which only 10 of 18 patients (55.0%) that entered study were followed up (4 of 8 patients with epileptic seizures and 6 of 10 patients with nonepileptic seizures). As a consequence of the large attrition rate (45.0 %) we are precluded from drawing valid conclusions pertaining the effectiveness of this diagnostic combination in improving patient outcomes.
| | Follow-up data poorly described making conclusions about value of diagnostic in improving patient outcome impossible to draw.
Shihabuddin (1999) | United States | Case series in which only 64 of 125 patients (51.2 %) that entered study were followed up. As a consequence of the large attrition rate (48.8 %) we are precluded from drawing valid conclusions pertaining the effectiveness of this diagnostic combination in improving patient outcomes.

Evidence Table 24. Articles addressing ambulatory EEG excluded for quality reasons

Reference | Country | Reason(s) for Exclusion
Shihabuddin (1999) | United States | Case series in which only 64 of 125 patients (51.2 %) that entered study were followed up. As a consequence of the large attrition rate (48.8 %) we are precluded from drawing valid conclusions pertaining the effectiveness of this diagnostic combination in improving patient outcomes.
Sivenius (1984) | Finland | Uninterpretable presentation of data.

Evidence Table 25. Articles included in previous technology assessments of utility of video-EEG

Technology Assessment | References Forming Database | Reason Article Not Included in Current Report (If Applicable)
AHCPR (1990) | Pierelli (1989) | Study reports on diagnostic yield and diagnoses made as a consequence of using vEEG. No reference standard was used so no diagnostic performance data presented. Patients were not followed to confirm accuracy of diagnoses. Thus, data from this study cannot be used to determine the efficacy of vEEG in the differential diagnosis of epileptic seizures from nonepileptic seizures.
| Rowan (1987) | Study reports on diagnostic yield and diagnoses made as a consequence of using vEEG. No reference standard was used so no diagnostic performance data presented. Patients were not followed to confirm accuracy of diagnoses. Thus, data from this study cannot be used to determine the efficacy of vEEG in the differential diagnosis of epileptic seizures from nonepileptic seizures.
| Willmer (1986) | Study reports on diagnostic yield and changes in diagnosis made as a consequence of using outpatient vEEG. No reference standard was used so no diagnostic performance data presented. Patients were not followed to confirm accuracy of diagnoses. Thus, data from this study cannot be used to determine the efficacy of vEEG in the differential diagnosis of epileptic seizures from nonepileptic seizures.
| Egli (1985) | Study reports on diagnostic yield and diagnoses made as a consequence of using vEEG. No reference standard was used so no diagnostic performance data were presented. Patients were not followed to confirm accuracy of diagnoses. Thus, data from this study cannot be used to determine the efficacy of vEEG in the differential diagnosis of epileptic seizures from nonepileptic seizures.
| Wada (1985) | Retrospective study that reports on diagnostic yield and diagnoses made as a consequence of using outpatient vEEG. No reference standard was used so no diagnostic performance data presented. Followed data were only presented for a few (15 of 136) patients making it impossible to confirm accuracy of diagnoses. Thus, data from this study cannot be used to determine the efficacy of vEEG in the differential diagnosis of epileptic seizures from nonepileptic seizures.
| Perry (1983) | Retrospective study reports on diagnostic yield and diagnoses made as a consequence of using vEEG and rEEG. No reference standard was used so diagnostic performance data not presented. Patients were not followed up to confirm accuracy of diagnoses. Thus, data from this study cannot be used to determine the efficacy of vEEG in the differential diagnosis of epileptic seizures from nonepileptic seizures.
| Sutula (1981) | Study reports on diagnostic yield and diagnoses made as a consequence of using vEEG and rEEG. No reference standard was used so no diagnostic performance data were presented. Patients were followed but data on changes in seizure frequency data were presented for the study population as a whole and not by diagnosis. As a consequence data from this study cannot be used to determine the efficacy of vEEG in the differential diagnosis of epileptic seizures from nonepileptic seizures.
| Holmes (1980) | This study utilized vEEG in conjunction with clinical opinion to characterize patients into patients with ES and patients with psychogencic seizures. The characteristics of both the patients and the seizures that they suffered were then compared. Thus this study is not a study of the effectiveness of vEEG in differentiating epileptic seizures from nonepileptic seizures and its data. Thus, data from this study cannot be used to determine the efficacy of vEEG in the differential diagnosis of epileptic seizures from nonepileptic seizures.
AHRQ (2001) | Shihabuddin (1999) | Study met general and question specific inclusion criteria for this report. However, study was excluded from current report for reasons of quality.
| Mohan (1996) | Study reports on diagnostic yield and diagnoses made as a consequence of using outpatient vEEG. No reference standard was used so no diagnostic performance data presented. Patients were not followed to confirm accuracy of diagnoses. Thus, data from this study cannot be used to determine the efficacy of vEEG in the differential diagnosis of epileptic seizures from nonepileptic seizures.
| Chen (1995) | Retrospective study that reports on diagnostic yield and differential diagnoses made as a consequence of using outpatient vEEG. No reference standard was used so no diagnostic performance data presented. Patients were not followed to confirm accuracy of diagnoses. Thus, data from this study cannot be used to determine the efficacy of vEEG in the differential diagnosis of epileptic seizures from nonepileptic seizures.
| Foley (1995) | Study reports on diagnostic yield and changes in diagnosis made as a consequence of using outpatient vEEG. No reference standard was used so no diagnostic performance data presented. Patients were not followed to confirm accuracy of diagnoses. Thus, data from this study cannot be used to determine the efficacy of vEEG in the differential diagnosis of epileptic seizures from nonepileptic seizures.
| Bye (1990) | Study reports on diagnostic yield and diagnoses made as a consequence of using outpatient vEEG. No reference standard was used so no diagnostic performance data presented. Patients were not followed to confirm accuracy of diagnoses. Thus, data from this study cannot be used to determine the efficacy of vEEG in the differential diagnosis of epileptic seizures from nonepileptic seizures.
| Duchowny (1988) | Study reports on diagnostic yield and diagnoses made as a consequence of using outpatient vEEG. No reference standard was used so no diagnostic performance data presented. Patients were not followed up to confirm accuracy of diagnoses. Thus, data from this study cannot be used to determine the efficacy of vEEG in the differential diagnosis of epileptic seizures from nonepileptic seizures.
| Roberts (1985) | Study reports on diagnostic yield and diagnoses made as a consequence of using outpatient vEEG. No reference standard was used so no diagnostic performance data presented. Patients were not followed to confirm accuracy of diagnoses. Thus, data from this study cannot be used to determine the efficacy of vEEG in the differential diagnosis of epileptic seizures from nonepileptic seizures.

## Question 3

Is there evidence that patients with treatment-resistant epilepsy are not optimized at their current level of treatment?

Evidence Table 26. Studies that provided evidence indicating that not all patients were optimized prior to study entry

Reference | Patient Population | N | Assessed Medical Intractability or Optimization | Required Compliance With Prescribed Drug Regimen | Reported Patients Not in The Therapeutic Range | Reported Patients Not in The Upper End of The Therapeutic Range | Reported Patients Who Had Not Been Titrated | Reported Patients Whose Drug Regimen Produced Side Effects
Studies conducted in the United States
McCabe (2001) | Adult | 21 | No | No | No | Yes | NR | NR
Sachdeo (2001) | Mixed adult and pediatric | 143 | No | Yes | No | Yes | NR | NR
Morris (1995) | Mixed adult and pediatric | 100 | No | No | NR | NR | NR | Yes
Gilman (1994) | Pediatric | 72 | Yes | No | NR | NR | Yes | NR
Leppik (1991) | Adult | 67 | No | Yes | Yes | Yes | NR | NR
Theodore (1991) | Adult | 47 | No | No | Yes | Yes | NR | NR
Lesser (1984) | Adult | 28 | No | No | Yes | Yes | Yes | Yes
Studies conducted in other countries
Jozwiak (2000) | Mixed adult and pediatric | 126 | No | No | No | Yes | NR | NR
El Desoky (1999) | Mixed adult and pediatric | 227 | Yes | No | Yes | NR | NR | NR
Bruni (1998) | Adult | 141 | No | No | Yes | Yes | NR | NR
Hermanns (1996) | Mixed adult and pediatric | 74 | Yes | No | No | Yes | Yes | NR
Semah (1994) | Adult | 18 | No | No | No | Yes | NR | NR
Bittencourt (1993) | Mixed adult and pediatric | 51 | No | No | No | NR | NR | Yes
Karande (1992) | NR | 54 | Yes | No | Yes | Yes | Yes | NR
Jawad (1989) | Adult | 24 | No | Yes | No | Yes | NR | NR
Cornaggia (1985) | Adult | 66 | No | Yes | No | Yes | NR | NR
Callaghan (1984) | Mixed adult and pediatric | 35 | No | No | Yes | Yes | NR | NR
Schmidt (1983) | Adult | 35 | No | No | Yes | Yes | Yes | NR
Milano Collaborative Group for Studies on Epilepsy (1977) | Mixed adult and pediatric | 60 | Yes | No | Yes | Yes | Yes | Yes
Shorvon (1977) | Adult | 50 | Yes | No | Yes | Yes | NR | NR

## Question 4

Which drug treatment strategy, 1) sequential monotherapy, 2) polytherapy, or 3) optimized current therapy leads to improved outcomes for patients with treatment-resistant epilepsy, and what are the relative improvements obtained with each strategy?

Evidence Table 27. General information for studies of sequential monotherapy

Reference | Author Affiliation | Patients | Multicenter | For-Profit Funding | Minimum Number of AEDs | Minimum Monthly Seizure Frequency | Minimum Duration of Condition | Were Side Effects in The Definition of Treatment-Resistant Epilepsy
Sachdeo (2001) | New Jersey Comprehensive Epilepsy Center, University of Medicine & Dentistry of New Jersey, New Brunswick, USA. | Uncontrolled partial seizures while receiving carbamazepine monotherapy | Yes | Yes | 1 | 2 | NR | No
Beydoun (2000) | University of Michigan Medical Center, Ann Arbor, MI 48109, USA. | Inadequately controlled partial seizures, with or without secondary generalization | Yes | Yes | 1 | 2 | NR | No
Kanner (2000) | Department of Neurological Sciences, Rush Medical College, Rush Epilepsy Center and Rush-Presbyterian Saint Luke's Medical Center, Chicago, Illinois 60612, USA. akanner@rush.edu | Partial seizures that had failed to respond to monotherapy trials | No | No | 1 | NR | NR | No
Schachter (1999) | Department of Neurology, Beth Israel Deaconess Medical Center and Harvard Medical School, Boston, MA 02215, USA. | Refractory partial seizures with or without secondary generalization | Yes | Yes | 1 | 30 | NR | No
Gilliam (1998) | University of Alabama at Birmingham, 35294-0021, USA. | Partial seizures, with or without secondary generalization, not adequately controlled by either carbamazepine or phenytoin monotherapy | Yes | Yes | 1 | 4 | NR | No
Bergey (1997) | Department of Neurology, University of Maryland Medical Center, Baltimore, USA. | Refractory complex partial seizures or secondarily generalized seizures | Yes | Yes | 1 | 3 | NR | No
Beydoun (1997a) | Department of Neurology, University of Michigan Medical Center, Ann Arbor 48109, USA. | Poorly controlled partial epilepsy, with or without secondary generalization | Yes | Yes | 1 | 2 | NR | No
Beydoun (1997b) | Department of Neurology, University of Michigan Medical Center, Ann Arbor, USA. | Refractory complex partial seizures or secondarily generalized seizures | Yes | Yes | 1 | 2 | NR | No
Sachdeo (1997a) | University of Medicine and Dentistry of New Jersey, Robert Wood Johnson Medical School, New Brunswick 08903-0019, USA. | Uncontrolled partial onset seizures, with or without secondary generalization | No | Yes | 1 | 4 | NR | No
Devinsky (1995) | NYU School of Medicine, Hospital for Joint Diseases, New York 10003, USA. | Medically intractable partial seizures | Yes | Yes | 2 | NR | NR | No
Schachter (1995) | Comprehensive Epilepsy Center, Beth Israel Hospital, Boston, Massachusetts, USA. | Partial seizures, with or without secondary generalized seizures, inadequately controlled with a single AED | Yes | Yes | 1 | NR | NR | No
Theodore (1995) | National Institutes of Health, Bethesda, Maryland 20892, USA. | Partial and secondarily generalized seizures, not controlled by a combination of carbamazepine and phenytoin | No | No | 2 | NR | NR | No
Faught (1993) | Department of Neurology, University of Alabama School of Medicine, Birmingham. USA | Uncontrolled partial-onset seizures with or without secondary generalization | Yes | Yes | 1 | 4 | NR | No

Evidence Table 28. General information for studies of sequential monotherapy

Reference | Reported Maximum Tolerable Dose of Prior Drugs | Required Good Compliance to Prior Drugs | All Patients Seen During Presurgical Evaluation | Patients Continue to Take Their Prestudy Drugs | Prospective | Randomized | Type of Control | Patients Receiveed a Placebo During The Baseline | Patients Blinded | Observers Blinded | Length of Baseline (Weeks) | Length of Titration Period (Weeks) | Length of Maintenance Period (Weeks) | Plasma Levels Monitored
Sachdeo (2001) | No | Yes | No | No | Yes | Yes | Different dose | No | Yes | Yes | 8 | 4 or 10 | 12 or 18 | Yes
Beydoun (2000) | No | Yes | No | No | Yes | Yes | Different dose | No | Yes | Yes | 7 | 2 | 112 days | Yes
Kanner (2000) | Yes | No | No | No | Yes | No | None | No | No | No | NR | 5–10 days | 3 months | Yes
Schachter (1999) | No | Yes | Yes | No | Yes | Yes | Placebo | No | Yes | Yes | NR | 2 days | 8 days | Yes
Gilliam (1998) | No | No | No | Yes | Yes | Yes | Different drug | No | Yes | Yes | 8 | 8 | 12 | Yes
Bergey (1997) | No | No | Yes | No | Yes | Yes | Different dose | No | Yes | Yes | 12 | 0 | 8 days | Yes
Beydoun (1997a) | No | Yes | No | No | Yes | Yes | Different dose | No | Yes | Yes | 8 or 12 | 8 | 16 | Yes
Beydoun (1997b) | No | No | No | No | Yes | Yes | Different dose | No | Yes | Yes | 8 | 10 | 16 | Yes
Sachdeo (1997a) | No | Yes | No | No | Yes | Yes | Different dose | No | Yes | Yes | 8 | 5 | 11 | Yes
Devinsky (1995) | No | Yes | Yes | No | Yes | Yes | Placebo | No | Yes | Yes | 4 | 2 days | 8 days | Yes
Schachter (1995) | No | No | No | No | Yes | Yes | Different dose | No | Yes | Yes | 8 | 6 | 12 | No
Theodore (1995) | No | No | Yes | No | Yes | Yes | Placebo | No | Yes | Yes | 6 days | 4 days | 2 | Yes
Faught (1993) | No | Yes | No | No | Yes | Yes | Different drug | No | Yes | Yes | 8 | 4 | 12 | Yes

Evidence Table 29. Reporting characteristics in trials of sequential monotherapy

| | | Reported
Reference | Seizure Types | Used Seizure Diaries | Individual Patient Data | Baseline Seizure Frequency | Seizure Frequency | Adverse Effects | Quality of Life | Functional Status/Ability | Return to Work | Return to School
Sachdeo (2001) | Partial | Yes | No | Yes | Yes | Yes | No | No | No | No
Beydoun (2000) | Partial | Yes | No | Yes | Yes | Yes | No | No | No | No
Kanner (2000) | Partial | Yes | No | No | Yes | Yes | No | No | No | No
Schachter (1999) | Partial | No | No | Yes | Yes | Yes | No | No | No | No
Gilliam (1998) | Partial | Yes | No | Yes | Yes | Yes | No | No | No | No
Bergey (1997) | Partial | No | No | Yes | Yes | Yes | No | No | No | No
Beydoun (1997a) | Partial | Yes | No | Yes | Yes | Yes | No | No | No | No
Beydoun (1997b) | Partial | Yes | No | Yes | Yes | Yes | Yes | No | No | No
Sachdeo (1997a) | Partial | Yes | No | Yes | Yes | Yes | No | No | No | No
Devinsky (1995) | Partial | Yes | No | Yes | Yes | Yes | No | No | No | No
Schachter (1995) | Partial | Not reported | No | Yes | Yes | Yes | Yes | Yes | No | No
Theodore (1995) | Partial | No | No | Yes | Yes | Yes | Yes | No | No | No
Faught (1993) | Partial | Yes | No | Yes | Yes | Yes | No | No | No | No

Evidence Table 30. Drug characteristics in studies of sequntial monotherapy

Reference | Name of Drug Given to This Group of Patients | Mechanism(s) of Action^a^ | Minimum Dose (mg/day) | Maximum Dose (mg/day)
Sachdeo (2001) | Oxcarbazepine | Sodium | NR | 2400
Beydoun (2000) | Oxcarbazepine | Sodium | 1800 | 2400
Kanner (2000) | Primidone | GABA | 50 | 750
Schachter (1999) | Oxcarbazepine | Sodium | NR | 2400
Gilliam (1998) | Lamotrigine | Sodium | 300 | 500
Bergey (1997) | Gabapentin | Inhibitory | 3000 | 3600
Beydoun (1997a) | Valproate | Inhibitory | 80 μg/mL | 150 μg/mL
Beydoun (1997b) | Gabapentin | Inhibitory | NR | 2400
Sachdeo (1997a) | Topiramate | Sodium, Calcium, Inhibitory, Excitatory | NR | 1000
Devinsky (1995) | Felbamate | Sodium, Inhibitory, Excitatory | NR | 3600
Schachter (1995) | Tiagabine | Inhibitory | NR | 36
Theodore (1995) | Felbamate | Sodium, Inhibitory, Excitatory | NR | 3600
Faught (1993) | Felbamate | Sodium, Inhibitory, Excitatory | NR | 3600

a The mechamism(s) of drug action were based on Table 3 of Brodie (2002).

μg/mL Micrograms per milliliter

Evidence Table 31. Numbers of patients and attrition in studies of sequential monotherapy

| | | Number of Patients
Reference | Drug And Dose (mg/day) | Characteristics Reported For Patients Who Started or Completed The Study | Started The Study | Exited Due to an Increase in Seizures | Exited Due to Adverse Effects | Exited For Other Reasons | Completed The Study | With Reported Patient Characteristics
Sachdeo (2001) | Oxcarbazepine 2400 | Neither | 51 | 30 | 0 | 5 | 16 | 49
Beydoun (2000) | Oxcarbazepine 2400 | Started | 41 | 14 | 6 | 1 | 20 | 41
Kanner (2000) | Primidone 750 | Started | 30 | 2 | 7 | 0 | 21 | 30
Schachter (1999) | Oxcarbazepine 2400 | Started | 51 | 24 | 2^a^ | 1a | 24 | 51
Gilliam (1998) | Lamotrigine 500 | Started | 76 | 22^a^ | 15^a^ | 11^a^ | 28 | 76
Bergey (1997) | Gabapentin 3600 | Started | 40 | 18 | 0 | 1 | 21 | 40
Beydoun (1997a) | Valproate 150 μg/mL | Neither | 131 | 12^a^ | 31^a^ | 35^a^ | 53^a^ | 96
Beydoun (1997b) | Gabapentin 2400 | Started | 91 | 66 | 4 | 4 | 17 | 91
Sachdeo (1997a) | Topiramate 1000 | Started | 24 | 9 | 1 | 1 | 13 | 24
Devinsky (1995) | Felbamate 3600 | Started | 25 | 11^a^ | 0 | 5 | 9 | 25
Schachter (1995) | Tiagabine 36 | Started | 96 | 58^a^ | 0 | 0 | 38^a^ | 96
Theodore (1995) | Felbamate 3600 | Started | 21 | 2 | 6 | 0 | 13 | 21
Faught (1993) | Felbamate 3600 | Started | 56 | 18 | 6 | 5 | 27 | 56

a Calculated by ECRI based on reported information

μg/mL Micrograms per milliliter

Evidence Table 32. Age, gender, and duration of condition of patients in studies of sequential monotherapy

Reference | Drug And Dose (mg/day) | Age Mean | Age SD | Minimum Age | Maximum Age | Number of Males | Number of Females | Mean Duration of Epilepsy | Duration SD | Median Duration of Epilepsy
Sachdeo (2001) | Oxcarbazepine 2400 | 35.6 | NR | 12 | 65 | 22 | 27 | NR | NR | NR
Beydoun (2000) | Oxcarbazepine 2400 | 35.1 | NR | 13 | 59 | 15 | 26 | NR | NR | NR
Kanner (2000) | Primidone 750 | 35.7 | 14 | 4 | 73 | 11 | 19 | 23.3 | 15.2 | NR
Schachter (1999) | Oxcarbazepine 2400 | 33 | NR | NR | NR | 31 | 20 | NR | NR | NR
Gilliam (1998) | Lamotrigine 500 | 37 | NR | 13 | 73 | 33 | 43 | NR | NR | NR
Bergey (1997) | Gabapentin 3600 | 36.1 | 10.2 | 19 | 61 | 19 | 21 | 19.8 | 12.8 | NR
Beydoun (1997a) | Valproate 150 (g/mL | 34 | NR | 10 | 70 | 43 | 53 | NR | NR | NR
Beydoun (1997b) | Gabapentin 2400 | 37.1 | 12.2 | 14 | 64 | 35 | 56 | NR | NR | 20
Sachdeo (1997a) | Topiramate 1000 | 39.3 | 11.0 | NR | NR | 9 | 15 | 22 | 12.5 | NR
Devinsky (1995) | Felbamate 3600 | 33.7 | NR | 20 | 60 | 11 | 14 | NR | NR | NR
Schachter (1995) | Tiagabine 36 | NR | NR | NR | NR | NR | NR | NR | NR | NR
Theodore (1995) | Felbamate 3600 | 34.1^a,b^ | 9.2^a,b^ | 14^a^ | 55^a^ | 10^a,b^ | 11^a,b^ | 23.4^a,b^ | 11.5^a,b^ | NR
Faught (1993) | Felbamate 3600 | 33.4 | NR | 16.3 | 71.7 | 32 | 24 | NR | NR | NR

a Reported only for the entire patient group, not separately for different groups.

b Information reported by a secondary publication.

μg/mL Micrograms per milliliter

Evidence Table 33. Baseline seizure frequencies and specific types of partial seizures in studies of sequential monotherapy

| | Seizure Frequency | | | | | | Number of Patients With
Reference | Drug And Dose (mg/day) | Type of Baseline Seizure | Mean Baseline | SD of Baseline | Median Baseline | Minimum Monthly | Maximum Monthly | Partial Seizures | Complex Partial Seizures | Simple Partial Seizures | Secondarily Generalized Seizures
Sachdeo (2001) | Oxcarbazepine 2400 | Partial | NR | NR | NR | NR | NR | 49 | 43 | 26 | 31
Beydoun (2000) | Oxcarbazepine 2400 | Partial | NR | NR | 10.5 | NR | NR | 41 | NR | NR | NR
Kanner (2000) | Primidone 750 | NR | NR | NR | NR | NR | NR | 30 | 30 | NR | 16
Schachter (1999) | Oxcarbazepine 2400 | Partial | 74.5^a^ | NR | 74.5^a^ | NR | NR | 51 | NR | NR | NR
Gilliam (1998) | Lamotrigine 500 | Partial | NR | NR | 9 | 1 | 737 | 76 | 64 | 31 | 38
Bergey (1997) | Gabapentin 3600 | Partial | NR | NR | 5.8 | 3 | 285 | 40 | NR | NR | 37
Beydoun (1997a) | Valproate 150 μg/mL | Complex partial | NR | NR | 6.7^c^ | NR | NR | 96 | 96 | 32 | 59
Beydoun (1997b) | Gabapentin 2400 | Partial | 8.6 | 7 | 6.5 | NR | NR | 91 | 83 | 61 | 31
Sachdeo (1997a) | Topiramate 1000 | Partial | 17.9 | 42.5 | 6.5 | NR | NR | 24 | 23 | 2 | 4
Devinsky (1995) | Felbamate 3600 | Partial | 18.3 | NR | NR | NR | NR | 25 | NR | NR | NR
Schachter (1995) | Tiagabine 36 | Complex partial | NR | NR | 7.3 | NR | NR | 96 | 96 | NR | NR
Theodore (1995) | Felbamate 3600 | Complex partial | 6.4^b^ | 8.2^b^ | NR | NR | NR | 21 | NR | NR | NR
Faught (1993) | Felbamate 3600 | Partial | 12.4 | NR | NR | 3.7 | 49.1 | 56 | NR | NR | NR

a Study did not report whether the reported value was a mean or median

b Information obtained from a secondary publication.

c Calculated by ECRI based on reported information

μg/ml Micrograms per milliliter

Evidence Table 34. Known etiology and prior drugs in studies of sequential monotherapy

| | Number of Patients | | | | Number of Patients Receiving Specific Prior Drugs
Reference | Drug And Dose (mg/day) | With Known Etiology | On One AED Prior to The Study | On Two AEDs Prior to The Study | On Three or More AEDs Prior to The Study | Carbamazepine | Felbamate | Gabapentin | Lamotrigine | Lorazepam | Phenytoin | Phenobarbital | Primidone | Valproate
Sachdeo (2001) | Oxcarbazepine 2400 | NR | 49 | 0 | 0 | 49 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Beydoun (2000) | Oxcarbazepine 2400 | NR | NR | NR | 0 | 22 | NR | 4 | 5 | NR | 8 | NR | NR | 6
Kanner (2000) | Primidone 750 | NR | 30 | 0 | 0 | >0 | 0 | 0 | 0 | 0 | >0 | 7 | 0 | >0
Schachter (1999) | Oxcarbazepine 2400 | NR | NR | NR | NR | NR | NR | NR | NR | 45 | NR | NR | NR | NR
Gilliam (1998) | Lamotrigine 500 | NR | 76 | 0 | 0 | 48 | 0 | 0 | 0 | 0 | 28 | 0 | 0 | 0
Bergey (1997) | Gabapentin 3600 | NR | 23 | 16 | 1 | 18 | 7 | NR | NR | NR | 14 | 0 | NR | 14
Beydoun (1997a) | Valproate 150 μg/mL | NR | 96 | 0 | 0 | >0 | NR | NR | NR | NR | >0 | >0 | >0 | NR
Beydoun (1997b) | Gabapentin 2400 | 53 | 57 | 34 | 0 | 67 | 8 | NR | NR | NR | 26 | NR | NR | 26
Sachdeo (1997a) | Topiramate 1000 | NR | 20 | 4 | 0 | 10 | 6 | 2 | 0 | 0 | 4 | 2 | 0 | 4
Devinsky (1995) | Felbamate 3600 | NR | 0 | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
Schachter (1995) | Tiagabine 36 | NR | 96 | 0 | 0 | NR | NR | NR | NR | NR | NR | NR | NR | NR
Theodore (1995) | Felbamate 3600 | NR | 0 | 21 | 0 | 21 | 0 | 0 | 0 | 0 | 21 | 0 | 0 | 0
Faught (1993) | Felbamate 3600 | NR | 56 | 0 | 0 | NR | NR | NR | NR | NR | NR | NR | NR | NR

μg/mL Micrograms per milliliter

>0 Atleast one patient had received the drug, but the study did not report the exact number of patients who received the drug.

Evidence Table 35. Seizure frequency outcomes in studies of sequential monotherapy

Reference | Patient Group Drug And Dose (mg/day) | Overall Seizure Type^a^ | Specific Seizure Type(s)^a^ | Description of Outcomes | N | Number of Patients Using Intent-to-Treat | Outcome^b^
Sachdeo (2001) | Oxcarbazepine 2400 | PAR | PAR | Median time to exit | 49 | 51 | 68 days
| | | | Number of patients who completed 18 weeks of monotherapy | 49 | 51 | 16
| | | | Number of patients who exited due to a new-onset tonic-clonic seizure | 49 | 51 | 5
| | | | Number of patients who exited due to any of four exit criteria | 49 | 51 | 30
| | | | Number of patients who exited due to doubling of monthly seizure frequency | 49 | 51 | 15
| | | | Number of patients who exited due to doubling of two-day seizure frequency | 49 | 51 | 7
| | | | Number of patients who exited due to prolongation of a tonic-clonic seizure | 49 | 51 | 3
Beydoun (2000) | Oxcarbazepine 2400 | PAR | PAR | Number of patients with 50% or more seizure reduction | 41 | 41 | 17c
| | | | Median time to exit | 34 | 41 | Median not yet reached
| | | | Number of patients who exited due to a new-onset secondarily generalized seizure | 34 | 41 | 5
| | | | Number of patients who exited due to any of four exit criteria | 34 | 41 | 14
| | | | Number of patients who exited due to doubling of monthly seizure frequency | 34 | 41 | 6
| | | | Number of patients who exited due to doubling of two-day seizure frequency | 34 | 41 | 3
| | | | Number of patients who exited due to prolongation of secondarily generalized seizures | 34 | 41 | 0
| | | | Number of patients seizure free | 41 | 41 | 5^c^
Kanner (2000) | Primidone 750 | PAR | PAR | Mean time on monotherapy | 30 | 30 | 16 months SD 21.6 months
| | | | Median time on monotherapy | 30 | 30 | 7.5 months range 0.5–80
| | | | Number of patients seizure free and no side effects for at least 12 months | 30 | 30 | 4
| | | | Number of patients seizure free and no side effects for at least 3 months | 30 | 30 | 15
| | | | Number of patients seizure free and no side effects for at least 6 months | 30 | 30 | 9
| | | | Number of patients who completed at least 12 months of monotherapy | 30 | 30 | 9
| | | | Number of patients who completed at least 3 months of monotherapy | 30 | 30 | 25
| | | | Number of patients who completed at least 6 months of monotherapy | 30 | 30 | 21
Schachter (1999) | Oxcarbazepine 2400 | PAR | PAR | Median monthly seizure frequency | 51 | 51 | 6.8^c^
| | | | Number of patients who exited due to a fourth seizure | 51 | 51 | 24
| | | | Number of patients who exited due to a new-onset secondarily generalized seizure | 51 | 51 | 0
| | | | Number of patients who exited due to any of three exit criteria | 51 | 51 | 24
| | | | Number of patients who exited due to doubling of monthly seizure frequency | 51 | 51 | 0
| | | | Number of patients who exited due to serial seizures | 51 | 51 | 0
| | | | Number of patients who exited due to status epilepticus | 51 | 51 | 0
| | | | Number of patients seizure free | 51 | 51 | 13
| | | | Risk ratio of time to exit | 102 | 102 | 0.2 (CI: 0.11 to 0.38)
Gilliam (1998) | Lamotrigine 500 | PAR | PAR | Median time to exit | 50 | 50 | 168 days
| | | | Number of patients who completed 12 weeks of monotherapy | 76 | 76 | 28
| | | | Number of patients who exited due to any of four exit criteria | 76 | 76 | 22c
Bergey (1997) | Gabapentin 3600 | PAR | PAR | Mean time on monotherapy | 40 | 40 | 151 hours
| | | | Number of patients who exited due to a continued intolerance to study medication following dose reduction | 40 | 40 | 0
| | | | Number of patients who exited due to a fourth seizure | 40 | 40 | 17
| | | | Number of patients who exited due to a new-onset secondarily generalized seizure | 40 | 40 | 0
| | | | Number of patients who exited due to any of six exit criteria | 40 | 40 | 19
| | | | Number of patients who exited due to other lack of efficacy | 40 | 40 | 0
| | | | Number of patients who exited due to prolongation of secondarily generalized seizures | 40 | 40 | 1
| | | | Number of patients who exited due to status epilepticus | 40 | 40 | 0
| | | | Number of patients seizure free | 40 | 40 | 11
Beydoun (1997a) | Valproate 150 μg/mL | PAR | CPS | Number of patients with 50% or more seizure reduction | 96 | 96 | 36^c^
| | | SPS | Number of patients with 50% or more seizure reduction | 30 | 32 | 11^c^
| | | SG | Number of patients with 50% or more seizure reduction | 30 | 59 | 17^c^
| | | CPS | Number of patients with 75% or more seizure reduction | 96 | 96 | 22^c^
| | | CPS | Number of patients with any reduction in seizure frequency | 96 | 96 | 66^c^
| | | SPS | Number of patients with any reduction in seizure frequency | 30 | 32 | 23^c^
| | | SG | Number of patients with any reduction in seizure frequency | 30 | 59 | 20^c^
| | | CPS | Median % reduction from baseline in seizure frequency | 96 | 96 | 30
| | | SG | Median % reduction from baseline in seizure frequency | 30 | 59 | 70
| | | CPS | Median difference from baseline in seizure frequency | 96 | 96 | 2.8
| | | SPS | Median difference from baseline in seizure frequency | 30 | 32 | 4.9
| | | SG | Median difference from baseline in seizure frequency | 30 | 59 | 1.9
| | | PAR | Number of patients who completed 16 weeks of monotherapy | 96 | 96 | 84
| | | CPS | Number of patients seizure free | 96 | 96 | 9^c^
Beydoun (1997b) | Gabapentin 2400 | PAR | CPS SG | Mean time on monotherapy | 91 | 91 | 61 days
| | | CPS SG | Median time to exit | 91 | 91 | 75 days
| | | CPS SG | Number of patients who exited due to a new-onset secondarily generalized seizure | 91 | 91 | 11
| | | CPS SG | Number of patients who exited due to any of five exit criteria | 91 | 91 | 66
| | | CPS SG | Number of patients who exited due to clinical judgment of lack of efficacy | 91 | 91 | 21
| | | CPS SG | Number of patients who exited due to doubling of monthly seizure frequency | 91 | 91 | 12
| | | CPS SG | Number of patients who exited due to doubling of two-day seizure frequency | 91 | 91 | 21
| | | CPS SG | Number of patients who exited due to status epilepticus | 91 | 91 | 1
Sachdeo (1997a) | Topiramate 1000 | PAR | PAR | Number of patients with 50% or more seizure reduction | 24 | 24 | 11
| | | | Number of patients with 75% or more seizure reduction | 24 | 24 | 6
| | | | Number of patients who exited due to a new-onset secondarily generalized seizure | 24 | 24 | 3
| | | | Number of patients who exited due to any of four exit criteria | 24 | 24 | 9
| | | | Number of patients who exited due to doubling of monthly seizure frequency | 24 | 24 | 4
| | | | Number of patients who exited due to doubling of two-day seizure frequency | 24 | 24 | 1
| | | | Number of patients who exited due to prolongation of secondarily generalized seizures | 24 | 24 | 4
| | | | Number of patients seizure free | 24 | 24 | 3
| | | | Risk ratio of time to exit | 48 | 48 | 0.336 (CI: 0.149 to 0.757)
Devinsky (1995) | Felbamate 3600 | ALL | ALL | Mean rank of daily seizure frequency | 25 | 25 | 21.6
| | | | Median time to fourth seizure | 25 | 25 | 6.26 days
| | | | Number of patients who exited due to a fourth seizure | 25 | 25 | 11c
Schachter (1995) | Tiagabine 36 | PAR | CPS | Number of patients with 50% or more seizure reduction | 96 | 96 | 30
| | | PAR | Mean time on monotherapy | 96 | 96 | 62.9 days
| | | CPS | Median monthly seizure frequency | 96 | 96 | 5.0c
Theodore (1995) | Felbamate 3600 | PAR | CPS | Mean monthly seizure frequency | 21 | 21 | 24.4^c^
| | | SPS | Mean monthly seizure frequency | 21 | 21 | 0.9^c^
| | | SG | Mean monthly seizure frequency | 21 | 21 | 2.4^c^
| | ALL | ALL | Mean monthly seizure frequency | 21 | 21 | 27.8 ^c^
| | | | Number of patients who exited due to exit criteria | 21 | 21 | 8
| | | | Number of patients who exited due to status epilepticus | 21 | 21 | 0
| | PAR | PAR | Mean monthly seizure frequency | 21 | 21 | 25.3 ^c^
Faught (1993) | Felbamate 3600 | PAR | PAR | Number of patients who exited due to a new-onset tonic-clonic seizure | 45 | 45 | 4
| | | PAR | Number of patients who exited due to any of four exit criteria | 45 | 45 | 18
| | | SG | Number of patients who exited due to any of four exit criteria | 18 | 18 | 4
| | | PAR | Number of patients who exited due to doubling of monthly seizure frequency | 45 | 45 | 4
| | | PAR | Number of patients who exited due to doubling of two-day seizure frequency | 45 | 45 | 6
| | | PAR | Number of patients who exited due to prolongation of a tonic-clonic seizure | 45 | 45 | 7

a The following abbreviations for seizure types have been used in Evidence Table 35

ALL all seizures

CPS complex partial seizures

PAR partial seizures

SG secondarily generalized seizures

SPS simple partial seizures

b In the outcome column, a positive value for either medium % reduction from baseline or median difference from baseline represents a beneficial reduction in seizures. This conforms to the convention in the epilepsy literature.

c Calculated by ECRI based on published information

μg/mL micrograms per milliliter

Evidence Table 36. Adverse effects in studies of sequential monotherapy

Reference | Drug And Dose (mg/day) | Description of Adverse Effect | Severity of Adverse Effect | Number With This Effect / Number of Patients in The Group | Percentage
Sachdeo (2001) | Oxcarbazepine 2400 | Dizziness | | 3/45 | 7%
| | Headache | | 5/45 | 11%
| | Increase in seizures | Severe | 2/45 | 4%
| | Nausea | | 1/45 | 2%
Beydoun (2000) | Oxcarbazepine 2400 | Abnormal vision | | 7/41 | 17%
| | Accidental injury | Severe | 1/41 | 2%
| | Angina | Severe | 1/41 | 2%
| | Any | Severe | 2/41 | 5%
| | Diplopia | | 8/41 | 20%
| | Dizziness | | 19/41 | 46%
| | Fatigue | | 16/41 | 39%
| | Headache | | 9/41 | 22%
| | Nausea | | 12/41 | 29%
| | Rash | | 5/41 | 12%
| | Somnolence | | 12/41 | 29%
| | Vomiting | | 9/41 | 22%
Kanner (2000) | Primidone 750 | Any | Any | 16/30 | 53%
| | Attention | | 1/30 | 3%
| | Dizziness | Severe | 3/30 | 10%
| | Dizziness | Withdrawal | 1/30 | 3%
| | Dysthymic disorder | | 4/30 | 13%
| | Irritability | | 11/30 | 37%
| | Mood lability | | 11/30 | 37%
| | Poor frustration tolerance | | 11/30 | 37%
| | Sedation | | 5/30 | 17%
| | Sexual impotence | | 2/30 | 7%
Schachter (1999) | Oxcarbazepine 2400 | Any | Mild / moderate | 46/51 | 91%
| | Any | Any | 38/51 | 75%
| | Body as a whole | | 7/51 | 14%
| | Diplopia | | 6/51 | 12%
| | Dizziness | | 9/51 | 18%
| | Fatigue | | 5/51 | 10%
| | Gastrointestinal system | | 21/51 | 41%
| | Headache | | 10/51 | 20%
| | Nausea | | 10/51 | 20%
| | Nervous system | | 23/51 | 45%
| | Pruritus | | 9/51 | 18%
| | Skin | | 12/51 | 24%
| | Somnolence | | 8/51 | 16%
| | Special senses | | 8/51 | 16%
| | Vomiting | | 5/51 | 10%
Gilliam (1998) | Lamotrigine 500 | Any | | 57/76 | 75%
| | Asthenia | | 9/76 | 12%
| | Coordination abnormalities | | 9/76 | 12%
| | Dizziness | | 15/76 | 20%
| | Dyspepsia | | 0/76 | 0%
| | Headache | | 10/76 | 13%
| | Nausea | | 12/76 | 16%
| | Rash | | 8/76 | 11%
| | Somnolence | | 6/76 | 8%
| | Tremor | | 5/76 | 7%
| | Vomiting | | 8/76 | 11%
| | Rash | Withdrawal | 6/76 | 8%
| | Vomiting/Dizziness | Withdrawal | 1/76 | 1%
| | Dizziness | Withdrawal | 1/76 | 1%
| | Myalgia | Withdrawal | 1/76 | 1%
| | Personality disorder | Withdrawal | 1/76 | 1%
| | Alopecia | Withdrawal | 1/76 | 1%
| | Anxiety | Withdrawal | 2/76 | 2%
| | Ataxia | Withdrawal | 1/76 | 1%
| | Chest pain | Withdrawal | 1/76 | 1%
Bergey (1997) | Gabapentin 3600 | Anorexia | | 2/40 | 5%
| | Any | Any | 29/40 | 73%
| | Ataxia | Severe | 1/40 | 3%
| | Ataxia | | 8/40 | 20%
| | Death | Severe | 0/40 | 0%
| | Dizziness | | 7/40 | 18%
| | Dysarthria | | 5/40 | 13%
| | Fatigue | | 4/40 | 10%
| | Headache | Severe | 1/40 | 3%
| | Headache | | 3/40 | 8%
| | Myalgia | | 3/40 | 8%
| | Nystagmus | | 5/40 | 13%
| | Paresthesia | | 4/40 | 10%
| | Somnolence | | 6/40 | 15%
| | Tremor | | 3/40 | 8%
Beydoun (1997a) | Valproate 150 μg/mL | Alopecia | | 2/47 | 4%
| | Anorexia | | 0/47 | 0%
| | Asthenia | | 0/47 | 0%
| | Death | Severe | 1/47 | 2%
| | Diarrhea | | 2/47 | 4%
| | Headache | | 15/47 | 32%
| | Thrombocytopenia | | 0/47 | 0%
| | Tremor | | 3/47 | 6%
| | Vomiting | | 0/47 | 0%
| | Weight gain | | 2/47 | 4%
Beydoun (1997b) | Gabapentin 2400 | Any | | 80/91 | 88%
| | Ataxia | | 12/91 | 13%
| | Death | Severe | 0/91 | 0%
| | Dizziness | | 23/91 | 25%
| | Fatigue | | 13/91 | 14%
| | Headache | | 9/91 | 10%
| | Insomnia | | 7/91 | 8%
| | Nausea and/or vomiting | | 4/91 | 4%
| | Organic delusional disorder | Severe | 1/91 | 1%
| | Purpura | | 7/91 | 8%
| | Sedation | Severe | 1/90 | 1%
| | Somnolence | | 15/91 | 16%
| | Upper respiratory tract infection | | 9/91 | 10%
Sachdeo (1997a) | Topiramate 1000 | Anorexia | | 10/24 | 42%
| | Confusion | | 3/24 | 13%
| | Death | Severe | 0/24 | 0%
| | Dizziness | | 6/24 | 25%
| | Facial edema | Withdrawal | 1/24 | 4%
| | Fatigue | | 11/24 | 46%
| | Headache | | 6/24 | 25%
| | Insomnia | | 4/24 | 17%
| | Nausea | | 4/24 | 17%
| | Paresthesia | | 14/24 | 58%
| | Renal stones | | 1/24 | 4%
| | Upper respiratory tract infection | | 5/24 | 21%
Devinsky (1995) | Placebo | Hypoesthesia | Withdrawal | 1/27 | 4%
Schachter (1995) | Tiagabine 36 | Accidental injury | | 20/96 | 21%
| | Amnesia | | 8/96 | 8%
| | Any | Any | 91/96 | 95%
| | Asthenia | | 12/96 | 13%
| | Dizziness | | 34/96 | 35%
| | Headache | | 8/96 | 8%
| | Impaired concentration | | 22/96 | 23%
| | Insomnia | | 10/96 | 10%
| | Nervousness | | 15/96 | 16%
| | Paresthesia | | 19/96 | 20%
| | Somnolence | | 24/96 | 25%
Theodore (1995) | Felbamate 3600 | Abdominal pain | Withdrawal | 1/21 | 5%
| | Anxiety | Withdrawal | 2/21 | 10%
| | Increase in seizures | Withdrawal | 2/21 | 10%
| | Insomnia | Withdrawal | 1/21 | 5%
| | Orobuccal dyskinesias | Withdrawal | 1/21 | 5%
| | Psychosis | Withdrawal | 1/21 | 5%
Faught (1993) | Felbamate 3600 | Abdominal pain | | 1/56 | 2%
| | Anorexia | | 6/56 | 11%
| | Diarrhea | | 2/56 | 4%
| | Diplopia | | 3/56 | 5%
| | Dizziness | | 9/56 | 16%
| | Dyspepsia | | 8/56 | 14%
| | Fatigue | | 3/56 | 5%
| | Headache | | 19/56 | 34%
| | Insomnia | | 2/56 | 4%
| | Nausea | | 17/56 | 30%
| | Nausea and/or vomiting | Withdrawal | 5/56 | 9%
| | Nervousness | | 4/56 | 7%
| | Rash | Withdrawal | 1/56 | 2%
| | Somnolence | | 10/56 | 18%
| | Tremor | | 3/56 | 5%
| | Upper respiratory tract infection | | 3/56 | 5%
| | Vomiting | | 8/56 | 14%
| | Weight loss | | 2/56 | 4%

μg/mL micrograms per milliliter

Evidence Table 37. Quality of life outcomes and mood outcomes in studies of sequential monotherapy

Primary Efficacy Study
Study Reporting Quality of Life | Drug And Dose (mg/day) | Quality of Life Scale | Subscale | Was Drug Better or Worse Than Baseline | Was The Difference Statistically Significant
Beydoun (1997b) | Gabapentin 2400 | Profile of Mood States | Tension-anxiety | Worse | No
Dodrill (1999) | | | Depression-dejection | Worse | No
| | | Anger-hostility | Better | No
| | | Vigor-activity | Worse | No
| | | Fatigue-inertia | Worse | No
| | | Confusion-bewilderment | Worse | No
| | | Total mood disturbance | Worse | No
| | Washington Psychosocial Seizure Inventory | Family background | Worse | No
| | | Emotional adjustment | Better | No
| | | Interpersonal adjustment | Better | No
| | | Vocational adjustment | Better | No
| | | Financial status | Better | No
| | | Adjustment to seizures | Better | No
| | | Medicine & medical management | Better | No
| | | Overall functioning | Better | No
| | | Lie Scale | Worse | No
| | | Rare Items | Worse | No
| | Mood Rating Scale | Mood Rating Scale | Worse | No
Schachter(1995) | Tiagabine 6 or 36 | Profile of Mood States | Tension-anxiety | Worse | No
Dodrill (1998) | | | Depression-dejection | Better | No
| | | Anger-hostility | Better | No
| | | Vigor-activity | Worse | Yes
| | | Fatigue-inertia | Worse | No
| | | Confusion-bewilderment | Worse | No
| | | Total mood disturbance | Worse | No
| | Washington Psychosocial Seizure Inventory | Family background | Better | No
| | | Emotional adjustment | Better | No
| | | Interpersonal adjustment | Better | No
| | | Vocational adjustment | Better | No
| | | Financial status | Better | No
| | | Adjustment to seizuresBetter | | No
| | | Medicine & medical management | Better | No
| | | Overall functioning | Better | No
| | | Lie Scale | Worse | No
| | | Race Items | Better | No
| | Mood Rating Scale | Mood Rating Scale | Worse | No
Theodore (1995) | Patients on no AEDs | Zung Anxiety | Zung Anxiety | Worse | Yes
Ketter (1996) | | Hamilton Depression | Hamilton Depression | Worse | Yes
| | Young mania | Young mania | Worse | No
| | Brief Psychiatric Rating Scale | Brief Psychiatric Rating Scale | Worse | Yes
| | Clinical Global Impression | Clinical Global Impression | Worse | Yes
| | Bunney-Hamburg anxiety | Bunney-Hamburg anxiety | Worse | Yes
| | Bunney-Hamburg depression | Bunney-Hamburg depression | Worse | Yes
| | Bunney-Hamburg mania | Bunney-Hamburg mania | Worse | No
| | Bunney-Hamburg psychosis | Bunney-Hamburg psychosis | Same | No
| | Bunney-Hamburg obsessive compulsive | Bunney-Hamburg obsessive compulsive | Same | No
| | Bunney-Hamburg global impairment | Bunney-Hamburg global impairment | Worse | Yes
| Felbamate 3600 week 1 | Zung Anxiety | Zung Anxiety | Worse | Yes
| | Hamilton Depression | Hamilton Depression | Worse | Yes
| | Young mania | Young mania | Worse | No
| | Brief Psychiatric Rating Scale | Brief Psychiatric Rating Scale | Worse | Yes
| | Clinical Global Impression | Clinical Global Impression | Worse | Yes
| | Bunney-Hamburg anxiety | Bunney-Hamburg anxiety | Worse | Yes
| | Bunney-Hamburg depression | Bunney-Hamburg depression | Worse | Yes
| | Bunney-Hamburg mania | Bunney-Hamburg mania | Worse | No
| | Bunney-Hamburg psychosis | Bunney-Hamburg psychosis | Worse | No
| | Bunney-Hamburg obsessive compulsive | Bunney-Hamburg obsessive compulsive | Same | No
| | Bunney-Hamburg global impairment | Bunney-Hamburg global impairment | Worse | Yes
| Felbamate 3600 week 2 | Zung Anxiety | Zung Anxiety | Worse | Yes
| | Hamilton Depression | Hamilton Depression | Worse | Yes
| | Young mania | Young mania | Worse | No
| | Brief Psychiatric Rating Scale | Brief Psychiatric Rating Scale | Worse | Yes
| | Clinical Global Impression | Clinical Global Impression | Worse | Yes
| | Bunney-Hamburg anxiety | Bunney-Hamburg anxiety | Worse | Yes
| | Bunney-Hamburg depression | Bunney-Hamburg depression | Worse | Yes
| | Bunney-Hamburg mania | Bunney-Hamburg mania | Worse | No
| | Bunney-Hamburg psychosis | Bunney-Hamburg psychosis | Worse | No
| | Bunney-Hamburg obsessive compulsive | Bunney-Hamburg obsessive compulsive | Worse | No
| | Bunney-Hamburg global impairment | Bunney-Hamburg global impairment | Worse | Yes

Evidence Table 38. Cognitive function outcomes in studies of sequential monotherapy

Primary Efficacy Study
Study Reporting Quality of Life | Drug And Dose (mg/day) | Functional Status / Ability Scale | Subscale | Was Drug Better or Worse Than Baseline | Was The Difference Statistically Significant
Beydoun (1997b) | Gabapentin 2400 | Lafayette Grooved Pegboard | Preferred hand | Better | No
Dodrill (1999)
| | Lafayette Grooved Pegboard | Nonpreferred hand | Better | No
| | Stroop Test | Reading speed | Worse | No
| | Stroop Test | Reading speed, errors | Better | No
| | Stroop Test | Interference | Better | No
| | Stroop Test | Interference, errors | Better | No
| | Benton Visual Retention Test | Form F | Better | No
| | Benton Visual Retention Test | Form G | Better | No
| | Controlled Oral Word Association Test | Controlled Oral Word Association Test | Better | No
| | Symbol Digit Modalities Test | Symbol Digit Modalities Test | Better | No
| | Rey Auditory Verbal Learning Test | Trial 1–5, first list recall | Better | No
| | Rey Auditory Verbal Learning Test | Trial 6, second list recall | Worse | No
| | Rey Auditory Verbal Learning Test | Trial 7, first list recall | Better | No
| | Rey Auditory Verbal Learning Test | Trial 8, first delay recall | Better | No
| | Rey Auditory Verbal Learning Test | Trial 9, first delay recognition | Worse | No
| | Wonderlic Personnel Test | Items correct | Worse | No
| | Wonderlic Personnel Test | items wrong | Worse | No
| | Digit Cancellation | Number right | Better | No
| | Digit Cancellation | Number omitted | Worse | No
Schachter (1995) | Tiagabine 6 or 36 | Lafayette Grooved Pegboard | Preferred hand | Better | Yes
Dodrill (1998)
| | Lafayette Grooved Pegboard | Nonpreferred hand | Better | No
| | Stroop Test | Reading speed | Same | No
| | Stroop Test | Reading speed, errors | Better | Yes
| | Stroop Test | Interference | Better | No
| | Stroop Test | Interference, errors | Better | Yes
| | Benton Visual Retention Test | Form F | Better | No
| | Benton Visual Retention Test | Form G | Worse | No
| | Controlled Oral Word Association Test | Controlled Oral Word Association Test | Better | Yes
| | Symbol Digit Modalities Test | Symbol Digit Modalities Test | Better | No
| | Rey Auditory Verbal Learning Test | Trial 1–5, first list recall | Worse | No
| | Rey Auditory Verbal Learning Test | Trial 6, second list recall | Worse | No
| | Rey Auditory Verbal Learning Test | Trial 7, first list recall | Worse | No
| | Rey Auditory Verbal Learning Test | Trial 8, first delay recall | Worse | No
| | Rey Auditory Verbal Learning Test | Trial 9, first delay recognition | Better | No
| | Wonderlic Personnel Test | Items correct | Better | No
| | Wonderlic Personnel Test | Items wrong | Worse | No
| | Digit Cancellation | Number right | Worse | No
| | Digit Cancellation | Number omitted | Worse | No

Evidence Table 39. Scales used to measure quality of life in trials of sequential monotherapy

Reference | Corresponding Primary Efficacy Trial | Trial Drug | Scales Used to Measure Quality of Life | Total Number of Subscales
Dodrill (1999) | Beydoun (1997) | Gabapentin | Washington Psychosocial Seizure Inventory | 10
| | | Family background
| | | Emotional adjustment
| | | Interpersonal adjustment
| | | Vocational adjustment
| | | Financial status
| | | Adjustment to seizures
| | | Medicine and medical management
| | | Overall functioning
| | | Lie scale
| | | Rare items
Dodrill (1998) | Schachter (1995) | Tiagabine | Same as above | 10

Evidence Table 40. Scales used to measure mood in trials of sequential monotherapy

Reference | Corresponding Primary Efficacy Trial | Trial Drug | Scales Used to Measure Mood | Total Number of Subscales
Dodrill (1999) | Beydoun (1997) | Gabapentin | Profile of Mood States: | 8
| | | Tension-anxiety
| | | Depression-dejection
| | | Anger-hostility
| | | Vigor-activity
| | | Fatigue-inertia
| | | Confusion-bewilderment
| | | Total mood disturbance
| | | Mood Rating Scale
Dodrill (1998) | Schachter (1995) | Tiagabine | Same as Dodrill (1999) | 8
Ketter (1996) | Theodore (1995) | Felbamate | Zung Anxiety | 11
| | | Hamilton Depression
| | | Young Mania
| | | Brief Psychiatric Rating Scale
| | | Clinical Global Impression
| | | Bunney-Hamburg ratings:
| | | Bunney-Hamburg Anxiety
| | | Bunney-Hamburg Depression
| | | Bunney-Hamburg Mania
| | | Bunney-Hamburg Psychosis
| | | Bunney-Hamburg Obsessive compulsive
| | | Bunney-Hamburg Global impairment

Evidence Table 41. Scales used to measure cognitive function in trials of sequential monotherapy

Reference | Corresponding Primary Efficacy Trial | Trial Drug | Scales Used to Measure Cognitive Function | Total Number of Subscales
Dodrill (1999) | Beydoun (1997) | Gabapentin | Lafayette Grooved Pegboard: | 19
| | | Preferred hand
| | | Nonpreferred hand
| | | Stroop Test:
| | | Reading speed
| | | Reading speed, errors
| | | Interference
| | | Interference, errors
| | | Benton Visual Retention Test:
| | | Form F
| | | Form G
| | | Controlled Oral Word Association Test
| | | Symbol Digit Modalities Test
| | | Rey Auditory Verbal Learning Test:
| | | Trial 1–5, first list recall
| | | Trial 6, second list recall
| | | Trial 7, first list recall
| | | Trial 8, first delay recall
| | | Trial 9, first delay recognition
| | | Wonderlic Personnel Test:
| | | Items correct
| | | items wrong
| | | Digit Cancellatio:
| | | Number right
| | | Number omitted
Dodrill (1998) | Schachter (1995) | Tiagabine | Same as above (Dodrill (1999)) | 19

Evidence Table 42. Mortality in trials of sequential monotherapy

Reference | Drug | Dose (mg/day) | Number of Patients Who Died During The Trial | Percentage
Sachdeo (2001) | Oxcarbazepine | 300 | 1/51 | 2%
Bergey (1997) | Gabapentin | 300 | 0/42 | 0%
Bergey (1997) | Gabapentin | 3600 | 0/40 | 0%
Beydoun (1997a) | Valproate | 50μG/mL | 1/47 | 2%
Beydoun (1997b) | Gabapentin | 600 | 0/94 | 0%
Beydoun (1997b) | Gabapentin | 1200 | 0/90 | 0%
Beydoun (1997b) | Gabapentin | 2400 | 0/91 | 0%
Sachdeo (1997a) | Topiramate | 100 | 0/24 | 0%
Sachdeo (1997a) | Topiramate | 1000 | 0/24 | 0%

mg/day Milligrams per day

μG/ml Micrograms per milliliter

Evidence Table 43. General information on studies of polytherapy

Reference | Author Affiliation | Patients | Country | Multicenter | For-Profit Funding | Minimum Number of AEDs | Minimum Monthly Seizure Frequency | Minimum Duration of Condition | Were Side Effects in The Definition of Treatment-Resistant Epilepsy
Faught (2001) | University of Alabama School of Medicine, Birmingham, USA | Refractory partial-onset seizures (complex partial or simple partial with an observable motor component, with or without secondary generalization to tonic-clonic seizures) | United States | Yes | Yes | 1 | 4 | NR | No
Ben-Menachem (2000) | Dr. E. Ben-Menachem, Department of Clinical Neuroscience, Section of Neurology, Sahlgren University Hospital, 413 45 Goteborg, Sweden | Partial seizures despite treatment with one AED | Sweden, Belgium, Czech Republic, Denmark, France, Germany, Hungary, The Netherlands, Norway, Poland, Switzerland, UK | Yes | Yes | 1 | 2 | 1 year | No
Betts (2000) | Birmingham University Seizure Clinic, UK | Well-characterized refractory epilepsy and any seizure type | UK, Belgium | Yes | Yes | 1 | 0.67 | NR | No
Cereghino (2000) | Oregon Health Sciences University, Portland, OR USA | Uncontrolled partial seizures with or without becoming secondarily generalized | United States | Yes | Yes | 2 | 4 | 2 years | No
Glauser (2000) | Children's Hospital, Department of Neurology, Cincinnati, OH 45229, USA | Partial seizures (with or without secondary generalization) that were inadequately controlled with one or two concomitant AEDs | United States, Argentina, Chile, Uruguay, Australia, New Zealand, Canada, Israel | Yes | Yes | 1 | 4 | NR | No
Appleton (1999) | Department of Neurology, Alder Hey Children's Hospital, Liverpool, England, UK | History of medically uncontrolled partial seizures with or without secondary generalization | UK, The Netherlands, France, South Africa, Ireland, Italy, Germany, Spain, Switzerland, United States, Hungary, Yugoslavia, Finland, Czech Republic | Yes | Yes | 1 | 2.67 | NR | No
Biton (1999) | Arkansas Epilepsy Program, Little Rock 72205, USA | Uncontrolled primary generalized tonic-clonic seizures | United States | Yes | Yes | 1 | 1.5 | NR | No
Duchowny (1999) | Miami Children's Hospital, FL 33155-4079, USA | Confirmed diagnosis of partial epilepsy, incompletely controlled by existing therapy | United States, France | Yes | Yes | 1 | 4 | NR | No
Elterman (1999) | Dallas Pediatric Neurology Associates, TX 75230, USA | Uncontrolled partial onset seizures with or without secondary generalized tonic-clonic seizures in children | United States | Yes | Yes | 1 | 3 | NR | No
KTSG (1999) | Department of Neurology, Yonsei University College of Medicine, Severance Hospital, CPO Box 8044, Seoul, Korea | Well-established partial epilepsy, medically intractable | Korea | Yes | Yes | 1 | 2 | NR | No
Sachdeo (1999) | Department of Neurology, University of Medicine and Dentistry of New Jersey-Robert Wood Johnson Medical School, New Brunswick 08903-0019, USA | Lennox-Gastaut syndrome | United States | Yes | Yes | 1 | 60 | NR | No
Uthman (1998) | Veterans Affairs Medical Center, and the Department of Neurology and Brain Institute, University of Florida College of Medicine, Gainesville 32608, USA | Intractable complex partial seizures, medically refractory | United States | Yes | Yes | 1 | 2.67 | NR | No
Sachdeo (1997b) | Department of Neurology, University of Medicine and Dentistry of New Jersey, New Brunswick 08901-2160, USA | Complex partial seizures that are refractory to other treatment | United States | Yes | Yes | 1 | 3 | NR | No
Ben-Menachem (1996) | Sahlgren University Hospital, Goteborg, Sweden | Patients with refractory partial seizures, with or without secondary generalized seizures | Sweden, Norway, Denmark, Germany | Yes | Yes | 1 | 4 | NR | No
Chadwick (1996) | Department of Medical and Surgical Neurology, Walton Hospital, Liverpool, UK | Medically uncontrolled generalized seizures despite treatment with one or two standard AEDs | UK, Australia, Sweden | Yes | Yes | 1 | 4 | NR | No
Faught (1996) | Department of Neurology, University of Alabama School of Medicine, Birmingham 35294-0021, USA | Unequivocal history of partial onset seizures with or without secondary generalized seizures | United States | Yes | Yes | 1 | 4 | NR | No
Privitera (1996) | Department of Neurology (525), University of Cincinnati Medical Center, OH 45267-0525, USA | History of refractory partial epilepsy with or without secondary generalized seizures | United States | Yes | Yes | 1 | 4 | NR | No
Sharief (1996) | Institute of Neurology, London, UK | Unequivocal history of partial onset seizures with or without secondary generalized seizures | Sweden, Spain, UK, France | Yes | Yes | 1 | 4 | NR | No
Tassinari (1996) | Institute of Clinical Neurology, Bellaria Hospital, Bologna, Italy | Documented history of partial seizures with or without secondary generalized seizures | UK, Italy, France, Norway, Denmark | Yes | Yes | 1 | 4 | NR | No
Willmore (1996) | Department of Neurology, University of Texas, Houston 77030, USA | Complex partial seizures incompletely controlled by either phenytoin or carbamazepine | United States, Canada | Yes | Yes | 1 | 4 | NR | No
Anhut (1994) | Parke-Davis Pharmaceutical Research, Freiburg, Germany | Partial seizures that failed to respond to standard AED therapy | Australia, France, Canada, Austria, Belgium, Denmark, Finland, South Africa, UK | Yes | Yes | 1 | 4 | NR | No
Messenheimer (1994) | Department of Neurology, University of North Carolina at Chapel Hill 27599 | Patients receiving a stable regimen fo AEDs that did not control their partial seizures adequately | United States | Yes | Yes | 1 | 4 | 32 weeks | No
Bourgeois (1993) | Cleveland Clinic Foundation, OH 44195-5221 | Refractory partial-onset seizures | United States | Yes | Yes | 1 | 28 | NR | No
FSG (1993) | Minnesota Epilepsy Group, 310 N. Smith Avenue, Suite 300, St. Paul, MN 55102 | Lennox-Gastaut syndrome resistant to standard AEDs | United States | Yes | Yes | 1 | 90 | NR | No
Matsuo (1993) | Department of Neurology, University of Utah, Salt Lake City 84132 | Partial seizures that were refractory to currently marketed AEDs | United States | Yes | No | 1 | 4 | NR | No
McLean (1993) | Department of Neurology, 352 Medical Center South, Vanderbilt University, 2100 Pierce Avenue, Nashville, TN 37212 | Documented partial seizures refractory to treatment with currently available AEDs | United States | Yes | Yes | 1 | 4 | NR | No
Schmidt (1993) | Epilepsy Research Group, Universitatsklinikum Rudolf Virchow, Berlin, Germany. | Refractory partial epilepsy in spite of therapeutic plasma concentrations of standard AEDs | Germany, France, Austria, Switzerland, | Yes | No | 1 | 4 | NR | No
Sivenius (1991) | Department of Neurology, University of Kuopio, Finland | Patients with AED-resistant partial or secondarily generalized epilepsy | Finland | No | No | 1 | 4 | NR | No
UKGSG (1990) | University Department of Neuroscience, Walton Hospital, Liverpool L9 1AE, UK | Partial epilepsy resistant to treatment with one or two standard AEDs | UK | Yes | Yes | 1 | 4 | NR | No
Jawad (1989) | Department of Pharmacology and Therapeutics, University of Wales College of Medicine, Heath Park, Cardiff | Partial seizures uncontrolled by optimal therapy with standard AED therapy | UK | No | Yes | 1 | 4 | NR | No

Evidence Table 44. Design characteristics of studies of polytherapy

Reference | Prospective | Randomized | Type of Control | Study Reported Maximum Tolerable Dose of Prior Drugs | Required Good Compliance to Prior Drugs | All Patients Seen During Presurgical Evaluation | Patients Continued to Take Their Pre-Study Drugs | Patients Received a Placebo During The Baseline | Patients Blinded | Observers Blinded | Length of Baseline (Weeks) | Length of TitrationPeriod (Weeks) | Length of MaintenancePeriod (Weeks) | Plasma LevelsMonitored
Faught (2001) | Yes | Yes | Placebo | No | No | No | Yes | Yes | Yes | Yes | 4 | 7 | 5 | Yes
Ben-Menachem (2000) | Yes | Yes | Placebo | No | Yes | No | Yes | No | Yes | Yes | 12 | 4 | 12 | Yes
Betts (2000) | Yes | Yes | Placebo | No | No | No | Yes | No | Yes | Yes | 1 to 4 | 0 | 24 | Yes
Cereghino (2000) | Yes | Yes | Placebo | No | No | No | Yes | Yes | Yes | Yes | 12 | 4 | 14 | Yes
Glauser (2000) | Yes | Yes | Placebo | No | Yes | No | Yes | No | Yes | Yes | 8 | 2 | 14 | Yes
Appleton (1999) | Yes | Yes | Placebo | No | No | No | Yes | No | Yes | Yes | 6 | 3 days | 11 | Yes
Biton (1999) | Yes | Yes | Placebo | No | No | No | Yes | No | Yes | Yes | 8 | 8 | 12 | Yes
Duchowny (1999) | Yes | Yes | Placebo | No | Yes | No | Yes | No | Yes | Yes | 8 | 6 | 12 | Yes
Elterman (1999) | Yes | Yes | Placebo | No | No | No | Yes | No | Yes | Yes | 8 | 8 | 8 | Yes
KTSG (1999) | Yes | Yes | Placebo | Yes | Yes | No | Yes | No | Yes | Yes | 12 | 10 | 8 | Yes
Sachdeo (1999) | Yes | Yes | Placebo | No | Yes | No | Yes | No | Yes | Yes | 4 | 3 | 8 | Yes
Uthman (1998) | Yes | Yes | Placebo | No | No | No | Yes | No | Yes | Yes | 12 | 4 | 12 | Yes
Sachdeo (1997b) | Yes | Yes | Placebo | No | No | No | Yes | No | Yes | Yes | 8 | 4 | 8 | Yes
Ben-Menachem (1996) | Yes | Yes | Placebo | No | Yes | No | Yes | No | Yes | Yes | 8 | 5 | 8 | Yes
Chadwick (1996) | Yes | Yes | Placebo | No | No | No | Yes | No | Yes | Yes | 12 | 2 | 12 | Yes
Faught (1996) | Yes | Yes | Placebo | Yes | Yes | No | Yes | No | Yes | Yes | 12 | 4 | 12 | Yes
Privitera (1996) | Yes | Yes | Placebo | No | Yes | No | Yes | No | Yes | Yes | 12 | 6 | 12 | Yes
Sharief (1996) | Yes | Yes | Placebo | No | No | No | Yes | No | Yes | Yes | 8 | 3 | 8 | Yes
Tassinari (1996) | Yes | Yes | Placebo | No | No | No | Yes | No | Yes | Yes | 8 | 4 | 8 | Yes
Willmore (1996) | Yes | Yes | Placebo | No | Yes | No | Yes | Yes | Yes | Yes | 16 | 8 | 8 | Yes
Anhut (1994) | Yes | Yes | Placebo | Yes | No | No | Yes | No | Yes | Yes | 12 | 2 days | 12 | Yes
Messenheimer (1994) | Yes | Yes | Placebo | No | Yes | No | Yes | No | Yes | Yes | 8 | 4 | 10 | Yes
Bourgeois (1993) | Yes | Yes | Placebo | No | Yes | Yes | No | No | Yes | Yes | 4 | 1 day | 4 | Yes
FSG (1993) | Yes | Yes | Placebo | No | Yes | No | Yes | No | Yes | Yes | 4 | 2 | 8 | Yes
Matsuo (1993) | Yes | Yes | Placebo | No | Yes | No | Yes | No | Yes | Yes | 12 | 3 to 5 | 19 to 21 | Yes
McLean (1993) | Yes | Yes | Placebo | No | No | No | Yes | No | Yes | Yes | 12 | 2 or 3 days | 12 | Yes
Schmidt (1993) | Yes | Yes | Placebo | No | No | No | Yes | No | Yes | Yes | 8 to 12 | 4 | 8 | Yes
Sivenius (1991) | Yes | Yes | Placebo | No | Yes | No | Yes | No | Yes | Yes | 13 | 2 days | 13 | Yes
UKGSG (1990) | Yes | Yes | Placebo | No | No | No | Yes | No | Yes | Yes | 13 | 2 | 12 | Yes
Jawad (1989) | Yes | Yes | Placebo | No | Yes | No | Yes | No | Yes | Yes | 8 | 4 | 8 | Yes

Evidence Table 45. Reporting characterstics of trials of polytherapy

| | | Reporting
Reference | Seizure Types | Seizure Diaries Used | Individual Patient Data | Baseline Seizure Freq. | Seizure Freq. | Adverse Effects | Quality of Life | Functional Status/ Ability | Return to Work | Return to School
Faught (2001) | Partial | Yes | No | Yes | Yes | Yes | No | No | No | No
Ben-Menachem (2000) | Partial | Yes | No | Yes | Yes | Yes | No | No | No | No
Betts (2000) | Generalized and partial | Yes | No | Yes | Yes | Yes | No | No | No | No
Cereghino (2000) | Partial | Yes | No | Yes | Yes | Yes | Yes | No | No | No
Glauser (2000) | Partial | Yes | No | Yes | Yes | Yes | No | No | No | No
Appleton (1999) | Generalized and partial | Yes | No | Yes | Yes | Yes | No | No | No | No
Biton (1999) | Generalized | Yes | No | Yes | Yes | Yes | No | No | No | No
Duchowny (1999) | Partial | Yes | No | Yes | Yes | Yes | No | No | No | No
Elterman (1999) | Partial | Yes | No | Yes | Yes | Yes | No | No | No | No
KTSG (1999) | Partial | Yes | No | Yes | Yes | Yes | No | No | No | No
Sachdeo (1999) | Generalized | Yes | No | Yes | Yes | Yes | No | No | No | No
Uthman (1998) | Partial | Yes | No | Yes | Yes | Yes | Yes | Yes | No | No
Sachdeo (1997b) | Partial | Yes | No | Yes | Yes | Yes | No | No | No | No
Ben-Menachem (1996) | Partial | Yes | No | Yes | Yes | Yes | No | No | No | No
Chadwick (1996) | Generalized | Yes | No | Yes | Yes | Yes | No | No | No | No
Faught (1996) | Partial | Yes | No | Yes | Yes | Yes | No | No | No | No
Privitera (1996) | Partial | Yes | No | Yes | Yes | Yes | No | No | No | No
Sharief (1996) | Generalized and partial | Yes | No | Yes | Yes | Yes | No | No | No | No
Tassinari (1996) | Partial | Yes | No | Yes | Yes | Yes | No | No | No | No
Willmore (1996) | Partial | Yes | No | Yes | Yes | Yes | No | No | No | No
Anhut (1994) | Partial | Yes | No | Yes | Yes | Yes | No | No | No | No
Messenheimer (1994) | Partial | Yes | No | Yes | Yes | Yes | No | No | No | No
Bourgeois (1993) | Partial | Yes | No | Yes | Yes | Yes | No | No | No | No
FSG (1993) | Generalized | Yes | No | Yes | Yes | Yes | No | No | No | No
Matsuo (1993) | Partial | Yes | No | Yes | Yes | Yes | No | No | No | No
McLean (1993) | Partial | Yes | No | Yes | Yes | Yes | No | No | No | No
Schmidt (1993) | Partial | Yes | No | Yes | Yes | Yes | No | No | No | No
Sivenius (1991) | Partial | Yes | No | Yes | Yes | Yes | No | No | No | No
UKGSG (1990) | Partial | Yes | No | Yes | Yes | Yes | No | No | No | No
Jawad (1989) | Partial | Yes | Yes | No | Yes | No | No | No | No | No

Freq. Frequencey

Evidence Table 46. Drug characteristics in studies of polytherapy

Reference | Name of Drug Given to This Group of Patients | Mechanism(s) of Action^a^ | Minimum Dose (mg/day) | Maximum Dose (mg/day) | Highest Dose in The Study | Lowest Dose in The Study
Faught (2001) | Placebo | NA | NA | NA | Yes | Yes
| Zonisamide | Sodium, Calcium | NR | 400 | Yes | Yes
Ben-Menachem (2000) | Placebo | NA | NA | NA | Yes | Yes
| Levetiracetam | Unknown | 3000 | 3000 | Yes | Yes
Betts (2000) | Placebo | NA | NA | NA | Yes | Yes
| Levetiracetam | Unknown | 2000 | 2000 | No | Yes
| Levetiracetam | Unknown | 4000 | 4000 | Yes | No
Cereghino (2000) | Placebo | NA | NA | NA | Yes | Yes
| Levetiracetam | Unknown | 1000 | 1000 | No | Yes
| Levetiracetam | Unknown | 3000 | 3000 | Yes | No
Glauser (2000) | Placebo | NA | NA | NA | Yes | Yes
| Oxcarbazepine | Sodium | 900 | 1800 | Yes | Yes
Appleton (1999) | Placebo | NA | NA | NA | Yes | Yes
| Gabapentin | Inhibitory | 600 | 1800 | Yes | Yes
Biton (1999) | Placebo | NA | NA | NA | Yes | Yes
| Topiramate | Sodium, Calcium, Inhibitory, Excitatory | 150 | 400 | Yes | Yes
Duchowny (1999) | Placebo | NA | NA | NA | Yes | Yes
| Lamotrigine | Sodium | 150 | 750 | Yes | Yes
Elterman (1999) | Placebo | NA | NA | NA | Yes | Yes
| Topiramate | Sodium, Calcium, Inhibitory, Excitatory | 125 | 400 | Yes | Yes
KTSG (1999) | Placebo | NA | NA | NA | Yes | Yes
| Topiramate | Sodium, Calcium, Inhibitory, Excitatory | 200 | 600 | Yes | Yes
Sachdeo (1999) | Placebo | NA | NA | NA | Yes | Yes
| Topiramate | Sodium, Calcium, Inhibitory, Excitatory | NR | 600 | Yes | Yes
| Placebo | NA | NA | NA | Yes | Yes
| Tiagabine | Inhibitory | 16 | 16 | No | Yes
| Tiagabine | Inhibitory | 32 | 32 | No | No
| Tiagabine | Inhibitory | 56 | 56 | Yes | No
Sachdeo (1997b) | Placebo | NA | NA | NA | Yes | Yes
| Tiagabine | Inhibitory | 24 | 32 | No | Yes
| Tiagabine | Inhibitory | 24 | 32 | Yes | No
Ben-Menachem (1996) | Placebo | NA | NA | NA | Yes | Yes
| Topiramate | Sodium, Calcium, Inhibitory, Excitatory | NR | 800 | Yes | Yes
Chadwick (1996) | Placebo | NA | NA | NA | Yes | Yes
| Gabapentin | Inhibitory | 1200 | 1200 | Yes | Yes
Faught (1996) | Placebo | NA | NA | NA | Yes | Yes
| Topiramate | Sodium, Calcium, Inhibitory, Excitatory | 200 | 200 | No | Yes
| Topiramate | Sodium, Calcium, Inhibitory, Excitatory | NR | 400 | No | No
| Topiramate | Sodium, Calcium, Inhibitory, Excitatory | NR | 600 | Yes | No
Privitera (1996) | Placebo | NA | NA | NA | Yes | Yes
| Topiramate | Sodium, Calcium, Inhibitory, Excitatory | NR | 600 | No | Yes
| Topiramate | Sodium, Calcium, Inhibitory, Excitatory | NR | 800 | No | No
| Topiramate | Sodium, Calcium, Inhibitory, Excitatory | NR | 1000 | Yes | No
Sharief (1996) | Placebo | NA | NA | NA | Yes | Yes
| Topiramate | Sodium, Calcium, Inhibitory, Excitatory | NR | 400 | Yes | Yes
Tassinari (1996) | Placebo | NA | NA | NA | Yes | Yes
| Topiramate | Sodium, Calcium, Inhibitory, Excitatory | NR | 600 | Yes | Yes
Willmore (1996) | Placebo | NA | NA | NA | Yes | Yes
| Valproate | Inhibitory | NR | 90 mg/kg | Yes | Yes
Anhut (1994) | Placebo | NA | NA | NA | Yes | Yes
| Gabapentin | Inhibitory | 900 | 900 | No | Yes
| Gabapentin | Inhibitory | 1200 | 1200 | Yes | No
Messenheimer (1994) | Placebo | NA | NA | NA | Yes | Yes
| Lamotrigine | Sodium | 100 | 400 | Yes | Yes
Bourgeois (1993) | Placebo | NA | NA | NA | Yes | Yes
| Felbamate | Sodium, Inhibitory, Excitatory | NR | 3600 | Yes | Yes
FSG (1993) | Placebo | NA | NA | NA | Yes | Yes
| Felbamate | Sodium, Inhibitory, Excitatory | NR | 3600 | Yes | Yes
Matsuo (1993) | Placebo | NA | NA | NA | Yes | Yes
| Lamotrigine | Sodium | 200 | 300 | No | Yes
| Lamotrigine | Sodium | 400 | 500 | Yes | No
McLean (1993) | Placebo | NA | NA | NA | Yes | Yes
| Gabapentin | Inhibitory | NR | 600 | No | Yes
| Gabapentin | Inhibitory | NR | 1200 | No | No
| Gabapentin | Inhibitory | NR | 1800 | Yes | No
Schmdit (1993) | Placebo | NA | NA | NA | Yes | Yes
| Zonisamide | Sodium, Calcium | 1.5 mg/kg | 20 mg/kg | Yes | Yes
Sivenius (1991) | Placebo | NA | NA | NA | Yes | Yes
| Gabapentin | Inhibitory | 900 | 900 | Yes | Yes
UKGSG (1990) | Placebo | NA | NA | NA | Yes | Yes
| Gabapentin | Inhibitory | 1200 | 1200 | Yes | Yes
Jawad (1989) | Placebo | NA | NA | NA | Yes | Yes
| Lamotrigine | Sodium | 75 | 400 | Yes | Yes

a The mechanism(s) of drug action were based on Table3 of Gilliam (2002).

mg/kg Milligrams per kilogram

NA Not applicable

Evidence Table 47. Drug characterstics in studies of polytherapy

| | Number of Patients
Reference | Drug And Dose (mg/day) | Started The Study | Exited Due to an Increase in Seizures | Exited Due to Adverse Effects | Exited For Other Reasons | Completed The Study | With Reported Patient Characteristics | Patient Characteristics Reported For Those Who Started or Completed The Study
Faught (2001) | Placebo | 85 | NR | 7 | NR | 72^a^ | 85 | Started
| Zonisamide 400 | 118 | NR | 14 | NR | 85^a^ | 118 | Started
Ben-Menachem (2000) | Placebo | 105 | 1 | 9 | 5^a^ | 90 | 105 | Started
| Levetiracetam 3000 | 181 | 3 | 17 | 12^a^ | 149 | 181 | Started
Betts (2000) | Placebo | 39 | NR | 6 | NR | 29 | 39 | Started
| Levetiracetam 2000 | 42 | NR | 11 | NR | 28 | 42 | Started
| Levetiracetam 4000 | 38 | NR | 5 | NR | 29 | 38 | Started
Cereghino (2000) | Placebo | 95 | NR | 5 | NR | 89 | 95 | Started
| Levetiracetam 1000 | 98 | NR | 6 | NR | 86 | 98 | Started
| Levetiracetam 3000 | 101 | NR | 7 | NR | 93 | 101 | Started
Glauser (2000) | Placebo | 129 | 4 | 4 | 2^a^ | 119 | 129 | Started
| Oxcarbazepine 1800 | 138 | 0 | 14 | 4 | 117 | 138 | Started
Appleton (1999) | Placebo | 128 | 19 | 3 | 6^a^ | 100 | 128 | Started
| Gabapentin 1800 | 119 | 11 | 6 | 4^a^ | 98 | 119 | Started
Biton (1999) | Placebo | 41 | NR | 1 | NR | 38 | 41 | Started
| Topiramate 400 | 39 | NR | 1 | NR | 34 | 39 | Started
Duchowny (1999) | Placebo | 101 | 8 | 6 | 4^a^ | 83 | 101 | Started
| Lamotrigine 750 | 98 | 6 | 5 | 2 | 84 | 98 | Started
Elterman (1999) | Placebo | 45 | NR | 1 | NR | 43 | 45 | Started
| Topiramate 400 | 41 | 0 | 0 | 0 | 41 | 41 | Started
KTSG (1999) | Placebo | 86 | NR | 3 | NR | 77 | 86 | Started
| Topiramate 600 | 91 | NR | 7 | NR | 76 | 91 | Started
Sachdeo (1999) | Placebo | 50 | 0 | 0 | 0 | 50 | 50 | Started
| Topiramate 600 | 48 | NR | 0 | NR | 47 | 48 | Started
Uthman (1998) | Placebo | 91 | 6 | 7 | 0 | 78 | 91 | Started
| Tiagabine 16 | 61 | 2 | 4 | 0 | 55 | 61 | Started
| Tiagabine 32 | 88 | 1 | 13 | 4^a^ | 70 | 88 | Started
| Tiagabine 56 | 57 | 5 | 9 | 3^a^ | 40 | 57 | Started
Sachdeo (1997b) | Placebo | 107 | 1 | 7 | 2^a^ | 97 | 107 | Started
| Tiagabine 32 | 105 | 1 | 8 | 12^a^ | 84 | 105 | Started
| Tiagabine 32 | 106 | 1 | 13 | 2^a^ | 90 | 106 | Started
Ben-Menachem (1996) | Placebo | 28 | 0 | 0 | 0 | 28 | 28 | Started
| Topiramate 800 | 28 | 0 | 6 | 0 | 22 | 28 | Started
Chadwick (1996) | Placebo | 71 | 0 | 6 | 0 | 65 | 71 | Started
| Gabapentin 1200 | 58 | 0 | 4 | 0 | 54 | 58 | Started
Faught (1996) | Placebo | 45 | 0 | 7 | 0 | 38^a^ | 45 | Started
| Topiramate 200 | 45 | 0 | 4 | 0 | 41^a^ | 45 | Started
| Topiramate 400 | 45 | 0 | 9 | 0 | 36^a^ | 45 | Started
| Topiramate 600 | 46 | 0 | 13 | 0 | 33^a^ | 46 | Started
Privitera (1996) | Placebo | 47 | 0 | 1 | 0 | 46^a^ | 47 | Started
| Topiramate 600 | 48 | 0 | 10 | 0 | 38^a^ | 48 | Started
| Topiramate 800 | 48 | 0 | 5 | 0 | 43^a^ | 48 | Started
| Topiramate 1000 | 47 | 0 | 8 | 0 | 39^a^ | 47 | Started
Sharief (1996) | Placebo | 24 | NR | 1 | NR | 22 | 24 | Started
| Topiramate 400 | 23 | 0 | 6 | 0 | 17 | 23 | Started
Tassinari (1996) | Placebo | 30 | 0 | 1 | 1a | 28 | 30 | Started
| Topiramate 600 | 30 | 1 | 3 | 1^a^ | 25 | 30 | Started
Willmore (1996) | Placebo | 70 | 3 | 1 | 6^a^ | 60 | 70 | Started
| Valproate 90 mg/kg | 77 | 0 | 5 | 4^a^ | 68 | 77 | Started
Anhut (1994) | Placebo | 109 | 2 | 4 | 4^a^ | 99 | 109 | Started
| Gabapentin 900 | 111 | 1 | 9 | 5^a^ | 96 | 111 | Started
| Gabapentin 1200 | 52 | 0 | 2 | 0 | 50 | 52 | Started
Messenheimer (1994) | Placebo | 48 | 2 | 1 | 1^a^ | 44 | 44 | Completed
| Lamotrigine 400 | 50 | NR | 5 | NR | 44 | 44 | Completed
Bourgeois (1993) | Placebo | 34 | 0 | 0 | 1^a^ | 33 | 34 | Started
| Felbamate 3600 | 30 | 0 | 2 | 0 | 28 | 30 | Started
FSG (1993) | Placebo | 36 | 0 | 1 | 0 | 35 | 36 | Started
| Felbamate 3600 | 37 | 0 | 1 | 0 | 36 | 37 | Started
Matsuo (1993) | Placebo | 73 | NR | 1 | NR | 67 | 73 | Started
| Lamotrigine 300 | 71 | NR | 3 | NR | 65 | 71 | Started
| Lamotrigine 500 | 72 | NR | 10 | NR | 59 | 72 | Started
McLean (1993) | Placebo | 98 | NR | 1 | NR | 95 | 98 | Started
| Gabapentin 600 | 53 | NR | 3 | NR | 49 | 53 | Started
| Gabapentin 1200 | 101 | NR | 2 | NR | 91 | 101 | Started
| Gabapentin 1800 | 54 | 0 | 2 | 0 | 52 | 54 | Started
Schmidt (1993) | Placebo | 68 | 0 | 0 | 4^a^ | 64 | 68 | Started
| Zonisamide 20 mg/kg | 71 | 1 | 1 | 2^a^ | 67 | 71 | Started
Sivenius (1991) | Placebo | 18 | 0 | 0 | 0 | 18 | 18 | Started
| Gabapentin 900 | 16 | 0 | 0 | 0 | 16 | 16 | Started
UKGSG (1990) | Placebo | 66 | 1 | 3 | 1^a^ | 61 | 66 | Started
| Gabapentin 1200 | 61 | 1 | 6 | 2^a^ | 52 | 61 | Started
Jawad (1989) | Placebo | 12 | 0 | 1 | 0 | 11 | 11 | Completed
| Lamotrigine 400 | 12 | NR | 1 | NR | 10 | 10 | Completed

a Calcuated by ECRI based on reported information

mg/kg Milligrams per kilogram

Evidence Table 48. Age, gender, and duration of condition of patients in studies of polytherapy

Reference | Drug And Dose (mg/day) | Age Mean | Age SD | Age Minimum | Age Maximum | Number of Males | Number of Females | Mean Duration of Epilepsy | SD Duration | Median Duration of Epilepsy
Faught (2001) | Placebo | 34.2^a^ | 11.4 | 14 | 67 | 35 | 50 | 22^a^ | 11.8^a^ | NR
| Zonisamide 400 | 34.7^a^ | 11.3^a^ | 13 | 68 | 69 | 49 | 22.2^a^ | 10.8^a^ | NR
Ben-Menachem (2000) | Placebo | 36 | 12 | NR | NR | 51 | 54 | 19 | 12 | NR
| Levetiracetam 3000 | 37 | 12 | NR | NR | 87 | 94 | 19 | 11 | NR
Betts (2000) | Placebo | 35 | 12 | NR | NR | 24 | 15 | 26 | 13.2 | NR
| Levetiracetam 2000 | 39 | 13 | NR | NR | 29 | 13 | 21.1 | 14.4 | NR
| Levetiracetam 4000 | 40 | 12 | NR | NR | 20 | 18 | 24.6 | 15.6 | NR
Cereghino (2000) | Placebo | 38 | 11 | NR | NR | 50 | 45 | 24.6^b^ | 12.0^b^ | NR
| Levetiracetam 1000 | 38 | 11 | NR | NR | 62 | 36 | 23.8^b^ | 12.7^b^ | NR
| Levetiracetam 3000 | 38 | 11 | NR | NR | 66 | 35 | 24.9^b^ | 12.1^b^ | NR
Glauser (2000) | Placebo | 11 | NR | 3 | 17 | 71 | 58 | NR | NR | NR
| Oxcarbazepine 1800 | 11 | NR | 3 | 17 | 70 | 68 | NR | NR | NR
Appleton (1999) | Placebo | 8.4 | 2.5 | 3 | 12 | 75 | 53 | 5.4 | 3.1 | NR
| Gabapentin 1800 | 8.5 | 2.6 | 3 | 12 | 59 | 60 | 5.7 | 3.0 | NR
Biton (1999) | Placebo | 25.6 | 13.4 | 3 | 50 | 21 | 20 | NR | NR | NR
| Topiramate 400 | 26.8 | 12.8 | 5 | 59 | 24 | 15 | NR | NR | NR
Duchowny (1999) | Placebo | 7.6^d^ | NR | NR | NR | 56 | 45 | NR | NR | NR
| Lamotrigine 750 | 8.2^d^ | NR | NR | NR | 47 | 51 | NR | NR | NR
Elterman (1999) | Placebo | 9 | 3.4 | 2 | 16 | 25 | 20 | NR | NR | NR
| Topiramate 400 | 8.8 | 3.6 | 2 | 16 | 23 | 18 | NR | NR | NR
KTSG (1999) | Placebo | 29.8 | 8.71 | NR | NR | 48 | 38 | 17.5 | 8.2 | NR
| Topiramate 600 | 29.6 | 7.8 | NR | NR | 47 | 44 | 15 | 8.8 | NR
Sachdeo (1999) | Placebo | 11.2 | 7.7 | 2 | 42 | 25 | 25 | NR | NR | NR
| Topiramate 600 | 11.2 | 6.2 | 2 | 29 | 28 | 20 | NR | NR | NR
Uthman (1998) | Placebo | 34^c^ | NR | 12^c^ | 77^c^ | 53^c^ | 38^c^ | NR | NR | 22.9^c^
| Tiagabine 16 | 34^c^ | NR | 12^c^ | 77^c^ | 35^c^ | 26^c^ | NR | NR | 22.9^c^
| Tiagabine 32 | 34^c^ | NR | 12^c^ | 77^c^ | 51^c^ | 37^c^ | NR | NR | 22.9^c^
| Tiagabine 56 | 34^c^ | NR | 12^c^ | 77^c^ | 33^c^ | 24^c^ | NR | NR | 22.9^c^
Sachdeo (1997b) | Placebo | 35.3 | NR | NR | NR | 54 | 53 | 24 | NR | NR
| Tiagabine 32 | 32.6 | NR | NR | NR | 60 | 45 | 22 | NR | NR
| Tiagabine 32 | 33.4 | NR | NR | NR | 65 | 41 | 18 | NR | NR
Ben-Menachem (1996) | Placebo | 37.2^c^ | NR | 18^c^ | 65^c^ | 24^c^ | 4^c^ | NR | NR | NR
| Topiramate 800 | 37.2^c^ | NR | 18^c^ | 65^c^ | 24^c^ | 4^c^ | NR | NR | NR
Chadwick (1996) | Placebo | 29 | NR | 13 | 61 | 28 | 43 | 20 | NR | NR
| Gabapentin 1200 | 30 | NR | 16 | 62 | 27 | 31 | 22 | NR | NR
Faught (1996) | Placebo | 36.2 | NR | 19 | 68 | 36 | 9 | NR | NR | NR
| Topiramate 200 | 38.6 | NR | 19 | 67 | 29 | 19 | NR | NR | NR
| Topiramate 400 | 38.9 | NR | 19 | 61 | 39 | 6 | NR | NR | NR
| Topiramate 600 | 33.8 | NR | 20 | 58 | 39 | 7 | NR | NR | NR
Privitera (1996) | Placebo | 35 | NR | 18 | 68 | 33 | 14 | NR | NR | NR
| Topiramate 600 | 35.6 | NR | 18 | 57 | 38 | 10 | NR | NR | NR
| Topiramate 800 | 34.3 | NR | 18 | 67 | 41 | 7 | NR | NR | NR
| Topiramate 1000 | 36.3 | NR | 18 | 64 | 40 | 7 | NR | NR | NR
Sharief (1996) | Placebo | 32.6 | 11.1 | NR | NR | 19 | 5 | NR | NR | NR
| Topiramate 400 | 35.4 | 14 | NR | NR | 21 | 2 | NR | NR | NR
Tassinari (1996) | Placebo | 32.9^c^ | NR | 18^c^ | 65^c^ | 20^c^ | 10^c^ | NR | NR | NR
| Topiramate 600 | 32.9^c^ | NR | 18^c^ | 65^c^ | 20^c^ | 10^c^ | NR | NR | NR
Willmore (1996) | Placebo | 32^c^ | NR | NR | NR | 29^c^ | 41^c^ | 19^c^ | NR | NR
| Valproate 90 mg/kg | 32^c^ | NR | NR | NR | 32^c^ | 45^c^ | 19^c^ | NR | NR
Anhut (1994) | Placebo | 32^c^ | NR | 12^c^ | 67^c^ | 61^c^ | 48^c^ | NR | NR | 19
| Gabapentin 900 | 32^c^ | NR | 12^c^ | 67^c^ | 62^c^ | 49^c^ | NR | NR | 19
| Gabapentin 1200 | 32^c^ | NR | 12^c^ | 67^c^ | 29^c^ | 23^c^ | NR | NR | 22
Messenheimer (1994) | Placebo | 35 | NR | 18 | 64 | 20 | 24 | 24 | NR | NR
| Lamotrigine 400 | 35 | NR | 18 | 58 | 21 | 23 | 22.3 | NR | NR
Bourgeois (1993) | Placebo | 33.3 | NR | 17 | 49 | 20 | 14 | NR | NR | NR
| Felbamate 3600 | 33.3 | NR | 18 | 51 | 18 | 12 | NR | NR | NR
FSG (1993) | Placebo | 14 | NR | 4 | 36 | 24 | 12 | NR | NR | NR
| Felbamate 3600 | 12 | NR | 4 | 24 | 27 | 10 | NR | NR | NR
Matsuo (1993) | Placebo | 34 | NR | 18 | 63 | 22 | 51 | 21.5 | NR | NR
| Lamotrigine 300 | 33 | NR | 20 | 57 | 30 | 41 | 22.4 | NR | NR
| Lamotrigine 500 | 32 | NR | 18 | 59 | 15 | 57 | 21.8 | NR | NR
McLean (1993) | Placebo | 34 | NR | 17 | 66 | 69 | 29 | NR | NR | 22
| Gabapentin 600 | 34 | NR | 16 | 67 | 36 | 17 | NR | NR | 20
| Gabapentin 1200 | 35 | NR | 19 | 65 | 60 | 41 | NR | NR | 21
| Gabapentin 1800 | 35 | NR | 18 | 70 | 37 | 17 | NR | NR | 21
Schmidt (1993) | Placebo | 33.4 | NR | NR | NR | 40 | 28 | 20.9 | NR | NR
| Zonisamide 20 mg/kg | 36.2 | NR | NR | NR | 41 | 30 | 23.5 | NR | NR
Sivenius (1991) | Placebo | 39^c^ | NR | 16^c^ | 59^c^ | 8^c^ | 10^c^ | NR | NR | 23^c^
| Gabapentin 900 | 39^c^ | NR | 16^c^ | 59^c^ | 7^c^ | 9^c^ | NR | NR | 23^c^
UKGSG (1990) | Placebo | 31 | NR | 14 | 73 | 29 | 37 | NR | NR | 19
| Gabapentin 1200 | 30 | NR | 15 | 62 | 24 | 37 | NR | NR | 17
Jawad (1989) | Placebo | NR | NR | NR | NR | NR | NR | NR | NR | NR
| Lamotrigine 400 | NR | NR | NR | NR | NR | NR | NR | NR | NR

a Calculated by ECRI based on reported information

b Information obtained from a secondary publication.

c Reported only for the entire patient group, not separately for different groups.

d Estimated by ECRI using the method of Chene.

mg/kg milligrams per kilogram

Evidence Table 49. Baseline seizure frequencies in studies of polytherapy

| | Baseline Seizure Frequency
Reference | Drug And Dose (mg/day) | Seizure Type | Mean | SD | Median | Minimum | Maximum
Faught (2001) | Placebo | Partial | NR | NR | 13 | NR | NR
| Zonisamide 400 | Partial | NR | NR | 12.1^a^ | NR | NR
Ben-Menachem (2000) | Placebo | Partial | NR | NR | 7.5 | NR | NR
| Levetiracetam 3000 | Partial | NR | NR | 7.3 | NR | NR
Betts (2000) | Placebo | Partial | NR | NR | 5.4^a^ | NR | NR
| Levetiracetam 2000 | Partial | NR | NR | 5.3^a^ | NR | NR
| Levetiracetam 4000 | Partial | NR | NR | 5.8^a^ | NR | NR
Cereghino (2000) | Placebo | Partial | 5.7^b^ week | 18.8^b^ week | 7.6^a^ | NR | NR
| Levetiracetam 1000 | Partial | 7.6^b^ week | 14^b^ week | 10.9^a^ | NR | NR
| Levetiracetam 3000 | Partial | 5.2^b^ week | 15.6^b^ week | 8.9^a^ | NR | NR
Glauser (2000) | Placebo | Partial | NR | NR | 13 | 2 | 554
| Oxcarbazepine 1800 | Partial | NR | NR | 12 | 3 | 1470
Appleton (1999) | Placebo | Partial | 63.3 | 103.8 | 28 | 1.3 | 698
| Gabapentin 1800 | Partial | 74.5 | 268.3 | 24.1 | 2.7 | 2893
Biton (1999) | Placebo | Generalized | NR | NR | 17.5 | 2 | 79,109
| Topiramate 400 | Generalized | NR | NR | 15.3 | 1 | 1134
Duchowny (1999) | Placebo | Partial | NR | NR | 10 | NR | NR
| Lamotrigine 750 | Partial | NR | NR | 7.5 | NR | NR
Elterman (1999) | Placebo | Partial | NR | NR | 19 | 2 | 1133
| Topiramate 400 | Partial | NR | NR | 22 | 2 | 232
KTSG (1999) | Placebo | Partial | 11.5 | 2.4 | 5.6 | NR | NR
| Topiramate 600 | Partial | 9.4 | 14.8 | 5.6 | NR | NR
Sachdeo (1999) | Placebo | Generalized and partial | NR | NR | 244 | 7 | 4324
| Topiramate 600 | Generalized and partial | NR | NR | 267 | 13 | 3795
Uthman (1998) | Placebo | Complex partial | NR | NR | 7.4 | 2.8 | 109
| Tiagabine 16 | Complex partial | NR | NR | 8.5 | 2.6 | 170
| Tiagabine 32 | Complex partial | NR | NR | 9.6 | 2.2 | 401
| Tiagabine 56 | Complex partial | NR | NR | 9.1 | 2.1 | 209
Sachdeo (1997b) | Placebo | Complex partial | NR | NR | 8^a^ | NR | NR
| Tiagabine 32 | Complex partial | NR | NR | 8^a^ | NR | NR
| Tiagabine 32 | Complex partial | NR | NR | 8.5^a^ | NR | NR
Ben-Menachem (1996) | Placebo | Partial | NR | NR | 11.4 | NR | NR
| Topiramate 800 | Partial | NR | NR | 14.2 | NR | NR
Chadwick (1996) | Placebo | Generalized tonic-clonic | 7.3 | NR | 3.3 | 0 | 103.3
| Gabapentin 1200 | Generalized tonic-clonic | 7.4 | NR | 3.9 | 0 | 54.3
Faught (1996) | Placebo | Partial | 16 | NR | 10 | NR | NR
| Topiramate 200 | Partial | 31.3 | NR | 11.5 | NR | NR
| Topiramate 400 | Partial | 33 | NR | 11 | NR | NR
| Topiramate 600 | Partial | 23.6 | NR | 11.2 | NR | NR
Privitera (1996) | Placebo | Partial | 18.2 | NR | 9.3 | NR | NR
| Topiramate 600 | Partial | 23.5 | NR | 10 | NR | NR
| Topiramate 800 | Partial | 39.8 | NR | 16.2 | NR | NR
| Topiramate 1000 | Partial | 24.7 | NR | 11.7 | NR | NR
Sharief (1996) | Placebo | Partial | 23.6 | 34.5 | 10 | NR | NR
| Topiramate 400 | Partial | 33.4 | 52.6 | 18 | NR | NR
Tassinari (1996) | Placebo | Partial | NR | NR | 15 | 4 | 925
| Topiramate 600 | Partial | NR | NR | 16.8 | 4 | 230
Willmore (1996) | Placebo | Complex partial | 29.4 | 32.8 | 16 | NR | NR
| Valproate 90 mg/kg | Complex partial | 27.1 | 40.4 | 15.2 | NR | NR
Anhut (1994) | Placebo | Partial | NR | NR | 9.3 | NR | NR
| Gabapentin 900 | Partial | NR | NR | 10.3 | NR | NR
| Gabapentin 1200 | Partial | NR | NR | 9.8 | NR | NR
Messenheimer (1994) | Placebo | Partial | NR | NR | 12.3 | NR | NR
| Lamotrigine 400 | Partial | NR | NR | 13.3 | NR | NR
Bourgeois (1993) | Placebo | Partial | 13.8 | NR | NR | NR | NR
| Felbamate 3600 | Partial | 19.4 | NR | NR | NR | NR
FSG (1993) | Placebo | Generalized | 19.9 | NR | NR | NR | NR
| Felbamate 3600 | Generalized | 43.7 | NR | NR | NR | NR
Matsuo (1993) | Placebo | Partial | NR | NR | 12.7 | NR | NR
| Lamotrigine 300 | Partial | NR | NR | 12 | NR | NR
| Lamotrigine 500 | Partial | NR | NR | 12.7 | NR | NR
McLean (1993) | Placebo | Partial | 31.1 | NR | 10.7 | 2.3 | 455
| Gabapentin 600 | Partial | 21.7 | NR | 10 | 2 | 271.7
| Gabapentin 1200 | Partial | 51.7 | NR | 11 | 2.3 | 1092.7
| Gabapentin 1800 | Partial | 31.5 | NR | 12.7 | 3.7 | 207.8
Schmidt (1993) | Placebo | Complex partial | 9.7 | NR | NR | NR | NR
| Zonisamide 20 mg/kg | Complex partial | 10 | NR | NR | NR | NR
Sivenius (1991) | Placebo | Partial | NR | NR | 36 | NR | NR
| Gabapentin 900 | Partial | NR | NR | 26 | NR | NR
UKGSG (1990) | Placebo | Partial | NR | NR | 13 | 1 | 216
| Gabapentin 1200 | Partial | NR | NR | 13 | 3 | 368
Jawad (1989) | Placebo | NR | NR | NR | NR | NR | NR
| Lamotrigine 400 | NR | NR | NR | NR | NR | NR

a Calculated by ECRI based on reported information

b Information obtained from a secondary publication.

mg/kg milligrams per kilogram

Evidence Table 50. Specific types of generalized seizures in studies of polytherapy

| | | Numbers of Patients With Specific Types of Generalized Seizures
Reference | Drug And Dose (mg/day) | Any Generalized Seizures | Tonic-Clonic | Tonic | Atonic | Myoclonic | Absence | Atypical Absence | Lennox-Gastaut Syndrome | Clonic | West Syndrome | Other Generalized Seizures
Faught (2001) | Placebo | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
| Zonisamide 400 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Ben-Menachem (2000) | Placebo | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
| Levetiracetam 3000 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Betts (2000) | Placebo | 16 | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
| Levetiracetam 2000 | 17 | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
| Levetiracetam 4000 | 17 | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
Cereghino (2000) | Placebo | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
| Levetiracetam 1000 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
| Levetiracetam 3000 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Glauser (2000) | Placebo | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
| Oxcarbazepine 1800 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Appleton (1999) | Placebo | 0 | 13 | 11 | 9 | 12 | 2 | 7 | 0 | 2 | 0 | 0
| Gabapentin 1800 | 0 | 15 | 8 | 8 | 16 | 0 | 7 | 0 | 2 | 0 | 0
Biton (1999) | Placebo | 41 | 40 | 10 | 0 | 8 | 16 | 4 | 0 | 1 | 0 | 0
| Topiramate 400 | 39 | 39 | 9 | 0 | 8 | 16 | 2 | 0 | 1 | 0 | 0
Duchowny (1999) | Placebo | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
| Lamotrigine 750 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Elterman (1999) | Placebo | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
| Topiramate 400 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
KTSG (1999) | Placebo | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
| Topiramate 600 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Sachdeo (1999) | Placebo | 50 | 0 | 0 | 0 | 0 | 0 | 0 | 50 | 0 | 0 | 0
| Topiramate 600 | 48 | 0 | 0 | 0 | 0 | 0 | 0 | 48 | 0 | 0 | 0
Uthman (1998) | Placebo | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
| Tiagabine 16 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
| Tiagabine 32 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
| Tiagabine 56 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Sachdeo (1997b) | Placebo | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
| Tiagabine 32 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
| Tiagabine 32 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Ben-Menachem (1996) | Placebo | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
| Topiramate 800 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Chadwick (1996) | Placebo | 71 | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
| Gabapentin 1200 | 58 | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
Faught (1996) | Placebo | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
| Topiramate 200 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
| Topiramate 400 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
| Topiramate 600 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Privitera (1996) | Placebo | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
| Topiramate 600 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
| Topiramate 800 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
| Topiramate 1000 | 1 | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Sharief (1996) | Placebo | 3 | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
| Topiramate 400 | 5 | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
Tassinari (1996) | Placebo | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
| Topiramate 600 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Willmore (1996) | Placebo | 0 | 51^b^ | 0 | 0 | NR | 4^b^ | 0 | 0 | 0 | 0 | 0
| Valproate 90 mg/kg | 0 | 56^b^ | 0 | 0 | NR | 5^b^ | 0 | 0 | 0 | 0 | 0
Anhut (1994) | Placebo | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
| Gabapentin 900 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
| Gabapentin 1200 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Messenheimer (1994) | Placebo | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
| Lamotrigine 400 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Bourgeois (1993) | Placebo | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
| Felbamate 3600 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
FSG (1993) | Placebo | 36 | 13 | 0 | 22 | 0 | 0 | 0 | 36 | 0 | 0 | 0
| Felbamate 3600 | 37 | 16 | 0 | 28 | 0 | 0 | 0 | 37 | 0 | 0 | 0
Matsuo (1993) | Placebo | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
| Lamotrigine 300 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
| Lamotrigine 500 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
McLean (1993) | Placebo | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
| Gabapentin 600 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
| Gabapentin 1200 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
| Gabapentin 1800 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Schmidt (1993) | Placebo | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
| Zonisamide 20 mg/kg | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Sivenius (1991) | Placebo | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
| Gabapentin 900 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
UKGSG (1990) | Placebo | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
| Gabapentin 1200 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Jawad (1989) | Placebo | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
| Lamotrigine 400 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0

a Calculated by ECRI based on reported information

b Reported only for the entire patient group, not separately for different groups.

mg/kg Milligrams per kilogram

Evidence Table 51. Specific types of partial seizures seizures in studies of polytherapy

| | | Numbers of Patients With Specific Types of Partial Seizures
Reference | Drug And Dose (mg/day) | Any Partial Seizures | Complex Partial | Simple Partial | Secondarily Generalized
Faught (2001) | Placebo | 85 | 81 | 4 | 20
| Zonisamide 400 | 118 | 114^a^ | 4^a^ | 26^a^
Ben-Menachem (2000) | Placebo | 105 | 105 | NR | NR
| Levetiracetam 3000 | 181 | 181 | NR | NR
Betts (2000) | Placebo | 19 | NR | NR | NR
| Levetiracetam 2000 | 20 | NR | NR | NR
| Levetiracetam 4000 | 19 | NR | NR | NR
Cereghino (2000) | Placebo | 95 | NR | NR | NR
| Levetiracetam 1000 | 98 | NR | NR | NR
| Levetiracetam 3000 | 101 | NR | NR | NR
Glauser (2000) | Placebo | 129 | NR | NR | 57
| Oxcarbazepine 1800 | 138 | NR | NR | 50
Appleton (1999) | Placebo | 128 | 112 | 58 | 70
| Gabapentin 1800 | 119 | 99 | 54 | 73
Biton (1999) | Placebo | 0 | 0 | 0 | 0
| Topiramate 400 | 0 | 0 | 0 | 0
Duchowny (1999) | Placebo | 101 | NR | NR | NR
| Lamotrigine 750 | 98 | NR | NR | NR
Elterman (1999) | Placebo | 45 | 37 | 12 | 17
| Topiramate 400 | 41 | 31 | 11 | 17
KTSG (1999) | Placebo | 86 | 72 | 5 | 39
| Topiramate 600 | 91 | 70 | 11 | 31
Sachdeo (1999) | Placebo | 0 | 0 | 0 | 0
| Topiramate 600 | 0 | 0 | 0 | 0
Uthman (1998) | Placebo | 91 | 90 | 51 | 38a
| Tiagabine 16 | 61 | 61 | 39 | 32a
| Tiagabine 32 | 88 | 86 | 49 | 37a
| Tiagabine 56 | 57 | 55 | 33 | 29a
Sachdeo (1997b) | Placebo | 107 | 107 | NR | NR
| Tiagabine 32 | 105 | 105 | NR | NR
| Tiagabine 32 | 106 | 106 | NR | NR
Ben-Menachem (1996) | Placebo | 28 | NR | NR | NR
| Topiramate 800 | 28 | NR | NR | NR
Chadwick (1996) | Placebo | 0 | 0 | 0 | 0
| Gabapentin 1200 | 0 | 0 | 0 | 0
Faught (1996) | Placebo | 45 | 39 | 20 | 34
| Topiramate 200 | 45 | 42 | 18 | 27
| Topiramate 400 | 45 | 43 | 21 | 26
| Topiramate 600 | 46 | 43 | 26 | 32
Privitera (1996) | Placebo | 47 | 44 | 19 | 36
| Topiramate 600 | 48 | 46 | 22 | 29
| Topiramate 800 | 48 | 42 | 22 | 33
| Topiramate 1000 | 47 | 45 | 27 | 21
Sharief (1996) | Placebo | 24 | 23 | 7 | 16
| Topiramate 400 | 23 | 20 | 9 | 19
Tassinari (1996) | Placebo | 30 | NR | NR | NR
| Topiramate 600 | 30 | NR | NR | NR
Willmore (1996) | Placebo | 70 | 70 | 33^b^ | NR
| Valproate 90 mg/kg | 77 | 77 | 36^b^ | NR
Anhut (1994) | Placebo | 109 | 98 | 40 | 58
| Gabapentin 900 | 111 | 99 | 42 | 61
| Gabapentin 1200 | 52 | 48 | 23 | 31
Messenheimer (1994) | Placebo | 44 | NR | NR | NR
| Lamotrigine 400 | 44 | NR | NR | NR
Bourgeois (1993) | Placebo | 34 | NR | NR | NR
| Felbamate 3600 | 30 | NR | NR | NR
FSG (1993) | Placebo | 0 | 0 | 0 | 0
| Felbamate 3600 | 0 | 0 | 0 | 0
Matsuo (1993) | Placebo | 73 | NR | NR | NR
| Lamotrigine 300 | 71 | NR | NR | NR
| Lamotrigine 500 | 72 | NR | NR | NR
McLean (1993) | Placebo | 98 | NR | NR | NR
| Gabapentin 600 | 53 | NR | NR | NR
| Gabapentin 1200 | 101 | NR | NR | NR
| Gabapentin 1800 | 54 | NR | NR | NR
Schmidt (1993) | Placebo | 68 | NR | NR | NR
| Zonisamide 20 mg/kg | 71 | NR | NR | NR
Sivenius (1991) | Placebo | 18 | 17 | 0 | 8
| Gabapentin 900 | 16 | 15 | 1 | 9
UKGSG (1990) | Placebo | 66 | NR | NR | NR
| Gabapentin 1200 | 61 | NR | NR | NR
Jawad (1989) | Placebo | 11^a^ | 8^a^ | 0^a^ | 10^a^
| Lamotrigine 400 | 10^a^ | 9^a^ | 1^a^ | 5^a^

a Calculated by ECRI based on reported information

b Reported only for the entire patient group, not separately for different groups.

mg/kg Milligrams per kilogram

Evidence Table 52. Known etiology and prior AEDs use in studies of polytherapy

| | Number of Patients
Reference | Drug And Dose (mg/day) | Known Etiology | One AED Prior to The Study | Two AEDs Prior to The Study | Three or More AEDs Prior to The Study
Faught (2001) | Placebo | NR | NR | NR | 0
| Zonisamide 400 | NR | NR | NR | 0
Ben-Menachem (2000) | Placebo | 52 | 105 | 0 | 0
| Levetiracetam 3000 | 74 | 181 | 0 | 0
Betts (2000) | Placebo | 15 | NR | NR | NR
| Levetiracetam 2000 | 13 | NR | NR | NR
| Levetiracetam 4000 | 18 | NR | NR | NR
Cereghino (2000) | Placebo | NR | 25 | 67 | 3
| Levetiracetam 1000 | NR | 35 | 57 | 6
| Levetiracetam 3000 | NR | 36 | 59 | 6
Glauser (2000) | Placebo | NR | NR | NR | NR
| Oxcarbazepine 1800 | NR | NR | NR | NR
Appleton (1999) | Placebo | NR | 44 | 57 | 27
| Gabapentin 1800 | NR | 31 | 58 | 30
Biton (1999) | Placebo | NR | NR | NR | NR
| Topiramate 400 | NR | NR | NR | NR
Duchowny (1999) | Placebo | 60 | NR | NR | 0
| Lamotrigine 750 | 61 | NR | NR | 0
Elterman (1999) | Placebo | NR | 25 | 20 | 1
| Topiramate 400 | NR | 15 | 25 | 1
KTSG (1999) | Placebo | NR | 16 | 70 | 0
| Topiramate 600 | NR | 22 | 69 | 0
Sachdeo (1999) | Placebo | NR | 20 | 29 | 1
| Topiramate 600 | NR | 19 | 27 | 2
Uthman (1998) | Placebo | NR | NR | NR | NR
| Tiagabine 16 | NR | NR | NR | NR
| Tiagabine 32 | NR | NR | NR | NR
| Tiagabine 56 | NR | NR | NR | NR
Sachdeo (1997b) | Placebo | NR | NR | NR | NR
| Tiagabine 32 | NR | NR | NR | NR
| Tiagabine 32 | NR | NR | NR | NR
Ben-Menachem (1996) | Placebo | NR | 11^b^ | 17^b^ | 0
| Topiramate 800 | NR | 11^b^ | 17^b^ | 0
Chadwick (1996) | Placebo | NR | 15 | 37 | 18
| Gabapentin 1200 | NR | 11 | 36 | 11
Faught (1996) | Placebo | NR | 16 | 29 | 0
| Topiramate 200 | NR | 15 | 30 | 0
| Topiramate 400 | NR | 16 | 29 | 0
| Topiramate 600 | NR | 16 | 30 | 0
Privitera (1996) | Placebo | NR | 25 | 22 | 0
| Topiramate 600 | NR | 23 | 25 | 0
| Topiramate 800 | NR | 22 | 26 | 0
| Topiramate 1000 | NR | 16 | 31 | 0
Sharief (1996) | Placebo | NR | NR | NR | NR
| Topiramate 400 | NR | NR | NR | NR
Tassinari (1996) | Placebo | NR | NR | NR | NR
| Topiramate 600 | NR | NR | NR | NR
Willmore (1996) | Placebo | NR | 70 | 0 | 0
| Valproate 90 mg/kg | NR | 77 | 0 | 0
Anhut (1994) | Placebo | NR | 26^b^ | 74^b^ | 9^b^
| Gabapentin 900 | NR | 27^b^ | 75^b^ | 9^b^
| Gabapentin 1200 | NR | 12^b^ | 35^b^ | 5^b^
Messenheimer (1994) | Placebo | NR | 16 | 27 | 1
| Lamotrigine 400 | NR | 20 | 23 | 1
Bourgeois (1993) | Placebo | NR | NR | NR | NR
| Felbamate 3600 | NR | NR | NR | NR
FSG (1993) | Placebo | NR | NR | NR | NR
| Felbamate 3600 | NR | NR | NR | NR
Matsuo (1993) | Placebo | NR | 36 | 33 | 4
| Lamotrigine 300 | NR | 21 | 45 | 5
| Lamotrigine 500 | NR | 29 | 36 | 7
McLean (1993) | Placebo | NR | 30 | 68 | 0
| Gabapentin 600 | NR | 21 | 32 | 0
| Gabapentin 1200 | NR | 34 | 66 | 1
| Gabapentin 1800 | NR | 28 | 26 | 0
Schmidt (1993) | Placebo | NR | NR | NR | NR
| Zonisamide 20 mg/kg | NR | NR | NR | NR
Sivenius (1991) | Placebo | 9^b^ | 9^b^ | 9^b^ | 0
| Gabapentin 900 | 8^b^ | 8^b^ | 8^b^ | 0
UKGSG (1990) | Placebo | NR | 21 | 43 | 2
| Gabapentin 1200 | NR | 20 | 38 | 2
Jawad (1989) | Placebo | NR | 1^a^ | 10^a^ | 0^a^
| Lamotrigine 400 | NR | 3^a^ | 7^a^ | 0^a^

a Calculated by ECRI based on reported information

b Reported only for the entire patient group, not separately for different groups.

>0 At least one patient had received the drug, but study did not report the number of patients who received the drug.

mg/kg milligrams per kilogram

Evidence Table 53. Prior drugs in studies of polytherapy

| | Number of Patients Receiving Specific Prior Drugs
Reference | Drug And Dose (mg/day) | Carbamazepine | Clonzaepam | Felbamate | Gabapentin | Lamotrigine | Phenytoin | Phenobarbital | Primidone | Valproate
Faught (2001) | Placebo | >0 | NR | NR | NR | NR | >0 | >0 | >0 | >0
| Zonisamide 400 | >0 | NR | NR | NR | NR | >0 | >0 | >0 | >0
Ben-Menachem (2000) | Placebo | NR | NR | NR | NR | NR | NR | NR | NR | NR
| Levetiracetam 3000 | NR | NR | NR | NR | NR | NR | NR | NR | NR
Betts (2000) | Placebo | >0 | NR | NR | NR | NR | >0 | >0 | NR | >0
| Levetiracetam 2000 | >0 | NR | NR | NR | NR | >0 | >0 | NR | >0
| Levetiracetam 4000 | >0 | NR | NR | NR | NR | >0 | >0 | NR | >0
Cereghino (2000) | Placebo | 59 | 3 | 0 | 24 | 4 | 29 | 7 | 9 | 28
| Levetiracetam 1000 | 52 | 1 | 0 | 35 | 3 | 37 | 9 | 2 | 24
| Levetiracetam 3000 | 56 | 2 | 0 | 24 | 5 | 36 | 10 | 9 | 26
Glauser (2000) | Placebo | 55 | NR | NR | NR | 29 | 22 | NR | NR | 31
| Oxcarbazepine 1800 | 27 | NR | NR | NR | 22 | 21 | NR | NR | 23
Appleton (1999) | Placebo | NR | NR | NR | NR | NR | NR | NR | NR | NR
| Gabapentin 1800 | NR | NR | NR | NR | NR | NR | NR | NR | NR
Biton (1999) | Placebo | 9 | 6 | 0 | 0 | 0 | 13 | 3 | 6 | 20
| Topiramate 400 | 11 | 6 | 0 | 0 | 0 | 12 | 8 | 0 | 19
Duchowny (1999) | Placebo | NR | NR | NR | NR | NR | NR | NR | NR | NR
| Lamotrigine 750 | NR | NR | NR | NR | NR | NR | NR | NR | NR
Elterman (1999) | Placebo | 26 | 0 | 0 | 0 | 0 | 9 | 0 | 0 | 10
| Topiramate 400 | 25 | 0 | 0 | 0 | 0 | 6 | 0 | 0 | 10
KTSG (1999) | Placebo | NR | NR | NR | NR | NR | NR | NR | NR | NR
| Topiramate 600 | NR | NR | NR | NR | NR | NR | NR | NR | NR
Sachdeo (1999) | Placebo | NR | NR | 8 | NR | NR | NR | NR | NR | NR
| Topiramate 600 | NR | NR | 7 | NR | NR | NR | NR | NR | NR
Uthman (1998) | Placebo | 61 | 0 | 0 | 0 | 0 | 19 | 8 | 9 | 21
| Tiagabine 16 | 36 | 0 | 0 | 0 | 0 | 24 | 7 | 6 | 13
| Tiagabine 32 | 55 | 0 | 0 | 0 | 0 | 18 | 13 | 12 | 24
| Tiagabine 56 | 28 | 0 | 0 | 0 | 0 | 19 | 3 | 10 | 9
Sachdeo (1997b) | Placebo | 68 | NR | NR | NR | NR | 31 | NR | NR | 34
| Tiagabine 32 | 62 | NR | NR | NR | NR | 33 | NR | NR | 41
| Tiagabine 32 | 69 | NR | NR | NR | NR | 34 | NR | NR | 30
Ben-Menachem (1996) | Placebo | NR | NR | NR | NR | NR | NR | NR | NR | NR
| Topiramate 800 | NR | NR | NR | NR | NR | NR | NR | NR | NR
Chadwick (1996) | Placebo | >0 | NR | NR | NR | NR | >0 | NR | NR | >0
| Gabapentin 1200 | >0 | NR | NR | NR | NR | >0 | NR | NR | >0
Faught (1996) | Placebo | 36 | NR | NR | NR | NR | 16 | NR | NR | NR
| Topiramate 200 | 33 | NR | NR | NR | NR | 16 | NR | NR | NR
| Topiramate 400 | 30 | NR | NR | NR | NR | 17 | NR | NR | NR
| Topiramate 600 | 36 | NR | NR | NR | NR | 19 | NR | NR | NR
Privitera (1996) | Placebo | 30 | NR | NR | NR | NR | 17 | NR | NR | NR
| Topiramate 600 | 36 | NR | NR | NR | NR | 15 | NR | NR | NR
| Topiramate 800 | 33 | NR | NR | NR | NR | 13 | NR | NR | NR
| Topiramate 1000 | 35 | NR | NR | NR | NR | 21 | NR | NR | NR
Sharief (1996) | Placebo | 16 | 1 | 0 | 0 | 0 | 10 | 5 | 2 | 4
| Topiramate 400 | 16 | 1 | 0 | 0 | 0 | 8 | 6 | 3 | 3
Tassinari (1996) | Placebo | 21 | 0 | 0 | 0 | 0 | 5 | 10 | 3 | 1
| Topiramate 600 | 20 | 0 | 0 | 0 | 0 | 11 | 8 | 5 | 2
Willmore (1996) | Placebo | 53^b^ | 0 | 0 | 0 | 0 | 17^b^ | 0 | 0 | 0
| Valproate 90 mg/kg | 59^b^ | 0 | 0 | 0 | 0 | 18^b^ | 0 | 0 | 0
Anhut (1994) | Placebo | 82^b^ | NR | NR | NR | NR | 31^b^ | >0 | NR | 34^b^
| Gabapentin 900 | 83^b^ | NR | NR | NR | NR | 31^b^ | >0 | NR | 34^b^
| Gabapentin 1200 | 39^b^ | NR | NR | NR | NR | 15^b^ | >0 | NR | 16^b^
Messenheimer (1994) | Placebo | 33 | NR | NR | NR | NR | 22 | NR | NR | NR
| Lamotrigine 400 | 33 | NR | NR | NR | NR | 23 | NR | NR | NR
Bourgeois (1993) | Placebo | NR | NR | NR | NR | NR | NR | NR | NR | NR
| Felbamate 3600 | NR | NR | NR | NR | NR | NR | NR | NR | NR
FSG (1993) | Placebo | NR | NR | NR | NR | NR | >0 | NR | NR | >0
| Felbamate 3600 | NR | NR | NR | NR | NR | >0 | NR | NR | >0
Matsuo (1993) | Placebo | 61 | NR | NR | NR | NR | 21 | NR | NR | NR
| Lamotrigine 300 | 50 | NR | NR | NR | NR | 32 | NR | NR | NR
| Lamotrigine 500 | 55 | NR | NR | NR | NR | 24 | NR | NR | NR
McLean (1993) | Placebo | 79 | NR | NR | NR | NR | 40 | NR | NR | 21
| Gabapentin 600 | 39 | NR | NR | NR | NR | 23 | NR | NR | 8
| Gabapentin 1200 | 79 | NR | NR | NR | NR | 36 | NR | NR | 21
| Gabapentin 1800 | 41 | NR | NR | NR | NR | 18 | NR | NR | 13
Schmidt (1993) | Placebo | >0 | 0 | 0 | 0 | 0 | >0 | >0 | >0 | >0
| Zonisamide 20 mg/kg | >0 | 0 | 0 | 0 | 0 | >0 | >0 | >0 | >0
Sivenius (1991) | Placebo | 16^b^ | 6^b^ | 0 | 0 | 0 | 1^b^ | 0 | 0 | 3^b^
| Gabapentin 900 | 14^b^ | 5^b^ | 0 | 0 | 0 | 1^b^ | 0 | 0 | 3^b^
UKGSG (1990) | Placebo | NR | NR | NR | NR | NR | NR | NR | NR | NR
| Gabapentin 1200 | NR | NR | NR | NR | NR | NR | NR | NR | NR
Jawad (1989) | Placebo | 10^a^ | 0 | 0 | 0 | 0 | 5^a^ | 1^a^ | 5^a^ | 0
| Lamotrigine 400 | 8^a^ | 0 | 0 | 0 | 0 | 2^a^ | 0 | 6^a^ | 1^a^

a Calculated by ECRI based on reported information

b Reported only for the entire patient group, not separately for different groups.

>0 At least one patient had received the drug, but study did not report the number of patients who received the drug.

mg/kg milligrams per kilogram

Evidence Table 54. Tests of potential selection bias in studies of polytherapy

| | | | | | | | | Proportion With
| Mean Age | | Proportion Female | | Duration of Condition | | Baseline Seizure Frequency | | Partial Seizures | | Known Etiology | | 1,2 or 3 Prior AEDs
Reference | Test | p | Test | p | Test | p | Test | p | Test | p | Test | p | Test | p
Faught (2001) | t(201) = 0.04 | 0.96 | X ^2^(1) = 5.917 | 0.015 | t(201) = 0.018 | 0.99 | NC | NC | NC | NC | NC | NC | NC | NC
Ben-Menachem (2000) | t(284) = 0.08 | 0.93 | X ^2^(1) = 0.007 | 0.93 | t(284) = 0 | 1 | NC | NC | NC | NC | X ^2^(1) = 2.012 | 0.16 | NC | NC
Betts (2000) | F(2,116) = 1.78 | 0.17 | X ^2^(2) = 2.268 | 0.32 | F(2,116) = 1.250 | 0.29 | NC | NC | X ^2^(2) = 0.019 | 0.99 | X ^2^(2) = 2.268 | 0.32 | NC | NC
Cereghino (2000) | F(2,291) = 0 | 1 | X ^2^(2) = 3.769 | 0.15 | F(2,291) = 0.212 | 0.81 | NC | NC | NC | NC | NC | NC | X ^2^(4) = 4.316 | 0.37
Glauser (2000) | NC | NC | X ^2^(1) = 0.498 | 0.48 | NC | NC | NC | NC | NC | NC | NC | NC | NC | NC
Appleton (1999) | t(245) = 0.04 | 0.97 | X ^2^(1) = 2.019 | 0.16 | t(245) = 0.098 | 0.92 | t(245) = 0.056 | 0.96 | NC | NC | NC | NC | X ^2^(2) = 2.095 | 0.35
Biton (1999) | t(78) = 0.09 | 0.93 | X ^2^(1) = 0.865 | 0.35 | NC | NC | NC | NC | NC | NC | NC | NC | NC | NC
Duchowny (1999) | NC | NC | X ^2^(1) = 1.116 | 0.29 | NC | NC | NC | NC | NC | NC | X ^2^(1) = 0.168 | 0.68 | NC | NC
Elterman (1999) | t(84) = 0.06 | 0.95 | X ^2^(1) = 0.003 | 0.96 | NC | NC | NC | NC | NC | NC | NC | NC | X ^2^(2) = 2.78 | 0.25
KTSG (1999) | t(175) = 0.02 | 0.98 | X ^2^(1) = 0.309 | 0.58 | t(175) = 0.294 | 0.77 | t(175) = 0.195 | 0.85 | NC | NC | NC | NC | X ^2^(1) = 0.814 | 0.37
Sachdeo (1999) | t(96) = 0 | 1 | X ^2^(1) = 0.685 | 0.41 | NC | NC | NC | NC | NC | NC | NC | NC | X ^2^(2) = 0.390 | 0.82
Uthman (1998) | NC | NC | NC | NC | NC | NC | NC | NC | cNC | NC | NC | NC | NC | NC
Sachdeo (1997b) | NC | NC | X ^2^(2) = 2.596 | 0.27 | NC | NC | NC | NC | NC | NC | NC | NC | NC | NC
Ben-Menachem (1996) | NC | NC | NC | NC | NC | NC | NC | NC | NC | NC | NC | NC | NC | NC
Chadwick (1996) | NC | NC | X ^2^(1) = 0.661 | 0.42 | NC | NC | NC | NC | NC | NC | NC | NC | X ^2^(2) = 1.204 | 0.55
Faught (1996) | NC | NC | NC^a^ | NC^a^ | NC | NC | NC | NC | NC | NC | NC | NC | X ^2^(3) = 0.065 | 0.99
Privitera (1996) | NC | NC | X ^2^(3) = 4.481 | 0.21 | NC | NC | NC | NC | X ^2^(3) = 2.995 | 0.39 | NC | NC | X ^2^(3) = 3.724 | 0.29
Sharief (1996) | t(45) = 0.22 | 0.83 | X ^2^(1) = 1.365 | 0.24 | NC | NC | t(45) = 0.221 | 0.83 | X ^2^(1) = 0.503 | 0.48 | NC | NC | NC | NC
Tassinari (1996) | NC | NC | NC | NC | NC | NC | NC | NC | NC | NC | NC | NC | NC | NC
Willmore (1996) | NC | NC | NC | NC | NC | NC | t(145) = 0.062 | 0.95 | NC | NC | NC | NC | NC | NC
Anhut (1994) | NC | NC | NC | NC | NC | NC | NC | NC | NC | NC | NC | NC | NC | NC
FSG (1993) | NC | NC | X ^2^(1) = 0.345 | 0.56 | NC | NC | NC | NC | NC | NC | NC | NC | NC | NC
Matsuo (1993) | NC | NC | X ^2^(2) = 7.706 | 0.021 | NC | NC | NC | NC | NC | NC | NC | NC | X ^2^(4) = 6.838 | 0.15
McLean (1993) | NC | NC | X ^2^(3) = 3.046 | 0.38 | NC | NC | NC | NC | NC | NC | NC | NC | X ^2^(6) = 9.42 | 0.15
Schmidt (1993) | NC | NC | X ^2^(1) = 0.017 | 0.90 | NC | NC | NC | NC | NC | NC | NC | NC | NC | NC
Sivenius (1991) | NC | NC | NC | NC | NC | NC | NC | NC | NC | NC | NC | NC | NC | NC
UKGSG (1990) | NC | NC | X ^2^(1) = 0.275 | 0.60 | NC | NC | NC | NC | NC | NC | NC | NC | X ^2^(2) = 0.047 | 0.98
Messenheimer (1994) | NC | NC | X ^2^(1) = 0.046 | 0.83 | NC | NC | NC | NC | NC | NC | NC | NC | X ^2^(2) = 0.764 | 0.68
Bourgeois (1993) | NC | NC | X ^2^(1) = 0.009 | 0.92 | NC | NC | NC | NC | NC | NC | NC | NC | NC | NC
Jawad (1989) | NC | NC | NC | NC | NC | NC | NC | NC | NC | NC | NC | NC | X ^2^(1) = 1.485 | 0.22

a There was an error in the publication by Faught (1996) with respect to the numbers of males and females in the group that received topiramate 200 mg/day, thus we could not test for potential gender selection bias in that study.

NC Not calculable

Evidence Table 55. Overall test of age selection bias in trials of polytherapy

Reference | N | Summary Effect Size Hedges' d (CI)^a^ | p-value | Standardized Residual | Outlier by Standard Residual | Greatest Outlier by Q
Faught (2001) | 203 | -0.04 (-0.32 to 0.23) | 0.76 | 0.08 | No | NA
Ben-Menachem (2000) | 286 | -0.08 (-0.32 to 0.16) | 0.5 | -0.25 | No | NA
Betts (2000) | 119 | -0.36 (-0.75 to 0.03) | 0.07 | -1.6 | No | NA
Cereghino (2000) | 294 | 0 (-0.24 to 0.24) | 1 | 0.48 | No | NA
Appleton (1999) | 247 | -0.04 (-0.29 to 0.21) | 0.76 | 0.14 | No | NA
Biton (1999) | 80 | -0.09 (-0.53 to 0.35) | 0.69 | -0.16 | No | NA
Elterman (1999) | 86 | 0.06 (-0.37 to 0.48) | 0.79 | 0.53 | No | NA
KTSG (1999) | 177 | 0.02 (-0.27 to 0.32) | 0.87 | 0.56 | No | NA
Sachdeo (1999) | 98 | 0 (-0.4 to 0.4) | 1 | 0.28 | No | NA
Sharief (1996) | 47 | -0.22 (-0.79 to 0.36) | 0.46 | -0.57 | No | NA
Fixed Effects Summary Effect Size (Hedges' d) | | -0.06 (-0.15 to 0.04) | 0.277
Test of Homogeneity^b^ | | Q=3.62 | 0.935
Random Effects Summary Effect Size (Hedges' d) | | -0.06 (-0.15 to 0.04) | 0.277

a A positive effect size indicates that the mean age of patients in the add-on placebo group(s) was higher than the mean age of patients in the add-on drug group(s). The finding that the summary effect size was not different from zero indicates that there was no age bias in assignment of patients to groups.

b Critical Q = 14.68 (df = 9)

NA Not applicable

Evidence Table 56. Overall test of gender selection bias in studies of polytherapy

Reference | N | Summary Effect Size Hedges' d (CI)^a^ | p-value | Standardized Residual | Outlier by Standard Residual | Greatest Outlier by Q
Faught (2001) | 203 | 0.35 (0.07 to 0.63) | 0.01 | 2.21 | Yes | NA
Ben-Menachem (2000) | 286 | -0.01 (-0.25 to 0.23) | 0.93 | -0.44 | No | NA
Betts (2000) | 119 | -0.01 (-0.39 to 0.38) | 0.98 | -0.25 | No | NA
Cereghino (2000) | 294 | 0.24 (-0.01 to 0.48) | 0.06 | 1.63 | No | NA
Glauser (2000) | 267 | -0.09 (-0.33 to 0.15) | 0.48 | -1.09 | No | NA
Appleton (1999) | 247 | -0.18 (-0.43 to 0.07) | 0.15 | -1.81 | No | NA
Biton (1999) | 80 | 0.21 (-0.23 to 0.65) | 0.35 | 0.75 | No | NA
Duchowny (1999) | 199 | -0.15 (-0.43 to 0.13) | 0.29 | -1.39 | No | NA
Elterman (1999) | 86 | 0.01 (-0.41 to 0.43) | 0.96 | -0.14 | No | NA
KTSG (1999) | 177 | -0.08 (-0.38 to 0.21) | 0.58 | -0.85 | No | NA
Sachdeo (1999) | 98 | 0.17 (-0.23 to 0.56) | 0.41 | 0.63 | No | NA
Sachdeo (1997b) | 318 | 0.18 (-0.06 to 0.41) | 0.14 | 1.19 | No | NA
Chadwick (1996) | 129 | 0.14 (-0.2 to 0.49) | 0.42 | 0.59 | No | NA
Privitera (1996) | 190 | 0.31 (-0.02 to 0.64) | 0.06 | 1.63 | No | NA
Sharief (1996) | 47 | 0.35 (-0.22 to 0.92) | 0.23 | 1.06 | No | NA
Messenheimer (1994) | 88 | 0.05 (-0.37 to 0.46) | 0.83 | 0.02 | No | NA
Bourgeois (1993) | 64 | 0.02 (-0.47 to 0.51) | 0.92 | -0.07 | No | NA
FSG (1993) | 73 | 0.14 (-0.32 to 0.6) | 0.56 | 0.41 | No | NA
Matsuo (1993) | 216 | 0.03 (-0.25 to 0.31) | 0.84 | -0.09 | No | NA
McLean (1993) | 306 | -0.14 (-0.38 to 0.1) | 0.26 | -1.52 | No | NA
Schmidt (1993) | 139 | -0.02 (-0.35 to 0.31) | 0.9 | -0.38 | No | NA
UKGSG (1990) | 127 | -0.09 (-0.44 to 0.25) | 0.6 | -0.77 | No | NA
Fixed Effects Summary Effect Size (Hedges' d) | | 0.04 (-0.03 to 0.11) | 0.217
Test of Homogeneity^b^ | | Q = 23.32 | 0.327
Random Effects Summary Effect Size (Hedges' d) | | 0.04 (-0.03 to 0.11) | 0.229

a A positive effect size indicates that the proportion of females was greater in the placebo group than in the drug groups. The finding that the summary effect size was not different from zero indicates that there was no gender bias in assignment of patients to groups.

b Critical Q = 32.7 (df = 21)

NA Not applicable

Evidence Table 57. Overall test of duration of condition selection bias in trials of polytherapy

Reference | N | Summary Effect Size Hedges' d (CI)^a^ | p-value | Standardized Residual | Outlier by Standard Residual | Greatest Outlier by Q
Faught (2001) | 203 | -0.02 (-0.3 to 0.26) | 0.9 | -0.45 | No | NA
Ben-Menachem (2000) | 286 | 0 (-0.24 to 0.24) | 1 | -0.38 | No | NA
Betts (2000) | 119 | 0.22 (-0.16 to 0.61) | 0.25 | 0.97 | No | NA
Cereghino (2000) | 294 | 0.02 (-0.22 to 0.26) | 0.88 | -0.2 | No | NA
Appleton (1999) | 247 | -0.1 (-0.35 to 0.15) | 0.44 | -1.22 | No | NA
KTSG (1999) | 177 | 0.29 (0 to 0.59) | 0.05 | 1.79 | No | NA
Fixed Effects Summary Effect Size (Hedges' d) | | 0.04 (-0.07 to 0.15) | 0.463
Test of Homogeneity^b^ | | Q = 5.13 | 0.400
Random Effects Summary Effect Size (Hedges' d) | | 0.04 (-0.07 to 0.15) | 0.463

a A positive effect size indicates that the mean duration of condition of patients in the add-on placebo group(s) was higher than the mean duration of condition of patients in the add-on drug group(s). The finding that the summary effect size was not different from zero indicates that there was no duration of condition bias in assignment of patients to groups.

b Critical Q = 9.24 (df = 5)

NA Not applicable

Evidence Table 58. Overall test of prior drug selection bias in trials of polytherapy

Reference | N | Summary Effect Size Hedges' d (CI)^a^ | p-value | Standardized Residual | Outlier by Standard Residual | Greatest Outlier by Q
Cereghino (2000) | 294 | 0.2 (-0.04 to 0.45) | 0.1 | 1.81 | No | NA
Appleton (1999) | 247 | -0.18 (-0.43 to 0.07) | 0.15 | -1.47 | No | NA
Elterman (1999) | 87 | -0.36 (-0.78 to 0.06) | 0.09 | -1.68 | No | NA
KTSG (1999) | 177 | 0.14 (-0.16 to 0.43) | 0.37 | 1 | No | NA
Sachdeo (1999) | 98 | -0.01 (-0.4 to 0.39) | 0.97 | -0.01 | No | NA
Chadwick (1996) | 128 | -0.06 (-0.41 to 0.29) | 0.73 | -0.32 | No | NA
Faught (1996) | 181 | -0.02 (-0.36 to 0.32) | 0.9 | -0.08 | No | NA
Privitera (1996) | 190 | -0.21 (-0.54 to 0.12) | 0.21 | -1.26 | No | NA
Messenheimer (1994) | 88 | 0.19 (-0.23 to 0.6) | 0.39 | 0.92 | No | NA
Matsuo (1993) | 216 | -0.29 (-0.57 to -0.01) | 0.04 | -2.09 | Yes | NA
McLean (1993) | 306 | 0.19 (-0.05 to 0.44) | 0.11 | 1.77 | No | NA
UKGSG (1990) | 126 | 0.03 (-0.32 to 0.38) | 0.86 | 0.23 | No | NA
Jawad (1989) | 21 | 0.55 (-0.31 to 1.4) | 0.21 | 1.27 | No | NA
Fixed Effects Summary Effect Size (Hedges' d) | | 0.01 (-0.10 to 0.08) | 0.878
Test of Homogeneity^b^ | | Q=18.98 | 0.089
Random Effects Summary Effect Size (Hedges' d) | | -0.01 (-0.13 to 0.10) | 0.839

a A positive effect size indicates that the mean age of patients in the add-on placebo group(s) was higher than the mean age of patients in the add-on drug group(s). The finding that the summary effect size was not different from zero indicates that there was no prior-drug bias in assignment of patients to groups.

b Critical Q = 18.55 (df = 12)

NA Not applicable

Evidence Table 59. Seizure frequency outcomes in studies of polytherapy

Reference | Drug And Dose (mg/day) | Phase of Study | Overall Seizure Type^a^ | Specific Seizure Type(s)^a^ | Description of Outcome | N | N Using Intent-to-Treat | Outcomeb And Dispersion
Faught (2001) | Placebo | MTN | PAR | PAR | Number of patients with 50% or more seizure reduction | 72 | 85 | 16
| Zonisamide 400 | MTN | PAR | PAR | Number of patients with 50% or more seizure reduction | 98 | 118 | 41
| Placebo | MTN | PAR | PAR | Number of patients with 75% or more seizure reduction | 72 | 85 | 7^c^
| Zonisamide 400 | MTN | PAR | PAR | Number of patients with 75% or more seizure reduction | 98 | 118 | 20^c^
| Placebo | MTN | PAR | PAR | Number of patients seizure free | 72 | 85 | 2
| Zonisamide 400 | MTN | PAR | PAR | Number of patients seizure free | 98 | 118 | 6
| Placebo | MTN | PAR | PAR | Median % reduction from baseline in seizure frequency | 72 | 85 | 9
| Placebo | MTN | PAR | PAR | Median % reduction from baseline in seizure frequency | 85 | 85 | 5.6
| Zonisamide 400 | MTN | PAR | PAR | Median % reduction from baseline in seizure frequency | 118 | 118 | 32.3
| Zonisamide 400 | Subset of MTN | PAR | PAR | Median % reduction from baseline in seizure frequency | 98 | 118 | 40.5
Ben-Menachem (2000) | Placebo | MTN | PAR | PAR | Number of patients with 50% or more seizure reduction | 102 | 105 | 17^c^
| Levetiracetam 3000 | MTN | PAR | PAR | Number of patients with 50% or more seizure reduction | 171 | 181 | 72^c^
| Placebo | MTN | PAR | PAR | Number of patients seizure free | 102 | 105 | 1
| Levetiracetam 3000 | MTN | PAR | PAR | Number of patients seizure free | 171 | 181 | 14
| Placebo | MTN | PAR | PAR | Median monthly seizure frequency | 102 | 105 | 7.5^c^
| Levetiracetam 3000 | MTN | PAR | PAR | Median monthly seizure frequency | 171 | 181 | 4.6^c^
| Placebo | MTN | PAR | PAR | Median % reduction from baseline in seizure frequency | 102 | 105 | 7.2
| Levetiracetam 3000 | MTN | PAR | PAR | Median % reduction from baseline in seizure frequency | 171 | 181 | 39.9
| Placebo | MTN | PAR | PAR | Number needed to treat to yield one patient with 50% reduction | 102 | 105 | 3.9CI: 2.8–6.6
| Levetiracetam 3000 | MTN | PAR | PAR | Number needed to treat to yield one patient with 50% reduction | 171 | 181 | 3.9CI: 2.8–6.6
| Placebo | MTN | PAR | PAR | Number needed to treat to yield one patient seizure free | 102 | 105 | 13.9CI: 8.5–37.4
| Levetiracetam 3000 | MTN | PAR | PAR | Number needed to treat to yield one patient seizure free | 171 | 181 | 13.9CI: 8.5–37.4
Betts (2000) | Placebo | MTN | ALL | ALL | Number of patients with 50% or more seizure reduction | 31 | 39 | 5
| Levetiracetam 2000 | MTN | ALL | ALL | Number of patients with 50% or more seizure reduction | 27 | 42 | 13
| Levetiracetam 4000 | MTN | ALL | ALL | Number of patients with 50% or more seizure reduction | 28 | 38 | 8
| Placebo | MTN | ALL | ALL | Number of patients seizure free | 39 | 39 | 1
| Levetiracetam 2000 | MTN | ALL | ALL | Number of patients seizure free | 42 | 42 | 4
| Levetiracetam 4000 | MTN | ALL | ALL | Number of patients seizure free | 38 | 38 | 2
| Placebo | MTN | ALL | ALL | Median monthly seizure frequency | 31 | 39 | 6^c^
| Levetiracetam 2000 | MTN | ALL | ALL | Median monthly seizure frequency | 27 | 2 | 2.7^c^
| Levetiracetam 4000 | MTN | ALL | ALL | Median monthly seizure frequency | 28 | 38 | 2.5^c^
| Placebo | MTN | GEN | GEN | Median % reduction from baseline in seizure frequency | 15 | 16 | 5.6
| Levetiracetam 2000 | MTN | GEN | GEN | Median % reduction from baseline in seizure frequency | 15 | 17 | 66.7
| Levetiracetam 4000 | MTN | GEN | GEN | Median % reduction from baseline in seizure frequency | 17 | 17 | 46.8
| Placebo | MTN | PAR | PAR | Median % reduction from baseline in seizure frequency | 19 | 19 | 19.8
| Levetiracetam 2000 | MTN | PAR | PAR | Median % reduction from baseline in seizure frequency | 17 | 20 | 41.2
| Levetiracetam 4000 | MTN | PAR | PAR | Median % reduction from baseline in seizure frequency | 17 | 19 | 43.4
Cereghino (2000) | Placebo | TTR & MTN | PAR | PAR | Number of patients with 50% or more seizure reduction | 95 | 95 | 7^c^
| Placebo | MTN | PAR | PAR | Number of patients with 50% or more seizure reduction | 93 | 95 | 10
| Levetiracetam 1000 | TTR & MTN | PAR | PAR | Number of patients with 50% or more seizure reduction | 98 | 98 | 26^c^
| Levetiracetam 1000 | MTN | PAR | PAR | Number of patients with 50% or more seizure reduction | 94 | 98 | 31
| Levetiracetam 3000 | MTN | PAR | PAR | Number of patients with 50% or more seizure reduction | 98 | 101 | 39
| Levetiracetam 3000 | TTR & MTN | PAR | PAR | Number of patients with 50% or more seizure reduction | 101 | 101 | 40^c^
| Placebo | MTN | PAR | PAR | Number of patients with 75% or more seizure reduction | 93 | 95 | 1
| Levetiracetam 1000 | MTN | PAR | PAR | Number of patients with 75% or more seizure reduction | 94 | 98 | 12
| Levetiracetam 3000 | MTN | PAR | PAR | Number of patients with 75% or more seizure reduction | 98 | 101 | 20
| Placebo | MTN | PAR | PAR | Number of patients seizure free | 93 | 95 | 0
| Levetiracetam 1000 | MTN | PAR | PAR | Number of patients seizure free | 94 | 98 | 3
| Levetiracetam 3000 | MTN | PAR | PAR | Number of patients seizure free | 98 | 101 | 8
| Placebo | MTN | PAR | PAR | Median % reduction from baseline in seizure frequency | 93 | 95 | 6.8
| Placebo | TTR & MTN | PAR | PAR | Median % reduction from baseline in seizure frequency | 93 | 95 | 6.9
| Levetiracetam 1000 | MTN | PAR | PAR | Median % reduction from baseline in seizure frequency | 94 | 98 | 32.5
| Levetiracetam 1000 | TTR &amp; MTN | PAR | PAR | Median % reduction from baseline in seizure frequency | 98 | 98 | 36.9
| Levetiracetam 3000 | MTN | PAR | PAR | Median % reduction from baseline in seizure frequency | 98 | 101 | 37.1
| Levetiracetam 3000 | TTR & MTN | PAR | PAR | Median % reduction from baseline in seizure frequency | 101 | 101 | 38.1
Glauser (2000) | Placebo | TTR & MTN | PAR | CPS | Median % reduction from baseline in seizure frequency | 93 | NR | 10
| Oxcarbazepine 1800 | TTR & MTN | PAR | CPS | Median % reduction from baseline in seizure frequency | 108 | NR | 42
| Placebo | TTR & MTN | PAR | | Number of patients with 50% or more seizure reduction | 128 | 129 | 28^c^
| Oxcarbazepine 1800 | TTR & MTN | PAR | PAR | Number of patients with 50% or more seizure reduction | 135 | 138 | 55^c^
| Placebo | TTR & MTN | PAR | PAR | Number of patients seizure free | 128 | 129 | 1
| Oxcarbazepine 1800 | TTR & MTN | PAR | PAR | Number of patients seizure free | 135 | 138 | 5
| Placebo | TTR & MTN | PAR | PAR | Median % reduction from baseline in seizure frequency | 128 | 129 | 9
| Oxcarbazepine 1800 | TTR & MTN | PAR | PAR | Median % reduction from baseline in seizure frequency | 136 | 138 | 35
| Placebo | TTR & MTN | PAR | SG | Median % reduction from baseline in seizure frequency | 57 | 57 | 33
| Oxcarbazepine 1800 | TTR & MTN | PAR | SG | Median % reduction from baseline in seizure frequency | 48 | 50 | 78
| Placebo | TTR & MTN | PAR | SPS | Median % reduction from baseline in seizure frequency | 44 | NR | 16
| Oxcarbazepine 1800 | TTR & MTN | PAR | SPS | Median % reduction from baseline in seizure frequency | 41 | NR | 45
Appleton (1999) | Placebo | TTR & MTN | ALL | ALL | Number of patients seizure free | 120 | 128 | 1
| Gabapentin 1800 | TTR & MTN | ALL | ALL | Number of patients seizure free | 113 | 119 | 3
| Placebo | TTR & MTN | PAR | PAR | Number of patients with 25% or more seizure reduction | 120 | 128 | 43^c^
| Gabapentin 1800 | TTR & MTN | PAR | PAR | Number of patients with 25% or more seizure reduction | 113 | 119 | 47^c^
| Placebo | TTR & MTN | PAR | PAR | Number of patients with 25% or more seizure increase | 120 | 128 | 30^c^
| Gabapentin 1800 | TTR & MTN | PAR | PAR | Number of patients with 25% or more seizure increase | 113 | 119 | 14^c^
| Placebo | TTR & MTN | PAR | PAR | Number of patients with 50% or more seizure reduction | 120 | 128 | 21^c^
| Gabapentin 1800 | TTR & MTN | PAR | PAR | Number of patients with 50% or more seizure reduction | 113 | 119 | 24^c^
| Placebo | TTR & MTN | PAR | PAR | Number of patients with 50% or more seizure increase | 120 | 128 | 16^c^
| Gabapentin 1800 | TTR & MTN | PAR | PAR | Number of patients with 50% or more seizure increase | 113 | 119 | 7^c^
| Placebo | TTR & MTN | PAR | PAR | Number of patients with 75% or more seizure reduction | 120 | 128 | 11
| Gabapentin 1800 | TTR & MTN | PAR | PAR | Number of patients with 75% or more seizure reduction | 113 | 119 | 11
| Placebo | TTR & MTN | PAR | PAR | Number of patients with 75 or more seizure increase | 120 | 128 | 13^c^
| Gabapentin 1800 | TTR & MTN | PAR | PAR | Number of patients with 75 or more seizure increase | 113 | 119 | 5^c^
| Placebo | TTR & MTN | PAR | PAR | Number of patients with any seizure increase | 120 | 128 | 49^c^
| Gabapentin 1800 | TTR & MTN | PAR | PAR | Number of patients with any seizure increase | 113 | 119 | 26^c^
| Placebo | TTR & MTN | PAR | PAR | Mean adjusted risk ratio | 128 | 128 | -0.079
| Placebo | TTR & MTN | PAR | PAR | Mean adjusted risk ratio | 120 | 128 | -0.072
| Gabapentin 1800 | TTR & MTN | PAR | PAR | Mean adjusted risk ratio | 113 | 119 | -0.161
| Gabapentin 1800 | TTR & MTN | PAR | PAR | Mean adjusted risk ratio | 119 | 119 | -0.146
| Placebo | TTR & MTN | PAR | PAR | Median % reduction from baseline in seizure frequency | 120 | 128 | 6.5
| Gabapentin 1800 | TTR & MTN | PAR | PAR | Median % reduction from baseline in seizure frequency | 113 | 119 | 17
Biton (1999) | Placebo | TTR & MTN | GEN | GEN | Number of patients with 50% or more seizure reduction | 41 | 41 | 7
| Topiramate 400 | TTR & MTN | GEN | GEN | Number of patients with 50% or more seizure reduction | 39 | 39 | 18
| Placebo | TTR & MTN | GEN | GEN | Number of patients with 75% or more seizure reduction | 41 | 41 | 3
| Topiramate 400 | TTR & MTN | GEN | GEN | Number of patients with 75% or more seizure reduction | 39 | 39 | 10
| Placebo | TTR & MTN | GEN | GEN | Number of patients seizure free | 41 | 41 | 0
| Topiramate 400 | TTR & MTN | GEN | GEN | Number of patients seizure free | 39 | 39 | 2
| Placebo | TTR & MTN | GEN | GEN | Median % reduction from baseline in seizure frequency | 41 | 41 | 1
| Topiramate 400 | TTR & MTN | GEN | GEN | Median % reduction from baseline in seizure frequency | 39 | 39 | 42
| Placebo | TTR & MTN | GEN | GTC | Number of patients with 50% or more seizure reduction | 40 | 40 | 8
| Topiramate 400 | TTR & MTN | GEN | GTC | Number of patients with 50% or more seizure reduction | 39 | 39 | 22
| Placebo | TTR & MTN | GEN | GTC | Number of patients with 75% or more seizure reduction | 40 | 40 | 5
| Topiramate 400 | TTR & MTN | GEN | GTC | Number of patients with 75% or more seizure reduction | 39 | 39 | 13
| Placebo | TTR & MTN | GEN | GTC | Number of patients seizure free | 40 | 40 | 2
| Topiramate 400 | TTR & MTN | GEN | GTC | Number of patients seizure free | 39 | 39 | 5
| Placebo | TTR & MTN | GEN | GTC | Median % reduction from baseline in seizure frequency | 40 | 40 | 9
| Topiramate 400 | TTR & MTN | GEN | GTC | Median % reduction from baseline in seizure frequency | 30 | 30 | 57
Duchowny (1999) | Placebo | MTN | PAR | PAR | Number of patients with 25% or more seizure reduction | 101 | 101 | 39^c^
| Lamotrigine 750 | MTN | PAR | PAR | Number of patients with 25% or more seizure reduction | 98 | 98 | 54^c^
| Placebo | TTR & MTN | PAR | PAR | Number of patients with 50% or more seizure reduction | 101 | 101 | 25^c^
| Placebo | MTN | PAR | PAR | Number of patients with 50% or more seizure reduction | 101 | 101 | 16^c^
| Lamotrigine 750 | TTR & MTN | PAR | PAR | Number of patients with 50% or more seizure reduction | 98 | 98 | 40^c^
| Lamotrigine 750 | MTN | PAR | PAR | Number of patients with 50% or more seizure reduction | 98 | 98 | 42^c^
| Placebo | TTR & MTN | PAR | PAR | Median monthly seizure frequency | 101 | 101 | 8
| Placebo | MTN | PAR | PAR | Median monthly seizure frequency | 101 | 101 | 8.5
| Lamotrigine 750 | TTR & MTN | PAR | PAR | Median monthly seizure frequency | 98 | 98 | 3
| Lamotrigine 750 | MTN | PAR | PAR | Median monthly seizure frequency | 98 | 98 | 5
| Placebo | MTN | PAR | PAR | Median % reduction from baseline in seizure frequency | 101 | 101 | 6.7
| Placebo | TTR & MTN | PAR | PAR | Median % reduction from baseline in seizure frequency | 101 | 101 | 12.8
| Lamotrigine 750 | MTN | PAR | PAR | Median % reduction from baseline in seizure frequency | 98 | 98 | 36.1
| Lamotrigine 750 | TTR & MTN | PAR | PAR | Median % reduction from baseline in seizure frequency | 98 | 98 | 44
| Placebo | MTN | PAR | SG | Number of patients with 25% or more seizure reduction | 46 | 46 | 17^c^
| Lamotrigine 750 | MTN | PAR | SG | Number of patients with 25% or more seizure reduction | 40 | 40 | 25^c^
| Placebo | MTN | PAR | SG | Number of patients with 50% or more seizure reduction | 46 | 46 | 12^c^
| Placebo | TTR & MTN | PAR | SG | Number of patients with 50% or more seizure reduction | 46 | 46 | 14^c^
| Lamotrigine 750 | MTN | PAR | SG | Number of patients with 50% or more seizure reduction | 40 | 40 | 21^c^
| Lamotrigine 750 | TTR & MTN | PAR | SG | Number of patients with 50% or more seizure reduction | 40 | 40 | 23^c^
| Placebo | TTR & MTN | PAR | SG | Median monthly seizure frequency | 46 | 46 | 1.5
| Placebo | TTR & MTN | PAR | SG | Median monthly seizure frequency | 46 | 46 | 1.5
| Lamotrigine 750 | TTR & MTN | PAR | SG | Median monthly seizure frequency | 40 | 40 | 0.8
| Lamotrigine 750 | TTR & MTN | PAR | SG | Median monthly seizure frequency | 40 | 40 | 1.2
| Placebo | TTR & MTN | PAR | SG | Median % reduction from baseline in seizure frequency | 46 | 46 | 8.6
| Placebo | TTR & MTN | PAR | SG | Median % reduction from baseline in seizure frequency | 46 | 46 | 11.2
| Lamotrigine 750 | TTR & MTN | PAR | SG | Median % reduction from baseline in seizure frequency | 40 | 40 | 53
| Lamotrigine 750 | TTR & MTN | PAR | SG | Median % reduction from baseline in seizure frequency | 40 | 40 | 66.7
Elterman (1999) | Placebo | TTR & MTN | PAR | PAR | Number of patients with 50% or more seizure reduction | 45 | 45 | 9
| Topiramate 400 | TTR & MTN | PAR | PAR | Number of patients with 50% or more seizure reduction | 41 | 41 | 16
| Placebo | TTR & MTN | PAR | PAR | Number of patients with 75% or more seizure reduction | 45 | 45 | 1
| Topiramate 400 | TTR & MTN | PAR | PAR | Number of patients with 75% or more seizure reduction | 41 | 41 | 7
| Placebo | TTR & MTN | PAR | PAR | Number of patients seizure free | 45 | 45 | 0
| Placebo | MTN | PAR | PAR | Number of patients seizure free | 43 | 45 | 2
| Topiramate 400 | TTR & MTN | PAR | PAR | Number of patients seizure free | 41 | 41 | 2
| Topiramate 400 | MTN | PAR | PAR | Number of patients seizure free | 41 | 41 | 4
| Placebo | TTR & MTN | PAR | PAR | Median % reduction from baseline in seizure frequency | 45 | 45 | 10.5
| Topiramate 400 | TTR & MTN | PAR | PAR | Median % reduction from baseline in seizure frequency | 41 | 41 | 33.1
| Placebo | TTR & MTN | PAR | SG | Number of patients with 50% or more seizure reduction | 20 | 20 | 6
| Topiramate 400 | TTR & MTN | PAR | SG | Number of patients with 50% or more seizure reduction | 20 | 20 | 9
| Placebo | TTR & MTN | PAR | SG | Number of patients with 75% or more seizure reduction | 20 | 20 | 3
| Topiramate 400 | TTR & MTN | PAR | SG | Number of patients with 75% or more seizure reduction | 20 | 20 | 6
| Placebo | TTR & MTN | PAR | SG | Median % reduction from baseline in seizure frequency | 20 | 20 | -10.6
| Topiramate 400 | TTR & MTN | PAR | SG | Median % reduction from baseline in seizure frequency | 20 | 20 | 31.6
KTSG (1999) | Placebo | TTR & MTN | PAR | CPS | Mean % reduction from baseline in seizure frequency | 72 | 72 | -14.2SD 662.5
| Topiramate 600 | TTR & MTN | PAR | CPS | Mean % reduction from baseline in seizure frequency | 70 | 70 | 28.4SD 96.7
| Placebo | TTR & MTN | PAR | CPS | Median % reduction from baseline in seizure frequency | 72 | 72 | -14.3
| Topiramate 600 | TTR & MTN | PAR | CPS | Median % reduction from baseline in seizure frequency | 70 | 70 | 49.4
| Placebo | TTR & MTN | PAR | PAR | Number of patients with 50% or more seizure reduction | 85 | 86 | 11
| Topiramate 600 | TTR & MTN | PAR | PAR | Number of patients with 50% or more seizure reduction | 89 | 91 | 45
| Placebo | TTR & MTN | PAR | PAR | Number of patients seizure free | 85 | 86 | 1
| Placebo | TTR & MTN | PAR | PAR | Number of patients seizure free | 80 | 86 | 2
| Topiramate 600 | TTR & MTN | PAR | PAR | Number of patients seizure free | 89 | 91 | 7
| Topiramate 600 | TTR & MTN | PAR | PAR | Number of patients seizure free | 78 | 91 | 13
| Placebo | TTR & MTN | PAR | PAR | Median monthly seizure frequency | 85 | 86 | 5.1
| Topiramate 600 | TTR & MTN | PAR | PAR | Median monthly seizure frequency | 89 | 91 | 2.4
| Placebo | TTR & MTN | PAR | PAR | Median % reduction from baseline in seizure frequency | 85 | 86 | 9.1
| Topiramate 600 | TTR & MTN | PAR | PAR | Median % reduction from baseline in seizure frequency | 89 | 91 | 51.3
| Placebo | TTR & MTN | PAR | SG | Mean % reduction from baseline in seizure frequency | 35 | 39 | -15.2SD 173.1
| Topiramate 600 | TTR & MTN | PAR | SG | Mean % reduction from baseline in seizure frequency | 28 | 31 | 26.3SD 128.7
| Placebo | TTR & MTN | PAR | SG | Median % reduction from baseline in seizure frequency | 35 | 39 | 40.3
| Topiramate 600 | TTR & MTN | PAR | SG | Median % reduction from baseline in seizure frequency | 28 | 31 | 100
| Placebo | TTR & MTN | PAR | SPS | Mean % reduction from baseline in seizure frequency | 4 | 5 | 52.5SD 64.2
| Topiramate 600 | TTR & MTN | PAR | SPS | Mean % reduction from baseline in seizure frequency | 9 | 11 | 60.6SD 59.3
| Placebo | TTR & MTN | PAR | SPS | Median % reduction from baseline in seizure frequency | 4 | 5 | 72.9
| Topiramate 600 | TTR & MTN | PAR | SPS | Median % reduction from baseline in seizure frequency | 9 | 11 | 87.5
Sachdeo (1999) | Placebo | TTR & MTN | ALL | ALL | Number of patients with 75% or more seizure reduction | 50 | 50 | 0
| Topiramate 600 | TTR & MTN | ALL | ALL | Number of patients with 75% or more seizure reduction | 48 | 48 | 4
| Placebo | TTR & MTN | ALL | ALL | Median % reduction from baseline in seizure frequency | 50 | 50 | 8.8
| Topiramate 600 | TTR & MTN | ALL | ALL | Median % reduction from baseline in seizure frequency | 48 | 48 | 20.6
| Placebo | TTR & MTN | ALL | ALL except ABS | Median % reduction from baseline in seizure frequency | 50 | 50 | 2
| Topiramate 600 | TTR & MTN | ALL | ALL except ABS | Median % reduction from baseline in seizure frequency | 48 | 48 | 23.9
| Placebo | TTR & MTN | GEN | GTC, TON, ATO | Number of patients with 50% or more seizure reduction | 50 | 50 | 4
| Topiramate 600 | TTR & MTN | GEN | GTC, TON, ATO | Number of patients with 50% or more seizure reduction | 46 | 48 | 15
| Placebo | TTR & MTN | GEN | GTC, TON, ATO | Number of patients with 75% or more seizure reduction | 50 | 50 | 2
| Topiramate 600 | TTR & MTN | GEN | GTC, TON, ATO | Number of patients with 75% or more seizure reduction | 46 | 48 | 8
| Placebo | TTR & MTN | GEN | GTC, TON, ATO | Number of patients seizure free | 50 | 50 | 0
| Topiramate 600 | TTR & MTN | GEN | GTC, TON, ATO | Number of patients seizure free | 46 | 48 | 1
| Placebo | TTR & MTN | GEN | GTC, TON, ATO | Median % reduction from baseline in seizure frequency | 50 | 50 | -5.2
| Topiramate 600 | TTR & MTN | GEN | GTC, TON, ATO | Median % reduction from baseline in seizure frequency | 46 | 48 | 25.8
| Placebo | TTR & MTN | GEN | TON, ATO | Number of patients with 50% or more seizure reduction | 49 | 50 | 7
| Topiramate 600 | TTR & MTN | GEN | TON, ATO | Number of patients with 50% or more seizure reduction | 46 | 48 | 13
| Placebo | TTR & MTN | GEN | TON, ATO | Number of patients with 75% or more seizure reduction | 49 | 50 | 3
| Topiramate 600 | TTR & MTN | GEN | TON, ATO | Number of patients with 75% or more seizure reduction | 46 | 48 | 8
| Placebo | TTR & MTN | GEN | TON, ATO | Number of patients seizure free | 49 | 50 | 0
| Placebo | MTN | GEN | TON, ATO | Number of patients seizure free | 49 | 50 | 0
| Topiramate 600 | TTR & MTN | GEN | TON, ATO | Number of patients seizure free | 46 | 48 | 1
| Topiramate 600 | MTN | GEN | TON, ATO | Number of patients seizure free | 46 | 48 | 5
| Placebo | TTR & MTN | GEN | TON, ATO | Median % reduction from baseline in seizure frequency | 49 | 50 | -5.1
| Topiramate 600 | TTR & MTN | GEN | TON, ATO | Median % reduction from baseline in seizure frequency | 46 | 48 | 14.8
Uthman (1998) | Placebo | TTR & MTN | PAR | CPS | Number of patients with 50% or more seizure reduction | 90 | 90 | 4
| Tiagabine 16 | TTR & MTN | PAR | CPS | Number of patients with 50% or more seizure reduction | 61 | 61 | 5
| Tiagabine 32 | TTR & MTN | PAR | CPS | Number of patients with 50% or more seizure reduction | 86 | 86 | 17
| Tiagabine 56 | TTR & MTN | PAR | CPS | Number of patients with 50% or more seizure reduction | 55 | 55 | 16
| Placebo | TTR & MTN | PAR | CPS | Median monthly seizure frequency | 90 | 90 | 7.4
| Placebo | TTR & MTN | PAR | CPS | Median monthly seizure frequency | 90 | 90 | 7.4
| Placebo | TTR & MTN | PAR | CPS | Median monthly seizure frequency | 90 | 90 | 7.4
| Tiagabine 16 | TTR & MTN | PAR | CPS | Median monthly seizure frequency | 61 | 61 | 8.5
| Tiagabine 32 | TTR & MTN | PAR | CPS | Median monthly seizure frequency | 86 | 86 | 9.6
| Tiagabine 56 | TTR & MTN | PAR | CPS | Median monthly seizure frequency | 55 | 55 | 9.1
| Placebo | TTR & MTN | PAR | CPS | Median % reduction from baseline in seizure frequency | 90 | 90 | 11
| Placebo | TTR & MTN | PAR | CPS | Median % reduction from baseline in seizure frequency | 90 | 90 | 11
| Tiagabine 16 | TTR & MTN | PAR | CPS | Median % reduction from baseline in seizure frequency | 61 | 61 | 13
| Tiagabine 32 | TTR & MTN | PAR | CPS | Median % reduction from baseline in seizure frequency | 86 | 86 | 25
| Tiagabine 56 | TTR & MTN | PAR | CPS | Median % reduction from baseline in seizure frequency | 55 | 55 | 33
| Placebo | TTR & MTN | PAR | CPS | Median difference from baseline in seizure frequency | 90 | 90 | 0.7
| Tiagabine 16 | TTR & MTN | PAR | CPS | Median difference from baseline in seizure frequency | 61 | 61 | 0.8
| Tiagabine 32 | TTR & MTN | PAR | CPS | Median difference from baseline in seizure frequency | 86 | 86 | 2.2
| Tiagabine 56 | TTR & MTN | PAR | CPS | Median difference from baseline in seizure frequency | 55 | 55 | 2.8
| Placebo | TTR & MTN | PAR | SG | Number of patients with a change in seizure type | 90 | 90 | 3
| Tiagabine 16 | TTR & MTN | PAR | SG | Number of patients with a change in seizure type | 61 | 61 | 4
| Tiagabine 32 | TTR & MTN | PAR | SG | Number of patients with a change in seizure type | 88 | 88 | 5
| Tiagabine 56 | TTR & MTN | PAR | SG | Number of patients with a change in seizure type | 57 | 57 | 3
| Placebo | TTR & MTN | PAR | SG | Number of patients with any seizure increase | 35 | 35 | 16
| Tiagabine 16 | TTR & MTN | PAR | SG | Number of patients with any seizure increase | 28 | 28 | 9
| Tiagabine 32 | TTR & MTN | PAR | SG | Number of patients with any seizure increase | 32 | 32 | 11
| Tiagabine 56 | TTR & MTN | PAR | SG | Number of patients with any seizure increase | 26 | 26 | 10
| Placebo | TTR & MTN | PAR | SG | Median monthly seizure frequency | 38 | 38 | 1.8
| Tiagabine 16 | TTR & MTN | PAR | SG | Median monthly seizure frequency | 32 | 32 | 0.9
| Tiagabine 32 | TTR & MTN | PAR | SG | Median monthly seizure frequency | 37 | 37 | 1
| Tiagabine 56 | TTR & MTN | PAR | SG | Median monthly seizure frequency | 29 | 29 | 0.8
| Placebo | TTR & MTN | PAR | SPS | Number of patients with 50% or more seizure reduction | 51 | 51 | 5
| Tiagabine 16 | TTR & MTN | PAR | SPS | Number of patients with 50% or more seizure reduction | 39 | 39 | 11
| Tiagabine 32 | TTR & MTN | PAR | SPS | Number of patients with 50% or more seizure reduction | 49 | 49 | 17
| Tiagabine 56 | TTR & MTN | PAR | SPS | Number of patients with 50% or more seizure reduction | 33 | 33 | 12
| Placebo | TTR & MTN | PAR | SPS | Number of patients with any seizure increase | 51 | 51 | 31
| Tiagabine 16 | TTR & MTN | PAR | SPS | Number of patients with any seizure increase | 39 | 39 | 9
| Tiagabine 32 | TTR & MTN | PAR | SPS | Number of patients with any seizure increase | 49 | 49 | 19
| Tiagabine 56 | TTR & MTN | PAR | SPS | Number of patients with any seizure increase | 33 | 33 | 9
| Placebo | TTR & MTN | PAR | SPS | Median monthly seizure frequency | 51 | 51 | 8.6
| Placebo | TTR & MTN | PAR | SPS | Median monthly seizure frequency | 51 | 51 | 8.6
| Placebo | TTR & MTN | PAR | SPS | Median monthly seizure frequency | 51 | 51 | 8.6
| Tiagabine 16 | TTR & MTN | PAR | SPS | Median monthly seizure frequency | 39 | 39 | 9.7
| Tiagabine 32 | TTR & MTN | PAR | SPS | Median monthly seizure frequency | 49 | 49 | 13.7
| Tiagabine 56 | TTR & MTN | PAR | SPS | Median monthly seizure frequency | 33 | 33 | 9.1
| Placebo | TTR & MTN | PAR | SPS | Median % reduction from baseline in seizure frequency | 51 | 51 | -10.5
| Tiagabine 16 | TTR & MTN | PAR | SPS | Median % reduction from baseline in seizure frequency | 39 | 39 | 23.7
| Tiagabine 32 | TTR & MTN | PAR | SPS | Median % reduction from baseline in seizure frequency | 49 | 49 | 12.4
| Tiagabine 56 | TTR & MTN | PAR | SPS | Median % reduction from baseline in seizure frequency | 33 | 33 | 36.3
| Placebo | TTR & MTN | PAR | SPS | Median difference from baseline in seizure frequency | 51 | 51 | 0.9
| Tiagabine 16 | TTR & MTN | PAR | SPS | Median difference from baseline in seizure frequency | 39 | 39 | 2.3
| Tiagabine 32 | TTR & MTN | PAR | SPS | Median difference from baseline in seizure frequency | 49 | 49 | 1.7
| Tiagabine 56 | TTR & MTN | PAR | SPS | Median difference from baseline in seizure frequency | 33 | 33 | 3.3
Sachdeo (1997b) | Placebo | TTR & MTN | PAR | CPS | Number of patients with 50% or more seizure reduction | 107 | 107 | 10
| Tiagabine 32 | TTR & MTN | PAR | CPS | Number of patients with 50% or more seizure reduction | 105 | 105 | 28
| Tiagabine 32 | TTR & MTN | PAR | CPS | Number of patients with 50% or more seizure reduction | 106 | 106 | 33
| Placebo | TTR & MTN | PAR | CPS | Median monthly seizure frequency | 107 | 107 | 8.1
| Placebo | TTR & MTN | PAR | CPS | Median monthly seizure frequency | 107 | 107 | 8.1
| Tiagabine 32 | TTR & MTN | PAR | CPS | Median monthly seizure frequency | 105 | 105 | 5.8
| Tiagabine 32 | TTR & MTN | PAR | CPS | Median monthly seizure frequency | 106 | 106 | 6.2
| Placebo | TTR & MTN | PAR | CPS | Median difference from baseline in seizure frequency | 107 | 107 | 0.2
| Tiagabine 32 | TTR & MTN | PAR | CPS | Median difference from baseline in seizure frequency | 105 | 105 | 1.2
| Tiagabine 32 | TTR & MTN | PAR | CPS | Median difference from baseline in seizure frequency | 106 | 106 | 1.6
| Placebo | TTR & MTN | PAR | PAR | Number of patients with 50% or more seizure reduction | 107 | 107 | 8
| Tiagabine 32 | TTR & MTN | PAR | PAR | Number of patients with 50% or more seizure reduction | 105 | 105 | 24
| Tiagabine 32 | TTR & MTN | PAR | PAR | Number of patients with 50% or more seizure reduction | 106 | 106 | 30
Ben-Menachem (1996) | Placebo | TTR & MTN | PAR | PAR | Number of patients with 50% or more seizure reduction | 28 | 28 | 0
| Topiramate 800 | TTR & MTN | PAR | PAR | Number of patients with 50% or more seizure reduction | 28 | 28 | 12
| Placebo | TTR & MTN | PAR | PAR | Number of patients with 75% or more seizure reduction | 28 | 28 | 0
| Topiramate 800 | TTR & MTN | PAR | PAR | Number of patients with 75% or more seizure reduction | 28 | 28 | 10
| Placebo | TTR & MTN | PAR | PAR | Median % reduction from baseline in seizure frequency | 28 | 28 | -17.8Range -152.1 to 42.3
| Topiramate 800 | TTR & MTN | PAR | PAR | Median % reduction from baseline in seizure frequency | 28 | 28 | 35.8Range -554.6 to 100
| Placebo | TTR & MTN | PAR | SG | Number of patients with 50% or more seizure reduction | 13 | 13 | 3
| Topiramate 800 | TTR & MTN | PAR | SG | Number of patients with 50% or more seizure reduction | 11 | 11 | 9
| Placebo | TTR & MTN | PAR | SG | Number of patients seizure free | 13 | 13 | 2
| Topiramate 800 | TTR & MTN | PAR | SG | Number of patients seizure free | 11 | 11 | 6
| Placebo | TTR & MTN | PAR | SG | Median % reduction from baseline in seizure frequency | 13 | 13 | 18.8
| Topiramate 800 | TTR & MTN | PAR | SG | Median % reduction from baseline in seizure frequency | 11 | 11 | 19
Chadwick (1996) | Placebo | TTR & MTN | GEN | ABS | Number of patients with 50% or more seizure reduction | 14 | NR | 1
| Gabapentin 1200 | TTR & MTN | GEN | ABS | Number of patients with 50% or more seizure reduction | 15 | NR | 1
| Placebo | TTR & MTN | GEN | ABS | Mean risk ratio | 14 | NR | 0.174SEM .112
| Gabapentin 1200 | TTR & MTN | GEN | ABS | Mean risk ratio | 15 | NR | 0.14SEM.134
| Placebo | TTR & MTN | GEN | ABS | Median % reduction from baseline in seizure frequency | 14 | NR | -2.3
| Gabapentin 1200 | TTR & MTN | GEN | ABS | Median % reduction from baseline in seizure frequency | 15 | NR | -5.5
| Placebo | TTR & MTN | GEN | GTC | Number of patients with 50% or more seizure reduction | 57 | NR | 10
| Gabapentin 1200 | TTR & MTN | GEN | GTC | Number of patients with 50% or more seizure reduction | 40 | NR | 11
| Placebo | TTR & MTN | GEN | GTC | Mean adjusted risk ratio | 57 | NR | -0.034
| Gabapentin 1200 | TTR & MTN | GEN | GTC | Mean adjusted risk ratio | 40 | NR | -0.181
| Placebo | TTR & MTN | GEN | GTC | Mean risk ratio | 57 | NR | -0.057SEM .061
| Gabapentin 1200 | TTR & MTN | GEN | GTC | Mean risk ratio | 40 | NR | -0.155SEM .066
| Placebo | TTR & MTN | GEN | GTC | Median % reduction from baseline in seizure frequency | 53 | NR | 15.2
| Gabapentin 1200 | TTR & MTN | GEN | GTC | Median % reduction from baseline in seizure frequency | 39 | NR | 29.3
| Placebo | TTR & MTN | GEN | MYO | Number of patients with 50% or more seizure reduction | 56 | NR | 13
| Gabapentin 1200 | TTR & MTN | GEN | MYO | Number of patients with 50% or more seizure reduction | 39 | NR | 11
| Placebo | TTR & MTN | GEN | MYO | Mean risk ratio | 56 | NR | -0.078
| Gabapentin 1200 | TTR & MTN | GEN | MYO | Mean risk ratio | 39 | NR | -0.117
| Placebo | TTR & MTN | GEN | MYO | Median % reduction from baseline in seizure frequency | 56 | NR | 16.5
| Gabapentin 1200 | TTR & MTN | GEN | MYO | Median % reduction from baseline in seizure frequency | 39 | NR | 16.4
| Placebo | TTR & MTN | GEN | OTH | Number of patients with 50% or more seizure reduction | 28 | NR | 4
| Gabapentin 1200 | TTR & MTN | GEN | OTH | Number of patients with 50% or more seizure reduction | 17 | NR | 7
| Placebo | TTR & MTN | GEN | OTH | Mean adjusted risk ratio | 28 | NR | 0.002
| Gabapentin 1200 | TTR & MTN | GEN | OTH | Mean adjusted risk ratio | 17 | NR | -0.182
| Placebo | TTR & MTN | GEN | OTH | Mean risk ratio | 28 | NR | 0.002SEM .096
| Gabapentin 1200 | TTR & MTN | GEN | OTH | Mean risk ratio | 17 | NR | -0.182SEM .126
| Placebo | TTR & MTN | GEN | OTH | Median % reduction from baseline in seizure frequency | 25 | NR | 15.2
| Gabapentin 1200 | TTR & MTN | GEN | OTH | Median % reduction from baseline in seizure frequency | 16 | NR | 41.9
Faught (1996) | Placebo | TTR & MTN | PAR | PAR | Number of patients with 50% or more seizure reduction | 45 | 45 | 8
| Topiramate 200 | TTR & MTN | PAR | PAR | Number of patients with 50% or more seizure reduction | 45 | 45 | 12
| Topiramate 400 | TTR & MTN | PAR | PAR | Number of patients with 50% or more seizure reduction | 45 | 45 | 21
| Topiramate 600 | TTR & MTN | PAR | PAR | Number of patients with 50% or more seizure reduction | 46 | 46 | 21
| Placebo | TTR & MTN | PAR | PAR | Number of patients with 75% or more seizure reduction | 45 | 45 | 4^c^
| Topiramate 200 | TTR & MTN | PAR | PAR | Number of patients with 75% or more seizure reduction | 45 | 45 | 4^c^
| Topiramate 400 | TTR & MTN | PAR | PAR | Number of patients with 75% or more seizure reduction | 45 | 45 | 10^c^
| Topiramate 600 | TTR & MTN | PAR | PAR | Number of patients with 75% or more seizure reduction | 46 | 46 | 10^c^
| Placebo | TTR & MTN | PAR | PAR | Median % reduction from baseline in seizure frequency | 45 | 45 | 13.1
| Placebo | TTR & MTN | PAR | PAR | Median % reduction from baseline in seizure frequency | 45 | 45 | 13.1
| Placebo | TTR & MTN | PAR | PAR | Median % reduction from baseline in seizure frequency | 45 | 45 | 13.1
| Topiramate 200 | TTR & MTN | PAR | PAR | Median % reduction from baseline in seizure frequency | 45 | 45 | 29.6
| Topiramate 400 | TTR & MTN | PAR | PAR | Median % reduction from baseline in seizure frequency | 45 | 45 | 47.8
| Topiramate 600 | TTR & MTN | PAR | PAR | Median % reduction from baseline in seizure frequency | 46 | 46 | 44.7
| Placebo | TTR & MTN | PAR | SG | Number of patients with 50% or more seizure reduction | 14 | 14 | 3
| Topiramate 200 | TTR & MTN | PAR | SG | Number of patients with 50% or more seizure reduction | 14 | 14 | 10
| Topiramate 400 | TTR & MTN | PAR | SG | Number of patients with 50% or more seizure reduction | 15 | 15 | 13
| Topiramate 600 | TTR & MTN | PAR | SG | Number of patients with 50% or more seizure reduction | 13 | 13 | 10
| Placebo | TTR & MTN | PAR | SG | Number of patients seizure free | 14 | 14 | 0
| Topiramate 200 | TTR & MTN | PAR | SG | Number of patients seizure free | 14 | 14 | 3
| Topiramate 400 | TTR & MTN | PAR | SG | Number of patients seizure free | 15 | 15 | 8
| Topiramate 600 | TTR & MTN | PAR | SG | Number of patients seizure free | 13 | 13 | 4
| Placebo | TTR & MTN | PAR | SG | Median % reduction from baseline in seizure frequency | 14 | 14 | 1
| Topiramate 200 | TTR & MTN | PAR | SG | Median % reduction from baseline in seizure frequency | 14 | 14 | 62
| Topiramate 400 | TTR & MTN | PAR | SG | Median % reduction from baseline in seizure frequency | 15 | 15 | 100
| Topiramate 600 | TTR & MTN | PAR | SG | Median % reduction from baseline in seizure frequency | 13 | 13 | 89
Privitera (1996) | Placebo | TTR & MTN | PAR | PAR | Number of patients with 50% or more seizure reduction | 47 | 47 | 4
| Topiramate 600 | TTR & MTN | PAR | PAR | Number of patients with 50% or more seizure reduction | 48 | 48 | 21
| Topiramate 800 | TTR & MTN | PAR | PAR | Number of patients with 50% or more seizure reduction | 48 | 48 | 19
| Topiramate 1000 | TTR & MTN | PAR | PAR | Number of patients with 50% or more seizure reduction | 47 | 47 | 18
| Placebo | TTR & MTN | PAR | PAR | Number of patients with 75% or more seizure reduction | 47 | 47 | 0
| Topiramate 600 | TTR & MTN | PAR | PAR | Number of patients with 75% or more seizure reduction | 48 | 48 | 11^c^
| Placebo | TTR & MTN | PAR | PAR | Median % reduction from baseline in seizure frequency | 47 | 47 | 1.2
| Placebo | TTR & MTN | PAR | PAR | Median % reduction from baseline in seizure frequency | 47 | 47 | 1.2
| Placebo | TTR & MTN | PAR | PAR | Median % reduction from baseline in seizure frequency | 47 | 47 | 1.2
| Topiramate 600 | TTR & MTN | PAR | PAR | Median % reduction from baseline in seizure frequency | 48 | 48 | 40.7
| Topiramate 800 | TTR & MTN | PAR | PAR | Median % reduction from baseline in seizure frequency | 48 | 48 | 41
| Topiramate 1000 | TTR & MTN | PAR | PAR | Median % reduction from baseline in seizure frequency | 47 | 47 | 37.5
| Placebo | TTR & MTN | PAR | SG | Number of patients with 50% or more seizure reduction | 17 | 17 | 6^c^
| Topiramate 600 | TTR & MTN | PAR | SG | Number of patients with 50% or more seizure reduction | 12 | 12 | 8^c^
| Topiramate 800 | TTR & MTN | PAR | SG | Number of patients with 50% or more seizure reduction | 17 | 17 | 8^c^
| Topiramate 1000 | TTR & MTN | PAR | SG | Number of patients with 50% or more seizure reduction | 11 | 11 | 6^c^
| Placebo | TTR & MTN | PAR | SG | Median % reduction from baseline in seizure frequency | 17 | 17 | 40.3
| Topiramate 600 | TTR & MTN | PAR | SG | Median % reduction from baseline in seizure frequency | 12 | 12 | 65.5
| Topiramate 800 | TTR & MTN | PAR | SG | Median % reduction from baseline in seizure frequency | 17 | 17 | 44.4
| Topiramate 1000 | TTR & MTN | PAR | SG | Median % reduction from baseline in seizure frequency | 11 | 11 | 78
Sharief (1996) | Placebo | TTR & MTN | PAR | PAR | Number of patients with 50% or more seizure reduction | 24 | 24 | 2^c^
| Topiramate 400 | TTR & MTN | PAR | PAR | Number of patients with 50% or more seizure reduction | 23 | 23 | 8^c^
| Placebo | TTR & MTN | PAR | PAR | Number of patients with 75% or more seizure reduction | 24 | 24 | 1^c^
| Topiramate 400 | TTR & MTN | PAR | PAR | Number of patients with 75% or more seizure reduction | 23 | 23 | 5^c^
| Placebo | TTR & MTN | PAR | PAR | Number of patients seizure free | 24 | 24 | 0
| Topiramate 400 | TTR & MTN | PAR | PAR | Number of patients seizure free | 23 | 23 | 2
| Placebo | TTR & MTN | PAR | PAR | Median % reduction from baseline in seizure frequency | 24 | 24 | 1.1
| Topiramate 400 | TTR & MTN | PAR | PAR | Median % reduction from baseline in seizure frequency | 23 | 23 | 40.7
| Placebo | TTR & MTN | PAR | SG | Number of patients with 50% or more seizure reduction | 8 | 8 | 3
| Topiramate 400 | TTR & MTN | PAR | SG | Number of patients with 50% or more seizure reduction | 14 | 14 | 10
| Placebo | TTR & MTN | PAR | SG | Number of patients with a change in seizure type | 8 | 8 | 5^c^
| Topiramate 400 | TTR & MTN | PAR | SG | Number of patients with a change in seizure type | 14 | 14 | 0
| Placebo | TTR & MTN | PAR | SG | Number of patients seizure free | 8 | 8 | 2
| Topiramate 400 | TTR & MTN | PAR | SG | Number of patients seizure free | 14 | 14 | 6
| Placebo | TTR & MTN | PAR | SG | Median % reduction from baseline in seizure frequency | 8 | 8 | 8.7
| Topiramate 400 | TTR & MTN | PAR | SG | Median % reduction from baseline in seizure frequency | 14 | 14 | 83.9
Tassinari (1996) | Placebo | TTR & MTN | PAR | PAR | Number of patients with 50% or more seizure reduction | 30 | 30 | 3
| Topiramate 600 | TTR & MTN | PAR | PAR | Number of patients with 50% or more seizure reduction | 30 | 30 | 14
| Placebo | TTR & MTN | PAR | PAR | Number of patients with 75% or more seizure reduction | 30 | 30 | 1
| Topiramate 600 | TTR & MTN | PAR | PAR | Number of patients with 75% or more seizure reduction | 30 | 30 | 7
| Placebo | TTR & MTN | PAR | PAR | Number of patients seizure free | 30 | 30 | 0
| Topiramate 600 | TTR & MTN | PAR | PAR | Number of patients seizure free | 30 | 30 | 0
| Placebo | TTR & MTN | PAR | PAR | Median monthly seizure frequency | 30 | 30 | 24.5 Range 1.9 to 1205.7
| Topiramate 600 | TTR & MTN | PAR | PAR | Median monthly seizure frequency | 30 | 30 | 8.8 Range 1 to 178.2
| Placebo | TTR & MTN | PAR | PAR | Median % reduction from baseline in seizure frequency | 30 | 30 | -12.2
| Topiramate 600 | TTR & MTN | PAR | PAR | Median % reduction from baseline in seizure frequency | 30 | 30 | 46.6
Willmore (1996) | Placebo | TTR & MTN | PAR | CPS | Number of patients with 25% or more seizure reduction | 63 | 70 | 26
| Valproate 90 mg/kg | TTR & MTN | PAR | CPS | Number of patients with 25% or more seizure reduction | 74 | 77 | 53
| Placebo | TTR & MTN | PAR | CPS | Number of patients with 50% or more seizure reduction | 63 | 70 | 15
| Valproate 90 mg/kg | TTR & MTN | PAR | CPS | Number of patients with 50% or more seizure reduction | 74 | 77 | 34
| Placebo | TTR & MTN | PAR | CPS | Number of patients with 75% or more seizure reduction | 63 | 70 | 8
| Valproate 90 mg/kg | TTR & MTN | PAR | CPS | Number of patients with 75% or more seizure reduction | 74 | 77 | 19
| Placebo | TTR & MTN | PAR | CPS | Number of patients seizure free | 63 | 70 | 1
| Valproate 90 mg/kg | TTR & MTN | PAR | CPS | Number of patients seizure free | 74 | 77 | 6
| Placebo | TTR & MTN | PAR | CPS | Mean monthly seizure frequency | 63 | 70 | 26.9 SD 39.1
| Valproate 90 mg/kg | TTR & MTN | PAR | CPS | Mean monthly seizure frequency | 74 | 77 | 18.6 SD 39.0
| Placebo | TTR & MTN | PAR | CPS | Mean difference from baseline in seizure frequency | 63 | 70 | 2.5
| Valproate 90 mg/kg | TTR & MTN | PAR | CPS | Mean difference from baseline in seizure frequency | 74 | 77 | 8.5
| Placebo | TTR & MTN | PAR | CPS | Median monthly seizure frequency | 63 | 70 | 11.7
| Valproate 90 mg/kg | TTR & MTN | PAR | CPS | Median monthly seizure frequency | 74 | 77 | 8.7
| Placebo | TTR & MTN | PAR | CPS | Median difference from baseline in seizure frequency | 63 | 70 | 2.5
| Valproate 90 mg/kg | TTR & MTN | PAR | CPS | Median difference from baseline in seizure frequency | 74 | 77 | 7.9
Anhut (1994) | Placebo | TTR & MTN | PAR | CPS | Median monthly seizure frequency | 98 | 98 | 7.4
| Gabapentin 900 | TTR & MTN | PAR | CPS | Median monthly seizure frequency | 99 | 99 | 5.7
| Gabapentin 1200 | TTR & MTN | PAR | CPS | Median monthly seizure frequency | 48 | 48 | 4.4
| Placebo | TTR & MTN | PAR | PAR | Number of patients with 50% or more seizure reduction | 99 | 109 | 10^c^
| Gabapentin 900 | TTR & MTN | PAR | PAR | Number of patients with 50% or more seizure reduction | 96 | 111 | 22^c^
| Gabapentin 1200 | TTR & MTN | PAR | PAR | Number of patients with 50% or more seizure reduction | 50 | 52 | 14^c^
| Placebo | TTR & MTN | PAR | PAR | Number of patients with 50% or more seizure increase | 99 | 109 | 14^c^
| Gabapentin 900 | TTR & MTN | PAR | PAR | Number of patients with 50% or more seizure increase | 96 | 111 | 5^c^
| Gabapentin 1200 | TTR & MTN | PAR | PAR | Number of patients with 50% or more seizure increase | 50 | 52 | 4^c^
| Placebo | TTR & MTN | PAR | PAR | Number of patients with any seizure reduction | 99 | 109 | 51^c^
| Gabapentin 900 | TTR & MTN | PAR | PAR | Number of patients with any seizure reduction | 96 | 111 | 77^c^
| Gabapentin 1200 | TTR & MTN | PAR | PAR | Number of patients with any seizure reduction | 50 | 52 | 38^c^
| Placebo | TTR & MTN | PAR | PAR | Number of patients with any seizure increase | 99 | 109 | 48^c^
| Gabapentin 900 | TTR & MTN | PAR | PAR | Number of patients with any seizure increase | 96 | 111 | 19^c^
| Gabapentin 1200 | TTR & MTN | PAR | PAR | Number of patients with any seizure increase | 50 | 52 | 12^c^
| Placebo | TTR & MTN | PAR | PAR | Mean adjusted risk ratio | 99 | 109 | -0.025 SEM .022
| Gabapentin 900 | TTR & MTN | PAR | PAR | Mean adjusted risk ratio | 96 | 111 | -0.136 SEM .026
| Gabapentin 1200 | TTR & MTN | PAR | PAR | Mean adjusted risk ratio | 50 | 52 | -0.157 SEM .047
| Placebo | TTR & MTN | PAR | PAR | Median monthly seizure frequency | 109 | 109 | 8.1
| Gabapentin 900 | TTR & MTN | PAR | PAR | Median monthly seizure frequency | 111 | 111 | 7.7
| Gabapentin 1200 | TTR & MTN | PAR | PAR | Median monthly seizure frequency | 52 | 52 | 6.8
| Placebo | TTR & MTN | PAR | PAR | Median % reduction from baseline in seizure frequency | 99 | 109 | 0.3 SD 53.8
| Gabapentin 900 | TTR & MTN | PAR | PAR | Median % reduction from baseline in seizure frequency | 96 | 111 | 21.8 SD 53.7
| Gabapentin 1200 | TTR & MTN | PAR | PAR | Median % reduction from baseline in seizure frequency | 50 | 52 | 17.8 SD 62.1
| Placebo | TTR & MTN | PAR | SG | Median monthly seizure frequency | 58 | 58 | 1
| Gabapentin 900 | TTR & MTN | PAR | SG | Median monthly seizure frequency | 61 | 61 | 1
| Gabapentin 1200 | TTR & MTN | PAR | SG | Median monthly seizure frequency | 31 | 31 | 0.6
| Placebo | TTR & MTN | PAR | SPS | Median monthly seizure frequency | 40 | 40 | 3.8
| Gabapentin 900 | TTR & MTN | PAR | SPS | Median monthly seizure frequency | 42 | 42 | 6.5
| Gabapentin 1200 | TTR & MTN | PAR | SPS | Median monthly seizure frequency | 23 | 23 | 5.5
Messenheimer (1994) | Placebo | TTR & MTN | PAR | PAR | Median % reduction from baseline in seizure frequency | 44 | 44 | 4
| Lamotrigine 400 | TTR & MTN | PAR | PAR | Median % reduction from baseline in seizure frequency | 44 | 44 | 29
Bourgeois (1993) | Placebo | TTR & MTN | PAR | PAR | Mean rank of seizure frequency | 34 | 34 | 35.4
| Felbamate 3600 | TTR & MTN | PAR | PAR | Mean rank of seizure frequency | 30 | 30 | 25.8
FSG (1993) | Placebo | TTR & MTN | GEN | ATO | Number of patients seizure free | 22 | 22 | 0
| Placebo | MTN | GEN | ATO | Number of patients seizure free | 22 | 22 | 0
| Felbamate 3600 | TTR & MTN | GEN | ATO | Number of patients seizure free | 28 | 28 | 3
| Felbamate 3600 | MTN | GEN | ATO | Number of patients seizure free | 28 | 28 | 5
| Placebo | MTN | GEN | ATO | Mean % reduction from baseline in seizure frequency | 22 | 22 | 7 Range -57 to 88
| Placebo | TTR & MTN | GEN | ATO | Mean % reduction from baseline in seizure frequency | 22 | 22 | 9 Range -64 to 85
| Felbamate 3600 | TTR & MTN | GEN | ATO | Mean % reduction from baseline in seizure frequency | 28 | 28 | 34 Range -156 to 100
| Felbamate 3600 | MTN | GEN | ATO | Mean % reduction from baseline in seizure frequency | 28 | 28 | 44 Range -145 to 100
| Placebo | TTR & MTN | GEN | GTC | Number of patients seizure free | 13 | 13 | 1
| Placebo | MTN | GEN | GTC | Number of patients seizure free | 13 | 13 | 1
| Felbamate 3600 | TTR & MTN | GEN | GTC | Number of patients seizure free | 16 | 16 | 2
| Felbamate 3600 | MTN | GEN | GTC | Number of patients seizure free | 16 | 16 | 7
| Placebo | MTN | GEN | GTC | Mean % reduction from baseline in seizure frequency | 13 | 13 | -12 Range -293 to 100
| Placebo | TTR & MTN | GEN | GTC | Mean % reduction from baseline in seizure frequency | 13 | 13 | -11 Range -203 to 100
| Felbamate 3600 | TTR & MTN | GEN | GTC | Mean % reduction from baseline in seizure frequency | 16 | 16 | 28 Range -172 to 100
| Felbamate 3600 | MTN | GEN | GTC | Mean % reduction from baseline in seizure frequency | 16 | 16 | 40 Range -206 to 100
| Placebo | TTR & MTN | ALL | GTC, TON, ATO, MYO, CPS | Number of patients seizure free | 36 | 36 | 0
| Placebo | MTN | ALL | GTC, TON, ATO, MYO, CPS | Number of patients seizure free | 36 | 36 | 1
| Felbamate 3600 | TTR & MTN | ALL | GTC, TON, ATO, MYO, CPS | Number of patients seizure free | 37 | 37 | 0
| Felbamate 3600 | MTN | ALL | GTC, TON, ATO, MYO, CPS | Number of patients seizure free | 37 | 37 | 4
| Placebo | MTN | ALL | GTC, TON, ATO, MYO, CPS | Mean % reduction from baseline in seizure frequency | 36 | 36 | -5 Range -231 to 100
| Placebo | TTR & MTN | ALL | GTC, TON, ATO, MYO, CPS | Mean % reduction from baseline in seizure frequency | 36 | 36 | 4 Range -176 to 74
| Felbamate 3600 | TTR & MTN | ALL | GTC, TON, ATO, MYO, CPS | Mean % reduction from baseline in seizure frequency | 37 | 37 | 19 Range -437 to 99
| Felbamate 3600 | MTN | ALL | GTC, TON, ATO, MYO, CPS | Mean % reduction from baseline in seizure frequency | 37 | 37 | 26 Range -521 to 100
| Placebo | TTR & MTN | GEN | ABS | Number of patients with 25% or more seizure reduction | 30 | 30 | 12a,^c^
| Felbamate 3600 | TTR & MTN | GEN | ABS | Number of patients with 25% or more seizure reduction | 32 | 32 | 22a,^c^
| Placebo | TTR & MTN | GEN | ABS | Number of patients with 50% or more seizure reduction | 30 | 30 | 9a,^c^
| Felbamate 3600 | TTR & MTN | GEN | ABS | Number of patients with 50% or more seizure reduction | 32 | 32 | 17a,^c^
| Placebo | TTR & MTN | GEN | ABS | Number of patients with 75% or more seizure reduction | 30 | 30 | 4a,^c^
| Felbamate 3600 | TTR & MTN | GEN | ABS | Number of patients with 75% or more seizure reduction | 32 | 32 | 12a,^c^
| Placebo | TTR & MTN | GEN | ABS | Number of patients seizure free | 30 | 30 | 2a,^c^
| Felbamate 3600 | TTR & MTN | GEN | ABS | Number of patients seizure free | 32 | 32 | 2a,^c^
| Placebo | TTR & MTN | GEN | ATO | Number of patients with 25% or more seizure reduction | 22 | 22 | 6a,^c^
| Felbamate 3600 | TTR & MTN | GEN | ATO | Number of patients with 25% or more seizure reduction | 27 | 27 | 19a,^c^
| Placebo | TTR & MTN | GEN | ATO | Number of patients with 50% or more seizure reduction | 22 | 22 | 2a,^c^
| Felbamate 3600 | TTR & MTN | GEN | ATO | Number of patients with 50% or more seizure reduction | 27 | 27 | 16a,^c^
| Placebo | TTR & MTN | GEN | ATO | Number of patients with 75% or more seizure reduction | 22 | 22 | 1a,^c^
| Felbamate 3600 | TTR & MTN | GEN | ATO | Number of patients with 75% or more seizure reduction | 27 | 27 | 9a,^c^
| Placebo | TTR & MTN | GEN | ATO | Number of patients seizure free | 22 | 22 | 0a
| Felbamate 3600 | TTR & MTN | GEN | ATO | Number of patients seizure free | 27 | 27 | 4a,^c^
| Placebo | TTR & MTN | GEN | ATO | Mean % reduction from baseline in seizure frequency | 22 | 22 | 9a
| Felbamate 3600 | TTR & MTN | GEN | ATO | Mean % reduction from baseline in seizure frequency | 27 | 27 | 34a
| Placebo | TTR & MTN | GEN | ATO, ABS | Number of patients with 25% or more seizure reduction | 35 | 35 | 7a,^c^
| Felbamate 3600 | TTR & MTN | GEN | ATO, ABS | Number of patients with 25% or more seizure reduction | 36 | 36 | 23a,^c^
| Placebo | TTR & MTN | GEN | ATO, ABS | Number of patients with 50% or more seizure reduction | 35 | 35 | 4a,^c^
| Felbamate 3600 | TTR & MTN | GEN | ATO, ABS | Number of patients with 50% or more seizure reduction | 36 | 36 | 18a,^c^
| Placebo | TTR & MTN | GEN | ATO, ABS | Number of patients with 75% or more seizure reduction | 35 | 35 | 0a
| Felbamate 3600 | TTR & MTN | GEN | ATO, ABS | Number of patients with 75% or more seizure reduction | 36 | 36 | 9a,^c^
| Placebo | TTR & MTN | GEN | ATO, ABS | Number of patients seizure free | 35 | 35 | 0a
| Felbamate 3600 | TTR & MTN | GEN | ATO, ABS | Number of patients seizure free | 36 | 36 | 3a,^c^
Matsuo (1993) | Placebo | TTR & some MTN | PAR | PAR | Number of patients with 25% or more seizure reduction | 70 | 73 | 21^c^
| Placebo | Last 12 weeks of MTN | PAR | PAR | Number of patients with 25% or more seizure reduction | 67 | 73 | 25^c^
| Lamotrigine 300 | TTR & some MTN | PAR | PAR | Number of patients with 25% or more seizure reduction | 67 | 71 | 30^c^
| Lamotrigine 300 | Last 12 weeks of MTN | PAR | PAR | Number of patients with 25% or more seizure reduction | 65 | 71 | 30^c^
| Lamotrigine 500 | Last 12 weeks of MTN | PAR | PAR | Number of patients with 25% or more seizure reduction | 59 | 72 | 34^c^
| Lamotrigine 500 | TTR & some MTN | PAR | PAR | Number of patients with 25% or more seizure reduction | 63 | 72 | 39^c^
| Placebo | Last 12 weeks of MTN | PAR | PAR | Number of patients with 25% or more seizure increase | 67 | 73 | 12^c^
| Placebo | TTR & some MTN | PAR | PAR | Number of patients with 25% or more seizure increase | 70 | 73 | 13^c^
| Lamotrigine 300 | Last 12 weeks of MTN | PAR | PAR | Number of patients with 25% or more seizure increase | 65 | 71 | 15^c^
| Lamotrigine 300 | TTR & some MTN | PAR | PAR | Number of patients with 25% or more seizure increase | 67 | 71 | 18^c^
| Lamotrigine 500 | Last 12 weeks of MTN | PAR | PAR | Number of patients with 25% or more seizure increase | 59 | 72 | 6^c^
| Lamotrigine 500 | TTR & some MTN | PAR | PAR | Number of patients with 25% or more seizure increase | 63 | 72 | 7^c^
| Placebo | TTR & some MTN | PAR | PAR | Number of patients with 50% or more seizure reduction | 70 | 73 | 10^c^
| Placebo | Last 12 weeks of MTN | PAR | PAR | Number of patients with 50% or more seizure reduction | 67 | 73 | 12^c^
| Lamotrigine 300 | TTR & some MTN | PAR | PAR | Number of patients with 50% or more seizure reduction | 67 | 71 | 12^c^
| Lamotrigine 300 | Last 12 weeks of MTN | PAR | PAR | Number of patients with 50% or more seizure reduction | 65 | 71 | 13^c^
| Lamotrigine 500 | Last 12 weeks of MTN | PAR | PAR | Number of patients with 50% or more seizure reduction | 59 | 72 | 20^c^
| Lamotrigine 500 | TTR & some MTN | PAR | PAR | Number of patients with 50% or more seizure reduction | 63 | 72 | 21^c^
| Placebo | Last 12 weeks of MTN | PAR | PAR | Number of patients with 50% or more seizure increase | 67 | 73 | 4^c^
| Placebo | TTR & some MTN | PAR | PAR | Number of patients with 50% or more seizure increase | 70 | 73 | 9^c^
| Lamotrigine 300 | Last 12 weeks of MTN | PAR | PAR | Number of patients with 50% or more seizure increase | 65 | 71 | 10^c^
| Lamotrigine 300 | TTR & some MTN | PAR | PAR | Number of patients with 50% or more seizure increase | 67 | 71 | 12^c^
| Lamotrigine 500 | TTR & some MTN | PAR | PAR | Number of patients with 50% or more seizure increase | 63 | 72 | 4^c^
| Lamotrigine 500 | Last 12 weeks of MTN | PAR | PAR | Number of patients with 50% or more seizure increase | 59 | 72 | 4^c^
| Placebo | TTR & MTN | PAR | PAR | Number of patients seizure free | 67 | 73 | 1
| Lamotrigine 300 | TTR & MTN | PAR | PAR | Number of patients seizure free | 65 | 71 | 7
| Lamotrigine 500 | TTR & MTN | PAR | PAR | Number of patients seizure free | 59 | 72 | 5
| Placebo | TTR & MTN | PAR | PAR | Median % reduction from baseline in seizure frequency | 67 | 73 | 8
| Placebo | TTR & some MTN | PAR | PAR | Median % reduction from baseline in seizure frequency | 70 | 73 | 10^c^
| Placebo | Last 12 weeks of MTN | PAR | PAR | Median % reduction from baseline in seizure frequency | 67 | 73 | 14^c^
| Lamotrigine 300 | TTR & some MTN | PAR | PAR | Median % reduction from baseline in seizure frequency | 67 | 71 | 19^c^
| Lamotrigine 300 | TTR & MTN | PAR | PAR | Median % reduction from baseline in seizure frequency | 65 | 71 | 20
| Lamotrigine 300 | Last 12 weeks of MTN | PAR | PAR | Median % reduction from baseline in seizure frequency | 65 | 71 | 23^c^
| Lamotrigine 500 | TTR & some MTN | PAR | PAR | Median % reduction from baseline in seizure frequency | 63 | 72 | 31^c^
| Lamotrigine 500 | Last 12 weeks of MTN | PAR | PAR | Median % reduction from baseline in seizure frequency | 59 | 72 | 32^c^
| Lamotrigine 500 | TTR & MTN | PAR | PAR | Median % reduction from baseline in seizure frequency | 59 | 72 | 36
McLean (1993) | Placebo | TTR & MTN | PAR | CPS | Mean risk ratio | 85 | NR | -.01^c^
| Gabapentin 600 | TTR & MTN | PAR | CPS | Mean risk ratio | 47 | NR | -.14^c^
| Gabapentin 1200 | TTR & MTN | PAR | CPS | Mean risk ratio | 80 | NR | -.15^c^
| Gabapentin 1800 | TTR & MTN | PAR | CPS | Mean risk ratio | 51 | NR | -.28^c^
| Placebo | TTR & MTN | PAR | PAR | Number of patients with 25% or more seizure reduction | 95 | 98 | 24^c^
| Gabapentin 600 | TTR & MTN | PAR | PAR | Number of patients with 25% or more seizure reduction | 49 | 53 | 23^c^
| Gabapentin 1200 | TTR & MTN | PAR | PAR | Number of patients with 25% or more seizure reduction | 91 | 101 | 37^c^
| Gabapentin 1800 | TTR & MTN | PAR | PAR | Number of patients with 25% or more seizure reduction | 53 | 54 | 32^c^
| Placebo | TTR & MTN | PAR | PAR | Number of patients with 50% or more seizure reduction | 95 | 98 | 8^c^
| Gabapentin 600 | TTR & MTN | PAR | PAR | Number of patients with 50% or more seizure reduction | 49 | 53 | 9^c^
| Gabapentin 1200 | TTR & MTN | PAR | PAR | Number of patients with 50% or more seizure reduction | 91 | 101 | 16^c^
| Gabapentin 1800 | TTR & MTN | PAR | PAR | Number of patients with 50% or more seizure reduction | 53 | 54 | 14^c^
| Placebo | TTR & MTN | PAR | PAR | Number of patients with 75% or more seizure reduction | 95 | 98 | 1^c^
| Gabapentin 600 | TTR & MTN | PAR | PAR | Number of patients with 75% or more seizure reduction | 49 | 53 | 1^c^
| Gabapentin 1200 | TTR & MTN | PAR | PAR | Number of patients with 75% or more seizure reduction | 91 | 101 | 6^c^
| Gabapentin 1800 | TTR & MTN | PAR | PAR | Number of patients with 75% or more seizure reduction | 53 | 54 | 3^c^
| Placebo | TTR & MTN | PAR | PAR | Number of patients with any seizure reduction | 95 | 98 | 57^c^
| Gabapentin 600 | TTR & MTN | PAR | PAR | Number of patients with any seizure reduction | 49 | 53 | 36^c^
| Gabapentin 1200 | TTR & MTN | PAR | PAR | Number of patients with any seizure reduction | 91 | 101 | 61^c^
| Gabapentin 1800 | TTR & MTN | PAR | PAR | Number of patients with any seizure reduction | 53 | 54 | 43^c^
| Placebo | TTR & MTN | PAR | PAR | Number of patients with any seizure increase | 95 | 98 | 38^c^
| Gabapentin 600 | TTR & MTN | PAR | PAR | Number of patients with any seizure increase | 49 | 53 | 13^c^
| Gabapentin 1200 | TTR & MTN | PAR | PAR | Number of patients with any seizure increase | 91 | 101 | 30^c^
| Gabapentin 1800 | TTR & MTN | PAR | PAR | Number of patients with any seizure increase | 53 | 54 | 10^c^
| Placebo | TTR & MTN | PAR | PAR | Mean adjusted risk ratio | 95 | 98 | -.025 SEM .022
| Gabapentin 600 | TTR & MTN | PAR | PAR | Mean adjusted risk ratio | 49 | 53 | -.151 SEM .037
| Gabapentin 1200 | TTR & MTN | PAR | PAR | Mean adjusted risk ratio | 91 | 101 | -.118 SEM.027
| Gabapentin 1800 | TTR & MTN | PAR | PAR | Mean adjusted risk ratio | 53 | 54 | -.233 SEM .034
| Placebo | TTR & MTN | PAR | PAR | Median % reduction from baseline in seizure frequency | 95 | 98 | 5.9
| Gabapentin 600 | TTR & MTN | PAR | PAR | Median % reduction from baseline in seizure frequency | 49 | 53 | 24.3
| Gabapentin 1200 | TTR & MTN | PAR | PAR | Median % reduction from baseline in seizure frequency | 91 | 101 | 20
| Gabapentin 1800 | TTR & MTN | PAR | PAR | Median % reduction from baseline in seizure frequency | 53 | 54 | 31.9
| Placebo | TTR & MTN | PAR | PAR | Median risk ratio | 95 | 98 | -.03
| Gabapentin 600 | TTR & MTN | PAR | PAR | Median risk ratio | 49 | 53 | -.138
| Gabapentin 1200 | TTR & MTN | PAR | PAR | Median risk ratio | 91 | 101 | -.111
| Gabapentin 1800 | TTR & MTN | PAR | PAR | Median risk ratio | 53 | 54 | -.19
| Placebo | TTR & MTN | PAR | SG | Mean risk ratio | 35 | NR | .12^c^
| Gabapentin 600 | TTR & MTN | PAR | SG | Mean risk ratio | 20 | NR | -.07^c^
| Gabapentin 1200 | TTR & MTN | PAR | SG | Mean risk ratio | 31 | NR | -.15^c^
| Gabapentin 1800 | TTR & MTN | PAR | SG | Mean risk ratio | 26 | NR | -.37^c^
| Placebo | TTR & MTN | PAR | SPS | Mean risk ratio | 47 | NR | .025^c^
| Gabapentin 600 | TTR & MTN | PAR | SPS | Mean risk ratio | 23 | NR | .025^c^
| Gabapentin 1200 | TTR & MTN | PAR | SPS | Mean risk ratio | 44 | NR | -.05^c^
| Gabapentin 1800 | TTR & MTN | PAR | SPS | Mean risk ratio | 23 | NR | -.11^c^
Schmidt (1993) | Placebo | MTN | ALL | ALL | Number of patients with 50% or more seizure reduction | 64 | 68 | 6
| Zonisamide 20 mg/kg | MTN | ALL | ALL | Number of patients with 50% or more seizure reduction | 67 | 71 | 20
| Placebo | MTN | ALL | ALL | Median % reduction from baseline in seizure frequency | 64 | 68 | -3
| Zonisamide 20 mg/kg | MTN | ALL | ALL | Median % reduction from baseline in seizure frequency | 67 | 71 | 22.5
| Placebo | MTN | PAR | CPS | Number of patients with 50% or more seizure reduction | 63 | 68 | 8
| Zonisamide 20 mg/kg | MTN | PAR | CPS | Number of patients with 50% or more seizure reduction | 66 | 71 | 20
| Placebo | MTN | PAR | CPS | Median % reduction from baseline in seizure frequency | 63 | 68 | -3.9
| Placebo | TTR | PAR | CPS | Median % reduction from baseline in seizure frequency | 63 | 68 | -3.2
| Placebo | First month of MTN | PAR | CPS | Median % reduction from baseline in seizure frequency | 63 | 68 | 8.2
| Zonisamide 20 mg/kg | First month of MTN | PAR | CPS | Median % reduction from baseline in seizure frequency | 66 | 71 | 26.7
| Zonisamide 20 mg/kg | MTN | PAR | CPS | Median % reduction from baseline in seizure frequency | 66 | 71 | 27.7
| Zonisamide 20 mg/kg | TTR | PAR | CPS | Median % reduction from baseline in seizure frequency | 66 | 71 | 31
| Placebo | MTN | GEN | GEN | Number of patients with 50% or more seizure reduction | 7 | NR | 4
| Zonisamide 20 mg/kg | MTN | GEN | GEN | Number of patients with 50% or more seizure reduction | 8 | NR | 2
| Placebo | MTN | GEN | GEN | Median % reduction from baseline in seizure frequency | 7 | NR | 61.5
| Zonisamide 20 mg/kg | MTN | GEN | GEN | Median % reduction from baseline in seizure frequency | 8 | NR | 23.2
| Placebo | MTN | PAR | PAR | Number of patients with 50% or more seizure reduction | 63 | 68 | 8
| Zonisamide 20 mg/kg | MTN | PAR | PAR | Number of patients with 50% or more seizure reduction | 66 | 71 | 20
| Placebo | MTN | PAR | PAR | Number of patients with 75% or more seizure reduction | 63 | 68 | 4
| Zonisamide 20 mg/kg | MTN | PAR | PAR | Number of patients with 75% or more seizure reduction | 66 | 71 | 10
| Placebo | MTN | PAR | PAR | Number of patients with any seizure reduction | 63 | 68 | 28
| Zonisamide 20 mg/kg | MTN | PAR | PAR | Number of patients with any seizure reduction | 66 | 71 | 43
| Placebo | MTN | PAR | PAR | Number of patients seizure free | 63 | 68 | 1
| Zonisamide 20 mg/kg | MTN | PAR | PAR | Number of patients seizure free | 66 | 71 | 4
| Placebo | MTN | PAR | PAR | Median % reduction from baseline in seizure frequency | 63 | 68 | -3.9
| Zonisamide 20 mg/kg | MTN | PAR | PAR | Median % reduction from baseline in seizure frequency | 66 | 71 | 26.9
| Placebo | MTN | PAR | SPS | Number of patients with 50% or more seizure reduction | 3 | NR | 1
| Zonisamide 20 mg/kg | MTN | PAR | SPS | Number of patients with 50% or more seizure reduction | 6 | NR | 4
| Placebo | MTN | PAR | SPS | Median % reduction from baseline in seizure frequency | 3 | NR | 48.1
| Zonisamide 20 mg/kg | MTN | PAR | SPS | Median % reduction from baseline in seizure frequency | 6 | NR | 72.6
Sivenius (1991) | Placebo | TTR & MTN | PAR | PAR | Number of patients with 25% or more seizure reduction | 18 | 18 | 6
| Gabapentin 900 | TTR & MTN | PAR | PAR | Number of patients with 25% or more seizure reduction | 16 | 16 | 6
| Placebo | TTR & MTN | PAR | PAR | Number of patients with 50% or more seizure reduction | 18 | 18 | 3
| Gabapentin 900 | TTR & MTN | PAR | PAR | Number of patients with 50% or more seizure reduction | 16 | 16 | 2
| Placebo | TTR & MTN | PAR | PAR | Number of patients with 75% or more seizure reduction | 18 | 18 | 0
| Gabapentin 900 | TTR & MTN | PAR | PAR | Number of patients with 75% or more seizure reduction | 16 | 16 | 0
| Placebo | TTR & MTN | PAR | PAR | Number of patients with any seizure reduction | 18 | 18 | 13
| Gabapentin 900 | TTR & MTN | PAR | PAR | Number of patients with any seizure reduction | 16 | 16 | 10
| Placebo | TTR & MTN | PAR | PAR | Number of patients with any seizure increase | 18 | 18 | 5
| Gabapentin 900 | TTR & MTN | PAR | PAR | Number of patients with any seizure increase | 16 | 16 | 6
| Placebo | TTR & MTN | PAR | PAR | Median monthly seizure frequency | 18 | 18 | 30
| Gabapentin 900 | TTR & MTN | PAR | PAR | Median monthly seizure frequency | 16 | 16 | 19.5
UKGSG (1990) | Placebo | TTR & MTN | PAR | PAR | Number of patients with 25% or more seizure reduction | 61 | 66 | 15^c^
| Gabapentin 1200 | TTR & MTN | PAR | PAR | Number of patients with 25% or more seizure reduction | 52 | 61 | 32^c^
| Placebo | TTR & MTN | PAR | PAR | Number of patients with 25% or more seizure increase | 61 | 66 | 11^c^
| Gabapentin 1200 | TTR & MTN | PAR | PAR | Number of patients with 25% or more seizure increase | 52 | 61 | 5^c^
| Placebo | TTR & MTN | PAR | PAR | Number of patients with 50% or more seizure reduction | 61 | 66 | 6^c^
| Gabapentin 1200 | TTR & MTN | PAR | PAR | Number of patients with 50% or more seizure reduction | 52 | 61 | 13^c^
| Placebo | TTR & MTN | PAR | PAR | Number of patients with 50% or more seizure increase | 61 | 66 | 5^c^
| Gabapentin 1200 | TTR & MTN | PAR | PAR | Number of patients with 50% or more seizure increase | 52 | 61 | 3^c^
| Placebo | TTR & MTN | PAR | PAR | Number of patients with 75% or more seizure reduction | 61 | 66 | 1^c^
| Gabapentin 1200 | TTR & MTN | PAR | PAR | Number of patients with 75% or more seizure reduction | 52 | 61 | 5^c^
| Placebo | TTR & MTN | PAR | PAR | Number of patients with 75 or more seizure increase | 61 | 66 | 3^c^
| Gabapentin 1200 | TTR & MTN | PAR | PAR | Number of patients with 75 or more seizure increase | 52 | 61 | 3^c^
| Placebo | TTR & MTN | PAR | PAR | Number of patients with any seizure reduction | 61 | 66 | 38^c^
| Gabapentin 1200 | TTR & MTN | PAR | PAR | Number of patients with any seizure reduction | 52 | 61 | 42^c^
| Placebo | TTR & MTN | PAR | PAR | Number of patients with any seizure increase | 61 | 66 | 23^c^
| Gabapentin 1200 | TTR & MTN | PAR | PAR | Number of patients with any seizure increase | 52 | 61 | 10^c^
| Placebo | TTR & MTN | PAR | PAR | Mean adjusted risk ratio | 61 | 66 | -0.06
| Gabapentin 1200 | TTR & MTN | PAR | PAR | Mean adjusted risk ratio | 52 | 61 | -0.192
| Placebo | TTR & MTN | PAR | PAR | Median % reduction from baseline in seizure frequency | 61 | 66 | 12.5
| Gabapentin 1200 | TTR & MTN | PAR | PAR | Median % reduction from baseline in seizure frequency | 52 | 61 | 29.2
Jawad (1989) | Placebo | TTR & MTN | PAR | PAR | Mean monthly seizure frequency | 11 | 11 | 12.2
| Lamotrigine 400 | TTR & MTN | PAR | PAR | Mean monthly seizure frequency | 10 | 10 | 7.2
| Placebo | TTR & MTN | PAR | PAR | Median monthly seizure frequency | 11 | 11 | 9
| Lamotrigine 400 | TTR & MTN | PAR | PAR | Median monthly seizure frequency | 10 | 10 | 6.8

a The following abbreviations for seizure types have been used in Evidence Table 59

ABS absence seizures

ALL all seizures

ATO atonic seizures

CPS complex partial seizures

GEN generalized seizures

GTC generalized tonic-clonic seizures

MYO myoclonic seizures

OTH other generalized seizures

PAR partial seizures

SG secondarily generalized seizures

SPS simple partial seizures

TON tonic seizures

mg/kg Milligrams per kilogram

MTN Maintenance phase of study

TTR Titration phase of study

SEM Standard error of the mean

b In the outcome column, a positive value for either median, % reduction from baseline, or median difference from baseline represents a beneficial reduction in seizures. This conforms to the convention in the epilepsy literature.

c Calculated by ECRI based on published information

Evidence Table 60. Adverse effects in studies of polytherapy

Reference | Drug And Dose (mg/day) | Adverse Effect | Severity of Adverse Effect | Patients With Effect/Patients in Group | Percentage
Faught (2001) | Zonisamide 400 | Abdominal pain | Withdrawal | 1/118 | 1%
| Zoni samide 400 | Agitation | Withdrawal | 2/118 | 2%
| Placebo | Anorexia | | 8/85 | 9%
| Zonisamide 400 | Anorexia | Withdrawal | 1/118 | 1%
| Zonisamide 400 | Anorexia | | 17/118 | 14%
| Placebo | | | 6/85 | 7%
| Zonisamide 400 | Ataxia | Severe | 1/118 | 1%
| Zonisamide 400 | Ataxia | | 12/118 | 10%
| Zonisamide 400 | Behavioral changes | Severe | 1/118 | 1%
| Zonisamide 400 | Blurred vision | Severe | 1/118 | 1%
| Placebo | Confusion | Withdrawal | 1/85 | 1%
| Zonisamide 400 | Confusion | Withdrawal | 3/118 | 3%
| Placebo | Depression | Withdrawal | 2/85 | 2%
| Zonisamide 400 | Depression | Withdrawal | 1/118 | 1%
| Placebo | Dizziness | Withdrawal | 1/85 | 1%
| | Dizziness | | 12/85 | 14%
| Zonisamide 400 | Dizziness | Severe | 1/118 | 1%
| Zonisamide 400 | Dizziness | | 16/118 | 14%
| Zonisamide 400 | Dry mouth | Severe | 1/118 | 1%
| Placebo | Fatigue | | 12/85 | 14%
| Zonisamide 400 | Fatigue | Withdrawal | 1/118 | 1%
| Zonisamide 400 | Fatigue | | 11/118 | 9%
| Placebo | Gall bladder disorder | Severe | 1/85 | 1%
| Zonisamide 400 | Glossitis | Severe | 1/118 | 1%
| Placebo | Headache | | 11/85 | 13%
| Zonisamide 400 | Headache | Withdrawal | 2/118 | 2%
| Zonisamide 400 | Headache | | 11/118 | 9%
| Placebo | Increase in seizures | Severe | 1/85 | 1%
| Zonisamide 400 | Memory | Withdrawal | 1/118 | 1%
| Zonisamide 400 | Mental slowing | Withdrawal | 1/118 | 1%
| Placebo | Migraine | Withdrawal | 1/85 | 1%
| Zonisamide 400 | Muscle spasm | Severe | 1/118 | 1%
| Placebo | Nausea | Withdrawal | 1/85 | 1%
| Placebo | Nausea and/or vomiting | | 15/85 | 18%
| Zonisamide 400 | Nausea and/or vomiting | Severe | 1/118 | 1%
| Zonisamide 400 | Nausea and/or vomiting | | 14/118 | 12%
| Zonisamide 400 | Paranoia | Severe | 2/118 | 2%
| Zonisamide 400 | Paranoid behavior | Withdrawal | 1/118 | 1%
| Placebo | Phenytoin toxicity | Severe | 1/85 | 1%
| Zonisamide 400 | Pneumonia | Severe | 1/118 | 1%
| Placebo | Psychomotor slowing | Withdrawal | 1/85 | 1%
| Zonisamide 400 | Psychosis | Withdrawal | 1/118 | 1%
| Placebo | Rash | Withdrawal | 1/85 | 1%
| Placebo | Rash | Severe | 1/85 | 1%
| Placebo | Rhinitis | | 13/85 | 15%
| Zonisamide 400 | Rhinitis | | 17/118 | 14%
| Zonisamide 400 | Schizophreniform behavior | Withdrawal | 1/118 | 1%
| Placebo | Somnolence | | 13/85 | 15%
| Zonisamide 400 | Somnolence | | 18/118 | 15%
| Zonisamide 400 | Status epilepticus | Severe | 1/118 | 1%
| Zonisamide 400 | Thyroid disorder | Severe | 1/118 | 1%
| Placebo | Tremor | Withdrawal | 1/85 | 1%
| Placebo | Uterine disorders | Severe | 1/85 | 1%
| Zonisamide 400 | Uterine disorders | Severe | 1/118 | 1%
| Zonisamide 400 | Weight loss | Withdrawal | 1/118 | 1%
Ben-Menachem (2000) | Placebo | Accidental injury | | 10/105 | 9.5%
| Levetiracetam 3000 | Accidental injury | | 4/181 | 2.2%
| Placebo | Any | Severe | 1/105 | 1%
| Placebo | Any | Any | 56/105 | 53%
| Levetiracetam 3000 | Any | Severe | 4/181 | 2%
| Levetiracetam 3000 | Any | Any | 100/181 | 55%
| Placebo | Asthenia | | 7/105 | 6.7%
| Levetiracetam 3000 | Asthenia | | 25/181 | 13.8%
| Placebo | Confusion | Severe | 1/105 | 1%
| Levetiracetam 3000 | Convulsions | Severe | 2/181 | 1%
| Placebo | Headache | | 11/105 | 10.5%
| Levetiracetam 3000 | Headache | | 6/181 | 3.3%
| Placebo | Infection | | 4/105 | 3.8%
| Levetiracetam 3000 | | | 3/181 | 7.2%
| Levetiracetam 3000 | Rash | Severe | 1/181 | 1%
| Placebo | Somnolence | | 4/105 | 3.8%
| Levetiracetam 3000 | Somnolence | | 11/181 | 6.1%
| Levetiracetam 3000 | Spontaneous abortion | Severe | 1/181 | 1%
Betts (2000) | Placebo | Accidental injury | | 6/39 | 15%
| Levetiracetam 2000 | Accidental injury | | 1/42 | 2%
| Levetiracetam 4000 | Accidental injury | | 5/38 | 13%
| Placebo | Any | Any | 33/39 | 85%
| Levetiracetam 2000 | Any | Any | 35/42 | 83%
| Levetiracetam 4000 | Any | Any | 32/38 | 84%
| Placebo | Asthenia | | 6/39 | 15%
| Levetiracetam 2000 | Asthenia | | 13/42 | 31%
| Levetiracetam 4000 | Asthenia | | 5/38 | 13%
| Placebo | Dizziness | | 0/39 | 0%
| Levetiracetam 2000 | Dizziness | | 2/42 | 5%
| Levetiracetam 4000 | Dizziness | | 4/38 | 11%
| Placebo | Infection | | 3/39 | 8%
| Levetiracetam 2000 | Infection | | 1/42 | 2%
| Levetiracetam 4000 | Infection | | 6/38 | 16%
| Placebo | Nausea | | 1/39 | 3%
| Levetiracetam 2000 | Nausea | | 0/42 | 0%
| Levetiracetam 4000 | Nausea | | 5/38 | 13%
| Placebo | Somnolence | | 10/39 | 26%
| Levetiracetam 2000 | Somnolence | | 11/42 | 26%
| Levetiracetam 4000 | Somnolence | | 17/38 | 45%
| Placebo | Urinary tract infection | | 1/39 | 3%
| Levetiracetam 2000 | Urinary tract infection | | 0/42 | 0%
| Levetiracetam 4000 | Urinary tract infection | | 4/38 | 11%
Cereghino (2000) | Placebo | Abdominal pain | | 10/95 | 11%
| Levetiracetam 1000 | Abdominal pain | | 5/98 | 5%
| Levetiracetam 3000 | Abdominal pain | | 3/101 | 3%
| Placebo | Accidental injury | | 23/95 | 24%
| Levetiracetam 1000 | Accidental injury | | 16/98 | 16%
| Levetiracetam 3000 | Accidental injury | | 13/101 | 13%
| Placebo | Any | Severe | 10/95 | 11%
| Placebo | Any | Any | 84/95 | 88%
| Levetiracetam 1000 | Any | Severe | 7/98 | 7%
| Levetiracetam 1000 | Any | Any | 87/98 | 89%
| Levetiracetam 3000 | Any | Severe | 2/101 | 2%
| Levetiracetam 3000 | Any | Any | 90/101 | 89%
| Placebo | Asthenia | | 11/95 | 12%
| Levetiracetam 1000 | Asthenia | | 16/98 | 16%
| Levetiracetam 3000 | Asthenia | | 13/101 | 13%
| Placebo | Death | Severe | 1/95 | 1%
| Placebo | Diarrhea | | | 11%
| Levetiracetam 1000 | Diarrhea | | 7/98 | 7%
| Levetiracetam 3000 | Diarrhea | | 7/101 | 7%
| Placebo | Dizziness | | 7/95 | 7%
| Levetiracetam 1000 | Dizziness | | 17/98 | 17%
| Levetiracetam 3000 | Dizziness | | 20/101 | 20%
| Placebo | Flu syndrome | | 8/95 | 8%
| Levetiracetam 1000 | Flu syndrome | | 6/98 | 6%
| Levetiracetam 3000 | Flu syndrome | | 11/101 | 11%
| Placebo | Headache | | 19/95 | 20%
| Levetiracetam 1000 | Headache | | 21/98 | 21%
| Levetiracetam 3000 | Headache | | 21/101 | 21%
| Placebo | Infection | | 12/95 | 13%
| Levetiracetam 1000 | Infection | | 27/98 | 28%
| Levetiracetam 3000 | Infection | | 27/101 | 27%
| Placebo | Pain | | 13/95 | 14%
| Levetiracetam 1000 | Pain | | 11/98 | 11%
| Levetiracetam 3000 | Pain | | 13/101 | 13%
| Placebo | Rhinitis | | 8/95 | 8%
| Levetiracetam 1000 | Rhinitis | | 13/98 | 13%
| Levetiracetam 3000 | Rhinitis | | 7/101 | 7%
| Placebo | Somnolence | | 13/95 | 14%
| Levetiracetam 1000 | Somnolence | | 20/98 | 20%
| Levetiracetam 3000 | Somnolence | | 19/101 | 19%
Glauser (2000) | Placebo | Abdominal pain | | 13/129 | 10%
| Oxcarbazepine 1800 | Abdominal pain | | 12/138 | 9%
| Placebo | Abnormal gait | | 4/129 | 3%
| Oxcarbazepine 1800 | Abnormal gait | Withdrawal | 1/138 | 1%
| Oxcarbazepine 1800 | Abnormal gait | | 14/138 | 10%
| Placebo | Abnormal vision | | 2/129 | 2%
| Oxcarbazepine 1800 | Abnormal vision | | 19/138 | 14%
| Placebo | Anorexia | | 13/129 | 10%
| Oxcarbazepine 1800 | Anorexia | | 9/138 | 7%
| Placebo | Any | Severe | 8/129 | 6%
| Placebo | Any | Any | 106/129 | 82%
| Oxcarbazepine 1800 | Any | Severe | 7/138 | 5%
| Oxcarbazepine 1800 | Any | Any | 125/138 | 91%
| Placebo | Ataxia | | 6/129 | 5%
| Oxcarbazepine 1800 | Ataxia | Withdrawal | 1/138 | 1%
| Oxcarbazepine 1800 | Ataxia | | 19/138 | 14%
| Oxcarbazepine 1800 | Death | Severe | 1/138 | 1%
| Oxcarbazepine 1800 | Digestive problems | Withdrawal | 5/138 | 4%
| Placebo | Diplopia | | 1/129 | 1%
| Oxcarbazepine 1800 | Diplopia | Withdrawal | 1/138 | 1%
| Oxcarbazepine 1800 | Diplopia | | 23/138 | 17%
| Placebo | Dizziness | | 10/129 | 8%
| Oxcarbazepine 1800 | Dizziness | Withdrawal | 1/138 | 1%
| Oxcarbazepine 1800 | Dizziness | | 40/138 | 29%
| Placebo | Fatigue | | 11/129 | 9%
| Oxcarbazepine 1800 | Fatigue | | 18/138 | 13%
| Placebo | Fever | | 20/129 | 16%
| Oxcarbazepine 1800 | Fever | | 21/138 | 15%
| Placebo | Headache | | 23/129 | 18%
| Oxcarbazepine 1800 | Headache | | 44/138 | 32%
| Placebo | Leukopenia | Withdrawal | 1/129 | 1%
| Placebo | Nausea | | 7/129 | 5%
| Oxcarbazepine 1800 | Nausea | | 30/138 | 22%
| Placebo | Nystagmus | | 2/129 | 2%
| Oxcarbazepine 1800 | Nystagmus | Withdrawal | 1/138 | 1%
| Oxcarbazepine 1800 | Nystagmus | | 14/138 | 10%
| Placebo | Pharyngitis | | 15/129 | 12%
| Oxcarbazepine 1800 | Pharyngitis | | 12/138 | 9%
| Placebo | Rash | | 6/129 | 5%
| Oxcarbazepine 1800 | Rash | Withdrawal | 4/138 | 3%
| Oxcarbazepine 1800 | Rash | | 6/138 | 4%
| Placebo | Rhinitis | | 11/129 | 9%
| Oxcarbazepine 1800 | Rhinitis | | 16/138 | 12%
| Placebo | Somnolence | | 18/129 | 14%
| Oxcarbazepine 1800 | Somnolence | | 48/138 | 35%
| Placebo | Upper respiratory tract infection | | 15/129 | 12%
| Oxcarbazepine 1800 | Upper respiratory tract infection | | 10/138 | 7%
| Placebo | Viral infection | | 21/129 | 16%
| Oxcarbazepine 1800 | Viral infection | | 19/138 | 14%
| Placebo | Vomiting | | 19/129 | 15%
| Oxcarbazepine 1800 | Vomiting | | 50/138 | 36%
Appleton (1999) | Placebo | Anorexia | | 3/128 | 2%
| Gabapentin 1800 | Anorexia | | 2/119 | 2%
| Placebo | Any | Severe | 3/128 | 2%
| Gabapentin 1800 | Any | Severe | 14/119 | 12%
| Placebo | Bronchitis | | 1/128 | 1%
| Gabapentin 1800 | Bronchitis | | 4/119 | 3%
| Placebo | Convulsions | | 4/128 | 3%
| Gabapentin 1800 | Convulsions | | 3/119 | 3%
| Placebo | Coughing | | 4/128 | 3%
| Gabapentin 1800 | Coughing | | 2/119 | 2%
| Placebo | Death | Severe | 0/128 | 0%
| Gabapentin 1800 | Death | Severe | 0/119 | 0%
| Placebo | Diarrhea | | 4/128 | 3%
| Gabapentin 1800 | Diarrhea | | 3/119 | 3%
| Placebo | Dizziness | | 2/128 | 2%
| Gabapentin 1800 | Dizziness | | 3/119 | 3%
| Placebo | Emotional lability | | 2/128 | 2%
| Gabapentin 1800 | Emotional lability | | 5/119 | 4%
| Placebo | Fatigue | | 2/128 | 2%
| Gabapentin 1800 | Fatigue | | 4/119 | 3%
| Placebo | Fever | | 4/128 | 3%
| Gabapentin 1800 | Fever | | 12/119 | 10%
| Placebo | Headache | | 8/128 | 6%
| Gabapentin 1800 | Headache | | 6/119 | 5%
| Placebo | Hostility | | 3/128 | 2%
| Gabapentin 1800 | Hostility | Withdrawal | 2/119 | 2%
| Gabapentin 1800 | Hostility | | 9/119 | 8%
| Placebo | Hyperkinesia | | 1/128 | 1%
| Gabapentin 1800 | Hyperkinesia | | 3/119 | 3%
| Gabapentin 1800 | Insomnia | Withdrawal | 2/119 | 2%
| Placebo | Nausea and/or vomiting | | 9/128 | 7%
| Gabapentin 1800 | Nausea and/or vomiting | | 10/119 | 8%
| Placebo | Otitis media | | 4/128 | 3%
| Gabapentin 1800 | Otitis media | | 1/119 | 1%
| Placebo | Pharyngitis | | 11/128 | 9%
| Gabapentin 1800 | Pharyngitis | | 10/119 | 8%
| Placebo | Respiratory infection | | 1/128 | 1%
| Gabapentin 1800 | Respiratory infection | | 3/119 | 3%
| Placebo | Rhinitis | | 6/128 | 5%
| Gabapentin 1800 | Rhinitis | | 6/119 | 5%
| Placebo | Somnolence | | 6/128 | 5%
| Gabapentin 1800 | Somnolence | Withdrawal | 2/119 | 2%
| Gabapentin 1800 | Somnolence | | 10/119 | 8%
| Placebo | Upper respiratory tract infection | | 8/128 | 6%
| Gabapentin 1800 | Upper respiratory tract infection | | 7/119 | 6%
| Placebo | Viral infection | | 4/128 | 3%
| Gabapentin 1800 | Viral infection | | 13/119 | 11%
| Placebo | Weight gain | | 1/128 | 1%
| Gabapentin 1800 | Weight gain | | 4/119 | 3%
Biton (1999) | Placebo | Abdominal pain | | 2/41 | 5%
| Topiramate 400 | Abdominal pain | | 4/39 | 10%
| Topiramate 400 | Abnormal gait | Severe | 1/39 | 3%
| Placebo | Anorexia | | 3/41 | 7%
| Topiramate 400 | Anorexia | Withdrawal | 1/39 | 3%
| Topiramate 400 | Anorexia | | 6/39 | 15%
| Placebo | Chest pain | Severe | 1/41 | 2%
| Placebo | Dizziness | | 6/41 | 15%
| Topiramate 400 | Dizziness | | 4/39 | 10%
| Placebo | Dyspepsia | Severe | 1/41 | 2%
| Placebo | Fatigue | | 3/41 | 7%
| Topiramate 400 | Fatigue | | 7/39 | 18%
| Placebo | Granulocytopenia | Withdrawal | 1/41 | 2%
| Placebo | Headache | Severe | 2/41 | 5%
| Placebo | Headache | | 8/41 | 20%
| Topiramate 400 | Headache | | 5/39 | 13%
| Placebo | Impotence | Severe | 1/41 | 2%
| Topiramate 400 | Injury | Severe | 1/39 | 3%
| Placebo | Memory difficulty | | 0/41 | 0%
| Topiramate 400 | Memory difficulty | | 5/39 | 13%
| Placebo | Nervousness | | 0/41 | 0%
| Topiramate 400 | Nervousness | | 4/39 | 10%
| Topiramate 400 | Pain | Severe | 1/39 | 3%
| Placebo | Pharyngitis | | 2/41 | 5%
| Topiramate 400 | Pharyngitis | | 4/39 | 10%
| Placebo | Psychomotor slowing | | 1/41 | 2%
| Topiramate 400 | Psychomotor slowing | | 4/39 | 10%
| Placebo | Saliva | Severe | 1/41 | 2%
| Placebo | Somnolence | | 6/41 | 15%
| Topiramate 400 | Somnolence | | 10/39 | 26%
| Placebo | Speech problems | | 1/41 | 2%
| Topiramate 400 | Speech problems | Severe | 1/39 | 3%
| Topiramate 400 | Speech problems | | 4/39 | 10%
| Placebo | Upper respiratory tract infection | | 13/41 | 32%
| Topiramate 400 | Upper respiratory tract infection | | 16/39 | 41%
| Topiramate 400 | Viral infection | Severe | 1/39 | 3%
| Placebo | Weight loss | | 1/41 | 2%
| Topiramate 400 | Weight loss | | 6/39 | 15%
Duchowny (1999) | Placebo | Abdominal pain | | 7/101 | 7%
| Lamotrigine 750 | Abdominal pain | | 13/98 | 13%
| Placebo | Accidental injury | | 15/101 | 15%
| Lamotrigine 750 | Accidental injury | | 14/98 | 14%
| Placebo | Any | Severe | 9/101 | 9%
| Placebo | Any | Any | 96/101 | 95%
| Lamotrigine 750 | Any | Severe | 7/98 | 7%
| Lamotrigine 750 | Any | Any | 92/98 | 94%
| Placebo | Asthenia | | 6/101 | 6%
| Lamotrigine 750 | Asthenia | | 11/98 | 11%
| Placebo | Ataxia | | 2/101 | 2%
| Lamotrigine 750 | Ataxia | | 10/98 | 10%
| Placebo | Brain tumor | Withdrawal | 1/101 | 1%
| Placebo | Diarrhea | | 13/101 | 13%
| Lamotrigine 750 | Diarrhea | | 13/98 | 13%
| Placebo | Dizziness | | 5/101 | 5%
| Lamotrigine 750 | Dizziness | | 21/98 | 21%
| Placebo | Fever | | 12/101 | 12%
| Lamotrigine 750 | Fever | | 14/98 | 14%
| Placebo | Headache | | 15/101 | 15%
| Lamotrigine 750 | Headache | | 18/98 | 18%
| Placebo | Increase in seizures | Withdrawal | 1/101 | 1%
| Placebo | Infection | | 22/101 | 22%
| Lamotrigine 750 | Infection | | 21/98 | 21%
| Placebo | Nausea | | 2/101 | 2%
| Lamotrigine 750 | Nausea | | 11/98 | 11%
| Placebo | Otitis media | | 11/101 | 11%
| Lamotrigine 750 | Otitis media | | 9/98 | 9%
| Placebo | Pharyngitis | | 10/101 | 10%
| Lamotrigine 750 | Pharyngitis | | 11/98 | 11%
| Placebo | Rash | Withdrawal | 3/101 | 3%
| Placebo | Rash | | 18/101 | 18%
| Lamotrigine 750 | Rash | Withdrawal | 4/98 | 4%
| Lamotrigine 750 | Rash | | 1/98 | 1%
| Placebo | Rhinitis | | 17/101 | 17%
| Lamotrigine 750 | Rhinitis | | 14/98 | 14%
| Placebo | Somnolence | | 18/101 | 18%
| Lamotrigine 750 | Somnolence | | 24/98 | 24%
| Placebo | Threatened suicide | Withdrawal | 1/101 | 1%
| Placebo | Tremor | | 2/101 | 2%
| Lamotrigine 750 | Tremor | Withdrawal | 1/98 | 1%
| Lamotrigine 750 | Tremor | | 12/98 | 12%
| Placebo | Vomiting | | 19/101 | 19%
| Lamotrigine 750 | Vomiting | | 22/98 | 22%
Elterman (1999) | Placebo | Aggression | | 3/45 | 7%
| Topiramate 400 | Aggression | | 4/41 | 10%
| Placebo | Anorexia | | 5/45 | 11%
| Topiramate 400 | Anorexia | | 5/41 | 12%
| Placebo | Bleeding | | 2/45 | 4%
| Topiramate 400 | Bleeding | | 6/41 | 15%
| Placebo | Bodily injury | | 4/45 | 9%
| Topiramate 400 | Bodily injury | | 8/41 | 20%
| Topiramate 400 | Constipation | Severe | 1/41 | 2%
| Placebo | Coughing | | 5/45 | 11%
| Topiramate 400 | Coughing | | 6/41 | 15%
| Placebo | Death | Severe | 0/45 | 0%
| Topiramate 400 | Death | Severe | 0/41 | 0%
| Placebo | Diarrhea | | 10/45 | 22%
| Topiramate 400 | Diarrhea | | 4/41 | 10%
| Placebo | Emotional lability | | 2/45 | 4%
| Topiramate 400 | Emotional lability | | 5/41 | 12%
| Placebo | Fatigue | | 3/45 | 7%
| Topiramate 400 | Fatigue | | 6/41 | 15%
| Placebo | Fever | | 11/45 | 24%
| Topiramate 400 | Fever | | 12/41 | 29%
| Placebo | Hospitalization for increase in seizures | Severe | 2/45 | 4%
| Placebo | Impaired concentration | | 1/45 | 2%
| Topiramate 400 | Impaired concentration | | 5/41 | 12%
| Placebo | Memory difficulty | | 0/45 | 0%
| Topiramate 400 | Memory difficulty | | 3/41 | 7%
| Placebo | Mood problems | | 5/45 | 11%
| Topiramate 400 | Mood problems | | 4/41 | 10%
| Placebo | Nervousness | | 3/45 | 7%
| Topiramate 400 | Nervousness | | 4/41 | 10%
| Placebo | Otitis media | | 5/45 | 11%
| Topiramate 400 | Otitis media | | 4/41 | 10%
| Placebo | Rash | Withdrawal | 1/45 | 2%
| Placebo | Rash | | 4/45 | 9%
| Topiramate 400 | Rash | | 5/41 | 12%
| Placebo | Sinusitis | | 12/45 | 27%
| Topiramate 400 | Sinusitis | | 7/41 | 17%
| Placebo | Somnolence | | 6/45 | 13%
| Topiramate 400 | Somnolence | | 5/41 | 12%
| Placebo | Upper respiratory tract infection | | 16/45 | 36%
| Topiramate 400 | Upper respiratory tract infection | | 17/41 | 41%
| Placebo | Viral infection | Severe | 1/45 | 2%
| Placebo | Viral infection | | 2/45 | 4%
| Topiramate 400 | Viral infection | | 6/41 | 15%
KTSG (1999) | Placebo | Abdominal pain | | 2/86 | 2%
| Topiramate 600 | Abdominal pain | | 19/91 | 21%
| Placebo | Ambylopia | Withdrawal | 2/86 | 2%
| Placebo | Ambylopia | | 4/86 | 5%
| Topiramate 600 | Ambylopia | | 10/91 | 11%
| Placebo | Anorexia | | 5/86 | 6%
| Topiramate 600 | Anorexia | | 19/91 | 21%
| Placebo | Any | Any | 42/86 | 49%
| Topiramate 600 | Any | Any | 74/91 | 81%
| Placebo | Ataxia | Withdrawal | 1/86 | 1%
| Placebo | Ataxia | | 2/86 | 2%
| Topiramate 600 | Ataxia | | 7/91 | 8%
| Placebo | Dizziness | | 18/86 | 21%
| Topiramate 600 | Dizziness | | 18/91 | 20%
| Placebo | General weakness | | 2/86 | 2%
| Topiramate 600 | General weakness | | 5/91 | 5%
| Placebo | Headache | | 6/86 | 7%
| Topiramate 600 | Headache | | 10/91 | 11%
| Placebo | Memory difficulty | | 1/86 | 1%
| Topiramate 600 | Memory difficulty | | 6/91 | 7%
| Placebo | Nausea and/or vomiting | | 7/86 | 8%
| Topiramate 600 | Nausea and/or vomiting | Withdrawal | 4/91 | 4%
| Topiramate 600 | Nausea and/or vomiting | | 15/91 | 16%
| Placebo | Psychomotor slowing | | 1/86 | 1%
| Topiramate 600 | Psychomotor slowing | Withdrawal | 1/91 | 1%
| Topiramate 600 | Psychomotor slowing | | 8/91 | 9%
| Placebo | Somnolence | | 8/86 | 9%
| Topiramate 600 | Somnolence | Y | 18/91 | 20%
| Placebo | Speech problems | | 1/86 | 1%
| Topiramate 600 | Speech problems | | 9/91 | 10%
| Topiramate 600 | Tremor | Withdrawal | 2/91 | 2%
| Placebo | Weight loss | | 0/86 | 0%
| Topiramate 600 | Weight loss | | 8/91 | 9%
Sachdeo (1999) | Placebo | Anorexia | | 10/50 | 20%
| Topiramate 600 | Anorexia | | 19/48 | 40%
| Placebo | Any | Severe | 5/50 | 10%
| Topiramate 600 | Any | Severe | 11/48 | 23%
| Placebo | Behavioral problems | | 5/50 | 10%
| Topiramate 600 | Behavioral problems | | 10/48 | 21%
| Placebo | Dizziness | | 0/50 | 0%
| Topiramate 600 | Dizziness | | 5/48 | 10%
| Placebo | Fatigue | | 2/50 | 4%
| Topiramate 600 | Fatigue | | 9/48 | 19%
| Placebo | Nervousness | | 5/50 | 10%
| Topiramate 600 | Nervousness | | 10/48 | 21%
| Placebo | Somnolence | | 11/50 | 22%
| Topiramate 600 | Somnolence | | 20/48 | 42%
| Placebo | Weight loss | | 0/50 | 0%
| Topiramate 600 | Weight loss | | 5/48 | 10%
Uthman (1998) | Placebo | Abnormal thinking | | 3/91 | 3%
| Tiagabine 16 | Abnormal thinking | | 2/61 | 3%
| Tiagabine 32 | Abnormal thinking | | 7/88 | 8%
| Tiagabine 56 | Abnormal thinking | | 8/57 | 14%
| Placebo | Depression | | 0/91 | 0%
| Tiagabine 16 | Depression | | 4/61 | 7%
| Tiagabine 32 | Depression | | 2/88 | 2%
| Tiagabine 56 | Depression | | 4/57 | 7%
| Placebo | Dizziness | | 15/91 | 16%
| Tiagabine 16 | Dizziness | | 18/61 | 30%
| Tiagabine 32 | Dizziness | | 29/88 | 33%
| Tiagabine 56 | Dizziness | | 17/57 | 30%
| Placebo | Nervous system | Withdrawal | 1/91 | 1%
| Placebo | Nervous system | | 57/91 | 63%
| Tiagabine 16 | Nervous system | Withdrawal | 2/61 | 3%
| Tiagabine 16 | Nervous system | | 42/61 | 69%
| Tiagabine 32 | Nervous system | Withdrawal | 10/88 | 11%
| Tiagabine 32 | Nervous system | | 62/88 | 70%
| Tiagabine 56 | Nervous system | Withdrawal | 8/57 | 14%
| Tiagabine 56 | Nervous system | | 44/57 | 77%
| Placebo | Tremor | | 3/91 | 3%
| Tiagabine 16 | Tremor | | 6/61 | 10%
| Tiagabine 32 | Tremor | | 13/88 | 15%
| Tiagabine 56 | Tremor | | 12/57 | 21%
Sachdeo (1997b) | Placebo | Abdominal pain | | 1/107 | 0.9%
| Tiagabine 32 | Abdominal pain | | 10/105 | 9.5%
| Tiagabine 32 | Abdominal pain | | 8/106 | 7.5%
| Placebo | Amnesia | | 1/107 | 0.9%
| Tiagabine 32 | Amnesia | | 5/105 | 4.8%
| Tiagabine 32 | Amnesia | | 7/106 | 6.6%
| Placebo | Any | Severe | 2/107 | 2%
| Tiagabine 32 | Any | Severe | 2/105 | 2%
| Tiagabine 32 | Any | Severe | 2/106 | 2%
| Placebo | Emotional lability | | 1/107 | 0.9%
| Tiagabine 32 | Emotional lability | | 8/105 | 7.6%
| Tiagabine 32 | Emotional lability | | 1/106 | 0.9%
| Placebo | Nervousness | | 1/107 | 0.9%
| Tiagabine 32 | Nervousness | | 11/105 | 10.5%
| Tiagabine 32 | Nervousness | | 10/106 | 9.4%
| Placebo | Vomiting | | 3/107 | 2.8%
| Tiagabine 32 | Vomiting | | 4/105 | 3.8%
| Tiagabine 32 | Vomiting | | 10/106 | 9.4%
Ben-Menachem (1996) | Placebo | Any | Severe | 0/28 | 0%
| Topiramate 800 | Any | Severe | 0/28 | 0%
| Placebo | Death | Severe | 0/28 | 0%
| Topiramate 800 | Death | Severe | 0/28 | 0%
| Placebo | Dizziness | | 1/28 | 4%
| Topiramate 800 | Dizziness | | 6/28 | 21%
| Placebo | Fatigue | | 10/28 | 36%
| Topiramate 800 | Fatigue | | 22/28 | 79%
| Placebo | Headache | | 10/28 | 36%
| Topiramate 800 | Headache | | 6/28 | 21%
| Placebo | Impaired concentration | | 0/28 | 0%
| Topiramate 800 | Impaired concentration | | 7/28 | 25%
| Placebo | Paresthesia | | 1/28 | 4%
| Topiramate 800 | Paresthesia | | 5/28 | 18%
| Placebo | Weight loss | | 0/28 | 0%
| Topiramate 800 | Weight loss | | 7/28 | 25%
Chadwick (1996) | Placebo | Amblyopia | | 2/71 | 3%
| Gabapentin 1200 | Amblyopia | | 3/58 | 5%
| Placebo | Any | Severe | 10/71 | 14%
| Placebo | Any | Moderate | 22/71 | 31%
| Placebo | Any | Mild | 8/71 | 11%
| Placebo | Any | Any | 40/71 | 56%
| Gabapentin 1200 | Any | Severe | 9/58 | 16%
| Gabapentin 1200 | Any | Moderate | 16/58 | 28%
| Gabapentin 1200 | Any | Mild | 14/58 | 24%
| Gabapentin 1200 | Any | Any | 39/58 | 67%
| Placebo | Ataxia | | 5/71 | 7%
| Gabapentin 1200 | Ataxia | | 4/58 | 7%
| Placebo | Convulsions | | 8/71 | 11%
| Gabapentin 1200 | Convulsions | | 5/58 | 9%
| Placebo | Death | Severe | 0/71 | 0%
| Gabapentin 1200 | Death | Severe | 1/58 | 2%
| Placebo | Dizziness | | 3/71 | 4%
| Gabapentin 1200 | Dizziness | | 6/58 | 10%
| Placebo | Emotional lability | | 3/71 | 4%
| Gabapentin 1200 | Emotional lability | | 4/58 | 7%
| Placebo | Fatigue | | 4/71 | 6%
| Gabapentin 1200 | Fatigue | | 6/58 | 10%
| Placebo | Headache | | 6/71 | 8%
| Gabapentin 1200 | Headache | | 2/58 | 3%
| Placebo | Nausea and/or vomiting | | 4/71 | 6%
| Gabapentin 1200 | Nausea and/or vomiting | | 4/58 | 7%
| Placebo | Rash | | 2/71 | 3%
| Gabapentin 1200 | Rash | | 3/58 | 5%
| Placebo | Somnolence | | 3/71 | 4%
| Gabapentin 1200 | Somnolence | | 7/58 | 12%
| Placebo | Thrombocytopenia | | 0/71 | 0%
| Gabapentin 1200 | Thrombocytopenia | | 3/58 | 5%
| Placebo | Weight gain | | 5/71 | 7%
| Gabapentin 1200 | Weight gain | | 4/58 | 7%
Faught (1996) | Placebo | Abnormal thinking | | 1/45 | 2%
| Topiramate 200 | Abnormal thinking | | 9/45 | 20%
| Topiramate 400 | Abnormal thinking | | 6/45 | 13%
| Topiramate 600 | Abnormal thinking | | 14/46 | 30%
| Placebo | Any | Severe | 0/45 | 0%
| Topiramate 200 | Any | Severe | 0/45 | 0%
| Topiramate 400 | Any | Severe | 0/45 | 0%
| Topiramate 600 | Any | Severe | 0/46 | 0%
| Placebo | Ataxia | | 4/45 | 9%
| Topiramate 200 | Ataxia | | 9/45 | 20%
| Topiramate 400 | Ataxia | | 13/45 | 29%
| Topiramate 600 | Ataxia | | 12/46 | 26%
| Placebo | Death | Severe | 0/45 | 0%
| Topiramate 200 | Death | Severe | 0/45 | 0%
| Topiramate 400 | Death | Severe | 0/45 | 0%
| Topiramate 600 | Death | Severe | 0/46 | 0%
| Placebo | Diplopia | | 2/45 | 4%
| Topiramate 200 | Diplopia | | 3/45 | 7%
| Topiramate 400 | Diplopia | | 11/45 | 24%
| Topiramate 600 | Diplopia | | 3/46 | 7%
| Placebo | Dizziness | | 13/45 | 29%
| Topiramate 200 | Dizziness | | 16/45 | 36%
| Topiramate 400 | Dizziness | | 15/45 | 33%
| Topiramate 600 | Dizziness | | 16/46 | 35%
| Placebo | Fatigue | | 5/45 | 11%
| Topiramate 200 | Fatigue | | 5/45 | 11%
| Topiramate 400 | Fatigue | | 3/45 | 7%
| Topiramate 600 | Fatigue | | 9/46 | 20%
| Placebo | Headache | | 13/45 | 29%
| Topiramate 200 | Headache | | 13/45 | 29%
| Topiramate 400 | Headache | | 14/45 | 31%
| Topiramate 600 | Headache | | 13/46 | 28%
| Placebo | Nystagmus | | 8/45 | 18%
| Topiramate 200 | Nystagmus | | 8/45 | 18%
| Topiramate 400 | Nystagmus | | 9/45 | 20%
| Topiramate 600 | Nystagmus | | 7/46 | 15%
| Placebo | Paresthesia | | 1/45 | 2%
| Topiramate 200 | Paresthesia | | 8/45 | 18%
| Topiramate 400 | Paresthesia | | 9/45 | 20%
| Topiramate 600 | Paresthesia | | 4/46 | 9%
| Placebo | Somnolence | | 4/45 | 9%
| Topiramate 200 | Somnolence | | 13/45 | 29%
| Topiramate 400 | Somnolence | | 12/45 | 27%
| Topiramate 600 | Somnolence | | 14/46 | 30%
Privitera (1996) | Topiramate 1000 | Abdominal pain | Severe | 1/47 | 2%
| Placebo | Abnormal thinking | | 3/47 | 6%
| Topiramate 600 | Abnormal thinking | | 16/48 | 33%
| Topiramate 800 | Abnormal thinking | | 21/48 | 44%
| Topiramate 1000 | Abnormal thinking | | 12/47 | 26%
| Placebo | Anorexia | | 2/47 | 4%
| Topiramate 600 | Anorexia | | 5/48 | 10%
| Topiramate 800 | Anorexia | | 3/48 | 6%
| Topiramate 1000 | Anorexia | | 10/47 | 21%
| Placebo | Ataxia | | 4/47 | 9%
| Topiramate 600 | Ataxia | | 7/48 | 15%
| Topiramate 800 | Ataxia | | 9/48 | 19%
| Topiramate 1000 | Ataxia | | 9/47 | 19%
| Placebo | Confusion | | 4/47 | 9%
| Topiramate 600 | Confusion | | 10/48 | 21%
| Topiramate 800 | Confusion | | 11/48 | 23%
| Topiramate 1000 | Confusion | | 13/47 | 28%
| Placebo | Death | Severe | 0/47 | 0%
| Topiramate 600 | Death | Severe | 0/48 | 0%
| Topiramate 800 | Death | Severe | 0/48 | 0%
| Topiramate 1000 | Death | Severe | 0/47 | 0%
| Placebo | Diplopia | | 6/47 | 13%
| Topiramate 600 | Diplopia | | 7/48 | 15%
| Topiramate 800 | Diplopia | | 10/48 | 21%
| Topiramate 1000 | Diplopia | | 13/47 | 28%
| Placebo | Dizziness | | 7/47 | 15%
| Topiramate 600 | Dizziness | | 16/48 | 33%
| Topiramate 800 | Dizziness | | 17/48 | 35%
| Topiramate 1000 | Dizziness | | 18/47 | 38%
| Placebo | Fatigue | | 4/47 | 9%
| Topiramate 600 | Fatigue | | 18/48 | 38%
| Topiramate 800 | Fatigue | | 11/48 | 23%
| Topiramate 1000 | Fatigue | | 11/47 | 23%
| Placebo | Headache | | 15/47 | 32%
| Topiramate 600 | Headache | | 16/48 | 33%
| Topiramate 800 | Headache | | 13/48 | 27%
| Topiramate 1000 | Headache | | 9/47 | 19%
| Placebo | Impaired concentration | | 0/47 | 0%
| Topiramate 600 | Impaired concentration | | 8/48 | 17%
| Topiramate 800 | Impaired concentration | | 4/48 | 8%
| Topiramate 1000 | Impaired concentration | | 10/47 | 21%
| Placebo | Nystagmus | | 8/47 | 17%
| Topiramate 600 | Nystagmus | | 4/48 | 8%
| Topiramate 800 | Nystagmus | | 11/48 | 23%
| Topiramate 1000 | Nystagmus | | 13/47 | 28%
| Placebo | Paresthesia | | 3/47 | 6%
| Topiramate 600 | Paresthesia | | 11/48 | 23%
| Topiramate 800 | Paresthesia | | 9/48 | 19%
| Topiramate 1000 | Paresthesia | | 6/47 | 13%
| Topiramate 1000 | Shortness of breath | Severe | 1/47 | 2%
| Placebo | Somnolence | | 6/47 | 13%
| Topiramate 600 | Somnolence | | 6/48 | 13%
| Topiramate 800 | Somnolence | | 15/48 | 31%
| Topiramate 1000 | Somnolence | | 16/47 | 34%
Sharief (1996) | Placebo | Abnormal vision | | 0/24 | 0%
| Topiramate 400 | Abnormal vision | | 6/23 | 26%
| Placebo | Amnesia | | 0/24 | 0%
| Topiramate 400 | Amnesia | | 3/23 | 13%
| Placebo | Anxiety | | 1/24 | 4%
| Topiramate 400 | Anxiety | | 5/23 | 22%
| Placebo | Any | Severe | 0/24 | 0%
| Topiramate 400 | Any | Severe | 0/23 | 0%
| Placebo | Aphasia | | 0/24 | 0%
| Topiramate 400 | Aphasia | | 3/23 | 13%
| Placebo | Asthenia | | 1/24 | 4%
| Topiramate 400 | Asthenia | | 4/23 | 17%
| Placebo | Central nervous system | Withdrawal | 1/24 | 4%
| Topiramate 400 | Central nervous system | Withdrawal | 5/23 | 22%
| Placebo | Confusion | | 4/24 | 17%
| Topiramate 400 | Confusion | | 3/23 | 13%
| Placebo | Depression | | 3/24 | 13%
| Topiramate 400 | Depression | | 2/23 | 9%
| Topiramate 400 | Dyspepsia | Withdrawal | 1/23 | 4%
| Placebo | Emotional lability | | 0/24 | 0%
| Topiramate 400 | Emotional lability | | 3/23 | 13%
| Placebo | Fatigue | | 4/24 | 17%
| Topiramate 400 | Fatigue | | 6/23 | 26%
| Placebo | Headache | | 5/24 | 21%
| Topiramate 400 | Headache | | 3/23 | 13%
| Placebo | Impaired concentration | | 1/24 | 4%
| Topiramate 400 | Impaired concentration | | 4/23 | 17%
| Placebo | Injury | | 3/24 | 13%
| Topiramate 400 | Injury | | 1/23 | 4%
| Placebo | Nervousness | | 3/24 | 13%
| Topiramate 400 | Nervousness | | 2/23 | 9%
| Placebo | Pharyngitis | | 0/24 | 0%
| Topiramate 400 | Pharyngitis | | 3/23 | 13%
| Placebo | Somnolence | | 4/24 | 17%
| Topiramate 400 | Somnolence | | 8/23 | 35%
| Placebo | Speech problems | | 2/24 | 8%
| Topiramate 400 | Speech problems | | 3/23 | 13%
| Placebo | Upper respiratory tract infection | | 2/24 | 8%
| Topiramate 400 | Upper respiratory tract infection | | 4/23 | 17%
| Placebo | Weight loss | | 2/24 | 8%
| Topiramate 400 | Weight loss | | 6/23 | 26%
Tassinari (1996) | Placebo | Abnormal thinking | | 0/30 | 0%
| Topiramate 600 | Abnormal thinking | | 5/30 | 17%
| Placebo | Amnesia | Withdrawal | 1/30 | 3%
| Placebo | Amnesia | | 2/30 | 7%
| Topiramate 600 | Amnesia | | 2/30 | 7%
| Placebo | Anxiety | | 3/30 | 10%
| Topiramate 600 | Anxiety | | 2/30 | 7%
| Placebo | Confusion | | 0/30 | 0%
| Topiramate 600 | Confusion | | 3/30 | 10%
| Placebo | Convulsions aggravated | | 2/30 | 7%
| Topiramate 600 | Convulsions aggravated | | 3/30 | 10%
| Placebo | Depression | | 2/30 | 7%
| Topiramate 600 | Depression | | 5/30 | 17%
| Placebo | Diarrhea | | 1/30 | 3%
| Topiramate 600 | Diarrhea | | 3/30 | 10%
| Placebo | Dizziness | | 3/30 | 10%
| Topiramate 600 | Dizziness | | 7/30 | 23%
| Placebo | Emotional lability | | 1/30 | 3%
| Topiramate 600 | Emotional lability | | 4/30 | 13%
| Placebo | Fatigue | | 3/30 | 10%
| Topiramate 600 | Fatigue | | 6/30 | 20%
| Placebo | Headache | | 3/30 | 10%
| Topiramate 600 | Headache | | 8/30 | 27%
| Placebo | Impaired concentration | | 0/30 | 0%
| Topiramate 600 | Impaired concentration | | 2/30 | 7%
| Topiramate 600 | Increased seizures | Withdrawal | 1/30 | 3%
| Placebo | Nausea | | 2/30 | 7%
| Topiramate 600 | Nausea | Withdrawal | 1/30 | 3%
| Topiramate 600 | Nausea | | 3/30 | 10%
| Topiramate 600 | Seizure-associated injuries | Withdrawal | 1/30 | 3%
| Placebo | Somnolence | | 4/30 | 13%
| Topiramate 600 | Somnolence | Withdrawal | 1/30 | 3%
| Topiramate 600 | Somnolence | | 6/30 | 20%
| Placebo | Upper respiratory tract infection | | 1/30 | 3%
| Topiramate 600 | Upper respiratory tract infection | | 3/30 | 10%
| Placebo | Weight loss | | 2/30 | 7%
| Topiramate 600 | Weight loss | | 5/30 | 17%
Willmore (1996) | Placebo | Abdominal pain | | 4/70 | 6%
| Valproate 90 mg/kg | Abdominal pain | | 18/77 | 23%
| Placebo | Anorexia | | 0/70 | 0%
| Valproate 90 mg/kg | Anorexia | | 9/77 | 12%
| Placebo | Asthenia | | 5/70 | 7%
| Valproate 90 mg/kg | Asthenia | | 21/77 | 27%
| Valproate 90 mg/kg | Erythema | Withdrawal | 1/77 | 1%
| Valproate 90 mg/kg | Leukopenia | Withdrawal | 1/77 | 1%
| Placebo | Nausea | | 10/70 | 14%
| Valproate 90 mg/kg | Nausea | | 37/77 | 48%
| Valproate 90 mg/kg | Nausea and/or vomiting | Withdrawal | 3/77 | 4%
| Valproate 90 mg/kg | Psychosis | Withdrawal | 1/77 | 1%
| Placebo | Somnolence | | 8/70 | 11%
| Valproate 90 mg/kg | Somnolence | | 21/77 | 27%
| Placebo | Tremor | | 4/70 | 6%
| Valproate 90 mg/kg | Tremor | | 19/77 | 25%
| Placebo | Vomiting | | 5/70 | 7%
| Valproate 90 mg/kg | Vomiting | | 21/77 | 27%
Anhut (1994) | Placebo | Any | Any | 57/109 | 52%
| Gabapentin 900 | Any | Any | 76/111 | 68%
| Gabapentin 1200 | Any | Any | 33/52 | 63%
| Placebo | Ataxia | | 3/109 | 3%
| Gabapentin 900 | Ataxia | | 12/111 | 11%
| Gabapentin 1200 | Ataxia | | 1/52 | 2%
| Placebo | Convulsions | | 3/109 | 3%
| Gabapentin 900 | Convulsions | | 8/111 | 7%
| Gabapentin 1200 | Convulsions | | 0/52 | 0%
| Gabapentin 900 | Death | Severe | 1/111 | 1%
| Placebo | Diplopia | | 2/109 | 2%
| Gabapentin 900 | Diplopia | | 5/111 | 5%
| Gabapentin 1200 | Diplopia | | 2/52 | 4%
| Placebo | Dizziness | | 9/109 | 8%
| Gabapentin 900 | Dizziness | | 23/111 | 21%
| Gabapentin 1200 | Dizziness | | 7/52 | 13%
| Placebo | Fatigue | | 5/109 | 5%
| Gabapentin 900 | Fatigue | | 10/111 | 9%
| Gabapentin 1200 | Fatigue | | 6/52 | 12%
| Placebo | Headache | | 8/109 | 7%
| Gabapentin 900 | Headache | | 2/111 | 2%
| Gabapentin 1200 | Headache | | 3/52 | 6%
| Placebo | Increased appetite | | 2/109 | 2%
| Gabapentin 900 | Increased appetite | | 3/111 | 3%
| Gabapentin 1200 | Increased appetite | | 3/52 | 6%
| Placebo | Nausea and/or vomiting | | 10/109 | 9%
| Gabapentin 900 | Nausea and/or vomiting | | 7/111 | 6%
| Gabapentin 1200 | Nausea and/or vomiting | | 2/52 | 4%
| Placebo | Somnolence | | 13/109 | 12%
| Gabapentin 900 | Somnolence | | 24/111 | 22%
| Gabapentin 1200 | Somnolence | | 7/52 | 13%
| Placebo | Tremor | | 2/109 | 2%
| Gabapentin 900 | Tremor | | 2/111 | 2%
| Gabapentin 1200 | Tremor | | 4/52 | 8%
Messenheimer (1994) | Lamotrigine 400 | Central nervous system | Withdrawal | 2/44 | 5%
| Placebo | Rash | Withdrawal | 1/44 | 2%
| Lamotrigine 400 | Rash | Withdrawal | 3/44 | 7%
Bourgeois (1993) | Felbamate 3600 | Agitation | Withdrawal | 1/30 | 3%
| Placebo | Anorexia | | 0/34 | 0%
| Felbamate 3600 | Anorexia | | 6/30 | 20%
| Placebo | Anxiety | | 2/34 | 6%
| Felbamate 3600 | Anxiety | | 4/30 | 13%
| Placebo | Constipation | | 1/34 | 3%
| Felbamate 3600 | Constipation | | 6/30 | 20%
| Placebo | Dizziness | | 5/34 | 15%
| Felbamate 3600 | Dizziness | Withdrawal | 1/30 | 3%
| Felbamate 3600 | Dizziness | | 7/30 | 23%
| Placebo | Dyspepsia | | 3/34 | 9%
| Felbamate 3600 | Dyspepsia | | 5/30 | 17%
| Placebo | Fatigue | | 2/34 | 6%
| Felbamate 3600 | Fatigue | | 6/30 | 20%
| Placebo | Headache | | 4/34 | 12%
| Felbamate 3600 | Headache | | 12/30 | 40%
| Placebo | Insomnia | | 2/34 | 6%
| Felbamate 3600 | Insomnia | | 11/30 | 37%
| Placebo | Nausea | | 1/34 | 3%
| Felbamate 3600 | Nausea | | 11/30 | 37%
| Placebo | Psychosis | Withdrawal | 1/34 | 3%
| Placebo | Somnolence | | 3/34 | 9%
| Felbamate 3600 | Somnolence | | 3/30 | 10%
| Felbamate 3600 | Stupor | Severe | 1/30 | 3%
| Placebo | Vomiting | | 1/34 | 3%
| Felbamate 3600 | Vomiting | | 4/30 | 13%
FSG (1993) | Placebo | Abnormal gait | | 0/36 | 0%
| Felbamate 3600 | Abnormal gait | | 5/37 | 14%
| Placebo | Anorexia | | 5/36 | 14%
| Felbamate 3600 | Anorexia | | 18/37 | 49%
| Placebo | Any | Severe | 3/36 | 8%
| Felbamate 3600 | Any | Severe | 8/37 | 22%
| Placebo | Ataxia | | 1/36 | 3%
| Felbamate 3600 | Ataxia | | 4/37 | 11%
| Placebo | Diarrhea | | 8/36 | 22%
| Felbamate 3600 | Diarrhea | | 1/37 | 3%
| Placebo | Fatigue | | 2/36 | 6%
| Felbamate 3600 | Fatigue | | 6/37 | 16%
| Placebo | Fever | | 5/36 | 14%
| Felbamate 3600 | Fever | | 8/37 | 22%
| Placebo | Headache | | 5/36 | 14%
| Felbamate 3600 | Headache | | 4/37 | 11%
| Placebo | Injury | | 10/36 | 28%
| Felbamate 3600 | Injury | | 6/37 | 16%
| Placebo | Insomnia | | 5/36 | 14%
| Felbamate 3600 | Insomnia | | 6/37 | 16%
| Placebo | Nervousness | | 5/36 | 14%
| Felbamate 3600 | Nervousness | | 5/37 | 14%
| Placebo | Pancreatitis | Withdrawal | 1/36 | 3%
| Placebo | Purpura | | 3/36 | 8%
| Felbamate 3600 | Purpura | | 4/37 | 11%
| Placebo | Rhinitis | | 4/36 | 11%
| Felbamate 3600 | Rhinitis | | 1/37 | 3%
| Placebo | Somnolence | | 3/36 | 8%
| Felbamate 3600 | Somnolence | Withdrawal | 1/37 | 3%
| Felbamate 3600 | Somnolence | | 16/37 | 43%
| Placebo | Upper respiratory tract infection | | 10/36 | 28%
| Felbamate 3600 | Upper respiratory tract infection | | 14/37 | 38%
| Placebo | Vomiting | | 5/36 | 14%
| Felbamate 3600 | Vomiting | | 15/37 | 41%
Matsuo (1993) | Lamotrigine 500 | Allergic reaction | Severe | 1/72 | 1%
| Lamotrigine 500 | Ataxia | Withdrawal | 1/72 | 1%
| Placebo | Ataxia | Any | 7/73 | 10%
| Lamotrigine 300 | Ataxia | Any | 7/71 | 10%
| Lamotrigine 500 | Ataxia | Any | 20/72 | 28%
| Lamotrigine 500 | Blurred vision | Withdrawal | 3/72 | 4%
| Placebo | Blurred vision | Any | 7/73 | 10%
| Lamotrigine 300 | Blurred vision | Any | 8/71 | 11%
| Lamotrigine 500 | Blurred vision | Any | 18/72 | 25%
| Lamotrigine 500 | Delerium | Severe | 1/72 | 1%
| Lamotrigine 500 | Delusions | Severe | 1/72 | 1%
| Lamotrigine 500 | Diplopia | Withdrawal | 2/72 | 3%
| Placebo | Diplopia | Any | 6/73 | 8%
| Lamotrigine 300 | Diplopia | Any | 17/71 | 24%
| Lamotrigine 500 | Diplopia | Any | 35/72 | 49%
| Lamotrigine 500 | Dizziness | Withdrawal | 4/72 | 6%
| Placebo | Dizziness | Withdrawal | 1/73 | 1%
| Placebo | Dizziness | Any | 20/73 | 27%
| Lamotrigine 300 | Dizziness | Any | 22/71 | 31%
| Lamotrigine 500 | Dizziness | Any | 39/72 | 54%
| Lamotrigine 500 | Headache | Withdrawal | 3/72 | 4%
| Placebo | Headache | Withdrawal | 1/73 | 1%
| Placebo | Headache | Any | 19/73 | 26%
| Lamotrigine 300 | Headache | Any | 23/71 | 32%
| Lamotrigine 500 | Headache | Any | 23/72 | 32%
| Lamotrigine 500 | Nausea | Withdrawal | 3/72 | 4%
| Placebo | Nausea | Withdrawal | 1/73 | 1%
| Placebo | Nausea | Any | 8/73 | 11%
| Lamotrigine 300 | Nausea | Withdrawal | 1/71 | 1%
| Lamotrigine 300 | Nausea | Any | 13/71 | 18%
| Lamotrigine 500 | Nausea | Any | 18/72 | 25%
| Placebo | Pain | Any | 2/73 | 3%
| Lamotrigine 300 | Pain | Any | 9/71 | 13%
| Lamotrigine 500 | Pain | Any | 5/72 | 7%
| Lamotrigine 500 | Panic | Severe | 1/72 | 1%
| Lamotrigine 300 | Psychosis | Severe | 1/71 | 1%
| Placebo | Rash | Any | 7/73 | 10%
| Lamotrigine 300 | Rash | Withdrawal | 1/71 | 1%
| Lamotrigine 300 | Rash | Any | 12/71 | 17%
| Lamotrigine 500 | Rash | Any | 7/72 | 10%
| Placebo | Somnolence | Any | 5/73 | 7%
| Lamotrigine 300 | Somnolence | Any | 15/71 | 21%
| Lamotrigine 500 | Somnolence | Any | 7/72 | 10%
| Lamotrigine 500 | Vomiting | Withdrawal | 1/72 | 1%
| Placebo | Vomiting | Any | 3/73 | 4%
| Lamotrigine 300 | Vomiting | Any | 8/71 | 11%
| Lamotrigine 500 | Vomiting | Any | 13/72 | 18%
McLean (1993) | Gabapentin 1200 | Agitation | Withdrawal | 1/101 | 1%
| Placebo | Any | Any | 71/98 | 72%
| Gabapentin 600 | Any | Any | 46/53 | 87%
| Gabapentin 1200 | Any | Any | 89/101 | 88%
| Gabapentin 1800 | Any | Any | 49/54 | 91%
| Placebo | Ataxia | | 11/98 | 11%
| Gabapentin 600 | Ataxia | | 6/53 | 11%
| Gabapentin 1200 | Ataxia | | 26/101 | 26%
| Gabapentin 1800 | Ataxia | | 10/54 | 19%
| Placebo | Diplopia | | 4/98 | 4%
| Gabapentin 600 | Diplopia | | 5/53 | 9%
| Gabapentin 1200 | Diplopia | | 11/101 | 11%
| Gabapentin 1800 | Diplopia | | 2/54 | 4%
| Placebo | Dizziness | | 9/98 | 9%
| Gabapentin 600 | Dizziness | | 13/53 | 25%
| Gabapentin 1200 | Dizziness | | 25/101 | 25%
| Gabapentin 1800 | Dizziness | | 10/54 | 19%
| Placebo | Dyspnea | Withdrawal | 1/98 | 1%
| Placebo | Fatigue | | 7/98 | 7%
| Gabapentin 600 | Fatigue | Withdrawal | 1/53 | 2%
| Gabapentin 600 | Fatigue | | 6/53 | 11%
| Gabapentin 1200 | Fatigue | Withdrawal | 1/101 | 1%
| Gabapentin 1200 | Fatigue | | 11/101 | 11%
| Gabapentin 1800 | Fatigue | | 7/54 | 13%
| Placebo | Headache | | 12/98 | 12%
| Gabapentin 600 | Headache | | 10/53 | 19%
| Gabapentin 1200 | Headache | | 9/101 | 9%
| Gabapentin 1800 | Headache | | 11/54 | 20%
| Gabapentin 1800 | Hemiparesis | Withdrawal | 1/54 | 2%
| Gabapentin 1800 | Low hemoglobin | Withdrawal | 1/54 | 2%
| Gabapentin 600 | Myoclonic jerks | Withdrawal | 1/53 | 2%
| Placebo | Nausea and/or vomiting | | 9/98 | 9%
| Gabapentin 600 | Nausea and/or vomiting | | 7/53 | 13%
| Gabapentin 1200 | Nausea and/or vomiting | | 6/101 | 6%
| Gabapentin 1800 | Nausea and/or vomiting | | 5/54 | 9%
| Placebo | Nystagmus | | 13/98 | 13%
| Gabapentin 600 | Nystagmus | | 5/53 | 9%
| Gabapentin 1200 | Nystagmus | | 17/101 | 17%
| Gabapentin 1800 | Nystagmus | | 9/54 | 17%
| Placebo | Rhinitis | | 10/98 | 10%
| Gabapentin 600 | Rhinitis | | 4/53 | 8%
| Gabapentin 1200 | Rhinitis | | 11/101 | 11%
| Gabapentin 1800 | Rhinitis | | 7/54 | 13%
| Placebo | Somnolence | | 12/98 | 12%
| Gabapentin 600 | Somnolence | | 4/53 | 8%
| Gabapentin 1200 | Somnolence | | 36/101 | 36%
| Gabapentin 1800 | Somnolence | | 11/54 | 20%
| Placebo | Tremor | | 9/98 | 9%
| Gabapentin 600 | Tremor | | 4/53 | 8%
| Gabapentin 1200 | Tremor | | 15/101 | 15%
| Gabapentin 1800 | Tremor | | 7/54 | 13%
| Gabapentin 600 | Urinary frequency | Withdrawal | 1/53 | 2%
Schmidt (1993) | Placebo | Abdominal pain | | 3/68 | 4%
| Zonisamide 20 mg/kg | Abdominal pain | | 5/71 | 7%
| Placebo | Abnormal thinking | | 1/68 | 1%
| Zonisamide 20 mg/kg | Abnormal thinking | | 8/71 | 11%
| Placebo | Anorexia | | 1/68 | 1%
| Zonisamide 20 mg/kg | Anorexia | | 9/71 | 13%
| Placebo | Any | Any | 19/68 | 28%
| Zonisamide 20 mg/kg | Any | Any | 42/71 | 59%
| Placebo | Ataxia | | 0/68 | 0%
| Zonisamide 20 mg/kg | Ataxia | | 8/71 | 11%
| Placebo | Confusion | | 0/68 | 0%
| Zonisamide 20 mg/kg | Confusion | Withdrawal | 1/71 | 1%
| Zonisamide 20 mg/kg | Confusion | | 4/71 | 6%
| Placebo | Dizziness | | 3/68 | 4%
| Zonisamide 20 mg/kg | Dizziness | | 12/71 | 17%
| Placebo | Fatigue | | 8/68 | 12%
| Zonisamide 20 mg/kg | Fatigue | | 16/71 | 23%
| Zonisamide 20 mg/kg | Increase in seizures | Withdrawal | 1/71 | 1%
| Placebo | Nausea and/or vomiting | | 3/68 | 4%
| Zonisamide 20 mg/kg | Nausea and/or vomiting | | 3/71 | 4%
| Placebo | Nervousness | | 2/68 | 3%
| Zonisamide 20 mg/kg | Nervousness | | 7/71 | 10%
| Placebo | Somnolence | | 3/68 | 4%
| Zonisamide 20 mg/kg | Somnolence | | 10/71 | 14%
Sivenius (1991) | Placebo | Blurred vision | | 2/18 | 11%
| Gabapentin 900 | Blurred vision | | 1/16 | 6%
| Placebo | Depression | | 0/18 | 0%
| Gabapentin 900 | Depression | | 0/16 | 0%
| Placebo | Dizziness | | 0/18 | 0%
| Gabapentin 900 | Dizziness | | 2/16 | 13%
| Placebo | Drowsiness | | 2/18 | 11%
| Gabapentin 900 | Drowsiness | | 4/16 | 25%
Sivenius (1991) | Placebo | Eczema | | 1/18 | 6%
| Gabapentin 900 | Eczema | | 1/16 | 6%
| Placebo | Gastric irritability | | 1/18 | 6%
| Gabapentin 900 | Gastric irritability | | 1/16 | 6%
| Placebo | Headache | | 1/18 | 6%
| Gabapentin 900 | Headache | | 0/16 | 0%
| Placebo | Mania | | 1/18 | 6%
| Gabapentin 900 | Mania | | 0/16 | 0%
| Placebo | Nystagmus | | 1/18 | 6%
| Gabapentin 900 | Nystagmus | | 1/16 | 6%
| Placebo | Tremor | Mild | 1/18 | 6%
| Gabapentin 900 | Tremor | Mild | 1/16 | 6%
UKGSG (1990) | Placebo | Altered mental state | Withdrawal | 1/66 | 2%
| Placebo | Any | Any | 27/66 | 41%
| Gabapentin 1200 | Any | Any | 38/61 | 62%
| Placebo | Confusion | Withdrawal | 1/66 | 2%
| Placebo | Dizziness | | 3/66 | 4.5%
| Gabapentin 1200 | Dizziness | | 4/61 | 6.6%
| Gabapentin 1200 | Fatigue | Withdrawal | 1/61 | 2%
| Gabapentin 1200 | Fatigue | | 8/61 | 13.1%
| Placebo | General feeling of ill health | Withdrawal | 1/66 | 2%
| Placebo | Generalized seizures | Withdrawal | 1/66 | 2%
| Placebo | Headache | | 6/66 | 9.1%
| Gabapentin 1200 | Increase in seizures | Withdrawal | 1/61 | 2%
| Gabapentin 1200 | Jitteriness | Withdrawal | 1/61 | 2%
| Gabapentin 1200 | Loss of speech | Withdrawal | 1/61 | 2%
| Gabapentin 1200 | Low white blood cell count | Withdrawal | 1/61 | 2%
| Gabapentin 1200 | Rash | Withdrawal | 1/61 | 2%
| Placebo | Somnolence | | 3/66 | 4.5%
| Gabapentin 1200 | Somnolence | | 9/61 | 14.8%
| Gabapentin 1200 | Vomiting | Withdrawal | 1/61 | 2%
| Gabapentin 1200 | Weight gain | | 3/61 | 4.9%

Evidence Table 61. Quality of life outcomes and mood outcomes in studies of polytherapy

Primary Efficacy Study | Study Reporting Quality of Life | Drug And Dose (mg/day) | Quality of Life Scale | Subscale | Was Drug Better or Worse Than Baseline | Was The Difference Statistically Significant
Cereghino (2000) | Cramer (2000) | Levetiracetam 1000 or 3000 | QOLIE-31 | Seizure worry | Better | Yes
| | Levetiracetam 1000 or 3000 | QOLIE-31 | Overal quality of life | Better | Yes
| | Levetiracetam 1000 or 3000 | QOLIE-31 | Emotional well-being | Better | No
| | Levetiracetam 1000 or 3000 | QOLIE-31 | Energy-fatigue | Better | No
| | Levetiracetam 1000 or 3000 | QOLIE-31 | Cognitive functioning | Better | Yes
| | Levetiracetam 1000 or 3000 | QOLIE-31 | Medication effects | Better | No
| | Levetiracetam 1000 or 3000 | QOLIE-31 | Social function | Better | No
| | Levetiracetam 1000 or 3000 | QOLIE-31 | Health status | Better | No
| | Levetiracetam 1000 or 3000 | QOLIE-31 | Total score | Better | Yes
Uthman (1998) | Dodrill (1997) | Tiagabine 32 or 56 | Profile of Mood States | Tension-anxiety | Worse | No
| | Tiagabine 32 or 56 | Profile of Mood States | Depression-dejection | Better | No
| | Tiagabine 32 or 56 | Profile of Mood States | Anger-hostility | Worse | No
| | Tiagabine 32 or 56 | Profile of Mood States | Vigor-activity | Better | No
| | Tiagabine 32 or 56 | Profile of Mood States | Fatigue-inertia | Worse | No
| | Tiagabine 32 or 56 | Profile of Mood States | Confusion-bewilderment | Worse | No
| | Tiagabine 32 or 56 | Profile of Mood States | Total mood disturbance | Worse | No
| | Tiagabine 32 or 56 | Washington Psychosocial Seizure Inventory | Family background | Better | No
| | Tiagabine 32 or 56 | Washington Psychosocial Seizure Inventory | Emotional adjustment | Worse | No
| | Tiagabine 32 or 56 | Washington Psychosocial Seizure Inventory | Interpersonal adjustment | Worse | No
| | Tiagabine 32 or 56 | Washington Psychosocial Seizure Inventory | Vocational adjustment | Better | No
| | Tiagabine 32 or 56 | Washington Psychosocial Seizure Inventory | Financial status | Worse | No
| | Tiagabine 32 or 56 | Washington Psychosocial Seizure Inventory | Adjustment to seizures | Better | No
| | Tiagabine 32 or 56 | Washington Psychosocial Seizure Inventory | Medicine and medical management | Worse | No
| | Tiagabine 32 or 56 | Washington Psychosocial Seizure Inventory | Overall functioning | Better | No
| | Tiagabine 32 or 56 | Washington Psychosocial Seizure Inventory | Lie Scale | Better | No
| | Tiagabine 32 or 56 | Washington Psychosocial Seizure Inventory | Rare Items | Better | No
| | Tiagabine 32 or 56 | Mood Rating Scale | Mood Rating Scale | Better | No

QOLIE-31 Quality of life in epilepsy, 31 item scale to measure quality of life

Evidence Table 62. Cognitive function outcomes in studies of polytherapy

Primary Efficacy Study | Study Reporting Quality of Life | Drug And Dose (mg/day) | Functional Status/Ability Scale | Subscale | Was Drug Better or Worse Than Baseline | Was The Difference Statistically Significant
Uthman (1998) | Dodrill (1997) | Tiagabine 32 or 56 | Lafayette Grooved Pegboard | Preferred hand | Better | No
| | Tiagabine 32 or 56 | Lafayette Grooved Pegboard | Nonpreferred hand | Worse | No
| | Tiagabine 32 or 56 | Stroop Test | Reading speed | Better
| | Tiagabine 32 or 56 | Stroop Test | Reading speed, errors | Better | No
| | Tiagabine 32 or 56 | Stroop Test | Interference | Better | No
| | Tiagabine 32 or 56 | Stroop Test | Interference, errors | Worse | No
| | Tiagabine 32 or 56 | Benton Visual Retention Test | Form F | Worse | Yes
| | Tiagabine 32 or 56 | Benton Visual Retention Test | Form G | Worse | No
| | Tiagabine 32 or 56 | Controlled Oral Word Association Test | Controlled Oral Word Association Test | Worse | No
| | Tiagabine 32 or 56 | Symbol Digit Modalities Test | Symbol Digit Modalities Test | Worse | No
| | Tiagabine 32 or 56 | Rey Auditory Verbal Learning Test | Trial 1‐5, first list recall | Better | No
| | Tiagabine 32 or 56 | Rey Auditory Verbal Learning Test | Trial 6, second list recall | Better | No
| | Tiagabine 32 or 56 | Rey Auditory Verbal Learning Test | Trial 7, first list recall | Better | No
| | Tiagabine 32 or 56 | Rey Auditory Verbal Learning Test | Trial 8, first delay recall | Better | No
| | Tiagabine 32 or 56 | Rey Auditory Verbal Learning Test | Trial 9, first delay recognition | Worse | No
| | Tiagabine 32 or 56 | Wonderlic Personnel Test | Items correct | Better | No
| | Tiagabine 32 or 56 | Wonderlic Personnel Test | Items wrong | Better | No
| | Tiagabine 32 or 56 | Digit Cancellation | Number right | Worse | No
| | Tiagabine 32 or 56 | Digit Cancellation | Number omitted | Better | No

Evidence Table 63. Meta-analysis of seizure freedom in trials of polytherapy, high dose groups

Reference | N | Cohen's h (CI)a | p-value | Standardized Residual | Outlier by Standardized Residual | Greatest Outlier by Q
Faught (2001) | 203 | 0.15 (-0.13 to 0.43) | 0.3 | -1.02 | No | NA
Ben-Menachem (2000) | 286 | 0.37 (0.13 to 0.61) | 0 | 0.72 | No | NA
Betts (2000) | 77 | 0.14 (-0.31 to 0.59) | 0.54 | -0.64 | No | NA
Cereghino (2000) | 196 | 0.57 (0.29 to 0.85) | 0 | 2.09 | Yes | NA
Glauser(2000) | 267 | 0.21 (-0.03 to 0.45) | 0.09 | -0.68 | No | NA
Appleton (1999) | 247 | 0.14 (-0.11 to 0.39) | 0.27 | -1.19 | No | NA
Biton (1999) | 80 | 0.46 (0.02 to 0.9) | 0.04 | 0.78 | No | NA
Elterman (1999) | 86 | 0.45 (0.02 to 0.87) | 0.04 | 0.76 | No | NA
KTSG (1999) | 177 | 0.35 (0.05 to 0.64) | 0.02 | 0.42 | No | NA
Sachdeo (1999) | 98 | 0.29 (-0.11 to 0.69) | 0.15 | 0.02 | No | NA
Sharief (1996) | 47 | 0.6 (0.03 to 1.17) | 0.04 | 1.09 | No | NA
Tassinari (1996) | 60 | 0 (-0.51 to 0.51) | 1 | -1.12 | No | NA
Willmore (1996) | 147 | 0.33 (0 to 0.65) | 0.05 | 0.26 | No | NA
FSG (1993) | 73 | 0 (-0.46 to 0.46) | 1 | -1.24 | No | NA
Matsuo (1993) | 145 | 0.3 (-0.03 to 0.62) | 0.07 | 0.08 | No | NA
Schmidt (1993) | 139 | 0.24 (-0.1 to 0.57) | 0.16 | -0.3 | No | NA
Random Effects Summary Effect Size (Cohen's h) | | | 0.29 (0.20 to 0.37) | 0.000000

a A positive effect size indicates that the drug treatment was beneficial: patients who received an add-on drug were more likely to become seizure free than patients who received a placebo.

NA Not applicable

Evidence Table 64. Meta-analysis of seizure freedom in trials of polytherapy, high dose groups

Reference | N | Cohen's h (CI)^a^ | p-value | Standardized Residual | Outlier by Standardized Residual | Greatest Outlier by Q
Faught (2001) | 203 | 0.15 (-0.13 to 0.43) | 0.3 | -0.97 | No | NA
Ben-Menachem (2000) | 286 | 0.37 (0.13 to 0.61) | 0 | 0.78 | No | NA
Betts (2000) | 81 | 0.31 (-0.13 to 0.74) | 0.17 | 0.12 | No | NA
Cereghino (2000) | 193 | 0.35 (0.07 to 0.63) | 0.01 | 0.53 | No | NA
Glauser (2000) | 267 | 0.21 (-0.03 to 0.45) | 0.09 | -0.62 | No | NA
Appleton (1999) | 247 | 0.14 (-0.11 to 0.39) | 0.27 | -1.14 | No | NA
Biton (1999) | 80 | 0.46 (0.02 to 0.9) | 0.04 | 0.81 | No | NA
Elterman (1999) | 86 | 0.45 (0.02 to 0.87) | 0.04 | 0.79 | No | NA
KTSG (1999) | 177 | 0.35 (0.05 to 0.64) | 0.02 | 0.47 | No | NA
Sachdeo (1999) | 98 | 0.29 (-0.11 to 0.69) | 0.15 | 0.06 | No | NA
Sharief (1996) | 47 | 0.6 (0.03 to 1.17) | 0.04 | 1.11 | No | NA
Tassinari (1996) | 60 | 0 (-0.51 to 0.51) | 1 | -1.09 | No | NA
Willmore (1996) | 147 | 0.33 (0 to 0.65) | 0.05 | 0.3 | No | NA
FSG (1993) | 73 | 0 (-0.46 to 0.46) | 1 | -1.21 | No | NA
Matsuo (1993) | 144 | 0.4 (0.08 to 0.73) | 0.02 | 0.78 | No | NA
Schmidt (1993) | 139 | 0.24 (-0.1 to 0.57) | 0.16 | -0.26 | No | NA
Random Effects Summary Effect Size (Cohen's h) | | | 0.28 (0.20 to 0.36) | 0.000000

a A positive effect size indicates that the drug treatment was beneficial: patients who received an add-on drug were more likely to become seizure free than patients who received a placebo.

NA Not applicable

Evidence Table 65. Sensitivity analyses of seizure freedom in trials of polytherapy, high dose groups

Trials Included in Sensitivity Analysis | Trials Removed | Random Effects Summary Effect Size^a^(CI) | P value
All trials included | | 0.29 (0.20 to 0.37) | 0.000000
Largest effect size | Sharief (1996) | 0.28 (0.20 to 0.36) | 0.000000
Smallest effect size | Felbamate Study Group (1993) | 0.29 (0.21 to 0.38) | 0.000000
Largest sample size | Ben-Menachem (2000) | 0.27 (0.19 to 0.36) | 0.000000
Smallest sample size | Tassinari (1996) | 0.28 (0.20 to 0.36) | 0.000000

a The effect size was Cohen's h. A positive effect size indicates that patients who received an add-on drug were more likely to become seizure free than patients who received a placebo.

Evidence Table 66. Sensitivity analyses of seizure freedom in trials of polytherapy, low dose groups

Trials Included in Sensitivity Analysis | Trials Removed | Random Effects Summary Effect Size^a^(CI) | P value
All trials included | | 0.28 (0.20 to 0.36) | 0.000000
Largest effect size | Sharief (1996) | 0.27 (0.19 to 0.35) | 0.000000
Smallest effect size | Felbamate Study Group (1993) | 0.29 (0.20 to 0.37) | 0.000000
Largest sample size | Ben-Menachem (2000) | 0.27 (0.18 to 0.35) | 0.000000
Smallest sample size | Tassinari (1996) | 0.27 (0.19 to 0.35) | 0.000000

a The effect size was Cohen's h. A positive effect size indicates that patients who received an add-on drug were more likely to become seizure free than patients who received a placebo.

Evidence Table 67. Meta-analysis of 50% reduction in trials of polytherapy, high dose groups

Reference | N | Cohen's h (CI)^a^ | p-value | Standardized Residual | Outlier by Standardized Residual | Greatest Outlier by Q
Faught (2001) | 203 | 0.36 (0.08 to 0.64) | 0.01 | -1.03 | No | No
Ben-Menachem (2000) | 286 | 0.54 (0.3 to 0.78) | 0 | 0.26 | No | No
Betts (2000) | 77 | 0.22 (-0.23 to 0.67) | 0.33 | -1.27 | No | No
Cereghino (2000) | 196 | 0.81 (0.53 to 1.09) | 0 | 2.2 | Yes | No
Glauser (2000) | 267 | 0.4 (0.16 to 0.64) | 0 | -0.93 | No | No
Appleton (1999) | 247 | 0.1 (-0.15 to 0.35) | 0.44 | -3.33 | Yes | No
Biton (1999) | 80 | 0.64 (0.2 to 1.08) | 0 | 0.61 | No | No
Duchowny (1999) | 199 | 0.34 (0.07 to 0.62) | 0.02 | -1.17 | No | No
Elterman (1999) | 86 | 0.42 (0 to 0.85) | 0.05 | -0.39 | No | No
KTSG (1999) | 177 | 0.83 (0.53 to 1.12) | 0 | 2.2 | Yes | No
Sachdeo (1999) | 98 | 0.61 (0.22 to 1.01) | 0 | 0.53 | No | No
Uthman (1998) | 145 | 0.71 (0.38 to 1.05) | 0 | 1.24 | No | No
Sachdeo (1997b) | 213 | 0.57 (0.3 to 0.84) | 0 | 0.46 | No | No
Ben-Menachem (1996) | 56 | 1.43 (0.9 to 1.95) | 0 | 3.47 | Yes | Yes
Chadwick (1996) | 97 | 0.24 (-0.16 to 0.64) | 0.25 | -1.31 | No | No
Faught (1996) | 91 | 0.61 (0.2 to 1.02) | 0 | 0.52 | No | No
Privitera (1996) | 94 | 0.74 (0.34 to 1.15) | 0 | 1.16 | No | No
Sharief (1996) | 47 | 0.68 (0.1 to 1.25) | 0.02 | 0.59 | No | No
Tassinari (1996) | 60 | 0.86 (0.35 to 1.37) | 0 | 1.38 | No | No
Willmore (1996) | 147 | 0.49 (0.17 to 0.81) | 0 | -0.09 | No | No
Anhut (1994) | 161 | 0.48 (0.15 to 0.81) | 0 | -0.19 | No | No
FSG (1993) | 71 | 0.88 (0.42 to 1.35) | 0 | 1.59 | No | No
Matsuo (1993) | 145 | 0.28 (-0.05 to 0.6) | 0.1 | -1.42 | No | No
McLean (1993) | 152 | 0.49 (0.16 to 0.82) | 0 | -0.1 | No | No
Schmidt (1993) | 139 | 0.52 (0.18 to 0.85) | 0 | 0.06 | No | No
Sivenius (1991) | 34 | -0.12 (-0.79 to 0.56) | 0.73 | -1.83 | No | No
UKGSG (1990) | 127 | 0.35 (0 to 0.7) | 0.05 | -0.91 | No | No
Random Effects Summary Effect Size (Cohen's h) | | | 0.52 (0.43 to 0.62) | 0.000000

a A positive effect size indicates that the drug treatment was beneficial: patients who received an add-on drug were more likely to experience 50% reduction than patients who received a placebo.

NA Not applicable

Evidence Table 68. Meta-analysis of 50% reduction in trials of polytherapy, low dose groups

Reference | N | Cohen's h (CI)^a^ | p-value | Standardized Residual | Outlier by Standardized Residual | Greatest Outlier by Q
Faught (2001) | 203 | 0.36 (0.08 to 0.64) | 0.01 | -0.51 | No | No
Ben-Menachem (2000) | 286 | 0.54 (0.3 to 0.78) | 0 | 0.87 | No | No
Betts (2000) | 81 | 0.45 (0.01 to 0.88) | 0.04 | 0.06 | No | No
Cereghino (2000) | 193 | 0.53 (0.25 to 0.81) | 0 | 0.71 | No | No
Glauser (2000) | 267 | 0.4 (0.16 to 0.64) | 0 | -0.31 | No | No
Appleton (1999) | 247 | 0.1 (-0.15 to 0.35) | 0.44 | -2.73 | Yes | No
Biton (1999) | 80 | 0.64 (0.2 to 1.08) | 0 | 0.94 | No | No
Duchowny (1999) | 199 | 0.34 (0.07 to 0.62) | 0.02 | -0.64 | No | No
Elterman (1999) | 86 | 0.42 (0 to 0.85) | 0.05 | -0.05 | No | No
KTSG (1999) | 177 | 0.83 (0.53 to 1.12) | 0 | 2.69 | Yes | No
Sachdeo (1999) | 98 | 0.61 (0.22 to 1.01) | 0 | 0.9 | No | No
Uthman (1998) | 151 | 0.16 (-0.17 to 0.48) | 0.35 | -1.71 | No | No
Sachdeo (1997b) | 212 | 0.44 (0.17 to 0.71) | 0 | 0.07 | No | No
Ben-Menachem (1996) | 56 | 1.43 (0.9 to 1.95) | 0 | 3.75 | Yes | Yes
Chadwick (1996) | 97 | 0.24 (-0.16 to 0.64) | 0.25 | -0.95 | No | No
Faught (1996) | 90 | 0.21 (-0.2 to 0.63) | 0.31 | -1.05 | No | No
Privitera (1996) | 95 | 0.85 (0.45 to 1.26) | 0 | 2.07 | Yes | No
Sharief (1996) | 47 | 0.68 (0.1 to 1.25) | 0.02 | 0.84 | No | No
Tassinari (1996) | 60 | 0.86 (0.35 to 1.37) | 0 | 1.67 | No | No
Willmore (1996) | 147 | 0.49 (0.17 to 0.81) | 0 | 0.36 | No | No
Anhut (1994) | 220 | 0.31 (0.04 to 0.57) | 0.02 | -0.96 | No | No
FSG (1993) | 71 | 0.88 (0.42 to 1.35) | 0 | 1.9 | No | No
Matsuo (1993) | 144 | 0.05 (-0.28 to 0.38) | 0.77 | -2.35 | Yes | No
McLean (1993) | 151 | 0.27 (-0.06 to 0.6) | 0.11 | -0.98 | No | No
Schmidt (1993) | 139 | 0.52 (0.18 to 0.85) | 0 | 0.5 | No | No
Sivenius (1991) | 34 | -0.12 (-0.79 to 0.56) | 0.73 | -1.61 | No | No
UKGSG (1990) | 127 | 0.35 (0 to 0.7) | 0.05 | -0.49 | No | No
Random Effects Summary Effect Size (Cohen's h) | | | 0.45 (0.35 to 0.55) | 0.000000

a A positive effect size indicates that the drug treatment was beneficial: patients who received an add-on drug were more likely to experience 50% reduction than patients who received a placebo.

NA Not applicable

Evidence Table 69. Sensitivity analyses of 50% reduction in trials of polytherapy, high dose groups

Trials Included in Sensitivity Analysis | Trials Removed | Random Effects Summary Effect Size^a^ (CI) | P value
All trials included | | 0.52 (0.43 to 0.62) | 0.000000
Largest effect size | Ben-Menachem (1996) | 0.50 (0.41 to 0.58) | 0.000000
Smallest effect size | Sivenius (1991) | 0.53 (0.44 to 0.63) | 0.000000
Largest sample size | Ben-Menachem (2000) | 0.52 (0.42 to 0.62) | 0.000000
Smallest sample size | Sivenius (1991) | 0.53 (0.44 to 0.63) | 0.000000

a The effect size was Cohen's h. A positive effect size indicates that patients who received add-on drug were more likely to experience 50% or more seizure reduction than patients who received add-on placebo.

Evidence Table 70. Sensitivity analyses of 50% reduction in trials of polytherapy, low dose groups

Trials Included in Sensitivity Analysis | Trials Removed | Random Effects Summary Effect Size^a^ (CI) | P value
All trials included | | 0.45 (0.35 to 0.55) | 0.000000
Largest effect size | Ben-Menachem (1996) | 0.43 (0.34 to 0.52) | 0.000000
Smallest effect size | Sivenius (1991) | 0.46 (0.36 to 0.56) | 0.000000
Largest sample size | Ben-Menachem (2000) | 0.45 (0.35 to 0.55) | 0.000000
Smallest sample size | Sivenius (1991) | 0.46 (0.36 to 0.56) | 0.000000

a The effect size was Cohen's h. A positive effect size indicates that patients who received add-on drug were more likely to experience 50% or more seizure reduction than patients who received add-on placebo.

Evidence Table 71. Meta-analysis of any reduction in trials of polytherapy, high dose groups

Reference | N | Cohen's h (CI)^a^ | P-value | Standardized Residual | Outlier by Standardized Residual | Greatest Outlier by Q
Anhut (1994) | 161 | 0.54 (0.21 to 0.87) | 0 | 1.13 | No | NA
McLean (1993) | 152 | 0.47 (0.14 to 0.8) | 0.01 | 0.63 | No | NA
Schmidt (1993) | 139 | 0.39 (0.06 to 0.72) | 0.02 | 0.08 | No | NA
Sivenius (1991) | 34 | -0.21 (-0.88 to 0.47) | 0.55 | -1.76 | No | NA
UKGSG (1990) | 127 | 0.23 (-0.11 to 0.58) | 0.19 | -0.91 | No | NA
Random Effects Summary Effect Size (Cohens'h) | | | 0.37 (0.19 to 0.55) | 0.000061

a A positive effect size indicates that the drug treatment was beneficial: patients who received an add-on drug were more likely to experienced seizure reductions than patients who received add-on placebo.

NA Not applicable

Evidence Table 72. Meta-analysis of any reduction in trials of polytherapy, low dose groups

Reference | N | Cohen's h (CI)^a^ | p-value | Standardized Residual | Outlier by Standardized Residual | Greatest Outlier by Q
Anhut (1994) | 220 | 0.46 (0.2 to 0.73) | 0 | 1.35 | No | NA
McLean (1993) | 151 | 0.2 (-0.13 to 0.54) | 0.23 | -0.74 | No | NA
Schmidt (1993) | 139 | 0.39 (0.06 to 0.72) | 0.02 | 0.51 | No | NA
Sivenius (1991) | 34 | -0.21 (-0.88 to 0.47) | 0.55 | -1.56 | No | NA
UKGSG (1990) | 127 | 0.23 (-0.11 to 0.58) | 0.19 | -0.5 | No | NA
Random Effects Summary Effect Size (Cohens'h) | | | 0.31 (0.15 to 0.47) | 0.000162

a A positive effect size indicates that the drug treatment was beneficial: patients who received an add-on drug were more likely to experienced seizure reductions than patients who received add-on placebo.

NA Not applicable

Evidence Table 73. Sensitivity analyses of any reduction in trials of polytherapy, high dose groups

Trials Included in Sensitivity Analysis | Trials Removed | Random Effects Summary Effect Size^a^ (CI) | P value
All trials included | | 0.37 (0.19 to 0.55) | 0.000061
Largest effect size | Anhut (1994) | 0.32 (0.11 to 0.52) | 0.002667
Smallest effect size | Sivenius (1991) | 0.41 (0.25 to 0.58) | 0.000001
Largest sample size | Anhut (1994) | 0.32 (0.11 to 0.52) | 0.002667
Smallest sample size | Sivenius (1991) | 0.41 (0.25 to 0.58) | 0.000001

a The effect size was Cohen's h. A positive effect size indicates that patients who received add-on drug were more likely to experience any seizure reduction than patients who received add-on placebo.

Evidence Table 74. Sensitivity analyses of any reduction in trials of polytherapy, low dose groups

Trials Included in Sensitivity Analysis | Trials Removed | Random Effects Summary Effect Size^a^ (CI) | P value
All trials included | | 0.31 (0.15 to 0.47) | 0.000162
Largest effect size | Anhut (1994) | 0.24 (0.05 to 0.43) | 0.012211
Smallest effect size | Sivenius (1991) | 0.34 (0.19 to 0.5) | 0.000019
Largest sample size | Anhut (1994) | 0.24 (0.05 to 0.43) | 0.012211
Smallest sample size | Sivenius (1991) | 0.34 (0.19 to 0.5) | 0.000019

a The effect size was Cohen's h. A positive effect size indicates that patients who received add-on drug were more likely to experience any seizure reduction than patients who received add-on placebo.

Evidence Table 75. Meta-analysis of any increase in trials of polytherapy, high dose groups

Reference | N | Cohen's h (CI)^a^ | p-value | Standardized Residual | Outlier by Standardized Residual | Greatest Outlier by Q
Appleton (1999) | 247 | 0.36 (0.11 to 0.61) | 0 | -0.21 | No | NA
Anhut (1994) | 161 | 0.45 (0.12 to 0.78) | 0.01 | 0.44 | No | NA
McLean (1993) | 152 | 0.45 (0.12 to 0.79) | 0.01 | 0.48 | No | NA
Sivenius (1991) | 34 | -0.21 (-0.88 to 0.47) | 0.55 | -1.76 | No | NA
UKGSG (1990) | 127 | 0.43 (0.08 to 0.78) | 0.02 | 0.29 | No | NA
Random Effects Summary Effect Size (Cohen's h) | | | 0.38 (0.23 to 0.53) | 0.000001

a A positive effect size indicates that the drug treatment was beneficial: patients who received an add-on drug were less likely to experience seizure increases than patients who received add-on placebo.

NA Not applicable

Evidence Table 76. Meta-analysis of any increase in trials of polytherapy, low dose groups

Reference | N | Cohen's h (CI)^a^ | p-value | Standardized Residual | Outlier by Standardized Residual | Greatest Outlier by Q
Appleton (1999) | 247 | 0.36 (0.11 to 0.61) | 0 | -0.42 | No | NA
Anhut (1994) | 220 | 0.6 (0.33 to 0.86) | 0 | 1.69 | No | NA
McLean (1993) | 151 | 0.31 (-0.03 to 0.64) | 0.07 | -0.63 | No | NA
Sivenius (1991) | 34 | -0.21 (-0.88 to 0.47) | 0.55 | -1.83 | No | NA
UKGSG (1990) | 127 | 0.43 (0.08 to 0.78) | 0.02 | 0.14 | No | NA
Random Effects Summary Effect Size (Cohen's h) | | | 0.39 (0.22 to 0.57) | 0.000012

a A positive effect size indicates that the drug treatment was beneficial: patients who received an add-on drug were less likely to experience seizure increases than patients who received add-on placebo.

NA Not applicable

Evidence Table 77. Sensitivity analyses of any increase in trials of polytherapy, high dose groups

Trials Included in Sensitivity Analysis | Trials Removed | Random Effects Summary Effect Size^a^ (CI) | P value
All trials included | | 0.38 (0.23 to 0.53) | 0.000001
Largest effect size | Anhut (1994) | 0.36 (0.19 to 0.54) | 0.000042
Smallest effect size | Sivenius (1991) | 0.41 (0.26 to 0.57) | 0.000000
Largest sample size | Anhut (1994) | 0.39 (0.19 to 0.59) | 0.000127
Smallest sample size | Sivenius (1991) | 0.41 (0.26 to 0.57) | 0.000000

a The effect size was Cohen's h. A positive effect size indicates that patients who received add-on drug were less likely to experience any seizure increase than patients who received add-on placebo.

Evidence Table 78. Sensitivity analyses of any increase in trials of polytherapy, low dose groups

Trials Included in Sensitivity Analysis | Trials Removed | Random Effects Summary Effect Size^a^ (CI) | P value
All trials included | | 0.39(0.22 to 0.57) | 0.000012
Largest effect size | Anhut (1994) | 0.33 (0.16 to 0.5) | 0.000127
Smallest effect size | Sivenius (1991) | 0.43 (0.29 to 0.58) | 0.000000
Largest sample size | Anhut (1994) | 0.38 (0.14 to 0.63) | 0.002404
Smallest sample size | Sivenius (1991) | 0.43 (0.29 to 0.58) | 0.000000

a The effect size was Cohen's h. A positive effect size indicates that patients who received add-on drug were less likely to experience any seizure increase than patients who received add-on placebo.

Evidence Table 79. Meta-analysis of trial exits due to adverse effects in trials of polytherapy, high dose groups

Reference | N | Cohen's h (CI)^a^ | P-value | Standardized Residual | Outlier by Standardized Residual | Greatest Outlier by Q
Faught (2001) | 203 | -0.12 (-0.4 to 0.16) | 0.39 | 0.4 | No | No
Ben-Menachem (2000) | 286 | -0.03 (-0.27 to 0.21) | 0.81 | 1.25 | No | No
Betts (2000) | 77 | 0.06 (-0.38 to 0.51) | 0.78 | 1.06 | No | No
Cereghino (2000) | 196 | -0.07 (-0.35 to 0.21) | 0.63 | 0.77 | No | No
Glauser (2000) | 267 | -0.29 (-0.53 to -0.05) | 0.02 | -1 | No | No
Appleton (1999) | 247 | -0.15 (-0.4 to 0.1) | 0.25 | 0.25 | No | No
Biton (1999) | 80 | -0.01 (-0.45 to 0.43) | 0.97 | 0.76 | No | No
Duchowny (1999) | 199 | 0.04 (-0.24 to 0.31) | 0.8 | 1.54 | No | No
Elterman (1999) | 86 | 0.3 (-0.12 to 0.72) | 0.17 | 2.23 | Yes | No
KTSG (1999) | 177 | -0.19 (-0.48 to 0.11) | 0.22 | -0.07 | No | No
Sachdeo (1999) | 98 | 0 (-0.4 to 0.4) | 1 | 0.89 | No | No
Uthman (1998) | 148 | -0.26 (-0.59 to 0.08) | 0.13 | -0.47 | No | No
Sachdeo (1997b) | 213 | -0.2 (-0.47 to 0.07) | 0.15 | -0.16 | No | No
Ben-Menachem (1996) | 56 | -0.96 (-1.49 to -0.44) | 0 | -2.96 | Yes | Yes
Chadwick (1996) | 129 | 0.06 (-0.29 to 0.41) | 0.74 | 1.35 | No | No
Faught (1996) | 91 | -0.31 (-0.72 to 0.1) | 0.14 | -0.64 | No | No
Privitera (1996) | 94 | -0.56 (-0.96 to -0.15) | 0.01 | -1.87 | No | No
Sharief (1996) | 47 | -0.66 (-1.23 to -0.09) | 0.02 | -1.67 | No | No
Tassinari (1996) | 60 | -0.28 (-0.78 to 0.23) | 0.28 | -0.39 | No | No
Willmore (1996) | 147 | -0.28 (-0.6 to 0.05) | 0.1 | -0.61 | No | No
Anhut (1994) | 161 | -0.01 (-0.34 to 0.32) | 0.96 | 1.01 | No | No
Messenheimer (1994) | 98 | -0.35 (-0.75 to 0.04) | 0.08 | -0.89 | No | No
Bourgeois (1993) | 64 | -0.52 (-1.01 to -0.03) | 0.04 | -1.39 | No | No
FSG (1993) | 73 | 0 (-0.45 to 0.46) | 0.98 | 0.78 | No | No
Matsuo (1993) | 145 | -0.53 (-0.85 to -0.2) | 0 | -2.16 | Yes | No
McLean (1993) | 152 | -0.18 (-0.52 to 0.15) | 0.28 | -0.05 | No | No
Schmidt (1993) | 139 | -0.24 (-0.57 to 0.09) | 0.16 | -0.37 | No | No
Sivenius (1991) | 34 | 0 (-0.67 to 0.67) | 1 | 0.52 | No | No
UKGSG (1990) | 127 | -0.21 (-0.56 to 0.14) | 0.24 | -0.18 | No | No
Jawad (1989) | 24 | 0 (-0.8 to 0.8) | 1 | 0.43 | No | No
Random Effects Summary Effect Size (Cohens'h) | | | -0.18 (-0.26 to -0.11) | 0.000003

a A negative effect size indicates that the drug treatment was harmful: patients who received an add-on drug were more likely to exit studies due to adverse effects than patients who received a placebo.

NA Not applicable

Evidence Table 80. Meta-analysis of trial exits due to adverse effects in trials of polytherapy, low dose groups

Reference | N | Cohen's h (CI)a | P-value | Standardized Residual | Outlier by Standardized Residual | Greatest Outlier by Q
Faught (2001) | 203 | -0.12 (-0.4 to 0.16) | 0.39 | 0.21 | No | No
Ben-Menachem (2000) | 286 | -0.03 (-0.27 to 0.21) | 0.81 | 1.02 | No | No
Betts (2000) | 81 | -0.27 (-0.7 to 0.17) | 0.23 | -0.54 | No | No
Cereghino (2000) | 193 | -0.04 (-0.32 to 0.25) | 0.8 | 0.8 | No | No
Glauser (2000) | 267 | -0.29 (-0.53 to -0.05) | 0.02 | -1.22 | No | No
Appleton (1999) | 247 | -0.15 (-0.4 to 0.1) | 0.25 | 0.04 | No | No
Biton (1999) | 80 | -0.01 (-0.45 to 0.43) | 0.97 | 0.64 | No | No
Duchowny (1999) | 199 | 0.04 (-0.24 to 0.31) | 0.8 | 1.35 | No | No
Elterman (1999) | 86 | 0.3 (-0.12 to 0.72) | 0.17 | 2.1 | Yes | No
KTSG (1999) | 177 | -0.19 (-0.48 to 0.11) | 0.22 | -0.25 | No | No
Sachdeo (1999) | 98 | 0 (-0.4 to 0.4) | 1 | 0.75 | No | No
Uthman (1998) | 152 | 0.04 (-0.28 to 0.37) | 0.79 | 1.2 | No | No
Sachdeo (1997b) | 212 | -0.04 (-0.31 to 0.23) | 0.76 | 0.81 | No | No
Ben-Menachem (1996) | 56 | -0.96 (-1.49 to -0.44) | 0 | -3.06 | Yes | Yes
Chadwick (1996) | 129 | 0.06 (-0.29 to 0.41) | 0.74 | 1.2 | No | No
Faught (1996) | 90 | 0.21 (-0.21 to 0.62) | 0.33 | 1.71 | No | No
Privitera (1996) | 95 | -0.66 (-1.06 to -0.25) | 0 | -2.49 | Yes | No
Sharief (1996) | 47 | -0.66 (-1.23 to -0.09) | 0.02 | -1.76 | No | No
Tassinari (1996) | 60 | -0.28 (-0.78 to 0.23) | 0.28 | -0.49 | No | No
Willmore (1996) | 147 | -0.28 (-0.6 to 0.05) | 0.1 | -0.78 | No | No
Anhut (1994) | 220 | -0.19 (-0.46 to 0.07) | 0.15 | -0.32 | No | No
Messenheimer (1994) | 98 | -0.35 (-0.75 to 0.04) | 0.08 | -1.02 | No | No
Bourgeois (1993) | 64 | -0.52 (-1.01 to -0.03) | 0.04 | -1.5 | No | No
FSG (1993) | 73 | 0 (-0.45 to 0.46) | 0.98 | 0.67 | No | No
Matsuo (1993) | 144 | -0.18 (-0.51 to 0.15) | 0.28 | -0.18 | No | No
McLean (1993) | 151 | -0.28 (-0.61 to 0.06) | 0.1 | -0.76 | No | No
Schmidt (1993) | 139 | -0.24 (-0.57 to 0.09) | 0.16 | -0.53 | No | No
Sivenius (1991) | 34 | 0 (-0.67 to 0.67) | 1 | 0.44 | No | No
UKGSG (1990) | 127 | -0.21 (-0.56 to 0.14) | 0.24 | -0.33 | No | No
Jawad (1989) | 24 | 0 (-0.8 to 0.8) | 1 | 0.37 | No | No
Random Effects Summary Effect Size (Cohens'h) | | -0.16 (-0.23 to -0.08) | 0.000066

a A negative effect size indicates that the drug treatment was harmful: patients who received an add-on drug were more likely to exit studies due to adverse effects than patients who received a placebo.

NA Not applicable

Evidence Table 81. Sensitivity analyses of trial exits due to adverse effects in trials of polytherapy, high dose groups

Trials Included in Sensitivity Analysis | Trials Removed | Random Effects Summary Effect Size^a^ (CI) | P value
All trials included | | -0.18 (-0.26 to -0.11) | 0.000003
Largest effect size | Ben-Menachem (1996) | -0.17 (-0.23 to -0.10) | 0.000002
Smallest effect size | Elterman (1999) | -0.19 (-0.27 to -0.12) | 0.000000
Largest sample size | Ben-Menachem (2000) | -0.19 (-0.27 to -0.11) | 0.000002
Smallest sample size | Jawad (1989) | -0.18 (-0.26 to -0.11) | 0.000003

a The effect size was Cohen's h. A negative effect size indicates that patients who received add-on drug were more likely to exit trials due to adverse effects than patients who received add-on placebo.

Evidence table 82. Sensitivity analyses of trial exits due to adverse effects in trials of polytherapy, low dose groups

Trials Included in Sensitivity Analysis | Trials Removed | Random Effects Summary Effect Size^a^ (CI) | P value
All trials included | | -0.16 (-0.23 to -0.08) | 0.000066
Largest effect size | Ben-Menachem (1996) | -0.14 (-0.21 to -0.07) | 0.000056
Smallest effect size | Elterman (1999) | -0.17 (-0.24 to -0.09) | 0.000011
Largest sample size | Ben-Menachem (2000) | -0.16 (-0.24 to -0.08) | 0.000057
Smallest sample size | Jawad (1989) | -0.16 (-0.24 to -0.08) | 0.000073

a The effect size was Cohen's h. A negative effect size indicates that patients who received add-on drug were more likely to exit trials due to adverse effects than patients who received add-on placebo.

Evidence Table 83. Scales used to measure quality of life in trials of polytherapy

Reference | Corresponding Primary Efficacy Trial | Drug | Scales Used to Measure Quality of Life | Total Number of Subscales
Cramer (2000)] | Cereghino (2000) | Levetiracetam | Quality of Life in Epilepsy-31 | 9
| | | Seizure worry
| | | Overall quality of life
| | | Emotional well-being
| | | Energy-fatigue
| | | Cognitive functioning
| | | Social function
| | | Health status
| | | Total score
Dodrill (1997) | Uthman (1998) | Tiagabine | Washington Psychosocial Seizure Inventory | 10
| | | Family background
| | | Emotional adjustment
| | | Interpersonal adjustment
| | | Vocational adjustment
| | | Financial status
| | | Adjustment to seizures
| | | Medicine and medical management
| | | Overall functioning
| | | Lie scale
| | | Rare items

Evidence Table 84. Scales used to measure mood in trials of polytherapy

Reference | Corresponding Primary Efficacy Trial | Drug | Scales Used to Measure Mood | Total Number of Subscales
Dodrill (1997) | Uthman (1998) | Tiagabine | Profile of Mood States | 8
| | | Tension-anxiety
| | | Depression-dejection
| | | Anger-hostility
| | | Vigor-activity
| | | Fatigue-inertia
| | | Confusion-bewilderment
| | | Total mood disturbance
| | | Mood Rating Scale

Evidence Table 85. Scales used to measure cognitive function in trials of polytherapy

Reference | Corresponding Primary Efficacy Trial | Drug | Scales Used to Measure Cognitive Function | Total Number of Subscales
Dodrill (1997) | Uthman (1998) | Tiagabine | Lafayette Grooved Pegboard | 19
| | | Preferred hand
| | | Nonpreferred hand
| | | Stroop Test
| | | Reading speed
| | | Reading speed, errors
| | | Interference
| | | Interference, errors
| | | Benton Visual Retention Test
| | | Form F
| | | Form G
| | | Controlled Oral Word Association Test
| | | Symbol Digit Modalities Test
| | | Rey Auditory Verbal Learning Test
| | | Trial 1–5, first list recall
| | | Trial 6, second list recall
| | | Trial 7, first list recall
| | | Trial 8, first delay recall
| | | Trial 9, first delay recognition
| | | Wonderlic Personnel Test
| | | Items correct
| | | items wrong
| | | Digit Cancellation
| | | Number right
| | | Number omitted

Evidence Table 86. Mortality results in trials of polytherapy

Reference | Drug | Dose(s) (mg/day) | Mortality Prior to Randomization | Mortality in Placebo Group | Mortality in Group With Lowest Dose | Mortality in Group With Next Higher Dose | Mortality in Group With Highest Dose
Cereghino (2000) | Levetiracetam | 1000, 3000 | 1/295 (0.3%) | 1/95 (1%) | NR | NR | NA
Glauser (2000) | Oxcarbazepine | 1800 | 0/267 (0%) | NR | 1/138 (1%) | NA | NA
Appleton (1999) | Gabapentin | 1800 | 0/247 (0%) | 0/128 (0%) | 0/119 (0%) | NA | NA
Elterman (1999) | Topiramate | 400 | 0/86 (0%) | 0/45 (0%) | 0/41 (0%) | NA | NA
Ben-Menachem (1996) | Topiramate | 800 | 0/56 (0%) | 0/28 (0%) | 0/28 (0%) | NA | NA
Chadwick (1996) | Gabapentin | 1200 | 0/129 (0%) | 0/71 (0%) | 1/58 (2%) | NA | NA
Faught (1996) | Topiramate | 200, 400, 600 | 0/90 (0%) | 0/45 (0%) | 0/45 (0%) | 0/45 (0%) | 0/46 (0%)
Privitera (1996) | Topiramate | 600, 800, 1000 | 0/95 (0%) | 0/47 (0%) | 0/48 (0%) | 0/48 (0%) | 0/47 (0%)
Anhut (1994) | Gabapentin | 900 | 0/272 (0%) | NR | 1/111 (1%) | NR | NA

mg/day milligrams per day

NA Not applicable

Evidence Table 87. Studies of optimized current therapy that met the inclusion criteria

| | Optimization Strategy
Reference | Country | Maximum Tolerable Dose | Drug Reduction | Changing Dosing Frequency
Semah (1994) | France | ✓
Mirza (1993) | United States | | ✓
May (1992) | Germany | | ✓
Duncan (1990) | United Kingdom | | ✓
Ryan (1990) | United Kingdom | | | ✓
Specht (1989) | Germany | | ✓
Callaghan (1984) | United Kingdom | | ✓
Armour (1988) | United Kingdom | | ✓
Schmidt (1983a) | Germany | ✓
Schmidt (1983b) | Germany | | ✓
Thompson (1982) | United Kingdom | | ✓
Total number of studies | | 2 | 8 | 1

Evidence Table 88. Excluded articles examining drug optimization strategies

Reference | Reason for exclusion
Armour (1988) | Baseline seizure rates for five patients indicated that they were so well controlled that “no improvement would be detected in the followup period.” As a result, investigators abandoned 3 month baseline period and instead obtained baseline seizure frequency data from historical seizure records. Each subjects baseline seizure frequency was changed to consist of the period of time from the last recorded dose change until the initiation of drug withdrawal. This period of time “varied considerably between subjects so the strict statistical basis of the study was weakened.” This approach resulted in the seizure frequency for the five pateints with low seizure rates to appear to be higher than they actually were during the original 3 month baseline period, thus biasing the study.

Evidence Table 89. General information of studies of optimized current therapy

Reference | Author Affiliation | Country | Multicenter | For-Profit Funding | Phrase Used to Describe Patients | Minimum Number of AEDs | Minimum Monthly Seizure Frequency | Minimum Duration of Condition | Side Effects in The Definition of Treatment-Resistant Epilepsy
Studies of drug reduction
Mirza (1993) | Bowman Gray School of Medicine | United States | No | Yes | Uncontrolled seizures, active generalized convulsive seizures, the use of 4 or more AEDs | 4 | NR | NR | No
May (1992) | Gesellschaft fur Epilepsieforschung | Germany | No | No | Therapy resistant, different types of epilepsy, the effectiveness of phenytoin was questionable | 2 | NR | NR | No
Duncan (1990) | Institute of Neurology | United Kingdom | No | Yes | Patients with severe active epilepsy | 2 | NR | NR | No
Specht (1989) | Epilepsie-Zentrum Bethel | Germany | No | No | Children with difficult-to-treat epilepsies | 2 | NR | NR | Yes
Callaghan (1984) | Cork Regional Hospital | United Kingdom | No | Yes | Patients with frequent seizures while on polypharmacy | 2 | 2 | NR | No
Schmidt (1983) | Abteilung fur Neurologie | Germany | No | No | Uncontrolled complex partial seizures despite adequate two-drug treatment | 2 | NR | NR | Yes
Thompson (1982) | National Hospital for Nervous Diseases | United Kingdom | No | No | Patients on polypharmacy who underwent a reduction in the number of different anticonvulsants prescribed | 2 | NR | NR | No
Other studies of optimized current therapy
Semah (1994) | Clinique Neurologique Paul Castaigne, Hopital de la Salpetriere, Paris, France. | France | No | Yes | Uncontrolled partial seizures with or without secondary generalization | 1 | 3 | NR | No
Schmidt (1983) | Abteilung fur Neurologie, Klinikum Charlottenburg, Freie Universitat Berlin, Spandauer Damm 130, D-1000 Berlin 19 | Germany | No | No | Uncontrolled chronic epilepsy with complex partial seizures despite single drug treatment | 1 | NR | NR | No

Evidence Table 90. Design characteristics of studies of optimized current therapy

Reference | Study Reported Maximum Tolerable Dose of Prior Drugs | Required Good Compliance to Prior Drugs | All Patients Seen During Presurgical Evaluation | Patients Continued to Take Their Prestudy Drugs | Prospective | Randomized | Type of Control | Patients Received a Placebo During The Baseline | Patients Blinded | Observers Blinded | Length of Baseline (Weeks) | Length of Titration Period (Weeks) | Length of Maintenance Period (Weeks) | Plasma Levels Monitored
Studies of drug reduction
Mirza (1993) | No | No | No | No | Yes | No | None | No | No | No | 90 days | 12 to 17 months | 4 to 9 months | Yes
May (1992) | No | No | No | No | Yes | No | No change in treatment | No | No | Yes | 52 | NR | NR | Yes
Duncan (1990) | No | No | No | No | Yes | No | No change in treatment | No | Yes | Yes | 2 | 1 to 7 | 4 | Yes
Specht (1989) | No | No | No | No | Yes | No | None | No | No | No | 2 | 2 to 7 | 2 to 4 | No
Callaghan (1984) | No | No | No | No | Yes | No | None | No | No | No | 6 months | 2 weeks to 3 months | 2 years | Yes
Schmidt (1983) | Yes | Yes | No | No | Yes | No | None | No | No | No | 5 to 197 | 2 to 20 | 4 to 260 | Yes
Thompson (1982) | No | No | No | No | Yes | No | No change in treatment | No | No | Yes | 3 months | 3 months | 3 months | Yes
Other studies of optimized current therapy
Semah (1994) | No | No | No | Yes | Yes | No | None | No | No | No | 2 months | NR | 6 months | Yes
Schmidt (1983) | No | No | No | Yes | Yes | No | None | No | No | No | NR | NR | 4 to 115 | Yes

Evidence Table 91. Reporting characteristics of trials of optimized current therapy

| Reporting
Reference | Individual Patient Data | Baseline Seizure Frequency | Seizure Frequency | Adverse Effects | Quality of Life | Functional Status / Ability | Return to Work | Return to School | Seizure Types | Seizure Diaries Used
Studies of drug reduction
Mirza (1993) | No | Yes | Yes | Yes | No | No | No | No | Generalized and partial | No
May (1992) | No | Yes | No | No | No | Yes | No | No | Generalized and partial | NR
Duncan (1990) | No | Yes | Yes | Yes | Yes | Yes | No | No | Generalized and partial | Yes
Specht (1989) | Yes | Yes | Yes | Yes | No | No | No | No | Generalized and partial | No
Callaghan (1984) | No | Yes | Yes | Yes | No | Yes | No | No | Generalized and partial | NR
Schmidt (1983) | Yes | Yes | Yes | Yes | No | No | No | No | Generalized and partial | Yes
Thompson (1982) | No | Yes | Yes | No | Yes | Yes | No | No | Generalized and partial | NR
Other studies of optimized current therapy
Semah (1994) | No | No | Yes | Yes | No | No | No | No | Partial | Yes
Schmidt (1983) | No | No | Yes | No | No | No | No | No | Generalized and partial | Yes

Evidence Table 92. Treatment descriptions, numbers of patients and attrition in studies of optimized current therapy

| | Number of Patients
Reference | Description of Treatment | Started The Study | Exited Due to an Increase in Seizures | Exited Due to Adverse Effects | Exited For Other Reasons | Completed The Study | With Reported Patient Characteristics | Patient Characteristics Reported For Those Who Started or Completed The Study
Studies of drug reduction
Mirza (1993) | Withdrawal of 3 or 4 AEDs | 44 | 0 | 0 | 0 | 44 | 44 | Started
May (1992) | No change in treatment | 12 | 0 | 0 | 0 | 12 | 12 | Started
| Withdrawal of phenytoin | 17 | 0 | 0 | 0 | 17 | 17 | Started
Duncan (1990) | No change in treatment | 25 | 0 | 0 | 0 | 25 | 25 | Started
| Withdrawal of phenytoin | 23 | 0 | 0 | 1 | 22 | 23 | Started
| Withdrawal of carbamazepine | 24 | 0 | 0 | 1 | 23 | 24 | Started
| Withdrawal of valproate | 25 | 0 | 0 | 0 | 25 | 25 | Started
Specht (1989) | Withdrawal of clonazepam | 40 | 0 | 0 | 0 | 40 | 40 | Started
Callaghan (1984) | Withdrawal of up to 3 AEDs | 35 | 6 | 0 | 0 | 29 | 35 | Started
Schmidt (1983) | Withdrawal of at exactly one AED | 36 | 0 | 0 | 0 | 36 | 36 | Started
Thompson (1982) | No change in treatment | 10 | 0 | 0 | 0 | 10 | 10 | Started
| Withdrawal of at least 1 AED | 20 | 0 | 0 | 0 | 20 | 20 | Started
Semah (1994) | Increase dose of carbamazepine until either seizure control or side effects | 18 | NR | NR | NR | 7 | 18 | Started
Schmidt (1983) | Increase dose of phenytoin, carbamazepine, or phenobarbital until side effects occur | 35 | 0 | 0 | 0 | 35 | 35 | Started

a Calculated by ECRI based on reported information

Evidence Table 93. Age, gender, and duration of condition of patients in studies of optimized current therapy

| | Age | | | | | | Duration of Epilepsy
Reference | Treatment Description | Mean | SD | Minimum | Maximum | Males | Females | Mean | SD | Median
Studies of drug reduction
Mirza (1993) | Reduction | 30.2 | NR | 8 | 68 | 25 | 19 | NR | NR | 29.1^a^
May (1992) | No change | 46.3 | 13.3 | NR | NR | 8 | 4 | 40.5 | 14.2 | NR
| Reduction | 55.2 | 8.7 | NR | NR | 7 | 10 | 49.4 | 8.4 | NR
Duncan (1990) | No change | 42 | NR | 25 | 65 | 19 | 6 | NR | NR | 37
| Reduction (phenytoin) | 35 | NR | 19 | 65 | 16 | 7 | NR | NR | 25
| Reduction (carbamazepine) | 31 | NR | 19 | 59 | 17 | 7 | NR | NR | 23
| Reduction (valproate) | 25 | NR | 17 | 48 | 13 | 12 | NR | NR | 17
Specht (1989) | Reduction | 9.9 | NR | 2.4 | 22.7 | 25 | 15 | 5.75 | NR | NR
Callaghan (1984) | Reduction | 26 | NR | 6 | 24 | 25 | 10 | 18 | NR | NR
Schmidt (1983) | Reduction | 38 | 12 | 16 | 74 | NR | NR | 21 | 10 | NR
Thompson (1982) | No change | 33.5 | 15.1 | NR | NR | 2 | 8 | 19.2 | 8.7 | NR
| Reduction | 28 | 13.5 | NR | NR | 10 | 10 | 19.5 | 11.3 | NR
Other studies of optimized current therapy
Semah (1994) | Other | 28.9 | 10.2 | 18 | 65 | 9 | 9 | 17.8 | 13.1 | NR
Schmidt (1983) | Other | 36 | 10 | 20 | 59 | NR | NR | 19 | 9 | NR

a Calculated by ECRI based on reported information.

Evidence Table 94. Baseline seizure frequencies and specific types of partial seizures in studies of optimized current therapy

Reference | Treatment Description | Seizure Type For Baseline Seizure Frequency | Mean Baseline Seizure Frequency | SD of Baseline Seizure Frequency | Median Baseline Seizure Frequency
Studies of drug reduction
Mirza (1993) | Reduction | Generalized and partial | 2 day | NR | NR
May (1992) | No change | Generalized and partial | 22.8 year | 25.6 year | NR
| Reduction | Generalized and partial | 25.6 year | 25.7 year | NR
Duncan (1990) | No change | Generalized and partial | 1.6 | NR | 9.7^a^
| Reduction (phenytoin) | Generalized and partial | 2.8 | NR | 13.7^a^
| Reduction (carbamazepine) | Generalized and partial | 1.7 | NR | 12.0^a^
| Reduction (valproate) | Generalized and partial | 2.6 | NR | 17.0^a^
Specht (1989) | Reduction | Generalized and partial | 157.8^a^ | 302.0^a^ | 40.9^a^
Callaghan (1984) | Reduction | Generalized and partial | 15 | NR | NR
Schmidt (1983) | Reduction | Generalized and partial | 6.1^a^ | 12.4^a^ | 3.4^a^
Thompson (1982) | No change | Partial | 6.8 | 9.7 | NR
| Reduction | Partial | 21.1 | 34.6 | NR
Other studies of optimized current therapy
Semah (1994) | Other | NR | NR | NR | NR
Schmidt (1983) | Other | NR | NR | NR | NR

a Calculated by ECRI based on reported information

Evidence Table 95. Specific types of generalized seizures in studies of optimized current therapy

| | | Numbers of Patients
Reference | Treatment Description | Any Generalized Seizures | Tonic-Clonic | Tonic | Atonic | Myoclonic | Absence | Atypical Absence | Lennox-Gastaut Syndrome | Clonic | West Syndrome | Other Generalized
Studies of drug reduction
Mirza (1993) | Reduction | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
May (1992) | No change | NR | 3 | 0 | 0 | 0 | 2 | 0 | 0 | 0 | 0 | 0
| Reduction | NR | 5 | 0 | 0 | 0 | 6 | 0 | 0 | 0 | 0 | 0
Duncan (1990) | No change | 8 | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
| Reduction (phenytoin) | 3 | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
| Reduction (carbamazepine) | 7 | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
| Reduction (valproate) | 3 | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
Specht (1989) | Reduction | 33 | NR | NR | NR | NR | NR | NR | 19 | NR | 2 | NR
Callaghan (1984) | Reduction | 26 | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
Schmidt (1983) | Reduction | 29 | 29 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Thompson (1982) | No change | 9 | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
| Reduction | 14 | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
Other studies of optimized current therapy
Semah (1994) | Other | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Schmidt (1983) | Other | 32 | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR

Evidence Table 96. Specific types of partial seizures in studies of optimized current therapy

| | | Numbers of Patients
Reference | Treatment Description | Any Partial Seizure | Complex Partial | Simple Partial | Secondarily Generalized
Studies of drug reduction
Mirza (1993) | Reduction | NR | 8 | NR | 38
May (1992) | No change | NR | 10 | 2 | 2
| Reduction | NR | 11 | 1 | 3
Duncan (1990) | No change | 17 | NR | NR | NR
| Reduction (phenytoin) | 19 | NR | NR | NR
| Reduction (carbamazepine) | 16 | NR | NR | NR
| Reduction (valproate) | 22 | NR | NR | NR
Specht (1989) | Reduction | 11 | NR | NR | NR
Callaghan (1984) | Reduction | 9 | 5 | 4 | 9
Schmidt (1983) | Reduction | 36 | 36 | 0 | 0
Thompson (1982) | No change | 9 | NR | NR | NR
| Reduction | 16 | NR | NR | NR
Other studies of optimized current therapy
Semah (1994) | Other | 18 | NR | NR | NR
Schmidt (1983) | Other | 35 | 35 | NR | NR

Evidence Table 97. Known etiology and prior AED use in studies of optimized current therapy

| | Number of Patients
Reference | Treatment Description | With Known Etiology | On One AED Prior to The Study | On Two AEDs Prior to The Study | On Three or More AEDs Prior to The Study
Studies of drug reduction
Mirza (1993) | Reduction | NR | 0 | 0 | 44
May (1992) | No change | NR | NR | NR | NR
| Reduction | NR | NR | NR | NR
Duncan (1990) | No change | 17 | 0 | NR | NR
| Reduction (phenytoin) | 16 | 0 | NR | NR
| Reduction (carbamazepine) | 22 | 0 | NR | NR
| Reduction (valproate) | 17 | 0 | NR | NR
Specht (1989) | Reduction | NR | 0 | 18 | 22
Callaghan (1984) | Reduction | 6^a^ | 0 | 19 | 16f
Schmidt (1983) | Reduction | 22 | 0 | 36 | 0
Thompson (1982) | No change | NR | NR | NR | NR
| Reduction | NR | NR | NR | NR
Other studies of optimized current therapy
Semah (1994) | Other | NR | 5 | 12 | 1
Schmidt (1983) | Other | 20 | 35 | 0 | 0

a Calculated by ECRI based on reported information

Evidence Table 98. Prior AEDs used in studies of optimized current therapy

| | Number of Patients Receiving Specific Prior Drugs
Reference | Treatment Description | Benzodiazepam | Carbamazepine | Clonzaepam | Diazepam | Ethosuximide | Phenytoin | Phenobarbital | Primidone | Valproate
Studies of drug reduction
Mirza (1993) | Reduction | 44 | 0 | 0 | 0 | 0 | 44 | 44 | 35 | 44
May (1992) | No change | 0 | 12 | 0 | 0 | 0 | 0 | 11 | 1 | 2
| Reduction | 0 | 17 | 0 | 0 | 2 | 0 | 0 | 2 | 2
Duncan (1990) | No change | NR | NR | NR | NR | NR | NR | NR | NR | NR
| Reduction (phenytoin) | NR | NR | NR | NR | NR | 23 | NR | NR | NR
| Reduction (carbamazepine) | NR | 24 | NR | NR | NR | NR | NR | NR | NR
| Reduction (valproate) | NR | NR | NR | NR | NR | NR | NR | NR | 25
Specht (1989) | Reduction | 0 | 9 | 40 | 1 | 4 | 9 | 9 | 16 | 15
Callaghan (1984) | Reduction | 0 | >0 | >0 | 0 | >0 | >0 | >0 | >0 | >0
Schmidt (1983) | Reduction | 0 | 11 | 6 | 0 | 0 | 30 | 4 | 15 | 4
Thompson (1982) | No change | NR | NR | NR | NR | NR | NR | NR | NR | NR
| Reduction | NR | >0 | >0 | NR | NR | >0 | >0 | >0 | >0
Other studies of optimized current therapy
Semah (1994) | Other | NR | 18 | NR | NR | NR | >0 | >0 | NR | >0
Schmidt (1983) | Other | 0 | 4 | 0 | 0 | 0 | 25 | 6 | 0 | 0

a Calculated by ECRI based on reported information

>0 At least one patient had received the drug, but the study did not report the exact number of patients who received the drug.

Evidence Table 99. Outcomes in studies of optimized current therapy - changes in seizure frequency

Reference | Treatment Description | Overall Seizure Type^a^ | Specific Seizure Type^a^ | Description of Outcome | Number of Patients | Outcomeb | Dispersion
Studies of drug reduction
Mirza (1993) | Reduction | ALL | ALL | Number of patients with 50% or more reduction | 44 | 30
| Reduction | ALL | ALL | Number of patients seizure free | 44 | 14
Duncan (1990) | No change | ALL | ALL | Mean monthly seizure frequency | 22 | 2.6
| Reduction(phenytoin) | ALL | ALL | Mean monthly seizure frequency | 23 | 3.3
| Reduction(carbamazepine) | ALL | ALL | Mean monthly seizure frequency | 25 | 2.9
| Reduction(valproate) | ALL | ALL | Mean monthly seizure frequency | 25 | 2.1
Specht (1989) | Reduction | ALL | ALL | Number of patients with 50% or more reduction | 35 | 9^c^
| Reduction | ALL | ALL | Number of patients with 75% or more reduction | 35 | 4^c^
| Reduction | ALL | ALL | Number of patients with any increase in seizures | 35 | 14^c^
| Reduction | ALL | ALL | Number of patients with any reduction in seizures | 35 | 20^c^
| Reduction | ALL | ALL | Mean % reduction from baseline | 35 | -2.0^c^
| Reduction | ALL | ALL | Mean difference from baseline | 35 | 35.3^c^
| Reduction | ALL | ALL | Mean monthly seizure frequency | 35 | 122.6^c^
| Reduction | ALL | ALL | Median % reduction from baseline | 35 | 20.3^c^
| Reduction | ALL | ALL | Median difference from baseline | 35 | 2.2^c^
| Reduction | ALL | ALL | Median monthly seizure frequency | 35 | 32.3^c^
| Reduction | ALL | ALL | Number of patients seizure free | 35 | 4^c^
Callaghan (1984) | Reduction | ALL | ALL | Number of patients with 50% or more reduction | 35 | 19^c^
| Reduction | ALL | ALL | Number of patients with any increase in seizures | 35 | 3
| Reduction | ALL | ALL | Number of patients seizure free | 35 | 6
Schmidt (1983) | Reduction | ALL | ALL | Number of patients with 50% or more reduction | 36 | 8^c^
| Reduction | ALL | ALL | Number of patients with 75% or more reduction | 36 | 3^c^
| Reduction | ALL | ALL | Number of patients with any increase in seizures | 36 | 15^c^
| Reduction | ALL | ALL | Number of patients with any reduction in seizures | 36 | 21^c^
| Reduction | ALL | ALL | Mean % reduction from baseline | 36 | -107.3^c^
| Reduction | ALL | ALL | Mean difference from baseline | 36 | -0.5^c^
| Reduction | ALL | ALL | Mean monthly seizure frequency | 36 | 6.5^c^
| Reduction | ALL | ALL | Median % reduction from baseline | 36 | 11.9^c^
| Reduction | ALL | ALL | Median difference from baseline | 36 | 0.5^c^
| Reduction | ALL | ALL | Median monthly seizure frequency | 36 | 3.8^c^
| Reduction | ALL | ALL | Number of patients seizure free | 36 | 2^c^
Thompson (1982) | No change | GEN | GTC | Mean monthly seizure frequency | 9 | 0.4 | SD 1
| No change | PAR | PAR | Mean monthly seizure frequency | 9 | 9.9 | SD 12.9
| Reduction | PAR | PAR | Mean monthly seizure frequency | 16 | 18.1 | SD 35.6
| Reduction | GEN | GTC | Mean monthly seizure frequency | 14 | 3.6 | SD 3.1
Other studies of optimized current therapy
Semah (1994) | Other | PAR | PAR | Number of patients with 50% or more reduction at 2 months | 18 | 7
| Other | PAR | PAR | Number of patients with 50% or more reduction at 6 months | 18 | 3
| Other | PAR | PAR | Number of patients seizure free | 18 | 1
Schmidt (1983) | Other | ALL | ALL | Number of patients seizure free | 27 | 6

Evidence Table 99-A. Outcomes in studies of optimized current therapy - changes in mood and cognitive function (continued)

| | | | | Pretreatment | | Posttreatment
Reference | Domain | Measure | Patients in Drug Reduction Group | Patients in Control Group | Drug Reduction Arm: Mean Score (SD) | Control Arm: Mean Score (SD) | Followup Time | Drug Reduction Arm: Mean Score (SD) | Control Arm: Mean Score (SD)
May (1992) | Psychomotor function | Finger Tapping: Dominant hand | 17 | 12 | 25.8 (9.5) | 28.5 (9.0) | 10 wks | 30.3 (10.6) | 30.1 (10.4)
| | Finger tapping: Non-dominant hand | 17 | 12 | 24.8 (8.7) | 27.1 (8.4) | | 26.2 (8.0) | 27.4 (8.0)
| | Pegboard: Dominant hand | 17 | 12 | 90.1 (70.1) | 83.1 (53.1) | | 71.8 (23.7) | 71.5 (19.0)
| | Pegboard: Non-dominant hand | 17 | 12 | 89.0 (38.7) | 79.7 (29.8) | | 87.1 (42.8) | 78.0 (26.3)
| | Pursuit rotor: Failure dominant hand | 17 | 12 | 26.3 (10.1) | 22.1 (10.7) | | 23.8 (12.6) | 28.4 (20.5)
| | Pursuit rotor: Failure duration dominant hand | 17 | 12 | 153.0 (63.0) | 141.0 (74.0) | | 159.0 (66.0) | 132.0 (67.0)
| | Pursuit rotor: Failure non-dominant hand | 17 | 12 | 26.7 (12.1) | 23.7 (8.5) | | 23.1 (15.2) | 20.8 (12.2)
| | Pursuit rotor: Failure duration non-dominant hand | 17 | 12 | 161.0 (73.0) | 123.0 (61.0) | | 163.0 (74.0) | 139.0 (93.0)
| Memory | LGT-Immediate recall | 17 | 12 | 5.88 (2.76) | 7.88 (3.26) | 10 wks | 5.92 (2.11) | 6.83 (2.89)
| | LGT-Delayed recall | 17 | 12 | 4.53 (2.72) | 5.33 (3.64) | | 4.66 (2.15) | 4.42 (2.84)
| | Digit span forward | 17 | 12 | 4.88 (1.32) | 4.76 (1.92) | | 4.25 (1.14) | 4.67 (1.15)
| | Digit span backwards | 17 | 12 | 3.29 (1.21) | 3.41 (1.93) | | 3.00 (1.28) | 2.92 (1.09)
| Concentration/attention | Modified FCTC | 17 | 12 | 45.8 (16.2) | 41.1 (17.5) | 10 wks | 525.7 (16.5) | 50.9 (16.9)
| | d2-test T-F | 17 | 12 | 267.0 (102.0) | 285.0 (108.0) | | 242.0 (50.0) | 258.0 (61.0)
| | d2-test Q | 17 | 12 | 11.7 (10.2) | 9.0 (10.5) | | 10.7 (7.0) | 12.7 (6.3)
Duncan (1990) | Mental speed and conceptual processing | Digit symbol substitution test | PHT: 19 | 21 | PHT: 15 (rng: 4 to 37) | 15 (rng: 3 to 40) | 5 to 11 wks | PHT: 17 (rng: 4 to 45) | 14 (rng: 2 to 38)
| | | CBZ: 12 | | CBZ: 16 (rng: 5 to 60 | | | CBZ:16 (rng: 4 to 70)
| | | VPA: 13 | | VPA: 23 (rng: 2 to 54) | | | VPA: 25 (rng: to 56)
| Memory and concentration | Digit scan forward | PHT: 19 | 21 | PHT: 5.1 (1.2) | 5.0 (1.0) | 5 to 11 wks | PHT: 3.6 (1.1) | 3.1 (1.2)
| | | CBZ: 12 | | CBZ: 5.5 (1.6) | | | CBZ: 3.3 (1.5)
| | | VPA: 13 | | VPA: 5.4 (1.2) | | | VPA: 4.0 (1.4)
| Attention and concentration | Letter cancellation task | PHT: 19 | 21 | PHT: 57.9 (23.7) | 55.2 (24.5) | 5 to 11 wks | PHT: 65.1 (30.5) | 48.7 (24.9)
| | | CBZ: 12 | | CBZ: 62.6 (33.7) | | | CBZ: 56.4 (39.0)
| | | VPA: 13 | | VPA: 81.5 (27.9) | | | VPA: 82.9 (29.7)
| Psychomotor function | Tapping rate: Dominant hand | PHT: 19 | 21 | PHT: 47.1 (10.7) | 48.0 (13.2) | 5 to 11 wks | PHT: 51.9 (12.0) | 49.2 (14.0)
| | | CBZ: 12 | | CBZ: 50.8 (16.1) | | | CBZ: 55.5 (20.0)
| | | VPA: 13 | | VPA: 51.9 (14.0) | | | VPA: 58.5 (14.5)
| Psychomotor function | Tapping Rate: Non-dominant hand | PHT: 19 | 21 | PHT: 43.2 (8.8) | 41.5 (12.1) | 5 to 11 wks | PHT: 46.8 (9.2) | 42.0 (12.9)
| | | CBZ: 12 | | CBZ: 44.5 (16.5) | | | CBZ: 48.1 (16.6)
| | | VPA: 13 | | VPA: 44.3 (12.8) | | | VPA: 49.0 (14.4)
| Mood | MHQ-Anxiety | PHT: 19 | 21 | PHT: 6.1 (3.7) | 5.6 (4.2) | 5 to 11 wks | PHT: 4.5 (3.4) | 4.3 (3.4)
| | | CBZ: 12 | | CBZ: 4.0 (3.6) | | | CBZ: 5.5 (3.1)
| | | VPA: 13 | | VPA: 4.8 (4.0) | | | VPA: 5.0 (3.1)
| | MHQ-Phobia | PHT: 19 | 21 | PHT: 3.6 (2.5) | 3.4 (2.8) | 5 to 11 wks | PHT: 5.9 (2.6) | 8.0 (3.5)
| | | CBZ: 12 | | CBZ: 3.0 (2.9) | | | CBZ: 7.1 (3.2)
| | | VPA: 13 | | VPA: 4.2 (3.0) | | | VPA: 6.2 (3.4)
| | MHQ-Obsession | PHT: 19 | 21 | PHT: 5.9 (2.6) | 8.0 (3.5) | 5 to 11 wks | PHT: 6.6 (3.1) | 8.1 (3.7)
| | | CBZ: 12 | | CBZ: 7.1 (3.2) | | | CBZ: 8.7 (3.2)
| | | VPA: 13 | | VPA: 6.2 (3.4) | | | VPA: 7.3 (3.4)
| | MHQ-Somatic anxiety | PHT: 19 | 21 | PHT: 5.1 (2.8) | 4.4 (3.4) | 5 to 11 wks | PHT: 3.7 (2.7) | 4.0 (2.6)
| | | CBZ: 12 | | CBZ: 5.0 (2.3) | | | CBZ: 4.3 (2.4)
| | | VPA: 13 | | VPA: 5.1 (2.0) | | | VPA: 4.3 (2.4)
| | MHQ-Depression | PHT: 19 | 21 | PHT: 4.5 (2.1) | 4.7 (3.3) | 5 to 11 wks | PHT: 4.0 (2.9) | 4.8 (2.6)
| | | CBZ: 12 | | CBZ: 3.9 (2.8) | | | CBZ: 4.6 (2.4)
| | | VPA: 13 | | VPA: 2.9 (1.8) | | | VPA: 3.5 (1.6)
| | MHQ-Hysteria | PHT: 19 | 21 | PHT: 5.2 (3.4) | 5.6 (3.4) | 5 to 11 wks | PHT: 4.8 (2.3) | 5.3 (2.7)
| | | CBZ: 12 | | CBZ: 4.3 (2.3) | | | CBZ: 5.3 (3.3)
| | | VPA: 13 | | VPA: 4.6 (3.9) | | | VPA: 4.7 (2.6)
Thompson (1982) | Memory | Pictures: Immediate recall | 20 | 10 | 8.4(2.7) | 8.9 (2.1) | 6 mos | 9.8 (3.3) | 9.9 (2.7)
| | Pictures: Delayed recall | 20 | 10 | 6.2 (2.3) | 8.5 (2.4) | | 8.3 (3.0) | 8.8 (2.7)
| | Pictures: Recognition | 20 | 10 | 36.3 (3.4) | 38.1 (1.9) | | 37.1 (3.5) | 37.8 (2.2)
| Memory | Words: Immediate recall | 20 | 10 | 7.4 (2.8) | 8.2 (2.8) | 6 mos | 7.5 (2.6) | 7.2 (2.3)
| | Words: Delayed recall | 20 | 10 | 4.1 (2.3) | 4.7 (3.1) | | 5.0 (2.7) | 5.6 (2.0)
| | Words: Recognition | 20 | 10 | 33.1 (4.7) | 32.8 (3.5) | | 31.8 (4.8) | 32.7 (3.3)
| Concentration | Stroop: Naming speed (s) III-II | 20 | 10 | 40.7 (53.0) | 23.6 (23.2) | 6 mos | 20.0 (21.9) | 25.2 (21.0)
| | Stroop: Naming speed (s) errors | 20 | 10 | 3.2 (2.7) | 1.0 (1.1) | | 2.2 (1.9) | 2.2 (1.5)
| | Visual scanning speeds (s) | 20 | 10 | 120.5 (64.3) | 78.5 (20.6) | | 86.1 (36.4) | 86.8 (18.0)
| | With auditory task | 20 | 10 | 138.3 (76.7) | 91.6 (21.9) | | 94.8 (41.2) | 98.5 (24.3)
| | Total number scanned | 20 | 10 | 134.8 (46.4) | 139.7 (51.9) | | 165.4 (54.5) | 140.6 (54.9)
| | Total number errors | 20 | 10 | 9.8 (8.9) | 7.4 (6.8) | | 6.6 (5.0) | 7.1 (9.4)
| Mental speed | Perceptual speed for words | 20 | 10 | 0.098 (0.034) | 0.076 (0.015) | 6 mos | 0.077 (0.021) | 0.076 (0.013)
| | Perceptual speed for pictures | 20 | 10 | 0.091 (0.029) | 0.076 (0.018) | | 0.082 (0.024) | 0.078 (0.016)
| | Decision making for color | 20 | 10 | 1.425 (1.296) | 0.841 (0.197) | | 0.959 (0.424) | 0.838 (0.242)
| | Decision making for pictures | 20 | 10 | 1.612 (1.140) | 0.976 (0.293) | | 1.151 (0.457) | 1.032 (0.257)
| | Visuomotor response | 20 | 10 | 0.420 (0.317) | 0.405 (0.205) | | 0.366 (0.130) | 0.371 (0.152)
| Motor speed | Dominant hand | 20 | 10 | 61.3 (15.9) | 64.7 (15.1) | 6 mos | 68.5 (11.8) | 67.0 (15.2)
| | Non-dominant hand | 20 | 10 | 49.8 (16.7) | 54.0 (15.2) | | 61.6 (10.5) | 57.8 (13.5)
| | Both hands | 20 | 10 | 44.0 (15.3) | 53.0 (19.6) | | 51.2 (12.8) | 53.9 (21.2)
| Mood | MACL: Anxiety | 20 | 10 | 3.9(2.4) | 2.1(1.7) | 6 mos | 1.7(1.5) | 1.5(1.5)
| | MACL: Fatigue | 20 | 10 | 3.6(4.5) | 1.9(2.3) | | 2.1(3.9) | 2.2(1.8)
| | MACL: Activity | 20 | 10 | 4.4(4.1) | 4.0(2.5) | | 6.2(3.4) | 4.5(2.4)
| | MACL: Depression | 20 | 10 | 3.4(4.0) | 1.5(2.8) | | 2.2(4.5) | 1.1(2.6)
| | MHQ: Anxiety | 20 | 10 | 6.1(3.8) | 5.2(3.9) | | 5.1(3.3) | 4.4(2.4)
| | MHQ: Depression | 20 | 10 | 4.8(3.2) | 3.5(2.5) | | 4.2(3.6) | 3.2(2.2)
| | MHQ: Total score | 20 | 10 | 32.8(14.6) | 31.2(10.0) | | 29.4(15.4) | 26.9(6.7)

a The abbreviations used in Evidence Table 99 appear on the following page

b In the outcome column, a positive value for either median % reduction from baseline or median difference from baseline represents a beneficial reduction in seizures. This conforms to the convention in the epilepsy literature.

c Calculated by ECRI based on published information

Abbreviations used in Evidence Table 99

ALL all seizures

CPS complex partial seizures

GEN generalized seizures

GTC generalized tonic-clonic seizures

PAR partial seizures

SPS simple partial seizures

mos months

wks weeks

Evidence Table 100. Adverse effects in studies of optimized current therapy

Reference | Treatment Description | Description of Adverse Effect | Severity of Adverse Effect | Patients With This Effect / Patients in The Group | Percentage
Studies of drug reduction
Mirza (1993) | Reduction | Status epilepticus | Severe | 1/44 | 2 %
| Reduction | Transient increase in seizure frequency | | 15/44 | 34 %
Duncan (1990) | No change | Agitation, new onset | | 7/22^a^ | 32 %^a^
| Reduction (phenytoin) | Agitation, new onset | | 2/23^a^ | 9 %^a^
| Reduction (carbamazepine) | Agitation, new onset | | 3/25^a^ | 12 %^a^
| Reduction (valproate) | Agitation, new onset | | 3/25^a^ | 12 %^a^
| No change | Anorexia, new onset | | 2/22^a^ | 9 %^a^
| Reduction (phenytoin) | Anorexia, new onset | | 3/23^a^ | 13 %^a^
| Reduction (carbamazepine) | Anorexia, new onset | | 4/25^a^ | 16 %^a^
| Reduction (valproate) | Anorexia, new onset | | 2/25^a^ | 8 %^a^
| No change | Anxiety, new onset | | 3/22^a^ | 14 %^a^
| Reduction (phenytoin) | Anxiety, new onset | | 3/23^a^ | 13 %^a^
| Reduction (carbamazepine) | Anxiety, new onset | | 2/25^a^ | 8 %^a^
| Reduction (valproate) | Anxiety, new onset | | 3/25^a^ | 12 %^a^
| No change | Auditory hallucinations, new onset | | 0/22^a^ | 0 %^a^
| Reduction (phenytoin) | Auditory hallucinations, new onset | | 0/23^a^ | 0 %^a^
| Reduction (carbamazepine) | Auditory hallucinations, new onset | | 0/25^a^ | 0 %^a^
| Reduction (valproate) | Auditory hallucinations, new onset | | 0/25^a^ | 0 %^a^
| No change | Depersonalization, new onset | | 1/22^a^ | 5 %^a^
| Reduction (phenytoin) | Depersonalization, new onset | | 2/23^a^ | 9 %^a^
| Reduction (carbamazepine) | Depersonalization, new onset | | 1/25^a^ | 4 %^a^
| Reduction (valproate) | Depersonalization, new onset | | 0/25^a^ | 0 %^a^
| No change | Depression, new onset | | 6/22^a^ | 27 %^a^
| Reduction (phenytoin) | Depression, new onset | | 5/23^a^ | 22 %^a^
| Reduction (carbamazepine) | Depression, new onset | | 1/25^a^ | 4 %^a^
| Reduction (valproate) | Depression, new onset | | 5/25^a^ | 20 %^a^
| No change | Derealisation, new onset | | 1/22^a^ | 5 %^a^
| Reduction (phenytoin) | Derealisation, new onset | | 0/23^a^ | 0 %^a^
| Reduction (carbamazepine) | Derealisation, new onset | | 0/25^a^ | 0 %^a^
| Reduction (valproate) | Derealisation, new onset | | 0/25^a^ | 0 %^a^
| No change | Disorientation, new onset | | 0/22^a^ | 0 %^a^
| Reduction (phenytoin) | Disorientation, new onset | | 0/23^a^ | 0 %^a^
| Reduction (carbamazepine) | Disorientation, new onset | | 0/25^a^ | 0 %^a^
| Reduction (valproate) | Disorientation, new onset | | 0/25^a^ | 0 %^a^
| No change | Distorted taste/smell, new onset | | 0/22^a^ | 0 %^a^
| Reduction (phenytoin) | Distorted taste/smell, new onset | | 0/23^a^ | 0 %^a^
| Reduction (carbamazepine) | Distorted taste/smell, new onset | | 0/25^a^ | 0 %^a^
| Reduction (valproate) | Distorted taste/smell, new onset | | 0/25^a^ | 0 %^a^
| No change | Dizziness, new onset | | 5/22^a^ | 23 %^a^
| Reduction (phenytoin) | Dizziness, new onset | | 1/23^a^ | 4 %^a^
| Reduction (carbamazepine) | Dizziness, new onset | | 4/25^a^ | 16 %^a^
| Reduction (valproate) | Dizziness, new onset | | 3/25^a^ | 12 %^a^
| No change | Flu-like illness, new onset | | 0/22^a^ | 0 %^a^
| Reduction (phenytoin) | Flu-like illness, new onset | | 0/23^a^ | 0 %^a^
| Reduction (carbamazepine) | Flu-like illness, new onset | | 0/25^a^ | 0 %^a^
| Reduction (valproate) | Flu-like illness, new onset | | 1/25^a^ | 4 %^a^
| No change | Headache, new onset | | 2/22^a^ | 9 %^a^
| Reduction (phenytoin) | Headache, new onset | | 4/23^a^ | 17 %^a^
| Reduction (carbamazepine) | Headache, new onset | | 2/25^a^ | 8 %^a^
| Reduction (valproate) | Headache, new onset | | 6/25^a^ | 24 %^a^
| No change | Hyperacusis, new onset | | 0/22^a^ | 0 %^a^
| Reduction (phenytoin) | Hyperacusis, new onset | | 0/23^a^ | 0 %^a^
| Reduction (carbamazepine) | Hyperacusis, new onset | | 0/25^a^ | 0 %^a^
| Reduction (valproate) | Hyperacusis, new onset | | 0/25^a^ | 0 %^a^
| No change | Hypo/eraesthesiae, new onset | | 0/22^a^ | 0 %^a^
| Reduction (phenytoin) | Hypo/eraesthesiae, new onset | | 0/23^a^ | 0 %^a^
| Reduction (carbamazepine) | Hypo/eraesthesiae, new onset | | 0/25^a^ | 0 %^a^
| Reduction (valproate) | Hypo/eraesthesiae, new onset | | 0/25^a^ | 0 %^a^
| No change | Impaired memory/concentration, new onset | | 2/22^a^ | 9 %^a^
| Reduction (phenytoin) | Impaired memory/concentration, new onset | | 2/23^a^ | 9 %^a^
| Reduction (carbamazepine) | Impaired memory/concentration, new onset | | 5/25^a^ | 20 %^a^
| Reduction (valproate) | Impaired memory/concentration, new onset | | 1/25^a^ | 4 %^a^
| No change | Incoordination, new onset | | 2/22^a^ | 9 %^a^
| Reduction (phenytoin) | Incoordination, new onset | | 2/23^a^ | 9 %^a^
| Reduction (carbamazepine) | Incoordination, new onset | | 3/25^a^ | 12 %^a^
| Reduction (valproate) | Incoordination, new onset | | 1/25^a^ | 4 %^a^
| No change | Insomnia, new onset | | 4/22^a^ | 18 %^a^
| Reduction (phenytoin) | Insomnia, new onset | | 4/23^a^ | 17 %^a^
| Reduction (carbamazepine) | Insomnia, new onset | | 3/25^a^ | 12 %^a^
| Reduction (valproate) | Insomnia, new onset | | 5/25^a^ | 20 %^a^
| No change | Irritability, new onset | | 5/22^a^ | 23 %^a^
| Reduction (phenytoin) | Irritability, new onset | | 5/23^a^ | 22 %^a^
| Reduction (carbamazepine) | Irritability, new onset | | 2/25^a^ | 8 %^a^
| Reduction (valproate) | Irritability, new onset | | 1/25^a^ | 4 %^a^
| No change | Lack of energy, new onset | | 3/22^a^ | 14 %^a^
| Reduction (phenytoin) | Lack of energy, new onset | | 4/23^a^ | 17 %^a^
| Reduction (carbamazepine) | Lack of energy, new onset | | 5/25^a^ | 20 %^a^
| Reduction (valproate) | Lack of energy, new onset | | 8/25^a^ | 32 %^a^
| No change | Muscle ache, new onset | | 3/22^a^ | 14 %^a^
| Reduction (phenytoin) | Muscle ache, new onset | | 5/23^a^ | 22 %^a^
| Reduction (carbamazepine) | Muscle ache, new onset | | 4/25^a^ | 16 %^a^
| Reduction (valproate) | Muscle ache, new onset | | 5/25^a^ | 20 %^a^
| No change | Nausea and/or vomiting, new onset | | 5/22^a^ | 23 %^a^
| Reduction (phenytoin) | Nausea and/or vomiting, new onset | | 0/23^a^ | 0 %^a^
| Reduction (carbamazepine) | Nausea and/or vomiting, new onset | | 2/25^a^ | 8 %^a^
| Reduction (valproate) | Nausea and/or vomiting, new onset | | 3/25^a^ | 12 %^a^
| No change | Onset of new seizure type | | 0/23^a^ | 0 %^a^
| Reduction (phenytoin) | Onset of new seizure type | | 0/24a | 0 %^a^
| Reduction (carbamazepine) | Onset of new seizure type | | 0/25^a^ | 0 %^a^
| Reduction (valproate) | Onset of new seizure type | | 0/25^a^ | 0 %^a^
| No change | Paranoia, new onset | | 1/22^a^ | 5 %^a^
| Reduction (phenytoin) | Paranoia, new onset | | 1/23^a^ | 4 %^a^
| Reduction (carbamazepine) | Paranoia, new onset | | 0/25^a^ | 0 %^a^
| Reduction (valproate) | Paranoia, new onset | | 0/25^a^ | 0 %^a^
| No change | Paresthesia, new onset | | 0/22^a^ | 0 %^a^
| Reduction (phenytoin) | Paresthesia, new onset | | 0/23^a^ | 0 %^a^
| Reduction (carbamazepine) | Paresthesia, new onset | | 0/25^a^ | 0 %^a^
| Reduction (valproate) | Paresthesia, new onset | | 0/25^a^ | 0 %^a^
| No change | Photophobia/sore eyes, new onset | | 0/22^a^ | 0 %^a^
| Reduction (phenytoin) | Photophobia/sore eyes, new onset | | 0/23^a^ | 0 %^a^
| Reduction (carbamazepine) | Photophobia/sore eyes, new onset | | 1/25^a^ | 4 %^a^
| Reduction (valproate) | Photophobia/sore eyes, new onset | | 1/25^a^ | 4 %^a^
| No change | Sweating, new onset | | 4/22^a^ | 18 %^a^
| Reduction (phenytoin) | Sweating, new onset | | 0/23^a^ | 0 %^a^
| Reduction (carbamazepine) | Sweating, new onset | | 6/25^a^ | 24 %^a^
| Reduction (valproate) | Sweating, new onset | | 1/25^a^ | 4 %^a^
| No change | Tremor, new onset | | 4/22^a^ | 18 %^a^
| Reduction (phenytoin) | Tremor, new onset | | 2/23^a^ | 9 %^a^
| Reduction (carbamazepine) | Tremor, new onset | | 2/25^a^ | 8 %^a^
| Reduction (valproate) | Tremor, new onset | | 2/25^a^ | 8 %^a^
| No change | Twitching, new onset | | 3/22^a^ | 14 %^a^
| Reduction (phenytoin) | Twitching, new onset | | 4/23^a^ | 17 %^a^
| Reduction (carbamazepine) | Twitching, new onset | | 5/25^a^ | 20 %^a^
| Reduction (valproate) | Twitching, new onset | | 2/25^a^ | 8 %^a^
| No change | Visual hallucinations, new onset | | 0/22^a^ | 0 %^a^
| Reduction (phenytoin) | Visual hallucinations, new onset | | 0/23^a^ | 0 %^a^
| Reduction (carbamazepine) | Visual hallucinations, new onset | | 0/25^a^ | 0 %^a^
| Reduction (valproate) | Visual hallucinations, new onset | | 0/25^a^ | 0 %^a^
Specht (1989) | Reduction | Any | | 19/40 | 48 %
| Reduction | Nonictal withdrawal symptoms | | 4/40 | 10 %
| Reduction | Seizure exacerbation and psychic symptoms | | 5/40 | 13 %
| Reduction | Seizures during drug withdrawal | | 14/40 | 35 %
| Reduction | Seizures during drug withdrawal | | 14/40 | 35 %
| Reduction | Transitory exacerbation of seizures | | 10/40 | 25 %
Callaghan (1984) | Reduction | Increase in seizures | Withdrawal | 6/35 | 17 %
Schmidt (1983) | Reduction | Anxiety, Number of side effects disappearing after drug withdrawal | | 0/36 | 0 %
| Reduction | Anxiety, Number of side effects occurring after drug withdrawal | | 1/36 | 3 %
| Reduction | Ataxia, Number of side effects disappearing after drug withdrawal | | 5/36 | 14 %
| Reduction | Ataxia, Number of side effects occurring after drug withdrawal | | 1/36 | 3 %
| Reduction | Diplopia, Number of side effects disappearing after drug withdrawal | | 1/36 | 3 %
| Reduction | Diplopia, Number of side effects occurring after drug withdrawal | | 0/36 | 0 %
| Reduction | Exanthemia, Number of side effects disappearing after drug withdrawal | | 0/36 | 0 %
| Reduction | Exanthemia, Number of side effects occurring after drug withdrawal | | 0/36 | 0 %
| Reduction | Fever, Number of side effects disappearing after drug withdrawal | | 0/36 | 0 %
| Reduction | Fever, Number of side effects occurring after drug withdrawal | | 0/36 | 0 %
| Reduction | Gingival hyperplasia, Number of side effects disappearing after drug withdrawal | | 0/36 | 0 %
| Reduction | Gingival hyperplasia, Number of side effects occurring after drug withdrawal | | 0/36 | 0 %
| Reduction | Myalgia, Number of side effects disappearing after drug withdrawal | | 0/36 | 0 %
| Reduction | Myalgia, Number of side effects occurring after drug withdrawal | | 0/36 | 0 %
| Reduction | Myoclonias, Number of side effects disappearing after drug withdrawal | | 0/36 | 0 %
| Reduction | Myoclonias, Number of side effects occurring after drug withdrawal | | 0/36 | 0 %
| Reduction | Nausea, Number of side effects disappearing after drug withdrawal | | 0/36 | 0 %
| Reduction | Nausea, Number of side effects occurring after drug withdrawal | | 1/36 | 3 %
| Reduction | Nystagmus, Number of side effects disappearing after drug withdrawal | | 7/36 | 19 %
| Reduction | Nystagmus, Number of side effects occurring after drug withdrawal | | 4/36 | 11 %
| Reduction | Sedation, Number of side effects disappearing after drug withdrawal | | 2/36 | 6 %
| Reduction | Sedation, Number of side effects occurring after drug withdrawal | | 2/36 | 6 %
| Reduction | Tremor, Number of side effects disappearing after drug withdrawal | | 0/36 | 0 %
| Reduction | Tremor, Number of side effects occurring after drug withdrawal | | 0/36 | 0 %
| Reduction | Vertigo, Number of side effects disappearing after drug withdrawal | | 2/36 | 6 %
| Reduction | Vertigo, Number of side effects occurring after drug withdrawal | | 1/36 | 3 %
| Reduction | Vomiting, Number of side effects disappearing after drug withdrawal | | 1/36 | 3 %
| Reduction | Vomiting, Number of side effects occurring after drug withdrawal | | 0/36 | 0 %
Other studies of optimized current therapy
Semah (1994) | Other | Any | Any | 14/18 | 78%
| Other | Ataxia | | 2/18 | 11%
| Other | Diplopia | | 4/18 | 22%
| Other | Drowsiness | | 7/18 | 39%
| Other | Dyspnea | | 2/18 | 11%
| Other | Headache | | 2/18 | 11%
| Other | Memory difficulty | | 2/18 | 11%
| Other | Nausea | | 3/18 | 17%
| Other | Tremor | | 2/18 | 11%

a Information reported by a secondary publication, Duncan (1988).

Evidence Table 101. Comparison of patients in drug reduction and control arms of controlled trials

Reference | Demographic | Study Arm | N | Pretreatment | Type of Effect Size | Effect Size (CI) | P =
May (1992) | Age (yrs) | Treatment | 17 | 55.2 (8.7) yrs | Original metric | 8.90 (0.29 to 17.51) yrs | 0.043
| | Control | 12 | 46.3 (13.3) yrs
| Sex ratio (males:females) | Treatment | 17 | 8:4 | Cohen's h | 0.31 (0.43 to 1.04) | 0.418
| | Control | 12 | 7:17
| Duration of epilepsy (yrs) | Treatment | 17 | 49.4 (8.4) yrs | Original metric | 8.9 (0.10 to 17.90) | 0.053
| | Control | 12 | 40.5 (14.2) yrs
| Number of seizures in previous year | Treatment | 17 | 25.6 (25.7) | Original metric | 2.8 (16.15 to 21.75) | 0.772
| | Control | 12 | 22.8 (25.6)
| Phenytoin dose (mg) | Treatment | 17 | 182.4 (38.3) mg | Original metric | -46.80 (-80.78 to -12.82) | 0.007
| | Control | 12 | 229.2 (50.6) mg
| Phenytoin serum conc (mg/l^3^) | Treatment | 17 | 5.4 (2.0) | Original metric | -3.40 (-5.37 to -1.43) | 0.0007
| | Control | 12 | 8.8 (3.4)
Duncan (1990) | Age (years) | PHT | 23 | 35 (rng: 19 to 65) | NC | NC | 0.01^a^
| | CBZ | 22 | 31 (rng: 19 to 59) | NC | NC | 0.006^a^
| | VPA | 25 | 25 (rng: 17 to 48) | NC | NC | <0.0001^a^
| | Control | 25 | 42 (rng: 25 to 65)
| Duration of epilepsy (years) | PHT | 23 | 25 (rng: 7 to 51) | NC | NC | 0.03^a^
| | CBZ | 22 | 23 (rng: 10 to 56) | NC | NC | 0.009^a^
| | VPA | 25 | 17 (rng: 7 to 39) | NC | NC | 0.0001^a^
| | Control | 25 | 37 (rng: 16 to 56)
| Number of seizures in previous 6 months | PHT | 23 | 82 (rng: 5 to 598) | NC | NC | NS
| | CBZ | 22 | 72 (rng: 1 to 2210) | NC | NC | NS
| | VPA | 25 | 102 (rng: 12 to 910) | NC | NC | NS
| | Control | 25 | 58 (rng: 3 to 404
| IQ (full scale) | PHT | 23 | 78 (10.9) | Original metric | 2.0 (-48.7 to 8.82) | 0.565
| | CBZ | 22 | 82 (13.9) | Original metric | 6.00 (-1.69 to 13.69) | 0.126
| | VPA | 25 | 81 (14.9) | Original metric | 5.00 (-2.75 to 12.75) | 0.206
| | Control | 25 | 76 (13.0)
| Ratio males:females | PHT | 23 | 16: 7 | Cohen's h | -0.09 (-0.66 to 0.47) | 0.745
| | CBZ | 22 | 17:7 | Cohen's h | 0.02 (-0.55 to 0.59) | 0.946
| | VPA | 25 | 13:12 | Cohen's h | -0.32 (-0.87 to 0.24) | 0.263
| | Control | 25 | 19:6
Thompson (1982) | Age (years) | Treatment | 10 | 28 (10.9) | Original metric | -5.50 (-14.16 to 3.16) | 0.213024
| | Control | 20 | 33.5 (12.4)
| Duration of epilepsy | Treatment | 10 | 19.5 (11.3) | Original metric | 0.30 (-7.70 to 8.30) | 0.941
| | Control | 20 | 19.2 (8.7)
| Ratio males:females | Treatment | 10 | 2:8 | Cohen's h | 0.32 (-0.44 to 1.08) | 0.405396
| | Control | 20 | 10:10
| Full scale IQ | Treatment | 10 | 93.8 (13.5) | Original metric | -2.30 (-12.95 to 8.35) | 0.672
| | Control | 20 | 96.1 (15.1)

a P-values extracted from article because reported data did not allow us to calculate the value

NC Not calculable given available information

NS Not statistically significant

CBZ Carbamazepine

PHT Phenytoin

VPA Valproate

IQ Intelligence quotient

Rng Range

## Question 5

Which methods of nondrug treatment for epilepsy after initial treatment failure lead to improved outcomes for patients with treatment-resistant epilepsy?

Evidence Table 102. All studies meeting the inclusion criteria for surgical interventions and the interventions examined

Reference | Temporal Lobe Surgery | Frontal Lobe Surgery | Parietal Lobe Surgery | Occipital Lobe Surgery | Multiple Subpial Transections | Hemispherectomy | Corpus Callosotomy | Surgical Control Patients
Bouilleret (2002) | ✓
Alsaadi (2001) | ✓
Bauer (2001) | | | | | | | | ✓
Boling (2001) | ✓
Carreno (2001) | | | | | | ✓
Ferrier (2001) | | ✓
Hennessy (2001) | ✓
Hennessy (2001) | ✓
Hodaie (2001) | | | | | | | ✓
Jan (2001) | ✓
Kanemoto (2001) | ✓
Kohler (2001) | ✓
Kral (2001) | | ✓
Kumlien (2001) | | | | | | | | ✓
Kwan (2001) | | | | | | | ✓
Maehara (2001) | | | | | | | ✓
Miranda (2001) | ✓
Mulligan (2001) | | | | | ✓
Nees (2001) | ✓
Orbach (2001) | | | | | ✓
Schramm (2001) | ✓
Schramm (2001) | | | | | | ✓
Siegel (2001) | | ✓
Sotero de Menezes (2001) | ✓
Verma (2001) | ✓
Wiebe (2001) | ✓ | | | | | | | ✓
Wilson (2001) | ✓
Anhoury (2000) | ✓
Canizares (2000) | ✓
Derry (2000) | ✓
Di Rocco (2000) | | | | | | ✓
Dupont (2000) | ✓
Eberhardt (2000) | ✓
Fandino-Franky (2000) | | | | | | | ✓
Foldvary (2000) | ✓
Holmes (2000) | ✓
Hong (2000) | | ✓
Iannelli (2000) | ✓
Markand (2000) | ✓ | | | | | | | ✓
Mosewich (2000) | | ✓
Rao (2000) | ✓
Robinson (2000) | ✓
Shimizu (2000) | | | | | | ✓
Shimizu (2000) | | | | | ✓
Westerveld (2000) | ✓
Wurm (2000) | ✓
Altshuler (1999) | ✓
Assaf (1999) | ✓
Battaglia (1999) | | | | | | ✓
Chassoux (1999) | | ✓
Eriksson (1999) | ✓ | ✓
Ferrier (1999) | | ✓
Henry (1999) | ✓
Holmes (1999) | ✓
Leung (1999) | ✓
Mathern (1999) | ✓
Matsuzaka (1999) | | | | | | | ✓
McInerney (1999) | | | | | | | ✓
Mitchell (1999) | ✓
Parrent (1999) | ✓
Pinard (1999) | | | | | | | ✓
Rossi (1999) | ✓
Salanova (1999) | ✓
Son (1999) | ✓
Visudhiphan (1999) | ✓
Wennberg (1999) | | ✓
Blumer (1998) | ✓
Carmant (1998) | | | | | | | ✓
Helmstaedter (1998) | | ✓
Holmes (1998) | | | | | | | | ✓
Maher (1998) | ✓
Radhakrishnan (1998) | ✓
Ring (1998) | ✓
Smith (1998) | | | | | ✓
Swartz (1998) | | ✓
Szabo (1998) | ✓
Wolf (1998) | | | | | | | | ✓
Wyllie (1998) | ✓ | | | | | ✓
Bizzi (1997) | ✓
Blume (1997) | ✓
Cappabianca (1997) | ✓ | ✓
Casazza (1997) | ✓
Ho (1997) | ✓
Hufnagel (1997) | | | | | ✓
Keene (1997) | ✓
Kilpatrick (1997) | ✓
McLachlan (1997) | ✓ | | | | | | | ✓
Pacia (1997) | | | | | ✓
Patil (1997) | | | | | ✓
Reeves (1997) | ✓
Schwartz (1997) | ✓
Silander (1997) | ✓
Sisodiya (1997) | ✓
Smith (1997) | | ✓
Sorenson (1997) | | | | | | | ✓
Vining (1997) | | | | | | ✓
Adam (1996) | ✓
Andersen (1996) | | | | | | | ✓
Goldstein (1996) | ✓
Hermanns (1996) | | | | | | | | ✓
Holmes (1996) | ✓
Peacock (1996) | | | | | | ✓
Rose (1996) | ✓
Rossi (1996) | | | | | | | ✓
Sakas (1996) | | | | | | | ✓
Sirven (1996) | ✓
Acciarri (1995) | ✓ | ✓
Berkovic (1995) | ✓
Claverie (1995) | | | | | | | ✓
Davies (1995) | ✓
Jooma (1995a) | ✓
Jooma (1995b) | ✓
Liu (1995) | ✓
Morrell (1995) | | | | | ✓
Renowden (1995) | ✓
Salanova (1995) | | | ✓
Salanova (1995) | | | ✓
Sawhney (1995) | | | | | ✓
Schramm (1995) | | | | | | ✓
Sperling (1995) | ✓
Thadani (1995) | ✓
Vickrey (1995) | | | | | | | | ✓
Vossler (1995) | ✓
Wyler (1995) | ✓
Blume (1994) | ✓
Guldvog (1994a) | ✓
Guldvog (1994b) | ✓
Naylor (1994) | ✓
Chelune (1993) | ✓
Reutens (1993) | | | | | | | ✓
Bladin (1992) | ✓
Salanova (1992) | | | | ✓
Adler (1991) | | ✓
Berkovic (1991) | ✓
Blume (1991) | | | | ✓
Cohen (1991) | | | | | | | ✓
Elwes (1991) | ✓
Fuiks (1991) | | | | | | | ✓
Garcia Sola (1991) | | ✓
Guldvog (1991) | | | | | | | | ✓
Hopkins (1991) | ✓
Nordgren (1991) | | | | | | | ✓
Oguni (1991) | | | | | | | ✓
Palmini (1991) | | ✓
Rasmussen (1991) | | ✓
Rasmussen (1991) | ✓
Shimizu (1991) | | | | | ✓
Wieser (1991) | ✓
Bidzinski (1990) | ✓
Huttenlocher (1990) | | | | | | | | ✓
Mackenzie (1990) | ✓
Marino (1990) | | | | | | | ✓
Mizrahi (1990) | ✓
Provinciali (1990) | | | | | | | ✓
Sass (1990) | | | | | | | ✓
Walczak (1990) | ✓
Yeh (1990) | ✓
So (1989) | ✓
Sperling (1989) | ✓
Estes (1988) | ✓
Ivnik (1988) | ✓
Murro (1988) | | | | | | | ✓
Purves (1988) | | | | | | | ✓
Spencer (1988) | | | | | | | ✓
Tinuper (1988) | | | | | | ✓
Bladin (1987) | ✓
Cutfield (1987) | ✓
Drake (1987) | ✓
Garcia-Flores (1987) | | | | | | | ✓
Gates (1987) | | | | | | | ✓
Harbord (1987) | | | | | | | | ✓
Lindsay (1987) | | | | | | ✓
King (1986) | ✓
Lieb (1986) | ✓
Meyer (1986) | ✓
Carey (1985) | ✓
Delgado-Escueta (1985) | ✓
Ojemann (1985) | ✓
Powell (1985) | ✓

Evidence Table 103. Studies of temporal lobe surgery - general study information

Reference | Number of Patients | Years | Country | Author Affiliation | Multicenter Study | Method of Patient Selection | Study Design
Bouilleret (2002) | 18 | 1993-2000 | France | | No | Prospective | Nested case-control with individual patient data
Alsaadi (2001) | 49 | 1989-1994 | United States | Department of Neurology, University of California San Francisco, 400 Parnassus Avenue, Room A889, San Francisco, California 94143, USA. | No | Retrospective | Nested case-control
Boling (2001) | 18 | 1981-1999 | Canada | Dr. W. Boling, Department of Neurosurgery, Montreal Neurol. Inst. and Hospital, Montreal, Que. H3A 2B4. Canada | No | Retrospective | Case series
Hennessy (2001) | 116 | 1975-1995 | England | Epilepsy Centre, Kings College Hospital, Denmark Hill, London SE5, Department of Biostatistics and Computing, Institute of Psychiatry, de Crespigny Park, London SE5. | No | Retrospective | Nested case-control
Hennessy (2001) | 80 | 1975-1995 | England | Epilepsy Centre, King's College Hospital, Denmark Hill, London SE5, UK. Michael@hennessy72.fsnet.co.uk | No | Retrospective | Nested case-control
Jan (2001) | 29 | 1990-1996 | Canada | | No | Retrospective | Case series
Kanemoto (2001) | 52 | 1987-1999 | Japan | | No | Retrospective | Case series
Kohler (2001) | 58 | 1986-1999 | United States | Neuropsychiatry Section, Department of Psychiatry, University of Pennsylvania, Philadelphia 19104-4283, USA. kohler@bblmail.psycha.upenn.edu | No | Retrospective | Case series
Miranda (2001) | 50 | 1976-1998 | Canada | | No | Retrospective | Case series
Nees (2001) | 50 | 1992-1994 | England | | No | Retrospective | Case series
Schramm (2001) | 61 | 1993-1999 | Germany | Department of Neurosurgery, University of Bonn, Germany. schrammj@mailer.meb.uni-bonn.de | No | Prospective | Case series
Sotero de Menezes (2001) | 15 | 1978-1993 | United States | Department of Neurology, Children's Hospital and Regional Medical Center, University of Washington, Seattle 98105, USA. msoter@chmc.org | No | Retrospective | Nested case-control with individual patient data
Verma (2001) | 13 | 1989-1996 | United States | Department of Medicine (Neurology), Duke University Medical Center, 27710, Durham, NC, USA | No | Retrospective | Nested case-control with individual patient data
Wiebe (2001) | 40 | 1996-2000 | Canada | Department of Clinical Neurological Sciences, University of Western Ontario, and London Health Sciences Centre, Canada. swiebe@uwo.ca | No | Prospective | RCT
Wilson (2001) | 90 | 1990-1993 | Australia | Comprehensive Epilepsy Program, Epilepsy Research Institute, Austin & Repatriation Medical Centre (A&RMC), Melbourne, Australia. s.wilson@psych.unimelb.edu.au | No | Retrospective | Case series
Anhoury (2000) | 121 | 1988-1997 | England | Raymond Way Neuropsychiatry Research Group, University Department of Clinical Neurology, Institute of Neurology, London, England. | No | Retrospective | Case series
Canizares (2000) | 33 | 1998-1999 | Spain | Department of Psychiatry and Clinical Psychobiology of the University of Barcelona, Spain. | No | Prospective | Case series
Derry (2000) | 39 | 1996-1998 | Canada | Department of Psychology, London Health Sciences Centre, University of Western Ontario, Canada. pderry@julian.uwo.ca | No | Prospective | Case series
Dupont (2000) | 30 | 1994-1999 | France | Service Hospitalier Frederic Joliot, Commissariat a l'Energie Atomique, 91401 Orsay Cedex, France. dupont@shfj.cea.fr | No | Not reported | Nested case-control
Eberhardt (2000) | 26 | 1995-1999 | Germany | Department of Neurosurgery, University of Erlangen-Nuremberg, Germany. neoruradiologie@rzmail.uni-erlangen.de | No | Prospective | Nested case-control with individual patient data
Foldvary (2000) | 79 | 1962-1984 | United States | Department of Neurology, Duke University Medical Center, Durham, NC, USA. | No | Retrospective | Nested case-control
Holmes (2000) | 23 | 1993-1997 | United States | Regional Epilepsy Center, University of Washington, Seattle, 98104, USA. mdholmes@u.washington.edu | No | Retrospective | Nested case-control
Iannelli (2000) | 37 | 1981-1997 | Italy | Institute of Neurosurgery, Section of Pediatric Neurosurgery, Catholic University, Rome, Italy. Iannel@tiscalinet.it | No | Retrospective | Case series
Markand (2000) | 53 | 1994-1997 | United States | Department of Neurology, Division of Biostatistics, Indiana University School of Medicine, Indianapolis, Indiana, USA. omarkand@iupui.edu | No | Prospective | Controlled
Rao (2000) | 119 | 1995-1998 | India | R. Madhavan Nayar Center for Comprehensive Epilepsy Care, Sree Chitra Tirunal Institute for Medical Sciences and Technology, Trivandrum, Kerala, India. | No | Retrospective | Case series
Robinson (2000) | 22 | 1993-1998 | United States | Department of Neurosurgery, Epilepsy Center, St. Louis Children's Hospital, Washington University School of Medicine, Missouri 63110, USA. | No | Prospective | Nested case-control
Westerveld (2000) | 82 | | United States | Department of Neurosurgery, Yale University School of Medicine, New Haven, Connecticut 06520-8082, USA. westerm@msn.com | Yes | Retrospective | Case series
Wurm (2000) | 16 | 1997-1998 | Austria | Department of Neurosurgery, OO Landesnervenklinik Wagner Jauregg, Linz, Austria. gabriele.wurm@lkh.ooe.gv.at | No | Not reported | Case series
Altshuler (1999) | 49 | 1974-1990 | United States | UCLA Department of Psychiatry and Biobehavioral Sciences, Mood Disorders Research Program 90095-7057, USA. | No | Retrospective | Case series
Assaf (1999) | 75 | 1989-1995 | United States | Department of Neurology, Saint Louis University, Missouri 63110, USA. | No | Retrospective | Case series
Eriksson (1999) | 75 | 1987-1995 | Sweden | Institute of Clinical Neuroscience, Dept. of Neurology, Sahlgrenska University Hospital, Goteborg, Sweden. | No | Retrospective | Case series
Henry (1999) | 38 | 1991-1994 | United States | Department of Neurology, Emory University School of Medicine, Atlanta, Georgia 30322, USA. | No | Retrospective | Case series
Holmes (1999) | 13 | 1992-1996 | United States | Department of Neurology, University of Washington School of Medicine, Seattle, USA. | No | Retrospective | Nested case-control with individual patient data
Leung (1999) | 11 | 1994-1998 | Hong Kong | Division of Neurosurgery, Department of Surgery, The University of Hong Kong, Queen Mary Hospital, Pokfulam, Hong Kong. | No | Retrospective | Case series
Mathern (1999) | 31 | 1986-1997 | United States | Division of Neurosurgery, The Mental Retardation Research Center, University of California, Los Angeles, USA. gmathern@ucla.edu | No | Prospective | Case series
Mitchell (1999) | 45 | 1993-1995 | Australia | Brain Imaging Research Institute, Austin and Repatriation Medical Centre, Heidelberg, Victoria, Australia. | No | Retrospective | Case series
Parrent (1999) | 19 | 1994-1997 | Canada | London Health Sciences Centre, Ontario, Canada. andrew.parrent@lhsc.on.ca | No | Retrospective | Case series
Rossi (1999) | 28 | 1980-1996 | Italy | Institute of Neurosurgery, Catholic University, Medical School, Rome, Italy. | No | Retrospective | Case series
Salanova (1999) | 145 | 1984-1995 | United States | Department of Neurology, Indiana University School of Medicine, Indianapolis 46202, USA. vsalanov@iumc.iupui.edu | No | Retrospective | Nested case-control
Son (1999) | 71 | 1994-1999 | South Korea | Department of Neurosurgery, Seoul National University College of Medicine, Korea. | No | Retrospective | Case series
Visudhiphan (1999) | 14 | 1993-1998 | Thailand | Department of Pediatrics, Faculty of Medicine, Ramathibodi Hospital, Mahidol University, Bangkok, Thailand. | No | Retrospective | Case series
Blumer (1998) | 44 | 1994-1995 | United States | Department of Psychiatry, University of Tennessee, and Epi-Care Center, Memphis 38103, USA. | No | Prospective | Case series
Maher (1998) | 93 | 1994-1996 | Canada | Department of Medicine, University of Manitoba, Winnipeg, Canada. | Yes | Retrospective | Case series
Radhakrishnan (1998) | 175 | 1988-1991 | United States | Department of Neurology, Mayo Clinic, Rochester, MN 55905, USA. | No | Retrospective | Nested case-control
Ring (1998) | 60 | 1995-1996 | England | National Hospital for Neurology and Neurosurgery, London, UK. | No | Prospective | Case series
Szabo (1998) | 14 | 1989-1994 | United States | Department of Neurology, The Cleveland Clinic Foundation, Ohio 44195, USA. | No | Retrospective | Nested case-control with individual patient data
Wyllie (1998) | 72 | 1990-1996 | United States | Department of Neurology, The Cleveland Clinic Foundation, OH 44195, USA. | No | Retrospective | Case series
Bizzi (1997) | 19 | 1990-1994 | United States | Columbia Children's Hospital and Children's Medical Center, Dallas, Tex., USA. | No | Retrospective | Case series
Blume (1997) | 14 | 1977-1994 | Canada | University Hospital, University of Western Ontario, London, Canada. | No | Retrospective | Case series
Cappabianca (1997) | 10 | 1985-1994 | Italy | Department of Neurosurgery, University Federico II School of Medicine, Naples, Italy. | No | Retrospective | Case series
Casazza (1997) | 40 | 1988-1994 | Italy | Istituto Nazionale Neurologico C. Besta, Milano, Italy. | No | Retrospective | Case series
Ho (1997) | 63 | 1989-1993 | Australia | Department of Neurology, Austin and Repatriation Medical Centre, Melbourne, Australia. | No | Retrospective | Case series
Keene (1997) | 44 | 1975-1996 | Canada | Department of Pediatrics, Children's Hospital of Eastern Ontario, Ottawa, Canada. | No | Retrospective | Case series
Kilpatrick (1997) | 36 | 1993-1995 | Australia | Department of Neurology, The Melbourne Neuroscience Centre, The Royal Melbourne Hospital, Victoria, Australia. | No | Not reported | Nested case-control with individual patient data
McLachlan (1997) | 56 | 1992-1995 | Canada | Department of Clinical Neurological Sciences, University of Western Ontario, London, Canada. | No | Prospective | Controlled
Reeves (1997) | 190 | 1988-1991 | United States | Department of Neurology, Mayo Clinic, Rochester, Minnesota 55905, USA. | No | Retrospective | Case series
Schwartz (1997) | 29 | 1992-1994 | United States | Department of Neurological Surgery, Columbia-Presbyterian Medical Center, New York, New York, USA. | No | Prospective | Nested case-control with individual patient data
Silander (1997) | 94 | 1980-1990 | Sweden | Dr. H.C. Silander, Department of Neurosurgery, University Hospital, S-751 85 Uppsala. Sweden | Yes | Retrospective | Case series
Sisodiya (1997) | 27 | 1993-1995 | England | Department of Clinical Neurology, National Hospital for Neurology and Neurosurgery, London, UK. | No | Retrospective | Nested case-control with individual patient data
Adam (1996) | 30 | 1991-1994 | France | Service de Neurophysiologie, Hopital de la Pitie-Salpetriere, Paris, France. | No | Prospective | Nested case-control with individual patient data
Goldstein (1996) | 33 | 1985-1993 | United States | Comprehensive Epilepsy Center, University of Miami School of Medicine, FL, USA. | No | Retrospective | Nested case-control
Holmes (1996) | 45 | 1982-1986 | United States | Department of Medicine (Neurology), University of Washington, School of Medicine, Seattle, USA. | No | Prospective | Case series
Rose (1996) | 56 | 1992-1994 | Canada | Department of Psychology, University Hospital, London, Ontario, Canada. | No | Prospective | Case series
Sirven (1996) | 174 | 1985-1992 | United States | Comprehensive Epilepsy Center, Graduate Hospital, Philadelphia, PA 19146, USA. | No | Retrospective | Case series
Acciarri (1995) | 10 | 1975-1992 | Italy | 2nd Division of Neurosurgery, Bellaria Hospital, Bologna, Italy. | No | Retrospective | Nested case-control with individual patient data
Berkovic (1995) | 135 | 1986-1991 | Australia | Department of Neurology, Austin Hospital, Heidelberg, Melbourne, Australia. | No | Not reported | Case series
Davies (1995) | 12 | 1969-1988 | England | Department of Neurosurgery, University Hospital of Wales, Cardiff, UK. | No | Retrospective | Case series
Jooma (1995a) | 30 | 1985-1992 | United States | Department of Neurosurgery, University of Cincinnati College of Medicine, Ohio, USA. | No | Retrospective | Nested case-control with individual patient data
Jooma (1995b) | 62 | 1992-1994 | United States | Department of Neurosurgery, University of Cincinnati College of Medicine, Ohio, USA. | No | Retrospective | Case series
Liu (1995) | 12 | 1983-1990 | United States | Department of Neurosurgery, University of Cincinnati College of Medicine, Mayfield Neurological Institute, OH 45267-0515. | No | Retrospective | Nested case-control with individual patient data
Renowden (1995) | 67 | 1983-1992 | England | Department of Neuroradiology, Radcliffe Infirmary NHS Trust, Oxford, United Kingdom. | No | Retrospective | Case series
Sperling (1995) | 73 | 1986-1990 | United States | Comprehensive Epilepsy Center, Graduate Hospital, Philadelphia, PA 19146, USA. | No | Retrospective | Case series
Thadani (1995) | 22 | 1983-1992 | United States | Section of Neurology, Dartmouth-Hitchcock Medical Center, Lebonon, NH 03756. | No | Retrospective | Case series
Vossler (1995) | 31 | 1979-1989 | United States | Epilepsy Center, Swedish Medical Center, 801 Broadway,Seattle, WA 98122. United States | No | Retrospective | Nested case-control with individual patient data
Wyler (1995) | 70 | 1990-1992 | United States | Epilepsy Center, Swedish Medical Center, Seattle, Washington, USA. | No | Prospective | RCT
Blume (1994) | 125 | 1974-1989 | Canada | Epilepsy Unit, University Hospital, The University of Western Ontario, London, Ontario, Canada | No | Retrospective | Nested case-control
Guldvog (1994b) | 79 | 1949-1988 | Norway | Foundation for Health Services Research, Nordbyhagen, Norway. | Yes | Retrospective | Case series
Guldvog (1994a) | 35 | 1952-1988 | Norway | Foundation for Health Services Research, Nordbyhagen, Norway. | Yes | Retrospective | Case series
Naylor (1994) | 37 | 1987-1991 | Denmark | Department of Psychiatry, Rigshospitalet, Blegdamsvej 9,DK-2100 Copenhagen O. Denmark | No | Retrospective | Case series
Chelune (1993) | 96 | 1990-1991 | United States | | No | Prospective | Case series
Bladin (1992) | 115 | 1975-1991 | Australia | Comprehensive Epilepsy Program, Austin Hospital, Melbourne, Australia. | No | Retrospective | Case series
Berkovic (1991) | 10 | 1985-1986 | Canada | Montreal Neurological Institute and Hospital, Quebec, Canada. | No | Retrospective | Nested case-control with individual patient data
Elwes (1991) | 108 | 1976-1987 | England | Institute of Psychiatry, De Crespigny Park, London, UK. | No | Prospective | Case series
Hopkins (1991) | 11 | 1978-1988 | Australia | Royal Children's Hospital, Melbourne, Australia. | No | Retrospective | Nested case-control with individual patient data
Rasmussen (1991) | 100 | 1961-1980 | Canada | Montreal Neurology Institute and Hospital, Department of Neurology and Neurosurgery, McGill University, Quebec, Canada. | No | Retrospective | Case series
Wieser (1991) | 215 | 1975-1990 | Switzerland | Department of Neurology, University Hospital, Zurich, Switzerland. | No | Retrospective | Case series
Bidzinski (1990) | 320 | 1957-1988 | Poland | Department of Neurosurgery, Warsaw Medical Academy, Poland. | No | Retrospective | Case series
Mackenzie (1990) | 30 | 1983-1989 | Australia | Prince Henry Hospital, Little Bay, NSW. | No | Retrospective | Case series
Mizrahi (1990) | 22 | 1980-1986 | United States | Department of Neurology, Baylor College of Medicine, Houston, TX 77030. | No | Retrospective | Nested case-control with individual patient data
Walczak (1990) | 100 | 1964-1985 | United States | Department of Medicine, Duke University Medical Center, Durham, NC 27710. | No | Retrospective | Case series
Yeh (1990) | 12 | 1982-1986 | Japan | Department of Neurosurgery, University of Cincinnati College of Medicine, Ohio. | No | Retrospective | Nested case-control with individual patient data
So (1989) | 48 | 1973-1987 | Canada | Department of Neurology and Neurosurgery, McGill University, Montreal, Quebec, Canada. | No | Retrospective | Nested case-control
Sperling (1989) | 39 | 1976-1983 | United States | Department of Neurology, University of Pennsylvania, Philadelphia. | No | Retrospective | Case series
Estes (1988) | 46 | 1979-1984 | United States | | No | Retrospective | Nested case-control with individual patient data
Ivnik (1988) | 142 | 1972-1987 | United States | Department of Psychiatry and Psychology, Mayo Clinic, Rochester, MN 55905. | No | Retrospective | Case series
Bladin (1987) | 63 | 1985-1987 | Australia | Department of Neurology, Austin Hospital, Melbourne, Vic. | No | Retrospective | Case series
Cutfield (1987) | 26 | 1961-1980 | New Zealand | North Shore Hospital. | No | Retrospective | Nested case-control
Drake (1987) | 16 | 1974-1986 | Canada | Division of Neurosurgery, Hospital for Sick Children, Toronto, Ontario. | No | Retrospective | Nested case-control with individual patient data
King (1986) | 23 | 1981-1983 | United States | | No | Prospective | Case series
Lieb (1986) | 75 | 1961-1977 | United States | | No | Retrospective | Case series
Meyer (1986) | 50 | 1970-1983 | United States | | No | Retrospective | Case series
Carey (1985) | 24 | 1975-1984 | Ireland | | No | Retrospective | Case series
Delgado-Escueta (1985) | 15 | 1972-1983 | United States | | No | Retrospective | Nested case-control with individual patient data
Ojemann (1985) | 14 | 1983-1983 | United States | | No | Not reported | Case series
Powell (1985) | 59 | 1973-1984 | England | | No | Prospective | Case series

Evidence Table 104. Studies of frontal lobe surgery - general study information

Reference | Number of Patients | Years | Country | Author Affiliation | Multicenter Study | Method of Patient Selection | Study Design
Ferrier (2001) | 35 | 1975-1996 | England | Institute of Epileptology, King's College Hospital, London, UK. | No | Retrospective | Nested case-control
Kral (2001) | 32 | 1989-2000 | Germany | Department of Neurosurgery, University of Bonn, Medical Center, Sigmund Freud Strasse 25, 53105 Bonn, Germany. | No. | Retrospective | Nested case-control
Siegel (2001) | 14 | 1992-1999 | United States | Sections of Neurology, Neurosurgery, and Nuclear Medicine, Department of Pathology, Dartmouth-Hitchcock Medical Center, Lebanon, New Hampshire, U.S.A; and Department of Neurology, University Hospital Zurich, Switzerland. | No | Retrospective | Case series
Hong (2000) | 18 | 1995-1999 | South Korea | Department of Neurosurgery, Samsung Medical Center, Sungkyunkwan University School of Medicine, Seoul, Korea. schong@smc.samsung.co.kr | No | Retrospective | Nested case-control with individual patient data
Mosewich (2000) | 68 | 1987-1994 | United States | Department of Neurology, Mayo Clinic and Mayo Foundation, Rochester, Minnesota 55905, USA. | No | Retrospective | Case series
Chassoux (1999) | 120 | 1964-1995 | France | Department of Neurosurgery, Sainte Anne Hospital Center, Paris, France. | No | Retrospective | Case series
Eriksson (1999) | 25 | 1987-1995 | Sweden | Institute of Clinical Neuroscience, Dept. of Neurology, Sahlgrenska University Hospital, Goteborg, Sweden. | No | Retrospective | Case series
Ferrier (1999) | 42 | 1975-1996 | England | Institute of Epileptology, King's College Hospital, London, UK. | No | Respective | Case series
Wennberg (1999) | 22 | 1970-1994 | Canada | Department of Neurology and Neurosurgery, Montreal Neurological Institute and Hospital, McGill University, Quebec, Canada. | No | Retrospective | Nested case-control with individual patient data
Helmstaedter (1998) | 33 | 1995-1996 | Germany | University Hospital of Epileptology, Bonn, Germany. psych@mailer.meb.unibonn.de | No | Retrospective | Case series
Swartz (1998) | 19 | 1986-1995 | United States | B.E. Swartz, UCLA Neurology Department, W127B Epilepsy Center, 11301 Wilshire Blvd., Los Angeles, CA 90073. United States | No | Retrospective | Nested case-control with individual patient data
Cappabianca (1997) | 13 | 1985-1994 | Italy | Department of Neurosurgery, University Federico II School of Medicine, Naples, Italy. | No | Retrospective | Case series
Smith (1997) | 53 | 1995-1997 | United States | Section of Neurosurgery, Medical College of Georgia, Augusta, USA. depatientsurg.jsmith@mail.mcg.edu | No | Retrospective | Nested case-control
Acciarri (1995) | 13 | 1975-1992 | Italy | 2nd Division of Neurosurgery, Bellaria Hospital, Bologna, Italy. | No | Retrospective | Nested case-control with individual patient data
Adler (1991) | 14 | 1972-1987 | United States | Department of Surgery, (Neurosurgery), Stanford University Medical School, Calif. | No | Retrospective | Case series
Garcia Sola (1991) | 18 | 1978-1990 | Spain | Department of Clinical Neurophysiology, Hospital Puerta de Hierro, Madrid, Spain. | No | Retrospective | Case series
Palmini (1991) | 12 | 1975-1990 | Canada | Department of Neurology and Neurosurgery, McGill University, Montreal, Quebec, Canada. | No | Retrospective | Case series
Rasmussen (1991) | 283 | 1928-1980 | Canada | Montreal Neurological Institute and Hospital, Quebec, Canada. | No | Retrospective | Case series

Evidence Table 105. Studies of multiple subpial transection - general study information

Reference | Number of Patients | Years | Country | Author Affiliation | Multicenter Study | Method of Patient Selection | Study Design
Mulligan (2001) | 12 | 1990-1999 | United States | Department of Neurosurgery, Yale University School of Medicine, New Haven, CT 06520, U.S.A. | No | Retrospective | Case series
Orbach (2001) | 54 | 1992-2000 | United States | Dr. O. Devinsky, NYU-Mt. Sinai Compreh. Epilepsy Ctr., 403 E. 34th St., New York, NY 10016. United States | No | Retrospective | Case series
Shimizu (2000) | 31 | 1983-1998 | Japan | Department of Neurosurgery, Tokyo Metropolitan Neurological Hospital, Japan. smz-h@qb3.so-net.ne.jp | No | Retrospective | Case series
Smith (1998) | 84 | | United States | Department of Neurological Sciences, Rush-Presbyterian-St. Luke's Medical Center, Chicago, Illinois 60612-3824, USA. | No | Retrospective | Case series
Hufnagel (1997) | 22 | 1993-1996 | Germany | Dr. A. Hufnagel, Department of Neurology, University of Essen, Hufelandstr. 55, D-45122 Essen. Germany | No | Retrospective | Nested case-control with individual patient data
Pacia (1997) | 21 | 1992-1994 | United States | Departments of Neurology and Neurosurgery, New York University School of Medicine, Hospital for Joint Diseases, New York, NY, USA | No | Retrospective | Nested case-control with individual patient data
Patil (1997) | 19 | 1991-1995 | United States | Epilepsy Care Center, Immanuel Medical Center, Omaha, Nebraska, USA. | No | Retrospective | Nested case-control with individual patient data
Morrell (1995) | 14 | 1987-1994 | United States | Department of Neurological Science, Rush-Presbyterian-St Luke's Medical Center, Chicago, IL 60612, USA. | No | Retrospective | Nested case-control with individual patient data
Sawhney (1995) | 21 | 1989-1993 | England | Department of Clinical Neurophysiology, Maudsley Hospital, London UK. | No | Retrospective | Nested case-control with individual patient data
Shimizu (1991) | 12 | 1989-1990 | England | Department of Neurosurgery, Tokyo Metropolitan Neurological Hospital, Japan. | No | Retrospective | Case series

Evidence Table 106. Studies of hemispherectomy - general study information

Reference | Number of Patients | Years | Country | Author Affiliation | Multicenter Study | Method of Patient Selection | Study Design
Carreno (2001) | 13 | 1992-1999 | United States | Departments of Neurology (Drs. Carreno, Wyllie, and Kotagal), Neurosurgery (Drs. Bingaman and Comair), and Neuroradiology (Dr. Ruggieri), The Cleveland Clinic Foundation, OH. | No | Retrospective | Case series
Schramm (2001) | 20 | 1991-1999 | Germany | Dr. J. Schramm, Department of Neurosurgery, University of Bonn Medical Center, Sigmund-Freud-Strasse 25, 53105 Bonn. Germany | No | Retrospective | Case series
Di Rocco (2000) | 15 | 1985-1996 | Italy | Pediatric Neurosurgery, Catholic University Medical School, Rome, Italy. cdirocco@RM.Unicatt.it | No | Retrospective | Nested case-control with individual patient data
Shimizu (2000) | 34 | 1993-1999 | Japan | Department of Neurosurgery, Tokyo Metropolitan Neurological Hospital, Japan. smzh@tmnh.fuchu.tokyo.jp | No | Retrospective | Case series
Battaglia (1999) | 10 | 1987-1998 | Italy | Child Neurology and Psychiatry Unit, UCSC, Rome, Italy. | No | Retrospective | Case series
Wyllie (1998) | 16 | 1990-1996 | United States | Department of Neurology, The Cleveland Clinic Foundation, OH 44195, USA. | No | Retrospective | Case series
Vining (1997) | 58 | 1968-1996 | United States | Pediatric Epilepsy Center, Johns Hopkins Medical Institutions, Baltimore, Maryland, USA. | No | Retrospective | Case series
Peacock (1996) | 58 | 1986-1995 | United States | Department of Surgery, UCLA Medical Center 90095-7039, USA. | No | Retrospective | Case series
Schramm (1995) | 13 | 1992-1994 | Germany | Neurosurgical Department, University of Bonn, Germany. | No | Retrospective | Case series
Tinuper (1988) | 14 | 1974-1987 | Canada | Montreal Neurological Hospital and Institute, McGill University, Quebec, Canada. | No | Retrospective | Nested case-control with individual patient data
Lindsay (1987) | 17 | 1948-1986 | England | National Centre for Children with Epilepsy, Park Hospital for Children, Headington, Oxford. | No | Retrospective | Nested case-control with individual patient data

Evidence Table 107. Studies of corpus callosotomy - general study information

Reference | Number of Patients | Years | Country | Author Affiliation | Multicenter Study | Method of Patient Selection | Study Design
Hodaie (2001) | 17 | 1992-1999 | Canada | Division of Neurosurgery, Hospital for Sick Children and University of Toronto, Ont., Canada. | No | Retrospective | Case series
Kwan (2001) | 61 | 1989-1996 | Taiwan | Section of Epilepsy, Neurological Institute, Taipei Veterans General Hospital, Taiwan, ROC. sykwan@vghtpe.gov.tw | No | Retrospective | Nested case-control
Maehara (2001) | 52 | 1991-1998 | Japan | Department of Neurosurgery, Tokyo Metropolitan Neurological Hospital, Fuchu, Tokyo, Japan. maehara.nsrg@tmd.ac.jp | No | Retrospective | Nested case-control
Fandino-Franky (2000) | 97 | 1989-1997 | Colombia | Neurological Hospital, Colombian League Against Epilepsy, Cartagena. | No | Prospective | Case series
Matsuzaka (1999) | 22 | 1989-1994 | Japan | Department of Pediatrics, Nagasaki University School of Medicine, Sakamoto, Japan. neuro@net.nagasaki-u.ac.jp | No | Retrospective | Case series
McInerney (1999) | 47 | 1972-1999 | United States | Sections of Neurosurgery and Neurology, Dartmouth-Hitchcock Medical Center, Lebanon, NH 03756, USA. | No | Retrospective | Case series
Pinard (1999) | 17 | 1989-1995 | France | Unite de Neurochirurgie Pediatrique, Fondation Rothschild, Hopital Saint Vincent de Paul, Paris, France. | No | Retrospective | Nested case-control with individual patient data
Carmant (1998) | 28 | 1989-1993 | United States | Department of Neurology, Harvard Medical School, Children's Hospital, Boston, Massachusetts | No | Retrospective | Case series
Sorenson (1997) | 23 | 1991-1994 | United States | Department of Neurology, Texas Comprehensive Epilepsy Program, University of Texas, Houston 77225-0708, USA. | No | Retrospective | Case series
Andersen (1996) | 20 | 1988-1994 | Denmark | University Clinic of Neurology, Hvidovre Hospital, Denmark. | No | Retrospective | Case series
Rossi (1996) | 20 | 1988-1995 | Italy | Institute of Neurosurgery, Catholic University School of Medicine, Rome, Italy. | No | Retrospective | Case series
Sakas (1996) | 20 | 1984-1993 | Ireland | National Centre for Neurosurgery, Beaumont Hospital, Dublin, Ireland. | No | Retrospective | Nested case-control
Claverie (1995) | 20 | 1983-1993 | France | University of Bordeaux 2, B. P. 40 Carreire,F33076 Bordeaux Cedex. France | No | Retrospective | Nested case-control with individual patient data
Reutens (1993) | 64 | 1973-1991 | Australia | Department of Neurology, Austin Hospital,Heidelberg, Vic. 3084. Australia | Yes | Retrospective | Case series
Cohen (1991) | 10 | 1987-1989 | United States | Section of Pediatric Neurology, Medical College of Georgia, 1120 15th Street, Augusta, GA 30912.United States | No | Prospective | Nested case-control
Fuiks (1991) | 80 | 1985-1990 | United States | EpiCare Center, Baptist Memorial Hospital, University of Tennessee, Memphis. | No | Retrospective | Nested case-control
Nordgren (1991) | 18 | 1972-1987 | United States | Section of Neurology, Dartmouth-Hitchcock Medical Center, Hanover, NH 03756. | No | Retrospective | Nested case-control with individual patient data
Oguni (1991) | 43 | 1981-1989 | Canada | Montreal Neurological Hospital, Canada. | No | Retrospective | Case series
Marino (1990) | 28 | 1978-1985 | Brazil | Division of Functional Neurosurgery, Hospital das Clinicas, Sao Paulo, Brazil. | No | Retrospective | Nested case-control with individual patient data
Provinciali (1990) | 15 | 1987-1988 | Italy | Neurological Clinic, University of Ancona, Italy. | No | Prospective | Case series
Sass (1990) | 32 | 1985-1987 | United States | Section Neurological Surgery, Yale Univ. School of Medicine, 333 Cedar Street,New Haven, CT 06510. United States | No | Retrospective | Case series
Murro (1988) | 25 | 1980-1986 | United States | Department of Neurology, Medical College of Georgia, Augusta 30912. | No | Retrospective | Nested case-control with individual patient data
Purves (1988) | 24 | 1977-1987 | Canada | Division of Neurosciences and Neurology, University of British Columbia, Vancouver, Canada. | No | Retrospective | Nested case-control with individual patient data
Spencer (1988) | 22 | 1979-1983 | United States | Department of Neurology, Yale University School of Medicine, New Haven, CT 06510. | No | Retrospective | Nested case-control with individual patient data
Garcia-Flores (1987) | 14 | 1980-1986 | Mexico | Osler Clinic, Monterrey, Mexico. | No | Retrospective | Case series
Gates (1987) | 24 | 1979-1985 | United States | Comprehensive Epilepsy Program and Department of Neurosurgery, University of Minnesota, Minneapolis, Minnesota, U.S.A. | No | Retrospective | Nested case-control

Evidence Table 108. Studies with epilepsy surgery control patients - general study information

Reference | Number of Patients | Years | Country | Author Affiliation | Multicenter Study | Method of Patient Selection | Study Design
Bauer (2001) | 63 | 1970-1989 | Germany | Department of Epileptology, University of Bonn, Germany | No | Retrospective | Case series
Kumlien (2001) | 47 | 1993-1999 | United States | Minnesota Epilepsy Group, St. Paul, MN, U.S.A. | No | Retrospective | Case series
Wiebe (2001) | 40 | 1996-2000 | Canada | Department of Clinical Neurological Sciences, University of Western Ontario, and London Health Sciences Centre, Canada. swiebe@uwo.ca | No | Prospective | RCT
Markand (2000) | 37 | 1994-1997 | United States | Department of Neurology, Division of Biostatistics, Indiana University School of Medicine, Indianapolis, Indiana, USA. omarkand@iupui.edu | No | Prospective | Controlled
Holmes (1998) | 35 | 1977-1997 | United States | Department of Neurology, University of Washington, Seattle, USA. | No | Prospective | Case series
Wolf (1998) | 15 | 1987-1992 | Germany | Epilepsiezentrum Bethel, Bielefeld, Germany. | No | Prospective | Case series
McLachlan (1997) | 21 | 1992-1995 | Canada | Department of Clinical Neurological Sciences, University of Western Ontario, London, Canada. | No | Prospective | Controlled
Hermanns (1996) | 74 | 1992-1994 | Germany | Bethel Epilepsy Centre, Bielefeld, Germany. | No | Prospective | Case series
Vickrey (1995) | 46 | 1974-1990 | United States | Department of Neurology, University of California, Los Angeles, USA. | No | Retrospective | Case series
Guldvog (1991) | 185 | 1960-1989 | Norway | National Center for Epilepsy, Sandvika, Norway. | Yes | Retrospective | Matched controls
Huttenlocher (1990) | 155 | 1970-1989 | United States | Department of Pediatrics, University of Chicago, IL 60637. | No | Retrospective | Case series
Harbord (1987) | 38 | 1969-1985 | Australia | Department of Neurology, Adelaide Children's Hospital, South Australia. | No | Retrospective | Case series

Evidence Table 109. Studies excluded from the evidence base for seizure-free outcomes after temporal lobe surgery

Reference | N | Reason for Exclusion
So (1989) | 48 | Only patients with bitemporal epileptiform abnormalities were enrolled in this study. Because foci are seen in both temporal lobes, surgery for this condition can be expected to produce poor results compared to patients in whom only one lobe is involved

Evidence Table 110. Patient Characteristics for studies of temporal lobe surgery reporting seizurefree outcome measurements

Reference | Type of Surgery | Pathology | Mean Age at Treatment (Years) | SD of Age at Treatment | Mean Age at First Seizure (Years) | SD of Age at First Seizure | Mean Duration of condition Before Surgery (Year) | SD of Duration before Surgery (Years) | Right Side Surgeries | Left Side Surgeries | Males | Females | Number of Patients With Simple Partial Seizures | Number of Patients With Complex Partial Seizures | Number of Patients With Secondarily Generalized Seizures
Bouilleret (2002) | Standard | MTS | 26.4 | 7.1 | 8.6 | 3.8 | 17.9 | 9.1 | 10 | 8 | 5 | 13 | 16 | 18
Alsaadi (2001) | Not Described | Not reported | | | | | | | | | | | | 49 | 12
Boling (2001) | AH | Various (no tumors) | 54 | | 18 | | 34.9 | 12.1 | | | 9 | 9
Hennessy (2001) | Standard | MTS | 24
Hennessy (2001) | Standard | Non-MTS focal lesions | 19 | | | | | | 42 | 38 | 39 | 41 | 23 | 73 | 31
Jan (2001) | Not Described | Various | 28 | 6.9 | | | | | 14 | 15 | 13 | 16
Kanemoto (2001) | Standard | Not reported | 27.1 | 5.9 | 9.7 | 5.3 | 17.5 | 7.8 | 22 | 30 | 28 | 24
Schramm (2001) | Neocortex | Various | 27.9 | | 14.4 | | 13.6 | | 26 | 35 | 27 | 34 | 14 | 57 | 33
Sotero de Menezes (2001) | Tailored | Various | 8.3 | 3.1 | | | | | 9 | 5 | | | 10 | 14
Verma (2001) | Standard | Various | 34.3 | 11.7 | 8.5 | 8.9 | 25.8 | 14.1 | 7 | 6 | 7 | 6
Wilson (2001) | Standard | Not reported | 32.7 | 11.3 | 11.1 | 9.5 | | | | | 38 | 52 | | 90
Dupont (2000) | Partial | Various | 29 | | | | | | | | 13 | 17
Eberhardt (2000) | Tailored | Various | 34.6 | 7.8 | | | | | 9 | 11 | 12 | 8
Foldvary (2000) | Tailored | Various | 23.9 | 9 | | | 12.9 | 8.5 | 34 | 45 | 45 | 34 | 62 | 79 | 48
Holmes (2000) | Tailored | Various | 33 | | 16 | | 17 | | 7 | 16 | 8 | 15
Iannelli (2000) | Neocortex | Tumor | 9.1 | 5 | | | 2.8 | | 16 | 21 | 27 | 10 | 2 | 21 | 2
Markand (2000) | Tailored | Not reported | 31 | 10.8 | 12.3 | 9.7 | 18.7 | 11.7 | 26 | 27 | 33 | 20 | | 53 | 48
Rao (2000) | Standard | Various | 25.6 | | | | 16.1 | | | | 60 | 59 | | 119
Robinson (2000) | AH | Various | 15.4 | | 5.2 | | 10.3 | | 8 | 14 | 13 | 9 | | 22
Assaf (1999) | Partial | Various
Eriksson (1999) | Tailored | Various | 34 | | 14 | | 18 | | Adults | | 31 | 29
| Tailored | Various | 9.9 | | 1.5 | | 5.5 | | Children | | 7 | 8
Henry (1999) | Not Described | Not reported | | | | | | | | | | | | 38
Holmes (1999) | Not Described | Various | 35.2 | 10.9 | | | | | 8 | 5 | 3 | 10
Mathern (1999) | Tailored | Various | 11.7 | 0.8 | 5.3 | 0.8 | 6.4 | 0.7 | 16 | 15 | 22 | 9
Mitchell (1999) | Not Described | Various | 31
Rossi (1999) | Not Described | Tumor | 20.8 | | | | 7
Salanova (1999) | Tailored | Various | 30.4 | | 10.5 | | 19.7 | | 71 | 74
Son (1999) | Standard | MTS | 28.9 | | | | | | | | 45 | 26
Maher (1998) | Not Described | Various | 32 | 10 | | | | | 50 | 43 | 45 | 48
Radhakrishnan (1998) | Tailored | Various | 31 | | 8 | | 19 | | 68 | 107 | 77 | 98 | | 175
Szabo (1998) | Standard | Various | 9.4 | 1.7 | 3.6 | 2.2 | 5.8 | 2.3 | 7 | 7 | 7 | 7 | | 14
Bizzi (1997) | Partial | Various | 11.9 | 4.6 | | | | | | | 11 | 8
Cappabianca (1997) | Neocortex | Vascular malformation | 28.8
Casazza (1997) | Neocortex | Tumor | 30.9 | 8.9 | 21 | 9.6 | 9.9 | 6.8 | | | | | 35 | 33 | 16
Ho (1997) | Partial | Various | 31 | 10 | | | | | 28 | 35 | 30 | 33 | | 63
Keene (1997) | Neocortex | Various | 13 | 3.6 | 6 | 4.6 | | | 29 | 15 | 28 | 16
Kilpatrick (1997) | Standard | Various | 36.8 | 11.5 | 15 | | | | 8 | 10 | 11 | 7
McLachlan (1997) | Tailored | Various | 31.9 | 10.9 | 12.1 | 9.8 | | | 26 | 25 | 24 | 27 | | 51
Schwartz (1997) | Partial | MTS | 26.8 | 10.2 | | | | | 6 | 7 | 9 | 4 | | 13
Silander (1997) | Tailored | Various | 32 | | | | 18 | | Adults | | 34 | 34 | 20 | 63 | 32
| Tailored | Various | 14 | | | | 7.5 | | Children | | 11 | 13 | 5 | 27 | 11
Sisodiya (1997) | Standard | MTS | 28.2 | 6.9 | | | | | 16 | 11 | 11 | 16
Adam (1996) | Standard | MTS | | | 9.4 | 4.1 | | | 7 | 8
Goldstein (1996) | Tailored | Various | 9.3 | | 3.2 | | 6.1 | | 16 | 17 | 17 | 16
Holmes (1996) | Tailored | Various | 29.6 | | | | | | | | | | | 45
Sirven (1996) | Standard | Various | | | | | | | | | | | 174 | 174
Acciarri (1995) | Neocortex | Vascular malformation | 34.8 | 12.5 | 33.3 | 12.8 | 1.6 | 1.2 | 5 | 5 | 5 | 5 | | 10 | 0
Berkovic (1995) | Partial | Various | 29 | 10
Davies (1995) | Tailored | Various | 23 | | | | 8
Jooma (1995b) | Tailored | Various | | | | | 19
Jooma (1995a) | Tailored | Tumor | 34.1 | 10 | 14.4 | 7.3 | 19.7 | 7.7 | Tailored | | | | | 12 | 6
| Neocortex | Tumor | 26.5 | 17.3 | 23.8 | 18.6 | 2.7 | 3.1 | Neocortex | | | | | 12 | 6
Liu (1995) | Tailored | Other | 37.2 | 13.7 | 17.8 | 9.5 | 19.3 | 8.2 | 5 | 7 | 5 | 7 | 0 | 12 | 8
Renowden (1995) | AH | MTS | 23.6 | | | | 12 | | 3 | 14 | 6 | 11
| Standard | MTS | 21.3 | | | | 12 | | 33 | 17 | 26 | 24
Thadani (1995) | Standard | MTS | 33 | | 10 | | | | 11 | 11 | | | 19 | 22 | 4
Vossler (1995) | Tailored | Various | 14.3 | 3.9 | 5 | 4.4 | 9.3 | 4.4 | 13 | 17 | 19 | 11
Blume (1994) | Standard | Various | | | | | | | | | 64 | 61 | | 125
Guldvog (1994a) | Standard | Various | | | | | 8 | | 25 | 10
Guldvog (1994b) | Standard | Various | | | | | 11.5
Berkovic (1991) | Standard | MTS | 22.5 | 6 | 6.3 | 4.1 | 16.2 | 5.9 | 3 | 7 | 5 | 5 | 1 | 10 | 4
Hopkins (1991) | Standard | Various | 5.5 | 2.2 | 2 | 1.4 | 3.6 | 2.1 | 5 | 6 | 8 | 3 | | 11
Rasmussen (1991) | Standard | Not reported
Wieser (1991) | AH | Various | 29.7 | 13.7 | 18.8 | 15.3 | 11 | 10.2 | 114 | 101 | 120 | 95
Bidzinski (1990) | Standard | Not reported | 23 | | 8 | | 13
Mizrahi (1990) | Tailored | Various | 21 | 8.4 | 5.9 | 2.3 | 15.1 | 8.1 | 10 | 12
Walczak (1990) | Standard | Not reported | 25 | | | | 15 | | 45 | 55 | 59 | 41 | | 100
Yeh (1990) | Neocortex | Vascular malformation | 36.3 | 11.9 | 25.3 | 8.3 | 11 | 8.2 | 3 | 9 | 8 | 4 | 3 | 9 | 10
Sperling (1989) | Standard | Not reported | | | | | | | | | | | | 39
Estes (1988) | Tailored | Various | | | | | | | 12 | 13
Bladin (1987) | Standard | Not reported
Cutfield (1987) | Tailored | Various | 22 | | | | 12 | | 17 | 9 | 11 | 15 | | 26
Drake (1987) | Tailored | Tumor | 12.7 | 2.7 | 6.3 | 4.3 | 6.5 | 3.9 | | | 8 | 3 | 3 | 11 | 7
Lieb (1986) | Standard | Not reported | | | | | | | 46 | 29 | 40 | 35 | | 75
Meyer (1986) | Tailored | Not reported | 15.8 | | 7.5 | | 8.3 | | 27 | 23 | 29 | 21
Delgado-Escueta (1985) | Standard | Various | 26.5 | 6.9 | 15.8 | 8 | 10.7 | 4.9 | 5 | 10 | 12 | 3 | 1 | 15 | 12

AH Amygdalohippocampectomy

MTS Mesial temporal sclerosis

Evidance Table 111. Studies of temporal lobe surgery that reported patients as seizure-free with no auras^a^

Reference | N | Mean FollowupPeriod in Years | Minimum Followup | Maximum Followup | Number of PatientsSeizure Freewith No Auras | Percentage | Cohen's h Effect Sizes | Effect Size CI | P Values for Effect Sizes | Standardized Residuals for Effect Sizes
Bouilleret (2002) | 18 | 4.8 | 2 | 7 | 12 | 66.7 | 1.91 | 1.26–2.56 | <0.000001 | 0.73
Wilson (2001) | 90 | | 2 | | 47 | 52.2 | 1.62 | 1.32–1.91 | <0.000001 | -0.40
Dupont (2000) | 30 | 3.5 | 2.1 | 5.3 | 14 | 46.7 | 1.50 | 1.00–2.01 | <0.000001 | -0.66
Eberhardt (2000) | 20 | 3 | 2.2 | 3.7 | 7 | 35.0 | 1.27 | 0.65–1.89 | 0.000062 | -1.30
Holmes (2000) | 23 | 3 | 2 | 6 | 11 | 47.8 | 1.53 | 0.95–2.11 | <0.000001 | -0.50
Markand (2000) | 51 | | 2 | | 30 | 58.8 | 1.75 | 1.36–2.14 | <0.000001 | 0.40
Rao (2000) | 68 | | 2 | | 46 | 67.6 | 1.93 | 1.60–2.27 | <0.000001 | 1.59
Holmes (1999) | 13 | 3 | 2 | 5 | 7 | 53.8 | 1.65 | 0.88–2.42 | 0.000027 | -0.06
Rossi (1999) | 28 | | 2 | | 21 | 75.0 | 2.09 | 1.57–2.62 | <0.000001 | 1.62
Maher (1998) | 93 | | 2 | | 53 | 57.0 | 1.71 | 1.42–2.00 | <0.000001 | 0.29
Szabo (1998) | 14 | 2.8 | 2 | 4 | 10 | 71.4 | 2.01 | 1.27–2.75 | <0.000001 | 0.92
Casazza (1997) | 40 | 4.6 | 2 | | 19 | 47.5 | 1.52 | 1.08–1.96 | <0.000001 | -0.69
McLachlan (1997) | 40 | 2 | 2 | 2 | 18 | 45.0 | 1.47 | 1.03–1.91 | <0.000001 | -0.92
Schwartz (1997) | 13 | 2.4 | 2 | 3.3 | 7 | 53.8 | 1.65 | 0.88–2.42 | 0.000027 | -0.06
Sisodiya (1997) | 27 | 2.5 | 2 | 4 | 15 | 55.6 | 1.68 | 1.15–2.22 | <0.000001 | 0.04
Adam (1996) | 15 | 2.7 | 2 | 3.7 | 7 | 46.7 | 1.50 | 0.79–2.22 | 0.000038 | -0.46
Holmes (1996) | 45 | 4.5 | 4 | 5 | 27 | 60.0 | 1.77 | 1.36–2.19 | <0.000001 | 0.50
Renowden (1995) | 17 - AH | | 2 | | 8 | 47.1 | 1.51 | 0.84–2.18 | 0.000010 | -0.47
| 50 - Standard lobectomy | | 2 | | 25 | 50.0 | 1.57 | 1.18–1.96 | <0.000001 | -0.52
Meyer (1986) | 24 | 5 | 5 | | 10 | 41.7 | 1.40 | 0.84–1.97 | 0.000001 | -0.94
Delgado-Escueta (1985) | 15 | 6 | 2 | 11 | 9 | 60.0 | 1.77 | 1.06–2.49 | 0.000001 | 0.28

a Seizure-free with no auras means that patients are free of complex and simple partial seizures

AH Amygdalohippocampectomy

Evidence Table 112. Studies of temporal lobe surgery that reported patients as seizure-free with auras^a^

Reference | N | Mean Followup Period in Years | Minimum Followup | Maximum Followup | Number of Patients Seizure Free With Auras | Percentage | Cohen's h Effect Sizes | Effect Size CI | P Values for Effect Sizes | Standardized Residuals for Effect Sizes
Hennessy (2001) | 116 | 5 | 2 | | 78 | 67.2 | 1.92 | 1.67–2.18 | <0.000001 | -0.21
Hennessy (2001) | 80 | | 2 | | 52 | 65.0 | 1.88 | 1.57–2.19 | <0.000001
Jan (2001) | 29 | | 2 | | 23 | 79.3 | 2.2 | 1.68–2.71 | <0.000001 | 0.95
Sotero de Menezes (2001) | 14 | 5 | 2 | 10 | 6 | 42.9 | 1.43 | 0.69–2.17 | 0.000159 | -1.39
Verma (2001) | 13 | | 2 | | 9 | 69.2 | 1.97 | 1.20–2.73 | 0.000001 | 0.04
Wilson (2001) | 90 | | 2 | | 60 | 66.7 | 1.91 | 1.62–2.20 | <0.000001 | -0.27
Eberhardt (2000) | 20 | 3 | 2.2 | 3.7 | 13 | 65.0 | 1.88 | 1.26–2.50 | <0.000001 | -0.23
Markand (2000) | 51 | | 2 | | 37 | 72.5 | 2.04 | 1.65–2.43 | <0.000001 | 0.46
Assaf (1999) | 75 | | 2 | | 52 | 69.3 | 1.97 | 1.65–2.29 | <0.000001 | 0.12
Eriksson (1999) | 15 - children | | 2 | | 9 | 60.0 | 1.77 | 1.06–2.49 | <0.000001 | -0.49
| 60 - adults | | | | 34 | 56.7 | 1.70 | 1.35–2.06 | <0.000001 | -1.37
Mitchell (1999) | 45 | | 2 | | 26 | 57.8 | 1.73 | 1.31–2.14 | <0.000001 | -1.07
Radhakrishnan (1998) | 175 | 3.6 | 2 | 5.7 | 134 | 76.6 | 2.13 | 1.92–2.34 | <0.000001 | 1.82
Ho (1997) | 63 | 4.1 | 2 | 6.2 | 38 | 60.3 | 1.78 | 1.43–2.13 | <0.000001 | -0.98
Kilpatrick (1997) | 18 | 2.5 | 2 | 3.2 | 13 | 72.2 | 2.03 | 1.38–2.68 | <0.000001 | 0.25
Reeves (1997) | 134 | 4.2 | 2.5 | 6.5 | 107 | 79.9 | 2.21 | 1.97–2.45 | <0.000001 | 2.25
Schwartz (1997) | 13 | 2.4 | 2 | 3.3 | 9 | 69.2 | 1.97 | 1.20–2.73 | 0.000001 | 0.04
Sisodiya (1997) | 27 | 2.5 | 2 | 4 | 16 | 59.3 | 1.76 | 1.22–2.29 | <0.000001 | -0.71
Adam (1996) | 15 | 2.7 | 2 | 3.7 | 12 | 80.0 | 2.21 | 1.50–2.93 | <0.000001 | 0.73
Liu (1995) | 12 | 5.3 | 2.2 | 8.5 | 6 | 50.0 | 1.57 | 0.77–2.37 | 0.000119 | -0.93
Vossler (1995) | 30 | 6.4 | 2.3 | 14.8 | 20 | 66.7 | 1.91 | 1.40–2.42 | <0.000001 | -0.15
Blume (1994) | 125 | 5.5 | 2 | 16 | 87 | 69.6 | 1.97 | 1.73–2.22 | <0.000001 | 0.20
Walczak (1990) | 100 | | 2 | | 63 | 63.0 | 1.83 | 1.56–2.11 | <0.000001 | -0.85
Yeh (1990) | 12 | 3.7 | 2 | 6 | 10 | 83.3 | 2.30 | 1.50–3.10 | <0.000001 | 0.86
Estes (1988) | 25 | 4.1 | 2.2 | 7 | 9 | 36.0 | 1.29 | 0.73–1.84 | 0.000005 | -2.36
Meyer (1986) | 24 | 5 | 5 | | 18 | 75.0 | 2.09 | 1.53–2.66 | <0.000001 | 0.51
Delgado-Escueta (1985) | 15 | 6 | 2 | 11 | 11 | 73.3 | 2.06 | 1.34–2.77 | <0.000001 | 0.29

a Seizure-free with auras means the patients are free of complex seizures but may have simple partial seizures

Evidence Table 113. Studies of surgery control patients reporting seizure-free outcome measurements

| | | | | | | Number of Patients and Percentage
Reference | N | Years | Country | Mean Followup Period in Years | Minimum Followup | Maximum Followup | Seizure-Free (undefined) | % | Seizure-Free (no auras) | % | Seizure-Free (with auras) | % | Engel Class I | %
Bauer (2001) | 63 | 1970-1989 | Germany | 8.7 | 3.7 | 19 | 9 | 14.3
Kumlien (2001) | 47 | 1993-1999 | USA | 3.4 | 2 | | 11 | 23.4
Wiebe (2001) | 40 | 1996-2000 | Canada | | 1 | | | | 1 | 2.5 | 3 | 7.5
Markand (2000) | 33 | 1994-1997 | USA | | 1 | | | | 0 | 0.0
Holmes (1998) | 35 | 1977-1997 | USA | | 10 | | 2 | 5.7
Wolf (1998) | 15 | 1987-1992 | Germany | | 4 | | | | 3 | 20.0 | 4 | 26.7 | 4 | 26.7
McLachlan (1997) | 21 | 1992-1995 | Canada | | 2 | | 0 | 0.0
Hermanns (1996) | 74 | 1992-1994 | Germany | 1.3 | 0.9 | 2 | 0 | 0.0
Vickrey (1995) | 43 | 1974-1990 | USA | 5.7 | 1 | 17 | | | 2 | 4.7 | 4 | 9.3
Guldvog (1991) | 185 | 1960-1989 | Norway | 9 | 2 | 31 | Reported changes in seizure frequency only
Huttenlocher (1990) | 155 | 1970-1989 | USA | 13 | 5 | 20 | 0 | 0.0
Harbord (1987) | 38 | 1969-1985 | Australia | 6.6 | 2 | 15 | 4 | 10.5

Evidence Table 114. Studies with epilepsy surgery control patients - reasons for patients not to receive surgery

Reference | Number of Patients | Control Group | Number of Patients Who Refused Surgery | Number of Patients Who Were Unsuitable For Surgery | Number of Patients Who Were Actual Surgical Candidates
Bauer (2001) | 63 | Medical management control
Kumlien (2001) | 47 | Temporal lobe - nonsurgical control | | 47
Wiebe (2001) | 40 | Temporal lobe - nonsurgical control | 0 | 0 | 40
Markand (2000) | 37 | Temporal lobe - nonsurgical control | 5 | 32
Holmes (1998) | 35 | Medical management control | 35
Wolf (1998) | 15 | Medical management control | 15
McLachlan (1997) | 21 | Temporal lobe - nonsurgical control | 8 | 13
Hermanns (1996) | 74 | Medical management control
Vickrey (1995) | 46 | Medical management control | 2 | 44
Guldvog (1991) | 185 | Medical management control | | | 38
Huttenlocher (1990) | 155 | Medical management control
Harbord (1987) | 38 | Medical management control

Evidence Table 115. Comparisons of summary estimates based on study level characteristics for temporal lobe surgery studies reporting seizure-free with no auras^ a^

| | | 95% Confidence Intervals | | | 95% Confidence Intervals
Study Level Characteristics | Number of Studies | Cohen's h Summary Estimate | Lower | Upper | Back-transformed Percentage Estimate | Lower | Upper
United States | 8 | 1.69 | 1.50 | 1.89 | 56% | 46% | 66%
Other countries | 13 | 1.66 | 1.54 | 1.78 | 54% | 48% | 60%
Mesial temporal sclerosis only | 6 | 1.63 | 1.39 | 1.86 | 53% | 41% | 64%
Various other pathologies | 15 | 1.68 | 1.57 | 1.79 | 55% | 50% | 61%
Standard temporal lobectomy | 11 | 1.74 | 1.61 | 1.88 | 58% | 52% | 65%
Tailored temporal lobectomy | 6 | 1.59 | 1.39 | 1.78 | 51% | 41% | 60%
Other surgical procedures | 4 | 1.53 | 1.25 | 1.81 | 48% | 34% | 62%

a Studies were regrouped according to the selected study level characteristics and new summary estimates were calculated.

Evidence Table 116. Comparisons of summary estimates based on study level characteristics for temporal lobe surgery studies reporting seizure-free with auras.^ a^

| | | 95% Confidence Intervals | | | 95% Confidence Intervals
Study Level Characteristics | Number of Studies | Cohen's h Summary Estimate | Lower | Upper | Back-transformed Percentage Estimage | Lower | Upper
United States | 13 | 2.00 | 1.90 | 2.11 | 71% | 66% | 76%
Other countries | 14 | 1.90 | 1.79 | 2.00 | 66% | 61% | 71%
Mesial temporal sclerosis only | 4 | 1.93 | 1.71 | 2.14 | 68% | 57% | 77%
Various other pathologies | 23 | 1.95 | 1.87 | 2.03 | 69% | 65% | 72%
Standard temporal lobectomy | 11 | 1.97 | 1.87 | 2.07 | 69% | 65% | 74%
Tailored temporal lobectomy | 10 | 1.93 | 1.79 | 2.06 | 68% | 61% | 73%
Other surgical procedures | 6 | 1.92 | 1.74 | 2.10 | 67% | 58% | 75%

a Studies were regrouped according to the selected study level characteristics and new summary estimates were calculated.

Evidence Table 117. Studies of temporal lobe surgery that reported patients as Enget class I

Reference | Number of Patients Evaluated | Mean Followup Period in Years | Minimum Followup | Maximum Followup | Number of Patients in Engel Class I | Percentage | Cohen's h Effect Sizes | Effect Size CI | p Values for Effect Sizes | Standardized Residuals for Effect Sizes
Bouilleret (2002) | 18 | 4.8 | 2 | 7 | 16 | 88.9 | 1.63 | 1.32–1.95 | <0.000001 | 1.59
Alsaadi (2001) | 49 | | 2 | | 37 | 75.5 | 2.09 | 1.29–2.89 | <0.000001 | 0.87
Boling (2001) | 18 | 5.3 | 2 | | 11 | 61.1 | 1.50 | 1.18–1.82 | <0.000001 | -0.42
Kanemoto (2001) | 52 | 7 | 2 | 12 | 42 | 80.8 | 1.43 | 0.69–2.17 | <0.000001 | 1.56
Schramm (2001) | 32 | 2 | 2 | 2 | 26 | 81.3 | 1.66 | 1.24–2.08 | <0.000001 | 1.26
Sotero de Menezes (2001) | 14 | 5 | 2 | 10 | 6 | 42.9 | 1.97 | 1.73–2.22 | 0.000159 | -1.34
Dupont (2000) | 30 | 3.5 | 2.1 | 5.3 | 24 | 80.0 | 1.76 | 1.52–2.00 | <0.000001 | 1.10
Eberhardt (2000) | 20 | 3 | 2.2 | 3.7 | 13 | 65.0 | 1.60 | 1.15–2.04 | <0.000001 | -0.18
Foldvary (2000) | 79 | | 2 | | 42 | 53.2 | 2.62 | 1.90–3.33 | <0.000001 | -1.93
Iannelli (2000) | 32 | 6 | 2 | 14 | 26 | 81.3 | 2.11 | 1.71–2.50 | <0.000001 | 1.26
Markand (2000) | 51 | | 2 | | 37 | 72.5 | 1.79 | 1.14–2.45 | <0.000001 | 0.54
Robinson (2000) | 17 | 2.7 | 2 | 5.5 | 11 | 64.7 | 2.23 | 1.85–2.62 | <0.000001 | -0.19
Salanova (1999) | 144 | | 2 | | 91 | 63.2 | 2.25 | 1.76–2.74 | <0.000001 | -0.85
Son (1999) | 71 | 3.2 | 2 | 5 | 66 | 93.0 | 1.84 | 1.61–2.07 | <0.000001 | 4.09
Maher (1998) | 93 | | 2 | | 73 | 78.5 | 2.01 | 1.27–2.75 | <0.000001 | 1.71
Szabo (1998) | 14 | 2.8 | 2 | 4 | 10 | 71.4 | 2.01 | 1.27–2.75 | <0.000001 | 0.21
Bizzi (1997) | 14 | 4.8 | 2 | 7 | 10 | 71.4 | 1.72 | 1.28–2.16 | <0.000001 | 0.21
Casazza (1997) | 40 | 4.6 | 2 | | 23 | 57.5 | 1.67 | 1.43–1.91 | <0.000001 | -0.96
Keene (1997) | 44 | 7.7 | 2 | | 24 | 54.5 | 1.05 | 0.25–1.85 | <0.000001 | -1.29
Kilpatrick (1997) | 18 | 2.5 | 2 | 3.2 | 13 | 72.2 | 2.56 | 1.76–3.36 | <0.000001 | 0.30
Sisodiya (1997) | 27 | 2.5 | 2 | 4 | 16 | 59.3 | 2.26 | 1.67–2.85 | <0.000001 | -0.65
Adam (1996) | 15 | 2.7 | 2 | 3.7 | 15 | 100.0 | 2.21 | 1.34–3.09 | <0.000001 | 3.32
Berkovic (1995) | 135 | 3.7 | 2 | 6.8 | 74 | 54.8 | 2.03 | 1.38–2.68 | <0.000001 | -2.29
Davies (1995) | 12 | 7.4 | 2 | | 9 | 75.0 | 1.76 | 1.22–2.29 | <0.000001 | 0.40
Jooma (1995b) | 62 | | 2 | | 40 | 64.5 | 3.14 | 2.43–3.86 | <0.000001 | -0.39
Jooma (1995a) | 12 - lesionectomy | 3.4 | 2 | 7 | 3 | 25.0 | 1.87 | 1.51–2.22 | 0.010315 | -2.18
| 12 - tailored surgery | 5 | 2.5 | 7 | 11 | 91.7 | 2.46 | 1.81–3.12 | <0.000001 | 1.53
Thadani (1995) | 22 | 4 | 3 | 9 | 18 | 81.8 | 2.25 | 1.76–2.74 | <0.000001 | 1.09
Blume (1994) | 125 | 5.5 | 2 | 16 | 87 | 69.6 | 2.21 | 1.71–2.72 | <0.000001 | 0.33
Berkovic (1991) | 10 | 2.8 | 2.4 | 3.3 | 8 | 80.0 | 1.88 | 1.26–2.50 | 0.000001 | 0.63
Wieser (1991) | 138 | | 2 | | 82 | 59.4 | 2.04 | 1.65–243 | <0.000001 | -1.51
Sperling (1989) | 39 | 5.7 | 3 | 9 | 20 | 51.3 | 1.87 | 1.20–2.54 | <0.000001 | -1.51
Lieb (1986) | 75 | 8 | 2 | 21 | 35 | 46.7 | 2.60 | 2.28–2.93 | <0.000001 | -2.70
Delgado-Escueta (1985) | 15 | 6 | 2 | 11 | 14 | 93.3 | 2.18 | 1.89–2.46 | <0.000001 | 1.89

Evidence Table 118. Studies of temporal lobe surgery reporting Engel class I - data used in meta-regression

Reference | N | Cohen's h Effect Size | Weight | Year Study Started | Year Study Ended | United States
Bouilleret (2002) | 18 | 2.46 | 9 | 1993 | 2000 | No
Alsaadi (2001) | 49 | 2.11 | 24.5 | 1989 | 1994 | Yes
Boling (2001) | 18 | 1.79 | 9 | 1981 | 1999 | No
Kanemoto (2001) | 52 | 2.23 | 26 | 1987 | 1999 | No
Schramm (2001) | 32 | 2.25 | 16 | 1993 | 1999 | No
Sotero de Menezes (2001) | 14 | 1.43 | 7 | 1978 | 1993 | Yes
Dupont (2000) | 30 | 2.21 | 15 | 1994 | 1999 | No
Eberhardt (2000) | 20 | 1.88 | 10 | 1995 | 1999 | No
Foldvary (2000) | 79 | 1.63 | 39.5 | 1962 | 1984 | Yes
Iannelli (2000) | 32 | 2.25 | 16 | 1981 | 1997 | No
Markand (2000) | 51 | 2.04 | 25.5 | 1994 | 1997 | Yes
Robinson (2000) | 17 | 1.87 | 8.5 | 1993 | 1998 | Yes
Salanova (1999) | 144 | 1.84 | 72 | 1984 | 1995 | Yes
Son (1999) | 71 | 2.60 | 35.5 | 1994 | 1999 | No
Maher (1998) | 93 | 2.18 | 46.5 | 1994 | 1996 | No
Szabo (1998) | 14 | 2.01 | 7 | 1989 | 1994 | Yes
Bizzi (1997) | 14 | 2.01 | 7 | 1990 | 1994 | Yes
Casazza (1997) | 40 | 1.72 | 20 | 1988 | 1994 | No
Keene (1997) | 44 | 1.66 | 22 | 1975 | 1996 | No
Kilpatrick (1997) | 18 | 2.03 | 9 | 1993 | 1995 | No
Sisodiya (1997) | 27 | 1.76 | 13.5 | 1993 | 1995 | No
Adam (1996) | 15 | 3.14 | 7.5 | 1991 | 1994 | No
Berkovic (1995) | 135 | 1.67 | 67.5 | 1986 | 1991 | No
Davies (1995) | 12 | 2.09 | 6 | 1969 | 1988 | No
Jooma (1995b) | 62 | 1.87 | 31 | 1992 | 1994 | Yes
Jooma (1995a) | 12 - lesionectomy | 1.05 | 6 | 1985 | 1992 | Yes
| 12 - tailored surgery | 2.56 | 6 | 1985 | 1992 | Yes
Thadani (1995) | 22 | 2.26 | 11 | 1983 | 1992 | Yes
Blume (1994) | 125 | 1.97 | 62.5 | 1974 | 1989 | No
Berkovic (1991) | 10 | 2.21 | 5 | 1985 | 1986 | No
Wieser (1991) | 138 | 1.76 | 69 | 1975 | 1990 | No
Sperling (1989) | 39 | 1.60 | 19.5 | 1976 | 1983 | Yes
Lieb (1986) | 75 | 1.50 | 37.5 | 1961 | 1977 | Yes
Delgado-Escueta (1985) | 15 | 2.62 | 7.5 | 1972 | 1983 | Yes

Evidence Table 119. Results of meta-regression of studies of temporal lobe surgery reporting Engel class I

One predictor models
Parameter | Qe | p value for Qe | Intercept | CI of Intercept | p Value for Intercept | Coefficient | CI of Coefficient | p Value for Coefficient
Year study ended | 55.7 | 0.006 | -58.5 | -83.7 - -33.3 | .0000006 | 0.030 | 0.017 – 0.044 | 0.000009
Year study started | 56.7 | 0.005 | -30.7 | -44.6 - -16.7 | 0.000016 | 0.016 | 0.009 – 0.024 | 0.00001
United States | 72.1 | 0.00006 | 1.8 | 1.7 – 1.9 | <0.000001 | 0.174 | 0.030 – 0.318 | 0.018
Two predictor models
Year study ended, | 54.4 | 0.006 | -50.4 | -79.1 - -21.7 | 0.006 | 0.019 | -0.005 – 0.042 | 0.12
Year study started | | | | | | 0.008 | -0.006 – 0.021 | 0.26
Year study started, | 54.8 | 0.005 | -28.4 | -42.7 - -14.1 | 0.0001 | 0.015 | 0.007 –0.002 | 0.00007
United States | | | | | | -0.105 | -0.250 - 0.040 | 0.16
Year study ended, | 55.0 | 0.005 | -54.5 | -81.3 - -27.7 | 0.00007 | 0.028 | -0.220 - 0.090 | 0.39
United States | | | | | | 0.028 | 0.020 – 0.040 | 0.00003
Three predictor model
Year study started, | 53.4 | 0.005 | -44.9 | -75.6 - -14.3 | 0.004 | 0.015 | -0.01 – 0.04 | 0.24
Year study started, | | | | | | 0.008 | -0.005 – 0.020 | 0.21
United States | | | | | | -0.079 | -0.07 – 0.23 | 0.31

Evidence Table 120. Studies of temporal lobe surgery that reported patients as seizure-free undefined

Reference | Number of Patients Evaluated | Mean Followup Period in Years | Minimum Followup | Maximum Followup | Number of Patients Seizure Free Undefined | Percentage | Cohen's h Effect Sizes | Effect Size CI | p Values for Effect Sizes | Standardized Residuals for Effect Sizes
Henry (1999) | 38 | 6.2 | 5 | 7.2 | 27 | 71.1 | 2.01 | 1.56–2.46 | <0.000001 | 0.90
Mathern (1999) | 20 | | 2 | | 13 | 65.0 | 1.88 | 1.26–2.50 | <0.000001 | 0.23
Cappabianca (1997) | 10 | | 2 | | 8 | 80.0 | 2.21 | 1.34–3.09 | 0.000001 | 0.92
Silander (1997) | 25 children | | 2 | | 12 | 48.0 | 1.64 | 1.28–1.99 | <0.000001 | -0.97
| 62 adults | | | | 33 | 53.2 | 1.53 | 0.98–2.09 | <0.000001 | -0.98
Goldstein (1996) | 33 | 4.7 | 2 | 10 | 15 | 45.5 | 1.48 | 1.00–1.96 | <0.000001 | -1.34
Sirven (1996) | 174 | 2.7 | 2.3 | 8 | 136 | 78.2 | 2.17 | 1.96–2.38 | <0.000001 | 3.76
Acciarri (1995) | 10 | 5.2 | 2 | 14 | 10 | 100.0 | 3.14 | 2.27–4.02 | <0.000001 | 3.01
Guldvog (1994b) | 53 adults | 7 | 2 | 26 | 29 | 54.7 | 1.67 | 1.28–2.05 | <0.000001 | -0.73
Guldvog (1994a) | 34 children | 7 | 2 | | 23 | 67.6 | 1.93 | 1.46–2.41 | <0.000001 | 0.54
Hopkins (1991) | 11 | 3.6 | 2 | 7.5 | 8 | 72.7 | 2.04 | 1.21–2.88 | 0.000002 | 0.56
Rasmussen (1991) | 100 | 12 | 2 | 24 | 55 | 55.0 | 1.67 | 1.39–1.95 | <0.000001 | -0.99
Bidzinski (1990) | 286 | 16 | 2 | 30 | 140 | 49.0 | 1.55 | 1.39–1.71 | <0.000001 | -3.61
Mizrahi (1990) | 22 | 5.3 | 2 | 8 | 14 | 63.6 | 1.85 | 1.26–2.44 | <0.000001 | 0.15
Bladin (1987) | 63 | | 2 | | 51 | 81.0 | 2.24 | 1.89–2.59 | <0.000001 | 2.52
Cutfield (1987) | 25 | 12 | 5 | 17 | 13 | 52.0 | 1.61 | 1.06–2.17 | <0.000001 | -0.69
Drake (1987) | 11 | 2.7 | 2 | 5 | 7 | 63.6 | 1.85 | 1.01–2.68 | 0.000015 | 0.10

Evidence Table 121. Studies of temporal lobe surgery reporting seizure-free undefined - data used in meta-regression

Reference | N | Cohen's h Effect Size | Weight | Year Study Started | Year Study Ended | United States
Henry (1999) | 38 | 2.01 | 19 | 1991 | 1994 | Yes
Mathern (1999) | 20 | 1.88 | 10 | 1986 | 1997 | Yes
Cappabianca (1997) | 10 | 2.21 | 5 | 1985 | 1994 | No
Silander (1997) | 25 children | 1.64 | 31 | 1980 | 1990 | No
| 62 adults | 1.53 | 12.5 | 1980 | 1990 | No
Goldstein (1996) | 33 | 1.48 | 16.5 | 1985 | 1993 | Yes
Sirven (1996) | 174 | 2.17 | 87 | 1985 | 1992 | Yes
Acciarri (1995) | 10 | 3.14 | 5 | 1975 | 1992 | No
Guldvog (1994b) | 53 adults | 1.67 | 26.5 | 1949 | 1988 | No
Guldvog (1994a) | 34 children | 1.93 | 17 | 1952 | 1988 | No
Hopkins (1991) | 11 | 2.04 | 5.5 | 1978 | 1988 | No
Rasmussen (1991) | 100 | 1.67 | 50 | 1961 | 1980 | No
Bidzinski (1990) | 286 | 1.55 | 143 | 1957 | 1988 | No
Mizrahi (1990) | 22 | 1.85 | 11 | 1980 | 1986 | Yes
Bladin (1987) | 63 | 2.24 | 31.5 | 1987 | 1985 | No
Cutfield (1987) | 25 | 1.61 | 12.5 | 1961 | 1980 | No
Drake (1987) | 11 | 1.85 | 5.5 | 1974 | 1986 | No

Evidence Table 122. Results of meta-regression of studies of temporal lobe surgery reporting seizure-free undefined

One predictor models
Parameter | Q_e_ | p value for Q_e_ | Intercept | CI of Intercept | p value for Intercept | Coefficient | CI of Coefficient | p value for Coefficient
Year study started | 26.2 | 0.036 | -24.7 | -37.3–-12.2 | 0.0001 | 0.013 | 0.007–0.019 | 0.000008
United States | 33.6 | 0.004 | 1.7 | 1.6–1.8 | <0.000001 | 0.311 | 0.116–0.506 | 0.002
Year study ended | 37.8 | 0.001 | -51.9 | -96.2–-7.6 | 0.022 | 0.027 | 0.004–0.049 | 0.017
Two predictor models
Year study started | 26.1 | 0.025 | -23.3 | -41.2–-5.4 | 0.011 | 0.013 | 0.004–0.021 | 0.004
United States | | | | | | 0.032 | -0.247–0.310 | .824
Year study started | 26.2 | 0.025 | -24.9 | -71.8–22.0 | .298 | 0.013 | 0.006–0.020 | 0.0002
Year study ended | | | | | | 0.0001 | -0.027–0.027 | 0.996
Year study ended | 33.3 | 0.003 | -14.1 | -70.6–42.5 | 0.626 | 0.008 | -0.020–0.036 | 0.579
United States | | | | | | 0.267 | 0.018–0.516 | 0.036
Three predictor model.
Year study started | 26.1 | 0.016 | -21.0 | -77.8–35.8 | 0.469 | 0.36 | -0.264–0.337 | 0.812
Year study started | | | | | | 0.013 | 0.003–0.002 | 0.010
United States | | | | | | -0.001 | -0.028–0.030 | 0.932

Evidence Table 123. Studies of temporal lobe surgery reporting relationships between patient or study characteristics and treatment outcome

| | | | Patient or Study Characteristics Examined
Reference | N | Seizure Outcome Measurement | Statistical Method | Age at Surgery | Age at Seizure Onset | Duration of Epilepsy Prior to Surgery | Length of Followup | Gender | Side of Surgery | Complex Partial Seizures | Simple Partial Seizures | Secondarily Generalized Seizures | Mesial Temporal Sclerosis
Hennessy (2001) | 80 | Seizure-free with auras | Univariate | Sig. | NS | Sig. | | NS | NS | NS | NS | NS
Hennessy (2001) | 116 | Seizure-free with auras | Univariate | NS | NS | NS | | | | | | Sig.
Foldvary (2000) | 79 | Engel class I | Univariate | NS | | NS | | NS | NS
Holmes (2000) | 23 | Seizure-free no auras | Univariate | NS | NS | NS | | NS | NS | | | | NS
Robinson (2000) | 22 | Engel class I | Univariate | NS | NS | NS | | | NS
Radhakrishnan (1998) | 175 | Seizure-free with auras | Univariate | NS | NS | NS | NS | | | | | | Sig.
Goldstein (1996) | 33 | Seizure-free (undefined) | Univariate | NS | NS | NS | | | NS | | | | NS
Blume (1994) | 125 | 90% Reduction in Seizure Frequency | Multiple regression | Sig. | | | | | | | | | NS
Cutfield (1987) | 26 | Seizure-free (undefined) | Multiple regression | | NS | NS | | | | | | | NS

Sig. Statistically significant according to authors

NS Not statistically significant according to authors

Evidence Table 124. Studies of temporal lobe surgery reporting relationships between patient characteristics and treatment outcome - other study variables

Reference | Number of Patients | Seizure Outcome Measurement | Statistical Method | Other Study Variables
Alsaadi (2001) | 49 | Engel class I | Univariate | Ictal and postictal clinical manifestations (NS)
Hennessy (2001) | 80 | Seizure-free with auras | Univariate | Special schooling (Sig.), Developmental dysplastic lesions (Sig.), Perinatal complications (NS), Delayed developmental milestones (NS), Family history of epilepsy (NS), Febrile convulsion (NS), EEG spikes confined to temporal lobe (NS), Neoplasms (NS)
Hennessy (2001) | 116 | Seizure-free with auras | Univariate | Perinatal complications (Sig.), EEG interictal spikes confined to operated temporal lobe (Sig.), Febrile convulsion (NS), Developmental delay (NS), Special schooling (NS), Psychiatric history (NS), Family history of epilepsy (NS), Lateralized abnormality on physical examination (NS)
Dupont (2000) | 30 | Seizure-free no auras | Multiple regression | PET determined metabolism of the temporal pole, basofrontal cortex, anterior part of the lateral temporal neocortex, and medial temporal cortex (Sig.)
Foldvary (2000) | 79 | Engel class I | Univariate | Monthly frequency of CPS less than 20 (Sig.), Recorded seizures during routine or prolonged EEG (NS)
Holmes (2000) | 23 | Seizure-free no auras | Univariate | EEG finding of basal-temporal ictal onset (Sig.), EEG finding of unilateral basal-temporal interictal epileptiform patterns (Sig.)
Robinson (2000) | 22 | Engel class I | Univariate | History of febrile seizures (NS), IAP memory localization (NS), Unilateral hypometabolism (Sig.)
Salanova (1999) | 144 | Engel class I | Univariate | History of febrile seizures (Sig.), MTS or discrete lesion (Sig.), Availability of PET scan and volumetric MRI (Sig.), Unitemporal interictal spiking (NS), Bitemporal interictal spiking (NS)
Radhakrishnan (1998) | 175 | Seizure-free with auras | Univariate | Scalp interictal epileptiform discharges concordant with ictal onset (Sig.), Seizure-free during first year (Sig.), No epileptiform discharge at 3 mo (Sig.), Symptomatic epilepsy etiology (NS), History of febrile seizure (NS), Lesions other than MTS on neuroimaging (NS), No epileptiform discharge at 1 wk (NS),
Goldstein (1996) | 33 | Seizure-free (undefined) | Univariate | Generalized motor seizures (NS) Mental retardation (NS), Unitlateral temporal interictal activity (NS), Unilateral temporal ictal activity (NS), Significant etiological history (NS)
Blume (1994) | 115 | Seizure-free with auras | Multiple regression | Febrile convulsions as etiology (NS), No generalized motor seizures (Sig.), Lateralized temporal spikes (Sig.), No extra-anterior temporal spikes on any record (Sig.), No postoperative seizures within one week of surgery (Sig.)
So (1989) | 48 | Engel class I | Univariate | Stereotactic depth EEG unilateral (seizure onset in the resected lobe) (Sig.), History of early convulsion (<3 yr) (Sig.), Extent of hippocampal removal (Sig.), Residual ECoG epileptiform abnormalities (Sig.), Early postoperative seizures (<2 mo) (Sig.), Pathology (NS), Major etiological factor (NS)
Cutfield (1987) | 26 | Seizure-free (undefined) | Multiple regression | EEG findings (NS)

Sig. Statistically significant according to authors NS Not statistically significant according to authors

Evidence Table 125. Studies of temporal lobe surgery reporting individual patient age at surgery

| | | | 95% Confidence Interval
Reference | Number of Patients | Seizure Outcome Measurement | Point-Biserial Correlation^a^ | Lower | Upper | Standardized Residuals for Effect Sizes
Bouilleret (2002) | 18 | Seizure-free no auras | 0.27 | -0.23 | 0.65 | 0.97
Sotero de Menezes (2001) | 14 | Seizure-free with auras | -0.37 | -0.75 | 0.20 | -1.42
Verma (2001) | 13 | Seizure-free with auras | -0.29 | -0.73 | 0.31 | -1.07
Eberhardt (2000) | 20 | Seizure-free no auras | 0.07 | -0.39 | 0.49 | 0.15
Holmes (1999) | 13 | Seizure-free no auras | 0.23 | -0.37 | 0.69 | 0.65
Szabo (1998) | 14 | Seizure-free with auras | -0.03 | -0.55 | 0.51 | -0.20
Kilpatrick (1997) | 18 | Seizure-free with auras | -0.16 | -0.58 | 0.33 | -0.75
Schwartz (1997) | 13 | Seizure-free no auras | 0.05 | -0.52 | 0.58 | 0.06
Sisodiya (1997) | 27 | Engel class I | -0.07 | -0.44 | 0.32 | -0.52
Jooma (1995a) | 12 lesionectomy | Seizure-free with auras | -0.19 | -0.69 | 0.43 | -0.64
| 12 tailored | | -0.03 | -0.59 | 0.55 | -0.14
Liu (1995) | 12 | Seizure-free with auras | 0.37 | -0.26 | 0.78 | 1.09
Vossler (1995) | 30 | Seizure-free with auras | 0.15 | -0.22 | 0.48 | 0.66
Berkovic (1991) | 10 | Seizure-free (undefined) | 0.31 | -0.40 | 0.79 | 0.77
Hopkins (1991) | 11 | Seizure-free (undefined) | 0.34 | -0.33 | 0.78 | 0.93
Mizrahi (1990) | 22 | Seizure-free (undefined) | 0.16 | -0.28 | 0.55 | 0.61
Yeh (1990) | 12 | Seizure-free with auras | -0.23 | -0.71 | 0.40 | -0.79
Drake (1987) | 11 | Seizure-free (undefined) | -0.23 | -0.73 | 0.43 | -0.74
Delgado-Escueta (1985) | 15 | Seizure-free no auras | -0.21 | -0.65 | 0.34 | -0.85

a A positive correlation indicates more successful surgeries with an older age at surgery.

Evidence Table 126. Sensitivity analysis of studies of temporal lobe surgery reporting individual patient age at surgery for successful and nonsuccessful patients

| | 95% Confidence Interval
Sensitivity Adjustment | Point-Biserial Correlation^a^ | Lower | Upper | p Value for Summary Estimate | Q | p Value for Q
Original analysis | 0.02 | -0.11 | 0.14 | 0.814 | 10.71 | 0.906
Removing study with largest negative correlation | 0.03 | -0.09 | 0.16 | 0.601 | 8.84 | 0.945
Removing study with largest positive correlation | 0.00 | -0.13 | 0.13 | 0.991 | 9.41 | 0.926
Removing study with smallest N | 0.01 | -0.12 | 0.13 | 0.926 | 10.04 | 0.902
Removing study with largest N | 0.00 | -0.14 | 0.13 | 0.978 | 10.15 | 0.897

a A positive correlation indicates more successful surgeries with an older age at surgery.

Evidence Table 127. Studies of temporal lobe surgery reporting individual age at seizure onset

| | | | 95% Confidence Interval
Reference | Number of Patients | Seizure Outcome Measurement | Point-Biserial Correlation^a^ | Lower | Upper | Standardized Residuals for Effect Sizes
Bouilleret (2002) | 18 | Seizure-free no auras | -0.18 | -0.60 | 0.31 | -0.16
Verma (2001) | 13 | Seizure-free with auras | 0.21 | -0.38 | 0.68 | 1.16
Szabo (1998) | 14 | Seizure-free with auras | -0.34 | -0.74 | 0.23 | -0.74
Adam (1996) | 15 | Seizure-free no auras | 0.01 | -0.51 | 0.52 | 0.53
Jooma (1995a) | 12 lesionectomy | Seizure-free with auras | -0.18 | -0.68 | 0.44 | -0.22
| 12 tailored | | 0.06 | -0.53 | 0.61 | 0.53
Liu (1995) | 12 | Seizure-free with auras | 0.13 | -0.48 | 0.65 | 0.84
Vossler (1995) | 30 | Seizure-free with auras | -0.16 | -0.49 | 0.22 | -0.09
Berkovic (1991) | 10 | Seizure-free (undefined) | -0.48 | -0.85 | 0.22 | -1.02
Hopkins (1991) | 11 | Seizure-free (undefined) | -0.11 | -0.66 | 0.53 | 0.10
Mizrahi (1990) | 22 | Seizure-free (undefined) | -0.15 | -0.54 | 0.29 | -0.06
Yeh (1990) | 12 | Seizure-free with auras | -0.35 | -0.77 | 0.28 | -0.69
Drake (1987) | 11 | Seizure-free (undefined) | 0.42 | -0.24 | 0.81 | 1.70
Delgado-Escueta (1985) | 15 | Seizure-free no auras | -0.20 | -0.64 | 0.35 | -0.21

a A positive correlation indicates more successful surgeries with an older age at seizure onset.

Evidence Table 128. Sensitivity analysis of studies of temporal lobe surgery reporting individual patient age at seizure onset

| | 95% Confidence Interval
Sensitivity Adjustment | Point-Biserial Correlation^a^ | Lower | Upper | p Value for Summary Estimate | Q | p Value for Q
Original analysis | -0.11 | -0.26 | 0.04 | 0.158 | 7.23 | 0.890
Removing study with largest negative correlation^b^ | -0.09 | -0.24 | 0.06 | 0.249 | 6.00 | 0.916
Removing study with largest positive correlation | -0.14 | -0.29 | 0.02 | 0.083 | 4.64 | 0.969
Removing study with smallest N | -0.09 | -0.24 | 0.06 | 0.249 | 6.00 | 0.916
Removing study with largest N | -0.10 | -0.26 | 0.07 | 0.238 | 7.16 | 0.847

a A positive correlation indicates more successful surgeries with an older age at seizure onset.

b The study with the largest negative effect size also had the smallest N.

Evidence Table 129. Studies of temporal lobe surgery reporting individual patients duration of epilepsy prior to surgery

| | | | 95% Confidence Interval
Reference | Number of Patients | Seizure Outcome Measurement | Point-Biserial Correlation^a^ | Lower | Upper | Standardized Residuals for Effect Sizes
Bouilleret (2002) | 18 | Seizure-free no auras | 0.28 | -0.21 | 0.66 | 0.21
Verma (2001) | 13 | Seizure-free with auras | -0.38 | -0.77 | 0.22 | -2.08
Szabo (1998) | 14 | Seizure-free with auras | 0.31 | -0.26 | 0.72 | 0.29
Jooma (1995a) | 12 lesionectomy | Seizure-free with auras | -0.01 | -0.58 | 0.57 | -0.50
| 12 tailored | | -0.10 | -0.63 | 0.51 | -0.77
Liu (1995) | 12 | Seizure-free with auras | 0.47 | -0.15 | 0.82 | 0.82
Vossler (1995) | 30 | Seizure-free with auras | 0.29 | -0.08 | 0.59 | 0.36
Berkovic (1991) | 10 | Seizure-free (undefined) | 0.64 | 0.02 | 0.90 | 1.40
Hopkins (1991) | 11 | Seizure-free (undefined) | 0.42 | -0.24 | 0.82 | 0.62
Mizrahi (1990) | 22 | Seizure-free (undefined) | 0.21 | -0.23 | 0.58 | -0.11
Yeh (1990) | 12 | Seizure-free with auras | 0.03 | -0.56 | 0.59 | -0.66
Drake (1987) | 11 | Seizure-free (undefined) | -0.62 | -0.89 | -0.03 | -2.79
Delgado-Escueta (1985) | 15 | Seizure-free no auras | 0.03 | -0.49 | 0.53 | -0.75

a A positive correlation indicates more successful surgeries with a longer duration of epilepsy prior to surgery.

Evidence Table 130. Sensitivity analysis of studies of temporal lobe surgery reporting individual patient duration of epilepsy prior to surgery

| | 95% Confidence Interval
Sensitivity Adjustment | Point-Biserial Correlation^a^ | Lower | Upper | p Value for Summary Estimate | Q | p Value for Q
Original analysis | 0.15 | -0.01 | 0.30 | 0.058 | 15.90 | 0.195
Removing study with largest negative correlation | 0.20 | 0.04 | 0.35 | 0.015 | 9.44 | 0.581
Removing study with largest positive correlation^b^ | 0.12 | -0.04 | 0.28 | 0.133 | 13.24 | 0.278
Removing study with smallest N | 0.12 | -0.04 | 0.28 | 0.133 | 13.24 | 0.278
Removing study with largest N | 0.12 | -0.05 | 0.29 | 0.172 | 15.19 | 0.174

a A positive correlation indicates more successful surgeries with a longer duration of epilepsy prior to surgery.

b The study with the largest effect size also had the smallest N.

Evidence Table 131. Studies of temporal lobe surgery reporting number of male and female patients with successful and nonsuccessful surgery

| | | | | | | 95% Confidence Interval
Reference | Seizure Outcome Measurement | Number of Male Patients | Number of Male Successes | Number of Female Patients | Number of Female Successes | Cohen's h Effect Sizes | Lower | Upper | p Values for Effect Sizes | Standardized Residuals for Effect Sizes
Bouilleret (2002) | Seizure-free no auras | 5 | 4 | 13 | 8 | 0.41 | -0.62 | 1.44 | 0.435201 | 0.92
Hennessy (2001) | Seizure-free with auras | 39 | 27 | 41 | 25 | 0.17 | -0.26 | 0.61 | 0.438003 | 1.23
Verma (2001) | Seizure-free with auras | 7 | 5 | 6 | 4 | 0.10 | -0.99 | 1.19 | 0.853018 | 0.30
Eberhardt (2000) | Seizure-free no auras | 12 | 1 | 8 | 6 | -1.51 | -2.40 | -0.61 | 0.000948 | -3.29
Holmes (1999) | Seizure-free no auras | 3 | 1 | 10 | 6 | -0.54 | -1.83 | 0.75 | 0.411001 | -0.74
Szabo (1998) | Seizure-free with auras | 7 | 6 | 7 | 4 | 0.65 | -0.40 | 1.70 | 0.222367 | 1.37
Kilpatrick (1997) | Seizure-free with auras | 11 | 9 | 7 | 4 | 0.55 | -0.40 | 1.49 | 0.258407 | 1.29
Schwartz (1997) | Seizure-free no auras | 9 | 4 | 4 | 3 | -0.63 | -1.81 | 0.54 | 0.290693 | -0.98
Sisodiya (1997) | Engel class I | 11 | 6 | 16 | 9 | -0.03 | -0.80 | 0.73 | 0.930230 | 0.07
Liu (1995) | Seizure-free with auras | 5 | 1 | 7 | 5 | -1.09 | -2.23 | 0.06 | 0.063539 | -1.79
Vossler (1995) | Seizure-free with auras | 19 | 12 | 11 | 8 | -0.21 | -0.95 | 0.54 | 0.587416 | -0.41
Berkovic (1991) | Seizure-free (undefined) | 5 | 3 | 5 | 5 | -1.37 | -2.61 | -0.13 | 0.030367 | -2.11
Yeh (1990) | Seizure-free with auras | 8 | 7 | 4 | 3 | 0.32 | -0.88 | 1.52 | 0.596218 | 0.64
Drake (1987) | Seizure-free (undefined) | 8 | 6 | 3 | 1 | 0.86 | -0.46 | 2.19 | 0.202175 | 1.39
Delgado-Escueta (1985) | Seizure-free no auras | 12 | 8 | 3 | 1 | 0.68 | -0.59 | 1.94 | 0.292366 | 1.17

Evidence Table 132. Studies of temporal lobe surgery reporting number of male and female patients with successful and nonsuccessful surgery - data used in meta-regression

Reference | Number of Patients | Cohen's h Effect Size | Weight | Mesial Temporal Sclerosis Patients Only | Tumor Patients Only | Standard Temporal Lobectomy | Tailored Temporal Lobectomy
Bouilleret (2002) | 18 | 0.4106 | 3.6111 | Yes | No | Yes | No
Hennessy (2001) | 80 | 0.17435 | 19.9875 | No | No | Yes | No
Verma (2001) | 13 | 0.1031 | 3.2308 | No | No | Yes | No
Eberhardt (2000) | 20 | -1.5087 | 4.8 | No | No | No | Yes
Holmes (1999) | 13 | -0.5412 | 2.3077 | No | No | Yes | No
Szabo (1998) | 14 | 0.6523 | 3.5 | No | No | Yes | No
Kilpatrick (1997) | 18 | 0.5464 | 4.2778 | No | No | Yes | No
Schwartz (1997) | 13 | -0.6349 | 2.7692 | Yes | No | No | No
Sisodiya (1997) | 27 | -0.0343 | 6.5185 | Yes | No | Yes | No
Liu (1995) | 12 | -1.0864 | 2.9167 | No | No | No | Yes
Vossler (1995) | 30 | -0.2056 | 6.9667 | No | No | No | Yes
Berkovic (1991) | 10 | -1.3694 | 2.5 | Yes | No | Yes | No
Yeh (1990) | 12 | 0.3245 | 2.6667 | No | Yes | No | No
Drake (1987) | 11 | 0.8634 | 2.1818 | No | Yes | No | Yes
Delgado-Escueta (1985) | 15 | 0.6797 | 2.4 | No | No | Yes | No

Evidence Table 133. Results of meta-regression of studies of temporal lobe surgery reporting percentage of male and female patients among patients with successful and nonsuccessful surgery

One predictor models Bolded = statistically significant coefficient
Covariate | Intercept (CI) | P (intercept) = | Coefficient (CI) | P (coefficient) | Q_e_ = | P (Q_e_) =
Start year (centered) | -0.11 (-0.35 to 0.13) | 0.359016 | -0.03 (-0.31 to 0.26) | 0.853727 | 24.615 | 0.026
End year (centered) | -0.04 (-0.28 to 0.20) | 0.726323 | -0.02 (-0.07 to 0.04) | 0.592742 | 27.642 | 0.010
Mesial temporal sclerosis (MTS=0) | -0.26 (-0.75 to 0.24) | 0.316342 | 0.25 (-0.32 to 0.81) | 0.387887 | 27.177 | 0.009
Tumor (Tumor = 0) | 0.57 (-0.32 to 1.46) | 0.211983 | -0.67 (-1.60 to 0.25) | 0.152673 | 25.882 | 0.018
Standard (St = 0) | 0.14 (-0.14 to 0.42) | 0.340748 | -0.62 (-1.13 to -0.12) | 0.014820 | 21.985 | 0.056
Tailored (Tailored = 0) | -0.59 (-1.07 to -0.11) | 0.015064 | 0.70 (0.15 to 1.24) | 0.0124402 | 21.683 | 0.060
Treatment age (centered) | -0.12 (-0.36 to 0.12) | 0.338682 | -0.03 (-0.05 to 0.00) | 0.053711 | 24.239 | 0.029
United States (USA = 0) | -0.14 (-0.54 to 0.26) | 0.491480 | 0.12 (-0.37 to 0.61) | 0.629453 | 27.693 | 0.010
Left side (centered) | -0.09 (-0.33 to 0.15) | 0.454805 | -0.02 (-0.03 to 0.01) | 0.075197 | 24.697 | 0.025

Average start year = 1985.7

Average end year = 1992.3

Average treatment age = 26.68

Average left = 50.6

Evidence Table 133-A. Results of meta-regression of studies of temporal lobe surgery reporting percentage of male and female patients among patients with successful and nonsuccessful surgery

Two predictor models: Standard and year plus one other variable Bolded in this table = homogeneous
Covariate: B_1_ | Covariate: B_2_ | Intercept (CI) | P (intercept) = | Coefficient B_1_ (CI) | P (B_1_) = | Coefficient B_2_ (CI) | P(B_2_) | Q_e_ = | P (Q_e_) =
Standard (St = 0) | Start year (centered) | 0.08 (-0.21 to 0.37) | 0.579398 | -0.60 (-1.10 to -0.10) | 0.019348 | -0.02 (-0.05 to 0.00) | 0.097903 | 19.135 | 0.084
Standard (St = 0) | End year (centered) | 0.23 (-0.08 to 0.54) | 0.146365 | -0.76 (-1.29 to -0.22) | 0.005391 | -0.04 (-0.10 to 0.02) | 0.149786 | 19.870 | 0.070
Standard (St = 0) | MTS (MTS=0) | -0.13 (-0.64 to 0.38) | 0.607917 | -0.67 (-1.18 to -0.17) | 0.009323 | 0.37 (-0.20 to 0.94) | 0.208745 | 20.405 | 0.060
Standard (St = 0) | Tumor (tumor = 0) | 1.48 (0.44 to 2.53) | 0.005361 | -0.92 (-1.46 to -0.37) | 0.001012 | -1.35 (-2.35 to -0.34) | 0.008741 | 15.108 | 0.236
Standard (St = 0) | Tailored (tailored = 0) | -0.29 (-1.30 to 0.72) | 0.573474 | -0.30 (-1.19 to 0.58) | 0.504500 | 0.43 (-0.54 to 1.39) | 0.387611 | 21.238 | 0.047
Standard (St = 0) | Treatment age (centered) | 0.07 (-0.22 to 0.76) | 0.618834 | -0.58 ()-1.09 to -0.08) | 0.023037 | -0.02 (-0.05 to 0.00) | 0.093667 | 19.076 | 0.087
Standard (St = 0) | United States (USA = 0) | 0.20 (-0.28 to 0.69) | 0.413259 | -0.65 (-1.18 to -0.12) | 0.015872 | -0.09 (-0.61 to 0.43) | 0.745048 | 21.880 | 0.039
Standard (St = 0) | Left (left = 0) | 0.09 (-0.21 to 0.40) | 0.561171 | -0.52 (-1.08 to 0.04) | 0.067680 | -0.08 (-0.09 to -0.06) | <0.000001 | 21.368 | 0.045
Tailored (Tailored = 0) | Start year (centered) | -0.65 (-1.13 to -0.17) | 0.008273 | 0.70 (0.16 to 0.00) | 0.011632 | -0.30 (-0.06 to 0.00) | 0.061406 | 18.245 | 0.108
Tailored (Tailored = 0) | End year (centered) | -0.61 (-1.09 to -0.13) | 0.012149 | 0.77 (0.21 to 1.34) | 0.007076 | -0.03 (-0.09 to 0.02) | 0.255782 | 20.376 | 0.060
Tailored (Tailored = 0) | MTS (MTS=0) | -1.10 (-1.86 to -0.34) | 0.004654 | 0.84 (0.27 to 1.42) | 0.003879 | 0.51 (-0.08 to 1.10) | 0.092632 | 18.861 | 0.092
Tailored (Tailored = 0) | Tumor (tumor = 0) | 0.15 (-0.79 to 1.09) | 0.760981 | 0.77 (0.21 to 1.32) | 0.006644 | -0.85 (-1.78 to 0.09) | 0.074982 | 18.507 | 0.101
Tailored (Tailored = 0) | Treatment age (centered) | -0.67 (-1.16 to -0.19) | 0.006435 | 0.72 (0.18 to 1.27) | 0.009648 | -0.03 (-0.06 to 0.00) | 0.042434 | 17.518 | 0.131
Tailored (Tailored = 0) | United States (USA = 0) | 0.56 (-1.09 to -0.04) | 0.034766 | 0.72 (0.15 to 1.29) | 0.013569 | -0.07 (-0.58 to 0.45) | 0.801865 | 21.620 | 0.042
Tailored (Tailored = 0) | Left (centered) | -0.54 (-1.02 to -0.05) | 0.029525 | 0.60 (0.03 to 1.17) | 0.038490 | -0.01 (-0.03 to 0.01) | 0.269959 | 20.490 | 0.060
Treatment age (centered) | Start year (centered) | -0.13 (-0.37 to 0.11) | 0.300278 | -0.02 (-0.05 to 0.02) | 0.289714 | -0.02 (-0.05 to 0.02) | 0.403631 | 23.516 | 0.024
Treatment age (centered) | End year (centered) | -0.11 (-0.36 to 0.14) | 0.386278 | -0.03 (-0.05 to 0.00) | 0.060675 | 0.00 (-0.06 to 0.05) | 0.883014 | 24.217 | 0.019
Treatment age (centered) | MTS (MTS=0) | -0.26 (-0.76 to 0.24) | 0.312923 | -0.03 (-0.05 to 0.00) | 0.069978 | 0.18 (-0.39 to 0.75) | 0.531492 | 23.846 | 0.021
Treatment age (centered) | Tumor (tumor = 0) | 0.54 (-0.35 to 1.43) | 0.235524 | -0.03 (-0.06 to 0.00) | 0.049363 | -0.71 (-1.63 to 0.22) | 0.133582 | 21.989 | 0.038
Treatment age (centered) | United States (USA = 0) | -0.22 (-0.63 to 0.19) | 0.257560 | -0.03 (-0.06 to 0.00) | 0.057296 | 0.16 (0.34 to 0.65) | 0.5432915 | 23.851 | 0.021
Treatment age (centered) | Left (centered) | -0.17 (-0.42 to 0.07) | 0.168086 | -0.03 (-0.06 to -0.01) | 0.016665 | -0.02 (-0.04 to 0.00) | 0.020548 | 18.996 | 0.089
Left (centered) | Start year (centered) | -0.19 (-0.43 to 0.06) | 0.138223 | -0.02 (-0.04 to -0.01) | 0.007930 | -0.04 (-0.07 to -0.01) | 0.008234 | 17.845 | 0.120
Left (centered) | End year (centered) | 0.85 (0.60 to 1.10) | <0.000001 | -0.02 (-0.04 to 0.00) | 0.022466 | -1.02 (-1.99 to 0.05) | 0.038476 | 20.411 | 0.0597
Left (centered) | MTS (MTS=0) | -0.28 (-0.79 to 0.22) | 0.269997 | -0.02 (-0.03 to 0.00) | 0.070488 | 0.25 (-0.32 to 0.82) | 0.390991 | 23.952 | 0.020
Left (centered) | Tumor (tumor = 0) | -0.04 (-0.28 to 0.20) | 0.717057 | -0.02 (-0.05 to 0.00) | 0.017863 | -0.06 (-0.12 to 0.01) | 0.086814 | 21.3701 | 0.041
Left (centered) | United States (USA = 0) | -0.10 (-0.50 to 0.31) | 0.641064 | -0.02 (-0.03 to 0.00) | 0.089033 | 0.01 (-0.50 to 0.52 | 0.971889 | 24.695 | 0.016

Evidence Table 134. Studies of temporal lobe surgery reporting the number of left-sided and right-sided operations with successful and nonsuccessful surgery ourcome measurements

| | | | | | | | 95% Confidence Interval
Reference | N | Seizure Outcome Measurement | Left Side | Left Side Successes | Right Side | Right Side Successes | Cohen's h Effect Sizes | Lower | Upper | p Values for Effect Sizes | Standardized Residuals for Effect Sizes
Bouilleret (2002) | 18 | Seizure-free no auras | 8 | 7 | 10 | 5 | 0.85 | -0.08 | 1.78 | 0.073797 | 1.98
Hennessy (2001) | 80 | Seizure-free with auras | 38 | 25 | 42 | 27 | 0.03 | -0.41 | 0.47 | 0.887980 | 0.50
Sotero de Menezes (2001) | 14 | Seizure-free with auras | 5 | 2 | 9 | 4 | -0.09 | -1.18 | 1.00 | 0.871789 | -0.04
Verma (2001) | 13 | Seizure-free with auras | 6 | 3 | 7 | 6 | -0.80 | -1.89 | 0.29 | 0.152705 | -1.33
Eberhardt (2000) | 20 | Seizure-free no auras | 11 | 3 | 9 | 4 | -0.36 | -1.24 | 0.52 | 0.422490 | -0.66
Holmes (1999) | 13 | Seizure-free no auras | 5 | 2 | 8 | 5 | -0.45 | -1.57 | 0.66 | 0.425779 | -0.69
Szabo (1998) | 14 | Seizure-free with auras | 7 | 5 | 7 | 5 | 0.00 | -1.05 | 1.05 | 1.000000 | 0.13
Kilpatrick (1997) | 18 | Seizure-free with auras | 10 | 6 | 8 | 7 | -0.65 | -1.58 | 0.28 | 0.172765 | -1.25
Schwartz (1997) | 13 | Seizure-free no auras | 7 | 4 | 6 | 3 | 0.14 | -0.95 | 1.23 | 0.796671 | 0.39
Sisodiya (1997) | 27 | Engel class I | 11 | 7 | 16 | 8 | 0.28 | -0.49 | 1.04 | 0.480658 | 0.91
Adam (1996) | 15 | Seizure-free no auras | 8 | 4 | 7 | 3 | 0.14 | -0.87 | 1.16 | 0.781800 | 0.42
Goldstein (1996) | 33 | Seizure-free (undefined) | 17 | 6 | 16 | 9 | -0.42 | -1.11 | 0.26 | 0.223648 | -1.06
Liu (1995) | 12 | Seizure-free with auras | 7 | 4 | 5 | 2 | 0.34 | -0.80 | 1.49 | 0.556065 | 0.72
Vossler (1995) | 30 | Seizure-free with auras | 17 | 12 | 13 | 8 | 0.19 | -0.53 | 0.91 | 0.603189 | 0.74
Berkovic (1991) | 10 | Seizure-free (undefined) | 7 | 5 | 3 | 3 | -1.13 | -2.48 | 0.22 | 0.102162 | -1.55
Mizrahi (1990) | 22 | Seizure-free (undefined) | 12 | 6 | 10 | 8 | -0.64 | -1.48 | 0.20 | 0.132866 | -1.38
Yeh (1990) | 12 | Seizure-free with auras | 9 | 8 | 3 | 2 | 0.55 | -0.76 | 1.86 | 0.408278 | 0.94
Estes (1988) | 25 | Seizure-free with auras | 13 | 4 | 12 | 5 | -0.23 | -1.01 | 0.56 | 0.570101 | -0.41
Delgado-Escueta (1985) | 15 | Seizure-free no auras | 10 | 7 | 5 | 2 | 0.61 | -0.46 | 1.69 | 0.263161 | 1.27

Evidence Table 135. Sensitivity analysis of studies of temporal lobe surgery reporting the number of left side and right side surgeries among patients with successful and nonsuccessful surgery

| | 95% Confidence Interval | | | | | | 95% Confidence Interval
Sensitivity Adjustment | Cohen's h Summary Estimate ^a^ | Lower | Upper | p value for Summary Estimate | Q | p value for Q | Back-transformed Percentage Estimate ^b^ | Lower | Upper
Original analysis | -0.07 | -0.27 | 0.13 | 0.49 | 17.88 | 0.46 | 0% | -2% | 0%
Removing study with smallest effect size ^c^ | -0.05 | -0.25 | 0.15 | 0.65 | 15.47 | 0.56 | 0% | -2% | 1%
Removing study with largest effect size | -0.11 | -0.32 | 0.09 | 0.27 | 13.96 | 0.67 | 0% | -3% | 0%
Removing study with smallest N | -0.05 | -0.25 | 0.15 | 0.65 | 15.47 | 0.56 | 0% | -2% | 1%
Removing study with largest N | -0.10 | -0.32 | 0.13 | 0.40 | 17.62 | 0.41 | 0% | -3% | 0%

a A positive summary estimate favors left side surgery patients achieving more successful surgeries.

b The back-transformed percentage estimate is the difference between the percentage of left side surgery patients who achieved successful surgery and the percentage of right side surgery patients who achieved successful surgery. A positive percentage favors left side surgeries and a negative percentage favors right side surgeries. A difference of 0% indicates no differences between left side and right side patients in achieving successful surgery.

c The study with the smallest effect size also had the smallest N.

Evidence Table 136. Studies of temporal lobe surgery reporting number of simple partial seizure (SPS) patients with successful and nonsuccessful surgery

| | | | | | | | 95% Confidence Interval
Reference | N | Seizure Outcome Measurement | SPS Patients | SPS Successes | Non-SPS Patients | Non-SPS Successes | Cohen's h Effect Sizes | Lower | Upper | p Values for Effect Sizes | Standardized Residuals for Effect Sizes
Bouilleret (2002) | 18 | Seizure-free no auras | 16 | 10 | 2 | 2 | -1.32 | -2.79 | 0.15 | 0.078835 | -1.97
Hennessy (2001) | 80 | Seizure-free with auras | 23 | 18 | 57 | 34 | 0.41 | -0.08 | 0.89 | 0.099855 | 2.24
Berkovic (1991) | 10 | Seizure-free (undefined) | 9 | 7 | 1 | 1 | -0.98 | -3.05 | 1.08 | 0.351655 | -1.05
Yeh (1990) | 12 | Seizure-free with auras | 3 | 2 | 9 | 8 | -0.55 | -1.86 | 0.76 | 0.408278 | -1.03
Drake (1987) | 11 | Seizure-free (undefined) | 3 | 2 | 8 | 5 | 0.09 | -1.24 | 1.41 | 0.897564 | -0.02

Evidence Table 137. Sensitivity analysis of studies of temporal lobe surgery reporting the percentage of patients with simple partial seizures among patients with successful and nonsuccessful surgery

| | 95% Confidence Interval | | | | | | 95% Confidence Interval
Sensitivity Adjustment | Cohen's h Summary Estimate ^a^ | Lower | Upper | p value for Summary Estimate | Q | p value for Q | Back-transformed Percentage Estimate ^b^ | Lower | Upper
Original analysis | 0.10 | -0.30 | 0.51 | 0.62 | 7.12 | 0.13 | 0% | -2% | 6%
Removing study with smallest effect size | 0.22 | -0.20 | 0.64 | 0.31 | 3.25 | 0.36 | 1% | -1% | 10%
Removing study with largest effect size ^c^ | -0.60 | -1.34 | 0.13 | 0.11 | 2.08 | 0.55 | -9% | -39% | 0%
Removing study with smallest N | 0.14 | -0.27 | 0.56 | 0.49 | 6.02 | 0.11 | 0% | -2% | 8%
Removing study with largest N ^c^ | -0.60 | -1.34 | 0.13 | 0.11 | 2.08 | 0.55 | -9% | -39% | 0%

a A positive summary estimate favors patients who have simple partial seizures achieving more successful surgeries.

b The back-transformed percentage estimate is the difference between the percentage of patients with simple partial seizures who achieved successful surgery and the percentage of patients without simple partial seizures who achieved successful surgery. A positive percentage favors patients with simple partial seizures and a negative percentage favors patients without simple partial seizures. A difference of 0% indicates no differences between patients with or without simple partial seizures in achieving successful surgery.

c The study with the largest effect size also had the largest N.

Evidence Table 138. Studies of temporal lobe surgery reporting number of secondarily generalized seizure (SGS) patients with successful and nonsuccessful surgery

| | | | | | | | 95% Confidence Interval
Reference | N | Seizure Outcome Measurement | SGS Patients | SGS Successes | Non-SGS Patients | Non-SGS Successes | Cohen's h Effect Sizes | Lower | Upper | p Values for Effect Sizes | Standardized Residuals for Effect Sizes
Hennessy (2001) | 80 | Seizure-free with auras | 31 | 22 | 49 | 30 | 0.21 | -0.24 | 0.66 | 0.368647 | 2.15
Hennessy (2001) | 116 | Seizure-free with auras | 57 | 31 | 59 | 47 | -0.55 | -0.91 | -0.18 | 0.003215 | -2.61
Liu (1995) | 12 | Seizure-free with auras | 8 | 3 | 4 | 3 | -0.78 | -1.98 | 0.42 | 0.204920 | -0.96
Berkovic (1991) | 10 | Seizure-free (undefined) | 4 | 4 | 6 | 4 | 1.23 | -0.03 | 2.50 | 0.056521 | 2.26
Yeh (1990) | 12 | Seizure-free with auras | 10 | 8 | 2 | 2 | -0.93 | -2.45 | 0.59 | 0.231255 | -0.95
Drake (1987) | 11 | Seizure-free (undefined) | 7 | 3 | 4 | 4 | -1.71 | -2.94 | -0.49 | 0.006241 | -2.47
Delgado-Escueta (1985) | 15 | Seizure-free no auras | 12 | 9 | 3 | 0 | 2.09 | 0.83 | 3.36 | 0.001176 | 3.63

Evidence Table 139. Studies of temporal lobe surgery reporting number of secondarily generalized seizure (SGS) patients with successful and nonsuccessful surgery - data used in meta-regression

Reference | Number of Patients | Cohen's h Effect Size | Weight | Mesial Temporal Sclerosis Patients Only | Tumor Patients Only | Standard Temporal Lobectomy | Tailored Temporal Lobectomy
Hennessy (2001) | 80 | 0.2063 | 18.9875 | No | No | Yes | No
Hennessy (2001) | 116 | -0.5472 | 28.9914 | Yes | No | Yes | No
Liu (1995) | 12 | -0.7763 | 2.6667 | No | No | No | Yes
Berkovic (1991) | 10 | 1.231 | 2.4 | Yes | No | Yes | No
Yeh (1990) | 12 | -0.9273 | 1.6667 | No | Yes | No | No
Drake (1987) | 11 | -1.7141 | 2.5455 | No | Yes | No | Yes
Delgado-Escueta (1985) | 15 | 2.0944 | 2.4 | No | No | Yes | No

Evidence Table 140. Results of meta-regression of studies of temporal lobe surgery reporting the number of patients with secondarily generalized seizures among patients with successful and nonsuccessful surgery

One predictor variable Bolded = statistically significant coefficient
Covariate | Intercept (CI) | P (intercept) | Coefficient (CI) | P (coefficient) | Q_e_ = | P (Q_e_) =
Start year (centered) | -1.96 (-2.28 to -1.64) | <0.000001 | 0.00 (-0.09 to 0.09) | 0.966950 | 31.779 | <0.0000017
End year (centered) | -0.06 (-0.35 to 0.47) | 0.780259 | -0.06 (-0.13 to 0.01) | 0.116190 | 29.312 | 0.000020
MTS (MTS=0) | -0.41 (-0.76 to -0.06) | 0.021420 | 0.45 (-0.06 to 0.95) | 0.086312 | 28.831 | 0.000020
Tumor (Tumor = 0) | -1.40 (-2.36 to -0.45) | 0.003970 | 1.29 (0.30 to 2.28) | 0.010444 | 25.277 | 0.000126
Standard (St = 0) | -0.08 (-0.34 to 0.19) | 0.584601 | -1.09 (-1.88 to -0.29) | 0.007470 | 24.620 | 0.000165
Tailored (Tailored = 0) | -1.23 (-2.09 to -0.38) | 0.004862 | 1.13 (0.23 to 2.03) | 0.013471 | 25.674 | 0.000103
Treatment age (centered) | -0.24 (-0.52 to 0.05) | 0.101922 | -0.01 (-0.07 to 0.04) | 0.574820 | 31.462 | 0.000008
United States (USA = 0) | -0.58 (-0.29 to 1.45) | 0.189245 | -0.86 (-1.77 to 0.05) | 0.065196 | 28.380 | 0.000031
Percent male (centered) | -0.23 (-0.50 to 0.04) | 0.096627 | -0.01 (-0.04 to 0.02) | 0.543944 | 31.413 | 0.000008
Percent simple partial seizures | -0.20 (-0.47 to 0.08) | 0.164976 | 0.00 (-0.03 to 0.03) | 0.916759 | 31.770 | 0.000007
Percent generalized seizures | -0.29 (-0.65 to 0.06) | 0.107075 | -0.01 (-0.03 to 0.01) | 0.462774 | 31.251 | 0.000008

Evidence Table 140-A. Results of meta-regression of studies of temporal lobe surgery reporting the number of patients with secondarily generalized seizures among patients with successful and nonsuccessful surgery (continued)

Two predictor variables: start year plus one variable
Bolded in this table = both coefficients significant, Italicized and bolded = both coefficients significant and MR homogeneous
Covariate: B_1_ | Covariate: B_2_ | Intercept (CI) | P (intercept) | Coefficient B_1_ (CI) | P (B_1_) = | Coefficient B_2_ (CI) | P(B_2_) | Q_e_ = | P (Q_e_) =
MTS (MTS = 0) | Tumor (Tumor = 0) | -2.10 (-3.19 to -1.01) | 0.000166 | 0.70 (0.17 to 1.23) | 0.010168 | 1.69 (0.65 to 2.72) | 0.001381 | 18.611 | 0.000937
MTS (MTS = 0) | Standard (St = 0) | -0.41 (-0.76 to -0.06) | 0.021115 | 0.83 (0.28 to 1.38) | 0.003086 | -1.58 (-2.44 to -0.72) | 0.000318 | 15.869 | 0.0032
MTS (MTS = 0) | Tailored (Tailored = 0) | -1.97 (-2.98 to -0.95) | 0.000143 | 0.73 (0.19 to 1.27) | 0.007651 | 1.56 (0.60 to 2.57) | 0.001340 | 18.594 | 0.000964
MTS (MTS = 0) | Treatment age (centered) | -0.42 (-0.78 to -0.06) | 0.022014 | 0.43 (-0.09 to 0.95) | 0.101515 | -0.01 (-0.06 to 0.05) | 0.834629 | 28.787 | 0.000009
MTS (MTS = 0) | United States (USA = 0) | 0.26 (-0.76 to 1.28) | 0.621027 | 0.33 (-0.221 to 0.86) | 0.235274 | -0.67 (-1.63 to 0.29) | 0.172392 | 26.968 | 0.000020
MTS (MTS = 0) | Percent male (centered) | -0.41 (-0.76 to -0.06) | 0.021216 | 0.44 (-0.10 to 0.97) | 0.107418 | 0.00 (-0.03 to 0.03) | 0.936807 | 28.824 | 0.000009
MTS (MTS = 0) | Percent simple | -0.42 (-0.77 to -0.07) | 0.018427 | 0.62 (0.03 to 1.20) | 0.0404442 | -0.02 (-0.06 to 0.02) | 0.266268 | 27.575 | 0.000015
MTS (MTS = 0) | Percent CGE | -0.52 (-0.96 to -0.09) | 0.019117 | 0.46 (-0.05 to 0.97) | 0.077299 | -0.01 (-0.03 to 0.01) | 0.401950 | 28.129 | 0.000012
MTS (MTS = 0) | Start year (centered) | -0.41 (-0.81 to -0.01) | 0.046672 | 0.45 (-0.06 to 0.95) | 0.086060 | 0.00 (-0.09 to 0.09) | 0.980949 | 28.830 | 0.000009
MTS (MTS = 0) | End year (centered) | -0.18 (-0.72 to 0.36) | 0.521359 | 0.36 (-0.18 to 0.89) | 0.189704 | -0.04 (-0.12 to 0.003) | 0.267427 | 27.596 | 0.000015
Tumor (Tumor = 0) | Standard (St = 0) | 0.70 (-2.26 to 0.85) | 0.376850 | 0.63 (-0.91 to 2.16) | 0.423728 | -0.70 (-1.93 to 0.53) | 0.264120 | 23.979 | 0.000081
Tumor (Tumor = 0) | Tailored (Tailored = 0) | -1.69 (-2.73 to -0.65) | 0.001444 | 0.89 (-0.26 to 2.04) | 0.128514 | 0.73 (-0.32 to 1.77) | 0.172070 | 23.361 | 0.000107
Tumor (Tumor = 0) | Treatment age (centered) | -1.46 (-2.43 to -0.49) | 0.003117 | 1.31 (0.32 to 2.30) | 0.009589 | -0.02 (-0.07 to 0.03) | 0.490667 | 24.753 | 0.000056
Tumor (Tumor = 0) | United States (USA = 0) | -0.64 (-1.96 to 0.68) | 0.341773 | 1.22 (0.23 to 2.22) | 0.015783 | -0.76 (-1.68 to 0.15) | 0.102166 | 22.554 | 0.000156
Tumor (Tumor = 0) | Percent male (centered) | -1.50 (-2.52 to -0.49) | 0.003679 | 1.44 (0.33 to 2.54) | 0.010665 | 0.01 (-0.02 to 0.04) | 0.563892 | 24.896 | 0.000053
Tumor (Tumor = 0) | Percent simple | -1.49 (-2.50 to -0.48) | 0.003880 | 1.36 (0.34 to 2.38) | 0.009061 | 0.01 (-0.02 to 0.04) | 0.608476 | 24.964 | 0.000051
Tumor (Tumor = 0) | Percent CGE | -1.52 (-2.52 to -0.52 | 0.002871 | 1.55 (0.37 to 2.72) | 0.010040 | 0.01 (-0.02 to 0.04) | 0.434255 | 24.625 | 0.000060
Tumor (Tumor = 0) | Start year (centered) | -1.39 (-2.35 to -0.43) | 0.004522 | 1.32 (0.32 to 2.32) | 0.00961 | 0.02 (-0.07 to 0.11) | 0.697709 | 25.077 | 0.000049
Tumor (Tumor = 0) | End year (centered) | -1.83 (-2.77 to -0.89) | 0.000142 | 2.52 (1.38 to 3.67) | 0.000016 | -0.16 (-0.24 to -0.08) | 0.000140 | 12.157 | 0.016221
Standard (St = 0) | Tailored (Tailored = 0) | -0.38 (-2.15 to 1.38) | 0.671466 | -0.85 (-2.39 to 0.69) | 0.278810 | 0.31 (-1.44 to 2.05) | 0.730062 | 24.501 | 0.000063
Standard (St = 0) | Treatment age (centered) | -0.04 (-0.36 to 0.29) | 0.830962 | -1.16 (-2.01 to -0.30) | 0.007991 | 0.01 (-0.04 to 0.07) | 0.655440 | 24.423 | 0.000066
Standard (St = 0) | United States (USA = 0) | 1.44 (0.46 to 2.42) | 0.004075 | -1.63 (-2.49 to -0.76) | 0.000222 | -1.59 (-2.58 to -0.60) | 0.001663 | 14.728 | 0.005300
Standard (St = 0) | Percent male (centered) | -0.09 (-0.38 to 0.20) | 0.529649 | -1.07 (-1.87 to -0.27) | 0.008599 | 0.00 (-0.04 to 0.03) | 0.745227 | 24.513 | 0.000063
Standard (St = 0) | Percent simple | -0.04 (-0.34 to 0.25) | 0.781214 | -1.12 (-1.92 to -0.31 | 0.006384 | -0.01 (-0.04 to 0.02) | 0.596896 | 24.337 | 0.000068
Standard (St = 0) | Percent CGE | 0.20 (-0.29 to 0.68) | 0.426228 | -1.54 (-2.59 to -0.50) | 0.003776 | -0.02 (-0.05 to 0.01) | 0.179913 | 22.870 | 0.00134
Standard (St = 0) | Start year (centered) | 0.13 (-0.26 to 0.51) | 0.521675 | -1.39 (-2.29 to -0.49) | 0.002344 | 0.07 (-0.03 to 0.18) | 0.147246 | 22.531 | 0.000157
Standard (St = 0) | End year (centered) | 0.82 (0.28 to 1.35) | 0.002696 | -2.17 (-3.14 to -1.20) | 0.000012 | -0.17 (-0.25 to -0.08) | 0.000146 | 22.531 | 0.038118
Tailored (Tailored = 0) | Treatment age (centered) | -1.24 (-2.09 to 0.38) | 0.004783 | 1.12 (0.21 to 2.03) | 0.015741 | -0.01 (-0.06 to 0.05) | 0.836505 | 25.631 | 0.000038
Tailored (Tailored = 0) | United States (USA = 0) | -0.35 (-1.35 to 0.64) | 0.487119 | 1.98 (0.96 to 3.00) | 0.000147 | -1.81 (-2.84 to -0.77) | 0.000619 | 13.960 | 0.007424
Tailored (Tailored = 0) | Percent male (centered) | -1.26 (-2.13 to -0.40) | 0.004135 | 1.13 (0.23 to 2.03) | 0.013545 | -0.01 (-0.04 to 0.02) | 0.548722 | 25.317 | 0.000043
Tailored (Tailored = 0) | Percent simple | -1.27 (-2.13 to -0.41) | 0.003935 | 1.22 (0.29 to 2.15) | 0.010041 | -0.01 (-0.05 to 0.02) | 0.461415 | 25.137 | 0.000047
Tailored (Tailored = 0) | Percent CGE | -1.26 (-2.13 to -0.39) | 0.004449 | 1.22 (0.22 to 2.22) | 0.016733 | 0.00 (-0.2 to 0.03) | 0.698106 | 25.521 | 0.000040
Tailored (Tailored = 0) | Start year (centered) | -1.26 (-2.12 to -0.40) | 0.004139 | 1.26 (0.31 to 2.20) | 0.009042 | 0.04 (-0.05 to 0.13) | 0.400510 | 24.967 | 0.000051
Tailored (Tailored = 0) | End year (centered) | -1.32 (-2.18 to -0.45) | 0.002739 | 1.83 (0.82 to 2.84) | 0.000369 | -0.12 (-0.20 to -0.40) | 0.002625 | 16.626 | 0.00285
United States (USA = 0) | Treatment age (centered) | 1.00 (0.03 to 1.96) | 0.042543 | -1.48 (-2.59 to -0.38) | 0.008544 | -0.06 (-0.12 to 0.00) | 0.051456 | 24.549 | 0.000062
United States (USA = 0) | Percent male (centered) | 0.58 (-0.29 to 1.45) | 0.190020 | -0.90 (-1.81 to 0.02) | 0.054632 | -0.01 (-0.04 to 0.02) | 0.412989 | 27.716 | 0.000014
United States (USA = 0) | Percent simple | 0.96 (-0.06 to 1.99) | 0.066008 | -1.38 (-2.55 to -0.20) | 0.021714 | 0.03 (-0.01 to 0.07) | 0.169206 | 26.506 | 0.000025
United States (USA = 0) | Percent CGE | 1.05 (0.10 to 1.99) | 0.029933 | -1.81 (-2.99 to -0.62) | 0.002728 | -0.04 (-0.07 to -0.01) | 0.014582 | 22.274 | 0.000177
United States (USA = 0) | Start year (centered) | 0.58 (-0.29 to 1.45) | 0.191861 | -0.89 (-1.83 to 0.04) | 0.060169 | -0.02 (-0.11 to .007) | 0.715934 | 28.248 | 0.000011
United States (USA = 0) | End year (centered) | 0.53 (-0.36 to 1.41) | 0.245352 | -0.65 (-1.75 to 0.45) | 0.244482 | -0.03 (-0.11 to 0.06) | 0.516362 | 27.956 | 0.000013

Evidence Table 141. Studies of temporal lobe surgery reporting quality of life outcome measurements

Epilepsy Surgery Inventory
Reference | Number of Patients | Surgery | Followup (Years) | Mean Overall Quality of Life Score | SD of Overall Score
Rose (1996) | 47 | Standard temporal lobectomy | 0 | 60.5 | 19.0
| | | 2 | 57.7 | 20.7

The study found no significant difference in overall quality of life scores measured prior to or 2 years after surgery, but reported that patients with low preoperative scores showed the greatest improvement in postoperative scores.

Evidence Table 141-A. Studies of temporal lobe surgery reporting quality of life outcome measurements

Quality of Life in Epilepsy
Reference | Number of Patients | Surgery | Followup (Years) | Mean Global Score | SD of global Score
Markand (2000) | 53 | Tailored temporal lobectomy | 0 | 47 | 10
| 51 | | 2 | 54 | 12
| 37 | Control | 0 | 42 | 10.1
| 33 | | 2 | 40 | 12

The study found that the baseline overall score was significantly higher in the surgery group. At 2 years after surgery the overall score was significantly improved in the surgery group compared to baseline and the control group. The improvement in the surgery group was almost entirely due to patients who became completely seizure-free. Patients who were free of complex partial seizures but still had auras or who still experienced complex partial seizures had no significant improvement in overall score after surgery.

Evidence Table 142. Studies of temporal lobe surgery reporting employment data

Reference | Number of Patients Evaluated | Mean Followup Time in Years | Minimum Followup | Maximum Followup | Number of Patients Not Able to Obtain Work Prior to Surgery | Number of Patients Able to Obtain Work After Surgery | Number of Patients Working Prior to Surgery | Number of Patients Able to Remain at Work After Surgery
Boling (2001) | 18 | 5.3 | 2 | | 1 | 0 | 13 | 9
Reeves (1997) | 134 | 4.2 | 2.5 | 6.5 | 20 | 7 | 67 | 57
Sperling (1995) | 73 | 2 | | | 28 | 15 | 33 | 30
Mizrahi (1990) | 22 | 5.3 | 2 | 8 | 5 | 3 | 4 | 3
Delgado-Escueta (1985) | 15 | 6 | 2 | 11 | 3 | 3 | 8 | 7

Evidence Table 143. Studies of temporal lobe surgery reporting the ability to attend or remain in school after surgery

| | | | | | Number of Patients
Reference | N | Surgery | Followup (Years) | Minimum Followup | Maximum Followup | Did Not Attend School Prior to Surgery | Able to Attend School After Surgery | Attending School Prior to Surgery | Able to Remain in School or Obtain Employment After Surgery
Mizrahi (1990) | 22 | Tailored temporal lobectomy | 5.3 | 2 | 8 | 0 | 0 | 11 | 11
Delgado-Escueta (1985) | 15 | Standard temporal lobectomy | 6 | 2 | 11 | 1 | 1 | 2 | 2

In Mizrahi, all eleven patients attending school at the time of surgery showed improvement in school or obtained employment at the time of followup. In Delgado-Escueta, only three patients were of school age; all showed improvement in schoolwork after surgery.

Evidence Table 144. Studies of temporal lobe surgery reporting ability to obtain a driver's license after surgery

Reference | Number of Patients | Surgery | Followup (Years) | Minimum Followup Time | Maximum Followup Time | Number of Patients Able to Obtain a Drivers License After Surgery
Reeves (1997) | 134 | Standard | 4.2 | 2.5 | 6.5 | 89 (66%)

The number of patients who were driving increased significantly after surgery; 16% compared to 66%.

Evidence Table 145. Studies reporting new cases of depression after temporal lobe surgery

Reference | Number of Patients | Years | Country | Method of Diagnosis
Kanemoto (2001) | 52 | 1987-1999 | Japan | Mood disorder due to a general medical condition that fulfilled the Diagnostic and Statistical Manual of Mental Disorders-4th edition (DSM-IV) criteria
Kohler (2001) | 58 | 1986-1999 | United States | Neurologic and neuropsychological evaluations were used to determine the presence of psychiatric symptoms meeting the severity criteria for mood and anxiety disorders as classified in the DSM-IV, including major depression and depression not otherwise specified.
Nees (2001) | 50 | 1992-1994 | England | Data derived from standard interviews on all patients by a clinical psychiatrist were used to make a diagnosis of depression.
Wiebe (2001) | 36 | 1996-2000 | Canada | Depression was assessed with the depression scale of the Center for Epidemiological Studies-Depression Scale (CES-D)
Anhoury (2000) | 109 | 1988-1997 | England | Clinical diagnoses of mood disorders were made by experienced psychiatrists with an interest in epilepsy.
Derry (2000) | 39 | 1996-1998 | Canada | The CES-D was used to define clinical depression for the purposes of this study.
Altshuler (1999) | 49 | 1974-1990 | United States | Patients were administered the Structured Clinical Interview for DSM-III-R that assesses current and past psychopathology for evidence of depression.
Ring (1998) | 60 | 1995-1996 | England | Depression was defined according to DSM-IV criteria, but as if there were no associated general medical condition.
Naylor (1994) | 37 | 1987-1991 | Denmark | Patients were diagnosed as having moderate or severe depressive episodes before or after surgery using the criteria of the International Classification of Diseases-10^th^ revision.
Bladin (1992) | 107 | 1975-1991 | Australia | DSM-III criteria were used to diagnose depression.

Evidence Table 146. Patient characteristics for studies of temporal lobe surgery reporting new cases of depression

Reference | N | Surgery | Pathology | Mean Age at Surgery (Years) | SD of Age at Surgery (Years) | Mean Age at Seizure Onset (Years) | SD of Age at Seizure Onset (Years) | Mean Duration of Epilepsy Before Surgery (Years) | SD of Duration Before Surgery (Years) | Right Side Surgeries | Left Side Surgeries | Number of Males | Number of Females | Number of Patients With Simple Partial Seizures
Kanemoto (2001) | 52 | Standard | Not reported | 27.1 | 5.9 | 9.7 | 5.3 | 17.5 | 7.8 | 22 | 30 | 28 | 24
Kohler (2001) | 58 | Standard | Various | 32.3 | 10.6 | | | 17.7 | 10.3 | 27 | 31 | 20 | 38 | 44
Nees (2001) | 50 | Not described | Various | 26 | | 8.8 | | | | 31 | 19 | 17 | 33
Wiebe (2001) | 36 | Standard | Various | 34.4 | 9.9 | 16.2 | 10 | | | 12 | 24 | 21 | 19
Anhoury (2000) | 109 | Not described | Various | 30.1 | 7.4 | | | | | | | 50 | 71
Derry (2000) | 39 | Standard | Not reported | 31.2 | 1 | 12.1 | 10 | 18.8 | 9.2 | 18 | 21 | 16 | 23
Altshuler (1999) | 49 | Standard | Mesial temporal sclerosis | 40 | 5.5 | 11.4 | 8.3 | 17.6 | 4.3 | 23 | 26 | 23 | 26
Ring (1998) | 60 | Not described | Not reported | 27 | 7.4 | | | | | 36 | 24 | 21 | 39
Naylor (1994) | 37 | AH | Various | 29.1 | 9.1 | 11.5 | 10.3 | 17.6 | 8.2 | | | 22 | 15
Bladin (1992) | 107 | Standard | Not reported | | | | | | | 62 | 48 | 46 | 64

AH Amygdalohippocampectomy

Evidence Table 147. Results of meta-analysis of studies of temporal lobe surgery reporting new cases of depression after surgery

Reference | Number of Patients | Number of New Cases of Depression After Treatment | Percentage | Cohen's h Effect Sizes | 95% Confidence Interval | p Values for Effect Sizes | Standardized Residuals for Effect Sizes
Kanemoto (2001) | 52 | 2 | 3.8 | 0.39 | 0.01–0.78 | 0.044109 | -1.66
Kohler (2001) | 58 | 6 | 10.3 | 0.65 | 0.29–1.02 | 0.000421 | -0.29
Nees (2001) | 50 | 14 | 28.0 | 1.12 | 0.72–1.51 | <0.000001 | 2.14
Wiebe (2001) | 36 | 7 | 19.4 | 0.91 | 0.45–1.38 | 0.000107 | 0.91
| 40 - control patients | 8 | 20.0 | --- | --- | --- | ---
Anhoury (2000) | 109 | 26 | 23.9 | 1.02 | 0.76–1.29 | <0.000001 | 2.57
Derry (2000) | 39 | 4 | 10.3 | 0.65 | 0.21–1.10 | 0.003988 | -0.25
Altshuler (1999) | 49 | 5 | 10.2 | 0.65 | 0.25–1.05 | 0.001288 | -0.29
Ring (1998) | 60 | 7 | 11.7 | 0.70 | 0.34–1.06 | 0.000134 | -0.05
Naylor (1994) | 37 | 2 | 5.4 | 0.47 | 0.01–0.92 | 0.043542 | -1.05
Bladin (1992) | 107 | 5 | 4.7 | 0.44 | 0.17–0.70 | 0.001436 | -2.18

Evidence Table 148. Studies of temporal lobe surgery reporting new cases of depression after surgery - data used in meta-regression

Reference | Number of Patients | Cohen's h Effect Size | Weight | Year Study Started | Year Study Ended | Mesial Temporal Sclerosis Patients Only | Standard Temporal Lobectomy | Age at Surgery | Conducted in the United States
Kanemoto (2001) | 52 | 0.3948 | 26 | 1987 | 1999 | No | Yes | 27.1 | No
Kohler (2001) | 58 | 0.6549 | 29 | 1986 | 1999 | No | Yes | 32.3 | Yes
Nees (2001) | 50 | 1.1152 | 25 | 1992 | 1994 | No | Yes | 26 | No
Wiebe (2001) | 36 | 0.9133 | 18 | 1996 | 2000 | No | Yes | 34.4 | No
Anhoury (2000) | 109 | 1.0205 | 54.5 | 1988 | 1997 | No | Yes | 30.1 | No
Derry (2000) | 39 | 0.652 | 19.5 | 1996 | 1998 | No | Yes | 31.2 | No
Altshuler (1999) | 49 | 0.6503 | 24.5 | 1974 | 1990 | Yes | Yes | 40 | Yes
Ring (1998) | 60 | 0.6972 | 30 | 1995 | 1996 | No | Yes | 27 | No
Naylor (1994) | 37 | 0.4693 | 18.5 | 1987 | 1991 | No | No | 29.1 | No
Bladin (1992) | 107 | 0.4358 | 53.5 | 1975 | 1991 | No | Yes | 30.8 | No

Evidence Table 149. Results of meta-regression of studies of temporal lobe surgery reporting new cases of depression after surgery

One predictor variable Bolded = statistically significant coefficient
Covariate | Intercept (CI) | P (intercept) = | Coefficient (CI) | P (coefficient) | Q_e_ = | P (Q_e_) =
Start year (centered)t | 0.73 (0.61 to 0.84) | <0.000001 | 0.02 (0.00 to 0.03) | 0.034561 | 13.400 | 0.099
End year (centered) | 0.71 (0.60 to 0.83) | <0.000001 | 0.02 (-0.01 to 0.06) | 0.163850 | 16.060 | 0.042
Mesial temporal sclerosis (MTS=0) | 0.65 (0.25 to 1.05) | 0.001318 | 0.06 (-0.35 to 0.47) | 0.773529 | 17.940 | 0.022
Standard (St = 0) | 0.72 (0.60 to 0.84) | <0.000001 | -0.25 (-0.72 to 0.22) | 0.293673 | 16.910 | 0.031
Treatmet age (centered) | 0.71 (0.59 to 0.82) | <0.000001 | -0.01 (-0.04 to 0.03) | 0.689034 | 17.964 | 0.021
United States (USA = 0) | 0.65 (0.39 to 0.92) | 0.000002 | 0.06 (-0.23 to 0.36) | 0.666754 | 17.8370 | 0.022
% Males (centered) | 0.70 (0.58 to 0.81) | <0.000001 | -0.01 (-0.02 to 0.01) | 0.347664 | 17.0790 | 0.029

Evidence Table 149-A. Results of meta-regression of studies of temporal lobe surgery reporting new cases of depression after surgery (continued)

Two predictor variables: Start year plus one variable
Bolded = homogeneous only (2^nd^ predictor variable not significant)
Covariate: B_1_ | Covariate: B_2_ | Intercept (CI) | P (intercept) | Coefficient B_1_ (CI) | P (B_1_) = | Coefficient B_2_ (CI) | P(B_2_) | Q_e_ = | P (Q_e_) =
Start year (centered) | End year (centered) | 0.73 (0.62 to 0.84) | <0.000001 | 0.02 (0.00 to 0.04) | 0.094916 | -0.01 (-0.05 to 0.04) | 0.821843 | 13.4900 | 0.061
Start year (centered) | MTS (MTS=0) | 0.92 (0.46 to 1.38) | 0.000084 | 0.02 (0.00 to 0.04) | 0.025968 | -0.20 (-0.67 to 0.27) | 0.397550 | 12.6830 | 0.080
Start year (centered) | Standard (St = 0) | 0.75 (0.63 to 0.86) | <0.000001 | 0.02 (0.00 to 0.03) | 0.029075 | -0.27 (-0.74 to 0.21) | 0.268487 | 12.1720 | 0.095
Start year (centered) | Treatmet age (centered) | 0.74 (0.62 to 0.85) | <0.000001 | 0.02 (0.00 to 0.04) | 0.028560 | 0.01 (-0.02 to 0.05) | 0.464442 | 12.8680 | 0.075
Start year (centered) | United States (USA = 0) | 0.78 (0.49 to 1.07) | <0.000001 | 0.02 (0.00 to 0.03) | 0.030205 | -0.06 (-0.37 to 0.26) | 0.729666 | 13.2810 | 0.066
Start year (centered) | % Males (centered) | 0.72 (0.61 to 0.84) | <0.000001 | 0.02 (0.00 to 0.03) | 0.032570 | -0.01 (-0.02 to 0.01) | 0.430557 | 12.7630 | 0.078

Evidence Table 150. Studies reporting new cases of psychosis after temporal lobe surgery

Reference | N | Years | Country | Exclusion from Surgery | Method of Diagnosis
Kanemoto (2001) | 52 | 1987-1999 | Japan | Patients were excluded from surgery if they had chronic psychosis | Psychotic disorder due to a general medical condition that fulfilled the Diagnostic and Statistical Manual of Mental Disorders-4^th^ edition (DSM-IV) criteria
Wiebe (2001) | 36 | 1996-2000 | Canada | Patients were excluded from surgery if they had chronic psychosis | Psychopathology was assessed with the General Health Questionnaire
Anhoury (2000) | 109 | 1988-1997 | England | Patients were not excluded for psychiatirc disorders | Clinical diagnoses of psychosis were made by experienced psychiatrists with an interest in epilepsy.
Blumer (1998) | 44 | 1994-1995 | United States | Patients were not excluded for psychiatirc disorders | Patients were evaluated by a psychiatrist using a standardized psychiatric evaluation developed specifically for patients with epilepsy
Naylor (1994) | 37 | 1987-1991 | Denmark | Patients were not excluded for psychiatirc disorders | Patients were diagnosed as having acute psychotic disorder before or after surgery using the criteria of the International Classification of Diseases-10^th^ revision.
Bladin (1992) | 107 | 1975-1991 | Australia | Patients were not excluded for psychiatirc disorders | DSM-III criteria were used to diagnose psychoses.

Evidence Table 151. Patient characteristics for studies of temporal lobe surgery reporting new cases of psychosis

Reference | N | Surgery | Pathology | Mean Age at Surgery (Years) | SD of Age at Surgery (Years) | Mean Age at Seizure Onset (Years) | SD of Age at Seizure Onset (Years) | Mean Duration of Epilepsy Before Surgery (Years) | SD of Duration Before Surgery (Years) | Right Side Surgeries | Left Side Surgeries | Number of Males | Number of Females
Kanemoto (2001) | 52 | Standard | Not reported | 27.1 | 5.9 | 9.7 | 5.3 | 17.5 | 7.8 | 22 | 30 | 28 | 24
Wiebe (2001) | 36 | Standard | Various | 34.4 | 9.9 | 16.2 | 10 | | | 12 | 24 | 21 | 19
Anhoury (2000) | 109 | Not described | Various | 30.1 | 7.4 | | | | | | | 50 | 71
Blumer (1998) | 44 | Not described | Various | 36 | | | | 20.5 | 13.2 | 22 | 22 | 19 | 25
Naylor (1994) | 37 | AH | Various | 29.1 | 9.1 | 11.5 | 10.3 | 17.6 | 8.2 | | | 22 | 15
Bladin (1992) | 107 | Standard | Not reported | | | | | | | 62 | 48 | 46 | 64

AH Amygdalohippocampectomy

Evidence Table 152. Studies of temporal lobe surgery reporting new cases of psychosis after surgery

Reference | Number of Patients | New Cases of Psychosis After Treatment | Percentage | Cohen's h Effect Sizes | 95% Confidence Interval | p Values for Effect Sizes | Standardized Residuals for Effect Sizes
Kanemoto (2001) | 52 | 7 | 13.5 | 0.75 | 0.37–1.14 | 0.000128 | 2.09
Wiebe (2001) | 36 | 1 | 2.8 | 0.33 | -0.13–0.80 | 0.155362 | -0.16
| 40 - control patients | 1 | 2.5 | --- | --- | --- | ---
Anhoury (2000) | 109 | 3 | 2.8 | 0.33 | 0.07–0.60 | 0.013860 | -0.32
Blumer (1998) | 44 | 2 | 4.5 | 0.43 | 0.01–0.85 | 0.043855 | 0.30
Naylor (1994) | 37 | 0 | 0.0 | 0.00 | -0.46–0.46 | 1.000000 | -1.67
Bladin (1992) | 107 | 3 | 2.8 | 0.34 | 0.07–0.60 | 0.013852 | -0.29

Evidence Table 153. Studies of temporal lobe surgery reporting both the number of patients with IQ changes after surgery and the pre-treatment and post-treatment mean IQ

Reference | N | Years | Country | Test Used to Determine IQ | Method Used to Determine Significant Change in IQ
Miranda (2001) | 50 | 1976-1998 | Canada | Wechsler Intelligence Scale for Children—Revised, Wechsler Intelligence Scale for Children—III, Wechsler Adult Intelligence Scale—Revised. Used Verbal IQ data for analysis. | A significant change following surgery for epilepsy was defined as two times the value of the average standard error of measurement for each scale.
Robinson (2000) | 21 | 1993-1998 | United States | Wechsler Intelligence Scale for Children—III, Wechsler Adult Intelligence Scale—Revised. Used Verbal IQ data for analysis. | A significant individual change was defined as a difference between pre- and postoperative scores greater than 0.5 SDs (>8 points)
Westerveld (2000) | 82 | | United States | Wechsler Intelligence Scale for Children. Used Verbal IQ data for analysis. | The frequency of changes in IQ exceeding two times the value of the standard error of the measurement from each scale was used to determine significant changes (seven points for VIQ).
Chelune (1993) | 96 | 1990-1991 | United States | Wechsler Adult Intelligence Scale—Revised. Used Verbal IQ data for analysis. | A significant individual change between pretest and posttest scores was defined as exceeding the reliable change interval of 90% after correction for expected practice effects.
Ivnik (1988) | 141 | 1972-1987 | United States | Wechsler Adult Intelligence Scale-Revised. Used Verbal IQ data for analysis. | Changes that are larger than the standard error of the measuring instrument represent cases in which true cognitive change occurred for a specific patient.
Powell (1985) | 59 | 1973-1984 | England | Wechsler Adult Intelligence Scale—Revised. Used Verbal IQ data for analysis. | Change in pretest to posttest scores of more than 10 points.

Evidence Table 154. Patient characteristics for studies of temporal lobe surgery reporting individual patient changes in IQ

Reference | N | Surgery | Pathology | Mean Age at Surgery (Years) | SD of Age at Surgery (Years) | Mean Age at Seizure Onset (Years) | SD of Age at Seizure Onset (Years) | Mean Duration of Epilepsy Before Surgery (Years) | SD of Duration Before Surgery (Years) | Right Side Surgeries | Left Side Surgeries | Number of Males | Number of Females | Patient With Secondarily Generalized Seizures
Miranda (2001) | 50 | Not described | Various | 13.3 | 3.4 | 6.1 | 4.6 | 7.3 | 4.5 | 25 | 25 | 21 | 29
Robinson (2000) | 22 | AH | Various | 15.4 | | 5.2 | | 10.3 | | 8 | 14 | 13 | 9
Westerveld (2000) | 82 | Not described | Various | 14.4 | | 5.4 | | | | | | 48 | 34
Chelune (1993) | 96 | Standard | Not reported | 29.4 | 7.4 | 13.2 | 9.2 | 16.5 | 8.4 | 49 | 47 | 60 | 36
Ivnik (1988) | 141 | Tailored | Not reported | 28 | 7.8 | 12.9 | 9.4 | | | | | 68 | 74 | 54
Powell (1985) | 59 | Standard | Not reported | 25.5 | 9.6 | 9.6 | 8 | | | 30 | 29 | 34 | 15

AH Amygdalohippocampectomy

Evidence Table 155. Studies of temporal lobe surgery reporting individual patient changes in verbal IQ after surgery

| | Significant Decrease in IQ | | | | | Significant Increase in IQ
Reference | Number of Patients | N | Cohen's h Effect Sizes | 95% Confidence Interval | p Values for Effect Sizes | Standardized Residuals for Effect Sizes | N | Cohen's h Effect Sizes | 95% Confidence Interval | p Values for Effect Sizes | Standardized Residuals for Effect Sizes
Miranda (2001) | 50 | 7 | 0.77 | 0.37–1.16 | 0.000126 | 0.61 | 7 | 0.77 | 0.37–1.16 | 0.000126 | 0.12
Robinson (2000) | 21 | 1 | 0.44 | -0.16–1.04 | 0.153959 | -0.71 | 4 | 0.90 | 0.30–1.51 | 0.003424 | 0.53
Westerveld (2000) | 82 | 8 | 0.64 | 0.33–0.94 | 0.000047 | -0.12 | 7 | 0.59 | 0.29–0.90 | 0.000146 | -1.07
Chelune (1993) | 96 surgery | 8 | 0.59 | 0.30–0.87 | 0.000050 | -0.52 | 8 | 0.59 | 0.30–0.87 | 0.000050 | -1.24
| 40 control | 2 | --- | --- | --- | --- | 2 | --- | --- | --- | ---
Ivnik (1988) | 141 | 13 | 0.62 | 0.38–0.85 | <0.000001 | -0.36 | 27 | 0.91 | 0.67–1.14 | <0.000001 | 1.63
Powell (1985) | 59 | 10 | 0.85 | .049–1.21 | 0.000004 | 1.14 | 8 | 0.75 | 0.39–1.12 | 0.000042 | 0.06

Evidence Table 156. Studies of temporal lobe surgery reporting individual patient changes in verbal IQ - changes in mean IQ

Reference | Number of Patients | Mean Pre-surgery IQ | SD of the Pre-surgery IQ | Mean Post-surgery IQ | SD of the Post-surgery IQ | Hedges'd Effect Sizes | 95% Confidence Interval | p Values for Effect Sizes | Standardized Residuals for Effect Sizes
Miranda (2001) | 50 | 86 | 17 | 87 | 16 | -0.06 | -0.45–0.33 | 0.763796 | -0.05
Robinson (2000) | 21 | 87 | 9 | 89 | 12 | -0.09 | -0.70–0.51 | 0.764497 | -0.14
Westerveld (2000) | 82 | 93 | 16 | 93 | 14 | 0.00 | -0.31–0.31 | 1.000000 | 0.38
Chelune (1993) | 96 surgery | 90 | 11 | 91 | 12 | -0.17 | -0.46–0.11 | 0.231396 | -1.02
| 40 control | 92.1 | 12.9 | 93.0 | 12.8 | --- | --- | --- | ---
Ivnik (1988) | 141 | 95 | NR | 96 | NR | --- | --- | --- | ---
Powell (1985) | 59 | 100 | 20 | 98 | 19 | 0.10 | -0.26–0.46 | 0.580321 | 0.92

Evidence Table 157. Sensitivity analysis of studies of temporal lobe surgery reporting mean IQ

| | 95% Confidence Interval
Sensitivity Adjustment | Hedges'd Summary Estimate | Lower | Upper | p Value for Summary Estimate | Q | p Value for Q
Original analysis | -0.05 | -0.21 | 0.11 | 0.53 | 1.53 | 0.82
Removing study with smallest effects size^a^ | 0.00 | -0.19 | 0.20 | 0.96 | 0.48 | 0.92
Removing study with largest effect size | -0.09 | -0.26 | 0.09 | 0.34 | 0.68 | 0.88
Removing study with smallest N | -0.05 | -0.21 | 0.12 | 0.57 | 1.51 | 0.68
Removing study with largest N | 0.00 | -0.19 | 0.20 | 0.96 | 0.48 | 0.92

a The study with the smallest effect size also had the largest N.

Evidence Table 158. Studies of temporal lobe surgery reporting individual changes in patient memory after surgery

Reference | Number of Patients | Years | Country | Wechsler Memory Scale Used in Study
Canizares (2000) | 33 | 1998-1999 | Spain | General Memory Score
Chelune (1993) | 96 | 1990-1991 | United States | Verbal
Ivnik (1988) | 141 | 1972-1987 | United States | Memory quotient
Ojemann (1985) | 13 | 1983-1983 | United States | Verbal
Powell (1985) | 59 | 1973-1984 | England | Logical Memory percent Recall

Evidence Table 159. Studies of temporal lobe surgery reporting individual patient changes in memory function

Reference | Number of Patients | Wechsler Memory Scale Used in Study | Number of Patients With a Significant Decrease in Memory Score | Percentage of Patients Experiencing a Decrease | Number of Patients With a Significant Increase in Memory Score | Percentage of Patients Experiencing an Increase | Baseline Mean Memory Score | Baseline SD of the Mean Memory Score | Mean Memory Score After Surgery | SD of the Mean Memory Score After Surgery
Canizares (2000) | 33 | General Memory Score | 3 | 9.1% | 10 | 30.3% | 80 | 15 | 88 | 19
Chelune (1993) | 96 surgery patients | Verbal | 28 | 29.2% | 1 | 1.0% | 90 | 14 | 87 | 14
| 40 control patients | Verbal | 1 | 2.5% | 2 | 5% | 94.5 | 17.4 | 102.5 | 18.3
Ivnik (1988) | 141 | Memory quotient | 48 | 34.0% | 48 | 34.0% | 100 | | 100
Ojemann (1985) | 13 | Verbal | 8 | 61.5% | 3 | 23.1% | 23 | | 17
Powell (1985) | 59 | Logical Memory percent Recall | 8 | 13.6% | 13 | 22.0% | 70 | 28 | 74 | 25

Evidence Table 160. Patient characteristics for studies of temporal lobe surgery reporting complications due to surgery

Reference | N | Surgery | Pathology | Mean Age at Surgery (Years) | SD of Age at Surgery (Years) | Mean Age at Seizure Onset (Years) | SD of Age at Seizure Onset (Years) | Mean Duration of Epilepsy Before Surgery (Years) | SD of Epilepsy Before Surgery (Years) | Right Side Surgeries | Left Side Surgeries | Number of Males | Number of Females | Number of Patients With Simple Partial Seizures | Number of Patients With Secondarily Generalized Seizures
Boling (2001) | 18 | AH | Various (no tumors) | 54 | | 18 | | 34.9 | 12.1 | | | 9 | 9
Schramm (2001) | 61 | Neocortex | Various | 27.9 | | 14.4 | | 13.6 | | 26 | 35 | 27 | 34 | 14 | 33
Sotero de Menezes (2001) | 15 | Tailored | Various | 8.3 | 3.1 | | | | | 9 | 5 | | | 10
Wiebe (2001) | 36 | Standard | Various | 34.4 | 9.9 | 16.2 | 10 | | | 12 | 24 | 21 | 19
Iannelli (2000) | 37 | Neocortex | Tumor | 9.1 | 5 | | | 2.8 | | 16 | 21 | 27 | 10 | 2 | 2
Rao (2000) | 164 | Standard | Various | 25.6 | | | | 16.1 | | | | 60 | 59
Robinson (2000) | 21 | AH | Various | 15.4 | | 5.2 | | 10.3 | | 8 | 14 | 13 | 9
Wurm (2000) | 16 | AH | Various | 35.7 | | | | | | 3 | 13 | 7 | 9
Altshuler (1999) | 49 | Standard | MTS | 40 | 5.5 | 11.4 | 8.3 | 17.6 | 4.3 | 23 | 26 | 23 | 26
Leung (1999) | 11 | Standard | MTS | 28 | | | | 17.2 | | 8 | 3 | 4 | 7
Parrent (1999) | 19 | AH | Not reported | 34.1 | | | | | | 7 | 12 | 10 | 9
Salanova (1999) | 145 | Tailored | Various | 30.4 | | 10.5 | | 19.7 | | 71 | 74
Son (1999) | 71 | Standard | MTS | 28.9 | | | | | | | | 45 | 26
Visudhiphan (1999) | 14 | Standard | Various | 13.1 | 3.6 | 6.7 | 3.8 | 6.4 | 4.5 | 4 | 10 | 7 | 7
Radhakrishnan (1998) | 175 | Tailored | Various | 31 | | 8 | | 19 | | 68 | 107 | 77 | 98
Wyllie (1998) | 72 | Standard | Various | | | 4.4
Bizzi (1997) | 14 | Partial | Various | 11.9 | 4.6 | | | | | | | 11 | 8
Blume (1997) | 14 | Tailored | Various | 8.5 | | 2.6 | | 6 | | 6 | 8 | 7 | 7 | 13
Kilpatrick (1997) | 36 | Standard | Various | 36.8 | 11.5 | 15 | | | | 8 | 10 | 11 | 7
Adam (1996) | 30 | Standard | MTS | 29 | | 9 | | | | 15 | 15 | 11 | 19 | 19 | 17
Acciarri (1995) | 10 | Neocortex | Vascular malformation | 34.8 | 12.5 | 33.3 | 12.8 | 1.6 | 1.2 | 5 | 5 | 5 | 5 | | 0
Davies (1995) | 12 | Tailored | Various | 23 | | | | 8
Jooma (1995a) | 14 | Tailored | Tumor | 34.1 | 10 | 14.4 | 7.3 | 19.7 | 7.7
| 16 | Neocortex | Tumor | 26.5 | 17.3 | 23.8 | 18.6 | 2.7 | 3.1
Jooma (1995b) | | | | | | | | | | | | | | | 6
Liu (1995) | 22 | Tailored | Other | 37.2 | 13.7 | 17.8 | 9.5 | 19.3 | 8.2 | 5 | 7 | 5 | 7 | 0 | 8
Wyler (1995) | 70 | Standard | Various | 30.9 | | 10.5 | | | | 23 | 47 | 37 | 33
Blume (1994) | 125 | Standard | Various | | | | | | | | | 64 | 61
Guldvog (1994b) | 64 | Standard | Various | | | | | 11.5
Guldvog (1994a) | 35 | Standard | Various | | | | | 8 | | 25 | 10
Hopkins (1991) | 11 | Standard | Various | 5.5 | 2.2 | 2 | 1.4 | 3.6 | 2.1 | 5 | 6 | 8 | 3
Bidzinski (1990) | 320 | Standard | Not reported | 23 | | 8 | | 13
Mackenzie (1990) | 30 | Standard | Not reported | | | | | | | | | | | 18 | 19
Mizrahi (1990) | 22 | Tailored | Various | 21 | 8.4 | 5.9 | 2.3 | 15.1 | 8.1 | 10 | 12
Walczak (1990) | 100 | Standard | Not reported | 25 | | | | 15 | | 45 | 55 | 59 | 41
So (1989) | 48 | Tailored | Bitemporal epileptiform abnormalities | 27.5
Cutfield (1987) | 26 | Tailored | Various | 22 | | | | 12 | | 17 | 9 | 11 | 15
Drake (1987) | 16 | Tailored | Tumor | 12.7 | 2.7 | 6.3 | 4.3 | 6.5 | 3.9 | | | 8 | 3 | 3 | 7
King (1986) | 23 | Not described | Various | 28.7 | 9.2 | 12.9 | 10.5 | 15.7 | 7.6 | | | 12 | 11
Meyer (1986) | 50 | Tailored | Not reported | 15.8 | | 7.5 | | 8.3 | | 27 | 23 | 29 | 21
Carey (1985) | 24 | Standard | Various | 21 | | 10.8 | | 14.7 | | | | 11 | 13 | 3 | 12
Delgado-Escueta (1985) | 15 | Standard | Various | 26.5 | 6.9 | 15.8 | 8 | 10.7 | 4.9 | 5 | 10 | 12 | 3 | 1 | 12

AH Amygdalohippocampectomy

MTS Mesial temporal sclerosis

Evidence Table 161. Complications due to surgery reported in studies of temporal lobe surgery

Reference | N | Number of Patients with a Serious Permanent Complication | Percentage of Permanent Complications | List of Permanent Complications a | Number of Patients with a Mild or Transient Complication | Percentage of Transient Complications | List of Transient Complications a
Boling (2001) | 18 | 0 | 0.00 | | 1 | 5.56 | Scalp wound infection (1)
Schramm (2001) | 61 | 0 | 0.00 | | 3 | 4.92 | Meningitis (2), Dysphasia (1)
Sotero de Menezes (2001) | 15 | 1 | 6.67 | Hemiparesis (1) | 3 | 20.00 | 4th cranial nerve palsy (1), Speech delay (1), Attention-deficit disorder (1)
Wiebe (2001) | 36 | 2 | 5.56 | Sensory abnormality of the thigh due to a small thalamic infarct (1) | 1 | 2.78 | Wound infection (1)
Iannelli (2000) | 37 | 1 | 2.70 | Hemiparesis (1) | 2 | 5.41 | Skin flap infection (1), Dysphasia (1)
Rao (2000) | 164 | 1 | 0.61 | Hemiplegia due to injury to the anterior choroidal artery (1) | | | Complications were not reported per patient. Hemiparesis (5), Dysphasia (2), Meningitis (2), Wound infection (2), Oculomotor nerve palsy (1)
Robinson (2000) | 41 | 2 | 9.09 | Partial peripheral nerve palsy (1), Dysnomia (1) | 6 | 14.6 | Partial peripheral nerve palsy (2), Dysnomia (2), Facial nerve palsy (1), Dysnomia (1)
Wurm (2000) | 16 | 1 | 6.25 | Hemiparesis (1) | 0 | 0.00
Altshuler (1999) | 49 | 5 | 10.20 | Hemiparesis (3), Cranial nerve palsy (1), Dysplagia (1) | | | Not reported
Leung (1999) | 11 | 1 | 9.09 | Paralysis of the frontalis muscle due to facial nerve injury (1) | 1 | 9.09 | Vocal cord palsy (1)
Parrent (1999) | 19 | 0 | 0.00 | | 1 | 5.26 | Hematoma
Salanova (1999) | 145 | 2 | 1.38 | Hemiparesis (1), Homonymous hemianopsia (1) | 1 | 0.69 | Hemiparesis (1)
Son (1999) | 71 | 2 | 2.82 | Hemiparesis (2) | 2 | 2.82 | Surgical wound infection (2)
Visudhiphan (1999) | 14 | 0 | 0.00 | | 0 | 0.00
Radhakrishnan (1998) | 175 | 2 | 1.14 | Hemiparesis (1), Dysphasia (1) | | | Not reported
Wyllie (1998) | 72 | 0 | 0.00 | | 2 | 2.78 | Language disturbance after venous infraction (1), Ipsilateral superior oblique paresis (1)
Bizzi (1997) | 14 | 1 | 7.14 | Basal ganglia infarction (1) | 3 | 21.43 | Micrographia (1), Hemiparesis (1), Bone flap osteomyelitis (1)
Blume (1997) | 14 | 0 | 0.00 | | | | Not reported
Kilpatrick (1997) | 36 | 0 | 0.00 | | 3 | 8.33 | Mild dysphasia (3)
Adam (1996) | 30 | 2 | 6.67 | Upper limb deficient due to infarction (1), Hemiparesis (1) | 0 | 0.00
Acciarri (1995) | 10 | 0 | 0.00 | | 0 | 0.00
Davies (1995) | 12 | 1 | 8.33 | Worsening of preoperative hemiparesis (1) | 3 | 25.00 | Persistent mild dysphasia (1), Bone flap infection (2)
Jooma (1995b) | 30 | 2 | 12.50 | Hemiparesis (2) | | | Not reported
Liu (1995) | 22 | 2 | 9.09 | Moderate increase in preexisting hemiparesis (2) | 0 | 0.00
Wyler (1995) | 70 | 3 | 4.29 | Subgaleal cerebrospinal fluid fistula (3) | 1 | 1.43 | Nerve paresis (1)
Blume (1994) | 125 | 1 | 0.80 | Hemiparesis (1) | 1 | 0.80 | Hemiparesis (1)
Guldvog (1994a) | 35 | 0 | 0.00 | | 6 | 17.14 | Minor hemiparesis (3), Minor partial facial paresis (2), Dysphasia (1)
Guldvog (1994b) | 64 | 6 | 9.38 | Memory deficit and Dysphasia (1), Long-term slow cerebration (1), Facial paresis and Dysphasia (1), Memory deficit and Hemiparesis (1), Hemiparesis and Hypalgesia (1), Paresis of the left arm and ataxia (1) | 5 | 7.81 | Facial paresis (4), Hemiparesis (1)
Hopkins (1991) | 11 | 0 | 0.00 | | 2 | 18.18 | Hemiparesis, mild (2)
Bidzinski (1990) | 320 | 2 | 0.63 | Hemiparesis (2) | | | Not reported
Mackenzie (1990) | 30 | 0 | 0.00 | | 2 | 6.67 | Mild word-finding difficulty (1), Mild hemiparesis (1)
Mizrahi (1990) | 22 | 0 | 0.00 | | 0 | 0.00
Walczak (1990) | 100 | 1 | 1.00 | Hemiplegia (1) | 9 | 9.00 | Bone flap infection (1), Decrease spontaneous speech or anomias (7), Hemiparesis (1)
So (1989) | 48 | 0 | 0.00 | | 3 | 6.25 | Dysphasia (2), Wound infection (1)
Cutfield (1987) | 26 | 0 | 0.00 | | 1 | 3.85 | Dysphasia (1)
Drake (1987) | 16 | 0 | 0.00 | | 4 | 25.00 | Mild contralateral hemiparesis (3), Contralateral increase in tone only (1)
King (1986) | 23 | 0 | 0.00 | | 3 | 13.04 | Dysphasia (3)
Meyer (1986) | 50 | 0 | 0.00 | | 6 | 12.00 | Infected bone flaps (2), Rhinorrhea (1), Upper-extremity paresis (2), Expressive Dysphasia (1)
Carey (1985) | 24 | 0 | 0.00 | | 2 | 8.33 | Hemiparesis, mild (1), Dysphasia (1)
Delgado-Escueta (1985) | 15 | 1 | 6.67 | Cerebral anoxic episode causing a drop in mental quotient (1) | 2 | 13.33 | Dysphasia and mild right arm clumsiness (1), Mild naming disorder (1)

a The number of patients with each specific complication is in parenthesis

Evidence Table 162. Patient characteristics for studies of temporal lobe surgery reporting surgery related mortality

Reference | N | Surgery | Pathology | Mean Age at Surgery (Years) | SD of Age at Surgery (Years) | Mean Age at Seizure Onset (Years) | SD of Age at Seizure Onset (Years) | Mean Duration of Epilepsy Before Surgery (Years) | SD of Duration Before Surgery (Years) | Right Side Surgeries | Left Side Surgeries | Number of Males | Number of Females | Number of Patients With Simple Partial Seizures | Number of Patients With Secondarily Generalized Seizures
Boling (2001) | 18 | AH | Various (no tumors) | 54 | | 18 | | 34.9 | 12.1 | | | 9 | 9
Schramm (2001) | 61 | Neocortex | | 27.9 | | 14.4 | | 13.6 | | 26 | 35 | 27 | 34 | 14 | 57
Wiebe (2001) | 36 | Standard | Various | 34.4 | 9.9 | 16.2 | 10 | | | 12 | 24 | 21 | 19
Iannelli (2000) | 37 | Neocortex | Tumor | 9.1 | 5 | | | 2.8 | | 16 | 21 | 27 | 10 | 2 | 21
Rao (2000) | 164 | Standard | Various | 25.6 | | | | 16.1 | | | | 60 | 59 | | 119
Robinson (2000) | 22 | AH | Various | 15.4 | | 5.2 | | 10.3 | | 8 | 14 | 13 | 9 | | 22
Wurm (2000) | 16 | AH | Various | 35.7 | | | | | | 3 | 13 | 7 | 9
Altshuler (1999) | 49 | Standard | MTS | 40 | 5.5 | 11.4 | 8.3 | 17.6 | 4.3 | 23 | 26 | 23 | 26 | | 49
Leung (1999) | 11 | Standard | MTS | 28 | | | | 17.2 | | 8 | 3 | 4 | 7 | | 11
Parrent (1999) | 19 | AH | Not reported | 34.1 | | | | | | 7 | 12 | 10 | 9
Salanova (1999) | 145 | Tailored | Various | 30.4 | | 10.5 | | 19.7
Son (1999) | 71 | Standard | MTS | 28.9 | | | | | | 71 | 74
Visudhiphan (1999) | 14 | Standard | Various | 13.1 | 3.6 | 6.7 | 3.8 | 6.4 | 4.5 | | | 45 | 26
Wyllie (1998) | 72 | Standard | Various | | | 4.4 | | | | 4 | 10 | 7 | 7 | | 14
Bizzi (1997) | 14 | Partial | Various | 11.9 | 4.6
Blume (1997) | 14 | Tailored | Various | 8.5 | | 2.6 | | 6 | | | | 11 | 8
Kilpatrick (1997) | 36 | Standard | Various | 36.8 | 11.5 | 15 | | | | 6 | 8 | 7 | 7 | 13 | 14
Adam (1996) | 30 | Standard | MTS | 29 | | 9 | | | | 8 | 10 | 11 | 7
Acciarri (1995) | 10 | Neocortex | Vascular malformation | 34.8 | 12.5 | 33.3 | 12.8 | 1.6 | 1.2 | 15 | 15 | 11 | 19 | 19 | 30
Berkovic (1995) | 135 | Partial | Various | 29 | 10 | | | | | 5 | 5 | 5 | 5 | | 10
Davies (1995) | 12 | Tailored | Various | 23 | | | | 8
Liu (1995) | 22 | Tailored | Other | 37.2 | 13.7 | 17.8 | 9.5 | 19.3 | 8.2
Wyler (1995) | 70 | Standard | Various | 30.9 | | 10.5 | | | | 5 | 7 | 5 | 7 | 0 | 12
Blume (1994) | 125 | Standard | Various | | | | | | | 23 | 47 | 37 | 33
Guldvog (1994b) | 64 | Standard | Various | | | | | 11.5 | | | | 64 | 61 | | 125
Guldvog (1994a) | 35 | Standard | Various | | | | | 8
Bladin (1992) | 107 | Standard | Not reported | | | | | | | 25 | 10
Elwes (1991) | 108 | Standard | Various | 23 | | | | | | 62 | 48 | 46 | 64
Hopkins (1991) | 11 | Standard | Various | 5.5 | 2.2 | 2 | 1.4 | 3.6 | 2.1 | 53 | 49 | 54 | 48
Bidzinski (1990) | 320 | Standard | Not reported | 23 | | 8 | | 13 | | 5 | 6 | 8 | 3 | | 11
Mizrahi (1990) | 22 | Tailored | Various | 21 | 8.4 | 5.9 | 2.3 | 15.1 | 8.1
Yeh (1990) | 12 | Neocortex | Vascular malformation | 36.3 | 11.9 | 25.3 | 8.3 | 11 | 8.2 | 10 | 12
So (1989) | 48 | Tailored | Bitemporal epileptiform abnormalities | 27.5 | | | | | | 3 | 9 | 8 | 4 | 3 | 9
Cutfield (1987) | 26 | Tailored | Various | 22 | | | | 12 | | 17 | 9 | 11 | 15 | | 26
Drake (1987) | 16 | Tailored | Tumor | 12.7 | 2.7 | 6.3 | 4.3 | 6.5 | 3.9 | | | 8 | 3 | 3 | 11
Meyer (1986) | 50 | Tailored | Not reported | 15.8 | | 7.5 | | 8.3 | | 27 | 23 | 29 | 21
Carey (1985) | 24 | Standard | Various | 21 | | 10.8 | | 14.7 | | | | 11 | 13 | 3 | 20

AH Amygdalohippocampectomy

MTS Mesial temporal sclerosis

Evidence Table 163. Corpus callosotomy studies excluded from the evidence base for seizure frequency outcomes

Reference | N | Reason for Exclusion
Pinard (1999) | 14 | Patients with West Syndrome are different from the patients in the other studies of corpus callosotomy because of the spasms that are characteristic of this syndrome. The main measure of surgical success for these patients is a reduction in spasms and is not comparable to the seizure-free and seizure frequency reduction outcome measurements reported in the other studies in the evidence base.

Evidence Table 164. Patient characteristics in studies of corpus callosotomy reporting seizure frequency outcomes

Reference | N | Pathology | Mean Age at Treatment (Years) | SD of Age at Treatment (Years) | Mean Age at Seizure Onset (Years) | SD of Age at Seizure Onset (Years) | Duration of Condition Before Treatment (Years) | SD of Duration Before Treatment (Years) | Males | Females | Simple Partial Seizures | Complex Partial Seizures | Secondarily Generalized Seizures | Generalized Convulsive Seizures
Kwan (2001) | 61 | Lennox-Gastaut | 7.9 | | | | | | 47 | 14
Maehara (2001) | 52 | | 18 | | 5.1 | | 12.9 | | 34 | 18 | 24 | 5 | | 52
Matsuzaka (1999) | 22 | | 19 | | 5.6 | | 13.3 | | | | 9 | 7 | | 17
McInerney (1999) | 47 | | 13.6 | | 3.8 | | 9.8 | | 28 | 19 | 18 | 19 | | 47
Sakas (1996) | 20 | | 25.7 | 1.4 | 8.8 | 1.4 | | | 14 | 6 | | 8 | | 20
Claverie (1995) | 20 | | 22.8 | 9.7
Reutens (1993) | 64 | | 20 | | 5.2 | | 14.8 | | 38 | 26 | 14 | 20 | | 64
Marino (1990) | 28 | | 21.4 | 10.1 | 6.5 | 5.7 | 14.9 | 8.2 | | | 25 | 23 | | 25
Murro (1988) | 25 | | 25.8 | 11.8 | 6.2 | 3.6 | 19.6 | 11.3 | 7 | 6 | 1 | 5 | | 10
Purves (1988) | 24 | | 25.9 | 10.9 | 6.3 | 6.8 | 19.6 | 10.2 | 12 | 12 | 8 | 19 | 5 | 12
Spencer (1988) | 22 | | 20.5 | 6.6 | 5.6 | 3.8 | 14.9 | 7 | 17 | 5 | 13 | 21 | | 22
Gates (1987) | 24 | | | | | | | | 15 | 7 | 1 | 19 | 22 | 22

Evidence Table 165. Studies of corpus callosotomy reporting a percentage reduction in seizure frequency

| | | | | | Number of Patients
Reference | N | Type of Seizure Evaluated | Followup Period in Years | Minimum Followup | Maximum Followup | 90% or Greater Reduction | 75% to 90% Reduction | 50% to 75% Reduction | Less than 50% Reduction | No Change or Worse
Kwan (2001) | 61 | All seizure types | | 2 | | 11 | 0 | 27 | 7 | 16
Maehara (2001) | 52 | Disabling generalized seizures | 3.3 | 2 | 6.8 | 32
Matsuzaka (1999) | 22 | Most disabling seizures | 4.8 | 2.1 | 8.4 | 4 | 10 | 3 | 5 | 0
McInerney (1999) | 43 | Most disabling seizures | 12.3 | 2 | 27 | 13 | 11 | 6 | 3 | 10
Sakas (1996) | 20 | Drop attacks and generalized tonic-clonic seizures | 6.7 | | | 6 | 0 | 10 | 0 | 4
Claverie (1995) | 15 | All seizure types | 4.5 | 2 | 10 | 4 | 1 | 2 | 2 | 6
Reutens (1993) | 27 | All seizure types | | 2 | | | | 14 | 13
Marino (1990) | 28 | All seizure types | 8.7 | 4 | 11 | 22 | 3 | 2 | 0 | 1
Murro (1988) | 13 | All seizure types | 3.1 | 2.3 | 5.6 | 3 | 4 | 2 | 1 | 3
Purves (1988) | 24 | All seizure types | 5.1 | 2 | 11 | | 17 | | | 3
Spencer (1988) | 22 | All seizure types | 2 | | | 2 | 5 | 5 | 7 | 3
Gates (1987) | 22 | All seizure types | 3.7 | 2.1 | 6.6 | 8 | 3 | 5 | 5 | 1

Evidence Table 166. Studies of corpus callosotomy reporting a 90% or greater reduction in frequency of all seizure types

Reference | N | Followup Period in Years | Minimum Followup | Maximum Followup | Number of Patients With a 90% or Greater Reduction in Seizure Frequency | Percentage | Cohen's h Effect Sizes | 95% Confidence Interval | p Values for Effect Sizes | Standardized Residuals for Effect Sizes
Kwan (2001) | 61 | | 2 | | 11 | 18.0 | 0.88 | 0.52–1.23 | 0.000001 | -0.46
Claverie (1995) | 15 | 4.5 | 2 | 10 | 4 | 26.7 | 1.09 | 0.37–1.80 | 0.002957 | 0.43
Murro (1988) | 13 | 3.1 | 2.3 | 5.6 | 3 | 23.1 | 1.00 | 0.23–1.77 | 0.010616 | 0.17
Spencer (1988) | 22 | | 2 | | 2 | 9.1 | 0.61 | 0.02–1.20 | 0.042193 | -1.18
Gates (1987) | 22 | 3.7 | 2.1 | 6.6 | 8 | 36.4 | 1.29 | 0.70–1.89 | 0.000018 | 1.29

Evidence Table 167. Studies of corpus callosotomy reporting patients who received no benefit from surgery

Patients' seizure frequencies were unchanged or become worse; all seizure types were considered
Reference | N | Followup Period in Years | Minimum Followup | Maximum Followup | No Change or Worse | Percentage | Cohen's h Effect Sizes | 95% Confidence Interval | p Values for Effect Sizes | Standardized Residuals for Effect Sizes
Kwan (2001) | 61 | | 2 | | 16 | 26.2 | 1.08 | 0.72–1.43 | <0.000001 | 1.67
Claverie (1995) | 15 | 4.5 | 2 | 10 | 6 | 40.0 | 1.37 | 0.65–2.09 | 0.000177 | 1.55
Marino (1990) | 28 | 8.7 | 4 | 11 | 1 | 3.6 | 0.38 | -0.14–0.90 | 0.154803 | -1.82
Murro (1988) | 13 | 3.1 | 2.3 | 5.6 | 3 | 23.1 | 1.00 | 0.23–1.77 | 0.010616 | 0.46
Purves (1988) | 24 | 5.1 | 2 | 11 | 3 | 12.5 | 0.72 | 0.16–.29 | 0.012293 | -0.39
Spencer (1988) | 22 | | 2 | | 3 | 13.6 | 0.76 | 0.17–1.35 | 0.012112 | -0.25
Gates (1987) | 22 | 3.7 | 2.1 | 6.6 | 1 | 4.5 | 0.43 | -0.16–1.02 | 0.154113 | -1.41

Evidence Table 168. Studies of corpus callosotomy reporting patients as completely seizure-free

Reference | Number of Patients Evaluated | Type of Seizure Evaluated | Mean Followup Period in Years | Minimum Followup | Maximum Followup | Patients Completely Seizure-Free (No Auras) | Percentage
Marino (1990) | 28 | All seizure types | 8.7 | 4 | 11 | 1 | 3.6
Murro (1988) | 13 | All seizure types | 3.1 | 2.3 | 5.6 | 0 | 0.0
Spencer (1988) | 22 | All seizure types | | 2 | | 1 | 4.5
Gates (1987) | 22 | All seizure types | 3.7 | 2.1 | 6.6 | 3 | 13.6

Evidence Table 169. Studies of corpus callosotomy reporting pre- and postsurgery seizure frequency^ a^

| | | | | Pre-surgery Seizure Frequency | | Post-surgery Seizure Frequency | | Results of Paired t-test^ b^
Reference | N | Followup Period in Years | Minimum Followup | Maximum Followup | Mean | SD | Mean | SD | t | df | p value
Murro (1988) | 13 | 3.1 | 2.3 | 5.6 | 110 | 164.6 | 20 | 35 | 2.0 | 12 | 0.065
Spencer (1988) | 22 | | 2 | | 159 | 210 | 78 | 130 | 2.7 | 21 | 0.014
Gates (1987) | 22 | 3.7 | 2.1 | 6.6 | 178.3 | 273.6 | 40 | 49 | 2.6 | 21 | 0.015

a Seizure frequency is presented as seizures per month

b Calculated by ECRI

Evidence Table 170. Studies of corpus callosotomy reporting relationships between patient or study characteristics and treatment outcome

| | | | Patient Characteristics Examined
Reference | N | Seizure Outcome Measurement | Statistical Method | Age at Treatment | Age at Seizure Onset | Other Study Variables
Kwan (2001) | 61 | Seizure-free or seizure reduction by more than 50% of all seizure types | Univariate | | | Bisynchronous anterior-dominant epileptiform discharges vs. posterior-dominant epileptiform discharges (NS)
Maehara (2001) | 52 | 90% reduction in frequency of disabling generalized seizures | Multiple regression | | | Total callosotomy was independently predictive of satisfactory reduction in drop attacks and disabling generalized seizures (Sig.)
Sakas (1996) | 20 | Completely free of drop attacks and generalized tonic-clonic seizures or significantly improved | Univariate | NS | Sig. Younger age of onset showed better improvement | Extent of resection (NS), Pre-operative electroencephalographic patterns (NS), Neuro-imaging finding (NS)
Spencer (1988) | 22 | Seizure-free with auras | Univariate | | NS | Full scale IQ scores less than 45 were associated with poor outcome (Sig.), Hemiparetic patients vs. normal physical examine (NS)

NS Not statistically significant

Sig. Statistically significant according to the authors

Evidence Table 171. Studies of corpus callosotomy reporting individual patient age at surgery

| | | | 95% Confidence Interval
Reference | Number of Patients | Seizure Outcome Measurement | Point-Biserial Correlation^a^ | Lower | Upper | Standardized Residuals for Effect Sizes
Claverie (1995) | 15 | 90% reduction in seizure frequency | -0.18 | -0.63 | 0.37 | -1.19
Nordgren (1991) | 18 | 80% reduction in seizure frequency | 0.17 | -0.32 | 0.59 | 0.13
Marino (1990) | 28 | 90% reduction in seizure frequency | 0.20 | -0.18 | 0.54 | 0.38
Murro (1988) | 13 | 90% reduction in seizure frequency | -0.22 | -0.69 | 0.38 | -1.21
Purves (1988) | 24 | 80% reduction in frequency and severity of all seizure types | 0.15 | -0.27 | 0.52 | 0.07
Spencer (1988) | 22 | Seizure-free with auras | 0.39 | -0.04 | 0.69 | 1.29

a A positive correlation coefficient indicates more successful surgeries with an older age at surgery.

Evidence Table 172. Sensitivity analysis of studies of corpus callosotomy reporting individual patient age at surgery

| | 95% Confidence Interval
Sensitivity Adjustment | Point-Biserial Correlation^ a^ | Lower | Upper | p Value for Summary Estimate | Q | p Value for Q
Original analysis | 0.14 | -0.05 | 0.32 | 0.16 | 4.05 | 0.54
Removing study with largest negative effect size^ b^ | 0.18 | -0.03 | 0.37 | 0.09 | 2.59 | 0.63
Removing study with largest positive effect size | 0.13 | -0.08 | 0.33 | 0.21 | 4.03 | 0.40
Removing study with smallest N | 0.18 | -0.03 | 0.37 | 0.09 | 2.59 | 0.63
Removing study with largest N | 0.14 | -0.08 | 0.34 | 0.22 | 4.04 | 0.40

a A positive correlation coefficient indicates more successful surgeries with an older age at surgery.

b The study with the largest negative effect size had the smallest N

Evidence Table 173. Studies of corpus callosotomy reporting individual patient age at seizure onset

| | | | 95% Confidence Interval
Reference | Number of Patients | Seizure Outcome Measurement | Point-Biserial Correlation^ a^ | Lower | Upper | Standardized Residuals for Effect Sizes
Nordgren (1991) | 18 | 80% reduction in seizure frequency | 0.26 | -0.24 | 0.65 | 0.95
Marino (1990) | 28 | 90% reduction in seizure frequency | -0.17 | -0.51 | 0.22 | -1.23
Murro (1988) | 13 | 90% reduction in seizure frequency | 0.18 | -0.42 | 0.66 | 0.46
Purves (1988) | 24 | 80% reduction in frequency and severity of all seizure types | 0.16 | -0.26 | 0.53 | 0.63
Spencer (1988) | 22 | Seizure-free with auras | -0.07 | -0.48 | 0.36 | -0.53

a A positive correlation coefficient indicates more successful surgeries with an older age at seizure onset.

Evidence Table 174. Sensitivity analysis of studies of corpus callosotomy reporting individual patient age at seizure onset

| | 95% Confidence Interval
Sensitivity Adjustment | Point-Biserial Correlation^ a^ | Lower | Upper | p Value for Summary Estimate | Q | p Value for Q
Original analysis | 0.04 | -0.16 | 0.24 | 0.70 | 2.55 | 0.64
Removing study with largest negative effect size^ b^ | 0.12 | -0.12 | 0.35 | 0.33 | 1.05 | 0.79
Removing study with largest positive effect size | 0.00 | -0.23 | 0.22 | 0.97 | 1.65 | 0.65
Removing study with smallest N | 0.02 | -0.19 | 0.24 | 0.83 | 2.34 | 0.51
Removing study with largest N | 0.12 | -0.12 | 0.35 | 0.33 | 1.05 | 0.79

a A positive correlation coefficient indicates more successful surgeries with an older age at seizure onset.

b The study with the largest negative effect size also had the largest N.

Evidence Table 175. Studies of corpus callosotomy reporting individual patient duration of epilepsy prior to surgery

| | | | 95% Confidence Interval
Reference | Number of Patients | Seizure Outcome Measurement | Point-Biserial Correlation ^a^ | Lower | Upper | Standardized Residuals for Effect Sizes
Nordgren (1991) | 18 | 80% reduction in seizure frequency | -0.14 | -0.57 | 0.35 | -1.25
Marino (1990) | 28 | 90% reduction in seizure frequency | 0.36 | -0.01 | 0.65 | 1.35
Murro (1988) | 13 | 90% reduction in seizure frequency | -0.28 | -0.72 | 0.32 | -1.49
Purves (1988) | 24 | 80% reduction in frequency and severity of all seizure types | 0.06 | -0.36 | 0.45 | -0.51
Spencer (1988) | 22 | Seizure-free with auras | 0.40 | -0.02 | 0.70 | 1.34

a A positive correlation coefficient indicates more successful surgeries with a longer duration of epilepsy prior to surgery.

Evidence Table 176. Sensitivity analysis of studies of corpus callosotomy reporting individual patient duration of epilepsy prior to surgery

| | 95% Confidence Interval
Sensitivity Adjustment | Point-Biserial Correlation ^a^ | Lower | Upper | p Value for Summary Estimate | Q | p Value for Q
Original analysis | 0.15 | -0.05 | 0.34 | 0.15 | 6.21 | 0.18
Removing study with largest negative effect size ^b^ | 0.21 | -0.01 | 0.40 | 0.06 | 3.98 | 0.26
Removing study with largest positive effect size | 0.08 | -0.15 | 0.30 | 0.50 | 4.41 | 0.22
Removing study with smallest N | 0.21 | -0.01 | 0.40 | 0.06 | 3.98 | 0.26
Removing study with largest N | 0.06 | -0.18 | 0.30 | 0.60 | 4.40 | 0.22

a A positive correlation coefficient indicates more successful surgeries with a longer duration of epilepsy prior to surgery.

b The study with the largest negative effect size also had the smallest N.

Evidence Table 177. Studies of corpus callosotomy reporting patients who were free of their most disabling seizures

Reference | N | Type of Seizures Evaluated | Followup Period in Years | Minimum Followup | Maximum Followup | Number of Patients Free of Disabling Seizures | Percentage | Cohen's h Effect Size | 95% Confidence Interval
Matsuzaka (1999) | 22 | Most disabling seizures | 4.8 | 2.1 | 8.4 | 4 | 18.2 | 0.88 | 0.210-1.47
McInerney (1999) | 43 | Most disabling seizures | 12.3 | 2 | 27 | 13 | 30.2 | 1.16 | 0.710-1.59
Sakas (1996) | 20 | Drop attacks and generalized tonic-clonic seizures | 6.7 | 2 | | 4 | 20.0 | 0.93 | 0.310-1.55
Marino (1990) | 23 | Drop attacks and generalized tonic-clonic seizures | 8.7 | 4 | 11 | 7 | 30.4 | 1.17 | 0.510-1.75
Murro (1988) | 13 | Tonic, Atonic, Tonic-clonic, Complex partial | 3.1 | 2.3 | 5.6 | 1 | 7.7 | 0.56 | -0.101-1.33
Spencer (1988) | 22 | Tonic, Atonic, Tonic-clonic, Complex partial | | 2 | | 9 | 40.9 | 1.39 | 0.810-1.98
Gates (1987) | 22 | Tonic, Atonic, Tonic-clonic, Complex partial | 3.7 | 2.1 | 6.6 | 6 | 27.3 | 1.10 | 0.510-1.69

Evidence Table 178. Studies of corpus callosotomy reportinh patients who were free of generalized tonic-clonic seizures

| | | | | Patients with Generalized Tonic-Clonic Seizures
Reference | N | Followup Period in Years | Minimum Followup | Maximum Followup | N | Free | %Free | Cohen's h Effect Sizes | 85% Confidence Interval | p Values for Effect Sizes | Standardized Residuals for Effect Sizes
Kwan (2001) | 61 | | 2 | | 23 | 3 | 13.0 | 0.74 | 0.16–1.32 | 0.012206 | -2.04
Maehara (2001) | 52 | 3.3 | 2 | 6.8 | 16 | 2 | 12.5 | 0.72 | 0.03–1.42 | 0.040834 | -1.71
McInerney (1999) | 43 | 12.3 | 2 | 27 | 35 | 10 | 28.6 | 1.13 | 0.66–1.60 | 0.000002 | -0.80
Sakas (1996) | 20 | 6.7 | | | 18 | 6 | 33.3 | 1.23 | 0.58–1.88 | 0.000222 | -0.21
Marino (1990) | 28 | 8.7 | 4 | 11 | 21 | 11 | 52.4 | 1.62 | 1.01–2.22 | <0.000001 | 1.12
Murro (1988) | 13 | 3.1 | 2.3 | 5.6 | 10 | 1 | 10.0 | 0.64 | -0.23–1.52 | 0.150175 | -1.51
Spencer (1988) | 22 | | 2 | | 21 | 16 | 76.2 | 2.12 | 1.52–2.73 | <0.000001 | 2.87
Gates (1987) | 22 | 3.7 | 2.1 | 6.6 | 15 | 11 | 73.3 | 2.06 | 1.34–2.77 | <0.000001 | 2.19

Evidence Table 179. Studies of corpus callosotomy reporting patients who were free of generalized tonic-clonic seizures - data used in meta-regression

Reference | Number of Patients | Cohen's h Effect Size | Weight | Year Study Started | Year Study Ended | Conducted in the United States | Mean Age at Surgery
Kwan (2001) | 61 | 0.74 | 11.50 | 1989 | 1996 | No | 7.9
Maehara (2001) | 52 | 0.72 | 8.00 | 1991 | 1998 | No | 18
McInerney (1999) | 43 | 1.13 | 17.50 | 1972 | 1999 | Yes | 13.6
Sakas (1996) | 20 | 1.23 | 9.00 | 1984 | 1993 | No | 25.7
Marino (1990) | 28 | 1.62 | 10.50 | 1978 | 1985 | No | 21.4
Murro (1988) | 13 | 0.64 | 5.00 | 1980 | 1986 | Yes | 25.8
Spencer (1988) | 22 | 2.12 | 10.50 | 1979 | 1983 | Yes | 20.5
Gates (1987) | 22 | 2.06 | 7.50 | 1979 | 1985 | Yes | 19

Evidence table 180. Results of the meta-regression for studies of corpus callosotomy reporting patients who were free of generalized tonic-clonic seizures after surgery

One predictor variables Bolded = statistically significant coefficient
Covariate | Intercept (CI) | P (intercept) = | Coefficient (CI) | P (coefficient) | Q_e_= | P (Q_e_) =
Start year (centered) | 1.265 (1.043 to 1.487) | <0.000001 | -0.033 (-0.068 to 0.0009) | 0.055932 | 17.7957 | 0.006764
End year (centered) | 1.359 (1.136 to 1.582) | <0.000001 | -0.060 (-0.094 to -0.026) | 0.000563 | 9.554118 | 0.144729
United States (USA = 0) | 1.497 (1.189 to 1.805) | <0.000001 | -0.411 (-0.85 to 0.027) | 0.066393 | 18.07976 | 0.006036
Age at treatment (centered) | 1.335 (1.111 to 1.560) | <0.000001 | 0.034 (-0.004 to 0.072) | 0.085921 | 18.50058 | 0.005096
Lennox-Gastaut (all others = 0) | 1.389 (1.152 to 1.627) | <0.000001 | -0.650 (-1.275 to -0.02) | 0.041219 | 17.28277 | 0.008298
Percentage male (centered) | 1.269 (1.047 to 1.491) | <0.000001 | 0.029 (-0.006 to 0.065) | 0.104512 | 18.81447 | 0.004489

Average N = 19.88

Average start year: 1981.5

Average end year: 1990.63

Average age at treatment: 18.987

Average percentage male: 68.106

Evidence Table 180-A. Results of the meta-regression for studies of corpus callosotomy reporting patients who were free of generalized tonic-clonic seizures after surgery (continued)

Two predictor variables
Covariate: B_1_ | Covariate: B_2_ | Intercept (95% CI's) | P (intercept) = | Coefficient B_1_ (95% CI's) | P (B_1_) = | Coefficient B_2_ (95% CI's) | P(B_2_) | Q_e_= | P (Q_e_) =
End year (centered) | Start year (centered) | 1.332 (1.106 to 1.557) | <0.001 | -0.058 (-0.092 to -0.023) | 0.001 | -0.028 (-0.063 to 0.007) | 0.112 | 7.028 | 0.219
End year (centered) | United States (USA = 0) | 1.499 (1.191 to 1.807) | <0.001 | -0.057 (-0.092 to -0.022) | 0.001 | -0.292 (-0.738 to 0.153) | 0.198 | 7.9 | 0.162
End year (centered) | Age at treatment (centered) | 1.353 (1.128 to 1.578) | <0.001 | -0.066 (-0.109 to -0.023) | 0.003 | -0.01 (-0.059 to 0.038) | 0.673 | 9.376 | 0.095
End year (centered) | Lennox-Gastaut (all others= 0) | 1.408 (1.17 to 1.646) | <0.001 | -0.055 (-0.091 to -0.019) | 0.003 | -0.374 (-1.025 to 0.276) | 0.26 | 8.283 | 0.141
End year (centered) | Percentage male (centered) | 1.338 (1.112 to 1.564) | <0.001 | -0.058 (-0.092 to -0.023) | 0.001 | 0.02 (-0.016 to 0.057) | 0.269 | 8.332 | 0.139

Evidence Table 181. Studies of corpus callosotomy reporting patients who became free of atonic seizures after surgery

| | | | | Patients with Atonic Seizures
Reference | N | Followup Period in Years | Minimum Followup | Maximum Followup | N | Free | % Free | Cohen's h Effect Sizes | 95% Confidence Interval | p Values for Effect Sizes | Standardized Residuals for Effect Sizes
Kwan (2001) | 61 | | 2 | | | 6 | 54.5 | 1.66 | 0.83–2.50 | 0.000097 | -0.35
Maehara (2001) | 52 | 3.3 | 2 | 6.8 | 52 | 42 | 80.8 | 2.23 | 1.85–2.62 | <0.000001 | 2.71
McInerney (1999) | 43 | 12.3 | 2 | 27 | 30 | 17 | 56.7 | 1.70 | 1.20–2.21 | <0.000001 | -0.44
Sakas (1996) | 20 | 6.7 | | | 13 | 7 | 53.8 | 1.65 | 0.88–2.42 | 0.000027 | -0.42
Marino (1990) | 28 | 8.7 | 4 | 11 | 18 | 9 | 50.0 | 1.57 | 0.92–2.22 | 0.000002 | -0.76
Gates (1987) | 22 | 3.7 | 2.1 | 6.6 | 22 | 8 | 36.4 | 1.29 | 0.70–1.89 | 0.000018 | -1.84

Evidence Table 182. Studies of corpus callosotomy reporting employment data

Reference | Number of Patients | Followup in Years | Number of Patients Not Able to Obtain Employment Prior to Surgery | Number of Patients Able to Obtain Employment or Begin Training After Surgery | Number of Patients With a 50% or Better Reduction in Drop Attacks and Generalized Tonic-Clonic Seizures
Sakas (1996) | 20 | 6.7 | 20 | 16 | 16

Patients in this study were between the ages of 15 and 37 years and no patients had regular employment or training prior to surgery. After surgery, 7 patients had full-time employment and 9 were in training.

Evidence Table 183. Studies of corpus callosotomy reporting changes in IQ

| | | | Baseline IQ | | IQ After Surgery
Reference | Number of Patients | Number of Patient With a Decrease in IQ | Number of Patient With an Increase in IQ | Mean | SD | Mean | SD
Cohen (1991) | 10 | 1 | 2 | 43 | 18 | 42 | 19

All patients were 18 years old or younger. The authors concluded that a majority of patients did not appear to experience any significant change in cognitive functioning.

Evidence Table 184. Patient characteristics from studies of corpus callosotomy reporting complications due to surgery

Reference | N | Pathology | Mean Age at Surgery (Years) | SD of Age at Surgery (Years) | Mean Age at Seizure Onset (Years) | SD of Age at Seizure Onset (Years) | Mean Duration of Epilepsy Before Surgery (Years) | SD of Duration Before Surgery (Years) | Males | Females | Simple Partial Seizures | Complex Partial Seizures | Secondarily Generalized Seizures | Generalized Convulsive Seizures
Hodaie (2001) | 17 | | 10.5 | | | | | | 8 | 9
Maehara (2001) | 52 | | 18 | | 5.1 | | 12.9 | | 34 | 18 | 24 | 5 | | 52
Fandino-Franky (2000) | 97 | | 14 | | | | | | 59 | 38
Pinard (1999) | 17 | West Syndrome | 6.9 | 3.5 | 0.5 | 0.3 | 6.4 | 3.5
Carmant (1998) | 28 | | 13.8 | 6.5
Sorenson (1997) | 23 | | 16.6 | | 5.5 | | 12.2 | 1.5
Andersen (1996) | 20 | | 20.8 | | | | | | 13 | 7
Rossi (1996) | 20 | | 23 | | | | 15 | | 14 | 6 | 9 | 13 | | 20
Sakas (1996) | 20 | | 25.7 | 1.4 | 8.8 | 1.4 | | | 14 | 6 | | 8 | | 20
Reutens (1993) | 64 | | 20 | | 5.2 | | 14.8 | | 38 | 26 | 14 | 20 | | 64
Fuiks (1991) | 80 | | 18.3 | | 5.3 | | | | 44 | 36 | | 9 | | 69
Nordgren (1991) | 18 | | 13.1 | 3.2 | 3.6 | 3.5 | 9.1 | 3.9 | 11 | 7 | 13 | 8 | 8 | 16
Oguni (1991) | 43 | | 23.5 | | | | 18.8 | | 20 | 23 | 5 | 8 | 24 | 43
Marino (1990) | 28 | | 21.4 | 10.1 | 6.5 | 5.7 | 14.9 | 8.2 | | | 25 | 23 | | 25
Provinciali (1990) | 15 | | 26.2 | 7.6 | | | | | 9 | 6
Sass (1990) | 32 | | 24 | 6.6 | 7.4 | 5 | 16.7 | 8.3 | 21 | 11 | | | 32
Murro (1988) | 25 | | 25.8 | 11.8 | 6.2 | 3.6 | 19.6 | 11.3 | 7 | 6 | 1 | 5 | | 10
Purves (1988) | 24 | | 25.9 | 10.9 | 6.3 | 6.8 | 19.6 | 10.2 | 12 | 12 | 8 | 19 | 5 | 12
Garcia-Flores (1987) | 14 | | 17.8 | 9 | 6.5 | 8.8 | | | | | 3 | 3 | 3 | 6
Gates (1987) | 24 | | | | | | | | 15 | 7 | 1 | 19 | 22 | 22

Evidence Table 185. Studies of corpus callosotomy reporting complications - list of complications

Reference | N | Years | Country | Number of Patients with a Serious Permanent Complication | List of Permanent Complications | Number of Patients with a Mild or Transient Complication | List of Transient Complications
Hodaie (2001) | 17 | 1992-1999 | Canada | 0 | | 2 | Wound infection (2)
Maehara (2001) | 52 | 1991-1998 | Japan | 0 | | 17 | Acute epidural hematoma without neurological deficit (1), Akinetic state (14), Marked disconnect syndrome (2)
Fandino-Franky (2000) | 97 | 1989-1997 | Colombia | 0 | | 12 | Leg weakness (10), Mutism (2)
Pinard (1999) | 17 | 1989-1995 | France | 2 | Deteriorated language (2) | 0
Carmant (1998) | 28 | 1989-1993 | United States | 0 | | 3 | Acute disconnection problems (3)
Sorenson (1997) | 23 | 1991-1994 | United States | 1 | Right frontal infarction related to venous thrombosis (1) | 13 | Complications were not identified per patient. Meningitis (3), Diabetes insipidus (1), Postoperative disconnection syndrome (13)
Andersen (1996) | 20 | 1988-1994 | Denmark | 7 | Seven patients had persistent interhemispheric disconnection syndrome with the following symptoms: Mild hemiapraxia (3), Severe cognitive and neurologic sequelae (language impairment, hemisphere competition, apraxia) (4) | 5 | Interhemispheric disconnection syndrome (5)
Rossi (1996) | 20 | 1988-1995 | Italy | 1 | Mild leg weakness (1) | 12 | Mutism (8), Mild hemiparesis (2), Dysarthria (2)
Sakas (1996) | 20 | 1984-1993 | Ireland | 0 | | 7 | Hemiparesis (3), Disconnection syndrome (3), Hemiparesis and Akinetism (1)
Reutens (1993) | 64 | 1973-1991 | Australia | 4 | Hemiparesis (2), Persistent disturbance in behavior (2) | | Complications were not identified per patient. Meningitis (4), Wound infections (4), Extradural hematoma (1), Hemiparesis (13), Akinesia or mutism (20), Postoperative aggression (6), Persistent mild disconnection syndrome (1)
Fuiks (1991) | 80 | 1985-1990 | United States | 0 | | 5 | Subdural hemotoma (1), Deep wound infection (1), Left hemiparesis (1), Epidural hematoma (2)
Nordgren (1991) | 18 | 1972-1987 | United States | 1 | Hemiparesis worsened (1) | 3 | Aseptic meningitis (2), hydrocephalus and shut (1)
Oguni (1991) | 43 | 1981-1989 | Canada | 0 | | 16 | Epidural hematoma with hemiparesis (1), Cranial infection (1), Collection of blood between the galea and bone flap (1), Contralateral weakness of the leg (2), Decreased output of speech (4), Minor confusional state (3), Mild fever (2), Drowsiness (2)
Marino (1990) | 28 | 1978-1985 | Brazil | 1 | Hemiplegia (1) | 1 | Meningitis (1)
Provinciali (1990) | 15 | 1987-1988 | Italy | 0 | | 8 | Broncho-pneumonia (1), Meningitis (1), Deficit in naming objects held in the left hand (1), Hemiparesis (1), Arachnoiditis (1), Apraxia and/or slight paresis of left arm (3)
Sass (1990) | 32 | 1985-1987 | United States | 4 | Clinically significant language impairments (4) | 1 | Venous hemorrhagic infarction (1)
Murro (1988) | 25 | 1980-1986 | United States | 0 | | 6 | Intracranial hemorrhage (2), Wound infection (2), Bone flap infection (1), Mild hemiparesis (1)
Purves (1988) | 24 | 1977-1987 | Canada | 0 | | 11 | Reduced speech output and left hemiparesis (7), Subdural hematoma (2), Meningitis and abscess (1), Diabetes insipidus (1)
Garcia-Flores (1987) | 14 | 1980-1986 | Mexico | 0 | | 1 | Hemiparesis (1)
Gates (1987) | 24 | 1979-1985 | United States | 3 | Stuttering disorders (2), Lower extremity weakness resulting from cerebral infarction (1) | 4 | Hematomas (2), Steroid-dependent cerebral edema (1), Bone flap infection (1)

Evidence Table 186. Patient characteristics from studies of frontal lobe surgery reporting seizure outcome measurements

Reference | N | Pathology | Mean Age at Surgery (Years) | SD of Age at Surgery (Years) | Mean Age at Seizure Onset (Years) | SD of Age at Seizure Onset (Years) | Mean Duration of Epliepsy Before Surgery (Years) | SD of Epilepsy Before Surgery (Years) | Right Side Surgery | Left Side Surgery | Males | Females | Complex Partial Seizures | Secondarily Generalized Seizures | Generalized Convulsive Seizures
Ferrier (2001) | 35 | | 17.3 | 8.5 | 6.2 | 4.1 | 11.1 | 7.2
Siegel (2001) | 14 | Various | 31.3 | | 12.2 | | 19.2
Hong (2000) | 18 | Cortical dysplasia | 18.3 | 9.8 | 5.6 | 4.1 | 12.6 | 7.4 | 3 | 8 | 7 | 4
Eriksson (1999) | 12 | Various | 34 | | 14 | | 18 | Adults | | 6 | 6
| 13 | Various | 9.9 | | 1.5 | | 5.5 | Children | | 6 | 7
Wennberg (1999) | 22 | Foreign tissue lesion | 23.2 | 12.8 | | | | | 10 | 9
Swartz (1998) | 19 | Various | 31.2 | 12.3 | 17.8 | 13.3 | 13.5 | 9.7 | 6 | 7
Cappabianca (1997) | 13 | | 28.8
Smith (1997) | 53 | Various
Acciarri (1995) | 13 | Vascular malformation | 31.7 | 14.4 | 27.7 | 10.2 | 4 | 5 | 3 | 8 | 7 | 4 | 1 | 2 | 8
Adler (1991) | 14 | Various | 12.2 | | 3 | | 7.8 | 11 | 3 | 8 | 6
Garcia Sola (1991) | 18 | Various | 18.7
Palmini (1991) | 12 | Neuronal migration disorder | 17.5 | | | | 11.9
Rasmussen (1991) | 283 | Non-tumoral lesion

Evidence Table 187. Studies of frontal lobe surgery reporting seizure-free undefined

Reference | N | Followup Period in Years | Minimum Followup | Maximum Followup | Patients Seizure Free Undefined | Percentage | Cohen's h Effect Sizes | 95% Confidence Interval | p Values for Effect Sizes | Standardized Residualsfor Effect Sizes
Ferrier (2001) | 35 | 6 | 2 | 19.5 | 21 | 60.0 | 1.77 | 1.30–2.24 | <0.000001 | 2.26
Cappabianca (1997) | 13 | | 2 | | 11 | 84.6 | 2.34 | 1.57–3.10 | <0.000001 | 2.80
Smith (1997) | 24 | | 2 | | 15 | 62.5 | 1.82 | 1.26–2.39 | <0.000001 | 2.03
Acciarri (1995) | 11 | 6.7 | 2 | 13 | 11 | 100.0 | 3.14 | 2.31–3.98 | <0.000001 | 4.48
Garcia Sola (1991) | 18 | 9 | 5 | 12.5 | 6 | 13.3 | 1.23 | 0.58–1.88 | 0.000222 | -0.08
Rasmussen (1991) | 283 | 16 | 2 | 49 | 68 | 24.0 | 1.02 | 0.86–1.19 | <0.000001 | -5.40

Evidence Table 188. Studies of frontal lobe surgery reporting patients who were seizure-free undefined - data used in meta-regression

Reference | N | Cohen's h Effect Size | Weight | Year Study Started | Year Study Ended | Conducted in the United States | Vascular Malformation Patients Only
Ferrier (2001) | 35 | 1.77 | 17.5 | 1975 | 1996 | No | No
Cappabianca (1997) | 13 | 2.34 | 6.5 | 1985 | 1994 | No | No
Smith (1997) | 24 | 1.82 | 12 | 1995 | 1997 | Yes | No
Acciarri (1995) | 11 | 3.14 | 5.5 | 1975 | 1992 | No | Yes
Garcia Sola (1991) | 18 | 1.23 | 9 | 1978 | 1990 | No | No
Rasmussen (1991) | 283 | 1.02 | 141.5 | 1928 | 1980 | No | No

Evidence Table 189. Results of the meta-regression for studies of frontal lobe surgery reporting patients who were seizure-free undefined

One predictor variable Bolded = statistically significant coefficient
Covariate | Intercept (CI) | P (intercept) = | Coefficient (CI) | P (coefficient) | Q_e_ = | P (Q_e_) =
Start year (centered) | 1.743 (1.514 to 1.973) | <0.000001 | 0.015 (0.010 to 0.0218) | <0.000001 | 15.33792 | 0.004049
End year (centered) | 1.711 (1.492 to 1.930) | <0.000001 | 0.059 (0.037 to 0.080) | <0.000001 | 14.93439 | 0.004839
United States (USA = 0) | 1.823 (1.257 to 2.389) | <0.000001 | -0.603 (-1.188 to -0.019) | 0.042828 | 39.13536 | <0.000001
Tumor (all others=0) | 3.141 (2.305 to 3.977) | <0.000001 | -1.939 (-2.787 to -1.091) | 0.000007 | 23.13496 | 0.000119

Average N = 64

Average year started = 1972.67

Average year ended = 1991.5

Evidence Table 189-A. Results of the meta-regression for studies of frontal lobe surgery reporting patients who were seizure-free undefined

Tow predictor variables
Covariate: B_1_ | Covariate: B_2_ | Intercept (CI) | P (intercept) | Coefficient B_1_ (CI) | P (B1) = | Coefficient B_2_ (CI) | P(B_2_) | Q_e_ = | P (Q_e_) =
Start year (centered) | End year (centered) | 1.726 (1.492 to 1.961) | <0.001 | 0.005 (-0.024 to 0.035) | 0.725 | 0.04 (-0.068 to 0.148) | 0.468 | 14.81 | 0.002
Start year (centered) | United States (USA = 0) | 1.412 (0.824 to 2) | <0.001 | 0.018 (0.011 to 0.026) | <0.001 | 0.436 (-0.275 to 1.147) | 0.23 | 13.894 | 0.003
Start year (centered) | Tumor (all others=0) | 3.11 (2.274 to 3.946) | <0.001 | 0.013 (0.007 to 0.02) | <0.001 | -1.483 (-2.356 to -0.611) | 0.001 | 4.239 | 0.237
End year (centered) | USA (USA = 0) | 1.466 (0.883 to 2.049) | <0.001 | 0.065 (0.04 to 0.091) | <0.001 | 0.312 (-0.374 to 0.998) | 0.373 | 14.14 | 0.003
End year (centered) | Tumor (all others=0) | 3.116 (2.28 to 3.952) | <0.001 | 0.051 (0.028 to 0.073) | <0.001 | -1.513 (-2.381 to -0.644) | 0.001 | 3.278 | 0.351
United States (USA = 0) | Tumor (all others=0) | 3.806 (2.786 to 4.826) | <0.001 | -0.664 (-1.249 to -0.079) | 0.026 | -1.983 (-2.831 to -1.134) | <0.001 | 18.178 | <0.001

Average N = 64

Average year started = 1972.67

Average year ended = 1991.5

Evidence Table 190. Studies of frontal lobe surgery reporting patients with seizure-free outcomes

Reference | Number of Patients | Followup Period in Years | Minimum Followup | Maximum Followup | Seizure Free Outcome | Number of Patients with Outcome | Percentage
Siegel (2001) | 14 | | 2 | | Engel Class I | 8 | 57.1
Hong (2000) | 11 | 3.5 | 2.1 | 4.7 | Engel Class I | 6 | 54.5
Eriksson (1999) | 12 - adults | 2 | | | Seizure-free with auras | 3 | 25.0
| 13 - Children | | | | | 4 | 30.8
Wennberg (1999) | 19 | 6.5 | 2 | 17 | Engel Class I | 11 | 57.9
Swartz (1998) | 14 | 4.1 | 2 | 9 | Seizure-free with no auras | 8 | 57.1
Adler (1991) | 14 | 8.2 | 3.6 | 19 | Seizure-free with no auras | 8 | 57.1
Palmini (1991) | 12 | 5.8 | 2 | 15 | Seizure-free with auras | 2 | 16.7

Evidence Table 191. Studies of frontal lobe surgery reporting relationships between patient or study characteristics and treatment outcome

| | | | Patient or Study Characteristic Examined
Reference | N | Seizure Outcome Measurement | Statistical Method | Age at Treatment | Age at Seizure Onset | Duration of Epilepsy Prior to Treatment | Length of Followup | Other Study Variables
Ferrier (2001) | 35 | Seizure-free with auras | Univariate | | | | | Abolition of seizure patterns (Sig.), Abolition of sporadic spikes or their presence in the postsurgery electrocorticograms (NS), Location of residual sporadic discharges (NS), Incomplete removal of abnormal tissue (NS)
Smith (1997) | 53 | Seizure-free (undefined) | Univariate | NS | NS | NS | NS | Seizure frequency (NS), Completeness of lesion resection (NS), Lesional cases had better outcomes than nonlesional cases (Sig.)

Sig. Statistically Significant

NS Not statistically significant

Evidence Table 192. Patient characteristics from studies of frontal lobe surgery reporting complications due to surgery

Reference | N | Pathology | Mean Age at Surgery (Years) | SD of Age at Surgery (Years) | Mean Age at Seizure Onset (Years) | SD of Age at Seizure Onset (Years) | Mean Duration of Epilepsy Before Surgery (Years) | SD of Duration of Epilepsy Before Surgery (Years) | Right Side Surgery | Left Side Surgery | Males | Females | Complex Partial Seizures | Secondarily Generalized Seizures | Generalized Convulsive Seizures
Kral (2001) | 32 | Various | 10.8 | | 4.6 | | 6.1 | | | | 22 | 10 | 20 | 12 | 4
Mosewich (2000) | 68 | | 28.5 | 12.4 | 12.1 | 9.9 | 16.5 | 10.6 | 39 | 29 | 45 | 23
Chassoux (1999) | 120 | Various | 21 | 8.2 | 9.2 | 7.3 | 11.9 | 7.3 | 75 | 44 | 77 | 43 | | | 79
Ferrier (1999) | 42 | Various | 16.8 | 10.4 | 6.1 | 5.2 | 10.6 | 7.9 | | | 18 | 19 | | 16
Helmstaedter (1998) | 33 | Various | 29.8 | 10 | 15 | 11 | 15.2 | 9 | 16 | 17 | 21 | 12
Swartz (1998) | 19 | Various | 31.3 | 12.3 | 17.8 | 13.3 | 13.5 | 9.7 | 6 | 7
Smith (1997) | 53 | Various
Acciarri (1995) | 13 | Vascular malformation | 31.7 | 14.4 | 27.7 | 10.2 | 4 | 5 | 3 | 8 | 7 | 4 | 1 | 2 | 8

Evidence Table 193. Studies of frontal lobe surgery reporting complications - list of complications

Reference | N | Years | Number of Patients with a Serious Permanent Complication | List of Permanent Complications | Number of Patients with a Mild or Transient Complication | List of Transient Complications
Kral (2001) | 32 | 1989-2000 | 0 | | | Complications were not identified per patient. Meningitis (1), Wound infection (2), Subdural hygroma (1), Weakness of the contralateral hand (3), Hemiparesis (1)
Mosewich (2000) | 68 | 1987-1994 | 0 | | 3 | Mild to moderate hemiparesis (2), Mild hemiparesis and expressive dyphasia (1)
Chassoux (1999) | 120 | 1964-1995 | 27 | One year or more after surgery: Spastic hemiparesis or pronounced worsening of the preoperative deficit (27) | 72 | Minor motor deficit or a worsening of the preoperative motor deficit (19), Isolated facial paresis (6), Motor inertia (5), Hemiparesis or hemiplegia (42)
Ferrier (1999) | 37 | 1975-1996 | 0 | | 19 | Complications were not identified per patient, but 18 of 37 patients had no postoperative complications. Hemiparesis (8), Mild dysphasia (2), Bone flap infection (8), CSF leak (1), Buzzing sensation in the left ear (1), Monoplegia with mild weakness (1)
Helmstaedter (1998) | 33 | 1995-1996 | 0 | | 14 | Motor aphasia and paresis (3), transcortical aphasia and paresis (4), Cortical dysarthria (2) Severe psychomotor slowing (3), Anosmia (1)
Swartz (1998) | 15 | 1986-1995 | 0 | | 6 | Decreased verbal fluency (2), Incontinence (1), Abulia (2), Monoparesis (1)
Smith (1997) | 53 | | 4 | Disabling hemipareses (2), Diabetes insipidus (1), Steroid-induced diabetes mellitus (1) | 6 | Osteomyelitis (1), Epidural hematoma (1), Hemiparesis (1), Aphasia (1), Aspiration pneumonitis (1), Mild dysnomia (1)
Acciarri (1995) | 11 | 1975-1992 | 0 | | 0

Evidence Table 194. Patient characteristics from studies of frontal lobe surgery reporting surgery related mortality

Reference | N | Pathology | Mean Age at Surgery (Years) | SD of Age at Surgery (Years) | Mean Age at Seizure Onset (Years) | SD of Age at Seizure Onset (Years) | Mean Duration of Epilepsy Before Surgery (Years) | SD of Duration of Epilepsy Before Surgery (Years) | Right Side Surgery | Left Side Surgery | Males | Females | Complex Partial Seizures | Secondarily Generalized Seizures | Generalized Convulsive Seizures
Kral (2001) | 32 | Mixed | 10.8 | | 4.6 | | 6.1 | | | | 22 | 10 | 20 | 12 | 4
Smith (1997) | 53 | Mixed
Acciarri (1995) | 13 | Vascular malformation | 31.7 | 14.4 | 27.7 | 10.2 | 4 | 5 | 3 | 8 | 7 | 4 | 1 | 2 | 8

Evidence Table 195. Patient characteristics from studies of hemispherectomy reporting seizure-free outcome measurements

Reference | N | Years | Country | Mean Age at Surgery (Years) | SD of Age at Surgery (Years) | Mean Age at Seizure Onset (Years) | SD of Age at Seizure Onset (Years) | Mean Duration of Epilepsy Before Surgery (Years) | SD of Duration of Epilepsy Before Surgery (Years) | Right Side Surgery | Left Side Surgery | Males | Females | Complex Partial Seizures | Secondarily Generalized Seizures | Generalized Convulsive Seizures
Di Rocco (2000) | 15 | 1985-1996 | Italy | 2.4 | 2.8 | | | | | 9 | 6 | 11 | 4
Tinuper (1988) | 14 | 1974-1987 | Canada | 14.5 | 10.2 | 4.7 | 5.6 | 9.8 | 9.5 | 6 | 8
Lindsay (1987) | 17 | 1948-1986 | England | 12 | 2.9 | 5.1 | 2.4 | 7 | 2 | 8 | 7 | 7 | 8

Evidence Table 196. Studies of hemispherectomy reporting seizure outcome measurements

Reference | N | Followup Period in Years | Minimum Followup | Maximum Followup | Seizure-free With No Auras | Percentage | Seizure Free (Undefined) | Percentage | Followup Period in Years | Minimum Followup | Maximum Followup | Engel Class I | Percentage | Engel Class IV | Percentage
Di Rocco (2000) | 15 | 5.5 | 3.5 | 14 | 6 | 40.0 | --- | --- | 5.5 | 3.5 | 14 | 10 | 66.7 | 1 | 6.7
Tinuper (1988) | 14 | 6.9 | 4 | 13 | --- | --- | 10 | 71.4 | 6.9 | 4 | 13 | --- | --- | --- | ---
Lindsay (1987) | 15 | 14.1 | 2 | 36 | --- | --- | 9 | 60.0 | 14.1 | 2 | 36 | 11 | 73.3 | 1 | 6.7

Evidence Table 197. Studies of hemispherectomy reporting education data

Reference | N | Mean Followup in Years | Minimum Followup | Maximum Followup | Number of Patients Going to School Prior to Surgery | Number of Patients Able to Remain at School or Obtain Employment After Surgery
Lindsay (1987) | 15 | 14.1 | 2 | 36 | 1 | 8

Evidence Table 198. Studies of hemispherectomy reporting changes in IQ

| | | | | | | Baseline IQ | | IQ After Surgery
Reference | N | Mean Followup in Years | Minimum Followup | Maximum Followup | Number of Patients with a Decrease in IQ | Number of Patients with an Increase in IQ | Mean | SD | Mean | SD
Lindsay (1987) | 15 | 14.1 | 2 | 36 | 2 | 6 | 59 | 14 | 66 | Not reported

Evidence Table 199. Patient characteristics from studies of hemispherectomy reporting complications

Reference | N | Mean Age at Surgery (Years) | SD of Age at Surgery (Years) | Mean Age at Seizure Onset (Years) | SD of Age at Seizure Onset (Years) | Mean Duration of Epilepsy Before Surgery (Years) | SD of Duration of Epilepsy Before Surgery (Years) | Right Side Surgery | Left Side Surgery | Males | Females | Complex Partial Seizures | Secondarily Generalized Seizures | Generalized Convulsive Seizures
Carreno (2001) | 13
Schramm (2001) | 20 | 14.3 | 12.4 | 3.3 | 3.8 | 10.5 | 10.9 | | | 11 | 9
Di Rocco (2000) | 15 | 2.4 | 2.8 | | | | | 9 | 6 | 11 | 4
Shimizu (2000) | 34 | 6.9 | | 5.5 | | 5.5 | | | | 21 | 13
Battaglia (1999) | 10 | 1.7 | 1.7 | | | | | | | 7 | 3 | 9 | 3 | 4
Wyllie (1998) | 16 | | | 1.5
Vining (1997) | 58 | 6.8 | | | | | | 32 | 26 | 18 | 40
Peacock (1996) | 58 | 4.8 | | 0.8 | | 3.9 | | 25 | 33 | 31 | 27
Schramm (1995) | 13 | 12 | | 3.7 | | 9 | | | | 11 | 2
Tinuper (1988) | 14 | 14.5 | 10.2 | 4.7 | 5.6 | 9.8 | 9.5 | 6 | 8
Lindsay (1987) | 17 | 12 | 2.9 | 5.1 | 2.4 | 7 | 2 | 8 | 7 | 7 | 8

Evidence Table 200. Studies of hemispherectomy reporting complications - list of complications

Reference | N | Years | Country | Number of Patients with a Serious Permanent Complication | List of Permanent Complications | Number of Patients with a Mild or Transient Complication | List of Transient Complications
Carreno (2001) | 13 | 1992-1999 | United States | 0 | | 4 | Bone flap infection (1), Placement of shunt for hydrocephalus (3)
Schramm (2001) | 20 | 1991-1999 | Germany | 0 | | 3 | Subgaleal cerebrospinal fluid effusion (1), Meningitis (1), Deep infection (1)
Di Rocco (2000) | 15 | 1985-1996 | Italy | 0 | | 12 | Five patients had more than one complication. Fever (6), Skin infection (2), Osteomyelitis and meningitis (1), Hemiparesis (2), Dystonia (2), Unilateral third cranial nerve deficit (1), Anemia (1), Hydrocephalus requiring a CSF shunt (5), Subdural hematoma (1)
Shimizu (2000) | 34 | 1993-1999 | Japan | 1 | Severe disability due to bilateral brain swelling (1) | 5 | Placement of shunts to treat CSF accumulation or hydrocephalus (5)
Battaglia (1999) | 10 | 1987-1998 | Italy | 0 | | 5 | Hydrocephalus (3), Subdural hematoma (1), Hyperthermia (1)
Wyllie (1998) | 16 | 1990-1996 | United States | 0 | | 2 | Deep vein thrombosis with secondary staphylococcus infection (1), Contralateral subdural hematoma (1)
Vining (1997) | 58 | 1968-1996 | United States | 1 | Coma (1) | | Complications were not identified per patient. Severe intraoperative bleeding (8), Shunts (16), Septic meningitis (2), Bone infection (1), Deep venous thrombosis in the leg (2)
Peacock (1996) | 58 | 1986-1995 | United States | 0 | | 6 | 3 of 27 patients receiving a functional hemispherectomy developed hydrocephalus requiring a shunt (3), Mild cerebrospinal fluid infections treated with antibiotics (3)
Schramm (1995) | 13 | 1992-1994 | Germany | 0 | | 2 | Placement of a shunt (1), Subgaleal cerebrospinal fluid effusion (1)
Tinuper (1988) | 14 | 1974-1987 | Canada | 0 | | 2 | Hydrocephalus corrected with a shunt (1), Abscess in the removal cavity treated with antibiotics (1)

Evidence Table 201. Patient characteristics in studies of multiple subpial transection

Reference | N | Pathology | Mean Age at Surgery (Years) | SD of Age at Surgery (Years) | Mean Age at Seizure Onset (Years) | SD of Age at Seizure Onset (Years) | Mean Duration of Epilepsy Before Surgery (Years) | SD of Duration of Epilepsy Before Surgery (Years) | Males | Females | Simple Partial Seizures | Complex Partial Seizures | Secondarily Generalized Seizures | Generalized Convulsive Seizures
Mulligan (2001) | 12 | | 29.4 | | 12.5 | | 13.8 | | 4 | 8
Orbach (2001) | 54
Shimizu (2000) | 31 | | 9.3 | | | | | | 24 | 7
Smith (1998) | 84
Hufnagel (1997) | 22 | | 25.7 | 10.4 | 8.7 | 8.4 | 17 | 9.8 | 12 | 10 | 8 | 14 | | 16
Pacia (1997) | 21 | Various | 30.6 | 8.8 | | | | | 13 | 8
Patil (1997) | 19 | | 21.7 | 14.1 | 8.3 | 6.9 | 13.3 | 9.4 | 6 | 13 | | 14 | 16
Morrell (1995) | 14 | Landau-Kleffner syndrome | 7 | 2.2 | 3.8 | 1.1 | 3.2 | 1.4 | 4 | 10
Sawhney (1995) | 21 | | 16 | 9.4 | 7 | 4.3 | 9 | 9.3 | 5 | 16
Shimizu (1991) | 12 | | 29 | | | | | | 9 | 3

Evidence Table 202. Studies of multiple subpial transection reporting seizure frequency outcomes

Reference | N | Followup Period in Years | Minimum Followup | Maximum Followup | Seizure-free Outcome | Number of Patients with Outcome | Percentage
Mulligan (2001) | 12 | 1.5 | 0.5 | 3 | Seizure-free (undefined) | 0 | 0.0
| | | | | 90% reduction in seizure frequency | 3 | 25.0
Orbach (2001) | 54 | 4.7 | 2.3 | 7.4 | Seizure-free with auras | 20 | 37.0
| | | | | Engel Class I | 20 | 37.0
| | | | | 90% reduction in seizure frequency | 20 | 37.0
Shimizu (2000) | 25 | | 1 | | Engel Class I | 5 | 20.0
Smith (1998) | 84 | | 2 | | Engel Class I | 42 | 50.0
Hufnagel (1997) | 22 | 1.5 | 0.7 | 3.1 | Seizure-free with auras | 9 | 40.9
| | | | | 90% reduction in seizure frequency | 15 | 68.2
Pacia (1997) | 21 | 1.8 | 1 | 2.8 | Seizure-free with auras | 12 | 57.1
| | | | | Engel Class I | 12 | 57.1
Patil (1997) | 19 | 2.6 | 1.3 | 4.5 | Seizure-free (undefined) | 5 | 26.3
| | | | | 90% reduction in seizure frequency | 17 | 89.5
Morrell (1995) | 14 | 3.7 | 1.1 | 6.5 | Seizure-free (undefined) | 11 | 78.6
Sawhney (1995) | 21 | 2.9 | 0.8 | 5 | Seizure-free (undefined) | 0 | 0.0

Evidence Table 203. Studies of multiple subpial transection reporting individual patient age at surgery

| | | | 95% Confidence Intervals
Reference | Number of Patients | Seizure Outcome Measurement | Point-Biserial Correlation^a^ | Lower | Upper | Standardized Residuals for Effect Sizes
Hufnagel (1997) | 22 | Seizure-free (undefined) | -0.18 | -0.56 | 0.26 | -1.63
Pacia (1997) | 21 | Seizure-free (undefined) | 0.16 | -0.29 | 0.55 | 0.08
Patil (1997) | 19 | Seizure-free (undefined) | 0.20 | -0.28 | 0.60 | 0.26
Morrell (1995) | 14 | Seizure-free (undefined) | 0.17 | -0.40 | 0.64 | 0.09
Sawhney (1995) | 21 | Improved | 0.38 | -0.06 | 0.70 | 1.25

a A positive correlation coefficient indicates more successful surgeries with an older age at surgery.

Evidence Table 204. Sensitivity analysis of studies of multiple subpial transection reporting individual patient age at surgery

| | 95% Confidence Interval
Sensitivity Adjustment | Point-Biserial Correlation^a^ | Lower | Upper | p Value for Summary Estimate | Q | p Value for Q
Original analysis | 0.14 | -0.07 | 0.34 | 0.196 | 3.33 | 0.504
Removing study with larest negative effect size^b^ | 0.24 | -0.01 | 0.45 | 0.055 | 0.68 | 0.879
Removing study with largest positive effect size | 0.07 | -0.17 | 0.30 | 0.579 | 1.76 | 0.63
Removing study with smallest N | 0.14 | -0.09 | 0.36 | 0.243 | 3.32 | 0.344
Removing study with largest N | 0.24 | -0.01 | 0.45 | 0.055 | 0.68 | 0.879

a A positive correlation coefficient indicates more successful surgeries with an older age at surgery.

b The same study had the largest negative effect size and the largest N

Evidence Table 205. Studies of multiple subpial transection reporting successful surgery among male and female patients

| | | | | | | | 95% Confidence Intervals
Reference | N | Seizure Outcome Measurement | Number of Male Patients | Number of Male Successes | Number of Female Patients | Number of Female Successes | Cohen's h Effect Size ^a^ | Lower | Upper | p Value for the Effect Size | Standardized Residuals for Effect Sizes
Hufnagel (1997) | 22 | Seizure-free (undefined) | 12 | 5 | 10 | 4 | 0.03 | -0.81 | 0.87 | 0.936876 | -0.56
Pacia (1997) | 21 | Seizure-free (undefined) | 13 | 7 | 8 | 5 | -0.18 | -1.06 | 0.71 | 0.695827 | -1.05
Patil (1997) | 19 | Seizure-free (undefined) | 6 | 2 | 13 | 3 | 0.23 | -0.74 | 1.20 | 0.642986 | -0.02
Morrell (1995) | 14 | Seizure-free (undefined) | 4 | 4 | 10 | 7 | 1.16 | 0.00 | 2.32 | 0.050049 | 1.67
Sawhney (1995) | 21 | Improved | 5 | 4 | 16 | 10 | 0.39 | -0.61 | 1.40 | 0.445580 | 0.33

a A positive effect size favors male patients achieving more successful surgeries.

Evidence Table 206. Sensitivity analysis of studies of multiple subpial transection reporting successful surgery among male and female patients

| | 95% Confidence Interval | | | | | | 95% Confidence nterval
Sensitivity Adjustment | Cohen's h Summary Estimate ^a^ | Lower | Upper | p value for Summary Estimate | Q | p value for Q | Back-transformed Percentage Estimate ^b^ | Lower | Upper
Original analysis | 0.24 | -0.19 | 0.66 | 0.272 | 3.59 | 0.464 | 1% | -1% | 11%
Removing study with smallest effect size | 0.37 | -0.12 | 0.85 | 0.141 | 2.48 | 0.479 | 3% | 0% | 17%
Removing study with largest effect size ^c^ | 0.10 | -0.36 | 0.55 | 0.684 | 0.79 | 0.852 | 0% | -3% | 7%
Removing study with smallest N | 0.10 | -0.36 | 0.55 | 0.684 | 0.79 | 0.852 | 0% | -3% | 7%
Removing study with largest N | 0.31 | -0.18 | 0.80 | 0.219 | 3.28 | 0.350 | 2% | -1% | 15%

a A positive summary estimate favors male patients achieving more successful surgeries.

b The back-transformed percentage estimate is the difference between the percentage of malr patients who achieved successful surgery and the percentage of female patients who achieved successful surgery. A positive percentage favors male patients and a negative percentage favors female patients. A difference of 0% indicates no differences between male and female patients in achieving successful surgery.

c The same study had the largest effect size and the smallest N

Evidence Table 207. Studies of multiple subpial transection reporting no benefit ^a^

Reference | Number of Patients | Followup Period in Years | Minimum Followup | Maximum Followup | No Benefit | Percentage
Mulligan (2001) | 12 | 1.5 | 0.5 | 3 | 5 | 41.7
Hufnagel (1997) | 22 | 1.5 | 0.7 | 3.1 | 3 | 13.6
Pacia (1997) | 21 | 1.8 | 1 | 2.8 | 1 | 4.8
Patil (1997) | 19 | 2.6 | 1.3 | 4.5 | 0 | 0.0

a Patients had no change in seizure frequency or experienced an increase in seizure frequency after surgery

Evidence Table 208. Studies of multiple subpial transection reporting complications

Reference | N | Years | Country | Number of Patients with a Serious Permanent Complication | List of Permanent Complications | Number of Patients with a Mild or Transient Complication | List of Transient Complications
Mulligan (2001) | 12 | 1990-1999 | USA | 0 | | 0
Shimizu (2000) | 31 | 1983-1998 | Japan | 0 | | 0
Smith (1998) | 84 | | USA | 7 | Aphasia, weakness, parietal sensory loss, worsening of a preexisting language disorder (7) | 8 | Eight patients experienced transient complications. Weakness (3), Cortical sensory loss (1), Dyslexia (1), Meningitis (1), Phlebitis (1), Orchitis (1), VIth cranial nerve palsy (1)
Hufnagel (1997) | 22 | 1993-1996 | Germany | 4 | Dysphasia (2), Global aphasia (1), Erethism and hyperkinesia (1) | 10 | Neurological deficits involving motor impairment (10)
Pacia (1997) | 21 | 1992-1994 | USA | 1 | Moderate dysphasia (1) | 9 | Mild higher corticosensory loss (1), Decreased left hand proprioception (1), Mild dysnomia and Dyslexia (1), Mild dysnomia (6)
Patil (1997) | 19 | 1991-1995 | USA | 0 | | 3 | Hemiparesis (3)
Morrell (1995) | 14 | 1987-1994 | USA | 0 | | 2 | Two small infarcts with one patient having right arm weakness (2)
Sawhney (1995) | 21 | 1989-1993 | England | 2 | Worsening of existing hemiplegia (2) | 12 | Neurological deficit (12), Arterial bleeding (1), Pulmonary embolism (1)
Shimizu (1991) | 12 | 1989-1990 | Japan | 0 | | 1 | Intracerebral hematoma (1)

Evidence Table 209. Studies addressing nondrug, nonsurgery interventions

Reference | Country | Vagal-Nerve Stimulation | Ketogenic Diet | Magnetic Therapy | Vitamin B_6_ Therapy | Herbal Medicine | Acupuncture | Elecrical Brain Stimulation | Chiropractic Therapy | Crainial Realignment | Hyperbaric Oxygen Therapy
Aldenkamp (2001) | Holland | ✓
Andriola (2001) | | ✓
Chayasirisobhon (2001) | United States | ✓
Ergene (2001) | United States | ✓
Hoppe (2001) | Germany | ✓
Liporace (2001) | | ✓
Pulsifer (2001) | United States | | ✓
DeGiorgio (2000) Followup of ClinicalTrial EO5 | United States | ✓
Hosain (2000) | United States | ✓
Ohtsuka (2000) | Japan | | | | | ✓
Valesco (2000a) | Mexico | | | | | | | ✓
Velasco (2000b) | Mexico | | | | | | | ✓
Ben-Menachem (1999) | Sweden | ✓
Boon (1999) | Belgium | ✓
Clinical Trial EO4 Labar (1999) | United States | ✓
Kloster (1999) | Norway | ✓
Mak (1999) | | | ✓
Parker (1999) | United Kingdom | ✓
Sirven (1999) | United States | | ✓
Clinical Study EO5 Handforth (1998) | United States | ✓
Freeman (1998) | United States | | ✓
Lundgren (1998) | Sweden | ✓
Vining (1998) | United States | | ✓
Salinski (1996) Followup of ClinicalTrial EO3 | Multi-national | ✓
Tiancai (1996) | China | | | | | ✓
Clinical Trial EO3 The VNS Group (1995) | Multi-national | ✓
Nagakubo (1993) | Japan | | | | | ✓
Fisher (1992) | United States | | | | | | | ✓
Sramka (1990) | Russia | | | | | | | ✓
Ogunmekan (1989) | Canada | | | | | ✓
Schwartz (1989) | | | ✓
Ziyu (1987) | China | | | | | | ✓
Sills (1986) | | | ✓
Trauner (1985) | United States | | ✓
Total Number of Studies | | 16 | 8 | 0 | 0 | 4 | 2 | 4 | 0 | 0 | 0

Evidence Table 210. Articles addressing vagal nerve stimulation (VNS) excluded for quality reasons

Study | Reason for Exclusion
Liporace (2001) | This study was designed to assess the effects of making program adjustments to the VNS device on side effects without reducing the effectiveness of the device. Patient characteristics poorly described. Seizure type and severity information not presented. Followup time not presented.

Evidence Table 211. Quality of reporting in studies of vagal nerve stimulation

Reference | Sampling methodology described? | Clinical setting clearly described? | Inclusion/exclusion criteria stated? | Criteria used to categorize patients reported? | Basic demographic data for patients presented? | Information on comorbidities presented? | Information on method of data collection presented? | Analytic methods clearly described? | Information on sample size requirements presented? | Outcome data clearly presented? | Individual patient data presnted?
RCTs performed in the United States
Clinical Study EO5 (1998) | No | Yes | Yes | No | Yes | No | Yes | Yes | No | Yes | No
Clinical Trial EO3 (1995) | No | Yes | Yes | Yes | Yes | No | Yes | Yes | No | Yes | No
Long-term followups of RCT's performed in the United States
DiGiorgio (2000) Followup of Clinical Trial EO5 | No | Yes | Yes | No | Yes | No | Yes | Yes | No | Yes | No
Salinski (1996) Followup of Clinical Trial EO3 | No | Yes | Yes | Yes | Yes | No | Yes | Yes | No | Yes | No
Case-series performed in the United States
Chayasirisobhon (2001) | No | Yes | Yes | No | Yes | No | Yes | Yes | No | Yes | Yes
Ergene (2001) | No | Yes | Yes | No | Yes | No | Yes | Yes | No | Yes | No
Hosain (2000) | No | Yes | Yes | No | Yes | No | Yes | Yes | No | Yes | No
Clinical Trial EO4 Labar (1999) | No | Yes | Yes | No | Yes | No | Yes | Yes | No | Yes | Yes
Case-series performed outside of the United States
Aldenkamp (2001) | No | Yes | Yes | No | No | Yes | Yes | Yes | No | Yes | No
Hoppe (2001) | No | Yes | Yes | No | No | No | NA | NA | No | Yes | No
Ben-Menachem (1999) | Yes | Yes | Yes | Yes | Yes | No | Yes | Yes | No | Yes | Yes
Boon (1999) | Yes | Yes | Yes | No | Yes | No | Yes | Yes | No | Yes | No
Parker (1999) | No | Yes | Yes | No | Yes | No | Yes | Yes | No | Yes | Yes
Lundgren (1998) | Yes | Yes | Yes | Yes | Yes | No | Yes | Yes | No | Yes | Yes

Evidence Table 212. Primary characteristics of included studies on vagal nerve stimulation

Reference | Start | End | Country | N | Longitudinal Study | Number of Study Groups | Number of Treatment Arms | Cross-Over Design | If Cross-Over Design, Was Washout Period Included | Type of Control Group | Randomized | Randomization Method Described | Method of Randomization Acceptable | Patients Blinded | 2nd or 3rd Party rates Blinded | Multi-center | Number of Centers | Industry Funded
Aldenkamp (2001) | NR | NR | Holland | 16 | Yes | 1 | 1 | No | NA | NA | NA | NA | NA | No | No | No | 1 | NR
Chayasirisobhon (2001) | 1998 | 1999 | United States | 24 | Yes | 1 | 1 | No | NA | NA | NA | NA | NA | No | No | No | 1 | Yes
Ergene (2001) | NR | NR | United States | 17 | Yes | 1 | 1 | NA | NA | NA | NA | NA | NA | No | No | No | 1 | NR
Hoppe (2001) | 1998 | 1999 | Germany | 36 | Yes | 1 | 1 | No | NA | NA | NA | NA | NA | No | No | No | 1 | Yes
DiGiorgio (2000) Follow-up of Clinical Trial EO5 | 1995 | 1996 | United States | 199 | Yes | 1 | 1 | No | NA | NA | NA | NA | NA | No | No | Yes | 20 | Yes
Hosain (2000) | NR | NR | United States | 13 | Yes | 1 | 1 | No | NA | NA | NA | NA | NA | No | No | No | 1 | NR
Ben-Menachem (1999) | 1992 | 1997 | Sweden | 64 | Yes | 1 | 1 | No | NA | NA | NA | NA | NA | No | No | No | 1 | No
Boon (1999) | 1995 | 1999 | Belgium | 25 | Yes | 1 | 1 | No | NA | NA | NA | NA | NA | No | No | No | 1 | No
Clinical Trial EO4Labar (1999) | NR | NR | United States | 25 | Yes | 1 | 1 | No | NA | NA | NA | NA | NA | No | No | Yes | NR | Yes
Parker (1999) | 1995 | 1996 | United Kingdom | 16 | Yes | 1 | 1 | No | NA | NA | NA | NA | NA | No | No | No | 1 | No
Clinical Study EO5 Handforth (1999) | 1995 | 1996 | United States | 199 | Yes | 2 | 2 | No | NA | Concurrent Active | Yes | Yes | Yes | Yes | Yes | Yes | 20 | Yes
Lundgren (1998) | NR | NR | Sweden | 16 | Yes | 1 | 1 | No | NA | NA | NA | NA | NA | No | No | No | 1 | NR
Salinski (1996) Follow-up of Clinical Trial EO3 | NR | NR | Multi-national^a^ | 114 | Yes | 1 | 1 | No | NA | NA | NA | NA | NA | No | No | Yes | 17 | Yes
Clinical Trial EO3 The VNS Group (1995) | NR | NR | Multi-national^a^ | 114 | Yes | 2 | 2 | No | NA | Concurrent Active | Yes | No | NA | Yes | Yes | Yes | 17 | Yes

a United States / Germany / Sweden / Canada / Holland

Evidence Table 213. Study characteristics: data collection and analysis for studies of vagal nerve stimulation

| | | | | | | Followup ^b^
Reference | Long Term Followup of Previous Controlled Trial | Subgroup Analysis of a Larger Trial | A Priori Power Calculations Performed | Pretreatment Baseline Data Reported | Baseline Observation Period | Method For Seizure Frequency Measurement | Multiple | Longest | Times | Total Attrition: N (%) | Patient Data Stratified by Seizure Type | Compliance Monitored | Individual Patient Data Presented | Statistical Methods Reported | Statistical Methods Appropriate | AED Regimes Fixed During Followup Period
RCTs performed in United States^a^
Clinical Study EO5 Handforth (1999) | No | No | Yes | Yes | 12 to 16 weeks | Patient or caregiver maintained seizure diary | Yes | 16 wks | 12 to 16 wks | 5 (2.5) | No | Yes | No | Yes | Yes | Yes
Clinical Trial EO3 The VNS Group (1995) | No | No | No | Yes | 12 weeks | Patient or caregiver maintained seizure diary | No | 14 wks | 14 wks | 0 (0.0) | No | NR | No | Yes | Yes | Yes
Long-term followup of RCTs performed in United States
DiGiorgio (2000) Followup of Clinical Trial EO5 | Yes | No | No | Yes | 12 to 16 weeks | Patient or caregiver maintained seizure diary | Yes | 1 yr | 3 mos | 31 (15.9) | No | NR | No | Yes | Yes | No
| | | | | | | | | 12 mos
Salinski (1996) Followup of Clinical Trial EO3 | Yes | No | No | Yes | 12 weeks | Patient or caregiver maintained seizure diary | Yes | 1 yr | 3 mos | 14 (12.3) | No | NR | No | Yes | Yes | No
| | | | | | | | | | | | | | | | 6 mos
| | | | | | | | | 9 mos
| | | | | | | | | 12 mos
Case series performed in United States
Chayasirisobhon (2001) | No | No | No | Yes | 4 weeks | Patient or caregiver maintained seizure diary | No | 6 mos | 6 mos | 0 (0.0) | No | NR | Yes | No (none performed) | NA | Yes
Ergene (2001) | No | No | No | Yes | NR | Patients asked to subjectively describe change in seizure frequency and severity | Yes | 12 mos | 1 to 3 wks | 0 (0.0) | No | NR | No | Yes | Yes | Yes
| | | | | | | | | 5 to 7 wks
| | | | | | | | | 3 mos
| | | | | | | | | 6 mos
| | | | | | | | | 9 to 12 mos
Hosain (2000) | No | No | No | Yes | 1 month | Unclear | No | 6 mos | 6 mos | 0 (0.0) | No | NR | Yes | Yes | Yes | No
Clinical Trial EO4 Labar (1999) | No | Yes | No | Yes | 1 month | Patient or caregiver maintained seizure diary | No | 3 mos | 3 mos | 1 (4.0) | No | Yes | No | Yes | Yes | Yes
Case series performed outside United States
Aldenkamp (2001) | No | No | No | Yes | NR | NR | No | 6 mos | 6 mos | 0 (0.0) | Yes | NR | No | Yes | Yes | No
Hoppe (2001) | No | No | No | Yes | None | Patient or caregiver maintained seizure diary | No | >6 mos | Mean: 8.0 | 0 (0.0) | No | NR | No | Yes | Yes | Yes
| | | | | | | | | (SD: 2.8) mos
Ben-Menachem (1999) | No | No | No | Yes | 3 months | Patient or caregiver maintained seizure diary (n = 57) Unknown (n = 7) | No | 5 yrs | Mean: 20 mos | 0 (0.0) | Yes | NR | Partial | No (none performed) | NA | NR
| | | | | | | | | Rng: 3 to 64 mos
Boon (1999) | No | No | No | Yes | 2 years | Patient or caregiver maintained seizure diary (and for baseline retrospective review of diary plus medical records) | No | 4 yrs 2 mos | Mean: 26 mos | 0 (0.0) | No | NR | Yes | Yes | Yes | No
| | | | | | | | | Rng: 3 to 64 mos
Parker (1999) | No | No | No | Yes | 8 weeks | Patient or caregiver maintained seizure diary | Yes | 12 mos | 6 mos | 1 (6.25) | No | NR | Yes | Yes | Yes | No ^d^
| | | | | | | | | 12 mos | 1 (6.25)
Lundgren (1998) | No | No | No | Yes | 6 months | Patient or caregiver maintained seizure diary | Yes | 24 mos | 4 to 6 mos | 0 (0.0) | No | NR | Yes | Yes | Yes | No ^e^
| | | | | | | | | 10 to 12 mos | 0 (0.0)
| | | | | | | | | 16 to 18 mos | 5 (31.3)
| | | | | | | | | 22 to 24 mos | 14 (87.5)

a Multinational studies in which the majority of study centers were based in the United States are included in this section

b Followup time refers to time after activation of device or in case of followup studies the followup time refers to time after completion of controlled phase of study

c Based on a retrospective review of medical records and patient seizure diaries

d Dosage of phenytoin increased in one patient with a >50% increase in seizures at 9 months. Authors report that this had no effect on seizure frequency. Remaining 14 patients maintained on same drugs and dosage for remainder of study.

e One patient received concomitant transient add-on treatment with felbamate. The dosage of clonazepam was increased from 1.25 to 1.50 mg daily in patient 1 during the eighth month of VNS treatment. The dosage of lamotrigine was increased in one patient after 11 months of vagal nerve stimulation treatment.

Mos = Months NA = Not applicable Wks = weeks NR = Not reported Rng = Range

Evidence Table 214. Study characteristics: attrition rates in studies of vagal nerve stimulation

| Attrition in the Whole Study (at Longest Followup)^a^
Reference | Total: N (%) | Due to Death: N (%) | Due to Adverse Event: N (%) | Due to Unrelated Illness: N (%) | Due to Treatment Dissatisfaction: N (%) | Due to Other Treatment: N (%) | Due to Other^b^ Causes: N (%) | Due to Censorship^c^ N (%)
RCTs performed in United States
Clinical Study EO5 Handforth (1999) | 5 (2.5) ^d^ | 0 (0.0) | 3 (1.5) ^d^ | 0 (0.0) | 0 (0.0) | 0 (0.0) | 2 (1.0) | 0 (0.0)
Clinical Trial EO3 The VNS Group (1995) | 0 (0.0) | 0 (0.0) | 0 (0.0) | 0 (0.0) | 0 (0.0) | 0 (0.0) | 0 (0.0) | 0 (0.0)
Long-term followup of RCTs performed in United States
DiGiorgio (2000) Followup of Clinical Trial EO5 | 31 (15.9) | 2 (1.0) | 2 (1.0) | 0 (0.0) | 18 (9.2) | 0 (0.0) | 9 (4.6) | 0 (0.0)
Salinski (1996) Followup of Clinical Trial EO3 | 14 (12.3) | 2 (1.8) | 0 (0.0) | 1 (0.9) | 9 (7.9) | 0 (0.0) | 2 (1.8) | 0 (0.0)
Case series performed in United States
Chayasirisobhon (2001) | 0 (0.0) | 0 (0.0) | 0 (0.0) | 0 (0.0) | 0 (0.0) | 0 (0.0) | 0 (0.0) | 0 (0.0)
Ergene (2001) | 0 (0.0) | 0 (0.0) | 0 (0.0) | 0 (0.0) | 0 (0.0) | 0 (0.0) | 0 (0.0) | 0 (0.0)
Hosain (2000) | 0 (0.0) | 0 (0.0) | 0 (0.0) | 0 (0.0) | 0 (0.0) | 0 (0.0) | 0 (0.0) | 0 (0.0)
Clinical Trial EO4 Labar (1999) | 1 (4.0) | 0 (0.0) | 0 (0.0) | 0 (0.0) | 0 (0.0) | 0 (0.0) | 1 (4.0) | 0 (0.0)
Case series performed outside United States
Aldenkamp (2001) | 0 (0.0) | 0 (0.0) | 0 (0.0) | 0 (0.0) | 0 (0.0) | 0 (0.0) | 0 (0.0) | 0 (0.0)
Hoppe (2001) | 0 (0.0) | 0 (0.0) | 0 (0.0) | 0 (0.0) | 0 (0.0) | 0 (0.0) | 0 (0.0) | 0 (0.0)
Ben-Menachem (1999) | 0 (0.0) | 0 (0.0) | 0 (0.0) | 0 (0.0) | 0 (0.0) | 0 (0.0) | 0 (0.0) | 0 (0.0)
Boon (1999) | 0 (0.0) | 0 (0.0) | 0 (0.0) | 0 (0.0) | 0 (0.0) | 0 (0.0) | 0 (0.0) | 0 (0.0)
Parker (1999) | 1 (6.25) | 0 (0.0) | 1 (6.25) | 0 (0.0) | 0 (0.0) | 0 (0.0) | 0 (0.0) | 0 (0.0)
Lundgren (1998) | 5 (31.3) ^g^ | NR | NR | NR | NR | NR | NR | NR
| 14 (87.5) ^h^
RCTs performed in United States
Clinical Study EO5 Handforth (1999) | High | 3 (3.2) | 0 (0.0) | 1 (1.1) | 0 (0.0) | 0 (0.0) | 0 (0.0) | 2 (2.1) ^e^
| Low | 1 (1.0) | 0 (0.0) | 0 (0.0) | 0 (0.0) | 0 (0.0) | 0 (0.0) | 1 (1.0) ^f^
Clinical Trial EO3 The VNS Group (1995) | High | NA | NA | NA | NA | NA | NA | NA
| Low | NA | NA | NA | NA | NA | NA | NA

a Exact attrition figures at different followup times and for different outcome measures are presented in the results table

b “Other” refers to patients lost to followup for unspecified reasons

c Censored patients are those who had not yet reached follow-up time at time of analysis

d Includes one patient who was not randomized because of surgical infection

e Poor compliance (n = 1); Uninterruptible patient diary

f Withdrawal of consent (n = 1)

g At 18 months

h At 24 months

NA = Not applicable

NR = Not reported

Evidence Table 215. Study characteristics: confirmation of diagnosis and definition used in studies of vagal nerve stimulation

Reference | Method(s) Used toEnsure That Patients Were Correctly Diagnosed | Patient Description
RCT's performed in the United States
Clinical Study EO5 Handforth (1999) | Not reported | Patients with medically refractory seizures defined as a frequency of ≥6 seizures per month
Clinical Trial EO3 The VNS Group (1995) | Not reported | Patients with medically refractory seizures defined as a frequency of ≥6 seizures per month
Long-term followup of RCT's performed in the United States
DiGiorgio (2000) Followup of Clinical Trial EO5 | As Clinical Study EO5 above | As Clinical Study EO5 above
Salinski (1996) Followup of Clinical Trial EO3 | As Clinical Study EO3 above | As Clinical Study EO3 above
Case-series performed in the United States
Chayasirisobhon (2001) | Not reported | Patients with seizures refractory to antiepilpetic drugs given alone or in various combinations
Ergene (2001) | Not reported | Patients with persistant, frequent seizures despite appropriate medical management
Hosain (2000) | Clinical evaluation | Patients with severe, medication resistant mixed seizures
| Routine EEG
| Video-EEG
Clinical Trial EO4 Labar (1999) | Retrospective review of clinical notes, EEG data, neroimaging data | Patients with medication resistant generalized epilepsy
Case-series performed outside the United States
Aldenkamp (2001) | Clinical evaluation | Patients with Lennox-Gestaut syndrome whose seizures were unacceptable to patient because of impact on dailiy function
| EEG evidence
| | Patients seizures were resistant to treatment with antiepileptic drugs and patients were inelligable for resective surgery
Hoppe (2001) | Not reported | Patients with pharmacoresistant complex-partial seizures
Ben-Menachem (1999) | Clinical evaluation | Patients with seizuers refractory to available antiepileptic drugs
| Routine EEG
| Ictal video-EEG in patients with partial seizures
| MRI
Boon (1999) | Extensive pre-surgical evaluation which included: | Patients with medically refractory partial seizures considered for resective surgery but, following an extensive evaluation, were found not to be suitable candidates because a confined or resectable epileptogenic zone could not be identified
| Clinical evaluation
| Video-EEG monitoring (+2 patients underwent intracranial video-EEG monitoring)
| MRI
| FDG-PET
Parker (1999) | Clinical assessment | Patients with cryptogenic epileptic enecepahlopathy
| Interictal EEG activity conjusive with generalized seizures
| Normal MRI (no evidence of focal lesion)
| PET (no evidence of focal lesion or focal lesion with absence of interical focal abnormality)
Lundgren (1998) | Not reported | Patients with intractable epilepsy

Evidence Table 216. Study characteristics: patient selection criteria in studies of vagal nerve stimulation

| Reasons for Patient Selection
Reference | Subpopulation of Patients Who Received VNS | Children | Adults | Particular Syndrome | Particular Seizure Type | Mentally Retarded or Have Deveolpmental Disability | Minimum Seizure Rate to be Eligible | Side Effects Included in Definition of Treatment Resistant Epilepsy | Study Reported Prior AEDs Failed at Maximum Tolerated Dose | Inclusion Critiera | Excusion Criteira | Patient Sampling Method
RCTs performed in United States
Clinical Study EO5 Handforth (1999) | Yes | No | No | No | Yes | No | 6 per month | No | No | ≥6 seizures in a 30 day period | Deteriorating medical or neurological conditions | Not reported
| | | | | | | | | | Age 12 to 65 years | Pregnancy
| | | | | | | | | | Use acceptable AX-contraception if fertile female | Cardiac or pulmonary disorder
| | | | | | | | | | Take 1 to 3 marketed AEDs on a stable regimen for >1 month | Active peptic ulcer
| | | | | | | | | | | History of non-epilpetic seizures
| | | | | | | | | | | >1 episode of status epilepticus in previous 12 mos
| | | | | | | | | | | Prior cervical vagotomy
| | | | | | | | | | | Prior brain stimulation
| | | | | | | | | | | Prior VNS
| | | | | | | | | | | Prior resective epilepsy surgery
| | | | | | | | | | | Inability to perform pulmonary function tests
| | | | | | | | | | | Unable to comply with clinical visits
Clinical Trial EO3 The VNS Group (1995) | Yes | No | No | No | Yes | No | 6 per month | No | No | Partial seizures | Progressive or unstable-medical condition | Consecutive
| | | | | | | | | | Seizures not adequatley controlled with medication | Eitiology best treated by surgery
| | | | | | | | | | ≥6 seizures per month | Use of >3 AED's at study entry
| | | | | | | | | | Age ≥12 years | Use of an experimental AED at time of entry
| | | | | | | | | | | Pregnancy
| | | | | | | | | | | ≥20% variation in serum AED levels during baseline.
Long-term followup of RCTs performed in United States
DiGiorgio (2000) Followup of Clinical Trial EO5 | Yes | No | No | No | Yes | No | 6 per month | No | No | See Clinical Trial EO3 | See Clinical Trial EO5 | See Clinical Trial EO5
Salinski (1996) Followup of Clinical Trial EO3 | Yes | No | No | No | Yes | No | 6 per month | No | No | See Clinical Trial EO3 | See Clinical Trial EO3 | See Clinical Trial EO3
Case series performed in United States
Chayasirisobhon (2001) | No | No | No | No | No | No | 6 per month | No | No | Refractory response to AED's given alone or in combination | Evidence of non-epilpetic seizures | All patients who met inclusion criteria implanted with VNS at study center
| | | | | | | | | | ≥ 6 seizures per mo | Previous left cervical vagotomy
| | | | | | | | | | Patients are unsuitable-for epilepsy surgery
Ergene (2001) | Yes | No | No | No | Yes | No | Not reported | No | No | Partial onset seizures | Not reported | Not reported
| | | | | | | | | | Persistant, frequent seizues despite appropriate medical management
| | | | | | | | | | Not candidates for surgical treatment
Hosain (2000) | Yes | No | No | Yes | No | No | Not reported | No | No | Patients with Lennox Gestaut syndrome | Not reported | All patients with Lennox-Gastaut syndrome
| | | | | | | | | | Severe medication resistant mixed seizures
| | | | | | | | | | Static encephalopathy
| | | | | | | | | | Generalized slow spike-and-wave discharges seen on EEG
| | | | | | | | | | Undergone video-EEG to confirm diagnosis
Clinical Trial EO4 Labar (1999) | Yes | No | No | No | Yes | No | ≥1 per month | No | No | Age >3 years | Cardiac or progressive neurologic disease | All patients with generalized seizures who met inclusion criteria of study EO4^b^
| | | | | | | | | | ≥1 seizure per month
Case series performed outside United States
Aldenkamp (2001) | Yes | Yes | No | Yes | No | Yes | Not reported | No | No | Multiple seizure types consistent with Lennox-Gastaut syndrome | Progressive neurological disease | All patients with Lennox-Gastaut syndrome
| | | | | | | | | | Mental retardation or developmental delay | Bad physical condition that would not allow the surgical implantation procedure
| | | | | | | | | | Seizures unacceptable-to patients or parent because of impact on daily life functions and development due to frequency or severity | Any risk for complications due to the implanataion procedure (cardiac disease, restrictive pulmonary disease, stomach ulcers)
| | | | | | | | | | Resistance to existing pharmacological treatments and ineligibility for surgical alternatives (resective surgery, callosotomy)
| | | | | | | | | | Written and signed informed consent
Hoppe (2001) | Yes | No | Yes | No | Yes | No | Not reported | No | No | Patients with pharmacoresistant complex-partial seizures | Not reported | Consecutive
| | | | | | | | | | Patients able to participate in neuropsychological assessment.
Ben-Menachem (1999) | No | No | No | No | No | No | Not reported | No | No | Refractory to available AED's | Not reported | Not reported
| | | | | | | | | | Patients deemed unsuitable-for epilepsy surgery or had received unsuccessful surgery
Boon (1999) | Yes | No | No | No | Yes | No | Not reported | No | No | Patients with partial seizures refractory to available AED's who had undergone extensive pre-surgical evaluation but were consequently deemed unsutiable candidates for surgery | Not reported | All patients with >6 mos followup.
Parker (1999) | Yes | Yes | No | No | No | No | Not reported | No | No | Mixed generilized seizures refractory to treatment with AED's | Not reported | All children receiving VNS device at study center who met inclusion criteria
| | | | | | | | | | Age ≤18 yrs
Lundgren (1998) | Yes | Yes | No | No | No | No | Not reported | No | No | Not reported | Not reported | Unclear

a See The Vagus Nerve Stimulation Study

b This report contains a subgroup of patients with generalized seizures who entered Clinical Study EO4. Data from whole study population is not available

Evidence Table 217. Study characteristics: settings in studies of vagal nerve stimulation

Reference | Study Arm | Output Current (mA) | Ramp Up Period | Frequency (Hz) | Pulse Width (μs) | On Time (sscs) | Off Time (min) | Manual Activation Mode
RCTs performed in United States
Clinical Study EO5 Handforth (1999) | High | 0.25 to 3.5 (maximum tolerable) | 2 weeks | 30 | 500 | 30 | 5 | Enabled
| Low | 0.25 to 3.5 (minimum level consistent sensation of stimulation) | 2 weeks | 1.0 | 130 | 30 | 180 | Disabled
Clinical Trial EO3 The VNS Group (1995) | High | 1.5 (range: 0.25 to 3.0 (max tolerable) | NR | 30 (range: 20 to 50) | 500 | 30 (range: 30 to 90) | 5 (range: 5 to 10) | Enabled
| Low | 1.25 (range: 0.25 to 2.75) (minimum level consistent a sensation stimulation) | NR | 1 (range: 1 to 2) | 130 | 30 | 90 (range: 60 to 180) | Disabled
Long-term followup of RCTs performed in United States
DiGiorgio (2000) Followup of Clinical Trial EO5 | High | 0.25 to 3.5 (maximum tolerable) | 2 weeks | 20 to 30 | 500 to 750 | 7 to 60 | 1.1 to 180 | Enabled
Salinski (1996) Followup of Clinical Trial EO3 | High | 1.5 (range: 0.25 to 3.0 (maximum tolerable) | NR | 30 (range: 20 to 50) | 500 | 30 (range: 30 to 90) | 5 (range: 5 to 10) | Enabled
Case series performed in United States
Chayasirisobhon (2001) | NA | 1.75 to 3.5 (maximum tolerable) | 6 weeks | 30 | 500 | 30 | 5 | Enabled
Ergene (2001) | NA | 1.0 to 2.5 (maximum tolerable) | 2 to 3months | 30 | 500 | 30 | 5 | NR
Hosain (2000) | NA | 0.50 to 1.75 (maximum tolerable) | 2 weeks to 2 months | 30 | 500 | 30 | 5 | Enabled
Clinical Trial EO4 Labar (1999) | NA | 0.25 to 3.5 (maximum tolerable) | 3 months | 30 | 500 | 30 | 5 | Enabled
Case series performed outside United States
Aldenkamp (2001) | NA | 1.5 to 2.0 (maximum tolerable) | 3 months | 30 | 500 | 30 (or 7 if patient did not respond) | 5 (or 18 secs if patient did not respond) | NR
Hoppe (2001) | NA | 0.5 to 2.0 (maximum tolerable) | 8 weeks | 30 | 500 | 30 (or 7 if patient did not respond | 5 (or 30 secs if patient did not respond) | NR
Ben-Menachem (1999) | NA | 1.0 to 1.5 (maximum tolerable) | NR | 30 | 500 | 30 (or 7 if patient did not respond) | 5 (or 20 secs if patient did not respond) | NR
Boon (1999) | NA | 1.0 to 2.7 (maximum tolerable) | NR | 30 | 500 | 30 | 5 to 10 | Enabled
Parker (1999) | NA | 1.25 to 2.0 (maximum tolerable) | NR | NR | NR | 30 | 5 | NR
Lundgren (1998) | NA | 1.25 to 2.0 (maximum tolerable) | 2 to 12 weeks | 30 | 500 | 30 (or 7 if patient did not respond) | 5 (or 12 to 30 secs if patient did not respond) | Yes

a Information on VNS device settings extracted from Labar (1999)

NA Not applicable

NR Not reported

Evidence Table 218. Patient characteristics: baseline demographics in studies of vagal nerve stimulation

Reference | Presented Baseline Demographic Data For All Patients Who Entered Study | Study Arm | % Male | Mean Age at Implantation in Years (SD) | Age Range in Years | Mean Duration of Disease in Years (SD) | Range of Disease Duration | Mean Age at Onset (SD) | Range of Age at Onset | Postsurgical Patients (%) | AED's Taken by Each Patient | Patients With IQ <70 (%)
RCTs performed in United States
Clinical Study EO5 Handforth (1999) | Yes | High | 51.6 | 32.1 (10.8) | 13 to 54 | 22.1 (11.5) | 2 to 48 | NR | NR | 0 (0.0) | 1 to 3 | NR
| | Low | 42.7 | 34.2 (10.1) | 15 to 60 | 23.7 (10.8) | 2 to 52 | NR | NR | 0 (0.0) | 1 to 3 | NR
Clinical Trial EO3 The VNS Group (1995) | No | High | 61 | 33.1 (NR) | NR | 23.1 (NR) | NR | NR | NR | 0 (0.0) | Mean: 2.09 | NR
| | Low | 63.9 | 33.5 (NR) | NR | 20.0 (NR) | NR | NR | NR | 0 (0.0) | Mean: 2.08 | NR
Long-term followup of RCTs performed in United States
DiGiorgio (2000) Followup of Clinical Trial EO5 | Yes | NA | 46.7 | 34 (NR) | NR | Median: 22 | NR | Median: 9 years | NR | 0 (0.0) | 1 to 3 | NR
Salinski (1996) Followup of Clinical Trial EO3 | Yes | NA | NR | 33 (NR) | 13 to 52 | NR | NR | NR | NR | 0 (0.0) | 1 to 3 | NR
Case series performed in United States
Chayasirisobhon (2001) | Yes | NA | 58.3 | 27.1 (17.2) | 6 to 70 | 20.1 (14.1) | 1 to 43 | 7.0 (8.9) years | 1 day to 31 years | NR | 1 to 3 | 11 (45.8)
Ergene (2001) | Yes | NA | 64.7 | 33.8 (NR) | 11 to 55 | NR | NR | NR | NR | 0 (0.0) | 2 or 3 | NR
Hosain (2000) | Yes | NA | 76.9 | 18.9 (10.8) | 4 to 44 | NR | NR | NR | NR | 3 (23.1) | Median: 6 (range: 4 to 12 | NR
Clinical Trial EO4 Labar (1999) | No | NA | 54.2 | NR (NR) | 4 to 40 | NR (NR) | 4 to 35 | NR (NR) | 0 to 14 yrs | NR | 1 to 5 | NR
Case series performed outside United States
Aldenkamp (2001) | Yes | NA | 81.3 | 11.1 (NR) | 6 to 17 | 8.5 (NR) | NR | 2.6 (NR) | 0 to 8 yrs | 0 | NR | NR
Hoppe (2001) | Yes | NA | NR | 33.6 (9.8) | NR | NR | NR | NR | NR | NR | NR | 0 (0.0)
Ben-Menachem (1999) | No | NA | NR | NR | NR | NR | NR | NR | NR | NR | 1 to 4 | NR
Boon (1999) | Yes | NA | 40.0 | 30.2 (9.0) | 12 to 45 | 17.0 (8.0) | 5 to 35 | 13.3 (7.8) years | 2 to 29 years | 0 (0.0) | NR | NR
Parker (1999) | Yes^a^ | NA | NR | 11.3 (3.1) | 5 to 17 | 10.0 (3.4) | 3 to 16 | 1.3 (1.6) years | 1 mo to 3 years | 0 | NR | NR
Lundgren (1998) | Yes | NA | 62.5 | 11.0 (4.5) | 4 to 19 | 8.1 (4.3) | 3.5 to 18.6 | 2.9 (2.7) years | 1 mos to 9 years | 6 (37.5) | 1 to 3 | 14 (87.5)

a Demographic data presented for the 15 of 16 patients in whom device was who initiated. Data from one patient who had device removed because of infection prior to device initiation was not presented.

NA = Not applicable

NR = Not reported

Evidence Table 219. Patient characteristics: seizure types and etiology in studies of vagal nerve stimulation

| | Number of Patients With Each Seizure Type (%)
Reference | Treatment Arm | Primary Partial | Primary Generalized | Complex Partial | Simple Partial | Secondary Generalized | Generalized Tonic, Clonic, or Tonic-Clonic | Generalized Absence | Lennoz-Gastaut Syndrome | Generalized Atonic | Treatment Arm | Etiology / Syndrome / History
RCTs performed in United States
Clinical Study EO5 Handforth (1999) | High | 95 (100.0) | NR | NR | NR | NR | NR | NR | NR | NR | High | NR
| Low | 103 (100.0) | NR | NR | NR | NR | NR | NR | NR | NR | Low | NR
Clinical Trial EO3 The VNS Group (1995) | High | 54 (100.0) | NR | 50 (92.6) | 24 (44.4) | 38 (70.4) | NR | NR | NR | NR | High | NR
| Low | 60 (100.0) | NR | 58 (96.7) | 25 (41.7) | 33 (55.0) | NR | NR | NR | NR | Low | NR
Long-term followup of RCTs performed in United States
DiGiorgio (2000) Followup of Clinical Trial EO5 | NA | 195 (100.0) | NR | 191 (98.0) | NR | NR | 96 (49.2) | NR | NR | NR | NA | NR
Salinski (1996) Followup of Clinical Trial EO3 | NA | 114 (100.0) | NR | NR | NR | NR | NR | NR | NR | NR | NA | NR
Case series performed in United States
Chayasirisobhon (2001) | NA | 14 (58.3) | ? | 10 (41.7) | 12 (50.0) | ? | 21 (87.5) | 8 (33.3) | 6 (25.0) | 7 (29.2) | NA | Lennox-Gestaut syndrome (n = 6) | Epidermoid tumor (n = 1)
| | | | | | | | | | | | Tuberous sclerosis (n = 3) | Caernous angioma (n = 1)
| | | | | | | | | | | | Encephalitis (n = 2) | Porencephalopathy (n = 1)
| | | | | | | | | | | | Head injury (n = 2) | Prenatal encephalopathy (n = 1)
| | | | | | | | | | | | Oligodendrioma (n = 1) | Unknown (n = 5)
| | | | | | | | | | | | Meningoencephalitis (n = 1)
Ergene (2001) | NA | 17 (100.0) | 0 (0.0%) | NR | NR | NR | NR | NR | NR | NR | NA | Cerebral palsy/ perinatal brain injury (n = 5 (29.4%) | Subarachnoid hemorrhage (n = 2 (11.8%)
| | | | | | | | | | | | Mesial temporal sclerosis (n = 3 (17.7%) | History of meningitis (n = 1 (5.9%)
| | | | | | | | | | | | Head injury (n = 2 (11.8%) | Unknown (n = 4 (23.5%)
Hosain (2000) | NA | 13 (100.0) | 4 (30.8) | 4 (30.8) | 0 (0.0) | 3 (23.1) | 9 (69.2) | 12 (92.3) | 13 (100.0) | 4 (30.8) | NA | Lennox Gestaut syndrome (n = 13)
Clinical Trial EO4 Labar (1999) | NA | 0 (0.0) | 24 (100.0) | 0 (0.0) | 0 (0.0) | 0 (0.0) | 22 (88.0) | 12 (48.0) | NR | NR | NA | Cryptogenic (n = 10) | Congenital brain injury (n = 3)
| | | | | | | | | | | | Postinfectious (n = 4) | Unknown (n = 7)
Case series performed outside United States
Aldenkamp (2001) | NA | NR | NR | 5 (31.3) | 0 (0.0) | 1 (6.3) | 10 (62.5)^a^ | 10 (62.5) | 12 (75.0) | 3 (18.8) | NA | Lennox-Gestaut syndrome (n = 12) | Myoclonic absence epilepsy (n = 1)
| | | | | | | 9 (56.3)^b^ | | (+4 patients (25.0%) with LG like syndromes) | | | Doose syndrome (n = 3)
Hoppe (2001) | NA | 36 (100.0) | 0 (0.0) | 36 (100.0) | 0 (0.0) | NR | NR | NR | NR | NR | NA | NR
Ben-Menachem (1999) | NA | 47 (73.4) | 17 (26.6) | 47 (73.4) | NR | NR | 9 (14.1) | NR | 8 (12.5) | NR | NA | Lennox-Gestaut syndrome (n = 8)
| | | | | | | | | | | | NR (n = 56)
Boon (1999) | NA | 0 (0.0) | 20 (100) | 4 (20.0) | 18 (90.0) | 0 (0.0) | 0 (0.0) | 0 (0.0) | 0 (0.0) | 0 (0.0) | NA | History of head injury (n = 5) | History of forceps delivery (n = 1)
| | | | | | | | | | | | History of encephalitis (n = 2) | History of fibrile seizures (n = 6)
| | | | | | | | | | | | History of premature birth (n = 1) | History of ventricular atrial drainage (n = 1)
| | | | | | | | | | | | History of meningitis (n = 5) | No history (n = 4)
Parker (1999) | NA | 0 (0.0) | 16 (100.0) | 0 (0.0) | 0 (0.0) | 0 (0.0) | 0 (0.0) | 0 (0.0) | 10 (62.5) | 0 (0.0) | NA | Lennox-Gestaut (n = 10)
| | | | | | | | | | | | Juvenile myoclonic epilepsy (n = 6)
Lundgren (1998) | NA | 8 (50.0) | 8 (50.0) | NR | NR | 2 (12.5) | 4 (25.0) | 0 (0.0) | 4 (25.0) | 0 (0.0) | NA | Lennox-Gestaut (n = 4)
| | | | | | | | | | | | NR (n = 12)

a Generalized tonic seizuers

b Generalized tonic-clonic seizuers

NA Not applicable

NR Not reported

Evidence Table 220. Subpopulations of patients with treatment-resistant epilepsy in whom vagal nerve stimulation was assessed

Reference | Patients Recruited Because of Seizure Type | Patients Recruited Because of Syndrome | Seizure Type or Syndrome (if Applicable) | Patients Chosen Because They Were Children | Patients Chosen Because They Were Adults
RCTs performed in United States
Clinical Study EO5 Handforth (1999) | ✓ | | Partial seizures
Clinical Trial EO3 The VNS Group (1995) | ✓ | | Partial seizures
Followup studies of RCTs
DiGiorgio 2000) | ✓ | | Partial seizures
Followup of Clinical Trial EO5
Salinski (1996) | ✓ | | Partial seizures
Followup of Clinical Trial EO3
Case series performed in United States
Chayasiriobhon (2001) | | | Mixed
Ergene (2001) | ✓ | | Partial seizures
Hosain (2000) | | ✓ | Lennox-Gestaut Syndrome
Clinical Trial EO4 Labar (1999) | ✓ | | Generalized seizures
Case series performed outside of the United States
Aldenkamp (2001) | | ✓ | Lennox-Gestaut Syndrome | ✓
Hoppe (2001) | ✓ | | Complex-partial seizures
Ben-Menachem (1999) | | | Mixed
Boon (1999) | ✓ | | Partial seizures
Parker (1999) | ✓ | | Primary or secondary generlaized seizures | ✓
Lundgren (1998) | | | Mixed | ✓

Evidence Table 221. Individual patient data extracted from Boon (1999)

Patient | Sex | Age | Seizure Type | Age at Onset of Disease (Years)^a^ | Duration of Disease (Years) | History | VNS Output Current (mA) | Baseline Mean Seizure Frequency (Seizures Per Month) | Followup Time (Months) | Post VNS Mean Seizure Frequency (Seizures Per Month) | % Reduction In Mean Seizure Rate^a^
1 | M | 36 | CPS, SG | 14 | 22 | Febrile seizures, head trauma | 2.25 | 8 | 50 | 0 | 100
2 | F | 34 | CPS, SG, SPS | 29 | 5 | Head trauma | 1.75 | 3 | 50 | 0 | 100
3 | M | 39 | CPS, SG | 26 | 13 | Head trauma | 1.5 | 4 | 45 | 0 | 100
4 | F | 32 | CPS, SG | 14 | 18 | Encephalitis | 2.75 | 40 | 43 | 25 | 37.5
5 | M | 30 | CPS, SG, SPS | 12 | 18 | Premature birth, callosotomy | 2.5 | 4 | 38 | 3 | 25.0
6 | M | 21 | CPC, SG | 3 | 18 | Febrile seizures | 2.5 | 4 | 38 | 1 | 75.0
7 | M | 29 | CPS, SG | 7 | 22 | Head trauma | 2.0 | 30 | 37 | 20 | 33.3
8 | F | 23 | CPS, SG, SPS | 5 | 18 | Febrile seizures, head trauma | 1.5 | 4 | 31 | 0 | 100
9 | F | 32 | CPS, SG | 23 | 9 | Febrile seizuers | 1.75 | 16 | 28 | 4 | 25.0
10 | F | 25 | CPS, SG | 2 | 23 | Febrile seizures, encephailitis | 3.0 | 35 | 26 | 30 | 14.3
11 | F | 39 | CPS, SG | 8 | 31 | Forceps birth | 2.75 | 8 | 23 | 2 | 25.0
12 | F | 44 | CPS, SG | 9 | 35 | Meningitis, ventricular atrial drainage | 1.75 | 2 | 20 | 0 | 100
13 | F | 17 | CPS, SG, SPS | 6 | 11 | None | 1.5 | 200 | 20 | 0 | 100
14 | F | 25 | CPS, SG (atonic) | 12 | 13 | None | 1 | 30 | 19 | 30 | 0.0
15 | M | 20 | CPS | 14 | 6 | Meningitis, head trauma | 2.75 | 4 | 15 | 1 | 25.0
16 | M | 38 | CPS, SG | 18 | 20 | None | 2 | 30 | 12 | 30 | 0.0
17 | F | 12 | CPS, SG | 7 | 5 | None | 2 | 12 | 10 | 9 | 25.0
18 | F | 37 | CPS, SG | 23 | 14 | Meningitis | 2 | 3 | 9 | 0.5 | 83.3
19 | M | 26 | CPS | 12 | 14 | Meningitis | 2.25 | 20 | 8 | 12 | 40.0
20 | F | 45 | CPS, SG | 21 | 24 | Meningitis, febrile seizures | 1 | 10 | 6 | 6 | 40.0

a Calculated from available data by ECRI

CPS Complex partial seizure

SG Secondary generalized

SPS Simple partial seizure

Evidence Table 222. Individual patient data extracted from Chayasirisobhon (2001)

Patient | Sex | Age at Device Implantation (Years) | Age at Onset of Epilepsy | Etiology/Syndrome | Type of Seizures | Medications | Current Settings (mA) | Type and Baseline Seizure Rate | Type and Baseline Seizure Rate at Followup | % Decrease in Seizure Frequency
1 | F | 43 | 8 years | Encephalitis | PS, PCS, GS | CBZ, PRM | 2.75 | PCS 127 | PCS 122 | 3.9
2^a^ | M | 24 | 6 months | Lennox-Gastaut syndrome | AB, AS, GS, MS, TS | CBZ, VPA | 2.25 | GS 24 / TS 12 | GS 12 / TS 2 | 50.0 / 83.3
3^a^ | M | 11 | 2 months | Lennox-Gastaut syndrome | AB, AS, GS, MS, TS | VPA | 2.50 | AS 241 / GS 74 | AS 4 / GS 7 | 98.3 / 90.5
4 | M | 22 | 2 years | Oligodendroglioma | PS, PCS, GS | CBZ, PRM | 2.00 | PS 34 / GS 6 | PS 3 / GS 1 | 91.2 / 83.3
5 | M | 54 | 12 years | Unknown | PS, PCS, GS | CBZ, PRM | 2.50 | PCS 18 / PS 10 | PCS 7 / PS 5 | 61.1 / 50.0
6 | M | 18 | 12 years | Head injury | PS, PCS, GS | CBZ, TGB | 3.00 | PCS 6 | PCS 4 | 33.3
7 | F | 45 | 5 years | Unknown | PS, PCS | CBZ, TPM | 1.75 | PCS 31 | PCS 12 | 61.3
8^a^ | M | 16 | 2 months | Meningoencephalitis | PS, GS | CBZ, VPA | 2.75 | PS/GS 63 | PS/GS 4 | 93.7
9 | F | 70 | 17 years | Unknown | AB, AS, GS, MS, TS | PHT, TGB | 2.75 | PCS 6 | PCS 4 | 33.3
10^a^ | M | 9 | 8 years | Encephalitis | PS, GS | VPA | 3.5 | PS/GS 30 | PS/GS 25 | 16.7
11^a^ | F | 10 | 2 years | Tuberous sclerosis | AB, AS, GS, MS, TS | PHT, VPA | 2.5 | AS 1072 /GS 231 | AS 78 / GS41 | 92.7 / 82.3
12 | F | 23 | 18 years | Head injury | PS, PCS, S | ETT, LTG | 2.0 | CPS 10 / GS 2 | PCS 4 / GS 0 | 60.0 / 100.0
13^a^ | F | 12 | 1 day | Tuberous sclerosis | AB, AS, GS, MS, TS | PRM, TPM, TGB | 3.25 | AS 1204 / GS 56 | AS 84 / GS 4 | 93.0 / 89.3
14 | M | 41 | 7 years | Unknown | AB, GS | VPA | 2.35 | AB 136 / GS 14 | AB 66 / GS 0 | 51.5 / 100.0
15 | F | 45 | 31 years | Epidermoid tumor | PS, PCS | CBZ | 2.0 | PS 11 / PCS 8 | PS 1 / PCS 0 | 90.9 / 100.0
16 | M | 32 | 15 years | Cavernous angioma | PS, PCS, GS | CBZ, TPM | 3.25 | PCS 28 | PCS 25 | 10.7
17^a^ | M | 13 | 11 months | Lennox-Gastaut syndrome | AB, AS, GS, MS, TS | CBZ, VPA | 3.25 | MS 60 / GS 74 | MS 56 / GS 60 | 6.7 / 19.0
18^a^ | M | 27 | 3 months | Lennox-Gastaut syndrome | AB, AS, GS, TS | PB, VPA | 3.5 | AB 30 / GS 12 | AB 15 / GS 11 | 50.0 / 8.3
19 | F | 46 | 27 years | Unknown | PCS, GS | CNZ, GBP | 2.75 | PCS 84 | PCS 15 | 82.1
20^a^ | M | 14 | 11 months | Lennox-Gastaut syndrome | TS, GS | VPA, TPM | 3.0 | TS 126 | TS 98 | 22.2
21 | M | 43 | 1 day | Porenephaly | PS, GS | PRM, LTG, TGB | 3.0 | PS 75 / GS 43 | PS 95 / GS 57 | -32.6 / -26.7
22^a^ | M | 6 | 2 years | Lennox-Gastaut syndrome | AB, AS, GS, MS, TS | LEV | 2.5 | TS 168 | TS 32 | 81.0
23 | F | 15 | 6 months | Prenatal encephalopathy | PS, GS | PHT, TPM, LEV | 3.25 | PCS 5 / GS 6 | PCS 2 / GS 2 | 60.0 / 66.7
24^a^ | F | 12 | 2 months | Tuberous sclerosis | AB, GS | CBZ, VPA | 3.25 | AB 71 | AB 5 | 93.0

a Mentally retarded

AB Absence seizure PS Partial seizure

AS Atonic seizure PCS Partial complex seizure

GS Generalized tonic-clonic seizure TS Tonic seizure

MS Myoclonic seizure

CBZ Carbamazepine PB Phenobarbital

CNZ Clonzapam PHT Phenytoin

ETT Ethotoin PRM Primodome

GBP Gabapentin TGB Tiagabine

LEV Levetiracetam TPM Topiramate

LTG Lamotrigine VPA Valproate

Evidence Table 223. Individual patient data extracted from Hosain (2000)

Patient | Age at Implant | Sex | Etiology | Seizure Types | Neuroimaging | Baseline Seizure Frequency | % Reduction in Seizures at 6 Months
1 | 10 | M | Cryptogenic | GTC, MY | Atrophy | 22 | 84
2 | 14 | F | Cryptogenic | GTC, MY, ATA | Diffuse atrophy | >100 | 0
3 | 14 | M | Hypoxic-ischemic encephalopathy | AT, T, ATA, CP, CP/2^nd^ gen | Difuse atrophy | 22 | 54
4 | 13 | M | CNS infection | ATA, MY, CP, GTC | Diffuse atrophy, calcifications | 77 | 77
5 | 9 | M | Tuberous sclerosis | ATA, AT, GTC, CP/2^nd^ gen | Cortical tubers | 96 | 93
6 | 16 | M | Cryptogenic | CP, CP/2^nd^ gen, ATA, MY | Atrophy CC section | 123 | 40
7 | 15 | M | Cryptogenic | ATA, MY, GTC | CC section | 19 | 47
8 | 4 | M | Tuberous sclerosis | ATA, AT, GTC, MY | Cortical tubers | 21 | 37
9 | 23 | M | Immunization-induced encephalopathy | GTC, ATA, T | CC section | 118 | 78
10 | 26 | M | Cryptogenic | ATA | Normal | 29 | 52
11 | 29 | F | Cryptogenic | ATA | Normal | 75 | 43
12 | 29 | F | Encephalitis | ATA, GTC | Atrophy | 94 | 42
13 | 44 | M | Trauma | ATA, AT | Atrophy | 54 | 89

ATA Atypical absence seizure MY Myoclonic seizure

AT Atonic seizure CP Partial complex seizure

GTC Generalized tonic-clonic seizure T Tonic seizure

nd CP/2 generation Partial complex seizure with secondary generalization

Evidence Table 224. Individual patient data extracted from Parker (1999)

Patient | Diagnosis | Age at Onset | Age at Implant | Seizure Types | Concurrent Treatment | Seizure Rate (Per Month) | % Change From Baseline at 6 months | % Change From Baseline at 12 months
1 | LGS | 1 month | 13 years 6 months | CPS, secondary generalized, NCS | Carbamazepine, Sodium Valproate | 68 | -15.0 | -34.0
2 | LGS | 3 months | 10 years 9 months | CPS, Atonic | Carbamazepine, Clobazam, Gabapentin | 43 | -32.0 | -17.0
3 | LGS | 6 months | 11 years 11 months | Atonic, CPS | Carbamazepine, Clobazam | 72 | -19.0 | +7.0
4 | LGS | 1 months | 11 years 2 months | GTCS, NCS | Carbamazepine, Vigabatrin, Lamotrigine | 6 | -41.0 | -50.0
5 | LGS | 3 months | 6 years 11 months | Myoclonic, GTCS | Carbamazepine, Clobazam, Lamotrigine | 166 | -63.0 | -80.0
6 | LGS | 8 months | 13 years 9 months | CPS, secondary generalized, atonic, atypical, absence | Carbamazepine, Phenytoin, Clobazam | 26 | -8.0 | +27.0
7 | LGS | 6 months | 16 years 6 months | Myoclonic, atonic, GTCS, NCS | Carbamazepine, Phenytoin, Gabapentin | 288 | -54.0 | -46.0
8 | De Novo LGS | 3 years | 6 years 3 months | CPS | Lamotrigine, Sodium Valproate | 4 | -25.0 | -100.0
9 | De Novo LGS | 3 years | 10 years 7 months | Atonic, atypical, absence, GTCS | Lamotrigine, Sodium Valproate | Device removed after implant
10 | De Novo LGS | 2 years | 9 years 7 months | GTCS, atonic | Carbamazepine, Clonazepam, Gabapentin | 5 | +100.0 | +40.0
11 | SME | 7 months | 14 years 11 months | Secondary generalized, CPS, atypical, absences | Lamotrigine, Sodium Valproate, Primidone | 26 | +165.0 | +62.0
12 | SME | 2 months | 11 years 3 months | CPS, secondary generalized | Carbamazepine, Lamotrigine, Phenytoin, Heminevrin | 23 | +17.0 | +65.0
13 | SME | 12 months | 11 years 4 months | GTCS, NCS | Carbamazepine, Vigabatrin, Diazepam | 9 | -23.0 | -23.0
14 | SME | 3 months | 5 years 1 months | Secondary generalized | Phenytoin, Clobazam, Lamotrigine, Vigabatrin | 20 | 0.0 | 0.00
15 | MAE | 2 years | 12 years 6 months | Atypical, absences, secondary generalized | Sodium Valproate, Lamotrigine, Nitrazepam | 7 | +14.0 | 0.00
16 | MAE | 11 months | 14 years 2 months | CPS, secondary generalized | Lamotrigine, Sodium Valproate, Vigabatrin | 85 | -40.0 | -67.0

CPS Complex partial seizures

GTCS Generalized tonic clonic seizures

LGS Lennox-Gastaut Syndrome

MAE Myoclonic astatic epilepsy

NCS Non-convulsive status eplilepticus

SME Severe myoclonic epilepsy

Evidence Table 225. Individual patient data extracted from Lundgren (1998)

| | | | | | | | | Number of Seizures Per Month | | | | | Quality of Life (Nonvalidated Visual Analog Instrument)
Patient | Sex | Age at Onset | Cause | Type of Epilepsy | Seizure Type | Pevious Surgery Type | Mentally Retarded (IQ <70)? | Age at Implant (years) | Baseline | 4 to 6 Months | 10 to 12 Months | 20 to 18 Months | 22 to 24 Months | Baseline | 4 to 6 Months | 10 to 12 Months | 20 to 18 Months | 22 to 24 Months
1 | M | 3 months | Cryptogenic | JME | TA, MYO, ABS | Anterior callosotomy | Yes | 10 | 26 | 10 | 16 | 14 | 27 | 70 | 75 | 65 | 65 | 70
2 | F | 2 years 6 months | Cryptogenic | Partial | SPS | None | No | 11 | 46 | 0 | 0 | 3 | 15 | 100 | 99 | 99 | 99 | 50
3 | M | 1 years 8 months | Malformation | Partial | TA, GTCS | Anterior callosotomy | Yes | 14 | 45 | 57 | 68 | 59 | | 20 | 15 | 10 | 10
4 | F | 1 month | Cryptogenic | Partial | CPS | None | Yes | 8 | 24 | 43 | 50 | 75 | | 0 | 0 | 0 | 0
5 | M | 3 years 3 months | Unknown granulomatous tumor | Partial | CPS | Frontal and temporal lobe resection | Yes | 7 | 203 | 300 | 56 | 135 | | 60 | 65 | 0 | 0
6 | M | 5 months | Malformation | LGS | TA, MYO, CPS | Frontal and occipital lobe resection | Yes | 4 | 1195 | 210 | 135 | 160 | | 50 | 50 | 50 | 50
7 | F | 5 months | Malformation | LGS | GTCS, ATO | Subtotal hemispherectomy, Anterior callosotomy | Yes | 19 | 25 | 23 | 8 | 16 | | 30 | 50 | 55 | 55
8 | M | 4 years 3 months | Malformation | Partial | CPS | Temproal and frontal lobe resection | Yes | 15 | 11 | 14 | 14 | | | 10 | 10
9 | M | 6 months | Cryptogenic | Generalized | ABS, MYO, GTCS | None | Yes | 6 | >100 | >100 | >100 | >100 | | 0 | 0 | 0 | 0
10 | M | 9 years | Malformation | Partial | CPS | None | Yes | 15 | 11 | 4 | 4 | 5 | | 75 | 75 | 75 | 75
11 | M | 4 months | Malformation | LGS | TA, CPS | None | Yes | 9 | 25 | 18 | 18 | | | 10 | 10
12 | F | 2 years | Malformation | Partial | CPS | None | Yes | 6 | 29 | 7 | 7 | 8 | | 0 | 25 | 25 | 25
13 | M | 6 years | Idiopathic | Generalized | TA, GTCS | Anterior callosotomy | | 16 | 40 | 35 | 35 | 30 | | 0 | 0 | 0 | 0
14 | F | 7 years 6 months | Unknown WM disease | Generalized | TA | None | Yes | 11 | 30 | 30 | 30 | | | 0 | 0
15 | F | 4 years | Malformation | Partial | SPS, CPS, TA | None | Yes | 17 | 100 | 80 | 80 | | | 25 | 30
16 | M | 4 years | ldiopathic | Generalized | GTCS | None | Yes | 8 | 115 | 60 | 70 | | | 25 | 25

ABS Absence seizures

CPS Complex partial seizures

GTCS Generalized tonic clonic seizures

PGS Primary generalized seizures

LGS Lennox Gastaut syndrome

MYO Myoclonic seizures

SME Severe myoclonic epilepsy of infancy

SCS Simple partial seizures

TA Tonic-axial seizures

WM White matter

Evidence Table 226. Percentage reduction in seizure frequency from baseline in studies of vagal nerve stimulation

| | | | | | | | | | | | Within Groups^a^ | | | Between Groups^b^
Reference | How Determined | Study Arm | N | Mean Pretreatment Absolute Seizure Frequency (SD) | Evidence of Selection Bias | Followup Time | Used Intent-to-Treat | N | Mean % Change From Baseline (SD) | Reported P = (Within Groups) | Reported P = (Between Groups) | % Change From Reduction (CI) | P = | Minimum Detectable Change (Power = 0.8; P = 0.05) | % Reduction From Baseline Difference (CI) | P = | Minimum Detectable Difference (Power = 0.8; P = 0.05)
RCTs performed in United States
Clinical Study EO5 Handforth (1999) | Patient or caregiver maintained seizure diary | High | 95 | 1.59 (3.26) per day Median: 0.51 (NR) per day | No | 3 months | Yes | 54 | -27.9 (34.3) | <0.0001 | 0.04 | 27.9 (18.5 to 37.65) | 0.00000 | NA | 12.70 (2.35 to 23.1) | 0.017 | NA
| | Low | 103 | 0.97 (1.13) per day Median: 0.49 (NR) per day | | | | 102 | -15.2 (39.2) | <0.0001 | | 15.2 (7.6 to 22.80) | 0.00090 | NA
Clinical Trial EO3 The VNS Group (1995) | Patient or caregiver maintained seizure diary | High | 54 | Median: 1.49 (Range: NR) per day | No | 14 wks | NA | 54 | -24.5 (CI: -14.1 to -34.9) | <0.01 | 0.01 | 24.5 (9.79 to 39.21) | 0.001094 | NA | 18.4 (4.5 to 32.3) | 0.009 | NA
| | Low | 60 | Median: 1.71 (Range: NR) per day | | | | 60 | -6.1 (CI: 3.6 to -15.8) | =0.21 | | 6.1 (-3.6 to 15.8) | 0.21780 | NA
Long-term followup of RCTs performed in United States
DiGiorgio (2000) Followup of Clinical Trial EO5 | Patient or caregiver maintained seizure diary | | 195 | Median: 0.54 per day | | 3 months | Yes | 195 | Median: -34.0 | <0.0001 | | NC | NC | NA
| | | | | | 6 months | Yes | 195 | Median: -45 | <0.0001 | | NC | NC | NA
Salinski (1996) Followup of Clinical Trial EO3 | Patient or caregiver maintained seizure diary | | 114 | Median: 0.79 (Range: NR) | | 3 months | | 114 | Median: -20.2 | <0.01 | | NC | NC | NA
| | | | | | 6 months | | | Median: -24.7 | <0.01 | | NC | NC | NA
| | | | | | 9 months | | | Median: -25.7 | <0.01 | | NC | NC | NA
| | | | | | 12 months | | | Median: -31.9 | <0.01 | | NC | NC | NA
Case series performed in United States
Chayasirisobhon (2001) | Patient or caregiver maintained seizure diary | | 24 | 175.3 (348.6) per month Median: 52.5 (Range: 6 to 1303) | | 6 months | | 24 | -55.1 (35.5) Median: -61.2 (-96.5 to +28.8) | | | 55.1 (30.5 to 79.70) | 0.000011 | NA
Hosain (2000) | Unclear | | 13 | 65.4 (39.4) per month Median: 75 (Range: 19 to 123) | | 6 months | NA | 13 | -56.6 (26.4) Median: -52 (0 to 93) | 0.04 | | 56.6 (36.30 to 76.90) | 0.00000 | NA
Clinical Trial EO4 Labar (1999) | Patient or caregiver maintained seizure diary | | 24 | Median: 48 (2 to 1650) per month | | 3 months | NA | 24 | Median: -46 (-100 to + 350%) | 0.004 | | NC | NC | NA
Case series performed outside United States
Aldenkamp (2001) | NR | | 16 | 3906 (NR) | | 6 months | | 16 | -26.9 (NR) | 0.005 | | NC | NC | NA
Hoppe (2001) | Patient or caregiver maintained seizure diary | | 36 | 42.0 (95.0) per month | | 6 months | NA | 36 | Median: -20% | NR | | NC | NC | NC
Boon (1999) | Patient or caregiver maintained seizure diary | | 20 | 23.4 (43.4) per month Median: 9.0 (Range: 2 to 200) | | Mean: 26.4 (SD: 14.4) | | 20 | -52.4 (37.5) Median: -38.75 (0 to -100) | NR | | 52.4 (28.55 to 76.25) | 0.000017 | NA
Parker (1999) | Patient or caregiver maintained seizure diary | | 15 | 72.5 (93.7) per month | | 6 months | NA | 15 | -19 (NR) | 0.083 | | NC | NC
Lundgren (1998) | Patient or caregiver maintained seizure diary | | 16 | Median: 35.5 (Range: 11 to 1195) | | 4 to 6 months | | 16 | -19.9 (50.2) | NR | | 19.9 (-4.7 to 44.5) | 0.11282
| | | | | | 10 to 12 months | | 16 | -26.3 (55.4) | NR | | 26.3 (-12.90 to 64.69) | 0.179357
| | | | | | 12 months | NA | 15 | -17 (NR) | 0.264 | | NC | NC

a Only applicable if individual patient data available

b Only applicable for studies that included ≥2 treatment arms

Evidence Table 227. Percentage change from baseline data in studies of vagal nerve stimulation (results of fixed effects meta-analysis of single treatment arm data)

Reference | N | Percentage Change From Baseline (CI) | P-Value | Standardized Residual | Outlier by Standardized Residual | Outlier by Q
Data from treatment arm of RCT
Clinical Study EO5 Handforth (1999) | 95 | 27.9 (18.5 to 37.65) | <0.000001 | -1.82 | Yes | No
Clinical Trial EO3 The VNS Group (1995) | 54 | 24.5 (9.79 to 39.21) | 0.001094 | -1.49 | No | No
Data from case series
Chayasirisobhon (2001) | 16 | 55.1 (30.5 to 79.7)) | 0.000011 | 1.72 | Yes | No
Hosain (2000) | 13 | 56.6 (36.3 to 76.9) | <0.000001 | 2.27 | Yes | Yes
Boon (1999) | 19 | 52.4 (28.55 to 76.25) | 0.000017 | 1.54 | No | No
Lundgren (1998) | 16 | 26.3 (-12.90 to 64.69) | 0.179357 | -0.42 | No | No
Test of Homogeneity of Fixed Effects Model ^b^ | | Q = 13.12 | 0.022256
Fixed Effects Summary Effect Size | | Not applicable due to statistically signficiant test for homogeneity
Random Effects Summary Effect Size^c^ | | 39.27 (26.58 to 51.97) | <0.000001

a By convention a positive effect size indicates treatment benefit.

b Critical Q (df = 5) = 11.07

c The random effects summary effect size is provided as an alternative when the fixed effects model has statistically significant heterogeneity.

Evidence Table 228. Univariate meta-regression analyses of percentage change from baseline data in studies of vagal nerve stimulation

Covariate | Intercept (CI) | P Value for Intercept | Coefficient (CI) | P Value for Coefficient | Qe = | P (Q_e_) =
Study RCT or not? | 26.86 (18.73 to 34.99) | <0.000001 | 25.07 (10.25 to 39.89) | 0.000911 | 2.124000 | 0.712965
Attrion rate | 40.55 (31.07 to 50.02) | <0.000001 | -5.06 (-10.50 to 0.38) | 0.068322 | 9.800000 | 0.043935
Followup time^a^ | 37.91 (30.18 to 45.63) | <0.000001 | 1.07 (-0.05 to 2.19) | 0.061703 | 9.630000 | 0.047143
Age at surgery^a^ | 40.12 (31.52 to 48.72) | <0.000001 | -1.35 (-2.59 to -0.11) | 0.033487 | 8.602000 | 0.071855
Proportion male | 12.21 (-29.62 to 54.03) | 0.567343 | 0.39 (-0.34 to 1.13) | 0.290400 | 12.01100 | 0.017270
Partial seizures only | 54.64 (33.28 to 75.99) | 0.000001 | -0.23 (-0.46 to 0.00) | 0.050799 | 9.288000 | 0.054290
Lennox-Gastaut only | 30.61 (23.25 to 37.97) | <0.000001 | 0.29 (0.07 to 0.50) | 0.008567 | 6.187000 | 0.185611

a Mean centered

Evidence Table 229. Difference in absolute seizure frequency in studies of vagal nerve stimulation

Reference | How Determined | Study Arm | N | Mean Pretreatment Seizure Frequency (SD) | Followup Time | Mean Posttreatment Seizure Frequency (SD) | Reported P = (Within Groups) | Reported P = (Between Groups) | Minimum Detecatble Change (Power = 0.8, P = 0.05) | Minimum Detectable Difference (Power = 0.8, P = 0.05) | Pre-Post Within Groups Summary Effect Size (Hedges'd)^a^ | Post-Treatment Between Groups Summary Effect Size (Hedges'd) | Individual Patient Data Availabale
Aldenkamp (2001) | NR | | 16 | 3906 (NR) | 6 months | 3172 (NR) | 0.005 | | NA | | NC | | No
Chayasirisobhon (2001) | Patient or caregiver maintained seizure diary | | 24 | 1.78 (0.61) log per month^b^ | 6 months | 1.24 (0.62) log per month^b^ | <0.001^c^ | | NA | | 0.88 (0.48 to 1.27)^e^ | | Yes
| | | | [Median: 52.5 (Range: 6 to 1303)] | | [Median: 14.5 (Range: 1 to 152)] | [<0.001^d^]
Hoppe (2001) | Patient maintained seizure diary | | 36 | 42.0 (95.0) per month | Mean: 8.0 (SD: 2.8) | 33.0 (86.3) per month | 0.09 | | NC | | NC | | No
Boon (1999) | Patient or caregiver maintained seizure diary | | 19^f^ | 14.0 (12.7) per month | Mean: 26.4 (SD: 14.4) | 9.1 (11.6) per month | 0.0003 | | NA | | 0.39 (0.21 to 0.58)^e^ | | Yes
| | | | [Median: 8.0 (Range: 2 to 40)] per month^f^ | | [Median: 3.0 (Range: 0 to 30)] per month^g^
Lundgren (1998) | Patient or caregiver maintained seizure diary | | 16 | 1.69 (0.51) log per month^c^ | 4 to 6 months | 1.54 (0.53) log per month^b^ | 0.073^c^ | | | | 0.27 (-0.02 to 0.56)^e^ | | Yes
| | | | [Median: 35.5 (Range: 11 to 1195)] | | [Median: 33.0 (0 to 300)] | [0.140^d^]
Clinical Trial EO3 | Patient or caregiver maintained seizure diary | High | 54 | Median: 0.73 (Range: NR) per day | 12 weeks | Median: 0.42 (Range: NR) per day | <0.01 | 0.02 | NA | NA | NC | NC | No
The VNS Group (1995) | | Low | 60 | Median: 0.82 (Range: NR) per day | | Median: 0.80 (Range: NR) per day | 0.19 | | NC | | NC
| | | | | 10 to 12 month | 1.48 (0.46) log per month^b^ | 0.030c | | NA | | 0.41 (0.05 to 0.77)^e^
| | | | | | [Median: 33. (0 to 135)] | [0.041^d^]

a Only calculated if individual patient data presented

b Calculated from raw data. Data are log transformed because pre-treatment data were non-normally distributed (Kolmogorov-Smirnov test)

c Based on a paired t-test of log transformed seizure frequency data

d Based on Wilcoxon Rank-Paired Test

e Calculated from raw data using method of Dunlap (1996)

f Does not include patient 13 who was excluded from analysis because her seizures only occurred in clusters

g Calculated from individual patient data presented by Boon (199)

NC = Not calculated. Data not sufficient to calculate an effect size (missing dispersion data, OR, data were presented as median and range, OR, individual patients data not presented)

Evidence Table 230. Proportion of patients seizure-free in studies of vagal nerve stimulation.

Reference | How Determined | N | Seizure Frequency at Baseline (SD) | Followup Time | Number of Patients Seizure Free Posttreatment (%) | Used an Intent-to-Treat Doctrine | Reported P = (Within Groups) | Pre-Post Effect Size (Cohen's h (CI)) | Minimum Detectable Change (Power = 0.8; P = 0.05)
Case series performed outside United States
Boon (1999) | Patient or caregiver maintained seizure diary | 20 | 23.4 (43.4) per month [Median: 9.0 (Range: 2 to 200)] | Mean: 26.4 (SD: 14.4) months | 6 (30.0) | Yes | NR | 1.16 (0.54 to 1.78) | NA

NA Not applicable

NR Not reported

Evidence Table 231. Proportion of patients with >50% reduction in seizure frequency in studies of vagal nerve stimulation

| | | | | | | | | | | Calculated by ECRI^a^
Reference | How Determined | Study Arm | N | Mean Pretreatment Absolute Seizure Frequency (SD) | Evidence of Selection Bias | Followup Time | Used Intent-To-Treat Doctrine | Number of Patients With >50% Reduction in Seizure Frequency (%) | Reported P = (Within Groups) | Reported P = (Between Groups) | Minimum Detectable Change (Power = 0.8; P = 0.05) | Within Groups Summary Effect Size, Cohens'h (CI) | Minimum Detectable Difference (Power = 0.8; P = 0.05) | Between Groups Summary Effect Size, Cohens'h (CI)
RCTs performed in United States
Clinical Study EO5 Handforth (1999) | Patient or caregiver maintained seizure diary | High | 95 | 1.29 (3.26) per day | No | 3 months | No^d,e^ | 22 (23.1) | NR | 0.172 ^f^ | NC | 1.00 (0.72 to 1.29) | | 0.19 (-0.09 to 0.47)
| | Low | 103 | 0.97 (1.13) per day | | | | 16 (15.5) | NR | | | 0.81 (0.54 to 1.08)
Clinical Trial EO3 The VNS Group (1995) | Patient or caregiver maintained seizure diary | High | 54 | Median: 0.73 (Range: NR) per day | No | 12 weeks | Yes | 17 (31.5) | NR | 0.02^g^ | NC | 0.91 (0.81 to 1.57) | NA | 0.44 (0.08 to 0.81)
| | Low | 60 | Median: 0.82 (Range: NR) per day | | | | 8 (13.3) | NR | | | 0.75 (0.39 to 1.11)
Long-term followup of RCTs performed in United States
DiGiorgio (2000) Followup of Clinical Trial EO5 | Patient or caregiver maintained seizure diary | | 195 | Median: 0.54 per day | | 3 months | Yes | 66 (33.8) | NR | | NA | 1.24 (1.04 to 1.44)
| | | | | | 6 months | | 68 (34.9) | NR | | NA | 1.26 (1.07 to 1.47)
Salinski (1996) Followup of Clinical Trial EO3 | Patient or caregiver maintained seizure diary | | 114 | Median 0.79 per day | | 3 months | Yes | 28 (24.6) | NR | | NA | 1.04 (0.78 to 1.30)
| | | | | | 6 months | | 24 (21.1) | NR | | NA | 0.95 (0.69 to 1.22)
| | | | | | 9 months | | 25 (21.9) | NR | | NA | 0.98 (0.72 to 1.23)
| | | | | | 12 months | | 31 (27.2) | NR | | NA | 1.10 (0.84 to 1.36)
Case series performed in United States
Chayasirisobhon (2001) | Patient or caregiver maintained seizure diary | | 24 | [Median: 52.5 (Range: 6 to 1303) per months] | | 6 months | Yes | 15 (62.5) | NR | | NA | 1.82 (0.57 to 1.26)
Hosain (2000) | Unclear | | 13 | 65.4 (39.4) per month[Median: 75 (Range: 19 to 123) per months] | | 6 months | NA^e^ | 7 (53.9) | NR | | NA | 1.65 (0.88 to 2.42)
| Patient or caregiver maintained seizure diary | | 25 | [Median: 48 (Range: 2 to 1650) per months] | | 3 months | Yes | 11 (45.8) | NR | | NA | 1.45 (0.90 to 2.01)
Case series performed outside United States
Aldenkamp (2001) | NR | | 16 | 3906 (NR) | | 6 months | Yes | 4 (25.0) | NR | | NA | 1.05 (0.35 to 1.74)
Hoppe (2001) | Patient maintained seizure diary | | 36 | 42.0 (95.0) per month | | Mean: 8.0 (SD: 2.8) | Yes | 11 (30.6) | NR | | NA | 1.17 (0.71 to 1.63)
Ben-Menachem (1999) | Patient or caregiver maintained seizure diary (n = 57)Unknown (n = 7) | | 64 | NR | | Mean: 20 (Range: 3 to 64 months) | Yes | 29 (46.0) | NR | | NA | 1.48 (1.13 to 1.82)
Boon (1999) | Patient or caregiver maintained seizure diary | | 20 | 23.4 (43.4) per month[Median: 9.0 (Range: 2 to 200)] | | Mean: 26.4 (SD: 14.4) | Yes | 8 (40.0) | NR | | NA | 1.37 (0.75 to 1.99)
Parker (1999) | Patient or caregiver maintained seizure diary | | 16 | [Median:26.0 (Range: 4 to 288)] | | | Yes | 4 (25.0) | NR | | NA | 1.05 (0.35 to 1.74)
Lundgren (1998) | Patient or caregiver maintained seizure diary | | 16 | [Median: 35.5 (Range: 11 to 1195)] | | 4 to 6 months | Yes | 5 (31.3) | NR | | NA | 1.19 (0.49 to 1.88)
| | | | | | 10 to 12 months | Yes | 6 (37.5) | NR | | NA | 1.32 (0.63 to 2.01)

a All calculations performed using intent-to-treat doctrine

b 1-tailed 2-sample arcsine binomial power analysis

c Between groups if a controlled trial. If case series based on comparison with a synthetic control group of equal size where no patients spontaneously has a >50% reduction in seizure frequency from baseline

d Does not include one patient who was whthdrawn during ramp-up stage dur to uniterruptible seizure dairy

e Does not include one patient who withdrew consent during ramp up stage

f Chi-Squared test

g Fishers exact test

h Not an outcome measure reported by Hosain et al.. Data were extracted from individual patient data presented in Evidence Table

I Not applicable because this was a case series with no control group

NA = Not applicalbe

NC = Not calculated

NR = Not reported

Evidence Table 232. Quality of life in studies of vagal nerve stimulation

| | | Treatment Arm | | | Control Arm
| | | | Outcome Mean (SD) | | | Outcome Mean (SD) | | Reported P Value | | ECRI Calculated Effect Sizes Hedges'd (CI)
Reference | Instrument and Followup Time | Domain | N | Pretreatment | Posttreatment | N | Pretreatment | Posttreatment | Within Groups | Posttreatment Between Groups | Pretreatment Between Groups | Posttreatment Between Groups
Clinical Trial EO5 (Data extracted from Dodrill 2001) | QOLIE-31 6 months | Seizure worry | 78 | 51.9 (26.8) | 60.7 (23.7) | 82 | 50.9 (25.2) | | NR | 0.261 | 0.04 (-0.27 to 0.35) | 0.15 (-0.16 to 0.46)
| | Overall QoL | | 67.0 (14.7) | 67.9 (13.4) | | 62.1 (15.3) | | NR | 0.991 | 0.32 (0.01 to 0.64) | 0.26 (-0.05 to 0.57)
| | Emotional well-being | | 68.3 (17.3) | 71.5 (16.3) | | 65.0 (19.3) | | NR | 0.316 | 0.18 (-0.13 to 0.49) | 0.30 (-0.01 to 0.61)
| | Energy/fatigue | | 57.1 (19.2) | 58.6 (18.9) | | 54.7 (19.7) | | NR | 0.313 | 0.12 (-0.19 to 0.43) | 0.24 (-0.07 to 0.55)
| | Cognitive function | | 53.4 (23.2) | 59.5 (21.9) | | 57.6 (21.9) | | NR | 0.279 | -0.19 (-0.50 to 0.13) | -0.03 (-0.34 to 0.28)
| | Medication effects | | 54.1 (31.2) | 58.5 (30.2) | | 57.9 (29.5) | | NR | 0.990 | -0.12 (-0.43 to 0.19) | -0.19 (-0.50 to 0.12)
| | Social functioning | | 53.2 (24.6) | 59.1 (24.0) | | 54.6 (22.0) | | NR | 0.283 | -0.06 (-0.37 to 0.25) | 0.14 (-0.17 to 0.45)
| | Overall score | | 58.1 (15.0) | 62.0 (14.1) | | 57.8 (14.3) | | NR | 0.274 | 0.02 (-0.29 to 0.33) | 0.15 (-0.17 to 0.46)
| SF-36 6 months | Physical function | 78 | 83.3 (17.1) | 89.7 (11.7) | 82 | 83.7 (18.4) | | NR | 0.105 | -0.02 (-0.33 to 0.29) | 0.28 (-0.03 to 0.59)
| | Role physical | | 68.5 (34.3) | 76.2 (27.2) | | 62.2 (33.0) | | NR | 0.037 | 0.19 (-0.12 to 0.50) | 0.40 (0.09 to 0.71)
| | Bodily pain | | 71.9 (22.4) | 72.7 (21.0) | | 68.41 (25.0) | | NR | 0.376 | 0.15 (-0.16 to 0.46) | 0.27 (-0.04 to 0.58)
| | General health | | 66.2 (19.3) | 69.3 (16.3) | | 61.9 (21.5) | | NR | 0.457 | 0.21 (-0.10 to 0.52) | 0.28 (-0.04 to 0.59)
| | Vitality | | 57.1 (19.2) | 58.6 (18.9) | | 54.7 (19.7) | | NR | 0.313 | 0.12 (-0.19 to 0.43) | 0.24 (-0.04 to 0.55)
| | Social function | | 68.9 (27.2) | 75.5 (19.7) | | 68.0 (21.3) | | NR | 0.473 | 0.04 (-0.27 to 0.35) | 0.23 (-0.08 to 0.54)
| | Role emotional | | 76.1 (27.4) | 85.9 (21.5) | | 72.7 (32.0) | | NR | 0.026 | 0.11 (-0.20 to 0.42) | 0.42 (0.10 to 0.73)
| | Mental health | | 68.3 (17.3) | 71.5 (16.3) | | 65.0 (19.3) | | NR | 0.316 | 0.18 (-0.13 to 0.49) | 0.30 (-0.01 to 0.62)
| | Summary: Physical | | 48.3 (9.4) | 49.9 (6.84) | | 47.1 (6.8) | | NR | 0.127 | 0.15 (-0.16 to 0.46) | 0.34 (0.03 to 0.65)
| | Summary: Emotional | | 45.4 (10.1) | 48.1 (9.12) | | 44.3 (10.8) | | NR | 0.202 | 0.10 (-0.21 to 0.41) | 0.31 (-0.01 to 0.62)
Ergene (2001) | QOLIE-10^a^ | Overall score | 17 | 32.8 (standard error: 2.0)
| 2 weeks | | | | 26.0 (9.5) | | | | <0.01
| 6 weeks | | | | 25.6 (9.9) | | | | <0.01
| 12 weeks | | | | 25.7 (9.9) | | | | <0.01
| 24 weeks | | | | 24.3 (8.7) | | | | <0.01
| 48 weeks | | | | 24.9 (14.8) | | | | <0.01

a This is a short form (10-item) version of QOLIE-31, which is in turn a short-form version of QOLIE-89.

NC Not calculated

QOLIE Quality of Life in Epilepsy

SF-36 Short-Form 36

Evidence Table 233. Adverse events in studies of vagal nerve stimulation

| | Treatment Group | | Control Group
Reference | Adverse Event | N | Patients Affected (%) | N | Patients Affected (%) | Reported P = (Between Groups) | Effect Size Cohen's h (CI)
RCTs performed in United States
Clinical Study EO5 Handforth (1999) | Voice alteration | 95 | 63 (66.3) | 103 | 31 (30.1) | 0.001 | 0.74 (0.46 to 1.02)
| Cough | | 43 (45.3) | | 44 (42.7) | ns | 0.05 (-0.23 to 0.33)
| Pharyngitis | | 33 (34.7) | | 26 (25.2) | ns | 0.21 (-0.07 to 0.49)
| Pain | | 27 (28.4) | | 31 (30.1) | ns | -0.04 (-0.32 to 0.24)
| Dyspnea | | 24 (25.3) | | 11 (10.7) | 0.007 | 0.39(0.11 to 0.67)
| Headache | | 23 (24.2) | | 24 (23.3) | ns | 0.02(-0.26 to 0.30)
| Dyspepsia | | 17 (17.9) | | 13 (12.6) | ns | 0.15(-0.13 to 0.43)
| Vomiting | | 17 (17.9) | | 14 (13.6) | ns | 0.12(-0.16 to 0.40)
| Paresthesia | | 17 (17.9) | | 26 (25.2) | ns | -0.18(-0.46 to 0.10)
| Nausea | | 14 (14.7) | | 21 (20.4) | ns | -0.15(-0.43 to 0.13)
| Accidental injury | | 12 (12.6) | | 13 (12.6) | ns | 0.00(-0.28 to 0.28)
| Fever | | 11 (11.6) | | 19(18.4) | ns | -0.19(-0.47 to 0.09)
| Infection | | 11 (11.6) | | 12 (11.7) | ns | 0.00(-0.28 to 0.28)
Clinical Trial EO3 The VNS Group (1995) | Hoarseness/voice change | 54 | 20 (37.2) | 60 | 8 (13.3) | <0.01 | 0.56 (0.19 to 0.93)
| Throat pain | | 6 (11.0) | | 7 (11.7) | 1.00 | -0.02 (-0.39 to 0.35)
| Coughing | | 4 (7.4) | | 5 (8.3) | 1.00 | -0.03 (-0.40 to 0.33)
| Dyspnea | | 3 (5.6) | | 1 (1.7) | 0.34 | 0.22 (-0.15 to 0.58)
| Paresthesia | | 3 (5.6) | | 2 (3.3) | 0.67 | 0.11(-0.26 to 0.48)
| Muscle pain | | 3 (5.6) | | 1 (1.7) | 0.34 | 0.22 (-0.15 to 0.58)
| Headache | | 1 (1.8) | | 5 (8.3) | 0.21 | -0.31(-0.68 to 0.05)
Long-term followup of RCTs performed in United States
Salinski (1996) Followup of Clinical Trial EO3 | Accidental injury | 195 | 30 (15.4)
| Cough, increased | | 29 (14.9)
| Voice alteration | | 107 (54.9)
| Dyspnea | | 25 (12.8)
| Pain | | 30 (15.4)
| Parasthesia | | 30 (15.4)
| Headache | | 31 (15.9)
| Pharyngitis | | 20 (10.3)
| Depression | | 10 (5.1)
| Infection | | 12 (6.2)
Salinski (1996)Followup of Clinical Trial EO3 | Device malfunction | 114 | 2 (1.8)
| Myocardial infaction | | 1 (0.9)
Case series performed in the United States
Chayasirisobhon (2001) | Vocal cord paralysis | 24 | 2 (8.3)
| Hoarseness | | 12 (50.0)
Ergene (2001) | Throat irritation | 17 | 4 (23.5)
| Difficulty breathing | | 1 (5.9)
| Difficulty speaking | | 1 (5.9)
| Epigastric discomfort | | 1 (5.9)
| Increased snoring | | 1 (5.9)
Hosain (2000) | Hoarseness | 13 | 3 (23.1)
| Excessive coughing | | 3 (23.1)
| Infection | | 1(7.7)
Clinical Trial EO4 Labar (1999) | Incisional parasthesias | 24 | 2 (8.3)
| Incisional pain | | 2 (8.3)
| Cough | | 6 (25.0)
| Abdominal pain | | 2 (8.3)
| Anorexia | | 1 (4.2)
| Hiccups | | 1 (4.2)
| Dysphagia | | 1 (4.2)
| Emesis | | 1 (4.2)
| Fatigue | | 1 (4.2)
Case series performed outside United States
Ben-Menachem (1999) | Hoarseness | 64 | 11 (17.2)
| Dyspnea | | 1 (1.6)
| Cord paresis | | 1 (1.6)
| Throat pain | | 3 (4.7)
| Generator placement problem | | 1 (1.6)
Boon (1999) | Throat parestaesias | 20 | 1 (5.0)
| Hoarseness or voice change | | 4 (20.0)
| Exercise dyspnea | | 1 (5.0)
Lundgren (1998) | Aspiration | 16 | 2 (12.5)
| Hoarseness | | 6 (37.5)
| Throat pain | | 1 (6.3)
| increased salivation | | 2(12.5)
| Tiredness | | 2(12.5)
| electrical line fracture | | 1 (6.3)
| Premature current failure | | 5(31.3)

Evidence Table 234. Mortality in studies of vagal nerve stimulation

| Treatment Group | | | Control Group
Reference | N | Number of Deaths (%) | Cause of Death | N | Number of Deaths (%) | Cause of Death
RCTs performed in United States
Clinical Study EO5 Handforth (1999) | 95 | 0 (0.0) | NA | 103 | 0 (0.0)
Clinical Trial EO3 The VNS Group (1995) | 54 | 0 (0.0) | NA | 60 | 0 (0.0)
Followup studies of RCT's performed in the United States (case-series)
DiGiorgio (2000) Followup of Clinical Trial EO5 | 195 | 2 (1.0) | 1 patient: Pneumonia, sepsis and respiratory failure related to untreated infection. Authors state that death was a direct result of VNS implantation and/or use.
| | | 1 patient: Suden unexpected death
Salinski (1996) Followup of Clinical Trial EO3 | 114 | 2 (1.8) | 1 patient: Thrombotic thrombocytopenic purpura
| | | 1 patient: Drowning.
| | | Authors state that deaths were unlikely to be related to VNS.
Case series performed in the United States
Chayasirisobhon (2001) | 24 | 0 (0.0)
Ergene (2001) | 17 | 0 (0.0)
Hosain (2000) | 13 | 0 (0.0)
Clinical Trial EO4 Labar (1999) | 24 | 0 (0.0)
Case series performed outside of the United States
Aldenkamp (2001) | 16 | 0 (0.0)
Hoppe (2001) | 36 | 0 (0.0)
Ben-Menachem (1999) | 64 | 4 (6.3) | 3 patients: Status epilepticus
| | | 1 patient: Sudden unexpected death
Boon (1999) | 20 | 0 (0.0)
Parker (1999) | 16 | 0 (0.0)
Lundgren (1998) | 16 | 0 (0.0)

Evidence Table 235. Articles addressing the ketogenic diet excluded for quality reasons

Study | Reason for Exclusion
Pulsifier (2001) | The aim of this study was to evaluate effects of ketogenic diet on behavior and cognitive function. Study only evaluated patients who had successfully completed 1 year of treatment. According to the authors 40% of patients who started ketogenic diet had discontinued it by 1 year due to treatment disatisfaction. This study provides a highly biased estimate of the effects of ketogenic diet on behavior and cognitive function because it is based entirely on data from patients who are satisfied with the treatment.
Mak (1998) | Although authors state that outcome data were recorded at 1 month followup, they refer to a table that states that seizure frequency data was recorded at least three months after discontinuation of the ketogenic diet in 10 of the 13 patients included in study. This flaw precludes determining whetehr there was a causal relationship between diet and outcome.
Edelstein (1996) | Efficacy and adverse event outcome data were poorly described. Changes in seizure frequency were only subjectively described (e.g. “deminished seizure activity occurred in 16 patients.” No empirical data presented).
Schwartz (1988) | 59 patients allocated to one of three ketogenic diets (Classical 4:1, MCT, modified MCT). If seizure control was unsatifactory or if major diet problems were encountered, patients were offered the option to change to alternative diet. If patient opted to try another diet, the child was readmitted, existing diet discontinued and new diet commenced. Four patients withdrew. Eight patients opted to try a new diet and data from both diets in the same patient were included in analysis resulting in an assessment of efficacy of treatment based on 63 studies originating from 55 patients. Data for three separate diets were not analyzed seperately but instead were combined leading to double counting of data from some patients. Double counting of data from a single patient is a fatal flaw.

## Question 6

Which social, psychological or psychiatric services for treatment-resistant epilesy lead to, or can be expected to lead to improved patient outcomes?

Evidence Table 236. Excluded studies of nondrug, nonsurgical treatments for treatment-resistant epilepsy

Reference | Intervention | Reason for Exclusion
Uhlmann (2001) | EEG Biofeedback and End-tidal CO2 biofeedback | Patients were treated with one of two interventions. Outcomes were reported for all patients combined, regardless of treatment group.
Andrews (2000) | Comprehensive multidisciplinary neurobehavioral treatment | Fewer than five studies reported on this intervention.
Reiter (2000) | Comprehensive multidisciplinary neurobehavioral treatment | Patients changed their AED regimen during treatment, making this trial subject to a strong extraneous events bias. Therefore, outcomes cannot be separately associated with either the result of the training or the change in AEDs.
Sidorenko (2000) | Medical Resonance Therapy Music | Fewer than five studies reported on this intervention.
Kotchoubey (1999) | EEG Biofeedback | Fewer than five studies reported on this intervention.
Kotchoubey (1999) | EEG Biofeedback | Fewer than five studies reported on this intervention.
Schmid-Schonbein (1998) | Self-control training | Patients changed their AED regimen during treatment, making this trial subject to a strong extraneous events bias. Therefore, outcomes cannot be separately associated with either the result of the training or the change in AEDs.
Kotchoubey (1996) | EEG Biofeedback | Patients received behavioral therapy during treatment, making this trial subject to a strong extraneous events bias. Therefore, outcomes cannot be separately associated with either the result of the biofeedback or the behavioral therapy.
Panjwani (1996) | Sahaja yoga | Fewer than five studies reported on this intervention.
Deepak (1994) | Meditation | Fewer than five studies reported on this intervention.
Eriksen (1994) | Physical Exercise | Fewer than five studies reported on this intervention.
Becu (1993) | Self-Help Group (Group Therapy) | Fewer than five studies reported on this intervention.
Rockstroh (1993) | EEG Biofeedback | Fewer than five studies reported on this intervention.
Usiskin (1993) | Counseling | Fewer than five studies reported on this intervention.
Andrews (1992) | Comprehensive multidisciplinary neurobehavioral treatment | Fewer than five studies reported on this intervention.
Puskarich (1992) | Progressive muscle relaxation | Fewer than five studies reported on this intervention.
Fried (1990) and Fried (1993) | End-Tidal CO_2_ Biofeedback | Fewer than five studies reported on this intervention.
Gillham (1990) | Comprehensive multidisciplinary neurobehavioral and psychological treatment | Fewer than five studies reported on this intervention.
Nakken (1990) | Physical Exercise | Fewer than five studies reported on this intervention.
Whitman (1990) | Progressive muscle relaxation | Fewer than five studies reported on this intervention.
Denio (1989) | Physical Exercise | Fewer than five studies reported on this intervention.
Lantz (1988) | EEG Biofeedback | Fewer than five studies reported on this intervention.
Dahl (1987) | Contingent relaxation with neurobehavioral training | Fewer than five studies reported on this intervention.
Fraser (1986) | Vocational Services | Fewer than five studies reported on this intervention.
Virudhagirinathan (1986) | Systematic Desensitization | Fewer than five studies reported on this intervention.

## Question 7

What characteristics of treatment-resistant epilepsy interfere with ability to obtain and maintain employment, or attend and perform well in school?

Evidence Table 237. Excluded studies of employment and schooling

Reference | Reason for Exclusion
Clemmons (1987) | No data are reported on patient characteristics. The number of patients who are treatment-resistant cannot be determined, and other factors such as the presence of severe neurological disorders are not considered.
Fraser (1986) | This study involved highly specialized patients: those with suspected brain impairment who enrolled in an intensive vocational intervention program. The reported data are unlikely to be generalizable to the greater population of patients with treatment-resistant epilepsy.

## Question 8

What is the mortality rate in patients with treatment-resistant epilepsy?

Evidence Table 238. Excluded studies of mortality rate in patients with treatment-resistant epilepsy

Reference | Reason for Exclusion
Dashieff (1991) | Length of followup not reported, therefore person-years of exposure cannot be determined and mortality rate cannot be calculated.
Tudehope (1988) | Article does not provide enough information to determine whether patients had treatment-resistant epilepsy. Also not clear that all patients had epilepsy.
Derby (1996) | Patients with epilepsy identified through AED prescriptions in databases rather than by clinical diagnosis. Since AEDs may be prescribed for conditions other than epilepsy, this increases the likelihood of including patients who were never diagnosed with epilepsy.
Tennis (1995) | Patients with epilepsy identified through AED prescriptions in databases rather than by clinical diagnosis. Since AEDs may be prescribed for conditions other than epilepsy, this increases the likelihood of including patients who were never diagnosed with epilepsy.

Evidence Table 239. Design and conduct of included studies mortality rate in patients with treatment-resistant epilepsy

Reference | Country | N | Epilepsy Diagnosis Determined | Study Design | Standardized Mortality Ratio Reported (or Calculable) | Standardized Mortality Ratio Adjusted For Factors Other Than Age | Compliance Reported
Physician's desk reference Gabapentin trial data (2001) | United States | 2203 | Clinical diagnosis | Retrospective case series | No | Not applicable | No
Racoosin (2001) | United States | 9144 | Clinical diagnosis | Retrospective case series^a^ | Yes | Gender (only for male vs. female standardized mortality ratio) | No
Wong (2001) | United Kingdom | 1050 | Clinical diagnosis | Retrospective double cohort | Yes | Gender | Yes
Annegers (2000) | United States | 1819 | Clinical diagnosis | Retrospective double cohort | Yes | Gender | Not applicable
Hennessy (1999) | United Kingdom | 305 | Clinical diagnosis | Retrospective double cohort | Yes | None | Not applicable
Sperling (1999) | United States | 393 | Clinical diagnosis | Prospective double cohort | Yes | Gender | Not applicable
Vickrey (1997) | United States | 248 | Clinical diagnosis | Retrospective case series | No | Not applicable | Not applicable
Leestma (1997) | United States, United Kingdom, Europe, Australia, South Africa | 4700 | Clinical diagnosis | Retrospective case series | No | Not applicable | No
Leppik (1995) | United States, Europe, Australia | 2600 | Clinical diagnosis | Retrospective case series | No | Not applicable | No
Klenerman (1993) | United Kingdom | Reported as person-years | Clinical diagnosis | Retrospective double cohort | Yes | Gender | No

a ECRI was able to calculate standardized mortality ratios using a general reference population. For our purposes, this study became a retrospective double cohort study.

Evidence Table 240. Overall mortality rates in studies of treatment-resistant epilepsy patients Comparison to mortality rates of general population in studies with reported standardized mortality ratios or from which standardized mortality ratios could be calculated

| | | | | Overall Mortality Rate Per 1000 Person-Years (CI)
Reference | Country | N | Treatment | Subgroup | Study Population | General Reference Population | Standardized Mortality Ratio (CI)
Racoosin (2001) | United States | 9144 | AEDs | All patients | 9.11 (7.64–10.85)^c^ | 2.53^a^ | 3.60 (2.99–4.29)^d^
| | | | Male | 11.3 (9.2–13.9) | 3.20^a^ | 3.6 (2.9–4.4)^d^
| | | | Female | 6.1 (4.4–8.5) | 1.75^a^ | 3.5 (2.5–4.8)^d^
| | | | Ages:
| | | | 1–14 | 4.1 (1.7–9.8) | 0.25^a^ | 16.4 (4.5–41.5)^d^
| | | | 15–34 | 7.2 (5.4–9.5) | 1.01^a^ | 7.1 (5.3–9.6)^d^
| | | | 35–54 | 9.6 (7.2–12.9) | 3.23^a^ | 3.0 (1.4–5.5)^d^
| | | | 55–72 | 32.1 (21.5–47.8) | 14.56^a^ | 2.2 (1.5–3.1)^d^
Wong^f^ (2001) | United Kingdom | 1050 | AEDs | All patients | 16.6 (12.1–22.6)^c^ | 1.59^c^ | 10.4 (7.1–13.7)
Annegers (2000) | United States | 1819 | Vagal nerve stimulation | All patients | 7.87 (5.34–11.59)^c^ | 2.18^a^ | 3.62 (2.34–5.35)
| | | | Male | 8.1 | | 2.80 (1.53–4.70)
| | | | Female | 7.7 | | 5.79 (2.89–10.37)
| | | | Ages:
| | | | <25 | | | 11.4 (4.9–22.5)
| | | | 25–34 | | | 6.1 (2.6–11.9)
| | | | ≥35 | | | 1.8 (0.8–3.5)
Hennessy (1999) | United Kingdom | 305 | Surgery | All patients | 7.33 (4.75–11.29)^c^ (includes some patients seizure-free after surgery) | 1.62 | 4.52 (2.76–6.99)e
Sperling (1999) | United States | 194^b^ | Surgery | All patients | 13.72 (7.68–24.41)^c^ | 2.90^a^ | 4.69 (2.34–8.41)e
Klenerman (1993) | United Kingdom | Not reproted | AEDs | All patients | 33.31 (27.78–39.90)^c^ | 17.19^c^ | 1.94 (1.60–2.34)e

a Calculated by ECRI from U.S. Census Bureau, Statistical Abstract of the United States, 2000.

b This study followed a total of 393 patients after surgery; 199 became seizure free and were not included in the mortality analysis (none of these patients died).

c Calculated by ECRI from Mortality Statistics (England and Wales, 1999).

d Calculated by ECRI

e 95% CI calculated by ECRI

f The study by Wong (2001) reported mortality data for groups of patients receiving different AEDs (lamotrigine, gabapentin, and/or vigabatrin). Because many patients received more than one of these drugs, they were included in more than one group. Therefore, we have evaluated only the patients receiving lamotrigine (the largest group, n = 1,050) to avoid double counting.

Evidence Table 241. Sudden unexpected death rates in studies of treatment-resistant epilepsy patients

Reference | Country | N | Treatment | Subgroup | Sudden Unexpected Death Rate Per 1000 Person-Years (CI) | Percentage of Total Deaths Represented by SUDEP
Physician's desk reference (PDR) Gabapentin trial data (2001) | United States | 2203 | AEDs | All patients | 3.80 (1.93–7.49)^a^ | Cannot be calculated
Racoosin (2001) | United States | 9144 | AEDs | All patients | 3.82 (2.91–5.00)^a^ | 41.9%
| | | | Male | 4.4 (3.2–6.2)
| | | | Female | 3.0 (1.8–4.8)
| | | | Ages:
| | | | 1–14 | 2.4 (0.8–7.6)
| | | | 15–34 | 3.2 (2.1–4.8)
| | | | 35–54 | 4.9 (3.3–7.4)
| | | | 55–72 | 5.3 (2.0–14.2)
Wong (2001) | United Kingdom | 1050 | AEDs | All patients | 7.64 (4.84–12.05)^a^ | 46.1%
Annegers (2000) | United States | 1819 | Vagal nerve stimulation | All patients | 4.09 (2.39–6.99)^a^ | 52%
Sperling (1999) | United States | 194 | Surgery | All patients | 7.49 (3.44–16.24)^a^ | 54.5%
Hennessy (1999) | United Kingdom | 305 | Surgery | All patients | 2.20 (1.01–4.79)^a^ | 30%
Leestma (1997) | United States, United Kingdom, Europe, Australia, South Africa | 4700 | AEDs | All patients | 3.13 (1.98–4.95)^a^ | 40%
Leppik (1995) | United States, Europe, Australia | 2600 | AEDs | All patients | 3.87 (1.87 to 7.96)^a^ | 29.2%
Klenerman (1993) | United Kingdom | NR | AEDs | All patients | 2.06 (1.00–4.25)^a^ | 6.2%

a Calculated by ECRI

Evidence Table 242. Drowning rates among patients with treatment-resistant epilepsy

| | | | Drowning Rate Per 1000 Person-Years (All Patients)
Reference | Country | N | Treatment | Study Population Rate (CI)^a^ | General Reference Population Rate | Crude Mortality Ratio (CI)^b^ | Highest Age-Specific Rate in General Reference Population | Crude Mortality Ratio (CI)^c^
Hennessy (1999) | United Kingdom | 305 | Surgery | 1.10 (0.37–3.23) | 0.005^e^ | 214 (43.07–626.11) | 0.0196^e^ | 56.18 (11.29–165.39)
Leestma (1997) | United States, United Kingdom, Europe, Australia, South Africa | 4700 | AEDs | 0.35 (0.10–1.27) | 0.013^d^ | 26.67 (3.00–96.29) | 0.0196^e^ | 17.70 (1.99–63.91)
Vickrey (1997) | United States | 248 | Surgery or AEDs | 0.67 (0.12–3.80) | 0.013^d^ | 51.81 (0.68–259.67) | 0.0196^r^ | 34.48 (0.45–170.14)
Klenerman (1993) | United Kingdom | NR (reported as patient-years) | AEDs | 0.59 (0.16–2.15) | 0.005^e^ | 117.65 (13.21–424.80) | 0.0196^e^ | 30.30 (3.40–109.42)

a Calculated by ECRI

b Study population rate / general reference population rate, calculated by ECRI

c Study population rate / highest age-specific rate in general reference population, calculated by ECRI

d From U.S. Census Bureau, Statistical Abstract of the United States, 2000

e Calculated by ECRI from Mortality Statistics (England and Wales, 1999)

Evidence Table 243. Accident-related mortality rates among patients with treatment-resistant epilepsy

| | | | Accident-Related Mortality Rate Per 1000 Person-Years
Reference | Country | N | Treatment | Study Population Rate (CI)^a^ | General Reference Population Rate | Crude Mortality Ratio (CI)^b^ | Highest Rate in General Reference Population | Crude Mortality Ratio (CI)^c^
Racoosin (2001) | United States | 9144 | AEDs | All patients: 1.47 (0.95–2.27 | Age-adjusted: 0.29^d^ | 5.06 (3.09–7.83) | 0.92^d^ | 1.60 (0.98–2.47)
Hennessy (1999) | United Kingdom | 305 | Surgery | All patients: 1.47 (0.57–3.76) (includes some patients seizure-free after surgery) | All patients: 0.21^e^ | 6.98 (1.86–17.88) | 0.25^e^ | 5.87 (1.57–15.02)
Sperling (1999) | United States | 194 | Surgery | All patients: 1.25 (0.22–7.03)^a^ | Age-adjusted:0.29^d^ | 4.31 (0.06–23.97) | 0.37^d^ | 3.37 (0.04–18.73)
Leestma (1997) | United States, United Kingdom, Europe, Australia, South Africa | 4700 | AEDs | All patients: 0.52 (0.18–1.53) | Age-adjusted: 0.29^d^ | 1.80 (0.36–5.26) | 0.92^d^ | 0.57 (0.11–1.67)
Leppik (1995) | United States, Europe, Australia | 2600 | AEDs | All patients: 1.66 (0.56 to 4.86) | Age adjusted: 0.29^d^ | 5.71 (1.15–16.70) | 0.92^d^ | 1.80 (0.36–5.26)
Klenerman (1993) | United Kingdom | NR | AEDs | All patients: 0.88 (0.30–2.60) | All patients: 0.21^e^ | 4.21 (0.85–12.32) | 2.57^e^ | 0.34 (0.07–1.01)

a Calculated by ECRI

b Study population rate / general reference population rate, calculated by ECRI

c Study population rate / highest rate in general reference population, calculated by ECRI

d From U.S. Census Bureau, Statistical Abstract of the United States, 2000. The standard population for age-adjustment was the U.S. population in 1940.

e Calculated by ECRI from Mortality Statistcs (England and Wales, 1999).

Evidence Table 244. Automobile accident-related mortality rates among patients with treatment-resistant epilepsy

| | | | Automobile-Accident-Related Mortality Rate Per 1000 Person-Years
Reference | Country | N | Treatment | Study Population Rate (CI)^a^ | General Reference Population Rate | Crude Mortality Ratio (CI)^b^
Sperling (1999) | United States | 194 | Surgery | All patients: 1.25 (0.22–7.03) | Age-adjusted: 0.16^c^ | 7.81 (0.10–43.47)

a Calculated by ECRI

b Study population rate / general reference population rate, calculated by ECRI

c From U.S. Census Bureau, Statistical Abstract of the United States, 2000. The standard population for age-adjustment was the U.S. population in 1940.

Evidence Table 245. Aspiration-related mortality rates among patients with treatment-resistant epilepsy

| | | | Aspiration-Related Mortality Rate Per 1000 Person-Years
Reference | Country | N | Treatment | Study Population Rate (CI)^a^ | General Reference Population Rate | Crude Mortality Ratio (CI)^b^
Racoosin (2001) | United States | 9144 | AEDs | All patients: 0.29 (0.11–0.76) | Not reported | Cannot be calculated
Hennessy (1999) | United Kingdom | 305 | Surgery | All patients: 0.73 (0.20–2.67) (includes some patients seizure-free after surgery) | Not reported | Cannot be calculated
Leestma (1997) | United States, United Kingdom, Europe, Australia, South Africa | 4700 | AEDs | All patients: 0.17 (0.03–0.99) | Not reported | Cannot be calculated
Klenerman (1993) | United Kingdom | Not reported (reported as patient-years) | AEDs | All patients: 1.77 (0.81–3.85) | Not reported | Cannot be calculated

a Calculated by ECRI

b Available studies did not report any deaths from aspiration.

Evidence Table 246. Pneumonia-related mortality rates among patients with treatment-resistant epilepsy

| | | | Pneumonia Mortality Rate Per 1000 Person-Years
Reference | Country | N | Treatment | Study Population Rate (CI)^a^ | General Reference Population Rate | Crude Mortality Ratio (CI)^b^ | Highest Rate in General Reference Population | Crude Mortality Ratio (CI)^c^
Sperling (1999) | United States | 194 | Surgery | All patients: 1.25 (0.22–7.03) | Age-adjusted: 0.13^d^ | 9.62 (0.13–53.53)^a^ | Not applicable^f^ | Not applicable^f^
Leestma (1997) | United States, United Kingdom, Europe, Australia, South Africa | 4700 | AEDs | All patients: 0.17 (0.03–0.99) | Age-adjusted: 0.13^d^ | 1.34 (0.02–7.45)^a^ | 2.28^e^ | 0.08 (0.01–0.42)
Klenerman (1993) | United Kingdom | Not reported (reported as patient-years) | AEDs | All patients: 8.25 (5.72–11.90) | All patients: 0.34^e^ | 24.28 (16.13–35.10)^a^ | 34.12^e^ | 0.24 (0.16–0.35)

a Calculated by ECRI

b Study population rate / general reference population rate, calculated by ECRI

c Study population rate / highest rate in general reference population, calculated by ECRI

d From U.S. Census Bureau, Statistical Abstract of the United States, 2000.

e From Mortality Statistics (England and Wales, 1999).

f The highest value for an individual age group was not higher than the value for the overall reference population, so no sensitivity analysis could be performed.

Evidence Table 247. Cardiovascular mortality rates among patients with treatment-resistant epilepsy

| | | | Cardiovascular Mortality Rate Per 1000 Person-Years
Reference | Country | N | Treatment | Study Population Rate (CI)^a^ | General Reference Population Rate | Crude Mortality Ratio (CI)^b^
Hennessy (1999) | United Kingdom | 305 | Surgery | Crude: 0.37 (0.06–2.07) | 0.42^c^ | 0.87 (0.01–4.87)

a Calculated by ECRI

b Study population rate / general reference population rate, calculated by ECRI

c Calculated from age-specific rates in Mortality Statistics (England and Wales, 1999).

Evidence Table 248. Cerebrovascular mortality rates among patients with treatment-resistant epilepsy

| | | | Cerebrovascular Mortality Rate Per 1000 Person-Years
Reference | Country | N | Treatment | Study Population Rate (CI)^a^ | General Reference Population Rate | Crude Mortality Ratio (CI)^b^
Racoosin (2001) | United States | 9144 | AEDs | All patients: 0.51 (0.25–1.06) | Age-adjusted: 0.25^c^ | 2.06 (0.55–4.24)
Leestma (1997) | United States, United Kingdom, Europe, Australia, South Africa | 4700 | AEDs | All patients: 0.17 (0.03–0.99) | Age-adjusted: 0.25^c^ | 0.70 (0.01–3.87)
Klenerman (1993) | United Kingdom | Not reported (reported as patient-years) | AEDs | All patients: 1.77 (0.81–3.85) | All patients: 1.01^d^ | 1.75 (0.64–3.81)

a Calculated by ECRI

b Study population rate / general reference population rate, calculated by ECRI

c From U.S. Census Bureau, Statistical Abstract of the United States, 2000. The standard population for age-adjustment was the U.S. population in 1940.

d From Mortality Statistics (England and Wales, 1999).

Evidence Table 249. Cancer-related mortality rates among patients with treatment-resistant epilepsy

| | | | Cancer Mortality Rate Per 1000 Person-Years
Reference | Country | N | Treatment | Study Population Rate (CI)^a^ | General Reference Population Rate | Crude Mortality Ratio (CI)^b^
Klenerman (1993) | United Kingdom | Not reported (reported as patient-years) | AEDs | All patients: 8.55 (5.96–12.25)^a^ | 4.28^c^ | SMR cancer: 2.0 (1.3–2.9)
| | | | | | Lung: 3.3 (1.7–5.9)
| | | | | | Pancreas: 6.2 (1.7–15.8)
| | | | | | Lymphatic/ Haemopoetic: 3.3 (0.7–9.3)
| | | | | | Hepatobiliary: 17.6 (3.6–51.5)

a Calculated by ECRI

b Study population rate / general reference population rate, calculated by ECRI

c Calculated by ECRI from age-specific rates in Mortality Statistics (England and Wales, 1999).

Evidence Table 250. Suicide rates among patients with treatment-resistant epilepsy

| | | | Suicide Rate Per 1000 Person-Years
Reference | Country | N | Treatment | Study Population Rate (CI)^a^ | General Reference Population Rate | Crude Mortality Ratio (CI)^b^
Sperling (1999) | United States | 194 | Surgery | All patients: 1.25 (0.22 to 7.03) | Age-adjusted: 0.10c | 12.5 (0.16 to 69.53)
Hennessy (1999) | United States | 305 | Surgery | All patients: 0.37 (0.06–2.07) | 0.11^d^ | 3.33 (0.37–18.55)
Leestma (1997) | United States, United Kingdom, Europe, Australia, South Africa | 4700 | AEDs | All patients: 0.17 (0.03 to 0.99) | Age-adjusted: 0.10^c^ | 1.74 (0.02 to 9.68)

a Calculated by ECRI

b Study population rate / general reference population rate, calculated by ECRI

c From U.S. Census Bureau, Statistical Abstract of the United States, 2000. The standard population for age-adjustment was the U.S. population in 1940.

d From Mortality Statistics (England and Wales, 1999).

## Question 9

Is there a correlation between the number and/or type of seizure and sudden death?

Evidence Table 251. Design and conduct of included studies of sudden unexpected death from epilepsy (SUDEP)

Reference | Country | N | Epilepsy Diagnosis | Study Reported Criteria For Diagnosis of SUDEP | Proportion (Percent) SUDEP Cases Determined by Autopsy | Study Design | Controls | Controls Matched to Cases | Methods Used to Correlate Seizure Type/Frequency And SUDEP | Study Adjusted For Potential Confounding Variables
Walczak (2001) | United States | 4578 | Clinical diagnosis | Yes | 10/20 (50%) | Prospective nested case-control | Living patients | Yes (matched by time of enrollment and epilepsy center) | Multiple logistic regression | Yes
McKee (2000) | United States | 180 | Clinical diagnosis plus AED treatment | Yes | 4/11 (36.4%) | Retrospective nested case-control | Living patients | No | t-test | No
Kloster (1999) | Norway | 79 | Clinical diagnosis | Yes | 42/42 (100%) | Retrospectivenested case-control | Deceased | No | Student's t-test or Pearson's X ^2^ test | No
Nilsson (1999) | United Kingdom | 228 | Clinical diagnosis | Yes | 52/57 (91.2%) | Retrospectivenested case-control | Living patients | Yes (matched for year of birth, gender, and assessment period) | Multiple logistic regression | Yes
Sperling (1999) | United States | 393 | Clinical diagnosis | Yes | Not reported | Prospective nested case-control | All patients in cohort (living and dead) | No | No statistical comparison (only for overall mortality) | No (only in overall mortality analysis, not for sudden death)
Nashef (1995) | United Kingdom | 601 | Clinical diagnosis | No | 10/11 (90.9%) | Retrospectivenested case-control | All patients in cohort (living and deceased) | No | No statistical comparison | No
Timmings (1993) | United Kingdom | 1820 | Clinical diagnosis | No | Not reported | Retrospectivenested case-control | Unclear, but could be all other patients in cohort | No | X ^2^ test | No
Jick (1992) | United States | 3280 (only 31 were relevant to this question) | Anticonvulsant usage and other information on file (based on random review of only 5% of records) | Yes | 11/11 (100%) | Retrospectivenested case-control | Living patients | Yes (matched on age at index date and gender) | No statistical comparison | No
Birnbach (1991) | United States | 108 | Clinical diagnosis | No | Not reported | Retrospectivenested case-control | Deceased and living patients | No | Student's t-test, X ^2^ test | No

Evidence Table 252. Correlation between SUDEP and seizure frequency

Studies adjusted for potential confounding variables
Reference | Country | N | Seizure Frequency | SUDEP (N) | Control (N) | Published Results | Statistically Significant Association | Other Variables Adjusted For in Multiple Regression Analysis
Walczak (2001) | United States | 4578 (only 100 were relevant to this question) | Monthly average: | | | OR^a^ (CI) Multiple regression | No (possibly for females, but the publication did not specifically report that the gender-specific ratios were derived from a multivariate analysis) | Frequency of tonic-clonic seizures, number of AEDs used
| | | 0 | 2 | 23 | 1.1 (0.3–4.0)
| | | ≤1 | 3 | 16
| | | >1 to ≤15 | 10 | 30
| | | >15 to ≤50 | 2 | 5
| | | >50 | 3 | 3
| | | Unknown | 0 | 3
| | | Males
| | | <1 | 2 | 17 | 1.0^b^
| | | 1–5 | 3 | 11 | 3.4 (0.5–22)
| | | >5 | 3 | 16 | 1.0 (0.1–7.9)
| | | Unknown | 0 | 0
| | | Females
| | | <1 | 2 | 19 | 1.0^b^
| | | 1–5 | 5 | 5 | 5.7 (0.6–43.9)
| | | >5 | 5 | 9 | 7.4 (1.3–43.0)
| | | Unknown | 0 | 3
Nilsson (1999) | United Kingdom | 228 | Seizures/year | | | Multiple regression RR^c^ (CI) | Yes | Age at epilepsy onset, epilepsy type, number of AEDs, changes in AED dose per year
| | | 0–2 | 5 | 87 | 1.00^b^
| | | 3–12 | 16 | 33 | 4.47 (1.33–15.03)
| | | >12 | 24 | 39 | 4.64 (1.22–17.63)
| | | Males | | | Unadjusted RR^c^
| | | 0–2 | 2 | 56 | 1.00^b^
| | | 3–12 | 12 | 18 | 14.8(3.1–69.7)
| | | 13–50 | 7 | 12 | 15.1 (2.8–81.2)
| | | >50 | 4 | 7 | 14.8 (2.3–96.1)
| | | Unknown | 9 | 9 | 24.1 (4.2–138.6)
| | | Females | | | Unadjusted RR^c^
| | | 0–2 | 3 | 31 | 1.00^b^
| | | 3–12 | 4 | 15 | 2.5 (0.5–12.0)
| | | 13–50 | 8 | 14 | 4.7 (1.1–19.6)
| | | >50 | 5 | 6 | 6.5 (1.2–34.3)
| | | Unknown | 3 | 3 | 7.2 (0.9–56.6)

a Odds ratio

b Used as a reference value for the other seizure frequencies

c Relative risk

Evidence Table 253. Correlation between SUDEP and seizure frequency

Studies did not adjust for potential confounding variables
Reference | Country | N | Seizure Frequency | SUDEP (N) | Control (N) | Published Results | Odds Ratio (CI)^a^ | Statistically Significant Association If Not, What Was The Minimum Detectable Difference
McKee (2000) | United States | 180 | Yearly mean | NA | NA | p = 0.07 | Cannot be calculated | No
| | | SUDEP: 143
| | | | | | | | Cannot be calculated
| | | Control: 27
Kloster (1999) | Norway | 79 | Seizures per year | | | p = 0.56 | | No
| | | | | | | | 6.28
| | | ≤1 | 4 | 6 | | 0.54 (0.14–2.10)
| | | 2–12 | 3 | 1 | | 2.77 (0.28–27.85)
| | | >12 | 32 | 26 | | 1.35 (0.50–3.68)
| | | No data | 3 | 4 | | 0.63 (0.13–3.04)
Sperling (1999) | United States | 393 | Seizures: | | | None^b^ | | No
| | | 0 | 0 | 199 | | 0.07 (0.00–1.30)
| | | | | | | | 15.1
| | | >0 | 6 | 188 | | 13.76 (0.77–245.93)
Timmings (1993) | United Kingdom | 1820 | Seizures per month | | NR | p = NS^c^ | Cannot be calculated | No
| | | | | | | | Cannot be calculated
| | | <1 | 4
| | | 1–4 | 5
| | | 5–60 | 4
| | | Unknown | 1
Jick (1992) | United States | 3280 (only 31 were relevant to this question) | Seizures per month | | | None^b^ | | No
| | | | | | | | 6.36
| | | ≤1 | 6 | 13 | | 0.65 (0.14–2.90)
| | | >1 | 3 | 4 | | 1.50 (0.27–8.38)
| | | Unknown | 2 | 3 | | 1.26 (0.18–8.97)
Birnbach (1991) | United States | 48 | Mean ±SD generalized seizures per month | NA | NA | SUDEP vs. Non-SUDEP deaths: | Cannot be calculated | No (SUDEP vs. Non-SUDEP deaths)
| | | | | | t = 0.70^d^ | | 1.56
| | | | | | p = 0.255^a^
| | | SUDEP:
| | | 1.86 ± 3.47 | | | | | Yes (SUDEP vs. Living controls)
| | | | | | SUDEP vs. Living controls:
| | | Non-SUDEP deaths:
| | | | | | t = 2.57^a^
| | | 1.24 ± 1.52 | | | p = 0.013^a^
| | | Living:
| | | 0.43 ± 0.80

a Calculated by ECRI

b No statistical analysis

c Specific p-value not reported

d Student's t-test

NA Not applicable

NR Not reported

NS Not statistically significant

Evidence Table 254. Correlation between SUDEP and seizure type

Studies adjusted for potential confounding variables
Reference | Country | N | Seizure Type | SUDEP (N) | Control (N) | Published Results | Statistically Significant Association | Other Variables Adjusted For In Multiple Regression Analysis
Walczak (2001) | United States | 4578 (only 100 were relevant to this question) | All patients Tonic-clonic | | | Multiple Regression OR (CI) | Yes | Overall seizure frequency, number of AEDs used
| | | 0 | 4 | 54 | OR (CI)
| | | 1–3 | 6 | 11
| | | >3 | 9 | 15 | 7.0(2.0–24.2)
| | | Unknown | 1 | 0
| | | Males Tonic-clonic | | | OR(CI)
| | | 0 | 2 | 26 | 1.0^b^
| | | 1–3 | 2 | 6 | 4.3(0.5–37.3)
| | | >3 | 3 | 12 | 3.3(0.5–22.1)
| | | Unknown | 1 | 0
| | | Females Tonic-clonic
| | | 0 | 2 | 28 | 1.0^b^
| | | 1–3 | 4 | 5 | 11.2(1.6–78.4)
| | | >3 | 6 | 3 | 28.0(3.8–205.8)
| | | Unknown | 0 | 0
Nilsson (1999) | United Kingdom | 228 | | | | Multiple regression RR (CI) | No | Seizure frequency during last year, age at epilepsy onset, number of AEDs, changes in AED dose per year
| | | Generalized idiopathic | 7 | 12 | 1.00
| | | Partial symptomatic | 26 | 92 | 1.15(0.18–7.17)
| | | Partial cryptogenic | 17 | 45 | 1.94(0.27–13.71
| | | Undetermined | 7 | 22 | 1.17(0.14–9.78)

a Calculated by ECRI

b Used as a reference value for the other seizure frequencies

OR Odds ratio

RR Relative risk

Evidence Table 255. Correlation between SUDEP and seizure type

Studies did not adjust for potential confounding variables
| | | | | | | | Statistically Significant Association
Reference | Country | N | Seizure Type | SUDEP (N) | Control (N) | Published Results | Odds Ratio (CI)^a^ | If Not, What Was The Minimum Detectable Difference
Kloster (1999) | Norway | 79 | Generalized motor seizures | | | p = 0.07 (X ^2^test) | | No
| | | | 42 | 35 | | 5.99 (0.28–128.8)
| | | | | | | | 10.27
| | | Partial seizures | 0 | 2 | | 0.17 (0.01–3.59)
Sperling (1999) | United States | 393 | Non-tonic-clonic | 2 | 297 | None^b^ | 0.15 (0.03–0.84) | Yes
| | | Tonic-clonic | 4 | 90 | | 6.60 (1.19–36.63)
Nashef (1995) | United Kingdom | 601 | Partial cryptogenic/ symptomatic | | | None^b^ | | Yes
| | | | 5 | 396 | | 0.41 (0.12–1.35)
| | | Generalized idiopathic
| | | | 1 | 75 | | 0.69 (0.09–5.44)
| | | Generalized cryptogenic/ symptomatic
| | | | 3 | 44 | | 4.65 (1.19–18.17)
| | | Undetermined | 2 | 63 | | 1.86 (0.39–8.80)
Timmings (1993) | United Kingdom | 1820 | Idiopathic generalized tonic clonic | | | p <0.05 (X ^2^test) | Cannot be calculated | Yes
| | | | 10 | Not reported
| | | Partial seizures (with or without secondary generalization)
| | | | 4
| | | | | Not reported
Jick (1992) | United States | 3280 (only 31 were relevant to this question) | Primary generalized | | | None^b^ | | No
| | | | 6 | 10 | | 1.20 (0.27–5.25)
| | | | | | | | 9.71
| | | Primary partial | 2 | 5 | | 0.67 (0.11–4.18)
| | | Unknown | 3 | 5 | | 1.13 (0.21–5.97)
Birnbach (1991) | United States | 108 | | | Non-SUDEP | None^b^ | | No
| | | Generalized convulsive
| | | | 24 | 22 | | 1.09 (0.06–18.52)
| | | Other | 1 | 1 | | 0.92 (0.05–15.56)
| | | Generalized convulsive | | Living | None^b^ | | No
| | | | 24 | 47 | | 6.64 (0.82–53.81)
| | | | | | | | 7.34
| | | Other | 1 | 13 | | 0.15 (0.02–1.22)

a Calculated by ECRI

b No statistical analysis