# Bibliography

Efficacy of felbamate in childhood epileptic encephalopathy (Lennox-Gastaut syndrome). The Felbamate Study Group in Lennox-Gastaut Syndrome. N Engl J Med 1993 Jan;328(1):29–33.
Gabapentin in partial epilepsy. UK Gabapentin Study Group. Lancet 1990 May;335(8698):1114–7.
ILAE Commission Report. The epidemiology of the epilepsies: future directions. International League Against Epilepsy. Epilepsia 1997 May;38(5):614–8.
National Institutes of Health Consensus Development Conference Statement: surgery for epilepsy, March 19–21, 1990. Epilepsia 1990;31(6):806–12.
Optimizing epilepsy management: seizure control, medication tolerability, and co-morbidities. Neurology 2002 Apr;58(8 Suppl 5):S1–39.
Physician's desk reference 2001. 55th ed. Montvale (NJ): Medical Economics/Thomson Healthcare; 2001. 3506 p.
Practice parameter: management issues for women with epilepsy (summary statement). Report of the Quality Standards Subcommittee of the American Academy of Neurology. Neurology 1998 Oct;51(4):944–8.
Proposal for revised classification of epilepsies and epileptic syndromes. Commission on Classification and Terminology of the International League Against Epilepsy. Epilepsia 1989;30(4):389–99.
Proposal for revised clinical and electroencephalographic classification of epileptic seizures. From the Commission on Classification and Terminology of the International League Against Epilepsy. Epilepsia 1981 Aug;22(4):489–501.
Quality of life in epilepsy QOLIE-31 (Version 1.0). Patient inventory.[internet]. Santa Monica (CA): RAND Health Communications; 1993[cited 2002 Jan 24].[9 p]. Available: http://www.rand.org/health/surveys/QOLIE31.pdf.
Quality of life in epilepsy QOLIE-89 (Version 1.0). Patient inventory.[internet]. Santa Monica (CA): RAND Health Communications;[cited 2002 Jan 24].]15 p]. Available: http://www.rand.org/health/surveys/QOLIE89.survey.pdf.
A randomized controlled trial of chronic vagus nerve stimulation for treatment of medically intractable seizures. The Vagus Nerve Stimulation Study Group. Neurology 1995 Feb;45(2):224–30.
Scoring manual for the quality of life in epilepsy inventory-89 (QOLIE-89).[internet]. Santa Monica (CA): RAND Health Communications;[cited 2002 Jan 24].[14 p]. Available: http://www.rand.org/health/surveys/QOLIE89.scoring.pdf.
Mortality statistics: general. Review of the Registrar General on deaths in England and Wales, 1999. London (UK): The Stationery Office; 2001. Death rates per 1,000 population within sex and age-groups, and infant mortality rates per 1,000 live births 1841-1999. (Series DH1; no. 32).p. 5–10. Also available: http://www.statistics.gov.uk/statbase. Table 4
Mortality statistics: general. Review of the Registrar General on deaths in England and Wales, 1999. London (UK): The Stationery Office; 2001. Death rates for 1,000,000 population: age-group and sex, infant mortality rates and standardized mortality ratios for selected underlying causes, 1999. (Series DH1; no. 32).p. 12–37. Table 7
Topiramate in medically intractable partial epilepsies: double-blind placebo-controlled randomized parallel group trial. Korean Topiramate Study Group. Epilepsia 1999 Dec;40(12):1767–74.
Statistical abstract of the United States. Washington (DC): U.S. Census Bureau; 2000. Vital statistics. p. various. Also available: http://www.census.gov/prod/www/statistical-abstract.html.
Aarli J A. Epilepsy and the immune system. Arch Neurol. Dec. 2000;57(12):1689-92. [pmid: 11115234].
Acciari N, Giulioni M, Padovani R, et al. Surgical management of cerebral cavernous angiomas causing epilepsy. J Neurosurg Sci. Mar. 1995;39(1):13-20. [pmid: 8568551].
Acharya J N, Dinner D S. Use of the intracarotid amobarbital procedure in the evaluation of memory. J Clin Neurophysiol. Jul. 1997;14(4):311-25. [pmid: 9337141].
Adam C, Clemenceau S, Semah F, et al. Variability of presentation in medial temporal lobe epilepsy: a study of 30 operated cases. Acta Neurol Scand. Jul. 1996;94(1):1-11. [pmid: 8874586].
Adler J, Erba G, Wlinston K R, et al. Results of surgery for extratemporal partial epilepsy that began in childhood. Arch Neurol. Feb. 1991;48(2):133-40. [pmid: 1899561].
Agency for Healthcare Research and Quality (AHRQ). Management of newly diagnosed patients with epilepsy: a systematic review of the literature: summary. Rockville (MD): AHRQ; 2001 Feb 1. 158 p. (Evidence report/technology assessment; no. 39). Also available: http://www.ahrq.gov.
Aiken S P, Brown W M. Treatment of epilepsy: existing therapies and future developments. Front Biosci. Nov. 2000;5:E124-52. [pmid: 11056076].
Aldenkamp AP. Cognitive and behavioural assessment in clinical trials: when should they be done? Epilepsy Res 2001 May 45(1–3):155–7; discussion 159–61.
Aldenkamp A P, Van de Veerdonk S H, Majoie H J, et al. Effects of 6 months of treatment with vagus nerve stimulation on behavior in children with Lennox-Gastaut syndrome in an open clinical nonrandomized study. Epilepsy Behav. Aug. 2001;2(4):343-50. [pmid: 12609211].
Alsaadi T, Morris G L, Mueller W M. Prognostic value of the consistency of lateralizing ictal features and ictal EEG in patients undergoing temporal lobectomy for refractory complex partial seizures. Clin Electroencephalogr. Apr. 2001;32(2):87-91. [pmid: 11360726].
Altshuler L, Rausch R, Delrahim S, et al. Temporal lobe epilepsy, temporal lobectomy, and major depression. J Neuropsychiatry Clin Neurosci 1999 Fall;11(4):436–43.
Alving J. Serum prolactin levels are elevated also after pseudo-epileptic seizures. Seizure. Apr. 1998;7(2):85-9. [pmid: 9627196].
Andersen B, Rogvi-Hansen B, Kruse-Larsen C, et al. Corpus callosotomy: seizure and psychosocial outcome A 39-month follow-up of 20 patients. Epilepsy Res. Feb. 1996;23(1):77-85. [pmid: 8925805].
Andrews D J, Schonfeld W H. Predictive factors for controlling seizures using a behavioural approach. Seizure. Jun. 1992;1(2):111-6. [pmid: 1344325].
Andriola M R, Vitale S A. Vagus nerve stimulation in the developmentally disabled. Epilepsy Behav. Apr. 2001;2(2):129-34. [pmid: 12609196].
Anhoury S, Brown R J, Krishnamoorthy E S, et al. Psychiatric outcome after temporal lobectomy: a predictive study. Epilepsia. Dec. 2000;41(12):1608-15. [pmid: 11114220].
Anhut H, Ashman P, Feuerstein T J, et al. Gabapentin (Neurontin) as add-on therapy in patients with partial seizures: a double-blind, placebo-controlled study. The International Gabapentin Study Group. Epilepsia. 1994;35(4):795-801. [pmid: 8082624].
Annegers J F, Coan S P. SUDEP: overview of definitions and review of incidence data. Seizure. Sep. 1999;8(6):347-52. [pmid: 10512776].
Annegers J E, Coan S P, Hauser W A, et al. Epilepsy, vagal nerve stimulation by the NCP system, all-cause mortality, and sudden, unexpected, unexplained death. Epilepsia. May. 2000;41(5):549-53. [pmid: 10802760].
Annegers J F, Coan S P, Hauser W A, et al. Epilepsy, vagal nerve stimulation by the NCP system, mortality, and sudden, unexpected, unexplained death. Epilepsia. Feb. 1998;39(2):206-12. [pmid: 9578002].
Anzola G P. Predictivity of plasma prolactin levels in differentiating epilepsy from pseudoseizures: a prospective study. Epilepsia. 1993;34(6):1044-8. [pmid: 8243355].
Appleton R, Fichtner K, LaMoreaux L, et al. Gabapentin as add-on therapy in children with refractory partial seizures: a 12-week, multicentre, double-blind, placebo-controlled study. Gabapentin Paediatric Study Group. Epilepsia. Aug. 1999;40(8):1147-54. [pmid: 10448830].
Armour D J, Veitch G B. Is valproate monotherapy a practical possibility in chronically uncontrolled epilepsy?. J Clin Pharm Ther. Feb. 1988;13(1):53-64. [pmid: 3129441].
Arnold L M, Privitera M D. Psychopathology and trauma in epileptic and psychogenic seizure patients. Psychosomatics. 1996;37(5):438-43. [pmid: 8824123].
Arroyo S, Brodie M J, Avanzini G, et al. Is refractory epilepsy preventable?. Epilepsia. Apr. 2002;43(4):437-44. [pmid: 11952776].
Assaf B A, Ebersole J S. Visual and quantitative ictal EEG predictors of outcome after temporal lobectomy. Epilepsia. Jan. 1999;40(1):52-61. [pmid: 9924902].
Atherton Skaff PJ, Sloan JA. Design and analysis of equivalence clinical trials via the SAS system. In: Proceedings of the 23rd annual SAS users group international. March 22–25, 1998; Nashville (TN). Also available: http://www2.sas.com/proceedings/sugi23/Stats/p218.pdf.
Barry J J, Atzman O, Morrell M J. Discriminating between epileptic and nonepileptic events: the utility of hypnotic seizure induction. Epilepsia. Jan. 2000;41(1):81-4. [pmid: 10643928].
Battaglia D, Di Rocco C, Iuvone L, et al. Neuro-cognitive development and epilepsy outcome in children with surgically treated hemimegalencephaly. Neuropediatrics. Dec. 1999;30(6):307-13. [pmid: 10706025].
Bauer J, Burr W. Course of chronic focal epilepsy resistant to anticonvulsant treatment. Seizure. Jun. 2001;10(4):239-46. [pmid: 11466018].
Baxendale S. Amnesia in temporal lobectomy patients: historical perspective and review. Seizure. Feb. 1998;7(1):15-24. [pmid: 9548221].
Bazil C W, Pedley T A. Advances in the medical treatment of epilepsy. Annu Rev Med. 1998;49:135-62. [pmid: 9509255].
Becu M, Becu N, Manzur G, et al. Self-help epilepsy groups: an evaluation of effect on depression and schizophrenia. Epilepsia. 1993;34(5):841-5. [pmid: 8404735].
Begg C B, Greenes R A. Assessment of diagnostic tests when disease verification is subject to selection bias. Biometrics. Mar. 1983;39(1):207-15. [pmid: 6871349].
Ben-Menachem E, Falter U. Efficacy and tolerability of levetiracetam 3000 mg/d in patients with refractory partial seizures: a multicenter, double-blind, responder-selected study evaluating monotherapy. Epilepsia. 2000;41(10):1276-83. [pmid: 11051122].
Ben-Menachem E, Hellstrom K, Waldton C, et al. Evaluation of refractory epilepsy treated with vagus nerve stimulation for up to 5 years. Neurology. Apr. 1999;52(6):1265-7. [pmid: 10214754].
Ben-Menachem E, Henriksen O, Dam M, et al. Double-blind, placebo-controlled trial of topiramate as add-on therapy in patients with refractory partial seizures. Epilepsia. Jun. 1996;37(6):539-43. [pmid: 8641230].
Benbadis S R. Provocative techniques should be used for the diagnosis of psychogenic nonepileptic seizures. Arch Neurol. Dec. 2001;58(12):2063-5. [pmid: 11735780].
Benbadis SR. What can EEG-video monitoring do for you and your patients? J Fla Med Assoc 1997 Jun-1997 Jul;84(5):320–2.
Benbadis S R, Tatum WO 4th. Advances in the treatment of epilepsy. Am Fam Physician. Jul. 2001;64(1):91-8. [pmid: 11456438].
Benbadis S R, Wolgamuth B R, Goren H, et al. Value of tongue biting in the diagnosis of seizures. Arch Intern Med. Nov. 1995;155(21):2346-9. [pmid: 7487261].
Berg A T, Shinnar S. The contributions of epidemiology to the understanding of childhood seizures and epilepsy. J Child Neurol. Oct. 1994;9(Suppl 2):19-26. [pmid: 7806782].
Berg A T, Shinnar S. Do seizures beget seizures? An assessment of the clinical evidence in humans. J Clin Neurophysiol. Mar. 1997;14(2):102-10. [pmid: 9165405].
Bergey G K, Morris H H, Rosenfeld W, et al. Gabapentin monotherapy: I. An 8-day, double-blind, dose-controlled, multicenter study in hospitalized patients with refractory complex partial or secondarily generalized seizures. The U.S. Gabapentin Study Group 88/89. Neurology. Sep. 1997;49(3):739-45. [pmid: 9305334].
Berkovic S F, Andermann F, Olivier A, et al. Hippocampal sclerosis in temporal lobe epilepsy demonstrated by magnetic resonance imaging. Ann Neurol. Feb. 1991;29(2):175-82. [pmid: 2012385].
Berkovic S F, McIntosh A M, Kalnins R M, et al. Preoperative MRI predicts outcome of temporal lobectomy: an actuarial analysis. Neurology. Jul. 1995;45(7):1358-63. [pmid: 7617198].
Berlin J A, Santanna J, Schmid C H, et al. Individual patient- versus group-level data meta-regressions for the investigation of treatment effect modifiers: ecological bias rears its ugly head. Stat Med. Feb. 2002;21(3):371-87. [pmid: 11813224].
Betts T, Waegemans T, Crawford P. A multicentre, double-blind, randomized, parallel group study to evaluate the tolerability and efficacy of two oral doses of levetiracetam, 2000 mg daily and 4000 mg daily, without titration in patients with refractory epilepsy. Seizure. Mar. 2000;9(2):80-7. [pmid: 10845730].
Beydoun A. Monotherapy trials with gabapentin for partial epilepsy. Epilepsia 1999;40(Suppl 6):S13–6; discussion S73–4.
Beydoun A, Fischer J, Labar D R, et al. Gabapentin monotherapy: II. A 26-week, double-blind, dose-controlled, multicenter study of conversion from polytherapy in outpatients with refractory complex partial or secondarily generalized seizures. The U.S. Gabapentin Study Group 82/83. Neurology. Sep. 1997b;49(3):746-52.
Beydoun A, Sachdeo R C, Rosenfeld W E, et al. Oxcarbazepine monotherapy for partial-onset seizures: a multicenter, double-blind, clinical trial. Neurology. Jun. 2000;54(12):2245-51. [pmid: 10881247].
Beydoun A, Sackellares J C, Shu V. Safety and efficacy of divalproex sodium monotherapy in partial epilepsy: a double-blind, concentration-response design clinical trial. Depakote Monotherapy for Partial Seizures Study Group. Neurology. Jan. 1997a;48(1):182-8.
Bidzinski J. Temporal lobectomy. Acta Neurochir Suppl (Wien). 1990;50:119-21. [pmid: 2097886].
Binnie C D. Vagus nerve stimulation for epilepsy: a review. Seizure. Apr. 2000;9(3):161-9. [pmid: 10775511].
Birnbach C D, Wilensky A J, Dodrill C B. Predictors of early mortality and sudden death in epilepsy: a multidisciplinary approach. J Epilepsy. 1991;4(1):11-7.
Biton V, Montouris G D, Ritter F, et al. A randomized, placebo-controlled study of topiramate in primary generalized tonic-clonic seizures. Topiramate YTC Study Group. Neurology. Apr. 1999;52(7):1330-7. [pmid: 10227614].
Bittencourt P R, Antoniuk S A, Bigarella M, et al. Carbamazepine and phenytoin in epilepsies refractory to barbiturates: efficacy, toxicity and mental function. Epilepsy Res. Oct. 1993;16(2):147-55. [pmid: 8269913].
Bizzi J W, Bruce D A, North R, et al. Surgical treatment of focal epilepsy in children: results in 37 patients. Pediatr Neurosurg. Feb. 1997;26(2):83-92. [pmid: 9419037].
Blackwelder W C. ‘Proving the null hypothesis’ in clinical trials. Control Clin Trials. Dec. 1982;3(4):345-53. [pmid: 7160191].
Bladin P F. Post-temporal lobectomy seizures. Clin Exp Neurol. 1987;24:77-83. [pmid: 3151879].
Bladin P F. Psychosocial difficulties and outcome after temporal lobectomy. Epilepsia. 1992;33(5):898-907. [pmid: 1396433].
Blumcke I, Beck H, Lie A A, et al. Molecular neuropathology of human mesial temporal lobe epilepsy. Epilepsy Res. Sep. 1999;36(23):205-23. [pmid: 10515166].
Blume W T. Current trends in electroencephalography. Curr Opin Neurol. Apr. 2001;14(2):193-7. [pmid: 11262735].
Blume W T. Temporal lobe epilepsy surgery in childhood: rationale for greater use. Can J Neurol Sci. May. 1997;24(2):95-8. [pmid: 9164683].
Blume W T, Desai H B, Girvin J P, et al. Effectiveness of temporal lobectomy measured by yearly follow-up and multivariate analysis. J Epilepsy. 1994;7:203-14.
Blume W T, Girvin J P, McLachlan R S, et al. Effective temporal lobectomy in childhood without invasive EEG. Epilepsia. Feb. 1997;38(2):164-7. [pmid: 9048667].
Blume W T, Whiting S E, Girvin J P. Epilepsy surgery in the posterior cortex. Ann Neurol. Jun. 1991;29(6):638-45. [pmid: 1892366].
Blumer D, Wakhlu S, Davies K, et al. Psychiatric outcome of temporal lobectomy for epilepsy: incidence and treatment of psychiatric complications. Epilepsia. May. 1998;39(5):478-86. [pmid: 9596199].
Boling W, Andermann F, Reutens D, et al. Surgery for temporal lobe epilepsy in older patients. J Neurosurg. 2001;95(2):242-8. [pmid: 11780893].
Boon P, De Reuck J, Drieghe C, et al. Long-term video-EEG monitoring revisited. The value of interictal and ictal video-EEG recording, a follow-up study. Eur Neurol. 1994;34(Suppl 1):33-9. [pmid: 8001608].
Boon P, Vonck K, D'Have M, et al. Cost-benefit of vagus nerve stimulation for refractory epilepsy. Acta Neurol Belg. Dec. 1999;99(4):275-80. [pmid: 10674145].
Boon P A, Williamson P D. The diagnosis of pseudoseizures. Clin Neurol Neurosurg. Mar. 1993;95(1):1-8. [pmid: 8453810].
Bouilleret V, Dupont S, Spelle L, et al. Insular cortex involvement in mesiotemporal lobe epilepsy: a positron emission tomography study. Ann Neurol. Feb. 2002;51(2):202-8. [pmid: 11835376].
Bourgeois B, Leppik I E, Sackellares J C, et al. elbamate: a double-blind controlled trial in patients undergoing presurgical evaluation of partial seizures. Neurology. Apr. 1993;43(4):693-6. [pmid: 8469324].
Brown M C, Levin B E, Ramsay R E, et al. Characteristics of patients with nonepileptic seizures. J Epilepsy. 1991;4(4):225-9.
Brown W M, Aiken S P. Felbamate: clinical and molecular aspects of a unique antiepileptic drug. Crit Rev Neurobiol. 1998;12(3):205-22. [pmid: 9847055].
Browne T R, Holmes G L. Primary care: epilepsy. N Engl J Med. Apr. 2001;344(15):1145-51. [pmid: 11297707].
Bruni J. Efficacy of topiramate. Can J Neurol Sci. Aug. 1998;25(3):S6-7. [pmid: 9706733].
Bruni J. Outcome evaluation of gabapentin as add-on therapy for partial seizures. ‘NEON’ Study Investigators Group. Neurontin Evaluation of Outcomes in Neurological Practice. Can J Neurol Sci. May. 1998;25(2):134-40. [pmid: 9604135].
Bulteau C, Jambaque I, Viguier D, et al. Epileptic syndromes, cognitive assessment and school placement: a study of 251 children. Dev Med Child Neurol. May. 2000;42(5):319-27. [pmid: 10855652].
Bus A G, van IJzendoorn M H. Phonological awareness and early reading: a meta-analysis of experimental training studies. J Educ Psychol. 1999;91(3):403-14.
Bye A, Lamont P, Healy L. Commencement of a paediatric EEG-video telemetry service. Clin Exp Neurol. 1990;27:83-8. [pmid: 2129962].
Callaghan N, O'Dwyer R, Keating J. Unnecessary polypharmacy in patients with frequent seizures. Acta Neurol Scand. Jan. 1984;69(1):15-9. [pmid: 6422691].
Canizares S, Torres X, Boget T, et al. Does neuroticism influence cognitive self-assessment after epilepsy surgery?. Epilepsia. Oct. 2000;41(10):1303-9. [pmid: 11051126].
Cappabianca P, Alfieri A, Maiuri F, et al. Supratentorial cavernous malformations and epilepsy: seizure outcome after lesionectomy on a series of 35 patients. Clin Neurol Neurosurg. Aug. 1997;99(3):179-83. [pmid: 9350398].
Carey P, O'Moore B, Sheahan K, et al. Experience of temporal lobectomy as a treatment modality for epilepsy, using inter-ictal EEG data alone to localize the epileptogenic focus. Ir Med J. 1985;78(3):74-7. [pmid: 3988494].
Carmant L, Holmes G L, Lombroso C T. Outcome following corpus callosotomy. J Epilepsy. 1998;11(4):224-8.
Carreno M, Wyllie E, Bingaman W, et al. Seizure outcome after functional hemispherectomy for malformations of cortical development. Neurology. Jul. 2001;57(2):331-3. [pmid: 11468323].
Carson B S Sr. Indications and outcomes for lobectomy, corpus callosotomy, and hemispherectomy in pediatric neurosurgical patients. Clin Neurosurg. 2000;47:385-99. [pmid: 11197713].
Casazza M, Avanzini G, Ciceri E, et al. Lesionectomy in epileptogenic temporal lobe lesions: preoperative seizure course and postoperative outcome. Acta Neurochir Suppl (Wien). 1997;68:64-9.
Castillo S, Schmidt DB, White S. Oxcarbazepine add-on for drug-resistant partial epilepsy (Cochrane Review). In: The Cochrane Library. Issue 4. Oxford: Update Software; 2001.
Cereghino J J, Biton V, Abou-Khalil B, et al. Levetiracetam for partial seizures: results of a double-blind, randomized clinical trial. Neurology. Jul. 2000;55(2):236-42. [pmid: 10908898].
Chadwick D. Epilepsy. J Neurol Neurosurg Psychiatry. Mar. 1994;57(3):264-77. [pmid: 8158172].
Chadwick D. Monotherapy clinical trials of new antiepileptic drugs: design, indications, and controversies. Epilepsia. 1997;38(Suppl 9):S16-20. [pmid: 9578541].
Chadwick D, Leiderman D B, Sauermann W, et al. Gabapentin in generalized seizures. Epilepsy Res. Nov. 1996;25(3):191-7. [pmid: 8956916].
Chassoux F, Devaux B, Landre E, et al. Postoperative motor deficits and recovery after cortical resections. Adv Neurol. 1999;81:189-99. [pmid: 10609016].
Chayasirisobhon S, Griggs L, Westmoreland S, et al. The usefulness of one to two hour video EEG monitoring in patients with refractory seizures. Clin Electroencephalogr. Apr. 1993;24(2):78-84. [pmid: 8500252].
Chayasirisobhon S, Koulouris S, Parker E, et al. Vagus nerve stimulation for refractory epilepsy. Perm J 2001 Fall;5(4):21–6.
Chelune G J, Naugle R I, Lueders H, et al. Individual change after epilepsy surgery: Practice effects and base-rate information. Neuropsychology. Jan. 1993;7(1):41-52.
Chen L S, Mitchell W G, Horton E J, et al. Clinical utility of video-EEG monitoring. Pediatr Neurol. Apr. 1995;12(3):220-4. [pmid: 7619188].
Chene G, Thompson S G. Methods for summarizing the risk associations of quantitative variables in epidemiologic studies in a consistent form. Am J Epidemiol. Sep. 1996;144(6):610-21. [pmid: 8797521].
Chesson A L, Kasarskis E J, Small V W. Postictal elevation of serum creatine kinase level. Arch Neurol. 1983;40(5):315-7. [pmid: 6847427].
Chugani H T, Chugani D C. Basic mechanisms of childhood epilepsies: studies with positron emission tomography. Adv Neurol. 1999;79:883-91. [pmid: 10514871].
Claverie B, Rougier A. Life comfort and psychosocial adjustment linked to age at the time of anterior callosotomy. J Epilepsy. 1995;8(4):321-31.
Clemmons DC, Fraser RT, Trejo W. The General Aptitude Test Battery: implications for vocational counseling and employment in epilepsy rehabilitation. J Appl Rehabil Couns 1987 Fall;18(3):33–8.
Cohen M J, Holmes G L, Campbell R, et al. Cognitive functioning following anterior two-thirds corpus callosotomy in children and adolescents: a one-year prospective report. J Epilepsy. 1991;4(2):63-5.
Collins W C, Lanigan O, Callaghan N. Plasma prolactin concentrations following epileptic and pseudoseizures. J Neurol Neurosurg Psychiatry. Jun. 1983;46(6):505-8. [pmid: 6410003].
Cook TD, Campbell DT. Quasi-experimentation: design and analysis issues for field settings. Boston (MA): Houghton Mifflin Company; 1979. 405 p.
Cornaggia C, Canevini M P, Giuccioli D, et al. Monotherapy and polytherapy for intractable epilepsies. Ital J Neurol Sci. Jun. 1985;6(2):201-5. [pmid: 3928525].
Corradetti R, Pugliese A M. Electrophysiological effects of felbamate. Life Sci. 1998;63(13):1075-88. [pmid: 9763203].
Cramer J A, Arrigo C, Van Hammee G, et al. Effect of levetiracetam on epilepsy-related quality of life. N132 Study Group. Epilepsia. Jul. 2000;41(7):868-74. [pmid: 10897159].
Culy C R, Goa K L. Lamotrigine. A review of its use in childhood epilepsy. Paediatr Drugs. 2000;2(4):299-330. [pmid: 10946418].
Cutfield R G, Wrightson P. Surgery for temporal lobe epilepsy. N Z Med J. Mar. 1987;100(820):163-6. [pmid: 3452033].
Dahl J, Melin L, Lund L. Effects of a contingent relaxation treatment program on adults with refractory epileptic seizures. Epilepsia. 1987;28(2):125-32. [pmid: 3545797].
Dasheiff R M. Sudden unexpected death in epilepsy: a series from an epilepsy surgery program and speculation on the relationship to sudden cardiac death. J Clin Neurophysiol. Apr. 1991;8(2):216-22. [pmid: 2050822].
Davies K G, Weeks R D. Results of cortical resection for intractable epilepsy using intra-operative corticography without chronic intracranial recording. Br J Neurosurg. 1995;9(1):7-12. [pmid: 7786430].
Davis R. Cerebellar stimulation for cerebral palsy spasticity, function, and seizures. Arch Med Res. 2000;31(3):290-9. [pmid: 11036180].
Deepak K K, Manchanda S K, Maheshwari M C. Meditation improves clinicoelectroencephalographic measures in drug-resistant epileptics. Biofeedback Self Regul. Mar. 1994;19(1):25-40. [pmid: 8167162].
DeGiorgio C M, Schachter S C, Handforth A, et al. Prospective long-term study of vagus nerve stimulation for the treatment of refractory seizures. Epilepsia. Sep. 2000;41(9):1195-200. [pmid: 10999559].
Delgado-Escueta A V, Walsh G O. Type I complex partial seizures of hippocampal origin: excellent results of anterior temporal lobectomy. Neurology. Feb. 1985;35(2):143-54. [pmid: 3969201].
Denio L S, Drake M E Jr, Pakalnis A. The effect of exercise on seizure frequency. J Med. 1989;20(2):171-6. [pmid: 2769084].
Derby L E, Tennis P, Jick H. Sudden unexplained death among subjects with refractory epilepsy. Epilepsia. Oct. 1996;37(10):931-5. [pmid: 8822690].
Derry P A, McLachlan R S. The MMPI-2 as an adjunct to the diagnosis of pseudoseizures. Seizure. 1996;5:35-40. [pmid: 8777550].
Derry P A, Rose K J, McLachlan R S. Moderators of the effect of preoperative emotional adjustment on postoperative depression after surgery for temporal lobe epilepsy. Epilepsia. Feb. 2000;41(2):177-85. [pmid: 10691114].
DerSimonian R, Laird N. Meta-analysis in clinical trials. Control Clin Trials. Sep. 1986;7(3):177-88. [pmid: 3802833].
DeToledo J C, Lowe M R. Seizures, lateral decubitus, aspiration, and shoulder dislocation: time to change the guidelines?. Neurology. Feb. 2001;56(3):290-1. [pmid: 11235662].
DeToledo J C, Lowe M R, Ramsay R E. Restraining patients and shoulder dislocations during seizures. J Shoulder Elbow Surg. 1999;8(4):300-2. [pmid: 10471999].
Devinsky O. Patients with refractory seizures. N Engl J Med. May. 1999;340(20):1565-70. [pmid: 10332020].
Devinsky O, Faught R E, Wilder B J, et al. Efficacy of felbamate monotherapy in patients undergoing presurgical evaluation of partial seizures. Epilepsy Res. Mar. 1995;20(3):241-6. [pmid: 7796796].
Devinsky O, Sanchez-Villasenor F, Vazquez B, et al. Clinical profile of patients with epileptic and nonepileptic seizures. Neurology. Jun. 1996;46(6):1530-3. [pmid: 8649542].
Devinsky O, Thacker K. Nonepileptic seizures. Neurol Clin. May. 1995;13(2):299-319. [pmid: 7643827].
Di Rocco C, Iannelli A. Hemimegalencephaly and intractable epilepsy: complications of hemispherectomy and their correlations with the surgical technique. A report on 15 cases. Pediatr Neurosurg. Oct. 2000;33(4):198-207. [pmid: 11124637].
Dirik E, Sen A, Anal O, et al. Serum cortisol and prolactin levels in childhood paroxysmal disorders. Acta Paediatr Jpn. Apr. 1996;38(2):118-20. [pmid: 8677785].
Dlugos D J. The early identification of candidates for epilepsy surgery. Arch Neurol. Oct. 2001;58(10):1543-6. [pmid: 11594910].
Dodrill C B, Arnett J L, Hayes A G, et al. Cognitive abilities and adjustment with gabapentin: results of a multisite study. Epilepsy Res. Jun. 1999;35(2):109-21. [pmid: 10372564].
Dodrill C B, Arnett J L, Shu V, et al. Effects of tiagabine monotherapy on abilities, adjustment, and mood. Epilepsia. Jan. 1998;39(1):33-42. [pmid: 9578010].
Dodrill C B, Arnett J L, Sommerville K W, et al. Cognitive and quality of life effects of differing dosages of tiagabine in epilepsy. Neurology. Apr. 1997;48(4):1025-31. [pmid: 9109894].
Dodrill C B, Morris G L. Effects of vagal nerve stimulation on cognition and quality of life in epilepsy. Epilepsy Behav. Feb. 2001;2(1):46-53. [pmid: 12609181].
Dodrill C B, Van Belle G, Wilkus R J. Stability of predictors of outcome of surgical treatment for epilepsy. J Epilepsy. 1990;3(1):29-35.
Dooley M, Plosker G L. Levetiracetam. A review of its adjunctive use in the management of partial onset seizures. Drugs. Oct. 2000;60(4):871-93. [pmid: 11085199].
Drake J, Hoffman H J, Kobayashi J, et al. Surgical management of children with temporal lobe epilepsy and mass lesions. Neurosurgery. Dec. 1987;21(6):792-7. [pmid: 3437944].
Drake M E Jr, Huber S J, Pakalnis A, et al. Neuropsychological and event-related potential correlates of nonepileptic seizures. J Neuropsychiatry Clin Neurosci. Winter. 1993;5(1):102-4. [pmid: 8428129].
Drury I, Selwa L M, Schuh L A, et al. Value of inpatient diagnostic CCTV-EEG monitoring in the elderly. Epilepsia. Aug. 1999;40(8):1100-2. [pmid: 10448822].
Duchowny M, Jayakar P, Koh S. Selection criteria and preoperative investigation of patients with focal epilepsy who lack a localized structural lesion. Epileptic Disord. Dec. 2000;2(4):219-26. [pmid: 11174153].
Duchowny M, Pellock J M, Graf W D, et al. A placebo-controlled trial of lamotrigine add-on therapy for partial seizures in children. Lamictal Pediatric Partial Seizure Study Group. Neurology. Nov. 1999;53(8):1724-31. [pmid: 10563619].
Duchowny M S, Resnick T J, Deray M J, et al. Video EEG diagnosis of repetitive behavior in early childhood and its relationship to seizures. Pediatr Neurol. 1988;4(3):162-4. [pmid: 3149479].
Duncan J S. Imaging and epilepsy. Brain. Feb. 1997;120(Pt 2):339-77. [pmid: 9117380].
Duncan J S, Shorvon S D, Trimble M R. Discontinuation of phenytoin, carbamazepine, and valproate in patients with active epilepsy. Epilepsia. 1990;31(3):324-33. [pmid: 2111768].
Duncan J S, Shorvon S D, Trimble M R. Effects of removal of phenytoin, carbamazepine, and valproate on cognitive function. Epilepsia. 1990;31(5):584-91. [pmid: 2119303].
Duncan J S, Shorvon S D, Trimble M R. Withdrawal symptoms from phenytoin, carbamazepine and sodium valproate. J Neurol Neurosurg Psychiatry. Jul. 1988;51(7):924-8. [pmid: 3144581].
Dunlap W P, Cortina J M, Vaslow J B, et al. Meta-analysis of experiments with matched groups or repeated measures designs. Psychol Methods. Jun. 1996;1(2):170-7.
Dupont S, Semah F, Clemenceau S, et al. Accurate prediction of postoperative outcome in mesial temporal lobe epilepsy: a study using positron emission tomography with 18fluorodeoxyglucose. Arch Neurol. Sep. 2000;57(9):1331-6. [pmid: 10987901].
Duse M, Notarangelo L D, Tiberti S, et al. Intravenous immune globulin in the treatment of intractable childhood epilepsy. Clin Exp Immunol. May. 1996;104(Suppl 1):71-6. [pmid: 8625548].
Eberhardt K E, Stefan H, Buchfelder M, et al. The significance of bilateral CSI changes for the postoperative outcome in temporal lobe epilepsy. J Comput Assist Tomogr. 2000;24(6):919-26. [pmid: 11105713].
Edelstein S F, Chisholm M. Management of intractable childhood seizures using the non-MCT oil ketogenic diet in 20 patients. J Am Diet Assoc. Nov. 1996;96(11):1181-2. [pmid: 8906147].
Egli M, O'Kane M, Mothersill I, et al. Monitoring at the Swiss Epilepsy Center. Electroencephalogr Clin Neurophysiol Suppl. 1985;37:371-84. [pmid: 3924569].
El Desoky E, Kandil M R, Afifi A H, et al. Spotlight on the continual applicability of routine plasma monitoring antiepileptic drugs in the treatment of epilepsy. Pharmacol Res. Apr. 1999;39(4):269-74. [pmid: 10208756].
Eller D P, Patterson C A, Webb G W. Maternal and fetal implications of anticonvulsive therapy during pregnancy. Obstet Gynecol Clin North Am. Sep. 1997;24(3):523-34. [pmid: 9266576].
Elterman R D, Glauser T A, Wyllie E, et al. A double-blind, randomized trial of topiramate as adjunctive therapy for partial-onset seizures in children. Topiramate YP Study Group. Neurology. Apr. 1999;52(7):1338-44. [pmid: 10227615].
Elwes R D, Dunn G, Binnie C D, et al. Outcome following resective surgery for temporal lobe epilepsy: a prospective follow up study of 102 consecutive cases. J Neurol Neurosurg Psychiatry. Nov. 1991;54(11):949-52. [pmid: 1800664].
Emilien G, Maloteaux J M. harmacological management of epilepsy. Mechanism of action, pharmacokinetic drug interactions, and new drug discovery possibilities. Int J Clin Pharmacol Ther. Apr. 1998;36(4):181-94. [pmid: 9587044].
Engel J Jr, editor. Surgical treatment of the epilepsies. New York (NY): Raven Press; 1986. Outcome with respect to epileptic seizures. p. 553-71.
Engel J Jr. Intractable epilepsy: definition and neurobiology. Epilepsia. 2001;42(Suppl 6):3. [pmid: 11902319].
Engel J Jr. The timing of surgical intervention for mesial temporal lobe epilepsy: a plan for a randomized clinical trial. Arch Neurol. Nov. 1999;56(11):1338-41. [pmid: 10555652].
Ergene E, Behr P K, Shih J J. Quality-of-life assessment in patients treated with vagus nerve stimulation. Epilepsy Behav. Jun. 2001;2(3):284-7. [pmid: 12609371].
Eriksen H R, Ellertsen B, Gronningsaeter H, et al. Physical exercise in women with intractable epilepsy. Epilepsia. 1994;35(6):1256-64. [pmid: 7988519].
Eriksson S, Malmgren K, Rydenhag B, et al. Surgical treatment of epilepsy—clinical, radiological and histopathological findings in 139 children and adults. Acta Neurol Scand. Jan. 1999;99(1):8-15. [pmid: 9925233].
Erlichman M. Electroencephalographic (EEG) video monitoring. Health Technol Assess Rep 1990(4):1–14.
Escobedo L G, Zack M M. Comparison of sudden and nonsudden coronary deaths in the United States. Circulation. Jun. 1996;93(11):2033-6. [pmid: 8640979].
Estes M L, Morris H H, Luders H, et al. Surgery for intractable epilepsy. Clinicopathologic correlates in 60 cases. Cleve Clin J Med. 1988;55(5):441-7. [pmid: 3146451].
Ettinger A B, Coyle P K, Jandorf L, et al. Postictal SPECT in epileptic versus nonepileptic seizures. J Epilepsy. 1998;11:67-73.
Fandino-Franky J, Torres M, Narino D, et al. Corpus callosotomy in Colombia and some reflections on care and research among the poor in developing countries. Epilepsia. 2000;41(Suppl 4):S22-7. [pmid: 10963473].
Faught E, Ayala R, Montouris G G, et al. Randomized controlled trial of zonisamide for the treatment of refractory partial-onset seizures. Neurology. Nov. 2001;57(10):1774-9. [pmid: 11723262].
Faught E, Sachdeo R C, Remler M P, et al. Felbamate monotherapy for partial-onset seizures: an active-control trial. Neurology. Apr. 1993;43(4):688-92. [pmid: 8469323].
Faught E, Wilder B J, Ramsay R E, et al. Topiramate placebo-controlled dose-ranging trial in refractory partial epilepsy using 200-, 400-, and 600-mg daily dosages. Topiramate YD Study Group. Neurology. Jun. 1996;46(6):1684-90. [pmid: 8649570].
Ferrier C H,, Alarcon G, Engelsman J, et al. Relevance of residual histologic and electrocorticographic abnormalities for surgical outcome in frontal lobe epilepsy. Epilepsia. Mar. 2001;42(3):363-71. [pmid: 11442154].
Ferrier C H, Engelsman J, Alarcon G, et al. Prognostic factors in presurgical assessment of frontal lobe epilepsy. J Neurol Neurosurg Psychiatry. Mar. 1999;66(3):350-6. [pmid: 10084534].
Ficker D M, So E L, Shen W K, et al. Population-based study of the incidence of sudden unexplained death in epilepsy. Neurology. Nov. 1998;51(5):1270-4. [pmid: 9818844].
Fisher R S, Chan D W, Bare M, et al. Capillary prolactin measurement for diagnosis of seizures. Ann Neurol. Feb. 1991;29(2):187-90. [pmid: 2012387].
Fisher R S, Uematsu S, Krauss G L, et al. Placebo-controlled pilot study of centromedian thalamic stimulation in treatment of intractable seizures. Epilepsia. 1992;33(5):841-51. [pmid: 1396427].
Fisher R S, Vickrey B G, Gibson P, et al. The impact of epilepsy from the patient's perspective I. Descriptions and subjective perceptions. Epilepsy Res. Aug. 2000;41(1):39-51. [pmid: 10924867].
Fletcher RH, Fletcher SW, Wagner EH. Clinical epidemiology: the essentials. 2nd ed. Baltimore (MD): Williams & Wilkins; 1988. 246 p.
Foldvary N, Nashold B, Mascha E, et al. Seizure outcome after temporal lobectomy for temporal lobe epilepsy: a Kaplan-Meier survival analysis. Neurology. Feb. 2000;54(3):630-4. [pmid: 10680795].
Foley C M, Legido A, Miles D K, et al. Long-term computer-assisted outpatient electroencephalogram monitoring in children and adolescents. J Child Neurol. Jan. 2000;15(1):49-55. [pmid: 10641611].
Foley C M, Legido A, Miles D K, et al. Diagnostic value of pediatric outpatient video-EEG. Pediatr Neurol. Feb. 1995;12(2):120-4. [pmid: 7779208].
Fraser R T, Clemmons D C, Dodrill C B, et al. The difficult-to-employ in epilepsy rehabilitation: predictions of response to an intensive intervention. Epilepsia. 1986;27(3):220-4. [pmid: 3698936].
Freeman J M, Vining E P, Pillas D J, et al. The efficacy of the ketogenic diet-1998: a prospective evaluation of intervention in 150 children. Pediatrics. Dec. 1998;102(6):1358-63. [pmid: 9832569].
French J, Smith M, Faught E, et al. Practice advisory: the use of felbamate in the treatment of patients with intractable epilepsy: report of the Quality Standards Subcommittee of the American Academy of Neurology and the American Epilepsy Society. Neurology. May. 1999;52(8):1540-5. [pmid: 10331676].
Fried R. Breathing training for the self-regulation of alveolar CO2 in the behavioural control of idiopathic epileptic seizures. In: Mostofsky DI, Loyning Y, editors. The neurobehavioural treatment of epilepsy. Hillsdale (NJ): Lawrence Erlbaum Associates; 1993. p. 19–66.
Fried R, Fox M C, Carlton R M. Effect of diaphragmatic respiration with end-tidal COinf 2 biofeedback on respiration, EEG, and seizure frequency in idiopathic epilepsy(a,b). Ann N Y Acad Sci. 1990;602:67-96. [pmid: 2122789].
Friis M L. Valproate in the treatment of epilepsy in people with intellectual disability. J Intellect Disabil Res. Dec. 1998;42(Suppl 1):32-5. [pmid: 10030429].
Fryback DG, Thornbury JR. The efficacy of diagnostic imaging. Med Decis Making 1991 Apr-1991 Jun;11(2):88–94.
Fuiks K S, Wyler A R, Hermann B P, et al. Seizure outcome from anterior and complete corpus callosotomy. J Neurosurg. Apr. 1991;74(4):573-8. [pmid: 2002370].
Gann PH. Prostate-specific antigen screening for prostate cancer: issues involving test validity. Endocr Related Cancer 1996 Fall;3(3):179–89.
Garcia-Flores E. Corpus callosum section for patients with intractable epilepsy. Appl Neurophysiol. 1987;50(16):390-7. [pmid: 3450244].
Garcia Sola R, Miravet J. Surgical treatment for epilepsy. Results after a minimum follow-up of five years. Acta Neurochir Suppl (Wien). 1991;52:157-60. [pmid: 1792958].
Garg S K, Gupta M C, Handu S S, et al. Therapeutic drug monitoring of antiepileptic drugs - a preliminary experience. Indian J Pharmacol. 2000;32(1):28-30.
Gates J R, Rosenfeld W E, Maxwell R E, et al. Response of multiple seizure types to corpus callosum section. Epilepsia. 1987;28(1):28-34. [pmid: 3098553].
Gates JR, Wada JA, Reeves AG, et al. Reevaluation of corpus callosotomy. In: Surgical treatment of the epilepsies. 2nd ed. New York (NY): Raven Press; 1993. p. 637‐48.
Gavaghan D J, Moore R A, McQuay H J. An evaluation of homogeneity tests in meta-analyses in pain using simulations of individual patient data. Pain. Apr. 2000;85(3):415-24. [pmid: 10781914].
Genton P, Guerrini R, Perucca E. Tiagabine in clinical practice. Epilepsia. 2001;42(Suppl 3):42-5. [pmid: 11520322].
Giesler R B, Ashton C M, Brody B, et al. Assessing the performance of utility techniques in the absence of a gold standard. Med Care. Jun. 1999;37(6):580-8. [pmid: 10386570].
Gillham R A. Refractory epilepsy: an evaluation of psychological methods in outpatient management. Epilepsia. 1990;31(4):427-32. [pmid: 2196170].
Gilliam F, Vazquez B, Sackellares J C, et al. An active-control trial of lamotrigine monotherapy for partial seizures. Neurology. Oct. 1998;51(4):1018-25. [pmid: 9781523].
Gilman J T, Duchowny M, Jayakar P, et al. Medical intractability in children evaluated for epilepsy surgery. Neurology. Jul. 1994;44(7):1341-3. [pmid: 8035945].
Glauser T A. Expanding first-line therapy options for children with partial seizures. Neurology. 2000;55(11 Suppl 3):S30-7. [pmid: 11147566].
Glauser T A, Nigro M, Sachdeo R, et al. Adjunctive therapy with oxcarbazepine in children with partial seizures. The Oxcarbazepine Pediatric Study Group. Neurology. Jun. 2000;54(12):2237-44. [pmid: 10881246].
Goldstein R, Harvey A S, Duchowny M, et al. Preoperative clinical, EEG, and imaging findings do not predict seizure outcome following temporal lobectomy in childhood. J Child Neurol. Nov. 1996;11(6):445-50. [pmid: 9120221].
Goodin D S, Aminoff M J. Does the interictal EEG have a role in the diagnosis of epilepsy?. Lancet. Apr. 1984;1(8381):837-9. [pmid: 6143148].
Grubb B P, Gerard G, Roush K, et al. Differentiation of convulsive syncope and epilepsy with head-up tilt testing. Ann Intern Med. Dec. 1991;115(11):871-6. [pmid: 1952474].
Guldvog B, Loyning Y, Hauglie-Hanssen E, et al. Surgical treatment for partial epilepsy among Norwegian adults. Epilepsia. 1994b;35(3):540-53. [pmid: 8026400].
Guldvog B, Loyning Y, Hauglie-Hanssen E, et al. Surgical treatment for partial epilepsy among Norwegian children and adolescents. Epilepsia. 1994a;35(3):554-65. [pmid: 8026401].
Guldvog B, Loyning Y, Hauglie-Hanssen E, et al. Surgical versus medical treatment for epilepsy. I. Outcome related to survival, seizures, and neurologic deficit. Epilepsia. 1991;32(3):375-88. [pmid: 2044500].
Haafiz A, Kissoon N. Status epilepticus: current concepts. Pediatr Emerg Care. Apr. 1999;15(2):119-29. [pmid: 10220084].
Handforth A, DeGiorgio C M, Schachter S C, et al. Vagus nerve stimulation therapy for partial-onset seizures: a randomized active-control trial. Neurology. Jul. 1998;51(1):48-55. [pmid: 9674777].
Hanna NJ, Black M, Sander JW, et al. The national sentinal clinical audit of epilepsy-related death: epilepsy—death in the shadows. The Stationary Office; 2002 May. 134 p.
Harbord M G, Manson J I. Temporal lobe epilepsy in childhood: reappraisal of etiology and outcome. Pediatr Neurol. 1987;3(5):263-8. [pmid: 3508075].
Hasselblad V, Hedges L V. Meta-analysis of screening and diagnostic tests. Psychol Bull. Jan. 1995;117(1):167-78. [pmid: 7870860].
Helmstaedter C, Gleibner U, Zentner J, et al. Neuropsychological consequences of epilepsy surgery in frontal lobe epilepsy. Neuropsychologia. Apr. 1998;36(4):333-41. [pmid: 9665644].
Hennessy M J, Elwes R D, Honavar M, et al. Predictors of outcome and pathological considerations in the surgical treatment of intractable epilepsy associated with temporal lobe lesions. J Neurol Neurosurg Psychiatry. Apr. 2001a;70(4):450-8. [pmid: 11254766].
Hennessy M J, Elwes R D, Rabe-Hesketh S, et al. Prognostic factors in the surgical treatment of medically intractable epilepsy associated with mesial temporal sclerosis. Acta Neurol Scand. Jun. 2001b;103(6):344-50. [pmid: 11421846].
Hennessy M J, Langan Y, Elwes R D, et al. A study of mortality after temporal lobe epilepsy surgery. Neurology. Oct. 1999;53(6):1276-83. [pmid: 10522885].
Henry T R. Functional neuroimaging with positron emission tomography. Epilepsia. Dec. 1996;37(12):1141-54. [pmid: 8956845].
Henry T R, Drury I. Non-epileptic seizures in temporal lobectomy candidates with medically refractory seizures. Neurology. May. 1997;48(5):1374-82. [pmid: 9153476].
Henry T R, Ross D A, Schuh L A, et al. Indications and outcome of ictal recording with intracerebral and subdural electrodes in refractory complex partial seizures. J Clin Neurophysiol. Sep. 1999;16(5):426-38. [pmid: 10576225].
Hermann B P, Wyler A R, VanderZwagg R, et al. Predictors of neuropsychological change following anterior temporal lobectomy: role of regression toward the mean. J Epilepsy. 1991;4(3):139-48.
Hermanns G, Noachtar S, Tuxhorn I, et al. Systematic testing of medical intractability for carbamazepine, phenytoin, and phenobarbital or primidone in monotherapy for patients considered for epilepsy surgery. Epilepsia. Jul. 1996;37(7):675-9. [pmid: 8681900].
Ho S S, Kuzniecky R I. Algorithm on the clinical evaluation of epilepsy. J Neuroimaging. Oct. 1997;7(4):236-41. [pmid: 9344007].
Ho S S, Newton M R, McIntosh A M, et al. Perfusion patterns during temporal lobe seizures: relationship to surgical outcome. Brain. Nov. 1997;120(Pt 1):1921-8. [pmid: 9397011].
Hodaie M, Musharbash A, Otsubo H, et al. Image-guided, frameless stereotactic sectioning of the corpus callosum in children with intractable epilepsy. Pediatr Neurosurg. Jun. 2001;34(6):286-94. [pmid: 11455228].
Holmes G L. Intractable epilepsy in children. Epilepsia. 1996;37(Suppl 3):14-27. [pmid: 8681906].
Holmes G L, Sackellares J C, McKiernan J, et al. Evaluation of childhood pseudoseizures using EEG telemetry and video tape monitoring. J Pediatr. Oct. 1980;97(4):554-8. [pmid: 7420217].
Holmes M D, Born D E, Kutsy R L, et al. Outcome after surgery in patients with refractory temporal lobe epilepsy and normal MRI. Seizure. Sep. 2000;9(6):407-11. [pmid: 10985997].
Holmes M D, Dodrill C B. What is the significance of subjective events recorded during long-term EEG video monitoring?. Epilepsia. Aug. 1998;39(8):857-62. [pmid: 9701376].
Holmes M D, Dodrill C B, Ojemann L M, et al. Five-year outcome after epilepsy surgery in nonmonitored and monitored surgical candidates. Epilepsia. Aug. 1996;37(8):748-52. [pmid: 8764813].
Holmes M D, Dodrill C B, Wilkus R J, et al. Is partial epilepsy progressive? Ten-year follow-up of EEG and neuropsychological changes in adults with partial seizures. Epilepsia. Nov. 1998;39(11):1189-93. [pmid: 9821983].
Holmes M D, Wilensky A J, Ojemann G A, et al. Hippocampal or neocortical lesions on magnetic resonance imaging do not necessarily indicate site of ictal onsets in partial epilepsy. Ann Neurol. Apr. 1999;45(4):461-5. [pmid: 10211470].
Hong S C, Kang K S, Seo D W, et al. Surgical treatment of intractable epilepsy accompanying cortical dysplasia. J Neurosurg. Nov. 2000;93(5):766-73. [pmid: 11059656].
Hopkins I J, Klug G L. Temporal lobectomy for the treatment of intractable complex partial seizures of temporal lobe origin in early childhood. Dev Med Child Neurol. Jan. 1991;33(1):26-31. [pmid: 1995406].
Hoppe C, Helmstaedter C, Scherrmann J, et al. No evidence for cognitive side effects after 6 months of vagus nerve stimulation in epilepsy patients. Epilepsy Behav. Aug. 2001;2(4):351-6. [pmid: 12609212].
Hosain S, Nikalov B, Harden C, et al. Vagus nerve stimulation treatment for Lennox-Gastaut syndrome. J Child Neurol. Aug. 2000;15(8):509-12. [pmid: 10961788].
Hufnagel A, Zentner J, Fernandez G, et al. Multiple subpial transection for control of epileptic seizures: effectiveness and safety. Epilepsia. 1997;38(6):678-88. [pmid: 9186250].
Huttenlocher P R, Hapke R J. A follow-up study of intractable seizures in childhood. Ann Neurol. Nov. 1990;28(5):699-705. [pmid: 2260857].
Iannelli A, Guzzetta F, Battaglia D, et al. Surgical treatment of temporal tumors associated with epilepsy in children. Pediatr Neurosurg. May. 2000;32(5):248-54. [pmid: 10965271].
Irwig L, Tosteson A N, Gatsonis C, et al. Guidelines for meta-analyses evaluating diagnostic tests. Ann Intern Med. Apr. 1994;120(8):667-76. [pmid: 8135452].
Ivnik R J, Sharbrough F W, Laws E R jr. Anterior temporal lobectomy for the control of partial complex seizures: information for counseling patients. Mayo Clin Proc. Aug. 1988;63(8):783-93. [pmid: 3398596].
Jallon P. The problem of intractability: the continuing need for new medical therapies in epilepsy. Epilepsia. 1997;38(Suppl 9):S37-42. [pmid: 9578544].
Jan M M, Sadler M, Rahey S R. Lateralized postictal EEG delta predicts the side of seizure surgery in temporal lobe epilepsy. Epilepsia. Mar. 2001;42(3):402-5. [pmid: 11442160].
Jawad S, Richens A, Goodwin G, et al. Controlled trial of lamotrigine (Lamictal) for refractory partial seizures. Epilepsia. 1989;30(3):356-63. [pmid: 2498073].
Jedrzejczak J, Owczarek K. Patients with coexistent psychogenic pseudoepileptic and epileptic seizures: a psychological profile. Seizure;10:566–9.
Jick S S, Cole T B, Mesher R A, et al. Sudden unexplained death in young persons with primary epilepsy. Pharmacoepidemiol Drug Safe. 1992;1:59-64.
Jokeit H, Ebner A. Long term effects of refractory temporal lobe epilepsy on cognitive abilities: a cross sectional study. J Neurol Neurosurg Psychiatry. Jul. 1999;67(1):44-50. [pmid: 10369821].
Jooma R, Yeh H S, Privitera M D, et al. Lesionectomy versus electrophysiologically guided resection for temporal lobe tumors manifesting with complex partial seizures. J Neurosurg. Aug. 1995a;83(2):231-6. [pmid: 7616267].
Jooma R, Yeh H S, Privitera M D, et al. Seizure control and extent of mesial temporal resection. Acta Neurochir (Wien). 1995b;133(12):44-9. [pmcid: 300905]. [pmid: 8561035].
Joy Andrews D, Reiter J M, Schonfeld W, et al. A neurobehavioral treatment for unilateral complex partial seizure disorders: a comparison of right- and left-hemisphere patients. Seizure. Apr. 2000;9(3):189-97. [pmid: 10775515].
Jozwiak S, Terczynski A. Open study evaluating lamotrigine efficacy and safety in add-on treatment and consecutive monotherapy in patients with carbamazepine- or valproate-resistant epilepsy. Seizure. Oct. 2000;9(7):486-92. [pmid: 11034873].
Juhasz C, Chugani D C, Muzik O, et al. Relationship between EEG and positron emission tomography abnormalities in clinical epilepsy. J Clin Neurophysiol. Jan. 2000;17(1):29-42. [pmid: 10709809].
Kalviainen R. Tiagabine: a new therapeutic option for people with intellectual disability and partial epilepsy. J Intellect Disabil Res. Dec. 1998;42(Suppl 1):63-7. [pmid: 10030435].
Kalviainen R, Salmenpera T, Partanen K, et al. Recurrent seizures may cause hippocampal damage in temporal lobe epilepsy. Neurology. May. 1998;50(5):1377-82. [pmid: 9595990].
Kanemoto K, Kim Y, Miyamoto T, et al. Presurgical postictal and acute interictal psychoses are differentially associated with postoperative mood and psychotic disorders. J Neuropsychiatry Clin Neurosci 2001 Spring;13(2):243-7.
Kanner AM PJFM. The ‘forgotten’ cross-tolerance between phenobarbital and primidone: it can prevent acute primidone-related toxicity. Kanner AM, Parra J, Frey M. The ‘forgotten’ cross-tolerance between phenobarbital and primidone: it can prevent acute primidone-related toxicity. Epilepsia 2000 Oct;41(10):1310-4.: EPC5cites_everything, Helen_transfer , EPC0005 . Epilepsia. 41. 2000:1310–4.
Karande S C, Joshi M V, Kshirsagar N A, et al. ‘An analysis of epileptic patients nonresponsive to drugs’. J Assoc Physicians India. Jul. 1992;40(7):445-7. [pmid: 1484024].
Kaufman D W, Kelly J P, Anderson T, et al. Evaluation of case reports of aplastic anemia among patients treated with felbamate. Epilepsia. Dec. 1997;38(12):1265-9. [pmid: 9578520].
Keene D L, Higgins M J, Ventureyra E C. Outcome and life prospects after surgical management of medically intractable epilepsy in patients under 18 years of age. Childs Nerv Syst. Oct. 1997;13(10):530-5. [pmid: 9403201].
Keene D L, Whiting S, Ventureyra E C. Electrocorticography. Epileptic Disord. Mar. 2000;2(1):57-63. [pmid: 10937174].
Kelsey JL, Whittemore AS, Evans AS, et al. Methods in observational epidemiology. 2nd ed. New York (NY): Oxford University Press; 1996. 432 p. (Monographs in epidemiology and biostatistics; vol. 26).
Kendrick A M, Duncan J S, Trimble M R. Effects of discontinuation of individual antiepileptic drugs on mood. Hum Psychopharmacol. 1993;8(4):263-270.
Kennedy P A, Schallert G. Practical issues and concepts in vagus nerve stimulation: a nursing review. J Neurosci Nurs. Apr. 2001;33(2):105-11. [pmid: 11326619].
Ketter T A, Malow B A, Flamini R, et al. Felbamate monotherapy has stimulant-like effects in patients with epilepsy. Epilepsy Res. Mar. 1996;23(2):129-37. [pmid: 8964274].
Kilpatrick C, Cook M, Kaye A, et al. Non-invasive investigations successfully select patients for temporal lobe surgery. J Neurol Neurosurg Psychiatry. Sep. 1997;63(3):327-33. [pmid: 9328249].
King D W, Flanigin H F, Gallagher B B, et al. Temporal lobectomy for partial complex seizures: evaluation, results, and 1-year follow-up. Neurology. Mar. 1986;36(3):334-9. [pmid: 3951699].
Klenerman P, Sander J W, Shorvon S D. Mortality in patients with epilepsy: a study of patients in long term residential care. J Neurol Neurosurg Psychiatry. Feb. 1993;56(2):149-52. [pmid: 8437003].
Kloster R, Engelskjon T. Sudden unexpected death in epilepsy (SUDEP): a clinical perspective and a search for risk factors. J Neurol Neurosurg Psychiatry. Oct. 1999;67(4):439-44. [pmid: 10486388].
Kloster R, Larsson P G, Lossius R, et al. The effect of acupuncture in chronic intractable epilepsy. Seizure. May. 1999;8(3):170-4. [pmid: 10356376].
Kohler C G, Carran M A, Bilker W, et al. Association of fear auras with mood and anxiety disorders after temporal lobectomy. Epilepsia. May. 2001;42(5):674-81. [pmid: 11380577].
Kotchoubey B, Busch S, Strehl U, et al. Changes in EEG power spectra during biofeedback of slow cortical potentials in epilepsy. Appl Psychophysiol Biofeedback. Dec. 1999;24(4):213-33. [pmid: 10788999].
Kotchoubey B, Schneider D, Schleichert H, et al. Self-regulation of slow cortical potentials in epilepsy: a retrial with analysis of influencing factors. Epilepsy Res. Nov. 1996;25(3):269-76. [pmid: 8956926].
Kotchoubey B, Strehl U, Holzapfel S, et al. Negative potential shifts and the prediction of the outcome of neurofeedback therapy in epilepsy. Clin Neurophysiol. Apr. 1999;110(4):683-6. [pmid: 10378738].
Kral T, Kuczaty S, Blumcke I, et al. Postsurgical outcome of children and adolescents with medically refractory frontal lobe epilepsies. Childs Nerv Syst. Oct. 2001;17(10):595-601. [pmid: 11685521].
Kumlien E, Doss R C, Gates J R. Treatment outcome in patients with mesial temporal sclerosis. Seizure. 2001;0:1-5.
Kuyk J, Spinhoven P, van Dyck R. Hypnotic recall: a positive criterion in the differential diagnosis between epileptic and pseudoepileptic seizures. Epilepsia. Apr. 1999;40(4):485-91. [pmid: 10219276].
Kwan S Y, Wong T T, Chang K P, et al. Seizure outcomes after anterior callosotomy in patients with posterior-dominant and with anterior-dominant epileptiform discharges. Childs Nerv Syst. Jan. 2001;17(12):71-5. [pmid: 11219628].
Labar D, Murphy J, Tecoma E. Vagus nerve stimulation for medication-resistant generalized epilepsy. E04 VNS Study Group. Neurology. Apr. 1999;52(7):1510-2. [pmid: 10227649].
Labar D, Nikolov B, Tarver B, et al. Vagus nerve stimulation for symptomatic generalized epilepsy: a pilot study. Epilepsia. Feb. 1998;39(2):201-5. [pmid: 9578001].
Lambert P C, Sutton A J, Abrams K R, et al. A comparison of summary patient-level covariates in meta-regression with individual patient data meta-analysis. J Clin Epidemiol. Jan. 2002;55(1):86-94. [pmid: 11781126].
Lancman M E, Asconape J J, Craven W J, et al. Predictive value of induction of psychogenic seizures by suggestion. Ann Neurol. Mar. 1994;35(3):359-61. [pmid: 8122889].
Langtry H D, Gillis J C, Davis R. Topiramate. A review of its pharmacodynamic and pharmacokinetic properties and clinical efficacy in the management of epilepsy. Drugs. Nov. 1997;54(5):752-73. [pmid: 9360061].
Lantz D L, Sterman M B. Neuropsychological assessment of subjects with uncontrolled epilepsy: effects of EEG feedback training. Epilepsia. 1988;29(2):163-71. [pmid: 3349967].
Laxer K D, Mullooly J P, Howell B. Prolactin changes after seizures classified by EEG monitoring. Neurology. Jan. 1985;35(1):31-5. [pmid: 3965999].
Lee B I, Markand O N, Stewart W A, et al. Evaluation of patients with intractable seizures for epilepsy surgery at Indiana University Medical Center. Indiana Med. May. 1986;79(5):420-4. [pmid: 3088098].
Leestma J E, Annegers J F, Brodie M J, et al. Sudden unexplained death in epilepsy: observations from a large clinical development program. Epilepsia. Jan. 1997;38(1):47-55. [pmid: 9024183].
Leppik I E. Monotherapy and polypharmacy. Neurology. 2000;55(11 Suppl 3):S25-9. [pmid: 11147565].
Leppik I E. Rational monotherapy for epilepsy. Baillieres Clin Neurol. Dec. 1996;5(4):749-55. [pmid: 9068878].
Leppik I E. Tiagabine: the safety landscape. Epilepsia. 1995;36(Suppl 6):S10-S13. [pmid: 8595787].
Leppik I E, Dreifuss F E, Pledger G W, et al. Felbamate for partial seizures: results of a controlled clinical trial. Neurology. Nov. 1991;41(11):1785-9. [pmid: 1944909].
Lesser R P, Arroyo S, Crone N, et al. Motor and sensory mapping of the frontal and occipital lobes. Epilepsia. 1998;39(Suppl 4):S69-80. [pmid: 9637595].
Lesser RP, Fisher RS, Uematsu S. Assessment of surgical outcome. Epilepsy Res 1992(Suppl 5):217–29.
Lesser R P, Pippenger C E, Luders H, et al. High-dose monotherapy in treatment of intractable seizures. Neurology. 1984;34:707-11. [pmid: 6539430].
Leung G K, Fan Y W, Fong K Y. Temporal lobe resection for intractable epilepsy: review of 11 cases. Hong Kong Med J. Dec. 1999;5(4):329-336. [pmid: 10870158].
Levisohn P M. Epilepsy surgery in children with developmental disabilities. Semin Pediatr Neurol. Sep. 2000;7(3):194-203. [pmid: 11023177].
Lewis D V. Febrile convulsions and mesial temporal sclerosis. Curr Opin Neurol. Apr. 1999;12(2):197-201. [pmid: 10226753].
Lhatoo S D, Johnson A L, Goodridge D M, et al. Mortality in epilepsy in the first 11 to 14 years after diagnosis: multivariate analysis of a long-term, prospective, population-based cohort. Ann Neurol. Mar. 2001;49(3):336-44. [pmid: 11261508].
Libman M D, Potvin L, Coupal L, et al. Seizure vs. syncope: measuring serum creatine kinase in the emergency department. J Gen Intern Med. 1991;6(5):408-12. [pmid: 1744754].
Lieb J P, Engel J Jr, Babb T L. Interhemispheric propagation time of human hippocampal seizures. I. Relationship to surgical outcome. Epilepsia. 1986;27(3):286-93. [pmid: 3516670].
Lieb J P, Walsh G O, Babb T L, et al. A comparison of EEG seizure patterns recorded with surface and depth electrodes in patients with temporal lobe epilepsy. Epilepsia. 1976;17:137-60. [pmid: 947745].
Lijmer J G, Mol B W, Heisterkamp S, et al. Empirical evidence of design-related bias in studies of diagnostic tests. JAMA. Sep. 1999;282(11):1061-6. [pmid: 10493205].
Lindsay J, Ounsted C, Richards P. Hemispherectomy for childhood epilepsy: a 36-year study. Dev Med Child Neurol. Oct. 1987;29(5):592-600. [pmid: 3666325].
Liporace J, Hucko D, Morrow R, et al. Vagal nerve stimulation: adjustments to reduce painful side effects. Neurology. Sep. 2001;57(5):885-6. [pmid: 11552021].
Littenberg B, Moses LE. Estimating diagnostic accuracy from multiple conflicting reports: a new meta-analytic method. Med Decis Making 1993 Oct-1993 Dec;13(4):313–21.
Liu MY, Yeh HS, Blisard K, et al. Surgical management of epilepsy associated with developmental anomalies of the brain. Surg Neurol 1995 Feb;43(2):182–8; discussion 188–90.
Loiseau P. Review of controlled trials of gabitril (tiagabine): a clinician's viewpoint. Epilepsia. 1999;40(Suppl 9):S14-9. [pmid: 10612357].
Loring D W, Meador K J. Cognitive and behavioral effects of epilepsy treatment. Epilepsia. 2001;42(Suppl 8):24-32. [pmid: 11902326].
Lundgren J, Amark P, Blennow G, et al. Vagus nerve stimulation in 16 children with refractory epilepsy. Epilepsia. Aug. 1998;39(8):809-13. [pmid: 9701369].
Lusic I, Pintaric I, Hozo I, et al. Serum prolactin levels after seizure and syncopal attacks. Seizure. Jun. 1999;8(4):218-22. [pmid: 10452919].
Mackenzie RA, Matheson JM, Smith JS, et al. Surgery for refractory epilepsy. Med J Aust 1990 Jul;153(2):69–72, 76.
Maehara T, Shimizu H. Surgical outcome of corpus callosotomy in patients with drop attacks. Epilepsia. Jan. 2001;42(1):67-71. [pmid: 11207787].
Maher J, McLachlan R S. Antiepileptic drug treatment following temporal lobectomy. Neurology. Jul. 1998;51(1):305-7. [pmid: 9674830].
Mak S C, Chi C S, Wan C J. Clinical experience of ketogenic diet on children with refractory epilepsy. Acta Paediatr Taiwan. 1999;40(2):97-100. [pmid: 10910595].
Makuch R, Simon R. Sample size requirements for evaluating a conservative therapy. Cancer Treat Rep. Jul. 1978;62(7):1037-40. [pmid: 688245].
Manchanda R, Schaefer B, McLachlan R S, et al. Psychiatric disorders in candidates for surgery for epilepsy. J Neurol Neurosurg Psychiatry. Jul. 1996;61(1):82-9. [pmid: 8676167].
Marino R Jr, Radvany J, Huck F R, et al. Selective electroencephalograph-guided microsurgical callosotomy for refractory generalized epilepsy. Surg Neurol. Oct. 1990;34(4):219-28. [pmid: 2399483].
Markand O N, Salanova V, Whelihan E, et al. Health-related quality of life outcome in medically refractory epilepsy treated with anterior temporal lobectomy. Epilepsia. Jun. 2000;41(6):749-59. [pmid: 10840409].
Mathern G W, Giza C C, Yudovin S, et al. Postoperative seizure control and antiepileptic drug use in pediatric epilepsy surgery patients: the UCLA experience, 1986-1997. Epilepsia. Dec. 1999;40(12):1740-9. [pmid: 10612338].
Matsuo F, Bergen D, Faught E, et al. Placebo-controlled study of the efficacy and safety of lamotrigine in patients with partial seizures. U.S. Lamotrigine Protocol 0.5 Clinical Trial Group. Neurology. Nov. 1993;43(11):2284-91. [pmid: 8232944].
Matsuzaka T, Ono K, Baba H, et al. Quantitative EEG analyses and surgical outcome after corpus callosotomy. Epilepsia. Sep. 1999;40(9):1269-78. [pmid: 10487191].
May T W, Bulmahn A, Wohlhuter M, et al. Effects of withdrawal of phenytoin on cognitive and psychomotor functions in hospitalized epileptic patients on polytherapy. Acta Neurol Scand. Aug. 1992;86(2):165-70. [pmid: 1414227].
McCabe P H, McNew C D, Michel N C. Effect of divalproex-lamotrigine combination therapy in frontal lobe seizures. Arch Neurol. Aug. 2001;58(8):1264-8. [pmid: 11493167].
McInerney J, Siegel A M, Nordgren R E, et al. Long-term seizure outcome following corpus callosotomy in children. Stereotactic Funct Neurosurg. 1999;73(14):79-83.
McKee J R, Bodfish J W. Sudden unexpected death in epilepsy in adults with mental retardation. Am J Ment Retard. Jul. 2000;105(4):229-35. [pmid: 10934565].
McLachlan RS, Maher J. Management of antiepileptic drugs following epilepsy surgery: a review. Can J Neurol Sci 2000 May;27(Suppl 1):S106–10; discussion S121.
McLachlan R S, Rose K J, Derry P A, et al. Health-related quality of life and seizure control in temporal lobe epilepsy. Ann Neurol. Apr. 1997;41(4):482-9. [pmid: 9124805].
McLean M J, Morrell M J, Willmore L J, et al. Safety and tolerability of gabapentin as adjunctive therapy in a large, multicenter study. Epilepsia. Jul. 1999;40(7):965-72. [pmid: 10403221].
McLean M J, Ramsay R E, Leppik L E, et al. Gabapentin as add-on therapy in refractory partial epilepsy: a double-blind, placebo-controlled, parallel-group study. Neurology. 1993;43(11):2292-8. [pmid: 8232945].
Meador K J, Baker G A. Behavioral and cognitive effects of lamotrigine. J Child Neurol. Nov. 1997;12(Suppl 1):S44-7. [pmid: 9429130].
Messenheimer J, Ramsay R E, Willmore L J, et al. Lamotrigine therapy for partial seizures: a multicenter, placebo-controlled, double-blind, cross-over trial. Epilepsia. 1994;35(1):113-21. [pmid: 8112232].
Meyer F B, Marsh W R, Laws E R Jr, et al. Temporal lobectomy in children with epilepsy. J Neurosurg. Mar. 1986;64(3):371-6. [pmid: 3950715].
Mikati M A, Holmes G L. Lamotrigine in absence and primary generalized epilepsies. J Child Neurol. Nov. 1997;12(Suppl 1):S29-37. [pmid: 9429128].
Milano Collaborative Group for Studies on Epilepsy. Long-term intensive monitoring in the difficult patient. Preliminary results of 16 months of observations - usefulness and limitations. In: Gardner-Thorpe C, Janz D, Meinardi H, et al, editors. Antiepileptic drug monitring. Kent: Pitman Medical; 1977. p. 197–213.
Miranda C, Smith M L. Predictors of intelligence after temporal lobectomy in children with epilepsy. Epilepsy Behav. Feb. 2001;2(1):13-9. [pmid: 12609177].
Mirza W U, Credeur L J, Penry J K. Results of antiepileptic drug reduction in patients with multiple handicaps and epilepsy. Drug Invest. 1993;5(6):320-6.
Mishra V, Gahlaut D S, Kumar S. Value of serum prolactin in differentiating epilepsy from pseudoseizures. J Assoc Physicians India. 1990;38:846-7. [pmid: 2079470].
Mitchell L A, Jackson G D, Kalnins R M, et al. Anterior temporal abnormality in temporal lobe epilepsy: a quantitative MRI and histopathologic study. Neurology. Jan. 1999;52(2):327-36. [pmid: 9932952].
Mizrahi E M, Kellaway P, Grossman R G, et al. Anterior temporal lobectomy and medically refractory temporal lobe epilepsy of childhood. Epilepsia. 1990;31(3):302-12. [pmid: 2344847].
Mohan K K, Chugani D C, Chugani H T, et al. Positron emission tomography in pediatric neurology. Semin Pediatr Neurol. Jun. 1999;6(2):111-9. [pmid: 10404565].
Mohan K K, Markand O N, Salanova V, et al. Diagnostic utility of video EEG monitoring in paroxysmal events. Acta Neurol Scand. Nov. 1996;94(5):320-5. [pmid: 8947283].
Moran N F, Lemieux L, Maudgil D, et al. Analysis of temporal lobe resections in MR images. Epilepsia. Aug. 1999;40(8):1077-84. [pmid: 10448819].
Morrell F, Kanner A M, de Toledo-Morrell L, et al. Multiple subpial transection. Adv Neurol. 1999;81:259-70. [pmid: 10609022].
Morrell F, Whisler W W, Bleck T P. Multiple subpial transection: a new approach to the surgical treatment of focal epilepsy. J Neurosurg. Feb. 1989;70(2):231-9. [pmid: 2492335].
Morrell F, Whisler W W, Smith M C, et al. Landau-Kleffner syndrome. Treatment with subpial intracortical transection. Brain. Dec. 1995;118(Pt 6):1529-46. [pmid: 8595482].
Morrell M J, McLean M J, Willmore L J, et al. Efficacy of gabapentin as adjunctive therapy in a large, multicenter study. The Steps Study Group. Seizure. Jun. 2000;9(4):241-8. [pmid: 10880282].
Morris G L 3rd. Efficacy and tolerability of gabapentin in clinical practice. Clin Ther. 1995;17(5):891-900. [pmid: 8595641].
Moses L E, Shapiro D, Littenberg B. Combining independent studies of a diagnostic test into a summary ROC curve: data-analytic approaches and some additional considerations. Stat Med. Jul. 1993;12(14):1293-316. [pmid: 8210827].
Mosewich R K, So E L, O'Brien T J, et al. Factors predictive of the outcome of frontal lobe epilepsy surgery. Epilepsia. Jul. 2000;41(7):843-9. [pmid: 10897155].
Mosquera D A, Goldman M D. Surgical audit without autopsy: tales of the unexpected. Ann R Coll Surg Engl. Mar. 1993;75(2):115-7. [pmid: 8476178].
Mulligan L P, Spencer D D, Spencer S S. Multiple subpial transections: the Yale experience. Epilepsia. Feb. 2001;42(2):226-9. [pmid: 11240594].
Murro A M, Flanigin H F, Gallagher B B, et al. Corpus callosotomy for the treatment of intractable epilepsy. Epilepsy Res. 1988;2(1):44-50. [pmid: 3197679].
Murthy J M, Yangala R. Etiological spectrum of symptomatic localization related epilepsies: a study from South India. J Neurol Sci. Jun. 1998;158(1):65-70. [pmid: 9667780].
Myers J E, Thompson M L, et al. Meta-analysis and occupational epidemiology. Occup Med (Lond). Feb. 1998;48(2):99-101. [pmid: 9614768].
Nagakubo S, Niwa S, Kumagai N, et al. Effects of TJ-960 on Sternberg's paradigm results in epileptic patients. Jpn J Psychiatry Neurol. Sep. 1993;47(3):609-20. [pmid: 8301876].
Nakken K O, Bjorholt P G, Johannessen S I, et al. Effect of physical training on aerobic capacity, seizure occurrence, and serum level of antiepileptic drugs in adults with epilepsy. Epilepsia. 1990;31(1):88-94. [pmid: 2303017].
Nashef L, Fish D R, Sander J W, et al. Incidence of sudden unexpected death in an adult outpatient cohort with epilepsy at a tertiary referral centre. J Neurol Neurosurg Psychiatry. Apr. 1995;58(4):462-4. [pmid: 7738555].
Nashef L, Sander J W. Sudden unexpected deaths in epilepsy--where are we now?. Seizure. Sep. 1996;5(3):235-8. [pmid: 8902927].
Naylor A S, Rogvi-Hansen B, Kessing L, et al. Psychiatric morbidity after surgery for epilepsy: short term follow up of patients undergoing amygdalohippocampectomy. J Neurol Neurosurg Psychiatry. 1994;57(11):1375-81. [pmid: 7964815].
Nees H, Moriarty J, Kitchen N D, et al. Psychosocial and neurobehavioral factors related to surgical treatment for partial epilepsy: a multivariate analysis. Epilepsy Behav. Apr. 2001;2(2):135-9. [pmid: 12609197].
Neufeld M Y, Korczyn A D. New drugs and vagal stimulation for treatment of epilepsy--the Israeli experience. Neurol Neurochir Pol. 1996;30(Suppl 2):113-20. [pmid: 9100249].
Neufeld M Y, Treves T A, Chistik V, et al. Sequential serum creatine kinase determination differentiates vaso-vagal syncope from generalized tonic-clonic seizures. Acta Neurol Scand. Mar. 1997;95(3):137-9. [pmid: 9088380].
Nilsson L, Farahmand B Y, Persson P G, et al. Risk factors for sudden unexpected death in epilepsy: a case-control study. Lancet. Mar. 1999;353(9156):888-93. [pmid: 10093982].
Nordgren R E, Reeves A G, Viguera A C, et al. Corpus callosotomy for intractable seizures in the pediatric age group. Arch Neurol. Apr. 1991;48(4):364-72. [pmid: 2012509].
Nordli D R. Epilepsy surgery in children, with special attention to focal cortical resections. Semin Pediatr Neurol. Sep. 2000;7(3):204-15. [pmid: 11023178].
Nordli D R Jr, Kelley K R. Selection and evaluation of children for epilepsy surgery. Pediatr Neurosurg. Jan. 2001;34(1):1-12. [pmid: 11275781].
Noseworthy J H, Ebers G C, Vandervoort M K, et al. The impact of blinding on the results of a randomized, placebo-controlled multiple sclerosis clinical trial. Neurology. Jan. 1994;44(1):16-20. [pmid: 8290055].
Nousiainen U, Suomalainen T, Mervaala E. Clinical benefits of scalp EEG studies in intractable seizure disorders. Acta Neurol Scand. Mar. 1992;85(3):181-6. [pmid: 1575000].
Novotny E, Ashwal S, Shevell M. Proton magnetic resonance spectroscopy: an emerging technology in pediatric neurology research. Pediatr Res. Jul. 1998;44(1):1-10. [pmid: 9667363].
Office for National Statistics, General Register Office for Scotland, Northern Ireland Statistics and Research Agency. 7.3 Age-standardised mortality rates: by cause, gender and NHS regional office area 1999.[internet]. United Kingdom: National Health Service; 1999[cited 2001 Oct 11].[1 p]. Available: http://www.statistics.gov.uk/statbase/.
Office for National Statistics. Mortality statistics: general. Review of the Registrar General on deaths in England and Wales, 1999. London (UK): The Stationery Office; 2001. (Series DH1; no. 32). Also available: http://www.statistics.gov.uk/statbase.
Oguni H, Olivier A, Andermann F, et al. Anterior callosotomy in the treatment of medically intractable epilepsies: a study of 43 patients with a mean follow-up of 39 months. Ann Neurol. Sep. 1991;30(3):357-64. [pmid: 1952824].
Ogunmekan A O, Hwang P A. A randomized, double-blind, placebo-controlled, clinical trial of D-alpha-tocopheryl acetate (vitamin E), as add-on therapy, for epilepsy in children. Epilepsia. 1989;30(1):84-9. [pmid: 2643513].
Ohman R, Walinder J, Balldin J, et al. Prolactin response to electroconvulsive therapy. Lancet. Oct. 1976;2(7992):936-7. [pmid: 62165].
Ohtsuka Y, Ogino T, Asano T, et al. Long-term follow-up of vitamin B(6)-responsive West syndrome. Pediatr Neurol. Sep. 2000;23(3):202-6. [pmid: 11033281].
Ojemann G A. Treatment of temporal lobe epilepsy. Annu Rev Med. 1997;48:317-28. [pmid: 9046965].
Ojemann G A, Dodrill C B. Verbal memory deficits after left temporal lobectomy for epilepsy. Mechanism and intraoperative prediction. J Neurosurg. Jan. 1985;62(1):101-7. [pmid: 3964840].
Olivier A. Surgical techniques in temporal lobe epilepsy. Clin Neurosurg. 1997;44:211-41. [pmid: 10080010].
Olson D M. Evaluation of children for epilepsy surgery. Pediatr Neurosurg. Mar. 2001;34(3):159-65. [pmid: 11359105].
Orbach D, Romanelli P, Devinsky O, et al. Late seizure recurrence after multiple subpial transections. Epilepsia. 2001;49(9):1130-33. [pmid: 11580759].
Ozuna J, et al. Ethical dilemmas in people with epilepsy who drive. Clin Nurs Pract Epilepsy. Mar. 1998;5(1):7-10. [pmid: 9726191].
Pacia S V, Devinsky O, Perrine K, et al. Multiple subpial transection for intractable partial seizures: seizure outcome. J Epilepsy. 1997;10(2):86-91.
Palmini A. Medical and surgical strategies for epilepsy care in developing countries. Epilepsia. 2000;41(Suppl 4):S10-7. [pmid: 10963471].
Palmini A, Andermann F, Olivier A, et al. Focal neuronal migration disorders and intractable partial epilepsy: results of surgical treatment. Ann Neurol. Dec. 1991;30(6):750-7. [pmid: 1789692].
Panjwani U, Selvamurthy W, Singh S H, et al. Effect of Sahaja yoga practice on seizure control & EEG changes in patients of epilepsy. Indian J Med Res. Mar. 1996;103:165-72. [pmid: 9062044].
Parker A P, Polkey C E, Binnie C D, et al. Vagal nerve stimulation in epileptic encephalopathies. Pediatrics. Apr. 1999;103(4 Pt 1):778-82. [pmid: 10103302].
Parrent A G, Blume W T. Stereotactic amygdalohippocampotomy for the treatment of medial temporal lobe epilepsy. Epilepsia. Oct. 1999;40(10):1408-16. [pmid: 10528937].
Patil AA, Andrews RV, Torkelson R. Surgical treatment of intractable seizures with multilobar or bihemispheric seizure foci (MLBHSF). Surg Neurol 1997 Jan;47(1):72–7; discussion 77–8.
Patrick D L, Deyo R A. Generic and disease-specific measures in assessing health status and quality of life. Med Care. Mar. 1989;27(3 Suppl):S217-32. [pmid: 2646490].
Peacock W J, Wehby-Grant M C, Shields W D, et al. Hemispherectomy for intractable seizures in children: a report of 58 cases. Childs Nerv Syst. Jul. 1996;12(7):376-84. [pmid: 8869773].
Pellock J M. Treatment of seizures and epilepsy in children and adolescents. Neurology. Nov. 1998;51(5 Suppl 4):S8-14. [pmid: 9818918].
Pellock J M, Watemberg N. New antiepileptic drugs in children: present and future. Semin Pediatr Neurol. Mar. 1997;4(1):9-18. [pmid: 9097362].
Perry T R, Gumnit R J, Gates J R, et al. Routine EEG vs. intensive monitoring in the evaluation of intractable epilepsy. Public Health Rep. 1983;98(4):384-9. [pmid: 6611825].
Perucca E. The management of refractory idiopathic epilepsies. Epilepsia. 2001;42(Suppl 3):31-5. [pmid: 11520320].
Perucca E. The new generation of antiepileptic drugs: advantages and disadvantages. Br J Clin Pharmacol. Nov. 1996;42(5):531-43. [pmid: 8951184].
Perucca E. Trial duration and follow-up. Epilepsy Res 2001 May;45(1–3):123–7; discussion 129–31.
Petitti D B. Approaches to heterogeneity in meta-analysis. Stat Med. Dec. 2001;20(23):3625-33. [pmid: 11746342].
Phelps C E, Hutson A. Estimating diagnostic test accuracy using a ‘fuzzy gold standard’. Med Decis Making. 1995;15(1):44-57. [pmid: 7898298].
Pierelli F, Chatrian G E, Erdly W W, et al. Long-term EEG-video-audio monitoring: detection of partial epileptic seizures and psychogenic episodes by 24-hour EEG record review. Epilepsia. 1989;30(5):513-23. [pmid: 2507300].
Pinard J M, Delalande O, Chiron C, et al. Callosotomy for epilepsy after West syndrome. Epilepsia. Dec. 1999;40(12):1727-34. [pmid: 10612336].
Powell G E, Polkey C E, McMillan T. The new Maudsley series of temporal lobectomy. I: Short-term cognitive effects. Br J Clin Psychol. May. 1985;24(Pt 2):109-24. [pmid: 3924150].
Pritchard P B 3rd, Wannamaker B B, Sagel J, et al. Serum prolactin and cortisol levels in evaluation of pseudoepileptic seizures. Ann Neurol. Jul. 1985;18(1):87-9. [pmid: 4037754].
Privitera M, Fincham R, Penry J, et al. Topiramate placebo-controlled dose-ranging trial in refractory partial epilepsy using 600-, 800-, and 1,000-mg daily dosages. Topiramate YE Study Group. Neurology. Jun. 1996;46(6):1678-83. [pmid: 8649569].
Provinciali L, Del Pesce M, Censori B, et al. Evolution of neuropsychological changes after partial callosotomy in intractable epilepsy. Epilepsy Res. Jul. 1990;6(2):155-65. [pmid: 2117530].
Provini F, Plazzi G, Lugaresi E. From nocturnal paroxysmal dystonia to nocturnal frontal lobe epilepsy. Clin Neurophysiol. Sep. 2000;111(Suppl 2):S2-8. [pmid: 10996549].
Pulsifer M B, Gordon J M, Brandt J, et al. Effects of ketogenic diet on development and behavior: preliminary report of a prospective study. Dev Med Child Neurol. May. 2001;43(5):301-6. [pmid: 11368482].
Purves S J, Wada J A, Woodhurst W B, et al. Results of anterior corpus callosum section in 24 patients with medically intractable seizures. Neurology. Aug. 1988;38(8):1194-201. [pmid: 3399067].
Puskarich C A, Whitman S, Dell J, et al. Controlled examination of effects of progressive relaxation training on seizure reduction. Epilepsia. 1992;33(4):675-80. [pmid: 1628583].
Racoosin J A, Feeney J, Burkhart G, et al. Mortality in antiepileptic drug development programs. Neurology. Feb. 2001;56(4):514-9. [pmid: 11222797].
Radhakrishnan K, So E L, Silbert P L, et al. Predictors of outcome of anterior temporal lobectomy for intractable epilepsy: a multivariate study. Neurology. Aug. 1998;51(2):465-71. [pmid: 9710020].
Ransohoff D F, Feinstein A R. Problems of spectrum and bias in evaluating the efficacy of diagnostic tests. N Engl J Med. Oct. 1978;299(17):926-30. [pmid: 692598].
Rao M B, Radhakrishnan K. Is epilepsy surgery possible in countries with limited resources?. Epilepsia. 2000;41(Suppl 4):S31-4. [pmid: 10963475].
Rao M L, Stefan H, Bauer J. Epileptic but not psychogenic seizures are accompanied by simultaneous elevation of serum pituitary hormones and cortisol levels. Neuroendocrinology. Jan. 1989;49(1):33-9. [pmid: 2716948].
Rasmussen T. Tailoring of cortical excisions for frontal lobe epilepsy. Can J Neurol Sci. Nov. 1991;18(4 Suppl):606-10. [pmid: 1777880].
Rasmussen T, Feindel W. Temporal lobectomy: review of 100 cases with major hippocampectomy. Can J Neurol Sci. Nov. 1991;18(4 Suppl):601-2. [pmid: 1777878].
Reeves A L, So E L, Evans R W, et al. Factors associated with work outcome after anterior temporal lobectomy for intractable epilepsy. Epilepsia. Jun. 1997;38(6):689-95. [pmid: 9186251].
Regis Y, Roberts D W. Gamma Knife radiosurgery relative to microsurgery: epilepsy. Stereotactic Funct Neurosurg. 1999;72(Suppl 1):11-21.
Reinikainen K J, Keranen T, Halonen T, et al. Comparison of oxcarbazepine and carbamazepine: a double-blind study. Epilepsy Res. Sep. 1987;1(5):284-9. [pmid: 3504404].
Reiss W G, Oles K S. Acetazolamide in the treatment of seizures. Ann Pharmacother. May. 1996;30(5):514-9. [pmid: 8740334].
Reiter J M, Andrews D J. A neurobehavioral approach for treatment of complex partial epilepsy: efficacy. Seizure. Apr. 2000;9(3):198-203. [pmid: 10775516].
Renowden S A, Matkovic Z, Adams C B, et al. Selective amygdalohippocampectomy for hippocampal sclerosis: postoperative MR appearance. AJNR Am J Neuroradiol. Oct. 1995;16(9):1855-61. [pmid: 8693986].
Reutens D C, Bye A M, Hopkins I J, et al. Corpus callosotomy for intractable epilepsy: seizure outcome and prognostic factors. Epilepsia. 1993;34(5):904-9. [pmid: 8404745].
Rey E, Treluyer J M, Pons G. Pharmacokinetic optimization of benzodiazepine therapy for acute seizures. Focus on delivery routes. Clin Pharmacokinet. Jun. 1999;36(6):409-24. [pmid: 10427466].
Rho J M, Sankar R. The pharmacologic basis of antiepileptic drug action. Epilepsia. Nov. 1999;40(11):1471-83. [pmid: 10565572].
Ring H A, Moriarty J, Trimble M R. A prospective study of the early postsurgical psychiatric associations of epilepsy surgery. J Neurol Neurosurg Psychiatry. May. 1998;64(5):601-4. [pmid: 9598674].
Roberts D W, Darcey T M. The evaluation and image-guided surgical treatment of the patient with a medically intractable seizure disorder. Neurosurg Clin N Am. Apr. 1996;7(2):215-27. [pmid: 8726437].
Roberts R, Fitch P. Monitoring at the National Hospital, Queen Square, London. Electroencephalogr Clin Neurophysiol Suppl. 1985;37:423-36. [pmid: 3924572].
Robinson S, Park T S, Blackburn L B, et al. Transparahippocampal selective amygdalohippocampectomy in children and adolescents: efficacy of the procedure and cognitive morbidity in patients. J Neurosurg. Sep. 2000;93(3):402-9. [pmid: 10969937].
Rockstroh B, Elbert T, Birbaumer N, et al. Cortical self-regulation in patients with epilepsies. Epilepsy Res. Jan. 1993;14(1):63-72. [pmid: 8449180].
Rodary C, Com-Nougue C, Tournade M F. How to establish equivalence between treatments: a one-sided clinical trial in paediatric oncology. Stat Med. May. 1989;8(5):593-8. [pmid: 2543048].
Rohmel J. Therapeutic equivalence investigations: statistical considerations. Stat Med. Aug. 1998;17(1516):1703-14. [pmid: 9749441].
Rose K J, Derry P A, Wiebe S, et al. Determinants of health-related quality of life after temporal lobe epilepsy surgery. Qual Life Res. Jun. 1996;5(3):395-402. [pmid: 8763808].
Rossi G F, Colicchio G, Marchese E, et al. Callosotomy for severe epilepsies with generalized seizures: outcome and prognostic factors. Acta Neurochir (Wien). 1996;138(2):221-7. [pmcid: 300905]. [pmid: 8686549].
Rossi G F, Pompucci A, Colicchio G, et al. Factors of surgical outcome in tumoural epilepsy. Acta Neurochir (Wien). 1999;141(8):819-24. [pmcid: 300905]. [pmid: 10536717].
Rowan A J, Siegel M, Rosenbaum D H. Daytime intensive monitoring: comparison with prolonged intensive and ambulatory monitoring. Neurology. Mar. 1987;37(3):481-4. [pmid: 3822143].
Ryan S W, Forsythe I, Hartley R, et al. Slow release carbamazepine in treatment of poorly controlled seizures. Arch Dis Child. Sep. 1990;65(9):930-5. [pmid: 2221963].
Sachdeo R, Beydoun A, Schachter S, et al. Oxcarbazepine (Trileptal) as monotherapy in patients with partial seizures. Neurology. Sep. 2001;57(5):864-71. [pmid: 11552018].
Sachdeo R C, Glauser T A, Ritter F, et al. A double-blind, randomized trial of topiramate in Lennox-Gastaut syndrome. Topiramate YL Study Group. Neurology. Jun. 1999;52(9):1882-7. [pmid: 10371538].
Sachdeo R C, Leroy R F, Krauss G L, et al. Tiagabine therapy for complex partial seizures. A dose-frequency study. The Tiagabine Study Group. Arch Neurol. May. 1997b;54(5):595-601. [pmid: 9152116].
Sachdeo R C, Reife R A, Lim P, et al. Topiramate monotherapy for partial onset seizures. Epilepsia. Mar. 1997a;38(3):294-300. [pmid: 9070591].
Sachdev P. Schizophrenia-like psychosis and epilepsy: the status of the association. Am J Psychiatry. Mar. 1998;155(3):325-36. [pmid: 9501741].
Sakas D E, Phillips J. Anterior callosotomy in the management of intractable epileptic seizures: significance of the extent of resection. Acta Neurochir (Wien). 1996;138(6):700-7. [pmcid: 300905]. [pmid: 8836285].
Salanova V, Andermann F, Olivier A, et al. Occipital lobe epilepsy: Electroclinical manifestations, electrocorticography, cortical stimulation and outcome in 42 patients treated between 1930 and 1991. Surgery of occipital lobe epilepsy. Brain. 1992;115(6):1655-80. [pmid: 1486456].
Salanova V, Andermann F, Rasmussen T, et al. Parietal lobe epilepsy. Clinical manifestations and outcome in 82 patients treated surgically between 1929 and 1988. Brain. Jun. 1995;118(Pt 3):607-27. [pmid: 7600082].
Salanova V, Andermann F, Rasmussen T, et al. Tumoural parietal lobe epilepsy. Clinical manifestations and outcome in 34 patients treated between 1934 and 1988. Brain. 1995;118(5):1289-304. [pmid: 7496787].
Salanova V, Markand O, Worth R. Longitudinal follow-up in 145 patients with medically refractory temporal lobe epilepsy treated surgically between 1984 and 1995. Epilepsia. Oct. 1999;40(10):1417-23. [pmid: 10528938].
Salinsky M C, Uthman B M, Ristanovic R K, et al. Vagus nerve stimulation for the treatment of medically intractable seizures. Results of a 1-year open-extension trial. Vagus Nerve Stimulation Study Group. Arch Neurol. Nov. 1996;53(11):1176-80. [pmid: 8912492].
Sander J W, Shorvon S D. Incidence and prevalence studies in epilepsy and their methodological problems: a review. J Neurol Neurosurg Psychiatry. Jul. 1987;50(7):829-39. [pmid: 3305790].
Sass K J, Novelly R A, Spencer D D, et al. Postcallosotomy language impairments in patients with crossed cerebral dominance. J Neurosurg. 1990;72(1):85-90. [pmid: 2294190].
Sawhney I M, Robertson I J, Polkey C E, et al. Multiple subpial transection: a review of 21 cases. J Neurol Neurosurg Psychiatry. Mar. 1995;58(3):344-9. [pmid: 7897419].
Saygi S, Katz A, Marks D A, et al. Frontal lobe partial seizures and psychogenic seizures: comparison of clinical and ictal characteristics. Neurology. Jul. 1992;42(7):1274-7. [pmid: 1620332].
Schachter S C. Tiagabine monotherapy in the treatment of partial epilepsy. Epilepsia. 1995;36(Suppl 6):S2-S6. [pmid: 8595789].
Schachter S C, Vazquez B, Fisher R S, et al. Oxcarbazepine: double-blind, randomized, placebo-control, monotherapy trial for partial seizures. Neurology. Mar. 1999;52(4):732-7. [pmid: 10078718].
Scharfman H E. Epileptogenesis in the parahippocampal region. Parallels with the dentate gyrus. Ann N Y Acad Sci. Jun. 2000;911:305-27. [pmid: 10911882].
Schmid-Schoenbein C. Improvement of seizure control by psychological methods in patients with intractable epilepsies. Seizure. Aug. 1998;7(4):261-70. [pmid: 9733400].
Schmidt D. Reduction of two-drug therapy in intractable epilepsy. Epilepsia. Jun. 1983b;24(3):368-76. [pmid: 6406214].
Schmidt D. Single drug therapy for intractable epilepsy. J Neurol. 1983a;229(4):221-6. [pmid: 6192223].
Schmidt D, Gram L, Brodie M, et al. Tiagabine in the treatment of epilepsy--a clinical review with a guide for the prescribing physician. Epilepsy Res. Oct. 2000;41(3):245-51. [pmid: 10962215].
Schmidt D, Jacob R, Loiseau P, et al. Zonisamide for add-on treatment of refractory partial epilepsy: a European double-blind trial. Epilepsy Res. May. 1993;15(1):67-73. [pmid: 8325280].
Schramm J, Behrens E, Entzian W. Hemispherical deafferentation: an alternative to functional hemispherectomy. Neurosurgery 1995 Mar;36(3):509–15; discussion 515–6.
Schramm J, Kral T, Clusmann H, et al. Transsylvian keyhole functional hemispherectomy. Neurosurgery. 2001;49(4):891-901. [pmid: 11564251].
Schramm J, Kral T, Grunwald T, et al. Surgical treatment for neocortical temporal lobe epilepsy: clinical and surgical aspects and seizure outcome. J Neurosurg. Jan. 2001;94(1):33-42. [pmid: 11147895].
Schulz K F, Grimes D A. Blinding in randomised trials: hiding who got what. Lancet. Feb. 2002;359:696-700. [pmid: 11879884].
Schulz K F, Grimes D A. Case-control studies: research in reverse. Lancet. Feb. 2002;359(9304):431-34. [pmid: 11844534].
Schwartz R H, Eaton J, Bower B D, et al. Ketogenic diets in the treatment of epilepsy: short-term clinical effects. Dev Med Child Neurol. Apr. 1989;31(2):145-51. [pmid: 2786822].
Schwartz TH, Bazil CW, Walczak TS, et al. The predictive value of intraoperative electrocorticography in resections for limbic epilepsy associated with mesial temporal sclerosis. Neurosurgery 1997 Feb;40(2):302–9 discussion 309–11.
Seidenberg M. Academic achievement and school performance of children with epilepsy. In: Hermann BP, Seidenberg M, editors. Childhood epilepsies: neuropsychological, psychosocial and intervention aspects. New York (NY): John Wiley & Sons, Ltd.; 1989. p. 105–18.
Semah F, Gimenez F, Longer E, et al. Carbamazepine and its epoxide: an open study of efficacy and side effects after carbamazepine dose increment in refractory partial epilepsy. Ther Drug Monit. Dec. 1994;16(6):537-40. [pmid: 7878690].
Shah A K, Shein N, Fuerst D, et al. Peripheral WBC count and serum prolactin level in various seizure types and nonepileptic events. Epilepsia. 2001;42(11):1472-5. [pmid: 11879352].
Sharief M, Viteri C, Ben-Menachem E, et al. Double-blind, placebo-controlled study of topiramate in patients with refractory partial epilepsy. Epilepsy Res. Nov. 1996;25(3):217-24. [pmid: 8956919].
Sheiner L B. Bioequivalence revisited. Stat Med. Sep. 1992;11(13):1777-88. [pmid: 1485060].
Shen W K, Edwards W D, Hammill S C, et al. Sudden unexpected nontraumatic death in 54 young adults: a 30-year population-based study. Am J Cardiol. Jul. 1995;76(3):148-52. [pmid: 7611149].
Shi Z Y, Gong B T, Jia Y W, et al. The efficacy of electro-acupuncture on 98 cases of epilepsy. J Tradit Chin Med. Mar. 1987;7(1):21-2. [pmid: 3497312].
Shihabuddin B, Abou-Khalil B, Fakhoury T. The value of combined ambulatory cassette-EEG and video monitoring in the differential diagnosis of intractable seizures. Clin Neurophysiol. Aug. 1999;110(8):1452-7. [pmid: 10454281].
Shimizu H, Maehara T. Modification of peri-insular hemispherotomy and surgical results. Neurosurgery 2000 Aug;47(2):367–72; discussion 372–3.
Shimizu H, Maehara T. Neuronal disconnection for the surgical treatment of pediatric epilepsy. Epilepsia. 2000;41(Suppl 9):28-30. [pmid: 11156507].
Shimizu H, Suzuki I, Ishijima B, et al. Multiple subpial transection (MST) for the control of seizures that originated in unresectable cortical foci. Jpn J Psychiatry Neurol. Jun. 1991;45(2):354-6. [pmid: 1762216].
Shorvon S D. The epidemiology and treatment of chronic and refractory epilepsy. Epilepsia. 1996;37(Suppl 2):S1-S3. [pmid: 8641240].
Shorvon S D, Reynolds E H. Unnecessary polypharmacy for epilepsy. Br Med J. Jun. 1977;1(6077):1635-7. [pmid: 406001].
Sidorenko V N. Effects of the medical resonance therapy music in the complex treatment of epileptic patients. Integr Physiol Behav Sci. 2000;35(3):212-7. [pmid: 11286374].
Siegel A M, Jobst B C, Thadani V M, et al. Medically intractable, localization-related epilepsy with normal mri: presurgical evaluation and surgical outcome in 43 patients. Epilepsia. Jul. 2001;42(7):883-8. [pmid: 11488888].
Sigler M, Strassburg H M, Boenigk H E. Effective and safe but forgotten: methsuximide in intractable epilepsies in childhood. Seizure. Mar. 2001;10(2):120-4. [pmid: 11407955].
Silander H C, Blom S, Malmgren K, et al. Surgical treatment for epilepsy: a retrospective Swedish multicenter study. Acta Neurol Scand. 1997;95(6):321-30. [pmid: 9395431].
Sillanpaa M. Long-term outcome of epilepsy. Epileptic Disord. Jun. 2000;2(2):79-88. [pmid: 10954238].
Sillanpaa M, Jalava M, Kaleva O, et al. Long-term prognosis of seizures with onset in childhood. N Engl J Med. Jun. 1998;338(24):1715-22. [pmid: 9624191].
Sills M A, Forsythe W I, Haidukewych D, et al. The medium chain triglyceride diet and intractable epilepsy. Arch Dis Child. Dec. 1986;61(12):1168-72. [pmid: 3101615].
Singh U K, Jana U K. Serum prolactin and cortisol in children with some paroxysmal disorders. Indian J Pediatr. 1994;61(1):57-61. [pmid: 7927599].
Sirven J, Whedon B, Caplan D, et al. The ketogenic diet for intractable epilepsy in adults: preliminary results. Epilepsia. Dec. 1999;40(12):1721-6. [pmid: 10612335].
Sirven J I, Sperling M R, French J A, et al. Significance of simple partial seizures in temporal lobe epilepsy. Epilepsia. May. 1996;37(5):450-4. [pmid: 8617173].
Sisodiya S M. Surgery for malformations of cortical development causing epilepsy. Brain. Jun. 2000;123(Pt 6):1075-91. [pmid: 10825348].
Sisodiya S M, Moran N, Free S L, et al. Correlation of widespread preoperative magnetic resonance imaging changes with unsuccessful surgery for hippocampal sclerosis. Ann Neurol. Apr. 1997;41(4):490-6. [pmid: 9124806].
Sivenius J, Kalviainen R, Ylinen A, et al. Double-blind study of Gabapentin in the treatment of partial seizures. Epilepsia. 1991;32(4):539-42. [pmid: 1907907].
Sivenius J, Keranen T, Reinikainen K, et al. Diagnostic evaluation of ambulatory, cassette EEG monitoring in 100 epileptic patients. Acta Neurol Scand. 1984;69(Suppl 98):99-100.
Slater J D, Brown M C, Jacobs W, et al. Induction of pseudoseizures with intravenous saline placebo. Epilepsia. Jun. 1995;36(6):580-5. [pmid: 7555971].
Smith J R, Lee M R, King D W, et al. Results of lesional vs. nonlesional frontal lobe epilepsy surgery. Stereotactic Funct Neurosurg. 1997;69(14 Pt 2):202-9.
Smith M C. Multiple subpial transection in patients with extratemporal epilepsy. Epilepsia. 1998;39(Suppl 4):S81-9. [pmid: 9637596].
Snodgrass S R. Ambulatory management of children with epilepsy. Pediatr Ann. Apr. 1999;28(4):246-53. [pmid: 10224618].
So N, Olivier A, Andermann F, et al. Results of surgical treatment in patients with bitemporal epileptiform abnormalities. Ann Neurol. May. 1989;25(5):432-9. [pmid: 2774484].
Son Y J, Chung C K, Lee S K, et al. Comparison of localizing values of various diagnostic tests in non-lesional medial temporal lobe epilepsy. Seizure. Dec. 1999;8(8):465-70. [pmid: 10627408].
Sorenson J M, Wheless J W, Baumgartner J E, et al. Corpus callosotomy for medically intractable seizures. Pediatr Neurosurg. Nov. 1997;27(5):260-7. [pmid: 9620004].
Sotero de Menezes M A, Connolly M, Bolanos A, et al. Temporal lobectomy in early childhood: the need for long-term follow-up. J Child Neurol. Aug. 2001;16(8):585-90. [pmid: 11510930].
Specht U, Boenigk H E, Wolf P. Discontinuation of clonazepam after long-term treatment. Epilepsia. 1989;30(4):458-63. [pmid: 2502386].
Spencer S S. Corpus callosum section and other disconnection procedures for medically intractable epilepsy. Epilepsia. 1988;29(Suppl 2):S85-99. [pmid: 3168962].
Spencer S S, Spencer D D, Williamson P D, et al. Corpus callosotomy for epilepsy. I. Seizure effects. Neurology. Jan. 1988;38(1):19-24. [pmid: 3122070].
Sperling M R, Feldman H, Kinman J, et al. Seizure control and mortality in epilepsy. Ann Neurol. Jul. 1999;46(1):45-50. [pmid: 10401779].
Sperling M R, Lieb J P, Engel J Jr, et al. Prognostic significance of independent auras in temporal lobe seizures. Epilepsia. 1989;30(3):322-31. [pmid: 2721465].
Sperling M R, O'Connor M J. Auras and subclinical seizures: characteristics and prognostic significance. Ann Neurol. Sep. 1990;28(3):320-8. [pmid: 2241115].
Sperling M R, Saykin A J, Roberts F D, et al. Occupational outcome after temporal lobectomy for refractory epilepsy. Neurology. May. 1995;45(5):970-7. [pmid: 7746417].
Spilker B, Segreti A. Validation of the phenomenon of regression of seizure frequency in epilepsy. Epilepsia. Aug. 1984;25(4):443-9. [pmid: 6378614].
Sramka M, Chkhenkeli SA. Clinical experience in intraoperational determination of brain inhibitory structures and application of implanted neurostimulators in epilepsy. Stereotactic Funct Neurosurg 1990;54–55:56–9.
Srikumar G, Bhatia M, Jain S, et al. Usefulness of short term video-EEG monitoring in children with frequent intractable episodes. Neurol India. Mar. 2000;48(1):29-32. [pmid: 10751810].
Stafstrom C E, Lynch M, Sutula T P. Consequences of epilepsy in the developing brain: implications for surgical management. Semin Pediatr Neurol. Sep. 2000;7(3):147-57. [pmid: 11023172].
Storzbach D, Binder L M, Salinsky M C, et al. Improved prediction of nonepileptic seizures with combined MMPI and EEG measures. Epilepsia. Mar. 2000;41(3):332-7. [pmid: 10714406].
Sturniolo M G, Galletti F. Idiopathic epilepsy and school achievement. Arch Dis Child. May. 1994;70(5):424-8. [pmid: 8017966].
Sutula T P, Sackellares J C, Miller J Q, et al. Intensive monitoring in refractory epilepsy. Neurology. Mar. 1981;31(3):243-7. [pmid: 7193817].
Swartz B E, Delgado-Escueta A V, Walsh G O, et al. Surgical outcomes in pure frontal lobe epilepsy and foci that mimic them. Epilepsy Res. 1998;29(2):97-108. [pmid: 9477141].
Szabo C A, Wyllie E, Stanford L D, et al. Neuropsychological effect of temporal lobe resection in preadolescent children with epilepsy. Epilepsia. Aug. 1998;39(8):814-9. [pmid: 9701370].
Takkouche B, Cadarso-Suarez C, Spiegelman D. Evaluation of old and new tests of heterogeneity in epidemiologic meta-analysis. Am J Epidemiol. Jul. 1999;150(2):206-15. [pmid: 10412966].
Tallian K B, Nahata M C, Tsao C Y. Role of the ketogenic diet in children with intractable seizures. Ann Pharmacother. Mar. 1998;32(3):349-61. [pmid: 9533066].
Tamer S K. Cognitive and behavioural concerns in epileptic children. Indian J Pediatr. 1999;66(6):877-86. [pmid: 10798155].
Tanenbaum L, Drayer B P, Anderson R E, et al. Epilepsy. American College of Radiology. ACR Appropriateness Criteria. Radiology. Jun. 2000;215(Suppl):459-70. [pmid: 11037457].
Tassinari C A, Michelucci R, Chauvel P, et al. Double-blind, placebo-controlled trial of topiramate (600 mg daily) for the treatment of refractory partial epilepsy. Epilepsia. Aug. 1996;37(8):763-8. [pmid: 8764816].
Tatum W O 4th, Benbadis S R, Vale F L. The neurosurgical treatment of epilepsy. Arch Fam Med. 2000;9(10):1142-7. [pmid: 11115221].
Tennis P, Cole T B, Annegers J F, et al. Cohort study of incidence of sudden unexplained death in persons with seizure disorder treated with antiepileptic drugs in Saskatchewan, Canada. Epilepsia. Jan. 1995;36(1):29-36. [pmid: 8001505].
Thadani V M, Williamson P D, Berger R, et al. Successful epilepsy surgery without intracranial EEG recording: criteria for patient selection. Epilepsia. Jan. 1995;36(1):7-15. [pmid: 8001512].
Theodore W H, Albert P, Stertz B, et al. Felbamate monotherapy: implications for antiepileptic drug development. Epilepsia. Nov. 1995;36(11):1105-10. [pmid: 7588454].
Theodore W H, Raubertas R F, Porter R J, et al. Felbamate: a clinical trial for complex partial seizures. Epilepsia. 1991;32(3):392-7. [pmid: 2044501].
Thompson PJ, Huppert FA. Problems in the development of measures to test cognitive performance in adult epileptic patients. In: Kulig B, Meinardi H, Stores G, editors. Epilepsy and behavior '79. Lisse: Swets & Zeitlinger; 1980. p. 37–42.
Thompson P J, Trimble M R. Anticonvulsant drugs and cognitive functions. Epilepsia. Oct. 1982;23(5):531-44. [pmid: 7140665].
Thompson P J, Trimble M R. Sodium valproate and cognitive functioning in normal volunteers. Br J Clin Pharmacol. 1981;12:819-24. [pmid: 6803819].
Timmings P L. Sudden unexpected death in epilepsy: a local audit. Seizure. Dec. 1993;2(4):287-90. [pmid: 8162397].
Tinuper P, Andermann F, Villemure J G, et al. Functional hemispherectomy for treatment of epilepsy associated with hemiplegia: rationale, indications, results, and comparison with callosotomy. Ann Neurol. Jul. 1988;24(1):27-34. [pmid: 3137858].
Trauner D A. Medium-chain triglyceride (MCT) diet in intractable seizure disorders. Neurology. Feb. 1985;35(2):237-8. [pmid: 3969213].
Trimble M R. Anticonvulsant-induced psychiatric disorders. The role of forced normalisation. Drug Saf. Sep. 1996;15(3):159-66. [pmid: 8879970].
Trimble M R. Serum prolactin in epilepsy and hysteria. Br Med J. Dec. 1978;2(6153):1682. [pmid: 737437].
Tudehope D I, Harris A, Hawes D, et al. Clinical spectrum and outcome of neonatal convulsions. Aust Paediatr J. Aug. 1988;24(4):249-53. [pmid: 3219107].
Uhlmann C, Froscher W. Biofeedback treatment in patients with refractory epilepsy: changes in depression and control orientation. Seizure. Jan. 2001;10(1):34-8. [pmid: 11181095].
U.S. Preventive Services Task Force (USPSTF). Cost-effectiveness analyses of colorectal cancer screening: a systematic review for the US Preventive Services Task Force. Rockville (MD): Agency for Healthcare Research and Quality (AHRQ); 2002. 37 p.
Usiskin S C. The role of counselling in an out-patient epilepsy clinic: a three year study. Seizure. Jun. 1993;2(2):111-4. [pmid: 8167961].
Uthman B M. Vagus nerve stimulation for seizures. Arch Med Res. 2000;31(3):300-3. [pmid: 11036181].
Uthman B M, Rowan A J, Ahmann P A, et al. Tiagabine for complex partial seizures: a randomized, add-on, dose-response trial. Arch Neurol. Jan. 1998;55(1):56-62. [pmid: 9443711].
Vanderzant C W, Giordani B, Berent S, et al. Personality of patients with pseudoseizures. Neurology. 1986;36:664-8. [pmid: 3703265].
Velasco F, Velasco M, Jimenez F, et al. Predictors in the treatment of difficult-to-control seizures by electrical stimulation of the centromedian thalamic nucleus. Neurosurgery 2000 Aug;47(2):295–304; discussion 304–5.
Velasco M, Velasco F, Velasco A L, et al. Subacute electrical stimulation of the hippocampus blocks intractable temporal lobe seizures and paroxysmal EEG activities. Epilepsia. Feb. 2000;41(2):158-69. [pmid: 10691112].
Verma A, Lewis D, VanLandingham K E, et al. Lateralized seizure termination: relationship to outcome following anterior temporal lobectomy. Epilepsy Res. Nov. 2001;47(12):9-15. [pmid: 11673016].
Vickrey B. Mortality in a consecutive cohort of 248 adolescents and adults who underwent diagnostic evaluation for epilepsy surgery. Epilepsia. 1997;38(Suppl 11):S67-9. [pmid: 19909332].
Vickrey B G, Hays R D, Rausch R, et al. Outcomes in 248 patients who had diagnostic evaluations for epilepsy surgery. Lancet. Dec. 1995;346(8988):1445-9. [pmid: 7490989].
Victor M, Ropper AH. Adams and Victor's principles of neurology. 7th ed. New York (NY): McGraw-Hill Companies, Inc.; 2001. Epilepsy and other seizure disorders. p. 331–65.
Villemure J G, de Tribolet N. Epilepsy in patients with central nervous system tumors. Curr Opin Neurol. Dec. 1996;9(6):424-8. [pmid: 9007399].
Vining E P, Freeman J M, Ballaban-Gil K, et al. A multicenter study of the efficacy of the ketogenic diet. Arch Neurol. Nov. 1998;55(11):1433-7. [pmid: 9823827].
Vining E P, Freeman J M, Pillas D J, et al. Why would you remove half a brain? The outcome of 58 children after hemispherectomy-the Johns Hopkins experience: 1968 to 1996. Pediatrics. Aug. 1997;100(2 Pt 1):163-71. [pmid: 9240794].
Vinters H V, Park S H, Johnson M W, et al. Cortical dysplasia, genetic abnormalities and neurocutaneous syndromes. Dev Neurosci. Nov. 1999;21(35):248-59. [pmid: 10575248].
Virudhagirinathan B S, Biswakumar B, Sultana M S. Psychological management of temporal lobe epilepsy. Indian J Clin Psychol. Sep. 1986;13(2):119-24.
Visudhiphan P, Bunyaratavej S, Visudtibhan A, et al. Temporal lobectomy for intractable complex partial seizures in pediatric patients. J Med Assoc Thai. Aug. 1999;82(8):778-83. [pmid: 10511785].
Vossler D G, Wilkus R J, Ojemann G A. Preoperative EEG correlates of seizure outcome from epilepsy surgery in children. J Epilepsy. 1995;8(3):236-45.
Wada J A. Differential diagnosis of epilepsy. Electroencephalogr Clin Neurophysiol Suppl. 1985;37:285-311. [pmid: 3924564].
Walczak T S, Leppik I E, D'Amelio M, et al. Incidence and risk factors in sudden unexpected death in epilepsy: a prospective cohort study. Neurology. Feb. 2001;56(4):519-25. [pmid: 11222798].
Walczak T S, Radtke R A, McNamara J O, et al. Anterior temporal lobectomy for complex partial seizures: evaluation, results, and long-term follow-up in 100 cases. Neurology. Mar. 1990;40(3 Pt 1):413-8. [pmid: 2314581].
Walczak T S, Williams D T, Berten W. Utility and reliability of placebo infusion in the evaluation of patients with seizures. Neurology. Mar. 1994;44(3 Pt 1):394-9. [pmid: 8145904].
Walker I A, Slovis C M. Lidocaine in the treatment of status epilepticus. Acad Emerg Med. Sep. 1997;4(9):918-22. [pmid: 9305436].
Wang T. Effects of Chinese medicine zhenxianling in 239 cases of epilepsy. J Tradit Chin Med. Jun. 1996;16(2):94-7. [pmid: 9389131].
Weller S C, Mann N C. Assessing rater performance without a ‘Gold Standard’ using consensus theory. Med Decis Making. 1997;17(1):71-9. [pmid: 8994153].
Welty T E, Privitera M, Shukla R. Increased seizure frequency associated with felbamate withdrawal in adults. Arch Neurol. May. 1998;55(5):641-5. [pmid: 9605720].
Wennberg R, Quesney L F, Lozano A, et al. Role of electrocorticography at surgery for lesion-related frontal lobe epilepsy. Can J Neurol Sci. Feb. 1999;26(1):33-9. [pmid: 10068805].
Westerveld M, Sass K J, Chelune G J, et al. Temporal lobectomy in children: cognitive outcome. J Neurosurg. Jan. 2000;92(1):24-30. [pmid: 10616078].
White H S, Wolf H H, Woodhead J H, et al. The National Institutes of Health Anticonvulsant Drug Development Program: screening for efficacy. Adv Neurol. 1998;76:29-39. [pmid: 9408461].
Whitman S, Dell J, Legion V, et al. Progressive relaxation for seizure reduction. J Epilepsy. 1990;3(1):17-22.
Wiebe S, Blume W T, Girvin J P, et al. A randomized, controlled trial of surgery for temporal-lobe epilepsy. N Engl J Med. Aug. 2001;345(5):311-8. [pmid: 11484687].
Wieser H G. Selective amygdalohippocampectomy: indications and follow-up. Can J Neurol Sci. Nov. 1991;18(4 Suppl):617-27. [pmid: 1777882].
Wieser H G, Blume W T, Fish D, et al. ILAE Commission Report. Proposal for a new classification of outcome with respect to epileptic seizures following epilepsy surgery. Epilepsia. Feb. 2001;42(2):282-6. [pmid: 11240604].
Wijdicks E F, Scott J P. Causes and outcome of mechanical ventilation in patients with hemispheric ischemic stroke. Mayo Clin Proc. 1997;72(3):210-3. [pmid: 9070194].
Williamson P D, Spencer D D, Spencer S S, et al. Complex partial seizures of frontal lobe origin. Ann Neurol. Oct. 1985;18(4):497-504. [pmid: 4073842].
Willmer J P, Brunet D G. The value of prolonged electroencephalographic and video monitoring in diagnosis of seizure disorders. Can J Neurol Sci. Nov. 1986;13(4):327-30. [pmid: 3779533].
Willmore L J, Shu V, Wallin B. Efficacy and safety of add-on divalproex sodium in the treatment of complex partial seizures. The M88–194 Study Group. Neurology. Jan. 1996;46(1):49-53. [pmid: 8559420].
Wilson S J, Bladin P F, Saling M M, et al. The longitudinal course of adjustment after seizure surgery. Seizure. Apr. 2001;10(3):165-72. [pmid: 11437614].
Wisniewski K E. Pheno/genotypic correlations of neuronal ceroid lipofuscinoses. Neurology. Aug. 2001;57(4):576-81. [pmid: 11548735].
Wolf P. Treatment of epilepsy following rejection of epilepsy surgery. Seizure. Feb. 1998;7(1):25-9. [pmid: 9548222].
Wong I C, Chadwick D W, Fenwick P B, et al. The long-term use of gabapentin, lamotrigine, and vigabatrin in patients with chronic epilepsy. Epilepsia. 1999;40(10):1439-45. [pmid: 10528941].
Wong I C, Mawer G E, Sander J W. Adverse event monitoring in lamotrigine patients: a pharmacoepidemiologic study in the United Kingdom. Epilepsia. Feb. 2001;42(2):237-44. [pmid: 11240596].
Wroe S J, Henley R, John R, et al. The clinical value of serum prolactin measurement in the differential diagnosis of complex partial seizures. Epilepsy Res. 1989;3(3):248-52. [pmid: 2499452].
Wurm G, Wies W, Schnizer M, et al. Advanced surgical approach for selective amygdalohippocampectomy through neuronavigation. Neurosurgery 2000 Jun;46(6):1377–82; discussion 1382–3.
Wyler AR. Recent advances in epilepsy surgery: temporal lobectomy and multiple subpial transections. Neurosurgery 1997 Dec;41(6):1294–301; discussion 1301.
Wyler AR, Hermann BP, Somes G. Extent of medial temporal resection on outcome from anterior temporal lobectomy: a randomized prospective study. Neurosurgery 1995 Nov;37(5):982–90; discussion 990–1.
Wyllie E. Surgery for catastrophic localization-related epilepsy in infants. Epilepsia. 1996;37(Suppl 1):S22-5. [pmid: 8647049].
Wyllie E, Comair Y G, Kotagal P, et al. Seizure outcome after epilepsy surgery in children and adolescents. Ann Neurol. Nov. 1998;44(5):740-8. [pmid: 9818929].
Wyllie E, Luders H, MacMillan J P, et al. Serum prolactin levels after epileptic seizures. Neurology. Dec. 1984;34(12):1601-4. [pmid: 6504333].
Yagi K. Epilepsy: comprehensive care, quality of life, and factors preventing people with epilepsy from being employed. Clin Ther. 1998;20(Suppl A):A19-29. [pmid: 9589811].
Yamamoto L G, Yim G K. The role of intravenous valproic acid in status epilepticus. Pediatr Emerg Care. Aug. 2000;16(4):296-8. [pmid: 10966355].
Yeh H S, Kashiwagi S, Tew J M Jr, et al. Surgical management of epilepsy associated with cerebral arteriovenous malformations. J Neurosurg. Feb. 1990;72(2):216-23. [pmid: 2295919].
Yerby M S, van Belle G, Friel P N, et al. Serum prolactins in the diagnosis of epilepsy: sensitivity, specificity, and predictive value. Neurology. Jul. 1987;37(7):1224-6. [pmid: 3601088].
Zaidi A, Clough P, Cooper P, et al. Misdiagnosis of epilepsy: many seizure-like attacks have a cardiovascular cause. J Am Coll Cardiol. Jul. 2000;36(1):181-4. [pmid: 10898432].
Zelnik N, Kahana L, Rafael A, et al. Prolactin and cortisol levels in various paroxysmal disorders in childhood. Pediatrics. Sep. 1991;88(3):486-9. [pmid: 1881727].
Zupanc M L. Neuroimaging in the evaluation of children and adolescents with intractable epilepsy: I. Magnetic resonance imaging and the substrates of epilepsy. Pediatr Neurol. Jul. 1997;17(1):19-26. [pmid: 9308971].