# References

1 Victor M, Ropper AH. Adams and Victor's principles of neurology. 7th ed. New York (NY): McGraw-Hill Companies, Inc.; 2001. Epilepsy and other seizure disorders. p. 331–65.
2 Engel J Jr. Intractable epilepsy: definition and neurobiology. Epilepsia. 2001;42(Suppl 6):3. [pmid: 11902319].
3 Arroyo S, Brodie M J, Avanzini G, et al. Is refractory epilepsy preventable?. Epilepsia. Apr. 2002;43(4):437-44. [pmid: 11952776].
4 Chadwick D. Epilepsy. J Neurol Neurosurg Psychiatry. Mar. 1994;57(3):264-77. [pmid: 8158172].
5 Proposal for revised clinical and electroencephalographic classification of epileptic seizures. From the Commission on Classification and Terminology of the International League Against Epilepsy. Epilepsia 1981 Aug;22(4):489–501.
6 Engel J Jr. The timing of surgical intervention for mesial temporal lobe epilepsy: a plan for a randomized clinical trial. Arch Neurol. Nov. 1999;56(11):1338-41. [pmid: 10555652].
7 Kalviainen R, Salmenpera T, Partanen K, et al. Recurrent seizures may cause hippocampal damage in temporal lobe epilepsy. Neurology. May. 1998;50(5):1377-82. [pmid: 9595990].
8 Shorvon S D. The epidemiology and treatment of chronic and refractory epilepsy. Epilepsia. 1996;37(Suppl 2):S1-S3. [pmid: 8641240].
9 ILAE Commission Report. The epidemiology of the epilepsies: future directions. International League Against Epilepsy. Epilepsia 1997 May;38(5):614–8.
10 Sander J W, Shorvon S D. Incidence and prevalence studies in epilepsy and their methodological problems: a review. J Neurol Neurosurg Psychiatry. Jul. 1987;50(7):829-39. [pmid: 3305790].
11 Sillanpaa M, Jalava M, Kaleva O, et al. Long-term prognosis of seizures with onset in childhood. N Engl J Med. Jun. 1998;338(24):1715-22. [pmid: 9624191].
12 Fisher R S, Vickrey B G, Gibson P, et al. The impact of epilepsy from the patient's perspective I. Descriptions and subjective perceptions. Epilepsy Res. Aug. 2000;41(1):39-51. [pmid: 10924867].
13 Sillanpaa M. Long-term outcome of epilepsy. Epileptic Disord. Jun. 2000;2(2):79-88. [pmid: 10954238].
14 Proposal for revised classification of epilepsies and epileptic syndromes. Commission on Classification and Terminology of the International League Against Epilepsy. Epilepsia 1989;30(4):389–99.
15 DerSimonian R, Laird N. Meta-analysis in clinical trials. Control Clin Trials. Sep. 1986;7(3):177-88. [pmid: 3802833].
16 Gavaghan D J, Moore R A, McQuay H J. An evaluation of homogeneity tests in meta-analyses in pain using simulations of individual patient data. Pain. Apr. 2000;85(3):415-24. [pmid: 10781914].
17 Takkouche B, Cadarso-Suarez C, Spiegelman D. Evaluation of old and new tests of heterogeneity in epidemiologic meta-analysis. Am J Epidemiol. Jul. 1999;150(2):206-15. [pmid: 10412966].
18 Petitti D B. Approaches to heterogeneity in meta-analysis. Stat Med. Dec. 2001;20(23):3625-33. [pmid: 11746342].
19 Lambert P C, Sutton A J, Abrams K R, et al. A comparison of summary patient-level covariates in meta-regression with individual patient data meta-analysis. J Clin Epidemiol. Jan. 2002;55(1):86-94. [pmid: 11781126].
20 Berlin J A, Santanna J, Schmid C H, et al. Individual patient- versus group-level data meta-regressions for the investigation of treatment effect modifiers: ecological bias rears its ugly head. Stat Med. Feb. 2002;21(3):371-87. [pmid: 11813224].
21 Cook TD, Campbell DT. Quasi-experimentation: design and analysis issues for field settings. Boston (MA): Houghton Mifflin Company; 1979. 405 p.
22 Patrick D L, Deyo R A. Generic and disease-specific measures in assessing health status and quality of life. Med Care. Mar. 1989;27(3 Suppl):S217-32. [pmid: 2646490].
23 Spilker B, Segreti A. Validation of the phenomenon of regression of seizure frequency in epilepsy. Epilepsia. Aug. 1984;25(4):443-9. [pmid: 6378614].
24 Lijmer J G, Mol B W, Heisterkamp S, et al. Empirical evidence of design-related bias in studies of diagnostic tests. JAMA. Sep. 1999;282(11):1061-6. [pmid: 10493205].
25 Irwig L, Tosteson A N, Gatsonis C, et al. Guidelines for meta-analyses evaluating diagnostic tests. Ann Intern Med. Apr. 1994;120(8):667-76. [pmid: 8135452].
26 Gann PH. Prostate-specific antigen screening for prostate cancer: issues involving test validity. Endocr Related Cancer 1996 Fall;3(3):179–89.
27 Begg C B, Greenes R A. Assessment of diagnostic tests when disease verification is subject to selection bias. Biometrics. Mar. 1983;39(1):207-15. [pmid: 6871349].
28 Ransohoff D F, Feinstein A R. Problems of spectrum and bias in evaluating the efficacy of diagnostic tests. N Engl J Med. Oct. 1978;299(17):926-30. [pmid: 692598].
29 Fletcher RH, Fletcher SW, Wagner EH. Clinical epidemiology: the essentials. 2nd ed. Baltimore (MD): Williams & Wilkins; 1988. 246 p.
30 Duchowny M, Pellock J M, Graf W D, et al. A placebo-controlled trial of lamotrigine add-on therapy for partial seizures in children. Lamictal Pediatric Partial Seizure Study Group. Neurology. Nov. 1999;53(8):1724-31. [pmid: 10563619].
31 Salinsky M C, Uthman B M, Ristanovic R K, et al. Vagus nerve stimulation for the treatment of medically intractable seizures. Results of a 1-year open-extension trial. Vagus Nerve Stimulation Study Group. Arch Neurol. Nov. 1996;53(11):1176-80. [pmid: 8912492].
32 French J, Smith M, Faught E, et al. Practice advisory: the use of felbamate in the treatment of patients with intractable epilepsy: report of the Quality Standards Subcommittee of the American Academy of Neurology and the American Epilepsy Society. Neurology. May. 1999;52(8):1540-5. [pmid: 10331676].
33 Schmidt D, Gram L, Brodie M, et al. Tiagabine in the treatment of epilepsy--a clinical review with a guide for the prescribing physician. Epilepsy Res. Oct. 2000;41(3):245-51. [pmid: 10962215].
34 Devinsky O. Patients with refractory seizures. N Engl J Med. May. 1999;340(20):1565-70. [pmid: 10332020].
35 Olson D M. Evaluation of children for epilepsy surgery. Pediatr Neurosurg. Mar. 2001;34(3):159-65. [pmid: 11359105].
36 Bazil C W, Pedley T A. Advances in the medical treatment of epilepsy. Annu Rev Med. 1998;49:135-62. [pmid: 9509255].
37 Henry T R, Drury I. Non-epileptic seizures in temporal lobectomy candidates with medically refractory seizures. Neurology. May. 1997;48(5):1374-82. [pmid: 9153476].
38 Zaidi A, Clough P, Cooper P, et al. Misdiagnosis of epilepsy: many seizure-like attacks have a cardiovascular cause. J Am Coll Cardiol. Jul. 2000;36(1):181-4. [pmid: 10898432].
39 Holmes M D, Dodrill C B. What is the significance of subjective events recorded during long-term EEG video monitoring?. Epilepsia. Aug. 1998;39(8):857-62. [pmid: 9701376].
40 Arnold L M, Privitera M D. Psychopathology and trauma in epileptic and psychogenic seizure patients. Psychosomatics. 1996;37(5):438-43. [pmid: 8824123].
41 Slater J D, Brown M C, Jacobs W, et al. Induction of pseudoseizures with intravenous saline placebo. Epilepsia. Jun. 1995;36(6):580-5. [pmid: 7555971].
42 Fryback DG, Thornbury JR. The efficacy of diagnostic imaging. Med Decis Making 1991 Apr-1991 Jun;11(2):88–94.
43 Ohman R, Walinder J, Balldin J, et al. Prolactin response to electroconvulsive therapy. Lancet. Oct. 1976;2(7992):936-7. [pmid: 62165].
44 Trimble M R. Serum prolactin in epilepsy and hysteria. Br Med J. Dec. 1978;2(6153):1682. [pmid: 737437].
45 Anzola G P. Predictivity of plasma prolactin levels in differentiating epilepsy from pseudoseizures: a prospective study. Epilepsia. 1993;34(6):1044-8. [pmid: 8243355].
46 Collins W C, Lanigan O, Callaghan N. Plasma prolactin concentrations following epileptic and pseudoseizures. J Neurol Neurosurg Psychiatry. Jun. 1983;46(6):505-8. [pmid: 6410003].
47 Fisher R S, Chan D W, Bare M, et al. Capillary prolactin measurement for diagnosis of seizures. Ann Neurol. Feb. 1991;29(2):187-90. [pmid: 2012387].
48 Pritchard P B 3rd, Wannamaker B B, Sagel J, et al. Serum prolactin and cortisol levels in evaluation of pseudoepileptic seizures. Ann Neurol. Jul. 1985;18(1):87-9. [pmid: 4037754].
49 Rao M L, Stefan H, Bauer J. Epileptic but not psychogenic seizures are accompanied by simultaneous elevation of serum pituitary hormones and cortisol levels. Neuroendocrinology. Jan. 1989;49(1):33-9. [pmid: 2716948].
50 Wroe S J, Henley R, John R, et al. The clinical value of serum prolactin measurement in the differential diagnosis of complex partial seizures. Epilepsy Res. 1989;3(3):248-52. [pmid: 2499452].
51 Wyllie E, Luders H, MacMillan J P, et al. Serum prolactin levels after epileptic seizures. Neurology. Dec. 1984;34(12):1601-4. [pmid: 6504333].
52 Yerby M S, van Belle G, Friel P N, et al. Serum prolactins in the diagnosis of epilepsy: sensitivity, specificity, and predictive value. Neurology. Jul. 1987;37(7):1224-6. [pmid: 3601088].
53 Lusic I, Pintaric I, Hozo I, et al. Serum prolactin levels after seizure and syncopal attacks. Seizure. Jun. 1999;8(4):218-22. [pmid: 10452919].
54 Dirik E, Sen A, Anal O, et al. Serum cortisol and prolactin levels in childhood paroxysmal disorders. Acta Paediatr Jpn. Apr. 1996;38(2):118-20. [pmid: 8677785].
55 Singh U K, Jana U K. Serum prolactin and cortisol in children with some paroxysmal disorders. Indian J Pediatr. 1994;61(1):57-61. [pmid: 7927599].
56 Zelnik N, Kahana L, Rafael A, et al. Prolactin and cortisol levels in various paroxysmal disorders in childhood. Pediatrics. Sep. 1991;88(3):486-9. [pmid: 1881727].
57 Mishra V, Gahlaut D S, Kumar S. Value of serum prolactin in differentiating epilepsy from pseudoseizures. J Assoc Physicians India. 1990;38:846-7. [pmid: 2079470].
58 Benbadis S R. Provocative techniques should be used for the diagnosis of psychogenic nonepileptic seizures. Arch Neurol. Dec. 2001;58(12):2063-5. [pmid: 11735780].
59 Devinsky O, Thacker K. Nonepileptic seizures. Neurol Clin. May. 1995;13(2):299-319. [pmid: 7643827].
60 Erlichman M. Electroencephalographic (EEG) video monitoring. Health Technol Assess Rep 1990(4):1–14.
61 Agency for Healthcare Research and Quality (AHRQ). Management of newly diagnosed patients with epilepsy: a systematic review of the literature: summary. Rockville (MD): AHRQ; 2001 Feb 1. 158 p. (Evidence report/technology assessment; no. 39). Also available: http://www.ahrq.gov.
62 Wijdicks E F, Scott J P. Causes and outcome of mechanical ventilation in patients with hemispheric ischemic stroke. Mayo Clin Proc. 1997;72(3):210-3. [pmid: 9070194].
63 Lieb J P, Walsh G O, Babb T L, et al. A comparison of EEG seizure patterns recorded with surface and depth electrodes in patients with temporal lobe epilepsy. Epilepsia. 1976;17:137-60. [pmid: 947745].
64 Williamson P D, Spencer D D, Spencer S S, et al. Complex partial seizures of frontal lobe origin. Ann Neurol. Oct. 1985;18(4):497-504. [pmid: 4073842].
65 Sperling M R, O'Connor M J. Auras and subclinical seizures: characteristics and prognostic significance. Ann Neurol. Sep. 1990;28(3):320-8. [pmid: 2241115].
66 Boon P A, Williamson P D. The diagnosis of pseudoseizures. Clin Neurol Neurosurg. Mar. 1993;95(1):1-8. [pmid: 8453810].
67 Leppik I E, Dreifuss F E, Pledger G W, et al. Felbamate for partial seizures: results of a controlled clinical trial. Neurology. Nov. 1991;41(11):1785-9. [pmid: 1944909].
68 Sachdeo R, Beydoun A, Schachter S, et al. Oxcarbazepine (Trileptal) as monotherapy in patients with partial seizures. Neurology. Sep. 2001;57(5):864-71. [pmid: 11552018].
69 Cornaggia C, Canevini M P, Giuccioli D, et al. Monotherapy and polytherapy for intractable epilepsies. Ital J Neurol Sci. Jun. 1985;6(2):201-5. [pmid: 3928525].
70 Jawad S, Richens A, Goodwin G, et al. Controlled trial of lamotrigine (Lamictal) for refractory partial seizures. Epilepsia. 1989;30(3):356-63. [pmid: 2498073].
71 Gilman J T, Duchowny M, Jayakar P, et al. Medical intractability in children evaluated for epilepsy surgery. Neurology. Jul. 1994;44(7):1341-3. [pmid: 8035945].
72 Milano Collaborative Group for Studies on Epilepsy. Long-term intensive monitoring in the difficult patient. Preliminary results of 16 months of observations - usefulness and limitations. In: Gardner-Thorpe C, Janz D, Meinardi H, et al, editors. Antiepileptic drug monitring. Kent: Pitman Medical; 1977. p. 197–213.
73 Schmidt D. Single drug therapy for intractable epilepsy. J Neurol. 1983;229(4):221-6. [pmid: 6192223].
74 Reinikainen K J, Keranen T, Halonen T, et al. Comparison of oxcarbazepine and carbamazepine: a double-blind study. Epilepsy Res. Sep. 1987;1(5):284-9. [pmid: 3504404].
75 Devinsky O, Faught R E, Wilder B J, et al. Efficacy of felbamate monotherapy in patients undergoing presurgical evaluation of partial seizures. Epilepsy Res. Mar. 1995;20(3):241-6. [pmid: 7796796].
76 Gilliam F, Vazquez B, Sackellares J C, et al. An active-control trial of lamotrigine monotherapy for partial seizures. Neurology. Oct. 1998;51(4):1018-25. [pmid: 9781523].
77 Faught E, Sachdeo R C, Remler M P, et al. Felbamate monotherapy for partial-onset seizures: an active-control trial. Neurology. Apr. 1993;43(4):688-92. [pmid: 8469323].
78 Bergey G K, Morris H H, Rosenfeld W, et al. Gabapentin monotherapy: I. An 8-day, double-blind, dose-controlled, multicenter study in hospitalized patients with refractory complex partial or secondarily generalized seizures. The U.S. Gabapentin Study Group 88/89. Neurology. Sep. 1997;49(3):739-45. [pmid: 9305334].
79 Schachter S C, Vazquez B, Fisher R S, et al. Oxcarbazepine: double-blind, randomized, placebo-control, monotherapy trial for partial seizures. Neurology. Mar. 1999;52(4):732-7. [pmid: 10078718].
80 Dodrill C B, Arnett J L, Shu V, et al. Effects of tiagabine monotherapy on abilities, adjustment, and mood. Epilepsia. Jan. 1998;39(1):33-42. [pmid: 9578010].
81 Dodrill C B, Arnett J L, Hayes A G, et al. Cognitive abilities and adjustment with gabapentin: results of a multisite study. Epilepsy Res. Jun. 1999;35(2):109-21. [pmid: 10372564].
82 Ketter T A, Malow B A, Flamini R, et al. Felbamate monotherapy has stimulant-like effects in patients with epilepsy. Epilepsy Res. Mar. 1996;23(2):129-37. [pmid: 8964274].
83 Beydoun A, Fischer J, Labar D R, et al. Gabapentin monotherapy: II. A 26-week, double-blind, dose-controlled, multicenter study of conversion from polytherapy in outpatients with refractory complex partial or secondarily generalized seizures. The U.S. Gabapentin Study Group 82/83. Neurology. Sep. 1997;49(3):746-52. [pmid: 9305335].
84 Sachdeo R C, Reife R A, Lim P, et al. Topiramate monotherapy for partial onset seizures. Epilepsia. Mar. 1997;38(3):294-300. [pmid: 9070591].
85 Beydoun A, Sackellares J C, Shu V. Safety and efficacy of divalproex sodium monotherapy in partial epilepsy: a double-blind, concentration-response design clinical trial. Depakote Monotherapy for Partial Seizures Study Group. Neurology. Jan. 1997;48(1):182-8. [pmid: 9008516].
86 Beydoun A, Sachdeo R C, Rosenfeld W E, et al. Oxcarbazepine monotherapy for partial-onset seizures: a multicenter, double-blind, clinical trial. Neurology. Jun. 2000;54(12):2245-51. [pmid: 10881247].
87 Kanner AM PJFM. The ‘forgotten’ cross-tolerance between phenobarbital and primidone: it can prevent acute primidone-related toxicity. Kanner AM, Parra J, Frey M. The ‘forgotten’ cross-tolerance between phenobarbital and primidone: it can prevent acute primidone-related toxicity. Epilepsia 2000 Oct;41(10):1310–4.: EPC5cites_everything, Helen_transfer, EPC0005. Epilepsia. 41. 2000:1310–4.
88 Schachter S C. Tiagabine monotherapy in the treatment of partial epilepsy. Epilepsia. 1995;36(Suppl 6):S2-S6. [pmid: 8595789].
89 Theodore W H, Albert P, Stertz B, et al. Felbamate monotherapy: implications for antiepileptic drug development. Epilepsia. Nov. 1995;36(11):1105-10. [pmid: 7588454].
90 Ben-Menachem E, Henriksen O, Dam M, et al. Double-blind, placebo-controlled trial of topiramate as add-on therapy in patients with refractory partial seizures. Epilepsia. Jun. 1996;37(6):539-43. [pmid: 8641230].
91 Faught E, Wilder B J, Ramsay R E, et al. Topiramate placebo-controlled dose-ranging trial in refractory partial epilepsy using 200-, 400-, and 600-mg daily dosages. Topiramate YD Study Group. Neurology. Jun. 1996;46(6):1684-90. [pmid: 8649570].
92 Cramer J A, Arrigo C, Van Hammee G, et al. Effect of levetiracetam on epilepsy-related quality of life. N132 Study Group. Epilepsia. Jul. 2000;41(7):868-74. [pmid: 10897159].
93 Dodrill C B, Arnett J L, Sommerville K W, et al. Cognitive and quality of life effects of differing dosages of tiagabine in epilepsy. Neurology. Apr. 1997;48(4):1025-31. [pmid: 9109894].
94 Faught E, Ayala R, Montouris G G, et al. Randomized controlled trial of zonisamide for the treatment of refractory partial-onset seizures. Neurology. Nov. 2001;57(10):1774-9. [pmid: 11723262].
95 Ben-Menachem E, Falter U. Efficacy and tolerability of levetiracetam 3000 mg/d in patients with refractory partial seizures: a multicenter, double-blind, responder-selected study evaluating monotherapy. Epilepsia. 2000;41(10):1276-83. [pmid: 11051122].
96 Betts T, Waegemans T, Crawford P. A multicentre, double-blind, randomized, parallel group study to evaluate the tolerability and efficacy of two oral doses of levetiracetam, 2000 mg daily and 4000 mg daily, without titration in patients with refractory epilepsy. Seizure. Mar. 2000;9(2):80-7. [pmid: 10845730].
97 Cereghino J J, Biton V, Abou-Khalil B, et al. Levetiracetam for partial seizures: results of a double-blind, randomized clinical trial. Neurology. Jul. 2000;55(2):236-42. [pmid: 10908898].
98 Glauser T A, Nigro M, Sachdeo R, et al. Adjunctive therapy with oxcarbazepine in children with partial seizures. The Oxcarbazepine Pediatric Study Group. Neurology. Jun. 2000;54(12):2237-44. [pmid: 10881246].
99 Appleton R, Fichtner K, LaMoreaux L, et al. Gabapentin as add-on therapy in children with refractory partial seizures: a 12-week, multicentre, double-blind, placebo-controlled study. Gabapentin Paediatric Study Group. Epilepsia. Aug. 1999;40(8):1147-54. [pmid: 10448830].
100 Biton V, Montouris G D, Ritter F, et al. A randomized, placebo-controlled study of topiramate in primary generalized tonic-clonic seizures. Topiramate YTC Study Group. Neurology. Apr. 1999;52(7):1330-7. [pmid: 10227614].
101 Elterman R D, Glauser T A, Wyllie E, et al. A double-blind, randomized trial of topiramate as adjunctive therapy for partial-onset seizures in children. Topiramate YP Study Group. Neurology. Apr. 1999;52(7):1338-44. [pmid: 10227615].
102 Topiramate in medically intractable partial epilepsies: double-blind placebo-controlled randomized parallel group trial. Korean Topiramate Study Group. Epilepsia 1999 Dec;40(12):1767–74.
103 Sachdeo R C, Glauser T A, Ritter F, et al. A double-blind, randomized trial of topiramate in Lennox-Gastaut syndrome. Topiramate YL Study Group. Neurology. Jun. 1999;52(9):1882-7. [pmid: 10371538].
104 Uthman B M, Rowan A J, Ahmann P A, et al. Tiagabine for complex partial seizures: a randomized, add-on, dose-response trial. Arch Neurol. Jan. 1998;55(1):56-62. [pmid: 9443711].
105 Sachdeo R C, Leroy R F, Krauss G L, et al. Tiagabine therapy for complex partial seizures. A dose-frequency study. The Tiagabine Study Group. Arch Neurol. May. 1997;54(5):595-601. [pmid: 9152116].
106 Chadwick D, Leiderman D B, Sauermann W, et al. Gabapentin in generalized seizures. Epilepsy Res. Nov. 1996;25(3):191-7. [pmid: 8956916].
107 Privitera M, Fincham R, Penry J, et al. Topiramate placebo-controlled dose-ranging trial in refractory partial epilepsy using 600-, 800-, and 1,000-mg daily dosages. Topiramate YE Study Group. Neurology. Jun. 1996;46(6):1678-83. [pmid: 8649569].
108 Sharief M, Viteri C, Ben-Menachem E, et al. Double-blind, placebo-controlled study of topiramate in patients with refractory partial epilepsy. Epilepsy Res. Nov. 1996;25(3):217-24. [pmid: 8956919].
109 Tassinari C A, Michelucci R, Chauvel P, et al. Double-blind, placebo-controlled trial of topiramate (600 mg daily) for the treatment of refractory partial epilepsy. Epilepsia. Aug. 1996;37(8):763-8. [pmid: 8764816].
110 Willmore L J, Shu V, Wallin B. Efficacy and safety of add-on divalproex sodium in the treatment of complex partial seizures. The M88-194 Study Group. Neurology. Jan. 1996;46(1):49-53. [pmid: 8559420].
111 Anhut H, Ashman P, Feuerstein T J, et al. Gabapentin (Neurontin) as add-on therapy in patients with partial seizures: a double-blind, placebo-controlled study. The International Gabapentin Study Group. Epilepsia. 1994;35(4):795-801. [pmid: 8082624].
112 Messenheimer J, Ramsay R E, Willmore L J, et al. Lamotrigine therapy for partial seizures: a multicenter, placebo-controlled, double-blind, cross-over trial. Epilepsia. 1994;35(1):113-21. [pmid: 8112232].
113 Bourgeois B, Leppik I E, Sackellares J C, et al. Felbamate: a double-blind controlled trial in patients undergoing presurgical evaluation of partial seizures. Neurology. Apr. 1993;43(4):693-6. [pmid: 8469324].
114 Efficacy of felbamate in childhood epileptic encephalopathy (Lennox-Gastaut syndrome). The Felbamate Study Group in Lennox-Gastaut Syndrome. N Engl J Med 1993 Jan;328(1):29–33.
115 Matsuo F, Bergen D, Faught E, et al. Placebo-controlled study of the efficacy and safety of lamotrigine in patients with partial seizures. U.S. Lamotrigine Protocol 0.5 Clinical Trial Group. Neurology. Nov. 1993;43(11):2284-91. [pmid: 8232944].
116 McLean M J, Ramsay R E, Leppik L E, et al. Gabapentin as add-on therapy in refractory partial epilepsy: a double-blind, placebo-controlled, parallel-group study. Neurology. 1993;43(11):2292-8. [pmid: 8232945].
117 Schmidt D, Jacob R, Loiseau P, et al. Zonisamide for add-on treatment of refractory partial epilepsy: a European double-blind trial. Epilepsy Res. May. 1993;15(1):67-73. [pmid: 8325280].
118 Sivenius J, Kalviainen R, Ylinen A, et al. Double-blind study of Gabapentin in the treatment of partial seizures. Epilepsia. 1991;32(4):539-42. [pmid: 1907907].
119 Gabapentin in partial epilepsy. UK Gabapentin Study Group. Lancet 1990 May;335(8698):1114–7.
120 Mirza W U, Credeur L J, Penry J K. Results of antiepileptic drug reduction in patients with multiple handicaps and epilepsy. Drug Invest. 1993;5(6):320-6.
121 May T W, Bulmahn A, Wohlhuter M, et al. Effects of withdrawal of phenytoin on cognitive and psychomotor functions in hospitalized epileptic patients on polytherapy. Acta Neurol Scand. Aug. 1992;86(2):165-70. [pmid: 1414227].
122 Duncan J S, Shorvon S D, Trimble M R. Discontinuation of phenytoin, carbamazepine, and valproate in patients with active epilepsy. Epilepsia. 1990;31(3):324-33. [pmid: 2111768].
123 Specht U, Boenigk H E, Wolf P. Discontinuation of clonazepam after long-term treatment. Epilepsia. 1989;30(4):458-63. [pmid: 2502386].
124 Callaghan N, O'Dwyer R, Keating J. Unnecessary polypharmacy in patients with frequent seizures. Acta Neurol Scand. Jan. 1984;69(1):15-9. [pmid: 6422691].
125 Schmidt D. Reduction of two-drug therapy in intractable epilepsy. Epilepsia. Jun. 1983;24(3):368-76. [pmid: 6406214].
126 Thompson P J, Trimble M R. Anticonvulsant drugs and cognitive functions. Epilepsia. Oct. 1982;23(5):531-44. [pmid: 7140665].
127 Rohmel J. Therapeutic equivalence investigations: statistical considerations. Stat Med. Aug. 1998;17(1516):1703-14. [pmid: 9749441].
128 Blackwelder W C. ‘Proving the null hypothesis’ in clinical trials. Control Clin Trials. Dec. 1982;3(4):345-53. [pmid: 7160191].
129 Atherton Skaff PJ, Sloan JA. Design and analysis of equivalence clinical trials via the SAS system. In: Proceedings of the 23rd annual SAS users group international. March 22–25, 1998; Nashville (TN). Also available: http://www2.sas.com/proceedings/sugi23/Stats/p218.pdf.
130 Rodary C, Com-Nougue C, Tournade M F. How to establish equivalence between treatments: a one-sided clinical trial in paediatric oncology. Stat Med. May. 1989;8(5):593-8. [pmid: 2543048].
131 Sheiner L B. Bioequivalence revisited. Stat Med. Sep. 1992;11(13):1777-88. [pmid: 1485060].
132 Hermann B P, Wyler A R, VanderZwagg R, et al. Predictors of neuropsychological change following anterior temporal lobectomy: role of regression toward the mean. J Epilepsy. 1991;4(3):139-48.
133 Thompson P J, Trimble M R. Sodium valproate and cognitive functioning in normal volunteers. Br J Clin Pharmacol. 1981;12:819-24. [pmid: 6803819].
134 U.S. Preventive Services Task Force (USPSTF). Cost-effectiveness analyses of colorectal cancer screening: a systematic review for the US Preventive Services Task Force. Rockville (MD): Agency for Healthcare Research and Quality (AHRQ); 2002. 37 p.
135 Thompson PJ, Huppert FA. Problems in the development of measures to test cognitive performance in adult epileptic patients. In: Kulig B, Meinardi H, Stores G, editors. Epilepsy and behavior '79. Lisse: Swets & Zeitlinger; 1980. p. 37–42.
136 Kendrick A M, Duncan J S, Trimble M R. Effects of discontinuation of individual antiepileptic drugs on mood. Hum Psychopharmacol. 1993;8(4):263-270.
137 Duncan J S, Shorvon S D, Trimble M R. Effects of removal of phenytoin, carbamazepine, and valproate on cognitive function. Epilepsia. 1990;31(5):584-91. [pmid: 2119303].
138 Duncan J S, Shorvon S D, Trimble M R. Withdrawal symptoms from phenytoin, carbamazepine and sodium valproate. J Neurol Neurosurg Psychiatry. Jul. 1988;51(7):924-8. [pmid: 3144581].
139 Wyler AR. Recent advances in epilepsy surgery: temporal lobectomy and multiple subpial transections. Neurosurgery 1997 Dec;41(6):1294–301; discussion 1301.
140 National Institutes of Health Consensus Development Conference Statement: surgery for epilepsy, March 19–21, 1990. Epilepsia 1990;31(6):806–12
141 Tatum W O, Benbadis S R, Vale F L. The neurosurgical treatment of epilepsy. Arch Fam Med. 2000;9(10):1142-7. [pmid: 11115221].
142 Wyler AR, Hermann BP, Somes G. Extent of medial temporal resection on outcome from anterior temporal lobectomy: a randomized prospective study. Neurosurgery 1995 Nov;37(5):982–90; discussion 990–1.
143 Olivier A. Surgical techniques in temporal lobe epilepsy. Clin Neurosurg. 1997;44:211-41. [pmid: 10080010].
144 Engel J Jr, editor. Surgical treatment of the epilepsies. New York (NY): Raven Press; 1986. Outcome with respect to epileptic seizures. p. 553–71.
145 Wiebe S, Blume W T, Girvin J P, et al. A randomized, controlled trial of surgery for temporal-lobe epilepsy. N Engl J Med. Aug. 2001;345(5):311-8. [pmid: 11484687].
146 Blume W T, Desai H B, Girvin J P, et al. Effectiveness of temporal lobectomy measured by yearly follow-up and multivariate analysis. J Epilepsy. 1994;7:203-14.
147 Cutfield R G, Wrightson P. Surgery for temporal lobe epilepsy. N Z Med J. Mar. 1987;100(820):163-6. [pmid: 3452033].
148 Hennessy M J, Elwes R D, Honavar M, et al. Predictors of outcome and pathological considerations in the surgical treatment of intractable epilepsy associated with temporal lobe lesions. J Neurol Neurosurg Psychiatry. Apr. 2001;70(4):450-8. [pmid: 11254766].
149 Dodrill C B, Van Belle G, Wilkus R J. Stability of predictors of outcome of surgical treatment for epilepsy. J Epilepsy. 1990;3(1):29-35.
150 Rose K J, Derry P A, Wiebe S, et al. Determinants of health-related quality of life after temporal lobe epilepsy surgery. Qual Life Res. Jun. 1996;5(3):395-402. [pmid: 8763808].
151 Markand O N, Salanova V, Whelihan E, et al. Health-related quality of life outcome in medically refractory epilepsy treated with anterior temporal lobectomy. Epilepsia. Jun. 2000;41(6):749-59. [pmid: 10840409].
152 Mizrahi E M, Kellaway P, Grossman R G, et al. Anterior temporal lobectomy and medically refractory temporal lobe epilepsy of childhood. Epilepsia. 1990;31(3):302-12. [pmid: 2344847].
153 Delgado-Escueta A V, Walsh G O. Type I complex partial seizures of hippocampal origin: excellent results of anterior temporal lobectomy. Neurology. Feb. 1985;35(2):143-54. [pmid: 3969201].
154 Reeves A L, So E L, Evans R W, et al. Factors associated with work outcome after anterior temporal lobectomy for intractable epilepsy. Epilepsia. Jun. 1997;38(6):689-95. [pmid: 9186251].
155 Manchanda R, Schaefer B, McLachlan R S, et al. Psychiatric disorders in candidates for surgery for epilepsy. J Neurol Neurosurg Psychiatry. Jul. 1996;61(1):82-9. [pmid: 8676167].
156 Altshuler L, Rausch R, Delrahim S, et al. Temporal lobe epilepsy, temporal lobectomy, and major depression. J Neuropsychiatry Clin Neurosci 1999 Fall;11(4)436–43.
157 Jokeit H, Ebner A. Long term effects of refractory temporal lobe epilepsy on cognitive abilities: a cross sectional study. J Neurol Neurosurg Psychiatry. Jul. 1999;67(1):44-50. [pmid: 10369821].
158 Chelune G J, Naugle R I, Lueders H, et al. Individual change after epilepsy surgery: Practice effects and base-rate information. Neuropsychology. Jan. 1993;7(1):41-52.
159 Loring D W, Meador K J. Cognitive and behavioral effects of epilepsy treatment. Epilepsia. 2001;42(Suppl 8):24-32. [pmid: 11902326].
160 Guldvog B, Loyning Y, Hauglie-Hanssen E, et al. Surgical treatment for partial epilepsy among Norwegian adults. Epilepsia. 1994;35(3):540-53. [pmid: 8026400].
161 Guldvog B, Loyning Y, Hauglie-Hanssen E, et al. Surgical treatment for partial epilepsy among Norwegian children and adolescents. Epilepsia. 1994;35(3):554-65. [pmid: 8026401].
162 Bidzinski J. Temporal lobectomy. Acta Neurochir Suppl (Wien). 1990;50:119-21. [pmid: 2097886].
163 Davies K G, Weeks R D. Results of cortical resection for intractable epilepsy using intra-operative corticography without chronic intracranial recording. Br J Neurosurg. 1995;9(1):7-12. [pmid: 7786430].
164 Walczak T S, Radtke R A, McNamara J O, et al. Anterior temporal lobectomy for complex partial seizures: evaluation, results, and long-term follow-up in 100 cases. Neurology. Mar. 1990;40(3 Pt 1):413-8. [pmid: 2314581].
165 Bouilleret V, Dupont S, Spelle L, et al. Insular cortex involvement in mesiotemporal lobe epilepsy: a positron emission tomography study. Ann Neurol. Feb. 2002;51(2):202-8. [pmid: 11835376].
166 Son Y J, Chung C K, Lee S K, et al. Comparison of localizing values of various diagnostic tests in non-lesional medial temporal lobe epilepsy. Seizure. Dec. 1999;8(8):465-70. [pmid: 10627408].
167 Alsaadi T, Morris G L, Mueller W M. Prognostic value of the consistency of lateralizing ictal features and ictal EEG in patients undergoing temporal lobectomy for refractory complex partial seizures. Clin Electroencephalogr. Apr. 2001;32(2):87-91. [pmid: 11360726].
168 Maher J, McLachlan R S. Antiepileptic drug treatment following temporal lobectomy. Neurology. Jul. 1998;51(1):305-7. [pmid: 9674830].
169 Boling W, Andermann F, Reutens D, et al. Surgery for temporal lobe epilepsy in older patients. J Neurosurg. 2001;95(2):242-8. [pmid: 11780893].
170 Radhakrishnan K, So E L, Silbert P L, et al. Predictors of outcome of anterior temporal lobectomy for intractable epilepsy: a multivariate study. Neurology. Aug. 1998;51(2):465-71. [pmid: 9710020].
171 Hennessy M J, Elwes R D, Rabe-Hesketh S, et al. Prognostic factors in the surgical treatment of medically intractable epilepsy associated with mesial temporal sclerosis. Acta Neurol Scand. Jun. 2001;103(6):344-50. [pmid: 11421846].
172 Szabo C A, Wyllie E, Stanford L D, et al. Neuropsychological effect of temporal lobe resection in preadolescent children with epilepsy. Epilepsia. Aug. 1998;39(8):814-9. [pmid: 9701370].
173 Bizzi J W, Bruce D A, North R, et al. Surgical treatment of focal epilepsy in children: results in 37 patients. Pediatr Neurosurg. Feb. 1997;26(2):83-92. [pmid: 9419037].
174 Jan M M, Sadler M, Rahey S R. Lateralized postictal EEG delta predicts the side of seizure surgery in temporal lobe epilepsy. Epilepsia. Mar. 2001;42(3):402-5. [pmid: 11442160].
175 Cappabianca P, Alfieri A, Maiuri F, et al. Supratentorial cavernous malformations and epilepsy: seizure outcome after lesionectomy on a series of 35 patients. Clin Neurol Neurosurg. Aug. 1997;99(3):179-83. [pmid: 9350398].
176 Kanemoto K, Kim Y, Miyamoto T, et al. Presurgical postictal and acute interictal psychoses are differentially associated with postoperative mood and psychotic disorders. J Neuropsychiatry Clin Neurosci 2001 Spring;13(2):243–7.
177 Casazza M, Avanzini G, Ciceri E, et al. Lesionectomy in epileptogenic temporal lobe lesions: preoperative seizure course and postoperative outcome. Acta Neurochir Suppl (Wien). 1997;68:64-9.
178 Schramm J, Kral T, Grunwald T, et al. Surgical treatment for neocortical temporal lobe epilepsy: clinical and surgical aspects and seizure outcome. J Neurosurg. Jan. 2001;94(1):33-42. [pmid: 11147895].
179 Ho S S, Newton M R, McIntosh A M, et al. Perfusion patterns during temporal lobe seizures: relationship to surgical outcome. Brain. Nov. 1997;120(Pt 1):1921-8. [pmid: 9397011].
180 Sotero de Menezes M A, Connolly M, Bolanos A, et al. Temporal lobectomy in early childhood: the need for long-term follow-up. J Child Neurol. Aug. 2001;16(8):585-90. [pmid: 11510930].
181 Keene D L, Higgins M J, Ventureyra E C. Outcome and life prospects after surgical management of medically intractable epilepsy in patients under 18 years of age. Childs Nerv Syst. Oct. 1997;13(10):530-5. [pmid: 9403201].
182 Verma A, Lewis D, VanLandingham K E, et al. Lateralized seizure termination: relationship to outcome following anterior temporal lobectomy. Epilepsy Res. Nov. 2001;47(12):9-15. [pmid: 11673016].
183 Kilpatrick C, Cook M, Kaye A, et al. Non-invasive investigations successfully select patients for temporal lobe surgery. J Neurol Neurosurg Psychiatry. Sep. 1997;63(3):327-33. [pmid: 9328249].
184 Wilson S J, Bladin P F, Saling M M, et al. The longitudinal course of adjustment after seizure surgery. Seizure. Apr. 2001;10(3):165-72. [pmid: 11437614].
185 McLachlan R S, Rose K J, Derry P A, et al. Health-related quality of life and seizure control in temporal lobe epilepsy. Ann Neurol. Apr. 1997;41(4):482-9. [pmid: 9124805].
186 Dupont S, Semah F, Clemenceau S, et al. Accurate prediction of postoperative outcome in mesial temporal lobe epilepsy: a study using positron emission tomography with 18fluorodeoxyglucose. Arch Neurol. Sep. 2000;57(9):1331-6. [pmid: 10987901].
187 Schwartz TH, Bazil CW, Walczak TS, et al. The predictive value of intraoperative electrocorticography in resections for limbic epilepsy associated with mesial temporal sclerosis. Neurosurgery 1997 Feb;40(2):302–9; discussion 309–11.
188 Eberhardt K E, Stefan H, Buchfelder M, et al. The significance of bilateral CSI changes for the postoperative outcome in temporal lobe epilepsy. J Comput Assist Tomogr. 2000;24(6):919-26. [pmid: 11105713].
189 Silander H C, Blom S, Malmgren K, et al. Surgical treatment for epilepsy: a retrospective Swedish multicenter study. Acta Neurol Scand. 1997;95(6):321-30. [pmid: 9395431].
190 Foldvary N, Nashold B, Mascha E, et al. Seizure outcome after temporal lobectomy for temporal lobe epilepsy: a Kaplan-Meier survival analysis. Neurology. Feb. 2000;54(3):630-4. [pmid: 10680795].
191 Sisodiya S M, Moran N, Free S L, et al. Correlation of widespread preoperative magnetic resonance imaging changes with unsuccessful surgery for hippocampal sclerosis. Ann Neurol. Apr. 1997;41(4):490-6. [pmid: 9124806].
192 Holmes M D, Born D E, Kutsy R L, et al. Outcome after surgery in patients with refractory temporal lobe epilepsy and normal MRI. Seizure. Sep. 2000;9(6):407-11. [pmid: 10985997].
193 Adam C, Clemenceau S, Semah F, et al. Variability of presentation in medial temporal lobe epilepsy: a study of 30 operated cases. Acta Neurol Scand. Jul. 1996;94(1):1-11. [pmid: 8874586].
194 Iannelli A, Guzzetta F, Battaglia D, et al. Surgical treatment of temporal tumors associated with epilepsy in children. Pediatr Neurosurg. May. 2000;32(5):248-54. [pmid: 10965271].
195 Goldstein R, Harvey A S, Duchowny M, et al. Preoperative clinical, EEG, and imaging findings do not predict seizure outcome following temporal lobectomy in childhood. J Child Neurol. Nov. 1996;11(6):445-50. [pmid: 9120221].
196 Holmes M D, Dodrill C B, Ojemann L M, et al. Five-year outcome after epilepsy surgery in nonmonitored and monitored surgical candidates. Epilepsia. Aug. 1996;37(8):748-52. [pmid: 8764813].
197 Rao M B, Radhakrishnan K. Is epilepsy surgery possible in countries with limited resources?. Epilepsia. 2000;41(Suppl 4):S31-4. [pmid: 10963475].
198 Sirven J I, Sperling M R, French J A, et al. Significance of simple partial seizures in temporal lobe epilepsy. Epilepsia. May. 1996;37(5):450-4. [pmid: 8617173].
199 Robinson S, Park T S, Blackburn L B, et al. Transparahippocampal selective amygdalohippocampectomy in children and adolescents: efficacy of the procedure and cognitive morbidity in patients. J Neurosurg. Sep. 2000;93(3):402-9. [pmid: 10969937].
200 Acciarri N, Giulioni M, Padovani R, et al. Surgical management of cerebral cavernous angiomas causing epilepsy. J Neurosurg Sci. Mar. 1995;39(1):13-20. [pmid: 8568551].
201 Assaf B A, Ebersole J S. Visual and quantitative ictal EEG predictors of outcome after temporal lobectomy. Epilepsia. Jan. 1999;40(1):52-61. [pmid: 9924902].
202 Berkovic S F, McIntosh A M, Kalnins R M, et al. Preoperative MRI predicts outcome of temporal lobectomy: an actuarial analysis. Neurology. Jul. 1995;45(7):1358-63. [pmid: 7617198].
203 Eriksson S, Malmgren K, Rydenhag B, et al. Surgical treatment of epilepsy--clinical, radiological and histopathological findings in 139 children and adults. Acta Neurol Scand. Jan. 1999;99(1):8-15. [pmid: 9925233].
204 Henry T R, Ross D A, Schuh L A, et al. Indications and outcome of ictal recording with intracerebral and subdural electrodes in refractory complex partial seizures. J Clin Neurophysiol. Sep. 1999;16(5):426-38. [pmid: 10576225].
205 Jooma R, Yeh H S, Privitera M D, et al. Lesionectomy versus electrophysiologically guided resection for temporal lobe tumors manifesting with complex partial seizures. J Neurosurg. Aug. 1995;83(2):231-6. [pmid: 7616267].
206 Holmes M D, Wilensky A J, Ojemann G A, et al. Hippocampal or neocortical lesions on magnetic resonance imaging do not necessarily indicate site of ictal onsets in partial epilepsy. Ann Neurol. Apr. 1999;45(4):461-5. [pmid: 10211470].
207 Jooma R, Yeh H S, Privitera M D, et al. Seizure control and extent of mesial temporal resection. Acta Neurochir (Wien). 1995;133(12):44-9. [pmcid: 300905]. [pmid: 8561035].
208 Mathern G W, Giza C C, Yudovin S, et al. Postoperative seizure control and antiepileptic drug use in pediatric epilepsy surgery patients: the UCLA experience, 1986-1997. Epilepsia. Dec. 1999;40(12):1740-9. [pmid: 10612338].
209 Liu MY, Yeh HS, Blisard K, et al. Surgical management of epilepsy associated with developmental anomalies of the brain. Surg Neurol 1995 Feb;43(2):182–8; discussion 188–90.
210 Mitchell L A, Jackson G D, Kalnins R M, et al. Anterior temporal abnormality in temporal lobe epilepsy: a quantitative MRI and histopathologic study. Neurology. Jan. 1999;52(2):327-36. [pmid: 9932952].
211 Renowden S A, Matkovic Z, Adams C B, et al. Selective amygdalohippocampectomy for hippocampal sclerosis: postoperative MR appearance. AJNR Am J Neuroradiol. Oct. 1995;16(9):1855-61. [pmid: 8693986].
212 Rossi G F, Pompucci A, Colicchio G, et al. Factors of surgical outcome in tumoural epilepsy. Acta Neurochir (Wien). 1999;141(8):819-24. [pmcid: 300905]. [pmid: 10536717].
213 Thadani V M, Williamson P D, Berger R, et al. Successful epilepsy surgery without intracranial EEG recording: criteria for patient selection. Epilepsia. Jan. 1995;36(1):7-15. [pmid: 8001512].
214 Salanova V, Markand O, Worth R. Longitudinal follow-up in 145 patients with medically refractory temporal lobe epilepsy treated surgically between 1984 and 1995. Epilepsia. Oct. 1999;40(10):1417-23. [pmid: 10528938].
215 Vossler D G, Wilkus R J, Ojemann G A. Preoperative EEG correlates of seizure outcome from epilepsy surgery in children. J Epilepsy. 1995;8(3):236-45.
216 Berkovic S F, Andermann F, Olivier A, et al. Hippocampal sclerosis in temporal lobe epilepsy demonstrated by magnetic resonance imaging. Ann Neurol. Feb. 1991;29(2):175-82. [pmid: 2012385].
217 Hopkins I J, Klug G L. Temporal lobectomy for the treatment of intractable complex partial seizures of temporal lobe origin in early childhood. Dev Med Child Neurol. Jan. 1991;33(1):26-31. [pmid: 1995406].
218 Rasmussen T, Feindel W. Temporal lobectomy: review of 100 cases with major hippocampectomy. Can J Neurol Sci. Nov. 1991;18(4 Suppl):601-2. [pmid: 1777878].
219 Wieser H G. Selective amygdalohippocampectomy: indications and follow-up. Can J Neurol Sci. Nov. 1991;18(4 Suppl):617-27. [pmid: 1777882].
220 Yeh H S, Kashiwagi S, Tew J M Jr, et al. Surgical management of epilepsy associated with cerebral arteriovenous malformations. J Neurosurg. Feb. 1990;72(2):216-23. [pmid: 2295919].
221 Sperling M R, Lieb J P, Engel J Jr, et al. Prognostic significance of independent auras in temporal lobe seizures. Epilepsia. 1989;30(3):322-31. [pmid: 2721465].
222 Estes M L, Morris H H 3rd, Luders H, et al. Surgery for intractable epilepsy. Clinicopathologic correlates in 60 cases. Cleve Clin J Med. 1988;55(5):441-7. [pmid: 3146451].
223 Bladin P F. Post-temporal lobectomy seizures. Clin Exp Neurol. 1987;24:77-83. [pmid: 3151879].
224 Drake J, Hoffman H J, Kobayashi J, et al. Surgical management of children with temporal lobe epilepsy and mass lesions. Neurosurgery. Dec. 1987;21(6):792-7. [pmid: 3437944].
225 Lieb J P, Engel J Jr, Babb T L. Interhemispheric propagation time of human hippocampal seizures. I. Relationship to surgical outcome. Epilepsia. 1986;27(3):286-93. [pmid: 3516670].
226 Meyer F B, Marsh W R, Laws E R Jr, et al. Temporal lobectomy in children with epilepsy. J Neurosurg. Mar. 1986;64(3):371-6. [pmid: 3950715].
227 Bauer J, Burr W. Course of chronic focal epilepsy resistant to anticonvulsant treatment. Seizure. Jun. 2001;10(4):239-46. [pmid: 11466018].
228 Kumlien E, Doss R C, Gates J R. Treatment outcome in patients with mesial temporal sclerosis. Seizure. 2001;0:1-5.
229 Holmes M D, Dodrill C B, Wilkus R J, et al. Is partial epilepsy progressive? Ten-year follow-up of EEG and neuropsychological changes in adults with partial seizures. Epilepsia. Nov. 1998;39(11):1189-93. [pmid: 9821983].
230 Wolf P. Treatment of epilepsy following rejection of epilepsy surgery. Seizure. Feb. 1998;7(1):25-9. [pmid: 9548222].
231 Hermanns G, Noachtar S, Tuxhorn I, et al. Systematic testing of medical intractability for carbamazepine, phenytoin, and phenobarbital or primidone in monotherapy for patients considered for epilepsy surgery. Epilepsia. Jul. 1996;37(7):675-9. [pmid: 8681900].
232 Vickrey B G, Hays R D, Rausch R, et al. Outcomes in 248 patients who had diagnostic evaluations for epilepsy surgery. Lancet. Dec. 1995;346(8988):1445-9. [pmid: 7490989].
233 Guldvog B, Loyning Y, Hauglie-Hanssen E, et al. Surgical versus medical treatment for epilepsy. I. Outcome related to survival, seizures, and neurologic deficit. Epilepsia. 1991;32(3):375-88. [pmid: 2044500].
234 Huttenlocher P R, Hapke R J. A follow-up study of intractable seizures in childhood. Ann Neurol. Nov. 1990;28(5):699-705. [pmid: 2260857].
235 Harbord M G, Manson J I. Temporal lobe epilepsy in childhood: reappraisal of etiology and outcome. Pediatr Neurol. 1987;3(5):263-8. [pmid: 3508075].
236 Sperling M R, Saykin A J, Roberts F D, et al. Occupational outcome after temporal lobectomy for refractory epilepsy. Neurology. May. 1995;45(5):970-7. [pmid: 7746417].
237 Kohler C G, Carran M A, Bilker W, et al. Association of fear auras with mood and anxiety disorders after temporal lobectomy. Epilepsia. May. 2001;42(5):674-81. [pmid: 11380577].
238 Nees H, Moriarty J, Kitchen N D, et al. Psychosocial and neurobehavioral factors related to surgical treatment for partial epilepsy: a multivariate analysis. Epilepsy Behav. Apr. 2001;2(2):135-9. [pmid: 12609197].
239 Anhoury S, Brown R J, Krishnamoorthy E S, et al. Psychiatric outcome after temporal lobectomy: a predictive study. Epilepsia. Dec. 2000;41(12):1608-15. [pmid: 11114220].
240 Derry P A, Rose K J, McLachlan R S. Moderators of the effect of preoperative emotional adjustment on postoperative depression after surgery for temporal lobe epilepsy. Epilepsia. Feb. 2000;41(2):177-85. [pmid: 10691114].
241 Ring H A, Moriarty J, Trimble M R. A prospective study of the early postsurgical psychiatric associations of epilepsy surgery. J Neurol Neurosurg Psychiatry. May. 1998;64(5):601-4. [pmid: 9598674].
242 Naylor A S, Rogvi-Hansen B, Kessing L, et al. Psychiatric morbidity after surgery for epilepsy: short term follow up of patients undergoing amygdalohippocampectomy. J Neurol Neurosurg Psychiatry. 1994;57(11):1375-81. [pmid: 7964815].
243 Bladin P F. Psychosocial difficulties and outcome after temporal lobectomy. Epilepsia. 1992;33(5):898-907. [pmid: 1396433].
244 Blumer D, Wakhlu S, Davies K, et al. Psychiatric outcome of temporal lobectomy for epilepsy: incidence and treatment of psychiatric complications. Epilepsia. May. 1998;39(5):478-86. [pmid: 9596199].
245 Miranda C, Smith M L. Predictors of intelligence after temporal lobectomy in children with epilepsy. Epilepsy Behav. Feb. 2001;2(1):13-9. [pmid: 12609177].
246 Westerveld M, Sass K J, Chelune G J, et al. Temporal lobectomy in children: cognitive outcome. J Neurosurg. Jan. 2000;92(1):24-30. [pmid: 10616078].
247 Ivnik R J, Sharbrough F W, Laws E R Jr. Anterior temporal lobectomy for the control of partial complex seizures: information for counseling patients. Mayo Clin Proc. Aug. 1988;63(8):783-93. [pmid: 3398596].
248 Powell G E, Polkey C E, McMillan T. The new Maudsley series of temporal lobectomy. I: Short-term cognitive effects. Br J Clin Psychol. May. 1985;24(Pt 2):109-24. [pmid: 3924150].
249 Canizares S, Torres X, Boget T, et al. Does neuroticism influence cognitive self-assessment after epilepsy surgery?. Epilepsia. Oct. 2000;41(10):1303-9. [pmid: 11051126].
250 Ojemann G A, Dodrill C B. Verbal memory deficits after left temporal lobectomy for epilepsy. Mechanism and intraoperative prediction. J Neurosurg. Jan. 1985;62(1):101-7. [pmid: 3964840].
251 Wurm G, Wies W, Schnizer M, et al. Advanced surgical approach for selective amygdalohippocampectomy through neuronavigation. Neurosurgery 2000 Jun;46(6):1377–82; discussion 1382–3.
252 Leung G K, Fan Y W, Fong K Y. Temporal lobe resection for intractable epilepsy: review of 11 cases. Hong Kong Med J. Dec. 1999;5(4):329-336. [pmid: 10870158].
253 Parrent A G, Blume W T. Stereotactic amygdalohippocampotomy for the treatment of medial temporal lobe epilepsy. Epilepsia. Oct. 1999;40(10):1408-16. [pmid: 10528937].
254 Mackenzie RA, Matheson JM, Smith JS, et al. Surgery for refractory epilepsy. Med J Aust 1990 Jul;153(2):69–72, 76.
255 Visudhiphan P, Bunyaratavej S, Visudtibhan A, et al. Temporal lobectomy for intractable complex partial seizures in pediatric patients. J Med Assoc Thai. Aug. 1999;82(8):778-83. [pmid: 10511785].
256 So N, Olivier A, Andermann F, et al. Results of surgical treatment in patients with bitemporal epileptiform abnormalities. Ann Neurol. May. 1989;25(5):432-9. [pmid: 2774484].
257 Wyllie E, Comair Y G, Kotagal P, et al. Seizure outcome after epilepsy surgery in children and adolescents. Ann Neurol. Nov. 1998;44(5):740-8. [pmid: 9818929].
258 King D W, Flanigin H F, Gallagher B B, et al. Temporal lobectomy for partial complex seizures: evaluation, results, and 1-year follow-up. Neurology. Mar. 1986;36(3):334-9. [pmid: 3951699].
259 Blume W T, Girvin J P, McLachlan R S, et al. Effective temporal lobectomy in childhood without invasive EEG. Epilepsia. Feb. 1997;38(2):164-7. [pmid: 9048667].
260 Carey P, O'Moore B, Sheahan K, et al. Experience of temporal lobectomy as a treatment modality for epilepsy, using inter-ictal EEG data alone to localize the epileptogenic focus. Ir Med J. 1985;78(3):74-7. [pmid: 3988494].
261 Elwes R D, Dunn G, Binnie C D, et al. Outcome following resective surgery for temporal lobe epilepsy: a prospective follow up study of 102 consecutive cases. J Neurol Neurosurg Psychiatry. Nov. 1991;54(11):949-52. [pmid: 1800664].
262 Lesser R P, Fisher R S, Uematsu S. Assessment of surgical outcome. Epilepsy Res. 1992;(Suppl 5):217-29.
263 Gates JR, Wada JA, Reeves AG, et al. Reevaluation of corpus callosotomy. In: Surgical treatment of the epilepsies. 2nd ed. New York (NY): Raven Press; 1993. p. 637–48.
264 Carson B S Sr. Indications and outcomes for lobectomy, corpus callosotomy, and hemispherectomy in pediatric neurosurgical patients. Clin Neurosurg. 2000;47:385-99. [pmid: 11197713].
265 Gates J R, Rosenfeld W E, Maxwell R E, et al. Response of multiple seizure types to corpus callosum section. Epilepsia. 1987;28(1):28-34. [pmid: 3098553].
266 Spencer S S. Corpus callosum section and other disconnection procedures for medically intractable epilepsy. Epilepsia. 1988;29(Suppl 2):S85-99. [pmid: 3168962].
267 Spencer S S, Spencer D D, Williamson P D, et al. Corpus callosotomy for epilepsy. I. Seizure effects. Neurology. Jan. 1988;38(1):19-24. [pmid: 3122070].
268 Sakas D E, Phillips J. Anterior callosotomy in the management of intractable epileptic seizures: significance of the extent of resection. Acta Neurochir (Wien). 1996;138(6):700-7. [pmcid: 300905]. [pmid: 8836285].
269 Cohen M J, Holmes G L, Campbell R, et al. Cognitive functioning following anterior two-thirds corpus callosotomy in children and adolescents: a one-year prospective report. J Epilepsy. 1991;4(2):63-5.
270 Kwan S Y, Wong T T, Chang K P, et al. Seizure outcomes after anterior callosotomy in patients with posterior-dominant and with anterior-dominant epileptiform discharges. Childs Nerv Syst. Jan. 2001;17(12):71-5. [pmid: 11219628].
271 Maehara T, Shimizu H. Surgical outcome of corpus callosotomy in patients with drop attacks. Epilepsia. Jan. 2001;42(1):67-71. [pmid: 11207787].
272 Matsuzaka T, Ono K, Baba H, et al. Quantitative EEG analyses and surgical outcome after corpus callosotomy. Epilepsia. Sep. 1999;40(9):1269-78. [pmid: 10487191].
273 McInerney J, Siegel A M, Nordgren R E, et al. Long-term seizure outcome following corpus callosotomy in children. Stereotactic Funct Neurosurg. 1999;73(14):79-83.
274 Claverie B, Rougier A. Life comfort and psychosocial adjustment linked to age at the time of anterior callosotomy. J Epilepsy. 1995;8(4):321-31.
275 Reutens D C, Bye A M, Hopkins I J, et al. Corpus callosotomy for intractable epilepsy: seizure outcome and prognostic factors. Epilepsia. 1993;34(5):904-9. [pmid: 8404745].
276 Marino R Jr, Radvany J, Huck F R, et al. Selective electroencephalograph-guided microsurgical callosotomy for refractory generalized epilepsy. Surg Neurol. Oct. 1990;34(4):219-28. [pmid: 2399483].
277 Murro A M, Flanigin H F, Gallagher B B, et al. Corpus callosotomy for the treatment of intractable epilepsy. Epilepsy Res. 1988;2(1):44-50. [pmid: 3197679].
278 Purves S J, Wada J A, Woodhurst W B, et al. Results of anterior corpus callosum section in 24 patients with medically intractable seizures. Neurology. Aug. 1988;38(8):1194-201. [pmid: 3399067].
279 Nordgren R E, Reeves A G, Viguera A C, et al. Corpus callosotomy for intractable seizures in the pediatric age group. Arch Neurol. Apr. 1991;48(4):364-72. [pmid: 2012509].
280 Hodaie M, Musharbash A, Otsubo H, et al. Image-guided, frameless stereotactic sectioning of the corpus callosum in children with intractable epilepsy. Pediatr Neurosurg. Jun. 2001;34(6):286-94. [pmid: 11455228].
281 Fandino-Franky J, Torres M, Narino D, et al. Corpus callosotomy in Colombia and some reflections on care and research among the poor in developing countries. Epilepsia. 2000;41(Suppl 4):S22-7. [pmid: 10963473].
282 Pinard J M, Delalande O, Chiron C, et al. Callosotomy for epilepsy after West syndrome. Epilepsia. Dec. 1999;40(12):1727-34. [pmid: 10612336].
283 Carmant L, Holmes G L, Lombroso C T. Outcome following corpus callosotomy. J Epilepsy. 1998;11(4):224-8.
284 Sorenson J M, Wheless J W, Baumgartner J E, et al. Corpus callosotomy for medically intractable seizures. Pediatr Neurosurg. Nov. 1997;27(5):260-7. [pmid: 9620004].
285 Andersen B, Rogvi-Hansen B, Kruse-Larsen C, et al. Corpus callosotomy: seizure and psychosocial outcome. A 39-month follow-up of 20 patients. Epilepsy Res. Feb. 1996;23(1):77-85. [pmid: 8925805].
286 Rossi G F, Colicchio G, Marchese E, et al. Callosotomy for severe epilepsies with generalized seizures: outcome and prognostic factors. Acta Neurochir (Wien). 1996;138(2):221-7. [pmcid: 300905]. [pmid: 8686549].
287 Fuiks K S, Wyler A R, Hermann B P, et al. Seizure outcome from anterior and complete corpus callosotomy. J Neurosurg. Apr. 1991;74(4):573-8. [pmid: 2002370].
288 Oguni H, Olivier A, Andermann F, et al. Anterior callosotomy in the treatment of medically intractable epilepsies: a study of 43 patients with a mean follow-up of 39 months. Ann Neurol. Sep. 1991;30(3):357-64. [pmid: 1952824].
289 Provinciali L, Del Pesce M, Censori B, et al. Evolution of neuropsychological changes after partial callosotomy in intractable epilepsy. Epilepsy Res. Jul. 1990;6(2):155-65. [pmid: 2117530].
290 Sass K J, Novelly R A, Spencer D D, et al. Postcallosotomy language impairments in patients with crossed cerebral dominance. J Neurosurg. 1990;72(1):85-90. [pmid: 2294190].
291 Garcia-Flores E. Corpus callosum section for patients with intractable epilepsy. Appl Neurophysiol. 1987;50(16):390-7. [pmid: 3450244].
292 Swartz B E, Delgado-Escueta A V, Walsh G O, et al. Surgical outcomes in pure frontal lobe epilepsy and foci that mimic them. Epilepsy Res. 1998;29(2):97-108. [pmid: 9477141].
293 Smith J R, Lee M R, King D W, et al. Results of lesional vs. nonlesional frontal lobe epilepsy surgery. Stereotactic Funct Neurosurg. 1997;69(14 Pt 2):202-9.
294 Chassoux F, Devaux B, Landre E, et al. Postoperative motor deficits and recovery after cortical resections. Adv Neurol. 1999;81:189-99. [pmid: 10609016].
295 Kral T, Kuczaty S, Blumcke I, et al. Postsurgical outcome of children and adolescents with medically refractory frontal lobe epilepsies. Childs Nerv Syst. Oct. 2001;17(10):595-601. [pmid: 11685521].
296 Ferrier C H, Alarcon G, Engelsman J, et al. Relevance of residual histologic and electrocorticographic abnormalities for surgical outcome in frontal lobe epilepsy. Epilepsia. Mar. 2001;42(3):363-71. [pmid: 11442154].
297 Siegel A M, Jobst B C, Thadani V M, et al. Medically intractable, localization-related epilepsy with normal mri: presurgical evaluation and surgical outcome in 43 patients. Epilepsia. Jul. 2001;42(7):883-8. [pmid: 11488888].
298 Hong S C, Kang K S, Seo D W, et al. Surgical treatment of intractable epilepsy accompanying cortical dysplasia. J Neurosurg. Nov. 2000;93(5):766-73. [pmid: 11059656].
299 Wennberg R, Quesney L F, Lozano A, et al. Role of electrocorticography at surgery for lesion-related frontal lobe epilepsy. Can J Neurol Sci. Feb. 1999;26(1):33-9. [pmid: 10068805].
300 Adler J, Erba G, Winston K R, et al. Results of surgery for extratemporal partial epilepsy that began in childhood. Arch Neurol. Feb. 1991;48(2):133-40. [pmid: 1899561].
301 Garcia Sola R, Miravet J. Surgical treatment for epilepsy. Results after a minimum follow-up of five years. Acta Neurochir Suppl (Wien). 1991;52:157-60. [pmid: 1792958].
302 Palmini A, Andermann F, Olivier A, et al. Focal neuronal migration disorders and intractable partial epilepsy: results of surgical treatment. Ann Neurol. Dec. 1991;30(6):750-7. [pmid: 1789692].
303 Rasmussen T. Tailoring of cortical excisions for frontal lobe epilepsy. Can J Neurol Sci. Nov. 1991;18(4 Suppl):606-10. [pmid: 1777880].
304 Mosewich R K, So E L, O'Brien T J, et al. Factors predictive of the outcome of frontal lobe epilepsy surgery. Epilepsia. Jul. 2000;41(7):843-9. [pmid: 10897155].
305 Ferrier C H, Engelsman J, Alarcon G, et al. Prognostic factors in presurgical assessment of frontal lobe epilepsy. J Neurol Neurosurg Psychiatry. Mar. 1999;66(3):350-6. [pmid: 10084534].
306 Helmstaedter C, Gleibner U, Zentner J, et al. Neuropsychological consequences of epilepsy surgery in frontal lobe epilepsy. Neuropsychologia. Apr. 1998;36(4):333-41. [pmid: 9665644].
307 Vining E P, Freeman J M, Pillas D J, et al. Why would you remove half a brain? The outcome of 58 children after hemispherectomy-the Johns Hopkins experience: 1968 to 1996. Pediatrics. Aug. 1997;100(2 Pt 1):163-71. [pmid: 9240794].
308 Berg A T, Shinnar S. The contributions of epidemiology to the understanding of childhood seizures and epilepsy. J Child Neurol. Oct. 1994;9(Suppl 2):19-26. [pmid: 7806782].
309 Tinuper P, Andermann F, Villemure J G, et al. Functional hemispherectomy for treatment of epilepsy associated with hemiplegia: rationale, indications, results, and comparison with callosotomy. Ann Neurol. Jul. 1988;24(1):27-34. [pmid: 3137858].
310 Lindsay J, Ounsted C, Richards P. Hemispherectomy for childhood epilepsy: a 36-year study. Dev Med Child Neurol. Oct. 1987;29(5):592-600. [pmid: 3666325].
311 Di Rocco C, Iannelli A. Hemimegalencephaly and intractable epilepsy: complications of hemispherectomy and their correlations with the surgical technique. A report on 15 cases. Pediatr Neurosurg. Oct. 2000;33(4):198-207. [pmid: 11124637].
312 Carreno M, Wyllie E, Bingaman W, et al. Seizure outcome after functional hemispherectomy for malformations of cortical development. Neurology. Jul. 2001;57(2):331-3. [pmid: 11468323].
313 Schramm J, Kral T, Clusmann H, et al. Transsylvian keyhole functional hemispherectomy. Neurosurgery. 2001;49(4):891-901. [pmid: 11564251].
314 Shimizu H, Maehara T. Modification of peri-insular hemispherotomy and surgical results. Neurosurgery 2000 Aug;47(2):367–72; discussion 372–3.
315 Battaglia D, Di Rocco C, Iuvone L, et al. Neuro-cognitive development and epilepsy outcome in children with surgically treated hemimegalencephaly. Neuropediatrics. Dec. 1999;30(6):307-13. [pmid: 10706025].
316 Peacock W J, Wehby-Grant M C, Shields W D, et al. Hemispherectomy for intractable seizures in children: a report of 58 cases. Childs Nerv Syst. Jul. 1996;12(7):376-84. [pmid: 8869773].
317 Schramm J, Behrens E, Entzian W. Hemispherical deafferentation: an alternative to functional hemispherectomy. Neurosurgery 1995 Mar;36(3):509–15; discussion 515–6.
318 Morrell F, Whisler W W, Bleck T P. Multiple subpial transection: a new approach to the surgical treatment of focal epilepsy. J Neurosurg. Feb. 1989;70(2):231-9. [pmid: 2492335].
319 Morrell F, Kanner A M, de Toledo-Morrell L, et al. Multiple subpial transection. Adv Neurol. 1999;81:259-70. [pmid: 10609022].
320 Orbach D, Romanelli P, Devinsky O, et al. Late seizure recurrence after multiple subpial transections. Epilepsia. 2001;49(9):1130-33. [pmid: 11580759].
321 Mulligan L P, Spencer D D, Spencer S S. Multiple subpial transections: the Yale experience. Epilepsia. Feb. 2001;42(2):226-9. [pmid: 11240594].
322 Sawhney I M, Robertson I J, Polkey C E, et al. Multiple subpial transection: a review of 21 cases. J Neurol Neurosurg Psychiatry. Mar. 1995;58(3):344-9. [pmid: 7897419].
323 Shimizu H, Maehara T. Neuronal disconnection for the surgical treatment of pediatric epilepsy. Epilepsia. 2000;41(Suppl 9):28-30. [pmid: 11156507].
324 Smith M C. Multiple subpial transection in patients with extratemporal epilepsy. Epilepsia. 1998;39(Suppl 4):S81-9. [pmid: 9637596].
325 Hufnagel A, Zentner J, Fernandez G, et al. Multiple subpial transection for control of epileptic seizures: effectiveness and safety. Epilepsia. 1997;38(6):678-88. [pmid: 9186250].
326 Pacia S V, Devinsky O, Perrine K, et al. Multiple subpial transection for intractable partial seizures: seizure outcome. J Epilepsy. 1997;10(2):86-91.
327 Patil AA, Andrews RV, Torkelson R. Surgical treatment of intractable seizures with multilobar or bihemispheric seizure foci (MLBHSF). Surg Neurol 1997 Jan;47(1):72–7; discussion 77–8.
328 Morrell F, Whisler W W, Smith M C, et al. Landau-Kleffner syndrome. Treatment with subpial intracortical transection. Brain. Dec. 1995;118(Pt 6):1529-46. [pmid: 8595482].
329 Shimizu H, Suzuki I, Ishijima B, et al. Multiple subpial transection (MST) for the control of seizures that originated in unresectable cortical foci. Jpn J Psychiatry Neurol. Jun. 1991;45(2):354-6. [pmid: 1762216].
330 Binnie C D. Vagus nerve stimulation for epilepsy: a review. Seizure. Apr. 2000;9(3):161-9. [pmid: 10775511].
331 A randomized controlled trial of chronic vagus nerve stimulation for treatment of medically intractable seizures. The Vagus Nerve Stimulation Study Group. Neurology 1995 Feb;45(2):224–30
332 Handforth A, DeGiorgio C M, Schachter S C, et al. Vagus nerve stimulation therapy for partial-onset seizures: a randomized active-control trial. Neurology. Jul. 1998;51(1):48-55. [pmid: 9674777].
333 DeGiorgio C M, Schachter S C, Handforth A, et al. Prospective long-term study of vagus nerve stimulation for the treatment of refractory seizures. Epilepsia. Sep. 2000;41(9):1195-200. [pmid: 10999559].
334 Labar D, Murphy J, Tecoma E. Vagus nerve stimulation for medication-resistant generalized epilepsy. E04 VNS Study Group. Neurology. Apr. 1999;52(7):1510-2. [pmid: 10227649].
335 Ergene E, Behr P K, Shih J J. Quality-of-life assessment in patients treated with vagus nerve stimulation. Epilepsy Behav. Jun. 2001;2(3):284-7. [pmid: 12609371].
336 Hosain S, Nikalov B, Harden C, et al. Vagus nerve stimulation treatment for Lennox-Gastaut syndrome. J Child Neurol. Aug. 2000;15(8):509-12. [pmid: 10961788].
337 Aldenkamp A P, Van de Veerdonk S H, Majoie H J, et al. Effects of 6 months of treatment with vagus nerve stimulation on behavior in children with Lennox-Gastaut syndrome in an open clinical nonrandomized study. Epilepsy Behav. Aug. 2001;2(4):343-50. [pmid: 12609211].
338 Boon P, Vonck K, D'Have M, et al. Cost-benefit of vagus nerve stimulation for refractory epilepsy. Acta Neurol Belg. Dec. 1999;99(4):275-80. [pmid: 10674145].
339 Hoppe C, Helmstaedter C, Scherrmann J, et al. No evidence for cognitive side effects after 6 months of vagus nerve stimulation in epilepsy patients. Epilepsy Behav. Aug. 2001;2(4):351-6. [pmid: 12609212].
340 Parker A P, Polkey C E, Binnie C D, et al. Vagal nerve stimulation in epileptic encephalopathies. Pediatrics. Apr. 1999;103(4 Pt 1):778-82. [pmid: 10103302].
341 Lundgren J, Amark P, Blennow G, et al. Vagus nerve stimulation in 16 children with refractory epilepsy. Epilepsia. Aug. 1998;39(8):809-13. [pmid: 9701369].
342 Bus A G, van IJzendoorn M H. Phonological awareness and early reading: a meta-analysis of experimental training studies. J Educ Psychol. 1999;91(3):403-14.
343 Ben-Menachem E, Hellstrom K, Waldton C, et al. Evaluation of refractory epilepsy treated with vagus nerve stimulation for up to 5 years. Neurology. Apr. 1999;52(6):1265-7. [pmid: 10214754].
344 Noseworthy J H, Ebers G C, Vandervoort M K, et al. The impact of blinding on the results of a randomized, placebo-controlled multiple sclerosis clinical trial. Neurology. Jan. 1994;44(1):16-20. [pmid: 8290055].
345 Schulz K F, Grimes D A. Blinding in randomised trials: hiding who got what. Lancet. Feb. 2002;359:696-700. [pmid: 11879884].
346 Chayasirisobhon S, Koulouris S, Parker E, et al. Vagus nerve stimulation for refractory epilepsy. Perm J 2001 Fall;5(4):21–6.
347 Dodrill C B, Morris G L. Effects of vagal nerve stimulation on cognition and quality of life in epilepsy. Epilepsy Behav. Feb. 2001;2(1):46-53. [pmid: 12609181].
348 Kotchoubey B, Schneider D, Schleichert H, et al. Self-regulation of slow cortical potentials in epilepsy: a retrial with analysis of influencing factors. Epilepsy Res. Nov. 1996;25(3):269-76. [pmid: 8956926].
349 Uhlmann C, Froscher W. Biofeedback treatment in patients with refractory epilepsy: changes in depression and control orientation. Seizure. Jan. 2001;10(1):34-8. [pmid: 11181095].
350 Seidenberg M. Academic achievement and school performance of children with epilepsy. In: Hermann BP, Seidenberg M, editors. Childhood epilepsies: neuropsychological, psychosocial and intervention aspects. New York (NY): John Wiley & Sons, Ltd.; 1989. p. 105–18.
351 Sturniolo M G, Galletti F. Idiopathic epilepsy and school achievement. Arch Dis Child. May. 1994;70(5):424-8. [pmid: 8017966].
352 Bulteau C, Jambaque I, Viguier D, et al. Epileptic syndromes, cognitive assessment and school placement: a study of 251 children. Dev Med Child Neurol. May. 2000;42(5):319-27. [pmid: 10855652].
353 Wong I C, Mawer G E, Sander J W. Adverse event monitoring in lamotrigine patients: a pharmacoepidemiologic study in the United Kingdom. Epilepsia. Feb. 2001;42(2):237-44. [pmid: 11240596].
354 Klenerman P, Sander J W, Shorvon S D. Mortality in patients with epilepsy: a study of patients in long term residential care. J Neurol Neurosurg Psychiatry. Feb. 1993;56(2):149-52. [pmid: 8437003].
355 Leestma J E, Annegers J F, Brodie M J, et al. Sudden unexplained death in epilepsy: observations from a large clinical development program. Epilepsia. Jan. 1997;38(1):47-55. [pmid: 9024183].
356 Annegers J F, Coan S P, Hauser W A, et al. Epilepsy, vagal nerve stimulation by the NCP system, all-cause mortality, and sudden, unexpected, unexplained death. Epilepsia. May. 2000;41(5):549-53. [pmid: 10802760].
357 Racoosin J A, Feeney J, Burkhart G, et al. Mortality in antiepileptic drug development programs. Neurology. Feb. 2001;56(4):514-9. [pmid: 11222797].
358 Physician's desk reference 2001. 55th ed. Montvale (NJ): Medical Economics/Thomson Healthcare; 2001. 3506 p.
359 Leppik I E. Tiagabine: the safety landscape. Epilepsia. 1995;36(Suppl 6):S10-S13. [pmid: 8595787].
360 Sperling M R, Feldman H, Kinman J, et al. Seizure control and mortality in epilepsy. Ann Neurol. Jul. 1999;46(1):45-50. [pmid: 10401779].
361 Vickrey B. Mortality in a consecutive cohort of 248 adolescents and adults who underwent diagnostic evaluation for epilepsy surgery. Epilepsia. 1997;38(Suppl 11):S67-9. [pmid: 19909332].
362 Hennessy M J, Langan Y, Elwes R D, et al. A study of mortality after temporal lobe epilepsy surgery. Neurology. Oct. 1999;53(6):1276-83. [pmid: 10522885].
363 Wong I C, Chadwick D W, Fenwick P B, et al. The long-term use of gabapentin, lamotrigine, and vigabatrin in patients with chronic epilepsy. Epilepsia. 1999;40(10):1439-45. [pmid: 10528941].
364 Myers J E, Thompson M L. Meta-analysis and occupational epidemiology. Occup Med (Lond). Feb. 1998;48(2):99-101. [pmid: 9614768].
365 Lhatoo S D, Johnson A L, Goodridge D M, et al. Mortality in epilepsy in the first 11 to 14 years after diagnosis: multivariate analysis of a long-term, prospective, population-based cohort. Ann Neurol. Mar. 2001;49(3):336-44. [pmid: 11261508].
366 Shen W K, Edwards W D, Hammill S C, et al. Sudden unexpected nontraumatic death in 54 young adults: a 30-year population-based study. Am J Cardiol. Jul. 1995;76(3):148-52. [pmid: 7611149].
367 Escobedo L G, Zack M M. Comparison of sudden and nonsudden coronary deaths in the United States. Circulation. Jun. 1996;93(11):2033-6. [pmid: 8640979].
368 Ficker D M, So E L, Shen W K, et al. Population-based study of the incidence of sudden unexplained death in epilepsy. Neurology. Nov. 1998;51(5):1270-4. [pmid: 9818844].
369 Walczak T S, Leppik I E, D'Amelio M, et al. Incidence and risk factors in sudden unexpected death in epilepsy: a prospective cohort study. Neurology. Feb. 2001;56(4):519-25. [pmid: 11222798].
370 Annegers J F, Coan S P, Hauser W A, et al. Epilepsy, vagal nerve stimulation by the NCP system, mortality, and sudden, unexpected, unexplained death. Epilepsia. Feb. 1998;39(2):206-12. [pmid: 9578002].
371 Statistical abstract of the United States. Washington (DC): U.S. Census Bureau; 2000. Vital statistics. p. various. Also available: http://www.census.gov/prod/www/statistical-abstract.html.
372 Mortality statistics: general. Review of the Registrar General on deaths in England and Wales, 1999. London (UK): The Stationery Office; 2001. : Death rates for 1,000,000 population: age-group and sex, infant mortality rates and standardized mortality ratios for selected underlying causes, 1999. (Series DH1; no. 32).p. 12–37. Table 7
373 Office for National Statistics, General Register Office for Scotland, Northern Ireland Statistics and Research Agency. 7.3 Age-standardised mortality rates: by cause, gender and NHS regional office area 1999. [internet]. United Kingdom: National Health Service; 1999 [cited 2001 Oct 11]. [1 p]. Available: http://www.statistics.gov.uk/statbase/.
374 Nilsson L, Farahmand B Y, Persson P G, et al. Risk factors for sudden unexpected death in epilepsy: a case-control study. Lancet. Mar. 1999;353(9156):888-93. [pmid: 10093982].
375 Timmings P L. Sudden unexpected death in epilepsy: a local audit. Seizure. Dec. 1993;2(4):287-90. [pmid: 8162397].
376 Nashef L, Fish D R, Sander J W, et al. Incidence of sudden unexpected death in an adult outpatient cohort with epilepsy at a tertiary referral centre. J Neurol Neurosurg Psychiatry. Apr. 1995;58(4):462-4. [pmid: 7738555].
377 McKee J R, Bodfish J W. Sudden unexpected death in epilepsy in adults with mental retardation. Am J Ment Retard. Jul. 2000;105(4):229-35. [pmid: 10934565].
378 Jick S S, Cole T B, Mesher R A, et al. Sudden unexplained death in young persons with primary epilepsy. Pharmacoepidemiol Drug Safe. 1992;1:59-64.
379 Birnbach C D, Wilensky A J, Dodrill C B. Predictors of early mortality and sudden death in epilepsy: a multidisciplinary approach. J Epilepsy. 1991;4(1):11-7.
380 Kloster R, Engelskjon T. Sudden unexpected death in epilepsy (SUDEP): a clinical perspective and a search for risk factors. J Neurol Neurosurg Psychiatry. Oct. 1999;67(4):439-44. [pmid: 10486388].
381 Wieser H G, Blume W T, Fish D, et al. ILAE Commission Report. Proposal for a new classification of outcome with respect to epileptic seizures following epilepsy surgery. Epilepsia. Feb. 2001;42(2):282-6. [pmid: 11240604].
382 Phelps C E, Hutson A. Estimating diagnostic test accuracy using a ‘fuzzy gold standard’. Med Decis Making. 1995;15(1):44-57. [pmid: 7898298].
383 Weller S C, Mann N C. Assessing rater performance without a ‘Gold Standard’ using consensus theory. Med Decis Making. 1997;17(1):71-9. [pmid: 8994153].
384 Giesler R B, Ashton C M, Brody B, et al. Assessing the performance of utility techniques in the absence of a gold standard. Med Care. Jun. 1999;37(6):580-8. [pmid: 10386570].
385 Hanna NJ, Black M, Sander JW, et al. The national sentinal clinical audit of epilepsy-related death: epilepsy--death in the shadows. The Stationary Office; 2002 May. 134 p.
386 Mosquera D A, Goldman M D. Surgical audit without autopsy: tales of the unexpected. Ann R Coll Surg Engl. Mar. 1993;75(2):115-7. [pmid: 8476178].
387 Kelsey JL, Whittemore AS, Evans AS, et al. Methods in observational epidemiology. 2nd ed. New York (NY): Oxford University Press; 1996. 432 p. (Monographs in epidemiology and biostatistics; vol. 26).
388 Schulz K F, Grimes D A. Case-control studies: research in reverse. Lancet. Feb. 2002;359(9304):431-34. [pmid: 11844534].
389 Tennis P, Cole T B, Annegers J F, et al. Cohort study of incidence of sudden unexplained death in persons with seizure disorder treated with antiepileptic drugs in Saskatchewan, Canada. Epilepsia. Jan. 1995;36(1):29-36. [pmid: 8001505].
390 Browne T R, Holmes G L. Primary care: epilepsy. N Engl J Med. Apr. 2001;344(15):1145-51. [pmid: 11297707].
391 Makuch R, Simon R. Sample size requirements for evaluating a conservative therapy. Cancer Treat Rep. Jul. 1978;62(7):1037-40. [pmid: 688245].