# Appendix A. Search Strategies

We employed different searches for different sections of the report, including different searches for different questions. The strategies for these different searches, given in PubMed/Medline syntax, are provided below.

Searches for general information on treatment-resistant epilepsy

S1 | epilepsy OR “convulsive disorder” OR “convulsive disorders” OR “seizure disorder” OR “seizure disorders”
S2 | (seizure*[ti] OR epilepsy[ti] OR epileptic[ti]) AND (premedline[sb] OR publisher[sb])
S3 | #1 OR #2
S4 | #3 AND english[la] AND (human[mh] OR premedline[sb] OR publisher[sb])
S5 | #4 AND (intract* OR “treatment-resistant” OR “treatment resistant” OR “drug-resistant” OR “drug resistant” OR “therapy-resistant” OR “therapy resistant” OR uncontrol* OR persistent OR refractory OR fail* OR continu* OR repeated* OR multiple OR “pseudo-intractability”)

Searches for Question #1 (What are the definitions of treatment-resistant epilepsy in the literature?)

S1 | epilepsy AND (intract* OR “treatment-resistant” OR “treatment resistant” OR “drug-resistant” OR “drug resistant” OR “therapy-resistant” OR “therapy resistant” OR uncontrol* OR persistent OR refractory OR fail* OR continu* OR repeated* OR multiple OR “pseudo-intractability”)
S2 | #1 AND review[pt] AND english[la] AND (human[mh] OR premedline[sb] OR publisher[sb]) AND 1985:2001[dp]
S3 | #2 NOT (letter[pt] OR editorial[pt] OR news[pt] OR comment[pt] OR case report[mh])

Searches for Question #2 (Which methods of rediagnosing or re-evaluating treatment-resistant epilepsy lead to, or can be expected to lead to improved patient outcomes?)

To answer this question, we searched for information on diagnosis and misdiagnosis, and we separately present the search strategies below.

Searches on Diagnosis:

S1 | epilepsy/di[mh] OR seizures/di[mh] OR convulsions/di[mh]
S2 | (epilepsy OR seizure* OR convulsion OR fit OR fits) AND (diagnosis OR diagnose* OR diagnostic OR identif* OR classif* OR detect*) AND (premedline[sb] OR publisher[sb])
S3 | (#1 OR #2) AND english[la] AND 1985:2001[dp]
S4 | #3 AND (“gold standard” OR “ROC” OR “receiver operating characteristic” OR sensitivity OR specificity OR sensitivity and specificity[mh] OR likelihood OR “false positive” OR “false negative” OR “true positive” OR “true negative” OR “predictive value” OR accuracy OR precision)
S5 | #3 AND (clinical trials[mh] OR clinical trial[pt] OR controls[ab] OR randomized controlled trials[mh] OR random allocation[mh] OR randomized controlled trial[pt] OR double-blind method[mh] OR single-blind method[mh] OR “single blind” OR “double blind” OR “single-dummy” OR “double-dummy” OR sham OR controlled clinical trials[mh] OR controlled clinical trial [pt] OR multicenter study[pt] OR meta-analysis OR meta-analysis[pt] OR placebo* OR outcomes research[mh] OR prospective studies[mh])
S6 | #4 OR #5
S7 | #3 AND (“EEG” OR “VEEG” OR electroencephalogra* OR ct[tiab] OR tomography, x-ray computed[mh] OR “cat scan”[tiab] OR “SPECT” OR magnetic resonance imaging OR “MRI” OR “MR” OR tomography, emission-computed[mh] OR “PET”[tiab] OR “positron emission tomography”)
S8 | #7 AND (intract* OR “treatment-resistant” OR “treatment resistant” OR “drug-resistant” OR “drug resistant” OR “therapy-resistant” OR “therapy resistant” OR uncontrol* OR persistent OR refractory OR fail* OR continu* OR repeated* OR multiple OR “pseudo-intractability”)
S9 | #1 AND (enzymes/blood[mh] OR hormones/blood[mh]) AND 1980:2001[dp] AND english[la] AND human[mh]
S10 | epilep* AND (prolactin OR creatine kinase OR enolase) AND english[la] AND (premedline[sb] OR publisher[sb])
S11 | #6 OR #8 OR #9 OR #10
S12 | #11 NOT (letter[pt] OR news[pt] OR comment[pt] OR editorial[pt] OR case report[mh])

Searches on Misdiagnosis:

S1 | epilepsy AND (reevaluat* OR “re-evaluate” OR “re-evaluation” OR “re-evalauted” OR “re-evaluating” OR reassess* OR “re-assess” OR “re-assessment” OR “re-assessed” OR “re-assessing” OR rediagnos* OR “re-diagnosis” OR “re-diagnose” OR “re-diagnosed” OR “re-diagnosing” OR misdiagnos* OR diagnostic errors[mh])
S2 | epilepsy AND (syncope OR asystole OR bradyarrthymia OR anoxic OR cardiogenic OR neurocardiogenic OR psychogenic OR hypoxia OR syncopal)
S3 | epilepsy AND (error* OR mistake*)
S4 | #1 OR #2 OR #3
S5 | #4 AND (di[sh] OR diagnosis[mh] OR du[sh])
S6 | #5 AND epilepsy[majr]
S7 | #4 AND (premedline[sb] OR publisher[sb])
S8 | (#6 OR #7) AND english[la] AND 1985:2001[dp]
S9 | #8 NOT (letter[pt] OR editorial[pt] OR news[pt] OR comment[pt] OR case report[mh])

Searches for Questions #3 (Which drug treatment strategy, (A) sequential monotherapy, (B) polytherapy, or (C) optimized current therapy leads to improved outcomes for patients with treatment-resistant epilepsy, and (D) What are the relative improvements obtained with each strategy?)

These searches included searches for “overall” information, searches on the natural history of epilepsy, and searches for articles on seizure frequency patterns. Below, we separately present information on each of these searches.

Searches for “overall” information:

S1 | epilepsy OR “convulsive disorder” OR “convulsive disorders” OR “seizure disorder” OR “seizure disorders”
S2 | (seizure*[ti] OR epilepsy[ti] OR epileptic[ti]) AND (premedline[sb] OR publisher[sb])
S3 | (#1 OR #2) AND 1975:2001[dp] AND english[la]
S4 | #3 AND drug therapy[sh] AND (“add-on” OR “sequential monotherapy” OR adjunct* OR drug therapy, combination[mh] OR “consecutive monotherapy” OR polytherapy)
S5 | #3 AND (anticonvulsants OR acetozolamide OR “apo-acetaxolamide” OR diamox OR “adrenocorticotropic hormone” OR “ACTH” OR corticotropin OR cortitrophin OR allopurinol OR zyloprim OR antiepilepsirine OR “BR 16A” OR mentat OR carbamazepine OR tegretol OR “apo-carbamazepine” OR epitol or mazepine or novocarbamaz or sinemet or carnitine or carnitor or levocarnitine or frisium or clonazepam or klonopin or clonopam or rivotril or clorazepate or tranxene or clozapine or clorzaril OR dexamethasone or cortastat or dalalone or decadrol or decadron or decaject or dexacorten or dexasone or dexone or hexadrol or mymethasone or primethasone or solurex or dextromethorphan or benylin or “crough x” or “creo-terpin” OR “delsym cough” or “diabe TUSS dm” or “hold dm” or “pertussin dm” OR robitussin or sucrets or trocal or “Vicks 44” or diazepam or valium or dichlorphenamide or diclofenamide or daranide or ethosuximide or zarontin or felbamate or felbatol or fenfluramine or flumazenil or romazicon or funarizine OR cinnarizine or sibelium or fosphenytoin or cerebyx or gabapentin or neurontin or imipramine or tofranil or lamotrigine or lamictal or keppra or lorazepam or ativan or methsuximide or celontin OR nifedipine or adalat or procradia or nimodipine or nimotop or oxcarbazepine or trileptal or Phenobarbital or luminal or phenytoin or dilantin or piracetam or primidone or remacemide or ecovia OR “Thyrotropin releasing hormone” or trh or tiagabine or topiramate or trimethadione or tridione or tmo or trimethinum or troxidone or “valproic acid” or depakene or depakote or epival or zonisamide or zonegran)
S6 | #5 AND (intract* OR “treatment-resistant” OR “treatment resistant” OR “drug-resistant” OR “drug resistant” OR “therapy-resistant” OR “therapy resistant” OR uncontrol* OR persistent OR refractory OR fail* OR continu* OR repeated* OR multiple OR “pseudo-intractability”)
S7 | #5 AND (blood[sh] OR optimiz* OR dosage OR dose* OR dosing OR titrat* OR “maximum tolerable” OR “blood level monitoring” OR “drug tolerance”)
S8 | #4 OR #5
S9 | #8 AND (“polytherapy reduction” OR withdrawal OR remove OR removal)
S10 | #4 OR #6 OR #7 OR #9
S11 | #10 AND (clinical trials[mh] OR clinical trial[pt] OR controls[ab] OR randomized controlled trials[mh] OR random allocation[mh] OR randomized controlled trial[pt] OR double-blind method[mh] OR single-blind method[mh] OR “single blind” OR “double blind” OR “single-dummy” OR “double-dummy” OR sham OR controlled clinical trials[mh] OR controlled clinical trial[pt] OR multicenter study[pt] OR meta-analysis OR meta-analysis[pt] OR placebo* OR outcomes research[mh] OR prospective studies[mh] OR evidence-based medicine[mh])
S12 | #11 NOT (letter[pt] OR editorial[pt] OR news[pt] OR comment[pt] OR case report[mh])

Searches on the natural history of epilepsy:

S1 | epilepsy[majr] OR epilep*[ti]
S2 | #1 AND (“natural history” OR developing countries[mh] OR untreated[tw] OR “natural progression” OR “clinical progression” OR “disease progression” OR “neurological course” OR “clinical course” OR time factors[mh] OR remission
OR remission, spontaneous[mh] OR transient[ti])
S3 | #2 AND english[la] AND 1985:2001[dp] AND (human[mh] OR premedline[sb] OR publisher[sb])
S4 | #3 NOT (letter[pt] OR news[pt] OR comment[pt] OR editorial[pt] OR case report[mh])

Searches on seizure frequency patterns:

S1 | seizure* AND (frequency OR occurrence) AND (increase* OR decrease* OR chang* OR variation*)
S2 | #1 AND (regression* OR sn[sh] OR statistic*)
S3 | #1 AND “seizure frequency”[ti]
S4 | “seizure frequency scoring system”
S5 | #1 AND (circadian OR pattern* OR season*)
S6 | #2 OR #3 OR #4 OR #5

Searches for Question #5 (Which methods of nondrug treatment for epilepsy after initial treatment failure lead to improved outcomes for patients with treatment-resistant epilepsy?)

S1 | epilepsy[mh] AND human[mh]
S2 | (epilep* OR seizure[ti]) AND (premedline[sb] OR publisher[sb])
S3 | #1 OR #2
S4 | #3 AND (alternative medicine[mh] OR acupuncture OR anthroposophy OR aromatherapy OR biofeedback OR chiropract* OR “color therapy” OR eclecticism OR homeopath* OR imagery OR kinesiology OR massage OR acupressure OR (medicine AND traditional) OR herbal OR “mental healing” OR “mind-body relations” OR metaphysics OR moxibustion OR naturopath* OR organother* OR radiesthesia OR reflexother* OR rejuvenation OR relaxation OR meditation OR “therapeutic touch”)
S5 | #3 AND ((vagal OR vagus nerve[mh] OR thalamic OR subcortical OR “deep brain”) AND (electric stimulation[mh] OR electric stimulation therapy[mh] OR (electric* AND stimulation))
S6 | #3 AND (diet therapy[sh] OR ketogenic OR vitamins/tu[mh] OR vitamin*)
S7 | #3 AND (hyperbaric oxygenation[mh] OR hyperbaric OR “HBO” OR “cranial realignment” OR “magnetic therapy”)
S8 | #3 AND (surgery OR surgical OR surgery[sh] OR resect* OR hemispherectomy OR hemispherotomy OR “temporal lobe resection” OR “temporal lobectomy” OR “neocortical resection” OR “corpus callosotomy” OR “MST” OR “multiple subfield transections”)
S9 | #4 OR #5 OR #6 OR #7 OR #8
S10 | #9 AND 1985:2001[dp] AND english[la]
S11 | #10 NOT (letter[pt] OR news[pt] OR comment[pt] OR editorial[pt] OR case report[mh])

Searches for Questions #6 (Which services for treatment-resistant epilepsy lead to, or can be expected to lead to improved patient outcomes?) and Question #7 (What characteristics of treatment-resistant epilepsy interfere with ability to obtain and maintain employment, or attend and perform well in school?)

S1 | epilepsy
S2 | #1 AND (psychology[sh] OR psychotherapy OR psychotherapeutic OR counseling OR cognitive therapy OR behavior therapy OR behavior modification OR group therapy OR family therapy OR psychoanaly* OR hypnosis OR “self-help” OR art therapy OR music therapy OR movement therapy)
S3 | #1 AND (rehabilitation[sh] OR rehabilit* OR hospice OR home care OR educational counseling OR vocational counseling OR occupational therapy OR physical therapy OR speech language therapy OR community health services OR “nurse specialist service” OR self care)
S4 | #1 AND (education OR patient education OR (nurs* AND special))
S5 | #1 AND (psychosocial OR neuropsychosocial OR social skill* OR social adapt* OR social work OR coping skill* OR stress management)
S6 | #1 AND (neuropsychological tests[mh] OR (neuropsychological AND (test* OR assess* OR evaluat*)))
S7 | #1 AND (education OR remedial education OR special education OR ability grouping OR (academic AND (achievement OR aptitude)) OR educational placement OR mainstream* OR ((school OR classroom) AND (adjustment OR attendance OR dropout* OR readiness OR transition)) OR (student AND (attitudes OR characteristics)) OR study habits OR teacher student interaction)
S8 | #1 AND (occupations OR (occupational AND (adjustment OR aspirations OR attitudes OR choice OR guidance OR interests OR mobility OR preference OR safety OR status OR stress OR success)))
S9 | #1 AND (employment status OR unemployment OR employability OR employment history OR reemployment OR employ* OR unemploy* OR “quality of work life” OR “work adjustment training” OR work schedule tolerance[mh] OR job*)
S10 | #1 AND (cognition OR (cognitive AND (ability OR assessment OR processes OR development OR rehabilitation))
S11 | #1 AND (intelligence OR IQ)
S12 | #1 AND (Quality of life[mh] OR QOL OR “life satisfaction” OR activities of daily living[mh] OR “activities of daily living” OR “ADL” OR “HRQOL” OR “HQOL”)
S13 | #1 AND (driving OR drive OR accidents[mh])
S14 | #1 AND (disable* OR disabil* OR handicap* OR psychomotor performance[mh] OR task performance and analysis[mh] OR “functional status” OR “functional ability”)
S15 | #2 OR #3 OR #4 OR #5 OR #6 OR #7 OR #8 OR #9 OR #10 OR #11 OR #12 OR #13 OR #14
S16 | #15 AND english[la] AND 1985:2001[dp]
S17 | #16 NOT (letter[pt] OR news[pt] OR comment[pt] OR editorial[pt] OR case report[mh])

Searches for Questions #8 (What is the mortality rate of patients with treatment-resistant epilepsy?) and Question #9 (Is there a correlation between the number and/or type of seizure and sudden death?):

S1 | epilepsy/epidemiology[majr]
S2 | epilepsy/mortality[majr]
S3 | (epilepsy OR “convulsive disorder” OR “convulsive disorders” OR “seizure disorder” OR “seizure disorders”) AND (epidemiology OR mortality OR “sudden death” OR sudden death[mh] OR “SUDEP”) AND (premedline[sb] OR publisher[sb])
S4 | epilepsy[majr] AND (sudden death[mh] OR “sudden death” OR “SUDEP”)
S5 | epilepsy AND accidents[mh] AND human[mh]
S6 | #1 OR #2 OR #3 OR #4 OR #5
S7 | #6 AND 1985:2001[dp]
S8 | #7 NOT (letter[pt] OR editorial[pt] OR news[pt] OR comment[pt] OR case report[mh])