# Acronyms

AEA | Adverse events analysis
AHRQ | Agency for Healthcare Research and Quality
ARMS | Adverse Reaction Monitoring System
BMI | Body Mass Index
CCT | Controlled clinical trial
CI | Confidence interval
CPK isozymes | Creatine phosphokinase isoenzyme
CPR | Cardio-plumonary resuscitation
CT scan | Computerized tomography scan
CVA | Cerebral vascular accident
CVD | Cardiovascular diseases
DF | Dexfenfluramine
DSHEA | Dietary Supplement Health and Education Act
EPC | Evidence-based Practice Center
FDA | US Food and Drug Administration
GAO | General Accounting Office
HHS | US Department of Health and Human Services
IOC | International Olympic Committee
Kg | kilograms
MB fractions | Myocardial band fractions (of CPK isoenzymes)
MI | Myocardial infarction
mg | milligrams
MRI | Magnetic resonance imagery
NCAA | National Collegiate Athletic Association
NHANES | National Health and Nutrition Examination Survey
NIH | National Institutes of Health
ODS | Office of Dietary Supplements
OTC | Over-the-counter
PDF | Portable document format
QRF | Quality review form
RCT | Randomized controlled trial
TEP | Technical Expert Panel
VCO_2_ | Volume of carbon dioxide production
VO_2_ | Volume of oxygen consumption