# Evidence Tables

Evidence Table 1. RCTs and CCTs reporting on Athletic Performance Enhancement with Ephedra

First Author Year | Design | | Arm# | Intervention | Sample Size | | Summary of Results
| Study Quality | | | Total Daily Dose
| Population (>75%) | | | Route of Administration
| Comorbidities | | | Duration
Bell DG & Jacobs I 1999 #24 | CCT | | 1 | Placebo | n Entered: | 9 | VO_2_ maximum during the treadmill runs, VO_2_ at standard running velocities, and the relationship between the heart rate and the VO_2_ were similar in both the Caffeine and Ephedrine (C+E, Arm 2) and the Placebo (Arm 1) groups. Run times of the performance test for subjects in the C+E group (Arm 2) was significantly faster (p < 0.05) than for subjects in the Placebo group (Arm 1).
| Jadad Score: | 1 | | Placebo for 2 days | n Analyzed: | 9
| Population: | Male athletes | 2 | Ephedrine | n Entered: | 9
| Comorbidities: | N/A | | 75 mg orally for 2 days | n Analyzed: | 9
| | | | Caffeine
| | | | 375 mg orally for 2 days
Bell DG, Jacobs I, et al. 2000 #25 | CCT | | 1 | Control | n Entered: | 10 | Individuals in the Caffeine and Ephedrine (C+E) group (Arm 3) experienced a significant VO_2_ increase of 7.5% compared to individuals in the Placebo group (Arm 2), but similar to individuals in the Control group (Arm 1). Tolerance times were similar for the C+E (Arm 3, 121.3 +/- 33.9 minutes) and Placebo (Arm 2, 120.0 +/- 28.4) groups, but significantly longer than the Control group (Arm 1, 106.6 +/- 24.0).
| Jadad Score: | 1 | | No dosage data reported | n Analyzed: | 10
| Population: | Male | 2 | Placebo | n Entered: | 10
| Comorbidities: | N/A | | Placebo for 1 day | n Analyzed: | 10
| | | 3 | Ephedrine | n Entered: | 10
| | | | 1 mg·kg-1 orally for 1 day | n Analyzed: | 10
| | | | Caffeine
| | | | 5 mg·kg-1 orally for 1 day
Bell DG, Jacobs I, et al. 2000 #26 | CCT | | 1 | Placebo | n Entered: | 12 | VO_2_ maximum was similar among all groups. Endurance ride times to exhaustion for all Caffeine and Ephedrine groups with different dosages (Arm 2, 27.5 +/- 12.4 minutes; Arm 3, 27.6 +/-10.9; and Arm 4, 28.2 +/- 9.3) were similar, and significantly greater than Placebo (Arm 1, 17.0 +/- 3.0) with an approximated 64% improvement.
| Jadad Score: | 3 | | Placebo for 1 day | n Analyzed: | 12
| Population: | Male | 2 | Ephedrine | n Entered: | 12
| Comorbidities: | N/A | | 0.8 mg·kg-1 orally for 1 day | n Analyzed: | 12
| | | | Caffeine
| | | | 5 mg·kg-1 orally for 1 day
| | | 3 | Caffeine | n Entered: | 12
| | | | 1 mg·kg-1 orally for 1 day | n Analyzed: | 12
| | | | Caffeine
| | | | 4 mg·kg-1 orally for 1 day
| | | 4 | Ephedrine | n Entered: | N/A
| | | | 0.8 mg·kg-1 orally for 1 day | n Analyzed: | N/A
| | | | Caffeine
| | | | 4 mg·kg-1 orally for 1 day
Bell DG, Jacobs I, et al. 1998 #27 | CCT | | 1 | Placebo | n Entered: | 12 | VO_2_ maximum increased progressively during exercise in all trials (Arms 1, 2, 3, and 4, p < 0.05), but no significant difference was found among them. Time to exhaustion was significantly longer for the Caffeine and Ephedrine trial ((Arm 2) when compared to Placebo (Arm1) and Caffeine (Arm 3) trials (p < 0.05).
| Jadad Score: | 4 | | Placebo for 1 day | n Analyzed: | 8
| Population: | Male | 2 | Ephedrine | n Entered: | 12
| Comorbidities: | N/A | | 1 mg·kg-1 orally for 1 day | n Analyzed: | 8
| | | | Caffeine
| | | | 1 mg·kg-1 orally for 1 day
| | | 3 | Caffeine | n Entered: | 12
| | | | 5 mg·kg-1 orally for 1 day | n Analyzed: | 8
| | | 4 | Ephedrine | n Entered: | 12
| | | | 1 mg·kg-1 orally for 1 day | n Analyzed: | 8
Bell DG, Jacobs I, et al. 2001 #512 | CCT | | 1 | Placebo | n Entered: | 24 | Accumulated VO_2_ was similar between all groups. The Ephedrine (Arm 3) and Caffeine plus Ephedrine (Arm 4) treatments increased power output significantly (p < 0.05) early in the Wingate test compared to the Placebo (Arm 1) and Caffeine (Arm 2) treatments. Caffeine-containing treatments (Arms 2 and 4) significantly improved times to exhaustion by 8% compared to non-caffeine treatments (Arms 1 and 3).
| Jadad Score: | 1 | | Placebo for 1 day | n Analyzed: | 24
| Population: | Military | 2 | Caffeine | n Entered: | 24
| Comorbidities: | N/A | | 5 mg·kg-1 orally for 1 day | n Analyzed: | 24
| | | 3 | Ephedrine | n Entered: | 24
| | | | 1 mg·kg-1 orally for 1 day | n Analyzed: | 24
| | | 4 | Ephedrine | n Entered: | 24
| | | | 1 mg·kg-1 orally for 1 day | n Analyzed: | 24
| | | | Caffeine
| | | | 1 mg·kg-1 orally for 1 day
Oksbjerg N, Meyer T, et al. 1986 #214 | CCT | | 1 | Ephedrine | n Entered: | 6 | A thermogenic effect of 4.3 +/- 1.3 watt was established for the Ephedrine group (Arm 1), the effect in the Placebo group (Arm 2) was only 1.6 +/- 1.6. The thermogenic effect in the Ephedrine group (Arm 1) increased by 100% ( p < 0.05) following aerobic training. Overall, aerobic training increased VO_2_ maximum by 7 % ( p < 0.05).
| Jadad Score: | 1 | | 40 mg orally for 1 day | n Analyzed: | 6
| Population: | Male | 2 | Placebo | n Entered: | 6
| Comorbidities: | N/A | | No dosage data reported | n Analyzed: | 6
Pasternak 1999 #511 | CCT | | 1 | Placebo | n Entered: | 13 | For muscular endurance outcomes, mean number of leg and bench press repetitions only in the first set increased significantly (p < 0.05) for individuals in the Caffeine and Ephedrine ( Arm 4) and the Ephedrine (Arm 3) groups compared to the Caffeine (Arm 2) and Placebo (Arm 1) groups. The mean number for all 3 sets of leg and bench repetitions was similar among all groups.
| Jadad Score: | 1 | | Placebo for 1 day | n Analyzed: | 13
| Population: | Male athletes | 2 | Caffeine | n Entered: | 13
| Comorbidities: | N/A | | 4 mg·kg-1 orally for 1 day | n Analyzed: | 13
| | | 3 | Ephedrine | n Entered: | 13
| | | | 0.8 mg·kg-1 orally for 1 day | n Analyzed: | 13
| | | 4 | Caffeine | n Entered: | 13
| | | | 4 mg·kg-1 orally for 1 day | n Analyzed: | 13
| | | | Ephedrine
| | | | 0.8 mg·kg-1 orally for 1 day
Sidney KH & Lefcoe NM 1977 #247 | CCT | | 1 | Placebo | n Entered: | 21 | No significant difference was seen between the Placebo (Arm 1) and Ephedrine (Arm 2) groups for any variable including VO_2_ maximum, and endurance.
| Jadad Score: | 2 | | Placebo for 1 day | n Analyzed: | 21
| Population: | Male | 2 | Ephedrine | n Entered: | 21
| Comorbidities: | N/A | | 24 mg orally for 1 day | n Analyzed: | 21

N/A = not available or not applicable

Evidence Table 2. RCTs and CCTs reporting on Weight Loss

First Author Year | Design | | Arm # | Intervention | Sample Size | | Meta-analysis Data* Or Summary of Results
| Study Quality | | | Total Daily Dose
| Population (>75%) | | | Route of Administration
| Cormorbidities | | | Duration
Astrup A, Buemann B, et al. 1992 #9 | CCT | | 1 | Placebo | n Entered: | 8 | Average weight loss at 2 months in kg:
| Jadad Score: | 2 | | Placebo for 8 weeks | n Analyzed: | 6 | Arm 1 = 8.4 (2.9)
| Population: | Female | 2 | Ephedrine | n Entered: | 8 | Arm 2 = 10.1 (1.0)
| Comorbidities: | Obesity | | 60 mg orally for 8 weeks | n Analyzed: | 6
| | | | Caffeine
| | | | 600 mg orally for 8 weeks
Belfie L, Petrie H, et al. 2001 #317 | CCT | | 1 | Placebo | n Entered: | N/A | Excluded from meta-analysis due to Insufficient statistics. At follow up, decreases were seen only in the Ma Huang Supplement group (Arm 2) for mass (106.0 +/-11.5 to 96.9 +/- 12.1 kg), fat mass (31.3 +/- 5.3 to 25.8 +/- 5.8 kg, p < 0.05), and percent body fat (29.4 +/- 3.1 to 26.4 +/- 3.0 %, p < 0.05).
| Jadad Score: | 1 | | Placebo for 12 weeks | n Analyzed: | 10
| Population: | N/A | 2 | Ephedrine from Ma Huang | n Entered: | N/A
| Comorbidities: | Obesity | | 60 mg orally for 12 weeks | n Analyzed: | 11
| | | | Caffeine from Guarana
| | | | 600 mg orally for 12 weeks
Boozer CN, Daly PA, et al. 2000 #34 | RCT | | 1 | Placebo | n Entered: | 84 | Average weight loss at 6 months in kg:
| Jadad Score: | 5 | | Placebo for 24 weeks | n Analyzed: | 38 | Arm 1 = 2.6 (3.2)
| Population: | Female | 2 | Ephedrine from Ma Huang | n Entered: | 83 | Arm 2 = 5.3 (5.0)
| Comorbidities: | Obesity | | 86.4 mg orally for 24 weeks | n Analyzed: | 45
| | | | Caffeine from Kola nut
| | | | 196 mg orally for 24 weeks
Boozer CN, Nasser JA, et al. 2001 #333 | RCT | | 1 | Placebo | n Entered: | 32 | Average weight loss at 2 months in kg:
| Jadad Score: | 5 | | Placebo for 8 weeks | n Analyzed: | 24 | Arm 1 = 0.8 (2.4)
| Population: | Female | 2 | Ephedrine from Ma Huang | n Entered: | 35 | Arm 2 = 4.0 (3.4)
| Comorbidities: | Obesity | | 77.4 mg orally for 8 weeks | n Analyzed: | 24
| | | | Caffeine from Guarana
| | | | 300 mg orally for 8 weeks
Breum L, Pedersen JK, et al. 1994 #41 | RCT | | 1 | Dexfenfluramine | n Entered: | 53 | Average weight loss at 3.75 months in kg:
| Jadad Score: | 4 | | 30 mg orally for 15 weeks | n Analyzed: | 43 | Arm 1 = 6.9 (4.3)
| Population: | Female | 2 | Ephedrine | n Entered: | 50 | Arm 2 = 8.3 (5.2)
| Comorbidities: | Obesity | | 60 mg orally for 15 weeks | n Analyzed: | 38
| | | | Caffeine
| | | | 600 mg orally for 15 weeks
Buemann B, Marckmann P, et al. 1994 #45 | RCT | | 1 | Placebo | n Entered: | N/A | Average weight loss at 2 months in kg:
| Jadad Score: | 3 | | Placebo for 8 weeks | n Analyzed: | 16 | Arm 1 = 7.1 (2.4)
| Population: | Female | 2 | Ephedrine | n Entered: | N/A | Arm 2 = 8.4 (2.4)
| Comorbidities: | Obesity | | 60 mg orally for 8 weeks | n Analyzed: | 16
| | | | Caffeine
| | | | 600 mg orally for 8 weeks
Colker, Swain, et al. 2001 #548 | RCT | | 1 | Placebo | n Entered: | 12 | Average weight loss at 2 months in kg:
| Jadad Score: | 2 | | Placebo for 8 weeks | n Analyzed: | 12 | Arm 1 = 0.49 (2.35)
| Population: | Female | 2 | Ephedrine from Ma Huang | n Entered: | 14 | Arm 2 = 2.56 (2.35)
| Comorbidities: | Obesity | | Taken orally for 8 weeks | n Analyzed: | 14
| | | | Coleus forksohlli
| | | | Taken orally for 8 weeks
Colker, Torina, et al. 1999 #549 | RCT | | 1 | Placebo | n Entered: | 8 | Excluded from meta-analysis because of insufficient statistics: study reports weight loss for one group only. The Ephedra, Caffeine, Aspirin, and Exercise (E+C+A+E) group (Arm 3) had a significant reduction in body weight (-3.8 kg, p<0.01) compared to the Ephedra, Caffeine, and Aspirin (E+C+A, Arm 2) and Placebo groups (Arm 1). The E+C+A (Arm 2) group experienced a significant reduction in caloric intake (-680.2 kcal, p<0.05) compared to the other groups.
| Jadad Score: | 1 | | Placebo for 8 Weeks | n Analyzed: | 8
| Population: | N/A | 2 | Ephedrine from Ma Huang | n Entered: | 8
| Comorbidities: | Obesity | | 60 mg orally for 8 weeks | n Analyzed | 8
| | | | Caffeine from unspecified herb
| | | | 600 mg orally for 8 weeksirin
| | | | Aspirin
| | | | 45 mg orally for 8 weeks
Daly PA, Krieger DR, et al. 1993 #68 | RCT | | 1 | Placebo | n Entered: | 15 | Average weight loss at 2 months in kg:
| Jadad Score: | 2 | | Placebo for 8 weeks | n Analyzed: | 13 | Arm 1 = 0.7 (2.2)
| Population: | Female | 2 | Ephedrine | n Entered: | 14 | Arm 2 = 2.2 (2.3)
| Comorbidities: | Obesity | | 75 mg orally for 4 weeks | n Analyzed: | 11
| | | | Second round of previous intervention
| | | | 150 mg orally for 4 weeks
| | | | Caffeine
| | | | 150 mg orally for 8 weeks
| | | | Aspirin
| | | | 330 mg orally for 8 weeks
Donikyan LA 2002 #509 | RCT | | 1 | Placebo | n Entered: | 94 | Average weight loss at 3 months in kg:
| Jadad Score: | 4 | | Placebo for 12 weeks | n Analyzed: | 78 | Arm 1 = 3.0 (6.0)
| Population: | Male and female | 2 | Ephedrine from Ma Huang | n Entered: | 93 | Arm 2 = excluded
| Comorbidities: | Obesity | | 72 mg orally for 8 weeks | n Analyzed: | 75 | Arm 3 = 7.4 (6.8)
| | | | Chromium picolinate
| | | | 450 mcq orally for 8 weeks
| | | | Placebo
| | | | Placebo for 4 weeks
| | | 3 | Ephedrine from Ma Huang | n Entered: | 92
| | | | 72 mg orally for 12 weeks | n Analyzed: | 76
| | | | Chromium picolinate
| | | | 450 mcq orally for 12 weeks
Greenway F, deJonge L, et al. Unpublished #475 | RCT | | 1 | Placebo | n Entered: | 20 | Average weight loss at 3 months in kg:
| Jadad Score: | 2 | | Placebo for 12 weeks | n Analyzed: | 18 | Arm 1 = 0.8 (2.6)
| Population: | N/A | 2 | Ephedrine from Ma Huang | n Entered: | 20 | Arm 2 = 3.9 (4.0)
| Comorbidities: | Obesity | | 72 mg orally for 12 weeks | N Analyzed: | 12
| | | | Caffeine from unspecified herb
| | | | 210 mg orally for 12 week
| | | | Phenylalanine
| | | | 300 mg orally for 12 days
Jensen, Dano, et al. 1980 #536 | RCT | | 1 | Ephedrine | n Entered: | 23 | Average weight loss at 4 months in kg:
| Jadad Score: | 1 | | 100 mg orally for 16 weeks | n Analyzed: | 14 | Arm 1 = 9.4 (4.7)
| Population: | N/A | | Caffeine | | | Arm 2 = 7.9 (4.7)
| Comorbidities: | Obesity | | 275 mg orally for 16 weeks | | | Arm 3 = 0.5 (4.7)
| | | 2 | Ephedrine | n Entered: | 24
| | | | 100 mg orally for 16 weeks | n Analyzed: | 13
| | | 3 | Placebo | n Entered: | 17
| | | | No dosage data reported | n Analyzed: | 4
Kalman DS, Colker CM, et al. 2000 #140 | RCT | | 1 | Placebo | n Entered: | 14 | Average weight loss at 2 months in kg:
| Jadad Score: | 3 | | Placebo for 8 weeks | n Analyzed: | 13 | Arm 1 = 2.1 (2.4)
| Population: | Male | 2 | Ephedrine | n Entered: | 16 | Arm 2 = 3.1 (2.4)
| Comorbidities: | Obesity | | 40 mg orally for 8 weeks | n Analyzed: | 12
| | | | Synephrine
| | | | 10 mg orally for 8 weeks
| | | | Caffeine
| | | | 400 mg orally for 8 weeks
| | | | Aspirin
| | | | 30 mg orally for 8 weeks
Kalman, Colker, et al. 2000 #550 | RCT | | 1 | Placebo | n Entered: | 15 | Excluded from meta-analysis because of insufficient statistics: study only reports weight loss in percent. Subjects in the Ephedrine, Synephrine, Caffeine, and Aspirin (E+S+C+A) group (Arm 2) experienced a significant reduction in body weight (-9%, p≤0.05) as well as in percent of body fat (-16%, p>0.001) compared to the Placebo group (Arm 1, -3.8% and -1% respectively). An intragroup difference in fat free mass was seen in both groups: -0.92 kg (p<0.01) in the E+S+C+A group (Arm 2) and -3.47 kg (p<0.05) in the Placebo group (Arm 1).
| Jadad Score: | 3 | | Placebo for 8 weeks | n Analyzed: | 15
| Population: | N/A | 2 | Ma Huang/Ephedra | n Entered: | 15
| Comorbidities: | Obesity | | 20 mg orally for 8 weeks | n Analyzed: | 15
| | | | 28
| | | | 5 mg orally for 8 weeks
| | | | Caffeine from unspecified herb
| | | | 200 mg orally for 8 weeks
| | | | Aspirin
| | | | 15 mg orally for 8 weeks
Kettle R, Toubro S, et al. 1998 #510 | CCT | | 1 | Placebo | n Entered: | 45 | Average weight loss at 6 months in kg:
| Jadad Score: | 0 | | Placebo for 6 monthsv | n Analyzed: | 37 | Arm 1 = 12.8 (6.7)
| Population: | N/A | 2 | Ephedrine | n Entered: | 45 | Arm 2 = 15.6 (7.1)
| Cormorbidities: | Obesity | | 20 mg orally for 6 months | n Analyzed: | 40
| | | | Caffeine
| | | | 200 mg orally for 6 months
Lumholtz IB, Thorsteinsson B, et al. 1980 #173 | RCT | | 1 | Ephedrine | n Entered: | 63 | Average weight loss at 4.5 months in kg:
| Jadad Score: | 2 | | 120 mg orally for 18 weeks | n Analyzed: | 18 | Arm 1 = 9.5 (5.3)
| Population: | N/A | 2 | Placebo | n Entered: | 63 | Arm 2 = 4.0 (5.3)
| Comorbidities: | Obesity | | No dosage data reported | n Analyzed: | 14
Malchow-Moller A, Larsen S, et al. 1981 #177 | CCT | | 1 | Placebo | n Entered: | 33 | Average weight loss at 3 months in kg:
| Jadad Score: | 3 | | Placebo for 12 weeks | n Analyzed: | 31 | Arm 1 = 4.1 (3.5)
| Population: | N/A | 2 | Ephedrine | n Entered: | 49 | Arm 2 = 8.1 (3.5)
| Comorbidities: | Obesity | | 60 mg orally for 12 weeks | n Analyzed: | 38 | Arm 3 = 8.4 (3.5)
| | | | Caffeine
| | | | 150 mg orally for 12 weeks
| | | 3 | Diethylpropion | n Entered: | 50
| | | | 37.5 mg orally for 12 weeks | n Analyzed: | 39
Moheb MA, Geissler CA, et al. 1998 #193 | RCT | | 1 | Placebo | n Entered: | N/A | Average weight loss at 3 months in kg:
| Jadad Score: | 2 | | Placebo for 12 weeks | n Analyzed: | 32 | Arm 1 = 6.2 (3.5)
| Population: | Female | 2 | Ephedrine | n Entered: | N/A | Arm 2 = 7.9 (3.5)
| Comorbidities: | Obesity | | 150 mg orally for 12 weeks | n Analyzed: | 32 | Arm 3 = 9.6 (3.5)
| | | 3 | Ephedrine | n Entered: | N/A | Arm 4 = 8.8 (3.5)
| | | | 150 mg orally for 12 weeks | n Analyzed: | 32 | Arm 5 = 8.9 (3.5)
| | | | Aspirin
| | | | 330 mg orally for 12 weeks
| | | 4 | Ephedrine | n Entered: | N/A
| | | | 150 mg orally for 12 weeks | n Analyzed: | 32
| | | | Caffeine
| | | | 150 mg orally for 12 weeks
| | | 5 | Ephedrine | n Entered: | N/A
| | | | 150 mg orally for 12 weeks | n Analyzed: | 32
| | | | Caffeine
| | | | 150 mg orally for 12 weeks
| | | | Aspirin
| | | | 330 mg orally for 12 weeks
Molnar D, Torok K, et al. 2000 #195 | RCT | | 1 | Placebo | n Entered: | 16 | Average weight loss at 5 months in kg:
| Jadad Score: | 4 | | Placebo for 20 weeks | n Analyzed: | 13 | Arm 1 = 0.5 (4.3)
| Population: | Adolescents (12–17) | 2 | Ephedrine | n Entered: | 16 | Arm 2 = 7.9 (6.0)
| Comorbidities: | Obesity | | 10 mg orally for 1 weeks | n Analyzed: | 16
| | | | Second round of previous intervention
| | | | 30–60 mg orally for 19 weeks
| | | | Caffeine
| | | | 100 mg orally for 1 weeks
| | | | Second round of previous intervention
| | | | 300–600 mg orally for 19 weeks
Norregaard J, Jorgensen S, et al. 1996 #210 | RCT | | 1 | Placebo | n Entered: | 80 | Excluded from meta-analysis because there was no weight loss outcome, this study addressed weight gain. Subjects in the Ephedrine plus Caffeine group (Arm 2) gained significantly less weight during the first 12 weeks (Week 3 = p<0.001; Week 6 = p<0.01; Week 12 = p<0.05) than subjects in the Placebo group (Arm 1). Weight gain was similar for both groups after 1 year.
| Jadad Score: | 3 | | Placebo for 9 months | n Analyzed: | 73
| Population: | N/A | 2 | Ephedrine | n Entered: | 167
| Comorbidities: | Obesity, hypertension, pulmonary, AVD. | | 60 mg orally for 3 months | n Analyzed: | 152
| | | | Second round of previous intervention
| | | | 40 mg orally for 3 months
| | | | Third round of previous intervention
| | | | 20 mg orally for 3 months
| | | | Caffeine
| | | | 600 mg orally for 3 months
| | | | Second round of previous intervention
| | | | 400 mg orally for 3 months
| | | | Third round of previous intervention
| | | | 200 mg orally for 3 months
Pasquali R, Baraldi G, et al. 1985 #220 | RCT | | 1 | Placebo | n Entered: | 21 | Average weight loss at 3 months in kg:
| Jadad Score: | 3 | | Placebo for 3 months | n Analyzed: | 12 | Arm 1 = 8.7 (3.5)
| Population: | N/A | 2 | Ephedrine | n Entered: | 19 | Arm 2 = 8.7 (2.4)
| Comorbidities: | Obesity | | 75 mg orally for 3 months | n Analyzed: | 7 | Arm 3 = 10.2 (3.5)
| | | 3 | Ephedrine | n Entered: | 22
| | | | 150 mg orally for 3 months | n Analyzed: | 12
Pasquali R, Cesari MP, et al. 1987 #223 | RCT | | 1 | Placebo | n Entered: | 10 | Excluded from meta-analysis because crossover study design. Patients' weight loss was significantly (p<0.05) more during the Ephedrine treatment (Arm 2, 2.41 +/- 0.6 kg.) than during the Placebo treatment (Arm 1, 0.64 +/- 0.05 kg.).
| Jadad Score: | 2 | | Placebo for 2 months | n Analyzed: | 10
| Population: | Female | 2 | Ephedrine | n Entered: | 10
| Comorbidities: | Obesity | | 150 mg orally for 2 months | n Analyzed: | 10
Quaade F, Astrup A, et al. 1992 #230 | RCT | | 1 | Ephedrine | n Entered: | 45 | Average weight loss at 3 months in kg:
| Jadad Score: | 3 | | 60 mg orally for 24 weeks | n Analyzed: | 35 | Arm 1 = 11.7 (5.3)
| Population: | Male and female | | Caffeine | | | Arm 2 = 10.3 (4.0)
| Comorbidities: | Obesity | | 600 mg orally for 24 weeks | | | Arm 3 = 9.0 (3.6)
| | | 2 | Ephedrine | n Entered: | 45 | Arm 4 = 10.2 (5.7)
| | | | 60 mg orally for 24 weeks | n Analyzed: | 35 | Average weight loss at 6 months in kg:
| | | 3 | Caffeine | n Entered: | 45 | Arm 1 = 16.6 (6.8)
| | | | 600 mg orally for 24 weeks | n Analyzed: | 36 | Arm 2 = 14.3 (5.9)
| | | 4 | Placebo | n Entered: | 45 | Arm 3 = 11.5 (6.0)
| | | | No dosage data reported | n Analyzed: | 35 | Arm 4 = 13.2 (6.6)
Roed, Hansen, et al. 1980 #535 | RCT | | 1 | Ephedrine | n Entered: | 70 | Average weight loss at 3 months in kg:
| Jadad Score: | 3 | | 60 mg orally for 12 weeks | n Analyzed: | 49 | Arm 1 = excluded
| Population: | Male and female | | Caffeine | | | Arm 2 = 10.0 (3.5)
| Comorbidities: | Obesity | | 150 mg orally for 12 weeks | | | Arm 3 = 5.2 (3.5)
| | | | Phenobarbital
| | | | 60 mg orally for 12 weeks
| | | 2 | Ephedrine | n Entered: | 69
| | | | 60 mg orally for 12 weeks | n Analyzed: | 52
| | | | Caffeine
| | | | 150 mg orally for 12 weeks
| | | 3 | Placebo | n Entered: | 69
| | | | No dosage data reported | n Analyzed: | 42
Toubro S & Astrup A 1997 #261 | RCT | | 1 | Ephedrine | n Entered: | 21 | Excluded from meta-analysis due to study design: ephedrine dose did not vary between arms.
| Jadad Score: | 2 | | 60 mg orally for 8 weeks | n Analyzed: | 19 | The mean weight loss achieved during the reduction phase was 12.6 kg (95% CI: 10.9–14.3) for the Low Energy Diet (LED) group (Arm1) and 12.6 kg (CI: 9.9–15.3) for the Conventional Diet (CD) group (Arm 2). The rate of weight loss was twice as high in the CD group (Arm 2, 1.6 kg/week, CI: 1.4–1.8) than in the LED group (Arm 1, 0.8 kg/week, CI: 0.7–1.0).
| Population: | Female | | Caffeine
| Comorbidities: | Obesity | | 600 mg orally for 8 weeks
| | | 2 | Ephedrine | n Entered: | 22
| | | | 60 mg orally for 17 weeks | n Analyzed: | 19
| | | | Caffeine
| | | | 600 mg orally for 17 weeks
Van Mil E & Molnar D 2000 #272 | RCT | | 1 | Placebo | n Entered: | 16 | Average weight loss at 5 months in kg:
| Jadad Score: | 1 | | Placebo for 20 weeks | n Analyzed: | 16 | Arm 1 = 1.5 (8.1)
| Population: | Adolescents(12–17) | 2 | Ephedrine | n Entered: | 16 | Arm 2 = 8.7 (5.7)
| Comorbidities: | Obesity | | 60 mg orally for 20 weeks | n Analyzed: | 16
| | | | Caffeine
| | | | 600 mg orally for 20 weeks

N/A = not available or not applicable

* Meta-analysis data reports standard deviation in parentheses.