# References

1 McGuffin M. Statement of Michael McGuffin. Hearings Before the FDA, Docket (Aug. 8, 2000).
2 Abrahamson A. Wheeler used supplement. Los Angeles Times. Aug. 11, 2001; Sect: Sports.
3 Fernas R, Heckert J. Substances are easily obtained. Los Angeles Times. Aug. 11, 2001; Sect: Sports.
4 Springer S. Bobby Bowden says deaths have him scared. Los Angeles Times. Aug. 11, 2001; Sect: Sports.
5 Carey B. Risks of ephedra usage in spotlight. Los Angeles Times. Aug. 27, 2001; Sect: Health.
6 Barnes J., Winter G. Major food companies using herbal additives. San Francisco Chronicle. May 27, 2001.
7 Rogers P. A deadly diet aid? People Magazine. July 1, 2002.
8 Fong H. Ephedra-containing compounds: Historical and pharmacologic context. Hearings Before the US Public Health Service (Aug. 8, 2000).
9 Love LA. Adverse event reports: Database and clinical studies. Hearings Before the US Public Health Service (Aug. 8, 2000).
10 Mokdad A H, Bowman B A, Ford E S, Vinicor F, Marks J S, Koplan J P. The continuing epidemics of obesity and diabetes in the United States. JAMA. 2001;286(10):1195-200. [pmid: 11559264].
11 Mokdad A H, Serdula M K, Dietz W H, Bowman B A, Marks J S, Koplan J P. The continuing epidemic of obesity in the United States. JAMA. 2000;284(13):1650-1. [pmid: 11015792].
12 Mokdad A H, Serdula M K, Dietz W H, Bowman B A, Marks J S, Koplan J P. The spread of the obesity epidemic in the United States, 1991-1998. JAMA. 1999;282(16):1519-22. [pmid: 10546690].
13 Centers for Disease Control and Prevention. Obesity Epidemic Increases Dramatically in the United States. available at URL: http://www.cdc.gov/nccdphp/dnpa/obesity-epidemic.htm. Accessed 6/11/2002.
14 Kuczmarski R J, Flegal K M, Campbell S M, et al. Increasing prevalence of overweight among US adults. JAMA. 1994;272:205-211. [pmid: 8022039].
15 Katzmarzyk P T. The Canadian obesity epidemic, 1985-1998. CMAJ. 2002;166(8):1039-40. [pmid: 12002980]. [pmcid: 100878].
16 Katzmarzyk PT. Obesity in Canadian children. CMAJ. 2001;164(11):1563–4; discussion 1564–5.
17 World Health Organization. Controlling the global obesity epidemic. available at URL: http://www.who.int/nut/obs.htm. Accessed 6/20/2002.
18 Friedrich M J. Epidemic of obesity expands its spread to developing countries. JAMA. 2002;287(11):1382-6. [pmid: 12495379].
19 Must A, Spadano J, Coakley E H, Field A E, Colditz G, Dietz W H. The disease burden associated with overweight and obesity. JAMA. 1999;282(16):1523-9. [pmid: 10546691].
20 Pi S Y. Medical Hazards of Obesity. Ann Intern Med. 1993;119:S655-660. [pmid: 8363205].
21 Pi-Sunyer X F. Medical hazards of obesity. Ann Intern Med. 1993;119(7 pt 2):655-660. [pmid: 8363205].
22 Allison D B, Fontaine K R, Manson J E, Stevens J, VanItallie T B. Annual deaths attributable to obesity in the United States. JAMA. 1999;282(16):1530-8. [pmid: 10546692].
23 Colditz G A. Economic costs of obesity. Am J Clin Nutr. 1992;55(2 Suppl):503S-507S. [pmid: 1315120].
24 Colditz G A. Economic costs of obesity and inactivity. Med Sci Sports Exerc. 1999;31(11 Suppl):S663-7. [pmid: 10593542].
25 Allison D B, Zannolli R, Narayan K M. The direct health care costs of obesity in the United States. Am J Public Health. 1999;89(8):1194-9. [pmid: 10432905]. [pmcid: 1508703].
26 Sturm R. The effects of obesity, smoking, and drinking on medical problems and costs. Obesity outranks both smoking and drinking in its deleterious effects on health and health costs. Health Aff (Millwood). 2002;21(2):245-53. [pmid: 12442853].
27 National Institutes of Health. NIH guidelines: Clinical Guidelines on the Identification, Evaluation, and Treatment of Overweight and Obesity in Adults. The Evidence Report. Obes Res. 1998;6(Suppl 2):51S-209S. [pmid: 9813653].
28 Williamson D F, Pamuk E, Thun M, Flanders D, Byers T, Heath C. Prospective study of intentional weight loss and mortality in never- smoking overweight US white women aged 40–64 years. Am J Epidemiol. 1995;141(12):1128-41. [pmid: 7771451].
29 Galuska D A, Will J C, Serdula M K, Ford E S. Are health care professionals advising obese patients to lose weight?. JAMA. 1999;282(16):1576-8. [pmid: 10546698].
30 Blanck H M, Khan L K, Serdula M K. Use of nonprescription weight loss products: results from a multistate survey. JAMA. 2001;286(8):930-5. [pmid: 11509057].
31 Heber D, Greenway FL. Herbal and alternative approaches to obesity. In: Handbook of Obesity. in press.
32 Harnack L J, Rydell S A, Stang J. Prevalence of use of herbal products by adults in the Minneapolis/St Paul, Minn, metropolitan area. Mayo Clin Proc. 2001;76(7):688-94. [pmid: 11444400].
33 Bowers L D. Abuse of performance-enhancing drugs in sport. Ther Drug Monit. 2002;24(1):178-81. [pmid: 11805741].
34 Catlin D H, Murray T H. Performance-enhancing drugs, fair competition, and Olympic sport. JAMA. 1996;276(3):231-7. [pmid: 8667569].
35 Sobal J, Marquart L F. Vitamin/mineral supplement use among athletes: a review of the literature. Int J Sport Nutr. 1994;4(4):320-34. [pmid: 7874149].
36 Jonnalagadda S S, Rosenbloom C A, Skinner R. Dietary practices, attitudes, and physiological status of collegiate freshman football players. J Strength Cond Res. 2001;15(4):507-13. [pmid: 11726265].
37 Baylis A, Cameron-Smith D, Burke L M. Inadvertent doping through supplement use by athletes: assessment and management of the risk in Australia. Int J Sport Nutr Exerc Metab. 2001;11(3):365-83. [pmid: 11591885].
38 Catlin D H, Hatton C K. Use and abuse of anabolic and other drugs for athletic enhancement. Adv Intern Med. 1991;36:399-424. [pmid: 1673818].
39 National College Athletics Association. NCAA study of substance use habits of college student-athletes. available at URL: http://www.ncaa.org/library/research/htm - substance_use_habits. Accessed 6/25/2002.
40 Kanayama G, Gruber A J, Pope H G Jr, Borowiecki J J, Hudson J I. Over-the-counter drug use in gymnasiums: an underrecognized substance abuse problem?. Psychother Psychosom. 2001;70(3):137-40. [pmid: 11340414].
41 Gruber A J, Pope H G Jr. Ephedrine abuse among 36 female weightlifters. Am J Addict. 1998;7(4):256-61. [pmid: 9809129].
42 Mahdihassan S. Ephedra, the oldest medicinal plant with the history of an uninterrupted use. In: Ancient Science of Life. 1987. pp. 105–109.
43 Lietava J. Medicinal plants in a middle paleolithic grave Shanidar IV?. J Ethnopharmacol. 1992;35:263-66. [pmid: 1548898].
44 Chen K K, Schmidt C F. Ephedrine and related substances. Medicine. 1930;9:1-117.
45 Karch SB. Ma huang and the ephedra alkaloids. In: Cupp MJ. (Ed) Toxicology and Clinical Pharmacology of Herbal Products. Totowa, NJ: Humana Press, Inc; 2000. pp. 11–30.
46 Hu S Y. Ephedra (ma-huang) in the new Chinese materia medica. Economic Botany. 1969;23:346-351.
47 Bensky D. Chinese Herbal Medicine: Materia Medica. Seattle, WA: Eastland Press; 1993.
48 Nadkarni KM. Indian Materia Medica, Vol. I. Bombay, India: Popular Prakashan; 1976.
49 Blumenthal M, Busse WR. Ephedra. In: Blumenthal M, Busse WR. (Eds) (Translated by) Klein S, Rister RS. Complete German Commission E Monographs: Therapeutic Guide to Herbal Medicines. Boston, MA: Integrative Medicine Communications; 1998. pp. 125–6, 414–6, 475–6.
50 Robbers JE, Tyler VE. Tyler's Herbs of Choice. New York: The Haworth Herbal Press; 1999.
51 Bruneton J. Phenethylamines. In: Bruneton J. Pharmacognosy, Phytochemistry, Medicinal Plants. Paris, France, Secausuc, NY: Lavoisier Pub; 1996. pp. 711–15.
52 Leung AY, Foster S. Ephedra. In: Leung AY, Foster S. Encyclopedia of Common Natural Ingredients Used in Foods, Drugs, and Cosmetics. New York, NY: John Wiley; 1996. p. 227.
53 Kamimura K, Iwamoto Y, Yamasaki K, Sakagami Y, et al. Variation of growth and contents in ephedrine type alkaloids in Ephedra distachya. Natural Medicines. 1994;48:122-125.
54 Tanaka T, Obha K, Kawaahara K, Sakai E. Comparison of the constituents of ephedra herbs from various countries on ephedrine type alkaloids. Natural Medicines. 1995;49:418-424.
55 Kondo N, Mikage M, Idaka K. Medico-botanical studies of Ephedra plants from the Himalayan region, part III: Causitive factors of variation of alkaloid content in herbal stems. Natural Medicines. 1999;53:194-200.
56 Zhang JS, Tian Z, Lou ZC. [Quality evaluation of twelve species of Chinese Ephedra (ma huang)]. Yao Xue Xue Bao. 1989 24:(11)865–71. (Abstract).
57 Zhu Y-P. Chinese Materia Medica. Amsterdam, Netherlands: Hardwood Academic Press; 1998.
58 McKenna DJ, Jones K, Hughes K. Botanical Medicines. New York, NY: The Haworth Herbal Press; in press.
59 Evans WC. Trease and Evans' Pharmacognosy. London: WB Saunders; 1989.
60 Sheu S-J. Identification by chemical analysis of the botanical sources of commercial samples of Chinese herbal drugs. Yao Wu Shih P'in Fen Hsi (J Food Drug Anal). 1997;5(4):285-294.
61 Gurley BJ, Gardner SF, White LM, Wang P. Ephedrine pharmacokinetics after the ingestion of commercially available herbal preparations of ephedra sinica (Ma-huang). Pharmaceut Res. 1997;14:(11 Suppl)S519(Abstract).
62 Chen K K, Wu C-K, Henriksen E. Relationship between the pharmacological action and the chemical constitution and configuration of the optical isomers of ephedrine and related compounds. J Pharmacol Exper Therapeut. 1929;36:363-400.
63 Chen K K, Schmidt C F. The action of ephedrine, the active principle of the Chinese drug Ma Hung. J Pharmacol Exper Therapeut. 1924;24:339-357.
64 Chen K K, Meek W J. Further studies on the effect of ephedrine on the circulation. J Am Pharmaceut Assoc. 1926;28:31-57.
65 Hardman JG, Limbird LE, Gilman A. (Eds). Goodman and Gilman's The Pharmacologic Basis of Disease. New York, NY: McGraw-Hill; 2001.
66 Burnham TH, Novak KK, Bell WL, Schweain SL. Ephedrine. In: Drug Facts and Comparisons. St Louis, MO: Facts and Comparisons; 2002. p. 692.
67 Astrup A, Toubro S. Thermogenic, metabolic, and cardiovascular responses to ephedrine and caffeine in man. Int J Obes Relat Metab Disord. 1993;17(Suppl 1):S41-3. [pmid: 8124407].
68 Martin W R, Sloan J W, Sapira J D, Jasinski D R. Physiologic, subjective, and behavioral effects of amphetamine, methamphetamine, ephedrine, phenmetrazine, and methylphenidate in man. Clin Pharmacol Ther. 1971;12(2):245-58. [pmid: 5554941].
69 Astrup A, Toubro S, Christensen N J, Quaade F. Pharmacology of thermogenic drugs. Am J Clin Nutr. 1992;55(1 Suppl):246S-248S. [pmid: 1345887].
70 Bukowiecki L, Jahjah L, Follea N. Ephedrine, a potential slimming drug, directly stimulates thermogenesis in brown adipocytes via beta-adrenoreceptors. Int J Obes. 1982;6(4):343-50. [pmid: 6290407].
71 Gurley B J, Gardner S F, White L M, Wang P L. Ephedrine pharmacokinetics after the ingestion of nutritional supplements containing Ephedra sinica (ma huang). Ther Drug Monit. 1998;20(4):439-45. [pmid: 9712471].
72 Pickup M E, May C S, Ssendagire R, Paterson J W. The pharmacokinetics of ephedrine after oral dosage in asthmatics receiving acute and chronic treatment. Br J Clin Pharmacol. 1976;3(1):123-34. [pmid: 973934]. [pmcid: 1428819].
73 Kanfer I, Dowse R, Vuma V. Pharmacokinetics of oral decongestants. Pharmacotherapy. 1993;13(6 Pt 2):116S–128S; discussion 143S–146S.
74 Sever P S, Dring L G, Williams R T. The metabolism of (-)-ephedrine in man. Eur J Clin Pharmacol. 1975;9(23):193-8. [pmid: 786688].
75 Haller, Jacob P 3rd, Benowitz N L. Pharmacology of ephedra alkaloids and caffeine after single-dose dietary supplement use. Clin Pharmacol Therap. 2002;71:421-32. [pmid: 12087345].
76 Gurley B J, Gardner S F, White L M, Wang P. Ephedrine pharmacokinetics after the ingestion of nutritional supplements containing Ephedra sinica (ma huang). Therapeut Drug Monit. 1998;20(4):439-445.
77 White L M, Gardner S F, Gurley B J, Marx M A, Wang P L, Estes M. Pharmacokinetics and cardiovascular effects of ma-huang (Ephedra sinica) in normotensive adults. J Clin Pharmacol. 1997;37(2):116-22. [pmid: 9055137].
78 Dulloo A G, Seydoux J, Girardier L, Chantre P, Vandermander J. Green tea and thermogenesis: interactions between catechin-polyphenols, caffeine and sympathetic activity. Int J Obes Relat Metab Disord. 2000;24(2):252-8. [pmid: 10702779].
79 Han L K, Takaku T, Li J, Kimura Y, Okuda H. Anti-obesity action of oolong tea. Int J Obes Relat Metab Disord. 1999;23(1):98-105. [pmid: 10094584].
80 Dulloo A G, Seydoux J, Girardier L. Peripheral mechanisms of thermogenesis induced by ephedrine and caffeine in brown adipose tissue. Int J Obes. 1991;15(5):317-26. [pmid: 1885257].
81 Greenway F. The safety and efficacy of pharmaceutical and herbal caffeine and ephedrine use as a weight loss agent. Obesity Reviews. 2001;2:199-211. [pmid: 12120105].
82 Jadad A R, Moore R A, Carroll D, Jenkinson C, Reynolds D J, Gavaghan D J, et al. Assessing the quality of reports of randomized clinical trials: is blinding necessary?. Control Clin Trials. 1996;17(1):1-12. [pmid: 8721797].
83 Moher D, Pham D, Jones A, Cook D J, Jadad A R, Moher M, et al. Does quality of reports of randomized trials affect estimates of interventions efficacy reported in meta-analyses?. Lancet. 1998;352:609-613. [pmid: 9746022].
84 Moheb MA, Geissler CA, Lancer K. Effect of ephedrine, caffeine, and aspirin, in combinations of weight loss in obese women. Int J Obesity Related Metabol Disord. 1998;22:(Suppl 3)S264(Abstract).
85 Pasquali R, Baraldi G, Cesari M P, Melchionda N, Zamboni M, Stefanini C, et al. A controlled trial using ephedrine in the treatment of obesity. Int J Obes. 1985;9(2):93-8. [pmid: 3897082].
86 Quaade F, Astrup A, Breum L, Toubro S, Hein P. [The effect of an ephedrine/caffeine combination as a supplement to a weight-reducing diet. A randomized, placebo-controlled, double-blind trial]. Ugeskr Laeger. 1992;154(18):1258-63. [pmid: 1509553].
87 Malchow-Moller A, Larsen S, Hey H, Stokholm K H, Juhl E, Quaade F. Ephedrine as an anorectic: the story of the ‘Elsinore pill’. Int J Obes. 1981;5(2):183-7. [pmid: 7228474].
88 Jensen K B, Dano P, Draeby N, Hansen S H, Kanstrup J. [Elsinore tablets and ephedrine as slimming agents]. Ugeskr Laeger. 1980;142(23):1499-501. [pmid: 6996254].
89 Boozer C N, Daly P A, Homel P, Solomon J L, Blanchard D, Nasser J A, et al. Herbal ephedra/caffeine for weight loss: a 6-month randomized safety and efficacy trial. Int J Obes Relat Metab Disord. 2002;26(5):593-604. [pmid: 12032741].
90 Kettle R, Toubro S, Astrup A. Ephedrine/Caffeine enhances abdominal fat loss in females. Intl J Obesity Related Metabolic Disorders. 1998;22(Suppl 3):S264.
91 Van Mil E, Molnar D. Drug treatment in obese adolescents. Int J Obesity. 2000 24:(Suppl 1)S184(Abstract).
92 Buemann B, Marckmann P, Christensen N J, Astrup A. The effect of ephedrine plus caffeine on plasma lipids and lipoproteins during a 4.2 MJ/day diet. Int J Obes Relat Metab Disord. 1994;18(5):329-32. [pmid: 8061726].
93 Colker CM, Swain MA, Lynch L. A pilot study evaluating the effects of an ephedrine and forskolin-based product on body weight and body composition in overweight, healthy women. J Am Coll Nutr. 2001;20(5):a98(Abstract).
94 Lumholtz I B, Thorsteinsson B, Wamberg T, Lehnschau A, Hansen G, Spellerberg S, et al. [Ephedrine in the treatment of obesity. A double-blind cross-over trial of the effect of Elsinore tablets]. Ugeskr Laeger. 1980;142(23):1487-90. [pmid: 6996251].
95 Roed P, Hansen P W, Bidstrup B, Kaern M, Helles A, Petersen K P. [Elsinore banting tablets. A controlled clinical trial in general practice]. Ugeskr Laeger. 1980;142(23):1491-5. [pmid: 6996252].
96 Kalman D S, Colker C M, Shi Q, Swain M A. Effects of a weight-loss aid in healthy overweight adults: Double-blind, placebo-controlled clinical trial. Curr Therapeut Res. 2000;61(4):199-205.
97 Hedges LV, Olkin I. Statistical methods for meta-analysis. San Diego, CA: Academic Press, Inc.; 1985.
98 Rosenthal R. Meta-analysis: a review. Psychosom Med. 1991;53(3):247-71. [pmid: 1882008].
99 DerSimonian R, Laird N. Meta-analysis in clinical trials. Control Clin Trials. 1986;7(3):177-88. [pmid: 3802833].
100 Mood AM, Graybill FA, Boes DC. Introduction to the Theory of Statistics. 3rd ed. London: McGraw-Hill, Inc.; 1974.
101 Ray J W, Shadish W R. How interchangeable are different estimators of effect size?. Journal of Consulting and Clinical Psychology. 1996;64:1316-1325. [pmid: 8991318].
102 Assismos D G, Langenstroer P, Leinbach R F, Mandel N S, Stern J M, Holmes R P. Guaifenesin - and ephedrine-induced stones. J Endourol. 1999;13(9):665-7. [pmid: 10608519].
103 Daly P A, Krieger D R, Dulloo A G, Young J B, Landsberg L. Ephedrine, caffeine and aspirin: safety and efficacy for treatment of human obesity. Int J Obes Relat Metab Disord. 1993;17(Suppl 1):S73-8. [pmid: 8384187].
104 Berkey C S, Hoaglin D C, Mosteller F, Colditz G A. A random-effects regression model for meta-analysis. Stat Med. 1995;14(4):395-411. [pmid: 7746979].
105 Begg C B, Mazumdar M. Operating characteristics of a rank correlation test for publication bias. Biometrics. 1994;50(4):1088-101. [pmid: 7786990].
106 Egger M, Davey Smith G, Schneider M, Minder C. Bias in meta-analysis detected by a simple, graphical test. BMJ. 1997;315(7109):629-34. [pmid: 9310563]. [pmcid: 2127453].
107 Stata Statistical Software: Release 7.0 [computer program]. College Station, TX: Stata Corporation; 2001.
108 StatXact 4 for Windows [computer program]. Version 4.0.1. Cambridge, MA: Cytel Software Corporation; 2000.
109 Landis J R, Koch G G. The measurement of observer agreement for categorical data. Biometrics. 1977;33(1):159-74. [pmid: 884196].
110 Robinson T E, Becker J B. Enduring changes in brain and behavior produced by chronic amphetamine administration: a review and evaluation of animal models of amphetamine psychosis. Brain Res. 1986;396(2):157-98. [pmid: 3527341].
111 Astrup A, Buemann B, Christensen N J, Toubro S, Thorbek G, Victor O J, et al. The effect of ephedrine/caffeine mixture on energy expenditure and body composition in obese women. Metabolism. 1992;41(7):686-8. [pmid: 1619985].
112 Molnar D, Torok K, Erhardt E, Jeges S. Safety and efficacy of treatment with an ephedrine/caffeine mixture. The first double-blind placebo-controlled pilot study in adolescents. Int J Obes Relat Metab Disord. 2000;24(12):1573-8. [pmid: 11126208].
113 Breum L, Pedersen J K, Ahlstrom F, Frimodt-Moller J. Comparison of an ephedrine/caffeine combination and dexfenfluramine in the treatment of obesity. A double-blind multi-centre trial in general practice. Int J Obes Relat Metab Disord. 1994;18(2):99-103. [pmid: 8148931].
114 Donikyan LA. A double-blind randomized, placebo-controlled, multicenter clinical study to evaluate the safety and efficacy of a natural herbal formulation when taken as recommended for weight control. Technical Report Version #1. Boca Raton, FL: Rexall Sundown. 2002 (Unpublished Work).
115 Boozer C N, Nasser J A, Heymsfield S B, Wang V, Chen G, Solomon J L. An herbal supplement containing Ma Huang-Guarana for weight loss: a randomized, double-blind trial. Int J Obes Relat Metab Disord. 2001;25(3):316-24. [pmid: 11319627].
116 Greenway F, deJonge L, Blanchard D, et al. Evaluation of a dietary herbal supplement containing caffeine and ephedrine on metabolic rate, body composition, serum lipids and tolerability. Pennington Center, Louisiana State University. (Unpublished Work).
117 Fujioka K, Seaton T B, Rowe E, Jelinek C A, Raskin P, Lebovitz H E, et al. Weight loss with sibutramine improves glycaemic control and other metabolic parameters in obese patients with type 2 diabetes mellitus. Diabetes Obes Metab. 2000;2(3):175-87. [pmid: 11220553].
118 Gokcel A, Karakose H, Ertorer E M, Tanaci N, Tutuncu N B, Guvener N. Effects of sibutramine in obese female subjects with type 2 diabetes and poor blood glucose control. Diabetes Care. 2001;24(11):1957-60. [pmid: 11679464].
119 Smith I G, Goulder M A. Randomized placebo-controlled trial of long-term treatment with sibutramine in mild to moderate obesity. J Fam Pract. 2001;50(6):505-12. [pmid: 11407998].
120 Wirth A, Krause J. Long-term weight loss with sibutramine: a randomized controlled trial. JAMA. 2001;286(11):1331-9. [pmid: 11560538].
121 Van Gaal L F, Broom J I, Enzi G, Toplak H. Efficacy and tolerability of orlistat in the treatment of obesity: a 6-month dose-ranging study. Orlistat Dose-Ranging Study Group. Eur J Clin Pharmacol. 1998;54(2):125-32. [pmid: 9626916].
122 Hill J O, Hauptman J, Anderson J W, Fujioka K, O'Neil P M, Smith D K, et al. Orlistat, a lipase inhibitor, for weight maintenance after conventional dieting: a 1-y study. Am J Clin Nutr. 1999;69(6):1108-16. [pmid: 10357727].
123 Karhunen L, Franssila-Kallunki A, Rissanen P, Valve R, Kolehmainen M, Rissanen A, et al. Effect of orlistat treatment on body composition and resting energy expenditure during a two-year weight-reduction programme in obese Finns. Int J Obes Relat Metab Disord. 2000;24(12):1567-72. [pmid: 11126207].
124 Micic D, Ivkovic-Lazar T, Dragojevic R, Jorga J, Stokic E, Hajdukovic Z. Orlistat, a gastrointestinal lipase inhibitor, in therapy of obesity with concomitant hyperlipidemia. Med Pregl. 1999;52(910):323-33. [pmid: 10624380].
125 Muls E, Kolanowski J, Scheen A, Van Gaal L. The effects of orlistat on weight and on serum lipids in obese patients with hypercholesterolemia: a randomized, double-blind, placebo- controlled, multicentre study. Int J Obes Relat Metab Disord. 2001;25(11):1713-21. [pmid: 11753595].
126 Munro J F, MacCuish A C, Wilson E M, Duncan L J. Comparison of continuous and intermittent anorectic therapy in obesity. BMJ. 1968;1:352. [pmid: 15508204]. [pmcid: 1984840].
127 Oksbjerg N, Meyer T, Hvid-Jacobsen K. [Aerobic training increases the effect of ephedrine on energy expenditure]. Ugeskr Laeger. 1986;148(32):2021-4. [pmid: 3529561].
128 Bell D G, Jacobs I, Zamecnik J. Effects of caffeine, ephedrine and their combination on time to exhaustion during high-intensity exercise. Eur J Appl Physiol Occup Physiol. 1998;77(5):427-33. [pmid: 9562293].
129 Bell D G, Jacobs I, McLellan T M, Zamecnik J. Reducing the dose of combined caffeine and ephedrine preserves the ergogenic effect. Aviat Space Environ Med. 2000;71(4):415-9. [pmid: 10766467].
130 Bell D G, Jacobs I. Combined caffeine and ephedrine ingestion improves run times of Canadian Forces Warrior Test. Aviat Space Environ Med. 1999;70(4):325-9. [pmid: 10373050].
131 Bell D G, Jacobs I, McLellan T M, Miyazaki M, Sabiston C M. Thermal regulation in the heat during exercise after caffeine and ephedrine ingestion. Aviat Space Environ Med. 1999;70(6):583-8. [pmid: 10373050].
132 Pasternak H, Jacobs I, Bell D. Effects of ingesting caffeine and ephedrine on muscular endurance. Can J Appl Physiol. 1999;24(5):471.
133 Bell D G, Jacobs I, Ellerington K. Effect of caffeine and ephedrine ingestion on anaerobic exercise performance. Med Sci Sports Exercise. 2001;33:1399-1403.
134 Sidney K H, Lefcoe N M. The effects of ephedrine on the physiological and psychological responses to submaximal and maximal exercise in man. Med Sci Sports. 1977;9(2):95-9. [pmid: 895434].
135 Horton T J, Geissler C A. Aspirin potentiates the effect of ephedrine on the thermogenic response to a meal in obese but not lean women. Int J Obes. 1991;15(5):359-66. [pmid: 1885260].
136 Horton T J, Geissler C A. Post-prandial thermogenesis with ephedrine, caffeine and aspirin in lean, pre-disposed obese and obese women. Int J Obes Relat Metab Disord. 1996;20(2):91-7. [pmid: 8646257].
137 Shugarman AE. Effect of thermogenic dietary supplements on resting metabolic rate in healthy male and female volunteers. Utah: University of Utah. 1998.
138 Toubro S, Astrup A. Randomised comparison of diets for maintaining obese subjects' weight after major weight loss: ad lib, low fat, high carbohydrate diet v fixed energy intake. BMJ. 1997;314(7073):29-34. [pmid: 9001476]. [pmcid: 2125573].
139 Ofman JJ, MacLean C, Straus WL, et al. A meta-analysis of dyspepsia and nonsteroidal anti-inflammatory drugs. Arthritis Care and Research. In press.