# Acknowledgment

We would like to thank Dr. Lori Love and Ms. Constance J. Hardy of the Food and Drug Administration for providing us with adverse event reports related to ephedra. We thank Dr. Catherine MacLean, a rheumatologist, and Dr. Barbara Vickrey, a neurologist, for providing advice on cases related to their fields. We thank Drs. Karen Miotto, a psychiatrist, and Martin Iguchi, a psychologist, for review of psychiatric case reports. We thank Ms. Birgit Danila, MA, for translation of Danish studies.