# Appendix 1. Bibliography

### Articles Accepted for Efficacy Analysis

1 Astrup A, Breum L, Toubro S, Hein P, Quaade F. The effect and safety of an ephedrine/caffeine compound compared to ephedrine, caffeine and placebo in obese subjects on an energy restricted diet. A double blind trial. Int J Obes Relat Metab Disord. 1992;16(4):269-77. Rec#: 7. [pmid: 1328095].
Notes: Considered for efficacy and adverse event analysis.
2 Astrup A, Breum L, Toubro S, Hein P, Quaade F. Ephedrine and weight loss. Int J Obes Relat Metab Disord. 1992;16(9):715. Rec#: 8. [pmid: 1328095].
Notes: Not considered for analysis. Same trial as Astrup, 1992. Rec#7.
3 Astrup A, Buemann B, Christensen N J, et al. The effect of ephedrine/caffeine mixture on energy expenditure and body composition in obese women. Metabolism. 1992;41(7):686-8. Rec#: 9. [pmid: 1619985].
Notes: Considered for efficacy and adverse event analysis.
4 Astrup A, Toubro S, Cannon S, Hein P, Madsen J. Thermogenic synergism between ephedrine and caffeine in healthy volunteers: a double-blind, placebo-controlled study. Metabolism. 1991;40(3):323-9. Rec#: 13. [pmid: 2000046].
Notes: Considered for efficacy and adverse event analysis.
5 Belfie L, Petrie H, Chown S, et al. Safety and effectiveness of an herbal dietary supplement containing ephedra (ma huang) and caffeine (guarana extract) when used in combination with a supervised diet and exercise intervention. Obesity Research Program Abstracts 9(Suppl 3):26. Rec# 317
Notes: Considered for efficacy and adverse event analysis.
6 Bell D G, Jacobs I. Combined caffeine and ephedrine ingestion improves run times of Canadian Forces Warrior Test. Aviat Space Environ Med. 1999;70(4):325-9. Rec#: 24. [pmid: 10373050].
Notes: Considered for efficacy and adverse event analysis.
7 Bell D G, Jacobs I, Ellerington K. Effect of caffeine and ephedrine ingestion on anaerobic exercise performance. Med. Sci. Sports Exercise. 2001;33:1399-1403. Rec#: 512.
Notes: Considered for efficacy and adverse event analysis.
8 Bell D G, Jacobs I, McLellan T M, Miyazaki M, Sabiston C M. Thermal regulation in the heat during exercise after caffeine and ephedrine ingestion. Aviat Space Environ Med. 1999;70(6):583-8. Rec#: 25. [pmid: 10373050].
Notes: Considered for efficacy and adverse event analysis.
9 Bell D G, Jacobs I, McLellan T M, Zamecnik J. Reducing the dose of combined caffeine and ephedrine preserves the ergogenic effect. Aviat Space Environ Med. 2000;71(4):415-9. Rec#: 26. [pmid: 10766467].
Notes: Considered for efficacy and adverse event analysis.
10 Bell D G, Jacobs I, Zamecnik J. Effects of caffeine, ephedrine and their combination on time to exhaustion during high-intensity exercise. Eur J Appl Physiol Occup Physiol. 1998;77(5):427-33. Rec#: 27. [pmid: 9562293].
Notes: Considered for efficacy and adverse event analysis.
11 Boozer C N, Daly P A, Homel P, et al. Herbal ephedra/caffeine for weight loss: a 6-month randomized safety and efficacy trial. Int J Obes Relat Metab Disord. 2002;26(5):593-604. Rec#: 474. [pmid: 12032741].
Notes: Considered for efficacy and adverse event analysis.
12 Boozer C N, Daly P A, Homel P, et al. Herbal ephedra/caffeine for weight loss: a 6-month randomized safety and efficacy trial. Int J Obes Relat Metab Disord. 2002;26(5):593-604. Rec#: 34. [pmid: 12032741].
Notes: Not considered for analysis. Same trial as Boozer, 2002. Rec#474.
13 Boozer C N, Nasser J A, Heymsfield S B, Wang V, Chen G, Solomon J L. An herbal supplement containing Ma Huang-Guarana for weight loss: a randomized, double-blind trial. Int J Obes Relat Metab Disord. 2001;25(3):316-24. Rec#: 333. [pmid: 11319627].
Notes: Considered for efficacy and adverse event analysis.
14 Breum L, Pedersen J K, Ahlstrom F, Frimodt-Moller J. Comparison of an ephedrine/caffeine combination and dexfenfluramine in the treatment of obesity. A double-blind multi-centre trial in general practice. Int J Obes Relat Metab Disord. 1994;18(2):99-103. Rec#: 41. [pmid: 8148931].
Notes: Considered for efficacy and adverse event analysis.
15 Buemann B, Marckmann P, Christensen N J, Astrup A. The effect of ephedrine plus caffeine on plasma lipids and lipoproteins during a 4.2 MJ/day diet. Int J Obes Relat Metab Disord. 1994;18(5):329-32. Rec#: 45. [pmid: 8061726].
Notes: Considered for efficacy and adverse event analysis.
16 Colker CM, Kalman DS, Minsch A: Ephedrine, caffeine, and aspirin enhance fat loss under non-exercising conditions. J Am Coll Nutr 1997;16:a116(Abstract) Rec#: 546
Notes: Considered for efficacy and adverse event analysis.
17 Colker CM, Swain MA, Lynch L: A pilot study evaluating the effects of an ephedrine and forskolin-based product on body weight and body composition in overweight, healthy women. J Am Coll Nutr 2001;20:a98(Abstract) Rec#: 548
Notes: Considered for efficacy and adverse event analysis.
18 Colker CM, Torina GC, Swain MA, Kalman DS: Double-blind, placebo controlled evaluation of the safety and efficacy of ephedra, caffeine, and salicin for short term weight reduction in overweight subjects. J Exer Physiol Online 1999;2:(Abstract) Rec#: 549
Notes: Considered for efficacy and adverse event analysis.
19 Daly P A, Krieger D R, Dulloo A G, Young J B, Landsberg L. Ephedrine, caffeine and aspirin: safety and efficacy for treatment of human obesity. Int J Obes Relat Metab Disord. 1993;17(Suppl 1):S73-8. Rec#: 68. [pmid: 8384187].
Notes: Considered for efficacy and adverse event analysis.
20 de Jonge L, Frisard M, Blanchard D, Greenway F. Safety and efficacy of an herbal dietary supplement containing caffeine and ephedra for obesity treatment. Obesity Research Program Abstracts. 2001;9(Suppl 3):20. Rec#: 316.
Notes: Not considered for analysis. Same trial as Greenway, Unpublished. Rec#475.
21 Donikyan LA: A double-blind randomized, placebo-controlled, multicenter clinical study to evaluate the safety and efficacy of a natural herbal formulation when taken as recommended for weight control. Technical Report Version # I, 2002:(UnPub) Rec# 509
Notes: Considered for efficacy and adverse event analysis.
22 Dulloo A G, Miller D S. The thermogenic properties of ephedrine/methylxanthine mixtures: human studies. Int J Obes. 1986;10(6):467-81. Rec#: 83. [pmid: 3804564].
Notes: Considered for efficacy and adverse event analysis.
23 Geissler C A. Effects of weight loss, ephedrine and aspirin on energy expenditure in obese women. Int J Obes Relat Metab Disord. 1993;17(Suppl 1):S45-8. Rec#: 97. [pmid: 8384180].
Notes: Considered for efficacy and adverse event analysis.
24 Greenway F, deJonge L, Blanchard D, et al.: Evaluation of a dietary herbal supplement containing caffeine and ephedrine on metabolic rate, body composition, serum lipids and tolerability, (UnPub) Rec# 475
Notes: Considered for efficacy and adverse event analysis.
25 Greenway F L, Raum W J, DeLany J P. The effect of an herbal dietary supplement containing ephedrine and caffeine on oxygen consumption in humans. J Altern Complement Med. 2000;6(6):553-5. Rec#: 106. [pmid: 11152061].
Notes: Considered for efficacy and adverse event analysis.
26 Ingerslev J, Svendsen T L, Mork A. Is an ephedrine caffeine treatment contraindicated in hypertension?. Int J Obesity Related Metabol Disord. 1997;21(8):666-673. Rec#: 132.
Notes: Considered for efficacy and adverse event analysis.
27 Jaedig S, Henningsen N C. Increased metabolic rate in obese women after ingestion of potassium, magnesium- and phosphate-enriched orange juice or injection of ephedrine. Int J Obes. 1991;15(6):429-36. Rec#: 391. [pmid: 1885267].
Notes: Considered for efficacy and adverse event analysis.
28 Jensen K B, Dano P, Draeby N, Hansen S H, Kanstrup J. [Elsinore tablets and ephedrine as slimming agents]. Ugeskr Laeger. 1980;142(23):1499-501. Rec#: 536. [pmid: 6996254].
Notes: Considered for efficacy and adverse event analysis.
29 Jonderko K, Kucio C. Effect of anti-obesity drugs promoting energy expenditure, yohimbine and ephedrine, on gastric emptying in obese patients. Aliment Pharmacol Ther. 1991;5(4):413-8. Rec#: 137. [pmid: 1777550].
Notes: Considered for efficacy and adverse event analysis.
30 Kaats GR, Aldeman JA: Effects of multiple herbal formulation on body composition, blood chemistry, vital signs and self-reported energy levels and appetite control. Int J Obesity Related Metabol Disord 1994;18:145(Abstract) Rec#: 139
Notes: Considered for efficacy and adverse event analysis.
31 Kalman D, Incledon T, Gaunaurd I, et al.: An acute clinical trial evaluating the cardiovascular effects of an herbal ephedra/caffeine weight loss product in healthy overweight adults. International Journal of Obesity In Press;(In Press) Rec#: 476
Notes: Considered for efficacy and adverse event analysis.
32 Kalman D S, Colker C M, Shi Q, Swain M A. Effects of a weight-loss aid in healthy overweight adults: Double-blind, placebo-controlled clinical trial. Curr Therapeut Res. 2000;61(4):199-205. Rec#: 140.
Notes: Considered for efficacy and adverse event analysis.
33 Kalman DS, Colker CM, Torina GC, Swain MS: Double-blind, placebo evaluation of the safety and efficacy of an ephedrine and synephrine based product for fat reduction in overweight subjects. Obs Research 2000;8:120(Abstract) Rec#: 550
Notes: Considered for efficacy and adverse event analysis.
34 Kettle R, Toubro S, Astrup A. Ephedrine/Caffeine enhances abdominal fat loss in females. Intl J Obesity Related Metabolic Disorders. 1998;22(suppl 3):S264. Rec#: 510.
Notes: Considered for efficacy and adverse event analysis.
35 Krieger D R, Daly P A, Dulloo A G, Ransil B J, Young J B, Landsberg L. Ephedrine, caffeine and aspirin promote weight loss in obese subjects. Trans Assoc Am Physicians. 1990;103:307-12. Rec#: 151. [pmid: 2132541].
Notes: Not considered for analysis. Same trial as Daly, 1993. Rec#68.
36 Liu Y L, Toubro S, Astrup A, Stock M J. Contribution of beta 3-adrenoceptor activation to ephedrine-induced thermogenesis in humans. Int J Obes Relat Metab Disord. 1995;19(9):678-85. Rec#: 169. [pmid: 8574280].
Notes: Considered for efficacy and adverse event analysis.
37 Lumholtz I B, Thorsteinsson B, Wamberg T, et al. [Ephedrine in the treatment of obesity. A double-blind cross-over trial of the effect of Elsinore tablets]. Ugeskr Laeger. 1980;142(23):1487-90. Rec#: 173. [pmid: 6996251].
Notes: Considered for efficacy and adverse event analysis.
38 Malchow-Moller A, Larsen S, Hey H, Stokholm K H, Juhl E, Quaade F. Ephedrine as an anorectic: the story of the ‘Elsinore pill’. Int J Obes. 1981;5(2):183-7. Rec#: 177. [pmid: 7228474].
Notes: Considered for efficacy and adverse event analysis.
39 Martinet A, Hostettmann K, Schutz Y. Thermogenic effects of commercially available plant preparations aimed at treating human obesity. Phytomedicine. 1999;6(4):231-8. Rec#: 335. [pmid: 10589441].
Notes: Considered for efficacy and adverse event analysis.
40 Moheb MA, Geissler CA, Lancer K: Effect of ephedrine, caffeine, and aspirin, in combinations of weight loss in obese women. Int J Obesity Related Metabol Disord 1998;22:S264(Abstract) Rec#: 193
Notes: Considered for efficacy and adverse event analysis.
41 Molnar D. Effects of ephedrine and aminophylline on resting energy expenditure in obese adolescents. Int J Obes Relat Metab Disord. 1993;17(Suppl 1):S49-52. Rec#: 194. [pmid: 8384181].
Notes: Considered for efficacy and adverse event analysis.
42 Molnar D, Torok K, Erhardt E, Jeges S. Safety and efficacy of treatment with an ephedrine/caffeine mixture. The first double-blind placebo-controlled pilot study in adolescents. Int J Obes Relat Metab Disord. 2000;24(12):1573-8. Rec#: 195. [pmid: 11126208].
Notes: Considered for efficacy and adverse event analysis.
43 Morgan J B, York D A, Wasilewska A, Portman J. A study of the thermic responses to a meal and to a sympathomimetic drug (ephedrine) in relation to energy balance in man. Br J Nutr. 1982;47(1):21-32. Rec#: 197. [pmid: 7037048].
Notes: Considered for efficacy and adverse event analysis.
44 Nasser JA, Wang V, Chen GC, Solomon JL, Heymsfield SB, Boozer CN: Efficacy trial for weight loss of an herbal supplement of Ma huang and guarana. FASEB J 1999;13:A874(Abstract) Rec#: 204
Notes: Not considered for analysis. Same trial as Boozer, 2001. Rec#333.
45 Norregaard J, Jorgensen S, Mikkelsen K L, et al. The effect of ephedrine plus caffeine on smoking cessation and postcessation weight gain. Clin Pharmacol Ther. 1996;60(6):679-86. Rec#: 210. [pmid: 8988071].
Notes: Considered for efficacy and adverse event analysis.
46 Oksbjerg N, Meyer T, Hvid-Jacobsen K. [Aerobic training increases the effect of ephedrine on energy expenditure]. Ugeskr Laeger. 1986;148(32):2021-4. Rec#: 214. [pmid: 3529561].
Notes: Considered for efficacy and adverse event analysis.
47 Pasquali R, Baraldi G, Cesari M P, et al. A controlled trial using ephedrine in the treatment of obesity. Int J Obes. 1985;9(2):93-8. Rec#: 220. [pmid: 3897082].
Notes: Considered for efficacy and adverse event analysis.
48 Pasquali R, Casimirri F, Melchionda N, et al. Effects of chronic administration of ephedrine during very-low-calorie diets on energy expenditure, protein metabolism and hormone levels in obese subjects. Clin Sci (Colch). 1992;82(1):85-92. Rec#: 222. [pmid: 1310922].
Notes: Considered for efficacy and adverse event analysis.
49 Pasquali R, Cesari M P, Melchionda N, Stefanini C, Raitano A, Labo G. Does ephedrine promote weight loss in low-energy-adapted obese women?. Int J Obes. 1987;11(2):163-8. Rec#: 223. [pmid: 3301709].
Notes: Considered for efficacy and adverse event analysis.
50 Pasternak H J I B D. Effects of ingesting caffeine and ephedrine on muscular endurance. Can. J. Appl. Physiol. 1999;24(5):471. Rec#: 511.
Notes: Considered for efficacy and adverse event analysis.
51 Quaade F, Astrup A, Breum L, Toubro S, Hein P. [The effect of an ephedrine/caffeine combination as a supplement to a weight-reducing diet. A randomized, placebo-controlled, double-blind trial]. Ugeskr Laeger. 1992;154(18):1258-63. Rec#: 230. [pmid: 1509553].
Notes: Not considered for analysis. Same trial as Astrup, 1992. Rec#7.
52 Roed P, Hansen P W, Bidstrup B, Kaern M, Helles A, Petersen K P. [Elsinore banting tablets. A controlled clinical trial in general practice]. Ugeskr Laeger. 1980;142(23):1491-5. Rec#: 535. [pmid: 6996252].
Notes: Considered for efficacy and adverse event analysis.
53 Shannon J R, Gottesdiener K, Jordan J, et al. Acute effect of ephedrine on 24-h energy balance. Clin Sci (Colch). 1999;96(5):483-91. Rec#: 243. [pmid: 10209080].
Notes: Considered for efficacy and adverse event analysis.
54 Shugarman AE. Effect of thermogenic dietary supplements on resting metabolic rate in healthy male and female volunteers. University of Utah. Utah. June, 1998. Rec#: 305
Notes: Considered for efficacy and adverse event analysis.
55 Sidney K H, Lefcoe N M. The effects of ephedrine on the physiological and psychological responses to submaximal and maximal exercise in man. Med Sci Sports. 1977;9(2):95-9. Rec#: 247. [pmid: 895434].
Notes: Considered for efficacy and adverse event analysis.
56 Toubro S, Astrup A. Randomised comparison of diets for maintaining obese subjects' weight after major weight loss: ad lib, low fat, high carbohydrate diet v fixed energy intake. BMJ. 1997;314(7073):29-34. Rec#: 261. [pmid: 9001476]. [pmcid: 2125573].
Notes: Considered for efficacy and adverse event analysis.
57 Toubro S, Astrup A V, Breum L, Quaade F. Safety and efficacy of long-term treatment with ephedrine, caffeine and an ephedrine/caffeine mixture. Int J Obes Relat Metab Disord. 1993;17(Suppl 1):S69-72. Rec#: 263. [pmid: 8124407].
Notes: Not considered for analysis. Same trial as Astrup, 1992. Rec#7.
58 Van Mil E, Molnar D: Drug treatment in obese adolescents . Int J Obesity 2000;24:S184(Abstract) Rec#: 272
Notes: Considered for efficacy and adverse event analysis.
59 Waluga M, Janusz M, Karpel E, Hartleb M, Nowak A. Cardiovascular effects of ephedrine, caffeine and yohimbine measured by thoracic electrical bioimpedance in obese women. Clin Physiol. 1998;18(1):69-76. Rec#: 276. [pmid: 9545623].
Notes: Considered for efficacy and adverse event analysis.

### Articles Rejected from Efficacy Analysis Revised

1 Anonymous. Ephedra herba. Kiso to Rinsho (Clin Rep) 1978;12:2125–2131. Rec#: 1
2 Anonymous. Ephedrae Herba, Bundesanzeiger No. 11. Bundesanzeiger 1991;11 Rec#: 534
3 Abdallah A H, Tye A, LaPidus J B, Patil P. Effects of ephedrine isomers on myocardial catecholamines. Life Sci. 1967;6(1):39-43. Rec#: 420. [pmid: 6030555].
4 Abernethy D R, Todd E L, Schwartz J B. Caffeine disposition in obesity. Br J Clin Pharmacol. 1985;20(1):61-6. Rec#: 378. [pmid: 4027137]. [pmcid: 1400629].
5 Acheson K J, Zahorska-Markiewicz B, Pittet P, Anantharaman K, Jequier E. Caffeine and coffee: their influence on metabolic rate and substrate utilization in normal weight and obese individuals. Am J Clin Nutr. 1980;33(5):989-97. Rec#: 371. [pmid: 7369170].
6 AHPA. Ephedra Survey Results: 1995-1999. Survey Administered & Results Compiled by: Arthur Andersen LLP. prepared for The American Herbal Products Association. 2000. Rec#: 2
7 Ahrendt D M. Ergogenic aids: counseling the athlete. American Family Physician. 2001;63(5):913-922. Rec#: 303. [pmid: 11261867].
8 al-Khalil S, Alkofahi A, el-Eisawi D, al-Shibib A. Transtorine, a new quinoline alkaloid from Ephedra transitoria. J Nat Prod. 1998;61(2):262-3. Rec#: 442. [pmid: 9514010].
9 Altschuler S, Conte A, Sebok M, Marlin R L, Winick C. Three controlled trials of weight loss with phenylpropanolamine. Int J Obes. 1982;6(6):549-56. Rec#: 399. [pmid: 6761288].
10 Anastario GD, Haston P. Fetal tachycardia associated with maternal use of pseudoephedrine and OTC oral decongestant. J Am Board Fam Pract 5:527–528. Rec#: 3
11 Anon. Herbal preparation: potential toxicity. Candian Adverse Drug Reaction Newsletter. 4, 1994. pages 3. Rec#: 498
12 Anon. Herbs to handle with care. Newsweek. New York. May 6, 1996. pages 62–3. Rec#: 497
13 Anselme F, Collomp K, Mercier B, Ahmaidi S, Prefaut C. Caffeine increases maximal anaerobic power and blood lactate concentration. Eur J Appl Physiol Occup Physiol. 1992;65(2):188-91. Rec#: 541. [pmid: 1396643].
14 Assismos D G, Langenstroer P, Leinbach R F, Mandel N S, Stern J M, Holmes R P. Guaifenesin - and ephedrine-induced stones. J Endourol. 1999;13(9):665-7. Rec#: 4. [pmid: 10608519].
15 Astrup A: Commentary on safety of products containing ephedrine alkaloids/caffeine, (UnPub) Rec#: 477
16 Astrup A. Thermogenesis in human brown adipose tissue and skeletal muscle induced by sympathomimetic stimulation. Acta Endocrinol Suppl (Copenh). 1986;278:1-32. Rec#: 389. [pmid: 3464154].
17 Astrup A. Thermogenic drugs as a strategy for treatment of obesity. Endocrine. 2000;13(2):207-12. Rec#: 5. [pmid: 11186222].
18 Astrup A, Breum L, Toubro S. Pharmacological and clinical studies of ephedrine and other thermogenic agonists. Obes Res. 1995;3(Suppl 4):537S-540S. Rec#: 6. [pmid: 8697055].
19 Astrup A, Lundsgaard C. What do pharmacological approaches to obesity management offer? Linking pharmacological mechanisms of obesity management agents to clinical practice. Exp Clin Endocrinol Diabetes. 1998;106(Suppl 2):29-34. Rec#: 10. [pmid: 9792479].
20 Astrup A, Lundsgaard C, Madsen J, Christensen N J. Enhanced thermogenic responsiveness during chronic ephedrine treatment in man. Am J Clin Nutr. 1985;42(1):83-94. Rec#: 11. [pmid: 4014068].
21 Astrup A, Madsen J, Holst J J, Christensen N J. The effect of chronic ephedrine treatment on substrate utilization, the sympathoadrenal activity, and energy expenditure during glucose-induced thermogenesis in man. Metabolism. 1986;35(3):260-5. Rec#: 387. [pmid: 3512957].
22 Astrup A, Toubro S. Thermogenic, metabolic, and cardiovascular responses to ephedrine and caffeine in man. Int J Obes Relat Metab Disord. 1993;17(Suppl 1):S41-3. Rec#: 12. [pmid: 8124407].
23 Astrup A, Toubro S, Cannon S, Hein P, Breum L, Madsen J. Caffeine: a double-blind, placebo-controlled study of its thermogenic, metabolic, and cardiovascular effects in healthy volunteers. Am J Clin Nutr. 1990;51(5):759-67. Rec#: 499. [pmid: 2333832].
24 Astrup A, Toubro S, Christensen N J, Quaade F. Pharmacology of thermogenic drugs. Am J Clin Nutr. 1992;55(1 Suppl):246S-248S. Rec#: 397. [pmid: 1345887].
25 Astrup A V. Treatment of obesity with thermogenic agents. Nutrition. 1989;5(1):70. Rec#: 403. [pmid: 2520263].
26 Aswal B S, Bhakuni D S, Goel A K, Kar K, Mehrotra B N. Screening of Indian plants for biological activity--Part XI. Indian J Exp Biol. 1984;22(9):487-504. Rec#: 14. [pmid: 6519693].
27 Atkinson R L. The herbal ephedra and caffeine debate continues. International Journal of Obesity. 2002;26:589. Rec#: 531.
28 Atkinson R L, Blank R C, Loper J F, Schumacher D, Lutes R A. Combined drug treatment of obesity. Obes Res. 1995;3(Suppl 4):497S-500S. Rec#: 15. [pmid: 8697049].
29 Audicana M, Urrutia I, Echechipia S, Munoz D, Fernandez de Corres L. Sensitization to ephedrine in oral anticatarrhal drugs. Contact Dermatitis. 1991;24(3):223. Rec#: 366. [pmid: 1831099].
30 Aviado DM, Wnuck AL, De Beer EJ. Cardiovascular effects of sympathomimetic bronchodilators: epinephrine, ephedrine, pseudoephedrine, isoproterenol, mehtoxyphenamine and isoprophenamine. J Pharmacology and Experimental Therapeutics 1958;122(407–417) Rec#: 405
31 Axelrod J. Studies on sympathomimetic amines: I. The biotransformation and physiological disposition of 1-ephedrine and 1-norephedrine. J Pharmacol Exper Therapeut. 1953;109(1):62-73. Rec#: 16.
32 Backer R, Tautman D, Lowry S, Harvey C M, Poklis A. Fatal ephedrine intoxication. J Forensic Sci. 1997;42(1):157-9. Rec#: 17. [pmid: 8988594].
33 Badiei B, Faciane J, Sly R M. Effect of theophylline, ephedrine and their combination upon exercise-induced airway obstruction. Ann Allergy. 1975;35(1):32-6. Rec#: 18. [pmid: 1155823].
34 Bailey C J, Thornburn C C, Flatt P R. Effects of ephedrine and atenolol on the development of obesity and diabetes in ob/ob mice. Gen Pharmacol. 1986;17(2):243-6. Rec#: 388. [pmid: 3516792].
35 Bale J F Jr, Fountain M T, Shaddy R. Phenylpropanolamine-associated CNS complications in children and adolescents. Am J Dis Child. 1984;138(7):683-5. Rec#: 19. [pmid: 6428218].
36 Barnes J, Mills S Y, Abbot N C, Willoughby M, Ernst E. Different standards for reporting ADRs to herbal remedies and conventional OTC medicines: face-to-face interviews with 515 users of herbal remedies. Br J Clin Pharmacol. 1998;45(5):496-500. Rec#: 439. [pmid: 9643624]. [pmcid: 1873549].
37 Baselt RC: Caffeine, in Baselt RC (ed): Drugs and Chemicals in Man (2nd). Foster City, CA, Chemical Toxicology Institute; 1982b:108–111. Rec#: 20
38 Baselt RC: Disposition of toxic drugs and chmicals in man, in AnonymousDavis, CA, Biomedical Publictions; 1982:108–111. Rec#: 433
39 Baselt RC: Ephedra, in Baselt RC (ed): Disposition of Toxic Drugs and Chemicals in Man (2nd). Foster City, CA, Chemical Toxicology Institute; 1982a: Rec#: 21
40 Battig K. Acute and chronic cardiovascular and behavioural effects of caffeine, aspirin and ephedrine. Int J Obes Relat Metab Disord. 1993;17(Suppl 1):S61-4. Rec#: 22. [pmid: 8384184].
41 Beck R A, Mercado D L, Seguin S M, Andrade W P, Cushner H M. Cardiovascular effects of pseudoephedrine in medically controlled hypertensive patients. Arch Intern Med. 1992;152(6):1242-5. Rec#: 23. [pmid: 1599353].
42 Bell D G, Jacobs I, Ellerington K. Effect of caffeine and ephedrine ingestion on anaerobic exercise performance. Med Sci Sports Exerc. 2001;33(8):1399-403. Rec#: 481. [pmid: 11474345].
43 Benichou C, Danan G, Flahault A. Causality assessment of adverse reactions to drugs--II. An original model for validation of drug causality assessment methods: case reports with positive rechallenge. J Clin Epidemiol. 1993;46(11):1331-6. Rec#: 325. [pmid: 8229111].
44 Betz J M, Gay M L, Mossoba M M, Adams S, Portz B S. Chiral gas chromatographic determination of ephedrine-type alkaloids in dietary supplements containing Ma Huang. J AOAC Int. 1997;80(2):303-15. Rec#: 28. [pmid: 9086588].
45 Bierman C W, Pierson W E, Shapiro G G. Exercise-induced asthma. Pharmacological assessment of single drugs and drug combinations. JAMA. 1975;234(3):295-8. Rec#: 29. [pmid: 1099263].
46 Blanc P D, Kuschner W G, Katz P P, Smith S, Yelin E H. Use of herbal products, coffee or black tea, and over-the-counter medications as self-treatments among adults with asthma. J Allergy Clin Immunol. 1997;100(6 Pt 1):789-91. Rec#: 30. [pmid: 9438488].
47 Blanc S, Leuenberger P, Berger J P, et al. Judgments of trained observers on adverse drug reactions. Clinical Pharmacology and Therapeutics. 1979;25(5):493-498. Rec#: 461. [pmid: 436353].
48 Blaszyk H J, Edwards W D. Sudden cardiac death in a healthy 28-year-old male truck driver abusing ephedrine. J Forensic Sci. 1997;42(1):169. Rec#: 348.
49 Blau J J. Ephedrine nephrolithiasis associated with chronic ephedrine abuse. J Urol. 1998;160(3 Pt 1):825. Rec#: 31. [pmid: 9720557].
50 Blenkinsopp A, Bradley C. Patients, society, and the increase in self medication. BMJ. 1996;312(7031):629-32. Rec#: 533. [pmid: 8608296].
51 Blumenthal M. FDA Holds Expert Advisory Committee Hearing on Ma Huang: Experts Recommend Appropriate Labeling and Warnings--Not Banning the Herb. HERBALGRAM 1996;36:21–3, 73. Rec#: 32
52 Blumenthal M, Busse WR: Ephedra, in Blumenthal M, Busse WR (eds): (Translated by) Klein S, Rister RS. Complete German Commission E Monographs: Therapeutic Guide to Herbal Medicines. Boston, MA, Integrative Medicine Communications; 125–6, 414–6, 475–6. Rec#: 33
53 Bondi M, Grugni G, Velardo A, et al. Adrenomedullary response to caffeine in prepubertal and pubertal obese subjects. Int J Obes Relat Metab Disord. 1999;23(9):992-6. Rec#: 376. [pmid: 10490807].
54 Borum M. Fulminant exacerbation of autoimmune hepatitis after the use of ma huang. American Journal of Gastroenterology. 2001;94:2430-4. Rec#: 521.
55 Boston L N. Dysuria following ephedrine therapy. Me dTimes. 1928;56:94-95. Rec#: 35.
56 Boston L N. Dysuria following ephedrine therapy. The Medical Times. 1928;56(Apr):94-95. Rec#: 302.
57 Boullata J I, Nace A M. Safety issues with herbal medicine. Pharmacotherapy. 2000;20(3):257-69. Rec#: 36. [pmid: 10730682].
58 Bowyer J F, Newport G D, Slikker W Jr, Gough B, Ferguson S A, Tor-Agbidye J. An evaluation of l-ephedrine neurotoxicity with respect to hyperthermia and caudate/putamen microdialysate levels of ephedrine, dopamine, serotonin, and glutamate. Toxicol Sci. 2000;55(1):133-42. Rec#: 37. [pmid: 10788568].
59 Bracco D, Ferrarra J M, Arnaud M J, Jequier E, Schutz Y. Effects of caffeine on energy metabolism, heart rate, and methylxanthine metabolism in lean and obese women. Am J Physiol. 1995;269(4 Pt 1):E671-8. Rec#: 375. [pmid: 7485480].
60 Bradley JG . Nonprescription drugs and hypertension. Which ones affect blood pressure? Postgrad Med 1991;89(6):195–7, 201–2. Rec#: 38
61 Bradley J G, Kallail K J, Dorsch J N, Fox J. The effects of pseudoephedrine on blood pressure in patients with controlled, uncomplicated hypertension: a randomized, double-blind, placebo-controlled trial. J Am Board Fam Pract. 1991;4(4):201-6. Rec#: 39. [pmid: 1927586].
62 Brater D C, Kaojarern S, BenetL Z, et al. Renal excretion of pseudoephedrine. Clin Pharmacol Ther. 1980;28(5):690-4. Rec#: 443. [pmid: 7438686].
63 Bray. Use and abuse of appetite-suppressant drugs in the treatment of obesity. Ann Intern Med. 1993;119(7 Pt 2):707-13. Rec#: 306. [pmid: 8363202].
64 Bray G A. Drug treatment of obesity. Baillieres Best Pract Res Clin Endocrinol Metab. 1999;13(1):131-48. Rec#: 40. [pmid: 10932681].
65 Bray G A. Evaluation of drugs for treating obesity. Obesity Research. 1995;3(Suppl 4):425S-434S. Rec#: 551. [pmid: 8697060].
66 Bright T P, Sandage B W jr, Fletcher H P. Selected cardiac and metabolic responses to pseudoephedrine with exercise. J Clin Pharmacol. 1981;21(1112 Pt 1):488-92. Rec#: 416. [pmid: 7037866].
67 Britton M G, Empey D W, John G C, McDonnell K A, Hughes D T. Histamine challenge and anterior nasal rhinometry: their use in the assessment of pseudoephedrine and triprolidine as nasal decongestants in subjects with hayfever. Br J Clin Pharmacol. 1978;6(1):51-8. Rec#: 419. [pmid: 78718]. [pmcid: 1429389].
68 Brown N J, Ryder D, Branch R A. A pharmacodynamic interaction between caffeine and phenylpropanolamine. Clin Pharmacol Ther. 1991;50(4):363-71. Rec#: 42. [pmid: 1914371].
69 Bruneton J: Phenethylamines, in Bruneton J (ed): Pharmacognosy, Phytochemistry, Medicinal Plants. Paris, France, Secausuc, NY, Lavoisier Pub;. 1996:711–15. Rec#: 43
70 Bruno A, Nolte K B, Chapin J. Stroke associated with ephedrine use. Neurology. 1993;43(7):1313-6. Rec#: 44. [pmid: 8327131].
71 Bucci L R. Selected herbals and human exercise performance. Am J Clin Nutr. 2000;72(2 Suppl):624S-36S. Rec#: 479. [pmid: 10919969].
72 Bukowiecki L, Jahjah L, Follea N. Ephedrine, a potential slimming drug, directly stimulates thermogenesis in brown adipocytes via beta-adrenoreceptors. Int J Obes. 1982;6(4):343-50. Rec#: 367. [pmid: 6290407].
73 Burkhart K K. Intravenous propranolol reverses hypertension after sympathomimetic overdose: two case reports. J Toxicol Clin Toxicol. 1992;30(1):109-14. Rec#: 46. [pmid: 1588677].
74 Bye C, Dewsbury D, Peck A W. Effects on the human central nervous system of the two isomers of ephedrine and triprolidine and their interaction. Br J Clin Pharmacol. 1974;1(1):71-78. Rec#: 47.
75 Bye C, Hill H M, Hughes D T, Peck A W. A comparison of plasma levels of L(+) pseudoephedrine following different formulations, and their relation to cardiovascular and subjective effects in man. Eur J Clin Pharmacol. 1975;8(1):47-53. Rec#: 415. [pmid: 1233202].
76 Capwell R R. Ephedrine-induced mania from an herbal diet supplement. Am J Psychiatry. 1995;152(4):647. Rec#: 48. [pmid: 7694923].
77 Caraco Y, Zylber-Katz E, Berry E M, Levy M. Caffeine pharmacokinetics in obesity and following significant weight reduction. Int J Obes Relat Metab Disord. 1995;19(4):234-9. Rec#: 380. [pmid: 7627246].
78 Case B, Oszko M A. Use of an algorithm to evaluate published reports of adverse drug reactions. Am J Hosp Pharm. 1991;48(1):121-2. Rec#: 331. [pmid: 2000870].
79 Catlin D H, Hatton C K. Use and abuse of anabolic and other drugs for athletic enhancement. Adv Intern Med. 1991;36:399-424. Rec#: 49. [pmid: 1673818].
80 CDC. Adverse events associated with ephedrine containing products. MMWR 1995;45:689–93. Rec#: 434
81 CDC. Adverse events associated with ephedrine-containing products. JAMA 1996;276(21):1711–2. Rec#: 436
82 Cetaruk E W, Aaron C K. Hazards of nonprescription medications. Emerg Med Clin North Am. 1994;12(2):483-510. Rec#: 50. [pmid: 8187693].
83 Chait L. Factors influencing the reinforcing and subjective effects of ephedrine in humans. Psychopharmacology. 1994;113:381-7. Rec#: 520. [pmid: 7871074].
84 Chance M R A. Aggregation as a factor influencing the toxicity of sympathomimetic amines in mice. J Pharmacol Exper Therapeut. 1946;87:214-19. Rec#: 51.
85 Chappel C I, Rona G, Balazs T, Gaudry R. Comparison of cardiotoxic actions of certain sympathomimetic amines. Cdn J Biochem Physiol. 1959;37:35-42. Rec#: 52.
86 Chen K K. The acute toxicity of ephedrine. Proc Soc Exper Biol Med. 1925a;22(7):404-405. Rec#: 53.
87 Chen K K. A comparative study of ephedrine, pseudoephedrine and beta-phenyl-ethylamine. Archives of Internal Medicine. 1927;39:404-411. Rec#: 407.
88 Chen K K. A comparative study of synthetic and natural ephedrines. J Pharmacol Exper Therapeutics. 1928;33:237-258. Rec#: 408.
89 Chen K K. The effect of ephedrine on experimental shock and hemorrhage. Proceedings of the Society for Experimental Biology and Medicine. 1925;22(3):203-206. Rec#: 406.
90 Chen K K. The effect of repeated administration of ephedrine. Proc Soc Exper Biol Med. 1925;22(8):568-570. Rec#: 54.
91 Chen K K, Kao C H. Ephedrine and pseudoephedrine, their isolation, constitution, isomerism, properties, derivatives and synthesis. J Am Pharmaceut Assoc. 1926;15(8):625-639. Rec#: 409.
92 Chen K K, Meek W J. A comparative study of ephedrine, tyramine and epinephrine with special reference to the circulation. J Pharmacol Exper Therapeut. 1926;28:59-76. Rec#: 411.
93 Chen K K, Meek W J. Further studies on the effect of ephedrine on the circulation. J Am Pharmaceut Assoc. 1926;28:31-57. Rec#: 410.
94 Chen K K, Poth E J. The racial difference of the mydriatic action of ephedrines, cocaine, and euphthalmine. Proc Soc Exper Biol Med. 1927;25(2):150-151. Rec#: 413.
95 Chen K K, Schmidt C F. The action of ephedrine, the active principle of the Chinese drug Ma Hung. J Pharmacol Exper Therapeut. 1924;24:339-357. Rec#: 414.
96 Chen K K, Schmidt C F. Ephedrine and related substances. Medicine. 1930;9:1-117. Rec#: 55.
97 Chen K K, Wu C-K, Henriksen E. Ephedrine homologs and isomers: Relationship between their pharmacological action and their chemical constitution and stereoisomerism. Proc Soc Exper Biol Med. 1929;26(4):348. Rec#: 56.
98 Chen K K, Wu C-K, Henriksen E. Relationship between the pharmacological action and the chemical constitution and configuration of the optical isomers of ephedrine and related compounds. J Pharmacol Exper Therapeut. 1929;36:363-400. Rec#: 57.
99 Chestnut D H, Weiner C P, Wang J P, Herrig J E, Martin J G. The effect of ephedrine upon uterine artery blood flow velocity in the pregnant guinea pig subjected to terbutaline infusion and acute hemorrhage. Anesthesiology. 1987;66(4):508-12. Rec#: 370. [pmid: 3565817].
100 Chicharro M, Zapardiel A, Bermejo E, Perez J A, Hernandez L. Direct determination of ephedrine and norephedrine in human urine by capillary zone electrophoresis. J Chromatogr. 1993;622(1):103-8. Rec#: 444. [pmid: 8120107].
101 Chua S S, Benrimoj S I. Non-prescription sympathomimetic agents and hypertension. Med Toxicol Adverse Drug Exp. 1988;3(5):387-417. Rec#: 58. [pmid: 3057328].
102 Chua S S, Benrimoj S I, Gordon R D, Williams G. A controlled clinical trial on the cardiovascular effects of single doses of pseudoephedrine in hypertensive patients. Br J Clin Pharmacol. 1989;28(3):369-72. Rec#: 59. [pmid: 2675953]. [pmcid: 1379959].
103 Clarkson P M, Thompson H S. Drugs and sport. Research findings and limitations. Sports Med. 1997;24(6):366-84. Rec#: 60. [pmid: 9421862].
104 Clemons J M, Crosby S L. Cardiopulmonary and subjective effects of a 60 mg dose of pseudoephedrine on graded treadmill exercise. J Sports Med Phys Fitness. 1993;33(4):405-12. Rec#: 61. [pmid: 8035590].
105 Clovis W L. Mania and cough syrup. J Clin Psychiatry. 1993;54(5):200. Rec#: 62. [pmid: 8509351].
106 Coates M L, Rembold C M, Farr B M. Does pseudoephedrine increase blood pressure in patients with controlled hypertension?. J Fam Pract. 1995;40(1):22-6. Rec#: 63. [pmid: 7807033].
107 Cockings J G, Brown M. Ephedrine abuse causing acute myocardial infarction. Med J Aust. 1997;167(4):199-200. Rec#: 64. [pmid: 9293266].
108 Cohen BM. A double-blind crossover study of ephedrine plus theophylline (Tedral) vs. ephedrine (Tedral without theophylline) after single and multiple dosage. New Jersey. Warner-Labert Research Institute. 1973. Report ID 950–0022. Rec#: 460
109 Colditz G A. Economic costs of obesity. Am J Clin Nutr. 1992;55(2 Suppl):503S-507S. Rec#: 543. [pmid: 1315120].
110 Colker CM, Swain MA: Acute in vivo pharmacokinetics of natural source ephedra (ma huang) vs. pure synthetic ephedrine: an open label human trial. Med Sci Sport Exerc 2002;34:s231(Abstract) Rec#: 547
111 Costello J F, May C S, Paterson J W, Pickup M E. Pharmacokinetics of ephedrine in asthmatics receiving acute and chronic treatment. Br J Clin Pharmacol. 1975;2(2):180-181. Rec#: 65.
112 Cowley G. Herbal warning. Newsweek. New York. May 6,. 1996. pages 60–8. Rec#: 496
113 Cupp M J. Herbal remedies: adverse effects and drug interactions. Am Fam Physician. 1999;59(5):1239-45. Rec#: 66. [pmid: 10088878].
114 Dalton R. Mixed bipolar disorder precipitated by pseudoephedrine hydrochloride. South Med J. 1990;83(1):64-5. Rec#: 67. [pmid: 1694045].
115 Danan G, Benichou C. Causality assessment of adverse reactions to drugs--I. A novel method based on the conclusions of international consensus meetings: application to drug-induced liver injuries. J Clin Epidemiol. 1993;46(11):1323-30. Rec#: 328. [pmid: 8229111].
116 Dangoumau J, Evreux J C, Jouglard J. [Mehtod for determination of undesirable effects of drugs]. Therapie. 1978;33(3):373-81. Rec#: 323. [pmid: 684688].
117 Dawson J K, Earnshaw S M, Graham C S. Dangerous monoamine oxidase inhibitor interactions are still occurring in the 1990s. J Accid Emerg Med. 1995;12(1):49-51. Rec#: 69. [pmid: 7640830].
118 Derreza H, Fine M D, Sadaniantz A. Acute myocardial infarction after use of pseudoephedrine for sinus congestion. J Am Board Fam Pract. 1997;10(6):436-8. Rec#: 70. [pmid: 9407485].
119 Dewsnap P, Libby G. A case of affective psychosis after routine use of proprietary cold remedy containing phenylpropanolamine. Hum Exp Toxicol. 1992;11(4):295-6. Rec#: 71. [pmid: 1354981].
120 Diaz J L. Ethnopharmacology of sacred psychoactive plants used by the Indians of Mexico. Annu Rev Pharmacol Toxicol. 1977;17:647-75. Rec#: 72. [pmid: 17363].
121 Diaz MA WTSG. Self medication with pseudo-ephedrine in a chronically depressed patient. Amer. J. Psychiat. 1979;136(9):1217–8. Rec#: 527
122 Dickerson J, Perrier D, Mayersohn M, Bressler R. Dose tolerance and pharmacokinetic studies of L (+) pseudoephedrine capsules in man. Eur J Clin Pharmacol. 1978;14(4):253-9. Rec#: 73. [pmid: 729619].
123 Dimson SB. The pressor actions of ephedrine and pseudoephedrine in man. Q J Pharmacy Pharmacol Rec#: 412
124 Dingemanse J, Guentert T, Gieschke R, Stabl M. Modification of the cardiovascular effects of ephedrine by the reversible monoamine oxidase A-inhibitor moclobemide. J Cardiovasc Pharmacol. 1996;28(6):856-61. Rec#: 74. [pmid: 8961085].
125 Dollery C: Caffeine, in Dollery C (ed): Therapeutic Drugs. New York, NY, Churchill Livingstone;. 1991:C3–C6 Rec#: 75
126 Dollery C: Ephedrine (Hydrochloride), in Dollery C (ed): Therapeutic Drugs. New York, NY, Churchill Livingstone;. 1991:E26–E29 Rec#: 76
127 Dollery C: Phenylpropanolamine (hydrochloride), in Dollery C (ed): Therapeutic Drugs. New York, NY, Churchill Livingstone;. 1991:P91–P93 Rec#: 77
128 Dollery C: Psuedophedrine hydrochloride, in Dollery C (ed): Therapeutic Drugs. New York, NY, Churchill Livingstone;. 1991:P297–P299 Rec#: 78
129 Dougherty R. Pseudo-speed: look-alikes or peashooters. NY State Journal of Medicine. 1982;1:74-75. Rec#: 524.
130 Doyle H, Kargin M. Herbal stimulant containing ephedrine has also caused psychosis. BMJ. 1996;313(7059):756. Rec#: 79. [pmid: 8819473].
131 Drew C D, Knight G T, Hughes D T, Bush M. Comparison of the effects of D-(-)-ephedrine and L-(+)-pseudoephedrine on the cardiovascular and respiratory systems in man. Br J Clin Pharmacol. 1978;6(3):221-5. Rec#: 80. [pmid: 687500]. [pmcid: 1429447].
132 Dulloo A G, Miller D S. The thermogenic properties of ephedrine/methylxanthine mixtures: animal studies. Am J Clin Nutr. 1986;43(3):388-94. Rec#: 501. [pmid: 3953478].
133 Dulloo A G. Ephedrine, xanthines and prostaglandin-inhibitors: actions and interactions in the stimulation of thermogenesis. Int J Obes Relat Metab Disord. 1993;17(Suppl 1):S35-40. Rec#: 81. [pmid: 8384187].
134 Dulloo A G. Herbal simulation of ephedrine and caffeine in treatment of obesity. International Journal of Obesity. 2002;26:590-2. Rec#: 532. [pmid: 12032740].
135 Dulloo A G, Duret C, Rohrer D, et al. Efficacy of a green tea extract rich in catechin polyphenols and caffeine in increasing 24-h energy expenditure and fat oxidation in humans. Am J Clin Nutr. 1999;70(6):1040-5. Rec#: 396. [pmid: 10584049].
136 Dulloo A G, Geissler C A, Horton T, Collins A, Miller D S. Normal caffeine consumption: influence on thermogenesis and daily energy expenditure in lean and postobese human volunteers. Am J Clin Nutr. 1989;49(1):44-50. Rec#: 374. [pmid: 2912010].
137 Dulloo A G, Miller D S. Aspirin as a promoter of ephedrine-induced thermogenesis: potential use in the treatment of obesity. Am J Clin Nutr. 1987;45(3):564-9. Rec#: 386. [pmid: 3825983].
138 Dulloo A G, Miller D S. Aspirin as a promoter of ephedrine-induced thermogenesis: potential use in the treatment of obesity. Am J Clin Nutr. 1987;45(3):564-9. Rec#: 500. [pmid: 3825983].
139 Dulloo A G, Miller D S. Ephedrine, caffeine and aspirin: “over-the-counter” drugs that interact to stimulate thermogenesis in the obese. Nutrition. 1989;5(1):7-9. Rec#: 82. [pmid: 2520262].
140 Dulloo A G, Miller D S. Thermogenic drugs for the treatment of obesity: sympathetic stimulants in animal models. Br J Nutr. 1984;52(2):179-96. Rec#: 385. [pmid: 6477859].
141 Dulloo AG, Seydoux J, Girardier L: Dietary and pharmacological effectiveness of thermogenic stimulation in obesity treatment, in Oomura et al. (ed): Progress in Obesity Research,. 1990. London, John Libbey and Company, Lt.;. 1991:135–144. Rec#: 504
142 Dulloo A G, Seydoux J, Girardier L. Peripheral mechanisms of thermogenesis induced by ephedrine and caffeine in brown adipose tissue. Int J Obes. 1991;15(5):317-26. Rec#: 364. [pmid: 1885257].
143 Dulloo A G, Seydoux J, Girardier L, Chantre P, Vandermander J. Green tea and thermogenesis: interactions between catechin-polyphenols, caffeine and sympathetic activity. Int J Obes Relat Metab Disord. 2000;24(2):252-8. Rec#: 395. [pmid: 10702779].
144 Dulloo A G, Stock M J. Ephedrine in the treatment of obesity. Int J Obes Relat Metab Disord. 1993;17(Suppl 1):S1-2. Rec#: 404. [pmid: 8384172].
145 Dunagan N, Greenleaf J E, Cisar C J. Thermoregulatory effects of caffeine ingestion during submaximal exercise in men. Aviat Space Environ Med. 1998;69(12):1178-81. Rec#: 542. [pmid: 9856543].
146 Dvorak R, Starling R D, Calles-Escandon J, Sims E A, Poehlman E T. Drug therapy for obesity in the elderly. Drugs Aging. 1997;11(5):338-51. Rec#: 84. [pmid: 9359021].
147 Dyck D J. Dietary fat intake, supplements, and weight loss. Can J Appl Physiol. 2000;25(6):495-523. Rec#: 85. [pmid: 11187927].
148 Edwards I R, Aronson J K. Adverse drug reactions: definitions, diagnosis, and management. Lancet. 2000;356(9237):1255-9. Rec#: 480. [pmid: 11072960].
149 Edwards M, Russo L, Harwood-Nuss A. Cerebral infarction with a single oral dose of phenylpropanolamine. Am J Emerg Med. 1987;5(2):163-4. Rec#: 86. [pmid: 3828020].
150 Egger G, Cameron-Smith D, Stanton R. The effectiveness of popular, non-prescription weight loss supplements. Med J Aust. 1999;171(1112):604-8. Rec#: 402. [pmid: 10721343].
151 Eldor J. Ephedrine in the initial treatment of haemorrhagic shock. Med Hypotheses. 1991;35(3):250-2. Rec#: 87. [pmid: 1943870].
152 Ellenhorn MJ, Barceloux DG: Over-the-counter products, in Ellenhorn MJ, Barceloux DG (eds): Medical Toxicology: Diagnosis and Treatment of Human Poisoning. New York, NY, Elsevier;. 1988:501–559. Rec#: 88
153 Emanueli A, Sacchetti G. An algorithm for the classification of untoward events in large scale clinical trials. Agents Actions Suppl. 1980;7:318-22. Rec#: 321. [pmid: 6941682].
154 Emmanuel N, Jones C, Lydiard R. Use of herbal products and symptoms of bipolar disorder. American Journal of Psychiatry. 1998;155:1627. Rec#: 519. [pmid: 9812133].
155 Emmanuel N P, Jones C, Lydiard R B. Use of herbal products and symptoms of bipolar disorder. Am J Psychiatry. 1998;155(11):1627. Rec#: 486. [pmid: 9812133].
156 Empey D W, Frosolono M F, Hughes D T, Perkins J G. Comparison of pseudoephedrine and triprolidine, alone and in combination in preventing nasal congestion in subjects with allergic rhinitis using nasal histamine challenge. Br J Clin Pharmacol. 1984;18(1):86-9. Rec#: 418. [pmid: 6204666]. [pmcid: 1463593].
157 Empey D W, Young G A, Letley E, et al. Dose-response study of the nasal decongestant and cardiovascular effects of pseudoephedrine. Br J Clin Pharmacol. 1980;9(4):351-8. Rec#: 417. [pmid: 6155131]. [pmcid: 1429971].
158 Escobar J I, Karno M. Chronic hallucinosis from nasal drops. JAMA. 1982;247(13):1859-60. Rec#: 488. [pmid: 6174744].
159 Fairchild M D, Alles G A. The central locomotor stimulatory acitivity and acute toxicity of the ephedrine and norephedrine isomers in mice. J Pharmacol Exp Ther. 1967;158(1):135-9. Rec#: 89. [pmid: 6054073].
160 FDA. Rockville, MD. Food and Drug Administration. 2000. Rec#: 440
161 FDA. Spontaneous adverse events reports. 2001. [web page]www.fda.gov/ohrms/dockets/ac/slides/3558sle/tsld003.htm. Rec#: 441
162 Feller D R, Malspeis L. Biotransformation of D(-)-ephedrine and L(+)-ephedrine in the rabbit, in vivo and in vitro. Drug Metab Dispos. 1977;5(1):37-46. Rec#: 90. [pmid: 13974].
163 Fillmore C M, Bartoli L, Bach R, Park Y. Nutrition and dietary supplements. Phys Med Rehabil Clin N Am. 1999;10(3):673-703. Rec#: 91. [pmid: 10516985].
164 Finer N. Present and future pharmacological approaches [obesity]. British Medical Bulletin. 1997;53(2):409-432. Rec#: 304. [pmid: 9246843].
165 Fisher C R, Veronneau S J. Herbal preparations: a primer for the aeromedical physician. Aviat Space Environ Med. 2000;71(1):45-60. Rec#: 92. [pmid: 10632130].
166 Floch A, Lagente V, Freslon J L, Blanc M, Advenier C. [Bronchomotor effects of (-) ephedrine, (+/-) ephedrine and (+) pseudoephedrine in guinea pigs]. Ann Pharm Fr. 1985;43(1):31-8. Rec#: 369. [pmid: 4062179].
167 Flordal P A, Svensson J. Hemostatic effects of ephedrine. Thromb Res. 1992;68(3):295-302. Rec#: 93. [pmid: 1471075].
168 Flurer C L, Lin L A, Satzger R D, Wolnik K A. Determination of ephedrine compounds in nutritional supplements by cyclodextrin-modified capillary electrophoresis. J Chromatogr B Biomed Appl. 1995;669(1):133-9. Rec#: 447. [pmid: 7581877].
169 Food and Drug Administration. Assessment of Public Health Risks Associated with the Use of Ephedrine Alkaloid-Containing Dietary Supplements. 2000. Report ID FDA Docket No. 00n-1200. Rec#: 94
170 Frick P A, Cohen L G, Rovers J P. Algorithms used in adverse drug event reports: a comparative study. Ann Pharmacother. 1997;31(2):164-7. Rec#: 330. [pmid: 9034415].
171 Fugh-Berman A. Clinical trials of Herbs. Primary Care - Clinics Office Pract. 1997;24(4):889-903. Rec#: 95.
172 Fugh-Berman A, Allina A. Ephedra for Weight Loss. Alternative Therapies in Women's Health. 2000;2:81-84. Rec#: 312.
173 Garcia Ortiz J T M B J. Nonpigmenting gixed exanthema from ephedrine and pseudoephedrine. Allergy. 1997;52:229-230. Rec#: 522. [pmid: 9105531].
174 Garriott J C, Simmons L M, Poklis A, Mackell M A. Five cases of fatal overdose from caffeine-containing “look-alike” drugs. J Anal Toxicol. 1985;9(3):141-3. Rec#: 96. [pmid: 4010239].
175 Gaultieri J. Cardiomyopathy in a heavy ephedrine abuser. J Toxicol Clin Toxicol. 1996;34:581-582. Rec#: 446.
176 Gilbert-Barness E, Drut R M. Association of sympathomimetic drugs with malformations. Vet Human Toxicol. 2000;42(3):168-171. Rec#: 98.
177 Gilbert EF, Matsuoka R, Bruyere H, Optiz JM: Teratogenic effect of Tedral (theophylline, ephedrine and phenobarbital) on cardiac development in chick embryos. Circulation. 1981;64:233(Abstract) Rec#: 99
178 Gill N D, Shield A, Blazevich A J, Zhou S, Weatherby R P. Muscular and cardiorespiratory effects of pseudoephedrine in human athletes. Br J Clin Pharmacol. 2000;50(3):205-13. Rec#: 100. [pmid: 10971304]. [pmcid: 2014984].
179 Gillies H, Derman W E, Noakes T D, Smith P, Evans A, Gabriels G. Pseudoephedrine is without ergogenic effects during prolonged exercise. J Appl Physiol. 1996;81(6):2611-7. Rec#: 101. [pmid: 9018513].
180 Glennon RAYBWCCTHDP. Cytotoxicity assessment of Mahuang (Ephedra) under different conditions of preparation. Toxicol Sci 2000;56:424–30. Rec#: 513
181 Glennon R A, Young R. (+)Amphetamine-stimulus generalization to an herbal ephedrine product. Pharmacol Biochem Behav. 2000;65(4):655-8. Rec#: 363. [pmid: 10899360].
182 Glick R, Hoying J, Cerullo L, Perlman S. Phenylpropanolamine: an over-the-counter drug causing central nervous system vasculitis and intracerebral hemorrhage. Case report and review. Neurosurgery. 1987;20(6):969-74. Rec#: 102. [pmid: 2956531].
183 Glidden R S, DiBona F J. Urinary retention associated with ephedrine. J Pediatr. 1977;90(6):1013-4. Rec#: 103. [pmid: 859049].
184 Goldberg LI CMDTeal. Comparative heart contractile force effects of equipressor does of several sympathomimetic amines. J Pharmacol Exp Ther 1953;108:177. Rec#: 526
185 Goldfrank L R, Hoffman R S. The cardiovascular effects of cocaine. Ann Emerg Med. 1991;20(2):165-75. Rec#: 104. [pmid: 1996800].
186 Gordiecheva N V, Shashkov V S, Kaplan E Y, et al. Effectiveness of drugs on physical exercises. Kosm Ciol Aviakosm Med. 1975;9(5):6. Rec#: 346.
187 Goto M MTTMeal. Studies on the biological action of prescriptions of Chinese medicine containing Ephedra. Jpn. J. Orient. Med. 1973;24:1–6. Rec#: 528
188 Graham T E, Spriet L L. Performance and metabolic responses to a high caffeine dose during prolonged exercise. J Appl Physiol. 1991;71(6):2292-8. Rec#: 539. [pmid: 1778925].
189 Greening G K. The effect of an antihistamine-pseudoephedrine drug on the blood pressure of moderate hypertensives. Curr Ther Res Clin Exp. 1969;11(5):252-5. Rec#: 427. [pmid: 4977395].
190 Greenway F. The safety and efficacy of pharmaceutical and herbal caffeine and ephedrine use as a weight loss agent. Obesity Reviews. 2001;2:199-211. Rec#: 314. [pmid: 12120105].
191 Greenway F, Herber D, Raum W, Herber D, Morales S. Double-blind, randomized, placebo-controlled clinical trials with non-prescription medications for the treatment of obesity. Obes Res. 1999;7(4):370-8. Rec#: 105. [pmid: 10440593].
192 Greenway F L. Clinical studies with phenylpropanolamine: a meta-analysis. Am J Clin Nutr. 1992;55(1 Suppl):203S-205S. Rec#: 307. [pmid: 1530830].
193 Greenway F L, Ryan D H, Bray G A, Rood J C, Tucker E W, Smith S R. Pharmaceutical cost savings of treating obesity with weight loss medications. Obes Res. 1999;7(6):523-31. Rec#: 398. [pmid: 10574509].
194 Griffith JD: Structure-activity relationships of several amphetamine drugs in man, in Ellinwood EH Jr., Kilbey MM (eds): Cocaine and other stimulants. New York, NY, Plenum Press; 1977:705–15. Rec#: 107
195 Gruber A J, Pope H G Jr. Ephedrine abuse among 36 female weightlifters. Am J Addict. 1998;7(4):256-61. Rec#: 108. [pmid: 9809129].
196 Grunberg E, Randall L O, Schnitzer R J. The chemotherapeutic and pharmacological properties of the l-ephedrine salt of penicillin G (Tersavin). J Pharmacol Exper Therapeut. 1949;95:336-346. Rec#: 109.
197 Gualtieri J, Harris C: Dilated cardiomyopathy in a heavy ephedrine abuser. J Toxicol (Clin Toxicol) 1996;34:581–582.(Abstract) Rec#: 110
198 Gurley BJ, Gardner SF, White LM, Wang P: Ephedrine pharmacokinetics after the ingestion of commercially available herbal preparations of ephedra sinica (Ma-huang). Pharmaceut Res 1997;14:S519(Abstract) Rec#: 111
199 Gurley B J, Gardner S F, White L M, Wang P. Ephedrine pharmacokinetics after the ingestion of nutritional supplements containing Ephedra sinica (ma huang). Therapeut Drug Monit. 1998;20(4):439-445. Rec#: 112.
200 Gurley BJ, Wang P, Gardner SF: Ephedrine alkaloid content of five commercially available herbal products containing ephedra sinica (Ma huang). Pharmaceut Res 1997;14 :S582–S582(Abstract) Rec#: 113
201 Gurley B J, Wang P, Gardner S F. Ephedrine-type alkaloid content of nutritional supplements containing Ephedra sinica (Ma huang) as determined by high performance liquid chromatography. J Pharmaceut Sci. 1998;87(12):1547-1553. Rec#: 114.
202 Gurley DJ, Gardner SF, Hubbard MA. Content versus label claims in ephedra-containing dietary supplements. Am J Healthy Syst Pharm 2000;57 Rec#: 115
203 Haffner S M, Knapp J A, Stern M P, Hazuda H P, Rosenthal M, Franco L J. Coffee consumption, diet, and lipids. Am J Epidemiol. 1985;122(1):1-12. Rec#: 381. [pmid: 4014187].
204 Hall RC, Beresford TP, Stickney SK, Nasdahl CS, Coleman JH. Psychiatric reactions produced by respiratory drugs. Psychosomatics 1985;26(7):605–8, 615–6. Rec#: 489
205 Haller C A, Benowitz N L. Adverse cardiovascular and central nervous system events associated with dietary supplements containing ephedra alkaloids. N Engl J Med. 2000;343(25):1833-8. Rec#: 116. [pmid: 11117974].
206 Han L K, Takaku T, Li J, Kimura Y, Okuda H. Anti-obesity action of oolong tea. Int J Obes Relat Metab Disord. 1999;23(1):98-105. Rec#: 393. [pmid: 10094584].
207 Hanzlick R. National Association of Medical Examiners Pediatric Toxicology (PedTox) Registry Report 3. Case submission summary and data for acetaminophen, benzene, carboxyhemoglobin, dextromethorphan, ethanol, phenobarbital, and pseudoephedrine. Am J Forensic Med Pathol. 1995;16(4):270-7. Rec#: 449. [pmid: 8599338].
208 Haseman J K. Patterns of tumor incidence in two-year cancer bioassay feeding studies in Fischer 344 rats. Fundam Appl Toxicol. 1983;3(1):1-9. Rec#: 117. [pmid: 6662302].
209 Haveson B. Herbal Appetite Suppressant and Weight Loss Composition. Patent-UC-5, 798, 101. 1998. Rec#: 338
210 Hellriegel E T, Bjornsson T D, Hauck W W. Interpatient variability in bioavailability is related to the extent of absorption: implications for bioavailability and bioequivalence studies. Clin Pharmacol Ther. 1996;60(6):601-7. Rec#: 118. [pmid: 8988062].
211 Henney JE. Food and Drug Administration, Department of Health and Human Services. Statement Before the Committee on Government Reform, U.S. House of Representatives, Washinton, DC . Mar. 25, 1999. [web page]http://www.fda.gov/ola/1999/dietary.html. Rec#: 119
212 Herridge C F, Brook M F. Ephedrine psychosis. Br Med J. 1968;2(598):160. Rec#: 120. [pmid: 5641981]. [pmcid: 1989207].
213 Hirabayashi Y, Saitoh K, Fukuda H, Mitsuhata H, Shimizu R. Coronary artery spasm after ephedrine in a patient with high spinal anesthesia. Anesthesiology. 1996;84(1):221-4. Rec#: 121. [pmid: 8572337].
214 Hirsch M S, Walter R M, Hasterlik R J. Subarachnoid hemorrhage following ephedrine and MAO inhibitor. JAMA. 1965;194(11):1259. Rec#: 485. [pmid: 5897757].
215 Hoffman BB, Lefkowitz RJ: Catecholamines, sympathomimetic drugs, and adrenergic receptors antagonists, in Hardman JG, Limbird LE, Molinoff PB, Ruddon RW, Goodman Gilman A (eds): Goodman and Gillman's The Pharmacological Basis of Therapeutics. New York, NY, Toronto, ON, McGraw Hill; 1996:199–248. Rec#: 122
216 Horn J, Anderson K. Who in America is trying to lose weight?. Ann Intern Med. 1993;119:672-676. Rec#: 467. [pmid: 8363212].
217 Horton T J, Geissler C A. Aspirin potentiates the effect of ephedrine on the thermogenic response to a meal in obese but not lean women. Int J Obes. 1991;15(5):359-66. Rec#: 123. [pmid: 1885260].
218 Horton T J, Geissler C A. Post-prandial thermogenesis with ephedrine, caffeine and aspirin in lean, pre-disposed obese and obese women. Int J Obes Relat Metab Disord. 1996;20(2):91-7. Rec#: 124. [pmid: 8646257].
219 Howard H J, Lee T P. The effect of instillations of ephedrine solution upon the eye. Proc Soc Exper Biol Med. 1927;24(7):700-702. Rec#: 421.
220 Hu S: Botanical, Agricultural, Production and Supply Aspects of Ephedra, 2000:(UnPub) Rec#: 125
221 Hu S Y. Ephedra (ma-huang) in the new Chinese materia medica. Economic Botany. 1969;23:346-351. Rec#: 505.
222 Huber GL: The benefits and risks of dietary supplements in the practice of bariatric medicine and weight management, 1999:(UnPub) Rec#: 126
223 Huber GL: Study on Dietary Supplements for Weight Loss, 2000:(UnPub) Rec#: 127
224 Hughes D T, Empey D W, Land M. Effects of pseudoephedrine in man. J Clin Hosp Pharm. 1983;8(4):315-21. Rec#: 128. [pmid: 6198336].
225 Hughes S C, Ward M G, Levinson G, et al. Placental transfer of ephedrine does not affect neonatal outcome. Anesthesiology. 1985;63(2):217-9. Rec#: 129. [pmid: 4025872].
226 Hull K M, Maher T J. Effects of L-tyrosine on mixed-acting sympathomimetic-induced pressor actions. Pharmacol Biochem Behav. 1992;43(4):1047-52. Rec#: 469. [pmid: 1475286].
227 Hull K M, Maher T J. L-tyrosine potentiates the anorexia induced by mixed-acting sympathomimetic drugs in hyperphagic rats. J Pharmacol Exp Ther. 1990;255(2):403-9. Rec#: 470. [pmid: 2243331].
228 Hull K M, Sanderson W D, Maher T J. Effect of phenylpropanolamine and related compounds on beta- adrenoceptor-induced activation of adenylyl cyclase. Life Sci. 1993;52(15):1287-94. Rec#: 468. [pmid: 8385253].
229 Hull K M, Zanzillari R, Maher T J. Comparison between phenylpropanolamine and structurally related compounds on gastric transit in the rat. Pharmacol Biochem Behav. 1993;46(2):411-4. Rec#: 471. [pmid: 8265696].
230 Hurlbut J A, Carr J R, Singleton E R, et al. Solid-phase extraction cleanup and liquid chromatography with ultraviolet detection of ephedrine alkaloids in herbal products. J AOAC Int. 1998;81(6):1121-7. Rec#: 448. [pmid: 9850573].
231 Hutchins GM. Dietary supplements containing ephedra alkaloids. N Engl J Med 2001;344(14):1095–6; discussion 1096–7. Rec#: 353
232 Hutchinson T A, Leventhal J M, Kramer M S, Karch F E, Lipman A G, Feinstein A R. An algorithm for the operational assessment of adverse drug reactions. II. Demonstration of reproducibility and validity. JAMA. 1979;242(7):633-8. Rec#: 326. [pmid: 449003].
233 Huxtable R J. The myth of beneficent nature: the risks of herbal preparations. Ann Intern Med. 1992;117(2):165-6. Rec#: 130. [pmid: 1605432].
234 hwang E J, Kan E M, Yang K S, Park S B, Kim T H. Effects of ephedrae herba extract on cellular and humoral immune responses. Korean J Pharmacog. 1990;21(3):256. Rec#: 350.
235 ICH Steering Committee. Guideline for Good Clinical Practice (ICH Harmonised Tripartite Guideline). International Conference on Harmonisation of Technical Requirements for Registration of Pharmaceuticals for Human Use (ICH). Rec#: 131
236 Insel PA: Beta-adrenergic receptors in pathophysiologic states and in clinical medicine, in Perkins JP (ed): The Beta-Adrenergic Receptors. Clifton, NJ, Humana Press; 1991:295–343. Rec#: 133
237 Insel PA, Motusky HJ: Physiologic and pharmacologic regulation of adrenergic receptors, in Insel PA (ed): Adrenergic Receptors in Man. New York, NY, Dekker; 1987:201–236. Rec#: 134
238 Ishigooka J, Yoshida Y, Murasaki M. Abuse of “BRON”: a Japanese OTC cough suppressant solution containing methylephedrine, codeine, caffeine and chlorpheniramine. Prog Neuropsychopharmacol Biol Psychiatry. 1991;15(4):513-21. Rec#: 135. [pmid: 1749828].
239 Jacobs I, Bell DG. Acute physical performance effects after ingestion of ephedrine or ephedrine combined with caffeine. 2002; Rec#: 530
240 Jacobs K M, Hirsch K A. Psychiatric complications of Ma-huang. Psychosomatics. 2000;41(1):58-62. Rec#: 136. [pmid: 10665269].
241 James LFHKEWWGCBRVJ. Sympathomimetic drug use in adolescents pesenting to a pediatric emergency department with chest pain. Journal of Toxicology-Clinical Toxicology 1998;36:321–8. Rec#: 517
242 Jawad S S, Eccles R. Effect of pseudoephedrine on nasal airflow in patients with nasal congestion associated with common cold. Rhinology. 1998;36(2):73-6. Rec#: 451. [pmid: 9695162].
243 Jequier E. Energy utilization in human obesity. Ann N Y Acad Sci. 1987;499:73-83. Rec#: 400. [pmid: 3300495].
244 Jiang M, Takesi T, Hiromichi O. Effect of ephedra sinica on liposyte lipid metabolism. Zhongguo Zhongyao Zazhi. 1999;24(5):302-4. Rec#: 339. [pmid: 12205890].
245 Jones JK: Approaches to evaluation causation of suspected drug reations, in Strom BL., Velo G (eds): Drug Epidemiology and Post-Marketing Surveillance. New York, NY, Plenum Press; 1992:103–113. Rec#: 138
246 Josefson D. Herbal stimulant causes US deaths. BMJ. 1996;312(7044):1441. Rec#: 309. [pmid: 8973222].
247 Jung R T, Shetty P S, James W P, Barrand M A, Callingham B A. Caffeine: its effect on catecholamines and metabolism in lean and obese humans. Clin Sci (Colch). 1981;60(5):527-35. Rec#: 372. [pmid: 7018802].
248 Kaberi-Otarod J, Conetta R, Kundo K K, Farkash A. Ischemic stroke in a user of Thermadrene: A case study in alternative medicine. Clin Pharmacol Ther. 2002;72:343-6. Rec#: 552. [pmid: 12235456].
249 Kalix P. The pharmacology of psychoactive alkaloids from ephedra and catha. J Ethnopharmacol. 1991;32(13):201-8. Rec#: 452. [pmid: 1881158].
250 Kalmar J M, Cafarelli E. Effects of caffeine on neuromuscular function. J Appl Physiol. 1999;87(2):801-8. Rec#: 540. [pmid: 10444642].
251 Kanai T, Nishikawa T, Satoh A, Kajita A. Cardiovascular teratogenicity of ephedrine in rats. Senten Ijo (Cong Anom). 1986;26(3):246. Rec#: 141.
252 Kandil A, Shukrallah I, Hussein L, Azmy A. Biological and chemical evaulation of ephedrine. J Drug Res (Egypt). 1983;14(1/2):119-122. Rec#: 349.
253 Kane F J Jr, Florenzano R. Psychosis accompanying use of bronchodilator compound. JAMA. 1971;215(13):2116. Rec#: 490. [pmid: 5108231].
254 Kanfer I , Dowse R , Vuma V . Pharmacokinetics of oral decongestants. Pharmacotherapy 1993;13(6 Pt 2):116S-128S; discussion 143S-146S. Rec#: 142
255 Karch F E, Lasagna L. Toward the operational identification of adverse drug reactions. Clin Pharmacol Ther. 1977;21(3):247-54. Rec#: 322. [pmid: 837643].
256 Karch S B, Green G S, Young S. Myocardial hypertrophy and coronary artery disease in male cocaine users. J Forensic Sci. 1995;40(4):591-5. Rec#: 143. [pmid: 7595294].
257 Karch SB: Ma huang and the ephedra alkaloids, in Cupp MJ (ed): Toxicology and Clinical Pharmacology of Herbal Products. Totowa, NJ, Humana Press, Inc; 2000:11–30. Rec#: 144
258 Karch SB: Synthetic stimulants <Fenfluramine, mescaline analogs>, in Karch SB (ed): The Pathology of Drug Abuse. Boca Raton, FL, CRC Press; 1993:199–218. Rec#: 145
259 Karch SB: Synthetic stimulants <Phenylpropanolamine>, in Karch SB (ed): The Pathology of Drug Abuse. Boca Raton, FL, CRC Press; 1993:165, 177–198. Rec#: 146
260 Karch S B. Comments on “ma huang toxicity” letter by Dr. Theoharides. J Clin Psychopharmacol. 1999;19(2):196-9. Rec#: 454. [pmid: 10211931].
261 Kasahara Y, HIkino H, Tsurufuji S, Watanabe M, Ohuchi K. Anti-inflammatory actions of ephedrines in acute inflammations. Planta Med. 1985;51(4):325-331. Rec#: 351. [pmid: 4070447].
262 Keld D B, Bendsen A K. [Doping--a medical problem in Denmark?]. Ugeskr Laeger. 1998;160(33):4749-53. Rec#: 147. [pmid: 9715655].
263 Kernan W N, Viscoli C M, Brass L M, et al. Phenylpropanolamine and the risk of hemorrhagic stroke. N Engl J Med. 2000;343(25):1826-32. Rec#: 148. [pmid: 11117973].
264 Kim T H, Yang K S, Hwang E Z, Park S B. Effect of ephedrae herba on the immune response in mice. Korean J Pharmacog. 1991;22(3):183-91. Rec#: 340.
265 Kimmel SE, Hutchins GM: Commentary on the article: “Adverse cardiovascular events temporally associated with Mahuang, an herbal source of ephedrine” published in Mayo Clinic Proceedings, January. 2002, (UnPub) Rec#: 478
266 Kitagawa H, Saito H. Differences in the effect of ephedrine isomers on blood pressure in rats. Jpn J Pharmacol. 1975;25(4):473-5. Rec#: 356. [pmid: 1206815].
267 Kizer K W. Intracranial hemorrhage associated with overdose of decongestant containing phenylpropanolamine. Am J Emerg Med. 1984;2(2):180-1. Rec#: 149. [pmid: 6518006].
268 Klepser TB, Klepser ME. Unsafe and potentially safe herbal therapies. Am J Health Syst Pharm 1999;56(2):125–38; quiz 139–41. Rec#: 150
269 Knight D C, Eden J A. Phytoestrogens: a short review. Maturitas. 1995;22:167-175. Rec#: 311. [pmid: 8746873].
270 Kolata G. Appetite suppressants aid obese. New York Times. New York, NY. 4,. 1992. pages 9(N), P12(L). Rec#: 466
271 Kramer M S, Leventhal J M, Hutchinson T A, Feinstein A R. An algorithm for the operational assessment of adverse drug reactions. I. Background, description, and instructions for use. JAMA. 1979;242(7):623-32. Rec#: 327. [pmid: 480646].
272 Kuczmarski R J, Flegal K M, Campbell S M, et al. Increasing prevalence of overweight among US adults. JAMA. 1994;272:205-211. Rec#: 465. [pmid: 8022039].
273 Kuitunen T, Karkkainen S, Ylitalo P. Comparison of the acute physical and mental effects of ephedrine, fenfluramine, phentermine and prolintane. Methods Find Exp Clin Pharmacol. 1984;6(5):265-70. Rec#: 152. [pmid: 6471970].
274 Kustrak D, Ramic A. Ephedra species and the alkaloids of this plants. Farmaceutski Glasnik_(_FARM. GLAS._). 1994;50(12):321-339. Rec#: 153.
275 Laitinen L A, Empey D W, Bye C, Britton M G, McDonnell K, Hughes D T. A comparison of the bronchodilator action of pseudoephedrine and ephedrine in patients with reversible airway obstruction. Eur J Clin Pharmacol. 1982;23(2):107-9. Rec#: 154. [pmid: 7140799].
276 Lake C R, Gallant S, Masson E, Miller P. Adverse drug effects attributed to phenylpropanolamine: a review of 142 case reports. Am J Med. 1990;89(2):195-208. Rec#: 155. [pmid: 2200264].
277 Lake C R, Rosenberg D B, Gallant S, Zaloga G, Chernow B. Phenylpropanolamine increases plasma caffeine levels. Clin Pharmacol Ther. 1990;47(6):675-85. Rec#: 156. [pmid: 2357862].
278 Lake C R, Tenglin R, Chernow B, Holloway H C. Psychomotor stimulant-induced mania in a genetically predisposed patient: a review of the literature and report of a case. J Clin Psychopharmacol. 1983;3(2):97-100. Rec#: 157. [pmid: 6341419].
279 Lake C Q R. CNS stimulants and the look-alike drugs. Psychiatr Clin North Am. 1984;7:689-701. Rec#: 525. [pmid: 6522308].
280 Lanctot K L, Naranjo C A. Comparison of the Bayesian approach and a simple algorithm for assessment of adverse drug events. Clin Pharmacol Ther. 1995;58(6):692-8. Rec#: 324. [pmid: 8529335].
281 Law MY, Pedersen GH, Hennen WJ, McCausland CW, Sidwell RW: Subacute toxicity study of ma-huang in mice. Fundam Appl Toxicol 1996;30:111(Abstract) Rec#: 158
282 Lee E B. Teratogenicity of the extracts of crude drugs. Saengyak Hakhoe Chi (Korean J Pharmacognosy). 1982;13:116-121. Rec#: 159.
283 Lee M K, Cheng B W, Che C T, Hsieh D P. Cytotoxicity assessment of Ma-huang (Ephedra) under different conditions of preparation. Toxicol Sci. 2000;56(2):424-30. Rec#: 160. [pmid: 10911002].
284 Lee MK, Wong YK, Che CT, Hsieh DPH: Adrenergic agonists effects and cyto-toxicity of Chinese ephedra (ma-huang) used for weight reduction. Toxicologist 1999;48:58(Abstract) Rec#: 161
285 Lefebvre R A, Surmont F, Bouckaert J, Moerman E. Urinary excretion of ephedrine after nasal application in healthy volunteers. J Pharm Pharmacol. 1992;44(8):672-5. Rec#: 450. [pmid: 1359093].
286 Lefkowitz RJ, Hoffman BB, Taylor P: Neurohumoral transmission: The autonomic and somatic motor nervous systems, in Gilman AG, Rall TW, Nies AS, Taylor P (eds): Goodman and Gilman's The Pharmacological Basis of Therapeutics. New York, NY, Toronto, ON, Pergamon Press Ltd;. 1990:89–90. Rec#: 162
287 Leung AY, Foster S: Ephedra, in Leung AY, Foster S (eds): Encyclopedia of Common Natural Ingredients Used in Foods, Drugs, and Cosmetics. New York, NY, John Wiley;. 1996:227 Rec#: 163
288 Levine B, Jones R, Klette K, Smith M L, Kilbane E. An intoxication involving BRON and verapamil. J Anal Toxicol. 1993;17(6):381-3. Rec#: 164. [pmid: 8271787].
289 Levitsky D A, Strupp B J. Direct and indirect thermogenic effects of anorectic drugs. Adv Nutr Res. 1985;7:187-201. Rec#: 165. [pmid: 3006454].
290 Li Q, Li B H. [Comparison of central stimulating effects between ephedrine and apomorphine]. Zhongguo Yao Li Xue Bao. 1991;12(5):468-71. Rec#: 365. [pmid: 1840455].
291 Liljestrand S H. The action of pseudoephedrine. I. On the isolated uterus and bladder. Chung-Kuo Sheng Li Hsueh Tsa Chih. 1929;3:249. Rec#: 343.
292 Lindahl A, Sandstrom R, Ungell A L, et al. Jejunal permeability and hepatic extraction of fluvastatin in humans. Clin Pharmacol Ther. 1996;60(5):493-503. Rec#: 166. [pmid: 8941022].
293 Lindqvist A, Jalonen J, Laitinen L A, Seppala T, Stromberg C. The effects of midazolam and ephedrine on post-exercise autonomic chronotropic control of the heart in normal subjects. Clin Auton Res. 1996;6(6):343-9. Rec#: 167. [pmid: 8985623].
294 Lindsay B D. Are serious adverse cardiovascular events an unintended consequence of the Dietary Supplement Health and Education Act of 1994?. Mayo Clin Proc. 2002;77(1):7-9. Rec#: 472. [pmid: 11888030].
295 Lin E T, Brater D C, Benet L Z. Gas-liquid chromatographic determination of pseudoephedrine and norpseudoephedrine in human plasma and urine. J Chromatogr. 1977;140(3):273-9. Rec#: 431. [pmid: 914918].
296 Ling M, Piddlesden S J, Morgan B P. A component of the medicinal herb ephedra blocks activation in the classical and alternative pathways of complement. Clin Exp Immunol. 1995;102(3):582-8. Rec#: 334. [pmid: 8536376]. [pmcid: 1553381].
297 Liu X X. [Pharmacologic action and clinical use of herbal Ephedrae]. Zhong Xi Yi Jie He Za Zhi. 1989;9(4):255-6. Rec#: 168. [pmid: 2692863].
298 Liu Y M, Sheu S J, Chiou S H, Chang H C, Chen Y P. A comparative study on commercial samples of Ephedra Herba. Planta Medica. 1993;59:376-378. Rec#: 506. [pmid: 17235993].
299 Loizou L A, Hamilton J G, Tsementzis S A. Intracranial haemorrhage in association with pseudoephedrine overdose. J Neurol Neurosurg Psychiatry. 1982;45(5):471-2. Rec#: 170. [pmid: 7086459].
300 Loosmore S, Armstrong D. Do-Do abuse. Br J Psychiatry. 1990;157:278-81. Rec#: 171. [pmid: 2224380].
301 Lowell B B, Napolitano A, Usher P, et al. Reduced adipsin expression in murine obesity: effect of age and treatment with the sympathomimetic-thermogenic drug mixture ephedrine and caffeine. Endocrinology. 1990;126(3):1514-20. Rec#: 392. [pmid: 2307116].
302 LSRO. Alternative and Traditional Models for Safety Evaluation of Food Ingredients. Prepared for: Center for Food Safety and Applied Nutrition Food and Drug Administration Department of Health and Human Services, Washington DC 20204, under FDA Contract No. 223-92-2195, Task Order #9. Bethesda, MD. Life Sciences Research Office, American Society for Nutritional Sciences. 1998. Rec#: 172
303 Lustik S J, Chhibber A K, van Vliet M, Pomerantz R M. Ephedrine-induced coronary artery vasospasm in a patient with prior cocaine use. Anesth Analg. 1997;84(4):931-3. Rec#: 174. [pmid: 9085987].
304 Lyon C C, Turney J H. Pseudoephedrine toxicity in renal failure. Br J Clin Pract. 1996;50(7):396-7. Rec#: 453. [pmid: 9015914].
305 Machii S. Pharmacological studies on the optical isomers of ephedrine and pseudoephedrine. Nippon Yakurigaku Zasshi. 1957;53:638. Rec#: 344.
306 Maertens P, Lum G, Williams J P, White J. Intracranial hemorrhage and cerebral angiopathic changes in a suicidal phenylpropanolamine poisoning. South Med J. 1987;80(12):1584-6. Rec#: 175. [pmid: 3423905].
307 Mahdihasan S. Ephedra the oldest medicinal plant with the history of an uninterrupted use. Ancient Sci Life. 1987;7(2):105-9. Rec#: 176.
308 Maitai C K. D-norpseudoephedrine as an anti-asthmatic: comparison with l-ephedrine, d-pseudoephedrine. East Afr Med J. 1975;52(6):330-2. Rec#: 425. [pmid: 1192984].
309 Mariani P J. Pseudoephedrine-induced hypertensive emergency: treatment with labetalol. Am J Emerg Med. 1986;4(2):141-2. Rec#: 310. [pmid: 3947442].
310 Martin W R, Sloan J W, Sapira J D, Jasinski D R. Physiologic, subjective, and behavioral effects of amphetamine, methamphetamine, ephedrine, phenmetrazine, and methylphenidate in man. Clin Pharmacol Ther. 1971;12(2):245-58. Rec#: 178. [pmid: 5554941].
311 Martinez F V, Badas A J, Goitia J F G, Aguirre I. Generalized dermatitis due to oral ephedrine. Contact Dermatit. 1993;29(4):215-216. Rec#: 179.
312 Marvola M. Effect of acetylated derivatives of some sympathomimetic amines on the acute toxicity, locomotor activity and barbiturate anaesthesia time in mice. Acta Pharmacol Toxicol (Copenh). 1976;38(5):474-89. Rec#: 180. [pmid: 989680].
313 Marvola M, Kivirinta R. Pharmacokinetics and locomotor activity increasing effect of ephedrine in mice. Acta Pharmacol Toxicol (Copenh). 1978;43(5):381-6. Rec#: 181. [pmid: 726903].
314 Massoudi M, Evans E, Miller D S. Thermogenic drugs for the treatment of obesity: screening using obese rats and mice. Ann Nutr Metab. 1983;27(1):26-37. Rec#: 384. [pmid: 6830140].
315 Massoudi M, Miller D S. Ephedrine, a thermogenic and potential slimming drug. Proc Nutr Soc. 1977;36(3):135A. Rec#: 182. [pmid: 601014].
316 Matsuoka R, Gilbert E F, Bruyers H Jr, Optiz J M. An aborted human fetus with truncus arteriosus communis--possible teratogenic effect of Tedral. Heart Vessels. 1985;1(3):176-8. Rec#: 183. [pmid: 3831024].
317 Matthews G, Smolinske S, White S: Ephedrine-related stroke in a teenager. J Toxicol (Clin Toxicol) 1997;35:555(Abstract) Rec#: 184
318 May C S, Paterson J W, Spiro S G, Johnson A J. Effect of intravenous injection of salbutamol in asthma. Br J Clin Pharmacol. 1975;2(6):495-501. Rec#: 185. [pmid: 1234013]. [pmcid: 1402639].
319 McCleave D J, Phillips P J, Vedig A E. Compartmental shift of potassium--a result of sympathomimetic overdose. Aust N Z J Med. 1978;8(2):180-3. Rec#: 482. [pmid: 277167].
320 McKenna D. Ma huang. INPR. 2001. Report ID Ephedra 2.1. Rec#: 508
321 McLaurin J Q, Shipman W F, Rosedale R. Oral decongestants. A double blind comparison study of the effectiveness of four sympathomimetic drugs: Objective and subjective. Laryngoscope. 1961;71:54-67. Rec#: 186. [pmid: 13774086].
322 McNamara S H. FDA Has Adequate Power and Authority to Protect the Public From Unsafe Dietary Supplements. HERBALGRAM. 1996;38:25-7. Rec#: 187.
323 Mendez M F. Mania self-induced with cough syrup. J Clin Psychiatry. 1992;53(5):173-4. Rec#: 188. [pmid: 1592847].
324 Midha K K, Cooper J K, McGilveray I J. Simple and specific electron-capture GLC assay for plasma and urine ephedrine concentrations following single doses. J Pharm Sci. 1979;68(5):557-60. Rec#: 189. [pmid: 430489].
325 Miller D K, McMahon L R, Green T A, Nation J R, Wellman P J. Repeated administration of ephedrine induces behavioral sensitization in rats. Psychopharmacology (Berl). 1998;140(1):52-6. Rec#: 190. [pmid: 9862402].
326 Miller D S. A controlled trial using ephedrine in the treatment of obesity. Int J Obes. 1986;10(2):159-60. Rec#: 191. [pmid: 3804564].
327 Miller T G. A consideration of the clinical value of ephedrine. American Journal of Medical Science. 1925;170:157-181. Rec#: 507.
328 Minimatsu S, Kobayashi Y, Kobayashi N, Juhii Y, Aburada M, Yamushita M. Acute ephedra herba and ephedrine poisoning in mice. Chudoku Kenkyu. 1991;4:143-149. Rec#: 192.
329 Mitsuya H. [Toxic psychosis due to ephedrine-containing antasthmatics--report of three cases (author's transl)]. Seishin Shinkeigaku Zasshi. 1978;80(4):155-68. Rec#: 491. [pmid: 674448].
330 Molenaar P C, Biewenga J E, Van Kempen G T, De Priester J A. Effect of ephedrine on muscle weakness in a model of myasthenia gravis in rats. Neuropharmacology. 1993;32(4):373-6. Rec#: 355. [pmid: 8497338].
331 Moolenaar M, Desmond P A, Mascord D J, Starmer G A, Tattam B, Volkerts E R. The effects of ephedrine on the development of fatigue in a prolonged driving related task. Hum Psychopharmacol Clin Exp. 1999;14(6):415-427. Rec#: 345.
332 Mores N, Campia U, Navarra P, Cardillo C, Preziosi P. No cardiovascular effects of single-dose pseudoephedrine in patients with essential hypertension treated with beta-blockers. Eur J Clin Pharmacol. 1999;55(4):251-4. Rec#: 196. [pmid: 10424315].
333 Morgan JP: Phenylpropanolamine: A Critical Analysis of Reported Adverse Reactions and Overdosage, Fort Lee, NJ, Jack K. Burgess, Inc.;. 1986: Rec#: 198
334 Morgan J P, Funderburk F R. Phenylpropanalomine and blood pressure: a review of prospective studies. Am J Clin Nutr. 1992;55(1 Suppl):206S-210S. Rec#: 463. [pmid: 1728835].
335 Morimoto I, Watanabe F, Osawa T, Okitsu T, Kada T. Mutagenicity screening of crude drugs with Bacillus subtilis rec-assay and Salmonella/microsome reversion assay. Mutat Res. 1982;97(2):81-102. Rec#: 199. [pmid: 6804865].
336 Morris H G, Rusnak S A, Selner J C, Barzens K, Barnes J. Comparative effects of ephedrine on adrenergic responsiveness in normal and asthmatic subjects. J Allergy Clin Immunol. 1978;61(5):294-302. Rec#: 200. [pmid: 205566].
337 Mortimer E A Jr. Drug toxicity from breast milk?. Pediatrics. 1977;60(5):780-1. Rec#: 201. [pmid: 917671].
338 Mueller S M, Solow E B. Seizures associated with a new combination “pick-me-up” pill. Ann Neurol. 1982;11(3):322. Rec#: 487. [pmid: 7092186].
339 Nadeau S E. Intracerebral hemorrhage and vasculitis related to ephedrine abuse. Ann Neurol. 1984;15(1):114-5. Rec#: 484. [pmid: 6712188].
340 Nadeau S E. Intracerebral hemorrhage and vasculitis related to ephedrine abuse. Ann Neurol. 1984;15(1):114-5. Rec#: 455. [pmid: 6712188].
341 Nadir A, Agrawal S, King P D, Marshall J B. Acute hepatitis associated with the use of a Chinese herbal product, ma-huang. Am J Gastroenterol. 1996;91(7):1436-8. Rec#: 202. [pmid: 8678010].
342 Nagai N. Pharm Seit 1887;32:700. Rec#: 529
343 Nakahara Y, Kikura R. Hair analysis for drugs of abuse. XIX. Determination of ephedrine and its homologs in rat hair and human hair. J Chromatogr B Biomed Sci Appl. 1997;700(12):83-91. Rec#: 456. [pmid: 9390717].
344 Namba T, Kubo M, Kanai Y, Namba K, Nishimura H, Qazilbash N A. Pharmacognostical studies of Ephedra plants Part I - The comparative histological studies on Ephedra rhizomes from Pakistan and Afghanistan and Chinese crude drugs “Ma-Hung-Gen”. Planta Med. 1976;29(3):216-25. Rec#: 203. [pmid: 948522].
345 Naranjo C A, Busto U, Sellers E M, et al. A method for estimating the probability of adverse drug reactions. Clin Pharmacol Ther. 1981;30(2):239-45. Rec#: 319. [pmid: 7249508].
346 National Academy of Sciences (NAS). National Academy of Sciences Model: Dietary Reference Intakes: A Risk Assessment Model for Establishing Upper Intake Levels for Nutrients. Washington DC. Institute of Medicine, National Academy Press (NAP). 1998. Rec#: 205
347 Nelson H S, Black J W, Branch L B, et al. Subsensitivity to epinephrine following the administration of epinephrine and ephedrine to normal individuals. J Allergy Clin Immunol. 1975;55(5):299-309. Rec#: 206. [pmid: 164490].
348 Nesheim M C. What is the research base for the use of dietary supplements?. Public Health Nutr. 1999;2(1):35-8. Rec#: 538. [pmid: 10452729].
349 Neve K A, Molinoff P B. Effects of chronic administration of agonists and antagonists on the density of beta-adrenergic receptors. Am J Cardiol. 1986;57(12):17F-22F. Rec#: 207. [pmid: 2871741].
350 Nielsen B, Atrup A, Samuelsen P, Wengholt H, Christensen N J. Effect of physical training on thermogenic responses to cold and ephedrine. Int J Obes Relat Metab Disord. 1993;17(7):383-90. Rec#: 308. [pmid: 8395473].
351 Nightingale S L. From the Food and Drug Administration. JAMA. 1996;275(20):1534. Rec#: 495. [pmid: 8940307].
352 Nightingale S L. From the Food and Drug Administration. JAMA. 1996;276(21):1710. Rec#: 502. [pmid: 8940307].
353 NIOSH. Registry of Toxic Effects of Chemical Substances, Centers for Disease Control and Prevention. Ephedrine. 1997. Rec#: 208
354 Nishikawa T, Bruyere H J Jr, Gilbert E F, Takagi Y. Potentiating effects of caffeine on the cardiovascular teratogenicity of ephedrine in chick embryos. Toxicol Lett. 1985;29(1):65-8. Rec#: 360. [pmid: 4082207].
355 Nishikawa T H J, Bruyere H J Jr, Takagi Y, Gilbert E F, Uno H. Cardiovascular teratogenicity of ephedrine in chick embryos. Toxicol Lett. 1985;29(1):59-63. Rec#: 209. [pmid: 4082206].
356 Noble R. A controlled clinical trial of the cardiovascular and psychological effects of phenylpropanolamine and caffeine. Drug Intell Clin Pharm. 1988;22(4):296-9. Rec#: 382. [pmid: 3286173].
357 NTP. Toxicology and Carcinogenesis Studies of Ephedrine Sulfate (CAS No. 134-72-5) in F344/N Rats and B6C3F1 Mice (Feed Studies) National Toxicology Program (NTP), Research Triangle Park, NC, (NTP Technical Reports Series) No. 307. 1986. Rec#: 211
358 Nuotto E. Psychomotor, physiological and cognitive effects of scopolamine and ephedrine in healthy man. Eur J Clin Pharmacol. 1983;24(5):603-9. Rec#: 212. [pmid: 6873137].
359 Nyland H. [Ephedrine, abuse and psychosis]. Tidsskr Nor Laegeforen. 1973;93(27):2027-9. Rec#: 213. [pmid: 4588006].
360 Oberman Z, Herzberg M, Jaskolka H, Harell A, Hoerer E, Laurian L. Changes in plasma cortisol, glucose and free fatty acids after caffeine ingestion in obese women. Isr J Med Sci. 1975;11(1):33-6. Rec#: 373. [pmid: 1116938].
361 Ogden J A. Congenital anomalies of the coronary arteries. Am J Cardiol. 1970;25(4):474-9. Rec#: 545. [pmid: 5438244].
362 Onuigbo M, Alikhan M. Over-the-counter sympathomimetics: a risk factor for cardiac arrhythmias in pregnancy. South Med J. 1998;91(12):1153-5. Rec#: 215. [pmid: 9853729].
363 Ooms T G, Khan S A, Means C. Suspected caffeine and ephedrine toxicosis resulting from ingestion of an herbal supplement containing guarana and ma huang in dogs: 47 cases (1997-1999). J Am Vet Med Assoc. 2001;218(2):225-9. Rec#: 216. [pmid: 11195828].
364 Oosterbaan R, Burns M J. Myocardial infarction associated with phenylpropanolamine. J Emerg Med. 2000;18(1):55-9. Rec#: 217. [pmid: 10645839].
365 Pace S: Ma huang food supplement toxicity in two adolescents. J Toxicol (Clin Toxicol) 1996;34:598(Abstract) Rec#: 218
366 Pantelis C, Hindler C G, Taylor J C. Use and abuse of khat (Catha edulis): a review of the distribution, pharmacology, side effects and a description of psychosis attributed to khat chewing. Psychol Med. 1989;19(3):657-68. Rec#: 219. [pmid: 2572026].
367 Pasquali R, Casimirri F. Clinical aspects of ephedrine in the treatment of obesity. Int J Obes Relat Metab Disord. 1993;17(Suppl 1):S65-8. Rec#: 221. [pmid: 8242128].
368 Pasquali R, Cesari M P, Besteghi L, Melchionda N, Balestra V. Thermogenic agents in the treatment of human obesity: preliminary results. Int J Obes. 1987;11(Suppl 3):23-6. Rec#: 390. [pmid: 2894367].
369 Patil P N, Tye A, Lapidus J B. A pharmacological study of the ephedrine isomers. J Pharmacol Exper Therapeut. 1965;148(2):158-168. Rec#: 422.
370 Pentel P. Toxicity of over-the-counter stimulants. JAMA. 1984;252(14):1898-903. Rec#: 368. [pmid: 6471321].
371 Pere J C, Begaud B, Haramburu F, Albin H. Computerized comparison of six adverse drug reaction assessment procedures. Clin Pharmacol Ther. 1986;40(4):451-61. Rec#: 329. [pmid: 3757408].
372 Perrota D M, Coody G, Culmo C. Adverse events associated with ephedrine-containing products: Texas, December 1993-September 1995. JAMA. 1996;276(21):1711-1712. Rec#: 224. [pmid: 8940308].
373 Peterson D I, Hardinge M G. The effect of various environmental factors on cocaine and eph edrine toxicity. J Pharm Pharmacol. 1967;19(12):810-4. Rec#: 225. [pmid: 4383648].
374 Pi-Sunyer X F. Medical hazards of obesity. Ann Intern Med. 1993;119(7 pt 2):655-660. Rec#: 464. [pmid: 8363205].
375 Pickup M E, May C S, Ssendagire R, Paterson J W. The pharmacokinetics of ephedrine after oral dosage in asthmatics receiving acute and chronic treatment. Br J Clin Pharmacol. 1976;3(1):123-34. Rec#: 226. [pmid: 973934]. [pmcid: 1428819].
376 Pickupp M E, Paterson J W. The determination of ephedrine plasma levels by a gas chromatographic method. J Pharm Pharmacol. 1974;26:561-62. Rec#: 432.
377 Pomerantz B, O'Rourke R A. The Stokes-Adams syndrome. Am J Med. 1969;46(6):941-60. Rec#: 227. [pmid: 4978920].
378 Porta M, Jick H, Habakangas J A. Follow-up study of pseudoephedrine users. Ann Allergy. 1986;57(5):340-2. Rec#: 426. [pmid: 3777533].
379 Powell T, et al. Dangers of Ma-huang. Alternative Medicine Alert. 1998;1:119. Rec#: 313.
380 Powell T, et al. Ma-huang strikes again: Ephedrine nephrolithiasis. Am J Kidney Dis. 1998;32:153-159. Rec#: 318. [pmid: 9669437].
381 Powell T, Hsu F F, Turk J, Hruska K. Ma-huang strikes again: ephedrine nephrolithiasis. Am J Kidney Dis. 1998;32(1):153-9. Rec#: 228. [pmid: 9669437].
382 Puar H S. Acute memory loss and nominal aphasia caused by phenylpropanolamine. South Med J. 1984;77(12):1604-5. Rec#: 229. [pmid: 6505775].
383 Raadstroem M, Bengtssonk J, Ederberg S, Bengtson A, Loswick A C, Bengtson J P. Effects of ephedrine on oxygen consumption and cardiac output. Acta Anaesthesiol Scand. 1995;39(8):1084-87. Rec#: 347. [pmid: 8607315].
384 Radstrom M, Bengtsson J, Ederberg S, Bengtsson A, Loswick A C, Bengtson J P. Effects of ephedrine on oxygen consumption and cardiac output. Acta Anaesthesiol Scand. 1995;39(8):1084-7. Rec#: 231. [pmid: 8607315].
385 Ramsey J J, Colman R J, Swick A G, Kemnitz J W. Energy expenditure, body composition, and glucose metabolism in lean and obese rhesus monkeys treated with ephedrine and caffeine. Am J Clin Nutr. 1998;68(1):42-51. Rec#: 232. [pmid: 9665095].
386 Rang HP, Dale MM: Pharmacology, NewYork, NY, Churchill Livingstone Inc.;. 1995: Rec#: 233
387 Read B E, Feng C T. The alleged ephedrine action of two california species of ephedra. Proc Soc Exp Biol Med. 1927;24:819-21. Rec#: 342.
388 Renwick A G. The use of an additional safety or uncertainty factor for nature of toxicity in the estimation of acceptable daily intake and tolerable daily intake values. Regul Toxicol Pharmacol. 1995;22(3):250-61. Rec#: 234. [pmid: 8837849].
389 Renwick A G, Lazarus N R. Human variability and noncancer risk assessment- An analysis of the default uncertainty factor. Regul Toxicol Pharmacol. 1998;27(1 Pt 2):3-20. Rec#: 235. [pmid: 9629592].
390 Robertson D, Frolich J C, Carr R K, et al. Effects of caffeine on plasma renin activity, catecholamines and blood pressure. N Engl J Med. 1978;298(4):181-6. Rec#: 236. [pmid: 339084].
391 Rogers P, Eftimiades M, Aunapu G, Keller M, Jones R. Lethal but legal: an over-the-counter high takes the life of a college student. People. 1996;45(20):105-109. Rec#: 462.
392 Rosene J M, Rosene J A, Koczajowski D L, Paolone V J. Decongestant effects on hemodynamics at rest, exercise, and recovery from exercise during--6 degrees of head down tilt. Aviat Space Environ Med. 1999;70(1):15-21. Rec#: 237. [pmid: 9895016].
393 Roth R P, Cantekin E I, Bluestone C D, Welch R M, Cho Y W. Nasal decongestant activity of pseudoephedrine. Ann Otol Rhinol Laryngol. 1977;86(2 pt. 1):235-42. Rec#: 428. [pmid: 322570].
394 Roxanas M G, Spalding J. Ephedrine abuse psychosis. Med J Aust. 1977;2(19):639-40. Rec#: 238. [pmid: 607100].
395 Rutstein H R. Ingestion of pseudoephedrine. Arch Otolaryngol. 1963;77:145-47. Rec#: 423. [pmid: 13990915].
396 Ryan D H. Medicating the obese patient. Endocrinol Metab Clin North Am. 1996;25(4):989-1004. Rec#: 239. [pmid: 8977057].
397 Sagara K, Oshima T, Misaki T. A simultaneous determination of norephedrine, pseudoephedrine, ephedrine and methylephedrine in Ephedrae Herba and oriental pharmaceutical preparations by ion-pair high-performance liquid chromatography. Chem Pharm Bull (Tokyo). 1983;31(7):2359-65. Rec#: 240. [pmid: 6640802].
398 Samenuk D, Link M S, Homoud M K, et al. Adverse cardiovascular events temporally associated with ma huang, an herbal source of ephedrine. Mayo Clin Proc. 2002;77(1):12-6. Rec#: 473. [pmid: 11795249].
399 Saunders A, Elliott P. Pseudoephedrine in the hypertensive patient. Australian J Hospit Pharm. 1987;17(2):150-151. Rec#: 424.
400 Sawynok J. Pharmacological rationale for the clinical use of caffeine. Drugs. 1995;49(1):37-50. Rec#: 383. [pmid: 7705215].
401 Schryver T. The buzz about ephedra and caffeine. Dietitian's Edge 2001;March Apr:30–31, 33–34. Rec#: 315
402 Schuckit M A. Ma-huang (Ephedrine) abuse and dependence. Drug Abuse Alcohol Newsl. 1996;25(5):1-4. Rec#: 337.
403 Scroggie DA, Harris M, Sakai L. Rhabdomyolysis associated with nutritional supplement use. Journal of Clinical Rheumatology_(_J. CLIN. RHEUMATOL._) 2000; Rec#: 241
404 Sever P S, Dring L G, Williams R T. The metabolism of (-)-ephedrine in man. Eur J Clin Pharmacol. 1975;9(23):193-8. Rec#: 242. [pmid: 786688].
405 Sharma AN, Cinci PM, Hoffman RS: Ma huang-induced myocardial infarction with normal coronary arteries. J Toxicol (Clin Toxicol) 2000;38:521(Abstract) Rec#: 244
406 Shenfield G M. Combination bronchodilator therapy. Drugs. 1982;24(5):414-39. Rec#: 245. [pmid: 6129123].
407 Sheu S-J. Identification by chemical analysis of the botanical sources of commercial samples of Chinese herbal drugs. Yao Wu Shih P'in Fen Hsi (J Food Drug Anal). 1997;5(4):285-294. Rec#: 246.
408 Shu H, Jin B, Yang Z. The mechanism of inhibitory action of ephedrine on the twitch response of mouse vas deferens to field stimulation. Sheng Li Hsueh Pao. 1986;38(6):583-88. Rec#: 352. [pmid: 3576238].
409 Sieb J P, Engel A G. Ephedrine: effects on neuromuscular transmission. Brain Res. 1993;623(1):167-71. Rec#: 358. [pmid: 8221087].
410 Sinsheimer J E, Dring L G, Williams R T. Species differences in the metabolism of norephedrine in man, rabbit and rat. Biochem J. 1973;136(3):763-71. Rec#: 248. [pmid: 4780698]. [pmcid: 1166013].
411 Smith D A, Perry P J. The efficacy of ergogenic agents in athletic competition. Part II: Other performance-enhancing agents. Ann Pharmacother. 1992;26(5):653-9. Rec#: 249. [pmid: 1362095].
412 Snook C, Otten M, Hassan M: Massive ephedrine overdose: Case report and toxicokinetic analysis. Vet Hum Toxicol 1992;34:335(Abstract) Rec#: 250
413 Sobal J, Marquart L F. Vitamin/mineral supplement use among athletes: a review of the literature. Int J Sport Nutr. 1994;4(4):320-34. Rec#: 537. [pmid: 7874149].
414 Sprague J E, Harrod A D, Teconchuk A L. Pharmacology and abuse potential of ephedrine. Pharm Times. 1998;64:72-80. Rec#: 251.
415 Stoessl A, Young G, Feasby T. Intracerebral haemorrhage and angiographic beading following ingestion of catecholaminergics. Stroke. 1985;16:734-6. Rec#: 514. [pmid: 4024187].
416 Stromberg C, Vanakoski J, Olkkola K T, Lindqvist A, Seppala T, Laitinen L A. Exercise alters the pharmacokinetics of midazolam. Clin Pharmacol Ther. 1992;51(5):527-32. Rec#: 252. [pmid: 1587067].
417 Swain R A, Harsha D M, Baenziger J, Saywell R M. Do pseudoephedrine or phenylpropanolamine improve maximum oxygen uptake and time to exhaustion?. Clin J Sport Med. 1997;7(3):168-73. Rec#: 253. [pmid: 9262882].
418 Tagliabue A, Terracina D, Cena H, Turconi G, Lanzola E, Montomoli C. Coffee induced thermogenesis and skin temperature. Int J Obes Relat Metab Disord. 1994;18(8):537-41. Rec#: 377. [pmid: 7951473].
419 Takaku T, Ming J, Okuda H, Maeda N. Isolation of inuslin-like substances from ephedra sinica stapf. Wakan Iyakugaku Zasshi. 1997;14(4):358-9. Rec#: 332.
420 Takayasu T, Ohshima T, Ohtsuji M, et al. False identification of urinary ephedrine as methamphetamine by gas chromatography/mass spectrometry with a DB-17 column. Nippon Hoigaku Zasshi. 1997;51(3):235-40. Rec#: 459. [pmid: 9301231].
421 Tamada M, Endo K, Hikino H. Maokonine, hypertensive principle of Ephedra roots. Planta Med. 1978;34(3):291-3. Rec#: 336. [pmid: 704697].
422 Tamada M, Endo K, Hikino H, Kabuto C. Structure of Ephedradine A, a hypotensive principle of ephedra roots. Planta Med. 1978;34:291. Rec#: 341. [pmid: 704697].
423 Tanaka M, Dohi S. [The effects of ephedrine and phenylephrine on arterial partial pressure of oxygen during one-lung ventilation]. Masui. 1994;43(8):1124-9. Rec#: 254. [pmid: 7815717].
424 Tang DH. Ephedra (‘Ma huang’). Clin Toxicol Rev 1996;18(10) Rec#: 255
425 Tashkin D P, Meth R, Simmons D H, Lee Y E. Double-blind comparison of acute bronchial and cardiovascular effects of oral terbutaline and ephedrine. Chest. 1975;68(2):155-61. Rec#: 256. [pmid: 1097203].
426 Taylor D M, O'Toole K S, Auble T E, Ryan C M, Sherman D R. The psychometric and cardiac effects of pseudoephedrine in the hyperbaric environment. Pharmacotherapy. 2000;20(9):1045-50. Rec#: 257. [pmid: 10999496].
427 Tekol Y, Tercan E, Esmaoglu A. Ephedrine enhances analgesic effect of morphine. Acta Anaesthesiol Scand. 1994;38(4):396-7. Rec#: 457. [pmid: 8067229].
428 Theoharides T C. Sudden death of a healthy college student related to ephedrine toxicity from a ma huang-containing drink. J Clin Psychopharmacol. 1997;17(5):437-9. Rec#: 258. [pmid: 9316003].
429 Tinsley J A, Watkins D D. Over-the-counter stimulants: abuse and addiction. Mayo Clin Proc. 1998;73(10):977-82. Rec#: 493. [pmid: 9787749].
430 Tinsley J A. The hazards of psychotropic herbs. Minn Med. 1999;82(5):29-31. Rec#: 259. [pmid: 10337137].
431 To L B, Sangster J F, Rampling D, Cammens I. Ephedrine-induced cardiomyopathy. Med J Aust. 1980;2(1):35-6. Rec#: 260. [pmid: 7432264].
432 Toubro S, Astrup A, Breum L, Quaade F. The acute and chronic effects of ephedrine/caffeine mixtures on energy expenditure and glucose metabolism in humans. Int J Obes Relat Metab Disord 1993;17 Suppl 3:S73–7; discussion S82. Rec#: 262
433 Traub S, Hoyek W, Hoffman R. Dietary supplements containing ephedra alkaloids. New England Journal of Medicine. 2001;344:1096. Rec#: 516. [pmid: 11291669].
434 Turner J E, Cravey R H. A fatal ingestion of caffeine. Clin Toxicol. 1977;10(3):341-4. Rec#: 264. [pmid: 862365].
435 Tyler VE: Tyler VE (ed): The Honest Herbal: A Sensible Guide to the Use of Herbs and Related Remedies. New York, NY, Pharmaceutical Products Press (PPP);. 1993:119–121. Rec#: 265
436 Ueng T H, Kang J J, Wang H W, Cheng Y W, Chiang L Y. Suppression of microsomal cytochrome P450-dependent monooxygenases and mitochondrial oxidative phosphorylation by fullerenol, a polyhydroxylated fullerene C60. Toxicol Lett. 1997;93(1):29-37. Rec#: 266. [pmid: 9381480].
437 Ueng T-H, Kang J-J, Wang H-W, Lin P-C. An overview of the toxicology of commonly used traditional Chinese medicine. Yao Wu Shih P'in Fen Hsi (J Food Drug Anal). 1997;5(4):241-264. Rec#: 267.
438 Unger D L. Blood pressure and pulse rate changes in hypertensive asthmatic patients: effects of an ephedrine compound. Ann Allergy. 1968;26(12):637-8. Rec#: 429. [pmid: 5716076].
439 United States General Accounting Office. Dietary Supplements: Uncertainties in Analyses Underlying FDA's Proposed Rule on Ephedrine Alkaloids. Washington, DC. United States General Accounting Office. 1999. Rec#: 268
440 Upton R A. Pharmacokinetic interactions between theophylline and other medication (Part I). Clin Pharmacokinet. 1991;20(1):66-80. Rec#: 269. [pmid: 1709398].
441 USDA. Dietary supplements containing ephedrine alkaloids; proposed rule. 21 CFR 111. Federal Register 1997;62(107):30677–724. Rec#: 445
442 Vahedi K, Domigo V, Amarenco P, Bousser M G. Ischaemic stroke in a sportsman who consumed MaHuang extract and creatine monohydrate for body building. J Neurol Neurosurg Psychiatry. 2000;68(1):112-3. Rec#: 270. [pmid: 10671124].
443 Van Mieghem W, Stevens E, Cosemans J. Ephedrine-induced cardiopathy. Br Med J. 1978;1(6116):816. Rec#: 271. [pmid: 638463].
444 Vanakoski J, Seppala T. Heat exposure and drugs. A review of the effects of hyperthermia on pharmacokinetics. Clin Pharmacokinet. 1998;34(4):311-22. Rec#: 273. [pmid: 9571303].
445 Vanakoski J, Stromberg C, Seppala T. Effects of a sauna on the pharmacokinetics and pharmacodynamics of midazolam and ephedrine in healthy young women. Eur J Clin Pharmacol. 1993;45(4):377-81. Rec#: 274. [pmid: 8299674].
446 Vansal S S, Feller D R. Direct effects of ephedrine isomers on human beta-adrenergic receptor subtypes. Biochem Pharmacol. 1999;58(5):807-10. Rec#: 361. [pmid: 10449190].
447 Venulet J, Ciucci A G, Berneker G C. Updating of a method for causality assessment of adverse drug reactions. Int J Clin Pharmacol Ther Toxicol. 1986;24(10):559-68. Rec#: 320. [pmid: 3781677].
448 Villas Martinez F, Badas A J, Garmendia Goitia J F, Aguirre I. Generalized dermatitis due to oral ephedrine. Contact Dermatitis. 1993;29(4):215-6. Rec#: 503. [pmid: 8281792].
449 Wahl M, Grant C, Jesperson R: Acute psychosis from a dietary weight control supplement. J Toxicol (Clin Toxicol) 2000;38:522–523. (Abstract) Rec#: 275
450 Walker R B, Fitz L D, Williams L M, Linton H Jr, Smith C C. The effect of ephedrine isomers and their oxazolidines on locomotor activity in rats. Gen Pharmacol. 1993;24(3):669-73. Rec#: 359. [pmid: 8365649].
451 Warot D, Berlin I, Aymard G, et al: Comparative pharmacodynamics and pharmacokinetics of oral and intranasal ephedrine. Fun & Clin Pharma 2000;Abstract 237–297.(Abstract) Rec#: 277
452 Warren M R, Werner H W. Acute toxicity of vasopressor amines: II. Comparative data. J Pharmacol Exper Therapeut. 1945;86:284-286. Rec#: 278.
453 Warren M R, Werner H W. The central stimulant action of some vasopressor amines. J Pharmacol Exper Therapeut. 1945;85:119-121. Rec#: 279.
454 Warren MR, Werner HW: Effect of temperature on the toxicity of some vasopressor amines. Fed Proc (FASEB) 1945;4:139(Abstract) Rec#: 280
455 Webb A A, Shipton E A. Re-evaluation of i.m. ephedrine as prophylaxis against hypotension associated with spinal anaesthesia for Caesarean section. Can J Anaesth. 1998;45(4):367-9. Rec#: 458. [pmid: 9597213].
456 Weesner K M, Denison M, Roberts R J. Cardiac arrhythmias in an adolescent following ingestion of an over-the- counter stimulant. Clin Pediatr (Phila). 1982;21(11):700-1. Rec#: 281. [pmid: 7127994].
457 Weinberger M, Bronsky E, Bensch G W, Bock G N, Yecies J J. Interaction of ephedrine and theophylline. Clin Pharmacol Ther. 1975;17(5):585-92. Rec#: 282. [pmid: 1092514].
458 Weiner I, Tilkian A G, Palazzolo M. Coronary artery spasm and myocardial infarction in a patient with normal coronary arteries: temporal relationship to pseudoephedrine ingestion. Cathet Cardiovasc Diagn. 1990;20(1):51-3. Rec#: 437. [pmid: 2344609].
459 Welling P G, Lee K P, Patel J A, Walker J E, Wagner J G. Urinary excretion of ephedrine in man without pH control following oral administration of three commercial ephedrine sulfate preparations. J Pharm Sci. 1971;60(11):1629-34. Rec#: 283. [pmid: 5133909].
460 Wellman P J, Miller D K, Livermore C L, Green T A, McMahon L R, Nation J R. Effects of (-)-ephedrine on locomotion, feeding, and nucleus accumbens dopamine in rats. Psychopharmacology (Berl). 1998;135(2):133-40. Rec#: 354. [pmid: 9497018].
461 White L M, Gardner S F, Gurley B J, Marx M A, Wang P L, Estes M. Pharmacokinetics and cardiovascular effects of ma-huang (Ephedra sinica) in normotensive adults. J Clin Pharmacol. 1997;37(2):116-22. Rec#: 284. [pmid: 9055137].
462 Whitehouse A M, Duncan J M. Ephedrine psychosis rediscovered. Br J Psychiatry. 1987;150:258-61. Rec#: 285. [pmid: 3651687].
463 WHO. Principles for the Safety Assessment of Food Additives and Contaminants in Food. World Health Organization (WHO), International Programme on Chemical Safety (IPCS), Geneva, Switz. Environmental Health Criteria No. 70. 1987. Rec#: 286
464 Wiener I T A P M. Coronary artery spasm and myocardial infarction in a patient with normal coronary arteries: temporal relationship to pseudoephedrine ingestion. Catheterization & Cardiovascular Diagnosis. 1990;20:51-3. Rec#: 518. [pmid: 2344609].
465 Wilkinson G R, Beckett A H. Absorption metabolism and excretion of the ephedrines in man. I. The influence of urinary pH and urine volume output. J Pharmacol Exp Ther. 1968;162(1):139-47. Rec#: 287. [pmid: 5656593].
466 Wilkinson G R, Beckett A H. Absorption, metabolism, and excretion of the ephedrines in man. II. Pharmacokinetics. J Pharm Sci. 1968;57(11):1933-8. Rec#: 288. [pmid: 5725924].
467 Williams R, Caldwell J, Dring L: Comparative metabolism of some amphetamines in various species, in Usdin E, Snyder S (eds): Frontiers in Catecholamine Research. New York, NY, Pergamon Press; 1973:927–932. Rec#: 289
468 Williamson D F, Pamuk E, Thun M, Flanders D, Byers T, Heath C. Prospective study of intentional weight loss and mortality in never- smoking overweight US white women aged 40–64 years. Am J Epidemiol. 1995;141(12):1128-41. Rec#: 544. [pmid: 7771451].
469 Wilson A F, Novey H S, Cloninger P, Davis J, White D. Cardiopulmonary effects of long-term bronchodilator administration. J Allergy Clin Immunol. 1976;58(1 PT. 2):204-12. Rec#: 290. [pmid: 956557].
470 Wolf H H, Schuster M A, Lanciault G. ‘Aggregation’ phenomenon and some ephedrine isomers. J Pharmaceut Sci. 1964;53:987-988. Rec#: 291.
471 Wood K A. Nasal decongestant and psychiatric disturbance. Br J Psychiatry. 1994;164(4):566-7. Rec#: 492. [pmid: 8038955].
472 Wooten M R, Khangure M S, Murphy M J. Intracerebral hemorrhage and vasculitis related to ephedrine abuse. Ann Neurol. 1983;13(3):337-40. Rec#: 438. [pmid: 6342508].
473 Xue-Jun Y, De-xiang L, Hechuan W, Yu Z. A study on the mutagenicity of 102 raw pharmaceuticals used in Chinese traditional medicine. Mutat Res. 1991;260(1):73-82. Rec#: 292. [pmid: 2027343].
474 Yacobi A, Stoll R G, Chao G C, et al. Evaluation of sustained-action chlorpheniramine-pseudoephedrine dosage form in humans. J Pharm Sci. 1980;69(9):1077-81. Rec#: 430. [pmid: 7411413].
475 Yale Hemorrhagic Stroke Project Final Study Report. The safety of phenylpropanolamine hydrochloride (PPA) used in OTC weight control and nasal decongestant drug products. 2000. Rec#: 293
476 Yates K M, O'Connor A, Horsley C A. “Herbal Ecstasy”: a case series of adverse reactions. N Z Med J. 2000;113(1114):315-7. Rec#: 294. [pmid: 10972312].
477 Yen T T, McKee M M, Bemis K G. Ephedrine reduces weight of viable yellow obese mice (Avy/a). Life Sci. 1981;28(2):119-28. Rec#: 295. [pmid: 7253810].
478 Yin P. Ephedrine-induced intracerebral hemorrhage and central nervous system vasculitis. Stroke. 1990;21:1641. Rec#: 515. [pmid: 2237962].
479 Yin P A. Ephedrine-induced intracerebral hemorrhage and central nervous system vasculitis. Stroke. 1990;21(11):1641. Rec#: 483. [pmid: 2237962].
480 Yoovathaworn K C, Sriwatanakul K, Thithapandha A. Influence of caffeine on aspirin pharmacokinetics. Eur J Drug Metab Pharmacokinet. 1986;11(1):71-6. Rec#: 296. [pmid: 3720797].
481 Yoshida T, Sakane N, Umekawa T, Kondo M. Relationship between basal metabolic rate, thermogenic response to caffeine, and body weight loss following combined low calorie and exercise treatment in obese women. Int J Obes Relat Metab Disord. 1994;18(5):345-50. Rec#: 379. [pmid: 7866480].
482 Yoshida T, Sakane N, Wakabayashi Y, Umekawa T, Kondo M. Thermogenic, anti-obesity effects of bofu-tsusho-san in MSG-obese mice. Int J Obes Relat Metab Disord. 1995;19(10):717-22. Rec#: 394. [pmid: 8589765].
483 Young R, Gabryszuk M, Glennon R A. (-)Ephedrine and caffeine mutually potentiate one another's amphetamine- like stimulus effects. Pharmacol Biochem Behav. 1998;61(2):169-73. Rec#: 357. [pmid: 9738532].
484 Young R, Glennon R A. Discriminative stimulus properties of (-)ephedrine. Pharmacol Biochem Behav. 1998;60(3):771-5. Rec#: 494. [pmid: 9738532].
485 Yuan D, Komatsu K, Cui Z, Kano Y. Pharmacological properties of traditional medicines. XXV. Effects of ephedrine, amygdalin, glycyrrhizin, gypsum and their combinations on body temperature and body fluid. Biol Pharm Bull. 1999;22(2):165-71. Rec#: 362. [pmid: 10077436].
486 Zaacks S M, Klein L, Tan C D, Rodriguez E R, Leikin J B. Hypersensitivity myocarditis associated with ephedra use. J Toxicol Clin Toxicol. 1999;37(4):485-9. Rec#: 297. [pmid: 10465246].
487 Zahn K A, Li R L, Purssell R A. Cardiovascular toxicity after ingestion of “herbal ecstacy”. J Emerg Med. 1999;17(2):289-91. Rec#: 298. [pmid: 10195489].
488 Zeisel S H. Is there a metabolic basis for dietary supplementation?. Am J Clin Nutr. 2000;72(2 Suppl):507S-11S. Rec#: 299. [pmid: 10966915].
489 Zgourides G D, Warren R, Englert M E. Ephedrine-induced thermogenesis as an adjunct to cognitive restructuring and covert conditioning: a proposal for treatment of obese individuals. Percept Mot Skills. 1989;69(2):563-72. Rec#: 401. [pmid: 2813003].
490 Zhang J, Tian Z, Lou Z C. Simultaneous determination of six alkaloids in Ephedrae herba by high performance liquid chromatography. Planta Med. 1988;54(1):69-71. Rec#: 300. [pmid: 17265209].
491 Zhang J S, Tian Z, Lou Z C. Quality evaluation of twelve species of Chinese Ephedra (ma-huang). Chung Kuo Yao Li Hsueh Pao (Acta Pharmacologica Sinica). 1993;22:419-425. Rec#: 301.