# Evidence Tables

Evidence Tables Antioxidants For Cancer Prevention/Treatment

Evidence Tables Antioxidants For Cancer Prevention/Treatment

[image]
[image]
First Author Year | Trial name
| Study Design
| Quality
| Population | Interventions
| Comorbidities | Arm Dosage Data | | Sample Size | | Summary of Results
Blot 1993 | Named trial: Linxian (General Population Trial) RCT | 1 | Placebo | n Entered: | N/D | Statistical pooling performed: Death: relative risk at 5.25 years follow-up
| Jadad Score: 2 | | Placebo for 5.25 Years | n Analyzed: | 3679
| Population: N/D | 2 | Niacin | n Entered: | N/D
| Comorbidities: N/D | | 40 mg orally for 5.25 Years | n Analyzed: | 3701
| | | Multi-vitamin
| | | Multi-vitamin orally for 5.25 Years
| | 3 | Vitamin C | n Entered: | N/D
| | | 120 mg orally for 5.25 Years | n Analyzed: | 3694
| | | Multi-vitamin
| | | Multi-vitamin orally for 5.25 Years
| | 4 | Vitamin C | n Entered: | N/D
| | | 120 mg orally for 5.25 Years | n Analyzed: | 3703
| | | Multi-vitamin
| | | Multi-vitamin orally for 5.25 Years
| | 5 | Vitamin E | n Entered: | N/D
| | | 30 mg orally for 5.25 Years | n Analyzed: | 3691
| | | Multi-vitamin
| | | Multi-vitamin orally for 5.25 Years
| | 6 | Vitamin C | n Entered: | N/D
| | | 120 mg orally for 5.25 Years | n Analyzed: | 3699
| | | Vitamin E
| | | 30 mg orally for 5.25 Years
| | | Multi-vitamin
| | | Multi-vitamin orally for 5.25 Years
| | 7 | Vitamin C | n Entered: | N/D
| | | 120 mg orally for 5.25 Years | n Analyzed: | 3705
| | | Vitamin E
| | | 30 mg orally for 5.25 Years
| | | Multi-vitamin
| | | Multi-vitamin orally for 5.25 Years
[image]
[image]
[image]
[image]
[image]
[image]
[image]
[image]
[image]
[image]
[image]
[image]
First Author Year | Trial name
| Study Design
| Quality
| Population | Interventions
| Comorbidities | Arm Dosage Data | | Sample Size | | Summary of Results
Taylor 1994 Study B | Named trial: Linxian (General Population Trial) RCT | 1 | Placebo | n Entered: | N/D | Statistical pooling performed: New tumor: relative risk at 5.25 years follow-up
| | | Placebo for 5.25 Years | n Analyzed: | 3679
| Jadad Score: 2 | 2 | Niacin | n Entered: | N/D
| | | 40 mg orally for 5.25 Years | n Analyzed: | 3701
| | | Multi-vitamin
| Population: N/D | | Multi-vitamin orally for 5.25 Years
| Comorbidities: N/D | 3 | Vitamin C | n Entered: | N/D
| | | 120 mg orally for 5.25 Years | n Analyzed: | 3694
| | | Multi-vitamin
| | | Multi-vitamin orally for 5.25 Years
| | 4 | Vitamin C | n Entered: | N/D
| | | 120 mg orally for 5.25 Years | n Analyzed: | 3703
| | | Multi-vitamin
| | | Multi-vitamin orally for 5.25 Years
| | 5 | Vitamin E | n Entered: | N/D
| | | 30 mg orally for 5.25 Years | n Analyzed: | 3691
| | | Multi-vitamin
| | | Multi-vitamin orally for 5.25 Years
| | 6 | Vitamin C | n Entered: | N/D
| | | 120 mg orally for 5.25 Years | n Analyzed: | 3699
| | | Vitamin E
| | | 30 mg orally for 5.25 Years
| | | Multi-vitamin
| | | Multi-vitamin orally for 5.25 Years
| | 7 | Vitamin C | n Entered: | N/D
| | | 120 mg orally for 5.25 Years | n Analyzed: | 3705
| | | Vitamin E
| | | 30 mg orally for 5.25 Years
| | | Multi-vitamin
| | | Multi-vitamin orally for 5.25 Years
[image]
[image]

N/D = not described