# References

1 IOM (Institute of Medicine); Dietary Reference Intakes for Vitamin C, Vitamin E, Selenium, and Carotenoids. Washington, DC: National Academy Press; 2000.
2 Block G, Levine M. Vitamin C: a new look. Ann Intern Med. 1991;114:909-10. [pmid: 2014955].
3 Young V R, Newberne P M. Vitamins and cancer prevention: issues and dilemmas. Cancer. 1981;47(suppl 5):1226-40. [pmid: 7237379].
4 Halliwell B. Free radicals, antioxidants, and human disease: curiosity, cause or consequence?. Lancet. 1994;344:721-24. [pmid: 7915779].
5 Uddin S, Ahmad S. Antioxidants protection against cancer and other human diseases. Compr Ther. 1995;21(1):41-5. [pmid: 7697981].
6 van Poppel G, van den Berg H. Vitamins and cancer. Cancer Lett. 1997;114(12):195-202. [pmid: 9103291].
7 van Zandwijk N, Pastorino U, de Vries N. Chemoprevention of cancer. Eur Respir J. 1993;6(3):322-4. [pmid: 8472818].
8 Overvad K, Diamant B, Holm L, Holmer G, Mortensen S A, Stender S. Coenzyme Q10 in health and disease. Eur J Clin Nutr. 1999;53(10):764-70. [pmid: 10556981].
9 Hattersley JG. Coenzyme Q10 and cancer. J Orthomol Med. 1996;11. 2:111–2.
10 Pepping J. Coenzyme Q10. Am J Health Syst Pharm. 1999;56(6):519-21. [pmid: 10192685].
11 Li B, Taylor P R, Li J Y, et al. Linxian nutrition intervention trials: design, methods, participant characteristics, and compliance. Ann Epidemiol. 1993;3:577-85. [pmid: 7921303].
12 Taylor P R, Li B, Dawsey S M, et al. Prevention of esophageal cancer: the nutrition intervention trials in Linxian, China. Linxian Nutrition Intervention Trials Study Group Cancer Res. 1994;54(suppl 7):2029s-2031s.
13 Schulz K F, Chalmers I, Hayes R J, Altman D G. Empirical evidence of bias. Dimensions of methodological quality associated with estimates of treatment effects in controlled trials. JAMA. 1995;273(5):408-12. [pmid: 7823387].
14 Jadad A R, Moore R A, Carroll D, et al. Assessing the quality of reports of randomized clinical trials: is blinding necessary?. Control Clin Trials. 1996;17(1):1-12. [pmid: 8721797].
15 Moher D, Pham B, Jones A, et al. Does the poor quality of reports of randomized trials exaggerate estimates of intervention effectiveness reported in meta-analyses. Lancet. 1998;352(9128):609-613. [pmid: 9746022].
16 SAS Institute. SAS/STAT [computer program]. Version 8. Cary, NC: SAS Institute Inc.; 1999.
17 Microsoft Excel for Windows 2000 [computer program]. Redmond, WA: Microsoft Corporation; 2000.
18 Stata Statistical Software: Release 6.0 [computer program]. Version 6.0. College Station, TX: Stata Corporation; 1999.
19 DerSimonian R, Laird N. Meta-analysis in clinical trials. Controlled Clinical Trials. 1986;7(3):177-188. [pmid: 3802833].
20 Hedges LV, Olkin I; Statistical Methods for Meta-Analysis. San Diego, CA: Academic Press, Inc.; 1985.
21 Begg C B, Mazumdar M. Operating characteristics of a rank correlation test for publication bias. Biometrics. 1994;50(4):1088-1101. [pmid: 7786990].
22 Egger M, Davey Smith G, Schneider M, Minder C. Bias in meta-analysis detected by a simple, graphical test. BMJ. 1997;315(7109):629-634. [pmid: 9310563]. [pmcid: 2127453].
23 Albanes D, Virtamo J, Rautalahti M, et al. Pilot study: The US-Finland lung cancer prevention trial. J Nutr Growth Cancer. 1986;3:207-14.
24 Albanes D, Heinonen O P, Taylor P R, et al. Alpha-Tocopherol and beta-carotene supplements and lung cancer incidence in the alpha-tocopherol, beta-carotene cancer prevention study: effects of base-line characteristics and study compliance. J Natl Cancer Inst. 1996;88(21):1560-70. [pmid: 8901854].
25 Albanes D, Malila N, Taylor P R, et al. Effects of supplemental alpha-tocopherol and beta-carotene on colorectal cancer: results from a controlled trial (Finland). Cancer. Causes Control. 2000;11(3):197-205. [pmid: 10782653].
26 Blot W. Preventing cancer by disrupting progression of precancerous lesions. J Natl Cancer. Inst. 2000;92(23):1868-9. [pmid: 11106670].
27 Creagan E T, Moertel C G, O'Fallon J R, et al. Failure of high-dose vitamin C (ascorbic acid) therapy to benefit patients with advanced cancer: a controlled trial. N Engl J Med. 1979;301(13):687-90. [pmid: 384241].
28 Creagan, E T, Moertel, C G, Schutt A J, and O'Connell M J. Vitamin-c (ascorbic-acid) therapy of pre-terminal cancer-patients. [abstract]. Proc Am Assoc Cancer Res. 79;20:355.
29 Gogos C A, Ginopoulos P, Salsa B, Apostolidou E, Zoumbos N C, Kalfarentzos F. Dietary omega-3 polyunsaturated fatty acids plus vitamin E restore immunodeficiency and prolong survival for severely ill patients with generalized malignancy: a randomized control trial. Cancer. 1998;82(2):395-402. [pmid: 9445198].
30 Heinonen O P, Albanes D, Virtamo J, et al. Prostate cancer and supplementation with alpha-tocopherol and beta-carotene: incidence and mortality in a controlled trial. J Natl Cancer Inst. 1998;90:414-15. [pmid: 9521160].
31 Lamm D, Riggs D R, Shriver J S, vanGilder P F, Rach J F, DeHaven J I. Megadose vitamins in bladder cancer: a double-blind clinical trial. J Urol. 1994;151(1):21-6. [pmid: 8254816].
32 Li J, Taylor P, Li B, et al. Nutrition intervention trials in Linxian, China: multiple vitamin/mineral supplementation, cancer incidence, and disease-specific mortality among adults with esophageal dysplasia. J Natl Cancer Inst. 1993;85(18):1492-8. [pmid: 8360932].
33 Moertel C G, Fleming T R, Creagan E T, Rubin J, O'Connell M J, Ames M M. High-dose vitamin C versus placebo in the treatment of patients with advanced cancer who have had no prior chemotherapy: a randomized double-blind comparison. N Engl J Med. 1985;312(3):137-41. [pmid: 3880867].
34 MRC/BHF Heart Protection Study Collaborative group. MRC/BHF Heart Protection Study of antioxidant vitamin supplementation in 20536 high-risk individuals: a randomised placebo-controlled trial. Lancet. 2002;360:23-33. [pmid: 12114037].
35 Ascorbic acid does not cure cancer. Nutr Rev. 1985; 43(5): 146–7.
36 Poulter J M, White W F, Dickerson J W. Ascorbic acid supplementation and five year survival rates in women with early breast cancer. Acta Vitaminol Enzymol. 1984;6(3):175-82. [pmid: 6524577].
37 Rautalahti M T, Virtamo J R, Taylor P R, et al. The effects of supplementation with alpha-tocopherol and beta-carotene on the incidence and mortality of carcinoma of the pancreas in a randomized, controlled trial. Cancer. 1999;86(1):37-42. [pmid: 10391561].
38 Virtamo J, Edwards B K, Virtanen M, et al. Effects of supplemental alpha-tocopherol and beta-carotene on urinary tract cancer: incidence and mortality in a controlled trial (Finland). Cancer Causes Control. 2000;11(10):933-9. [pmid: 11142528].
39 Alpha-Tocopherol B-CCPSG. The effects of vitamin E and beta-carotene on the incidence of lung cancer and other cancers in male smokers. N Engl J Med. 1994;330:1029-35. [pmid: 8127329].
40 Blot W, Li J Y, Taylor P R, et al. Nutrition intervention trials in Linxian, China: supplementation with specific vitamin/mineral combinations, cancer incidence, and disease-specific mortality in the general population. J Natl Cancer Inst. 1993;85(18):1483-92. [pmid: 8360931].
41 Pauling L, Moertel C. A proposition: megadoses of vitamin C are valuable in the treatment of cancer. Nutr Rev. 1986;44(1):28-32. [pmid: 3951764].
42 Creagan E T, Moertel C G. Vitamin C therapy of advanced cancer. N Engl J Med. 1979;301(25):1399. [pmid: 503177].
43 Dawsey S M, Wang G Q, Taylor P R, et al. Effects of vitamin/mineral supplementation on the prevalence of histological dysplasia and early cancer of the esophagus and stomach: results from the Dysplasia Trial in Linxian, China. Cancer Epidemiol Biomarkers Prev. 1994;3(2):167-72. [pmid: 8049639].
44 Heinonen O P, Albanes D, Virtamo J, et al. Prostate cancer and supplementation with alpha-tocopherol and beta-carotene: incidence and mortality in a controlled trial. J Natl Cancer Inst. 1998;90:414-15. [pmid: 9521160].
45 Varis K, Taylor P R, Sipponen P, et al. Gastric cancer and premalignant lesions in atrophic gastritis: a controlled trial on the effect of supplementation with alpha-tocopherol and beta-carotene. The Helsinki Gastritis Study Group. Scand J Gastroenterol. 1998;33(3):294-300. [pmid: 9548624].
46 Li B, Taylor P R, Li J Y, et al. Linxian nutrition intervention trials: design, methods, participant characteristics, and compliance. Ann Epidemiol. 1993;3:577-85. [pmid: 7921303].
47 Greenberg E R, Baron J A, Tosteson T D, et al. A clinical trial of antioxidant vitamins to prevent colorectal adenoma. N Engl J Med. 1994;331:141-47. [pmid: 8008027].
48 Hofstad B, Almendingen K, Vatn M, et al. Growth and recurrence of colorectal polyps: a double -blind, three-year intervention with calcium and antioxidants. Digestion. 1998;59:148-56. [pmid: 9586828].
49 McKeown-Eyssen G, Holloway C, Jazmaji V, Bright-See E, Dion P, Bruce W R. A randomized trial of vitamins C and E in the prevention of recurrence of colorectal polyps. Cancer Res. 1988;48(16):4701-5. [pmid: 3293777].
50 Roncucci L, Di Donato P, Carati L, et al. Antioxidant vitamins or lactulose for the prevention of the recurrence of colorectal adenomas. Colorectal Cancer Study Group of the University of Modena and the Health Care District 16. Dis Colon Rectum. 1993;36(3):227-34. [pmid: 8449125].
51 Roncucci L, Ponz de Leon M. Antioxidant vitamins or lactulose as chemopreventive agents for colorectal cancer. In: Waldron K, Johnson I, Fenwick G, eds. Food and Cancer Prevention: Chemical and Biological Aspects. Cambridge, UK: Royal Society of Cambridge; 1993:p.147–150.
52 Malila N, Virtamo J, Virtanen M, Albanes D, Tangrea J A, Huttunen J K. The effect of alpha-tocopherol and beta-carotene supplementation on colorectal adenomas in middle-aged male smokers. Cancer Epidemiol Biomarkers Prev. 1999;8(6):489-93. [pmid: 10385137].
53 DeCosse J J, Miller H H, Lesser M L. Effect of wheat fiber and vitamins C and E on rectal polyps in patients with familial adenomatous polyposis. J Natl Cancer Inst. 1989;81(17):1290-7. [pmid: 2549261].
54 Bussey H J, DeCosse J J, Deschner E E, et al. A randomized trial of ascorbic acid in polyposis coli. Cancer. 1982;50(7):1434-9. [pmid: 7049351].
55 Zaridze D, Evstifeeva T, Boyle P. Chemoprevention of oral leukoplakia and chronic esophagitis in an area of high incidence of oral and esophageal cancer. Ann Epidemiol. 1993;3(3):225-34. [pmid: 8275193].
56 Zullo A, Rinaldi V, Hassan C, et al. Ascorbic acid and intestinal metaplasia in the stomach: a prospective, randomized study. Aliment Pharmacol Ther. 2000;14(10):1303-9. [pmid: 11012475].
57 Mackerras D, Irwig L, Simpson J M, et al. Randomized double-blind trial of beta-carotene and vitamin C in women with minor cervical abnormalities. Br J Cancer. 1999;79(910):1448-53. [pmid: 10188889].
58 Cahill R J, O'Sullivan K R, Mathias P M, Beattie S, Hamilton H, O'Morain C. Effects of vitamin antioxidant supplementation on cell kinetics of patients with adenomatous polyps. Gut. 1993;34(7):963-7. [pmid: 8344584]. [pmcid: 1374235].
59 Zullo A, Rinaldi V, Hassan C, et al. Ascorbic acid and intestinal metaplasia in the stomach: a prospective, randomized study. Aliment Pharmacol Ther. 2000;14(10):1303-9. [pmid: 11012475].
60 Liede K, Hietanen J, Saxen L, et al. Long-term supplementation with alpha-tocopherol and beta-carotene and prevalence of oral mucosal lesions in smokers. Oral Dis. 1998;4(2):78-83. [pmid: 9680894].
61 Schroder F H, Kranse R, Dijk M A, et al. Tertiary prevention of prostate cancer by dietary intervention: results of a randomised, double blind, placebo controlled, cross-over study. European Urology. 2000;37(2 suppl):24. [pmid: 10828684].
62 Correa P, Fontham E T, Bravo J C, et al. Chemoprevention of gastric dysplasia: randomized trial of antioxidant supplements and anti-helicobacter pylori therapy. J Natl Cancer Inst. 2000;92(23):1881-8. [pmid: 11106679].
63 Liede K, Hietanen J, Saxen L, et al. Long-term supplementation with alpha-tocopherol and beta-carotene and prevalence of oral mucosal lesions in smokers. Oral Dis. 1998;4(2):78-83. [pmid: 9680894].
64 Schroder F H, Kranse R, Dijk M A, et al. Tertiary prevention of prostate cancer by dietary intervention: results of a randomised, double blind, placebo controlled, cross-over study. European Urology. 2000;37(2 suppl):24. [pmid: 10828684].
65 McAuley L, Pham B, Tugwell P, Moher D. Does the inclusion of the grey literature influence estimates of intervention effectiveness reported in meta-analyses?. Lancet. 2000;356:1228-1231. [pmid: 11072941].