# Appendix D

RAND EPC, CAM Project

Quality Review Form, Topic = ANTIOXIDANT

Article ID:____ Reviewer:________________

First Author: _______________________________________

(Last Name Only)

Study Number: ___of____Description:___________________

(Enter ‘1of 1’ if only one) (if more than one study)

1. Design: (Circle one)
RCT | | 1
CCT | | 2
Other | | 3 (STOP)
(If not RCT or CCT, change study design on cover sheet and STOP)
2 What topic(s) does the study report on? (check all that apply)
Vitamin C | | □
Vitamin E | | □
Co-Q10 | | □
None of the above | | □ (STOP)
2. What condition(s) does the study report on? (circle one)
Cardiovascular | | 1
Cancer | | 2
Both | | 3
None | | 4 (STOP)
3. Is the study described as randomized? (circle one)
Yes | | 1
No | | 2
4. If the study was randomized, was method of randomization appropriate? (circle one)
Yes | | 1
No | | 2
Method not described | | 8
Not applicable | | 9
5. Is the study described as: (circle one)
Double blind | | 1
Single blind, patient | | 2
Single blind, outcome assessment | | 3
Open | | 4
Blinding not described | | 8
Not applicable | | 9
6. If reported, was the method of double blinding appropriate? (circle one)
Yes | | 1
No | | 2
Double blinding method not described | | 8
Not applicable | | 9
7. If study was randomized, did the method of randomization provide for concealment of allocation? (circle one)
Yes | | 1
No | | 2
Concealment not described | | 8
Not applicable | | 9
8. Are withdrawals (W) and dropouts (D) described? (circle one)
Yes, reason described for all W and D | | 1
Yes, reason described for some W and D | | 2
Not described | | 8
Not applicable | | 9
9. Is this a cross-over study design? (circle one)
Yes | | 1
No | | 2
Not described | | 8
10. Does the study population include a purposefully selected group of individuals chosen because they have any of the following characteristics? (check all that apply)
Race:
| African-American | □ (01)
| Asian | □ (02)
| Hispanic | □ (03)
Gender:
| Male | □(04)
| Female | □ (05)
Age:
| Children (under 18) | □ (06)
| Elderly (over 65) | □ (07)
Miscellaneous:
| Smokers | □ (08)
Other:
| (Enter code: ____ ____, ____ ____, ____ ___, ____ ____, ____ ____ )
None of the above | | □ (97)
11. Does the study population include a purposefully selected group of individuals chosen because they have any of the following comorbidities? (enter code or circle)
Code: ____ ____, ____ ____, ____ ___, ____ ____, ____ ____
Not applicable | | 99
12. Does the study population include a purposefully selected group of individuals chosen because they have any of the following predisposing factors? (enter code or circle)
Code: ____ ____, ____ ____, ____ ___, ____ ____, ____ ____
Not applicable | | 99
13. If this study is from a larger trial, please note the name of original trial. (circle one or enter code)
ADMT | | □ (01)
ATBC | | □ (02)
CGPPP | | □ (03)
CHAOS | | □ (04)
GISSI/GIZZI | | □ (05)
HOPE | | □ (06)
MRC/BHF | | □ (07)
PHS II | | □ (08)
SPACE | | □ (09)
SUVIMAX | | □ (10)
WHI | | □ (11)
WHS | | □ (12)
Code: ____ ____
Not from a larger trial | | □ (99)
Patient Characteristics - CARDIOVASCULAR
14. What type of cardiovascular disease did the study report on? (check all that apply and/or add code)
CAD | | π (01)
CVA/TIA | | ρ (02)
PVD | | ρ (03)
CHF | | ρ (04)
Angina | | ρ (05)
Code: ____ ____
____ ____
____ ____
____ ____
Not Applicable | | ρ (99)
15. What was the severity of the disease?
Enter code: ____ ____ (enter 99 if not applicable)
Patient Characteristics - CANCER
16. What type of cancer did the study report on? (check all that apply and/or add code)
Breast | | ρ (01)
Lung | | ρ (02)
Prostate | | ρ (03)
Oral | | ρ (04)
Cervix | | ρ (05)
Gastric | | ρ (06)
Colon | | ρ (07)
Code: ____ ____
____ ____
____ ____
____ ____
Not Applicable | | 99
17. What was the severity of the disease? (check all that apply and/or add code)
Pre-cancerous | | ρ (01)
Localized | | ρ (02)
Metastatic | | ρ (03)
Other code: ____ ____
Not Applicable | | 99
If the study has a control/usual care arm, enter that data in arm 1. Otherwise, enter data for the groups in order of first mention.

Arm 1 of Description

18. What type of arm is this? (circle one)
Placebo | 1
Usual care | 2
Primary Antioxidant | 3
Other active treatment | 4
19. What was the sample size in this arm?
___ ___ ___ , ___ ___ ___ | ___ ___ ___ , ___ ___ ___
Entering | Completing
(Enter 999,999 if not reported.)

20. Intervention

Intervention | Daily Dose | Units | | Route of administration | Duration | Units
1 _______ | _______ | ________ | taken | _________ | _________ | ________
2 _______ | _______ | ________ | taken | _________ | _________ | ________
3 _______ | _______ | ________ | taken | _________ | _________ | ________
4 _______ | _______ | ________ | taken | _________ | _________ | ________
Enter code | Enter a number | 1. μg | | 1. PO | Enter a number | 1. Hour | 8. Mean Year
| | 2. mg | | 2. IV | | 2. Day | 9. Median Year
| 998. ND | 3. gm | | 8. ND | 998. ND | 3. Week | 10. Maximum Month
| 999. NA | 4. IU | | 9. NA | 999. NA | 4. Month | 11. Minimum Month
| | 8. ND | | | | 5. Year | 12. Maximum Year
| | 9. NA | | | | 6. Mean Month | 13. Minimum Year
| | | | | | 7. Median Month | 98. ND
| | | | | | | 99. NA

Arm 2 of Description

18. What type of arm is this? (circle one)
Placebo | 1
Usual care | 2
Primary Antioxidant | 3
Other active treatment | 4
19. What was the sample size in this arm?
___ ___ ___ , ___ ___ ___ | ___ ___ ___ , ___ ___ ___
Entering | Completing
(Enter 999,999 if not reported.)

20. Intervention

Intervention | Daily Dose | Units | | Route of administration | Duration | Units
1 _______ | _______ | ________ | taken | _________ | _________ | ________
2 _______ | _______ | ________ | taken | _________ | _________ | ________
3 _______ | _______ | ________ | taken | _________ | _________ | ________
4 _______ | _______ | ________ | taken | _________ | _________ | ________
Enter code | Enter a number | 1. μg | | 1. PO | Enter a number | 1. Hour | 8. Mean Year
| | 2. mg | | 2. IV | | 2. Day | 9. Median Year
| 998. ND | 3. gm | | 8. ND | 998. ND | 3. Week | 10. Maximum Month
| 999. NA | 4. IU | | 9. NA | 999. NA | 4. Month | 11. Minimum Month
| | 8. ND | | | | 5. Year | 12. Maximum Year
| | 9. NA | | | | 6. Mean Month | 13. Minimum Year
| | | | | | 7. Median Month | 98. ND
| | | | | | | 99. NA

Arm 3 of Description

18. What type of arm is this? (circle one)
Placebo | 1
Usual care | 2
Primary Antioxidant | 3
Other active treatment | 4
19. What was the sample size in this arm?
___ ___ ___ , ___ ___ ___ | ___ ___ ___ , ___ ___ ___
Entering | Completing
(Enter 999,999 if not reported.)

20. Intervention

Intervention | Daily Dose | Units | | Route of administration | Duration | Units
1 _______ | _______ | ________ | taken | _________ | _________ | ________
2 _______ | _______ | ________ | taken | _________ | _________ | ________
3 _______ | _______ | ________ | taken | _________ | _________ | ________
4 _______ | _______ | ________ | taken | _________ | _________ | ________
Enter code | Enter a number | 1. μg | | 1. PO | Enter a number | 1. Hour | 8. Mean Year
| | 2. mg | | 2. IV | | 2. Day | 9. Median Year
| 998. ND | 3. gm | | 8. ND | 998. ND | 3. Week | 10. Maximum Month
| 999. NA | 4. IU | | 9. NA | 999. NA | 4. Month | 11. Minimum Month
| | 8. ND | | | | 5. Year | 12. Maximum Year
| | 9. NA | | | | 6. Mean Month | 13. Minimum Year
| | | | | | 7. Median Month | 98. ND
| | | | | | | 99. NA

Arm 4 of Description

18. What type of arm is this? (circle one)
Placebo | 1
Usual care | 2
Primary Antioxidant | 3
Other active treatment | 4
19. What was the sample size in this arm?
___ ___ ___ , ___ ___ ___ | ___ ___ ___ , ___ ___ ___
Entering | Completing
(Enter 999,999 if not reported.)

20. Intervention

Intervention | Daily Dose | Units | | Route of administration | Duration | Units
1 _______ | _______ | ________ | taken | _________ | _________ | ________
2 _______ | _______ | ________ | taken | _________ | _________ | ________
3 _______ | _______ | ________ | taken | _________ | _________ | ________
4 _______ | _______ | ________ | taken | _________ | _________ | ________
Enter code | Enter a number | 1. μg | | 1. PO | Enter a number | 1. Hour | 8. Mean Year
| | 2. mg | | 2. IV | | 2. Day | 9. Median Year
| 998. ND | 3. gm | | 8. ND | 998. ND | 3. Week | 10. Maximum Month
| 999. NA | 4. IU | | 9. NA | 999. NA | 4. Month | 11. Minimum Month
| | 8. ND | | | | 5. Year | 12. Maximum Year
| | 9. NA | | | | 6. Mean Month | 13. Minimum Year
| | | | | | 7. Median Month | 98. ND
| | | | | | | 99. NA

Outcomes

21. Type of outcomes measured:

Enter the code for each outcome measured.
____ ____
____ ____
____ ____
____ ____
____ ____
____ ____
____ ____
____ ____
____ ____
____ ____
____ ____
____ ____

Evaluation

22. When, relative to the start of the intervention, were outcomes reported?

Enter the number and letters in the appropriate box

| Number | Unit
1^st^ follow-up
2^nd^ follow-up
3^rd^ follow-up
4^th^ follow-up
5^th^ follow-up
6^th^ follow-up
Additional follow-ups:

Use the following abbreviations for units:

MI | minute
HR | hour
DY | day
WK | week
MO | month
YR | year
YRMN | mean for year
YRME | median for year
YRMX | maximum for year
YRMI | minimum for year
MOMN | mean for month
MOME | median for month
MOMX | maximum for month
MOMI | minimum for month
ND | not described
NA | not applicable

23. Is there a sub-group analysis? (circle one)
Yes | 1
No | 2
If yes, code | _____ _____ _____ _____
| _____ _____ _____ _____
| _____ _____ _____ ____