# Appendix C

Article# Antioxidant RAND EPC [underlined: Reviewers]: [underlined: Assigned on]:

Screener Alternative Medicine ___________ mm/dd/yy

_____________ mm/dd/yy

[article author, title, journal, date, vol, pages]

1. Data Source: Circle One
Article | 1
Abstract of article | 2
Conference proceeding | 3
Other (Specify_____________________) | 4
2. What topic does the article study: Check all that apply
Vitamin C | π
Vitamin E | π
Co-Enzyme Q10 | π
Other (Specify______________________) | π(STOP)
Unclear | π
3. Condition(s) and/or disease(s) studied in article: Check all that apply
Cancer | π
Cardiovascular Disease | π
No condition/disease | π(STOP)
Other (Specify_____________________) | π(STOP)
Unclear | π
4. Subject Population: Check all that apply
Human | π
In vitro / In vivo | π(STOP)
Animal | π(STOP)
Other (Specify_____________________) | π(STOP)
Unclear | π
5. Article Type: Check all that apply
Historical/Descriptive/System/Bkgrd | π
Review/Meta-analysis | π
Pharmacological | π
Clinical Study
Trial | π
Cohort | π
Other clinical study | π
Other (Specify_____________________) | π
Unclear | π
6. How is the intervention being used in the study? Circle One
Treatment | 1
Primary prevention | 2
Secondary prevention | 3
Adjunct to conventional treatment | 4
Other (Specify______________________) | 5
Unclear | 6
7. Language of Article: Circle One
English | 1
Foreign | 2

Abstract:

NOTES: