# Appendix B. Search Methodologies

## Coenzyme Q10 And Cancer Prevention/Treatment Search Methodology

SEARCH #1 (PERFORMED 11/16/01)

DATABASES SEARCHED/TIME PERIOD COVERED:

MEDLINE | 1966-2001/Dec W2
MANTIS | 1880-2001/Aug
Allied & Complementary Medicine | 1984-2001/Dec
CancerLit | 1975-2001/Oct
CAB HEALTH | 1983-2001/Oct
TGG Health&Wellness DB | 1976-2001/Nov W1
Biosis Previews | 1969-2001/Nov W2
EMBASE | 1974-2001/Nov W2
Social SciSearch | 1972-2001/Nov W3
SciSearch Cited Ref Sci | 1990-2001/Nov W3
SciSearch Cited Ref Sci | 1974-1989/Dec
ELSEVIER BIOBASE | 1994-2001/Nov W2

SEARCH STRATEGY:

ubiquinone OR ubidecarenone OR coenzyme q10 OR co-enzyme q10 OR coenzyme q 10 OR co-enzyme q 10 OR coenzyme q-10 OR co-enzyme q-10

AND

neoplasms(exploded) from Medline OR malignant neoplastic disease(exploded) from Embase OR cancer* in title or subject heading field from all other databases (exception - In CancerLit the terms for cancer were omitted and just the total of “coenzyme q-10” terms were used”)

AND

Human

TOTAL NUMBER OF ITEMS RETRIEVED: 176

## Vitamin C And Cancer Prevention/Treatment Search Methodology

SEARCH #2a (PERFORMED 11/27/01)

DATABASES SEARCHED/TIME PERIOD COVERED:

MEDLINE | 1966-2001/Dec W4
MANTIS | 1880-2001/Aug
Allied & Complementary Medicine | 1984-2001/Dec
CancerLit | 1975-2001/Oct
CAB HEALTH | 1983-2001/Oct
TGG Health&Wellness DB | 1976-2001/Nov W2
Biosis Previews | 1969-2001/Nov W3
EMBASE | 1974-2001/Nov W3
Social SciSearch | 1972-2001/Nov W4
SciSearch Cited Ref Sci | 1990-2001/Nov W4
SciSearch Cited Ref Sci | 1974-1989/Dec
ELSEVIER BIOBASE | 1994-2001/Nov W4

SEARCH STRATEGY:

ascorbic acid(exp loded)from Medline, Embase OR ascorbic acid from all other databases OR dehydroascorbic acid* OR ascorbate OR vitamin c OR antiscorbutic vitamin* OR cevitamic acid*

AND

neoplasms(exploded) from Medline OR malignant neoplastic disease(exploded) from Embase OR (cancer OR neoplasm*) in subject heading field from BIOSIS OR cancer* in title or subject heading field from all other databases OR neoplasm* from all other databases (exception - in CancerLit the terms for cancer were omitted and just the total of the “vitamin c” terms were used)

AND

(prevention OR preventive OR therapy OR therapeutic OR treatment) in title,subject heading fields

AND

human

TOTAL NUMBER OF ITEMS RETRIEVED: 1987

SEARCH #2b (PERFORMED 11/7/01)

DATABASES SEARCHED:

Cochrane Library

SEARCH STRATEGY:

vitamin c OR ascorbic acid OR ascorbate OR antiscorbutic vitamin OR cevitamic acid OR dehydroascorbic acid

AND

neoplasms(exploded)

TOTAL NUMBER OF ITEMS RETRIEVED:

The Cochrane Controlled Trials Register (CENTRAL/CCTR) References - 92

## Vitamin E And Cancer Prevention/Treatment Search Methodology

SEARCH #3a (PERFORMED 12/13/01)

DATABASES SEARCHED/TIME PERIOD COVERED:

MEDLINE | 1966-2001/Jan W1
MANTIS | 1880-2001/Oct
Allied & Complementary Medicine | 1984-2001/Jan
CancerLit | 1975-2001/Oct
CAB HEALTH | 1983-2001/Oct
TGG Health&Wellness DB | 1976-2001/Nov W4
Biosis Previews | 1969-2001/Dec W2
EMBASE | 1974-2001/Dec W2
Social SciSearch | 1972-2001/Dec W3
SciSearch Cited Ref Sci | 1990-2001/Dec W3
SciSearch Cited Ref Sci | 1974-1989/Dec
ELSEVIER BIOBASE | 1994-2001/Dec W2

SEARCH STRATEGY:

Vitamin e (exploded) from Medline OR vitamin e OR alpha tocopherol* OR D1 alpha tocopherol* OR d alpha tocopherol OR rrr alpha tocopherol* OR all rac alpha tocopherol*

AND

neoplasms(exploded) from Medline OR malignant neoplastic disease(exploded) from Embase OR (cancer OR neoplasm*) in subject heading field from BIOSIS OR cancer* in title or subject heading field from all other databases OR neoplasm* from all other databases (exception - in CancerLit the terms for cancer were omitted and just the total of the “vitamin e” terms were used)

AND

(prevention OR preventive OR therapy OR therapeutic OR treatment) in title,subject heading fields

AND

human

TOTAL NUMBER OF ITEMS RETRIEVED: 1990

SEARCH #3b (PERFORMED 12/19/01)

DATABASES SEARCHED/TIME PERIOD COVERED:

Cochrane Library 1922-2001

SEARCH STRATEGY:

vitamin-e

AND

neoplasms (exploded) OR cancer*

TOTAL NUMBER OF ITEMS RETRIEVED:

Database of Abstracts of Reviews of Effectiveness

Abstracts of quality assessed systematic reviews: 1

The Cochrane Controlled Trials Register (CENTRAL/CCTR) References: 112

## Co Q10 Synonyms + Cancer Search Methodology

SEARCH #4 (PERFORMED 1/18/02)

DATABASES SEARCHED/TIME PERIOD COVERED:

MEDLINE | 1966-2002/JAN W3
MANTIS | 1880-2001/Oct
Allied & Complementary Medicine | 1984-2001/Feb
CancerLit | 1975-2001/Oct
CAB HEALTH | 1983-2001/Dec
TGG Health&Wellness DB | 1976-2002/Dec W5
Biosis Previews | 1969-2002/Jan W2
EMBASE | 1974-2002/Jan W2
Social SciSearch(R) | 1972-2002/Jan W3
SciSearch Cited Ref Sci | 1990-2002/Jan W3
SciSearch Cited Ref Sci | 1974-1989/Dec
ELSEVIER BIOBASE | 1994-2002/Jan W2

SEARCH STRATEGY:

ubidecarenon? OR isoprostane? OR f2(2w)isoprostane?

AND

neoplasms(exploded) from Medline, Embase OR cancer* in title or subject heading field OR neoplasm* from all other databases (exception - in CancerLit the terms for cancer were omitted)

AND

human

TOTAL NUMBER OF ITEMS RETRIEVED: 127