# Appendix A. Acknowledgments

## Reviewers

We gratefully acknowledge the following individuals who reviewed the initial draft of this report and provided us with constructive feedback. Acknowledgments are made with the explicit statement that this does not constitute endorsement of the report.

- Jeffrey Blumberg, PhD, FACN, CNS
- Nutrition Research Center on Aging
- Tufts University
- Boston, MA

- Julie Buring, ScD
- Brigham and Women's Hospital
- Harvard Medical School
- Boston, MA

- Rebecca Costello, PhD
- Office of Dietary Supplements
- National Institutes of Health
- Bethesda, MD

- David Golde, MD
- Memorial Sloan-Kettering Cancer Center
- New York, NY

- Michael Hawkins, MD
- Washington Cancer Institute
- Washington, DC

- Ishwarlal Jialal, MD, PdD
- UCD Medical Center
- University of California, Davis
- Sacramento, CA

- Martin Kendall, MD, FRCP
- Department of Medicine
- Queen Elizabeth Hospital
- Birmingham, United Kingdom

- David Leaf, MD
- Department of Medicine
- VA Greater Los Angeles Medical Center
- Los Angeles, CA

- Ralph Moss, PhD
- The Moss Reports
- State College, PA

- Alex Sevanian, MD
- Department of Molecular Pharmacology and Toxicology
- University of Southern California
- Los Angeles, CA

## Technical Expert Panel

We wish to acknowledge the work of our technical expert panel:

- Betty L. Chang, DNSc, FNP-C, FAAN Professor, School of Nursing University of California, Los Angeles Los Angeles, CA
- Seigward-Markus Elsas, MD
- Clinical Fellow in Neurophysiology
- University of California, Los Angeles
- Los Angeles, CA

- Glenn Clark, DDS
- School of Dentistry
- University of California, Los Angeles
- Los Angeles, CA

- Deborah Glik, Ph.D.
- Associate Professor, School of Public Health University of California, Los Angeles
- Los Angeles, CA

- Michael Goldstein, PhD
- Professor, School of Public Health
- University of California, Los Angeles
- Los Angeles, CA

- Eric Hurwitz, DC, PhD
- Assistant Professor, Department of Epidemiology,
- School of Public Health, University of California
- Los Angeles, CA

- Ka Kit Hui, MD, FACP
- Director, UCLA Center for East-West Medicine
- University of California Los Angeles, CA

- Simon Mills, MA, MCPP, FNIMH
- Director for the Center of Complementary
- Medicine University of Exeter
- Exeter, England

- Lakshmi C. Mishra, BIMS, M Pharm, PhD
- Professor of Research
- Southern California University of Health Science
- Whittier, CA

- Shri K. Mishra, MD, MS, Doctor of Ayurveda
- Professor of Neurology and Coordinator
- Integrative Medicine
- USC School of Medicine
- USC Keck School of Medicine
- Los Angeles, CA

- Lucy Postolov, LAc Postolova Acupuncture Group
- Los Angeles, CA

- David Riley, MD
- Clinical Associate Professor
- University of North West Medical School,
- Director, Integrative Medicine Research
- Santa Fe, NM

- Betsy B. Singh, PhD
- Dean of Research
- Southern California University of Health Sciences
- Whittier, CA

- George Solomon, MD
- Professor Emeritus, UCLA School of Medicine,
- Dept. of Psychiatry and Biobehavioral Medicine
- University of California
- Los Angeles, CA

- Hitoshi Tomizawa, MD
- Director, Japanese Executive Medical Services,
- Cedars-Sinai Medical Center
- Los Angeles, CA

- Xiao-Ping Xu, LAc
- Burns and Allen Research Institute
- Cedars Sinai Medical Center
- Los Angeles CA