# References

1 Kohn LT, Corrigan JM, Donaldson MS, editors. To err is human: building a safer health system. Washington DC: National Academy Press; 2000.
2 Rosness R, Hakonsen G, Steiro T, et al. The vulnerable robustness of high reliabilty organisations: a case study report from an offshore oil production platform. In: http://webster.iot.ntnu.no/ fag/1049/faginformasjon/; 2001.
3 Reason J. Human error. Cambridge: Cambridge University Press; 1990.
4 Berwick D M. Developing and testing changes in delivery of care. Ann Intern Med. 1998;128(8):651-6. [pmid: 9537939].
5 Zimmerman P G. More RNs mean better care… “Do staffing levels influence drug errors? The jury's out,”. Nurs Spectr. 2000;13(23):13.
6 Barr D A. The effects of organizational structure on primary care outcomes under managed care. Ann Intern Med. 1995;122(5):353-9. [pmid: 7847647].
7 California Medical Association. Report on the medical insurance feasibility study. Sutton, CA: California Medical Association; 1977.
8 Brennan T A, Leape L L, Laird N M, et al. Incidence of adverse effects and negligence in hospitalized patients. N Engl J Med. 1991;324:370-376. [pmid: 1987460].
9 Thomas E J, Studdert D M, Burstin H R, et al. Incidence and types of adverse events and negligent care in Utah and Colorado. Med Care. 2000;38:261-271. [pmid: 10718351].
10 Brennan T A. Reporting of errors: how much should the public know?. Effect Clin Pract. 2000;3:298-299.
11 Gawande A, Thoma E, Zinner M, et al. The incidence and nature of surgical adverse events in Colorado and Utah. Surgery. 1999;126(1):66-75. [pmid: 10418594].
12 Fischer G, Fetters M D, Munro A P, et al. Adverse events in primary care identified from a risk-management database. J Fam Pract. 1997;45:40-46. [pmid: 9228913].
13 Leape L L, Bates D W, Cullen D J, et al. Systems analysis of adverse drug events. JAMA. 1995;274:35-43. [pmid: 7791256].
14 Shojania KG, Duncan BW, McDonald KM, et al. Making healthcare safer: a critical analysis of patient safety practices Evidence Report/Technology Assessment No. 43 AHRQ publication 01-E058. Rockville, MD: Agency for Healthcare Research and Quality 2001.
15 Levy BS, Wegman DH. Occupational health: recognizing and preventing work-related disease and injury. Philadelphia, PA: Lippincott Williams & Wilkins; 2000.
16 Edwards J R, Scully J A, Brtek M D. The nature and outcomes of work: a replication and extension of interdisciplinary work-design research. J Appl Psychol. 2000;85(6):860-868. [pmid: 11125651].
17 Demerouti E, Bakker A B, Nachreiner F, et al. A model of burnout and life satisfaction amongst nurses. J Adv Nurs. 2000;32(2):454-64. [pmid: 10964195].
18 Demerouti E, Bakker A B, Nachreiner F, et al. The job demands-resources model of burnout. J App Psychol. 2001;86(3):499-512.
19 Taris T W. The mutual effects between job resources and mental health: a prospective study among Dutch youth. Genet Soc Gen Psychol Monogr. 1999;125(4):433-50. [pmid: 10570822].
20 Poole C J, Harrington J M, Aw T C, et al. Guidance on standards of health for clinical health care workers. Occup Med (Oxford). 2002;52(1):17-24.
21 Reid W H. Recognizing and dealing with impaired clinicians, Part 1: Recognition and reporting. J Med Prac Manage. 2001;17(2):97-9.
22 Boisaubin E V, Levine R E. Identifying and assisting the impaired physician. Am J Med Sci. 2001;322(1):31-6. [pmid: 11465244].
23 Evans O, Steptoe A. The contribution of gender-role orientation, work factors and home stressors to psychological well-being and sickness absence in male- and female-dominated occupational groups. Soc Sci Med. 2002;54(4):481-92. [pmid: 11848269].
24 Anonymous. Doing what counts for patient safety: federal actions to reduce medical errors and their impact. Washington, DC: Quality Interagency Coordination Task Force.; 2000.
25 Haddon W. A logical framework for categorizing highway safety phenomena and activity. J Trauma. 1972;12:197-207.
26 Thomas E J, Lipsitz S R, Studdert D M, et al. The reliability of medical record review for estimating adverse event rates. Ann Intern Med. 2002;136(11):812-6. [pmid: 12044129].
27 Weeks W B, Mills P D, Dittus R S, et al. Using an improvement model to reduce adverse drug events in VA facilities. Jt Comm J Qual Improv. 2001;27(5):243-54. [pmid: 11367772].
28 Halm EA, Lee C, Chassin M. How is volume related to quality in health care? A systematic review of the literature: Institute of Medicine; 2000.
29 Petrosino A, Boruch R F, Rounding C, et al. The Campbell Collaboration Social, Psychological, Educational and Criminological Trials Register (C2-SPECTR) to facilitate the preparation and maintenance of systematic reviews of social and educational interventions. Evaluation and Research in Education. 2000;14(34):206-219.
30 Woolsen RF. Statistical Methods for the Analysis of Biomedical Data. New York: John Wiley and Sons; 1987.
31 Harris R P, Helfand M, Woolf S H, et al. Current methods of the third U.S. Preventive Services Task Force. Am J Prev Med. 2001;20(3S):21-35. [pmid: 11306229].
32 Briss P A, Zaza S, Pappaionou M, et al. Developing an evidence-based Guide to Community Preventive Services - methods. Am J Prev Med. 2000;18(1S):35-43. [pmid: 10806978].
33 Anonymous. Levels of Evidence and Grades of Recommendations. In: Centre for Evidence Based Medicine: http://www.minervation.com/cebm/documents/levels_cebm_23nov99.rtf 2002.
34 West S, King V, Carey TS, et al. Systems to rate the strength of scientific evidence. Evidence report/technology assessment no. 47 (prepared by the Research Triangle Institute - University of North Carolina evidence-based practice center under contract no. 290-97-0011). AHRQ publication no. 02-E016. Rockville, MD: Agency for Healthcare Research and Quality; 2002.
35 Cook DJ, Mulrow CD, R.B. H. Systematic reviews: synthesis of best evidence for clinical decisions. Ann Intern Med 1997;126:(5):376–80
36 Cochrane Collaboration Secretatiat. The Cochrane manual. Oxford, UK: The Cochrane Library; 2002.
37 Tierney W M, Overhage J M, McDonald C J. A plea for controlled trials in medical informatics. J Am Med Inform Assoc. 1994;1(4):353-5. [pmcid: 116217]. [pmid: 7719821].
38 Sackett D L, Wennberg J E. Choosing the best research design for each question. BMJ. 1997;315:1636. [pmid: 9448521].
39 Heathfield H, Pitty D, Hanka R. Evaluating information technology in health care: barriers and challenges. BMJ. 1998;316:1959-61. [pmid: 9641938].
40 Leape L L, Berwick D M, Bates D W. What practices will most improve safety? Evidence-based medicine meets patient safety. JAMA. 2002;288(4):501-7. [pmid: 12132984].
41 Shojania K G, Duncan B W, McDonald K M, et al. Safe but sound: patient safety meets evidence-based medicine. JAMA. 2002;288(4):508-13. [pmid: 12132985].
42 Aiken L H, Sloane D M, Lake E T, et al. Organization and outcomes of inpatient AIDS care. Med Care. 1999;37(8):760-772. [pmid: 10448719].
43 Bond C A, Raehl C L, Pitterle M E, et al. Health care professional staffing, hospital characteristics, and hospital mortality rates. Pharmacotherapy. 1999;19(2):130-8. [pmid: 10030762].
44 Hartz A J, Kuhn E M, Pulido J. Prestige of training programs and experience of bypass surgeons as factors in adjusted patient mortality rates. Med Care. 1999;37(1):93-103. [pmid: 10413397].
45 Howard S K, Gaba D M, Tish K J, et al. Anesthesia crisis resource management training: teaching anesthesiologists to handle critical incidents. Aviat Space Environ Med. 1992;63:763-70. [pmid: 1524531].
46 Amaravadi R K, Dimick J B, Pronovost P J, et al. ICU nurse-to-patient ratio is associated with complications and resource use after esophagectomy. Intensive Care Med. 2000;26(12):1857-62. [pmid: 11271096].
47 Lichtig L K, Knauf R A, Milholland D K. Some impacts of nursing on acute care hospital outcomes. J Nurs Adm. 1999;29(2):25-33. [pmid: 10029799].
48 Anderson R A, Hsieh P, Su H. Resource allocation and resident outcomes in nursing homes: comparisons between the best and worst. Res Nurs Health. 1998;21(4):297-313. [pmid: 9679807].
49 Blegen M A, Goode C J, Reed L. Nurse staffing and patient outcomes. Nurs Res. 1998;47(1):43-50. [pmid: 9478183].
50 Shortell S M, Zimmerman J E, Rousseau D M, et al. The performance of intensive care units: does good management make a difference?. Med Care. 1994;32(5):508-25. [pmid: 8182978].
51 Flood SD, Diers D. Nurse staffing, patient outcome and cost. Nurs Manage 1988;19:(5):34–5, 38–9, 42–3.
52 Needleman J, Buerhaus P, Mattke S, et al. Nurse-staffing levels and the quality of care in hospitals. N Engl J Med. 2002;346(22):1715-1722. [pmid: 12037152].
53 Dimick J B, Swoboda S M, Provonost P J, et al. Effect of nurse-to-patient ratio in the intensive care unit on pulmonary complications and resource use after hepatectomy. Am J Crit Care. 2001;10(6):376-382. [pmid: 11688604].
54 Pronovost P J, Dang D, Dorman T, et al. Intensive care unit nurse staffiing and the risk for complications after abdominal aortic surgery. Effect Clin Pract. 2001;4:199-206.
55 Tarnow-Mordi W O, Hau C, Warden A, et al. Hospital mortality in relation to staff workload: a 4-year study in an adult intensive-care unit. Lancet. 2000;356(9225):185-9. [pmid: 10963195].
56 Blegen M A, Vaughn T. A multisite study of nurse staffing and patient occurrences. Nurs Econ. 1998;16(4):196-203. [pmid: 9748985].
57 Kovner C, Gergen P J. Nurse staffing levels and adverse effects following surgery in US hospitals. Image J Nurs Sch. 1998;30(4):315-321. [pmid: 9866290].
58 American Nurses Association. Implementing nursing's report card: a study of RN staffing, length of stay and patient outcomes. Washington, DC: American Nurses Publishing; 1997.
59 Tutuarima J A, de Haan R J, Limburg M. Number of nursing staff and falls: a case-control study on falls by stroke patients in acute-care settings. J Adv Nurs. 1993;18(7):1101-5. [pmid: 8370900].
60 Joint Commission for Accreditation of Healthcare Organizations. Health Care at the Crossroads: Strategies for Addrssing the Evolving Nursing Crisis; 2002.
61 Bolton L B, Jones D, Aydin C E, et al. A response to California's mandated nursing ratios. J Nurs Sch. 2001;33(2):179-84.
62 Sochalski J. Quality of care, nurse staffing, and patient outcomes. Policy Politics Nurs Prac. 2001;2(1):9-18.
63 Hunt J, Hagen S. Nurse to patient ratios and patient outcomes. Nurs Times. 1998;94(45):63-6. [pmid: 9919285].
64 Hartz A J, Kranauer H, Kuhn E M, et al. Hospital characteristics and mortality rates. N Engl J Med. 1989;321:1720-1725. [pmid: 2594031].
65 Fridkin S K, Pear S M, Williamson T H, et al. The role of understaffing in central venous catheter-associated bloodstream infections. Infect Control Hosp Epidemiol. 1996;17:150-158. [pmid: 8708352].
66 Aiken L H, Clarke S P, Sloane D M, et al. Hospital nurse staffing and patient mortality, nurse burnout, and job dissatisfaction. JAMA. 2002;288(16):1987-1993. [pmid: 12387650].
67 Anonymous. Appropriateness of minimum nurse staffing ratios in nursing homes. Phase II final report. Baltimore, MD: Centers for Medicare and Medicaid Services; 2001.
68 Anonymous. Appropriateness of minimum nurse staffing ratios in nursing homes. Report to Congress, Baltimore, MD: Health Care Financing Administration; 2000.
69 Kovner C, Jones C, Zhan C, et al. Nurse staffing and postsurgical adverse events: an analysis of administrative data from a sample of US hospitals, 1990-1996. Health Serv Res. 2002;37(3):611-629. [pmid: 12132597].
70 Byrne A J, Sellen A J, Jones J G. Errors on anaesthetic record charts as a measure of anaesthetic performance during simulated critical incidents. Br J Anaesth. 1998;80(1):58-62. [pmid: 9505779].
71 Straker J. Reliability of OSCAR occupancy, census and staff data: a comparison with the Ohio Department of Health annual survey of long-term care facilities. Miami, FL: Scripps Gerontology Center, Miami University; 1999.
72 Blegen M A. Health Care Challenges Beyond 2001: Mapping the Journey for Research and Practice, proceedings from the 34th Annual Communicating Nursing Research Conference/15th Annual WIN Assembly, April 19–21, 2001 Seattle, Washington. Commun Nurs Res. 2001;34(9):3-16.
73 Czaplinski C, Diers D. The effect of staff nursing on length of stay and mortality. Med Care. 1998;36(12):1626-38. [pmid: 9860053].
74 Malenka D J, McGrath P D, Wennberg D E, et al. The relationship between operator volume and outcomes after percutaneous coronary interventions in high volume hospitals in 1994-1996: the northern New England experience. Northern New England Cardiovascular Disease Study Group. J Am Coll Cardiol. 1999;34(5):1471-80. [pmid: 10551694].
75 Klein L W, Schaer G L, Calvin J E, et al. Does low individual operator coronary interventional procedural volume correlate with worse institutional procedural outcome? [see comments]. J Am Coll Cardiol. 1997;30(4):870-7. [pmid: 9316511].
76 Khuri S F, Daley J, Henderson W, et al. Relation of surgical volume to outcome in eight common operations. Results from the VA National Surgical Quality Improvement Program. Ann Surg. 1999;230:414-432. [pmid: 10493488].
77 Hannan E L, Siu A L, Kumar D, et al. The decline in coronary artery bypass graft surgery mortality in New York State. The role of surgeon volume. JAMA. 1995;273(3):209-13. [pmid: 7807659].
78 Hillner B E, Smith T J, Desch C E. Hospital and physician volume or specialization and outcomes in cancer treatment: importance in quality of cancer care. J Clin Oncol. 2000;18(11):2327-40. [pmid: 10829054].
79 Nash I S, Corrato R R, Dlutowski M J, et al. Generalist versus specialist care for acute myocardial infarction. Am J Cardiol. 1999;83(5):650-654. [pmid: 10080413].
80 Margulies DR, Cryer HG, McArthur DL, et al. Patient volume per surgeon does not predict survival in adult level I trauma centers. J Trauma Inj Infect Crit Care 2001;50:(4):597–601; discussion 601–3.
81 Ellis SG, Weintraub W, Holmes D, et al. Relation of operator volume and experience to procedural outcome of percutaneous coronary revascularization at hospitals with high interventional volumes. Circulation. 1997;95:(11):2479-84. [pmid: 9184577].
82 McGhan W F, Smith W E, Adams D W. A randomized trial comparing pharmacists and technicians as dispensers of prescriptions for ambulatory patients. Med Care. 1983;21(4):445-53. [pmid: 6843197].
83 Ness J E, Sullivan S D, Stergachis A. Accuracy of technicians and pharmacists in identifying dispensing errors. Am J Hosp Pharm. 1994;51:354-357. [pmid: 8160687].
84 Latif A Z, Signorini D F, Whittle I R. Treatment by a specialist surgical neuro-oncologist does not provide any survival advantage for patients with a malignant glioma. Br J Neurosurg. 1998;12(1):29-32. [pmid: 11013644].
85 Gerbert B, Maurer T, Berger T, et al. Primary care physicians as gatekeepers in managed care. Primary care physicians' and dermatologists' skills at secondary prevention of skin cancer. Arch Dermatol. 1996;132(9):1030-8. [pmid: 8795541].
86 Fleischer A B Jr, Feldman S R, Barlow J O, et al. The specialty of the treating physician affects the likelihood of tumor-free resection margins for basal cell carcinoma: results from a multi-institutional retrospective study. J Am Acad Dermatol. 2001;44(2):224-30. [pmid: 11174379].
87 Dorrance H R, Docherty G M, O'Dwyer P J. Effect of surgeon specialty interest on patient outcome after potentially curative colorectal cancer surgery. Dis Colon Rectum. 2000;43(4):492-8. [pmid: 10789744].
88 Nash I S, Nash D B, Fuster V. Do cardiologists do it better?. J Am Coll Cardiol. 1997;29(3):475-8. [pmid: 9060880].
89 Goodwin A T, Birdi I, Ramesh T P, et al. Effect of surgical training on outcome and hospital costs in coronary surgery. Heart. 2001;85(4):454-7. [pmid: 11250976].
90 Nelson L S, Gordon P E, Simmons M D, et al. The benefit of houseofficer education on proper medication dose calculation and ordering. Acad Emerg Med. 2000;7(11):1311-6. [pmid: 11073484].
91 Stevenson J G. Adherence to physician training guidelines for pediatric transesophageal echocardiography affects the outcome of patients undergoing repair of congenital cardiac defects. J Am Soc Echocardiogr. 1999;12(3):165-72. [pmid: 10070180].
92 Pollack M M, Patel K M, Ruttimann U E. Pediatric critical care training programs have a positive effect on pediatric intensive care mortality. Crit Care Med. 1997;25:1637-42. [pmid: 9377876].
93 Eldar S, Kunin J, Chouri H, et al. Safety of laparoscopic cholecystectomy on a teaching service: a prospective trial. Surg Laparosc Endosc Percut Tech. 1996;6(3):218-20.
94 Paauw D S, Wenrich M D, Curtis J R, et al. Ability of primary care physicians to recognize physical findings associated with HIV infection. JAMA. 1995;274(17):1380-1382. [pmid: 7563564].
95 Pollack M M, Cuerdon T T, Patel K M, et al. Impact of quality-of-care factors onpediatric intensive care unit mortality. JAMA. 1994;272:941-6. [pmid: 8084061].
96 Blegen M A, Vaughn T E, Goode C J. Nurse experience and education: effect on quality of care. J Nurs Adm. 2001;31(1):33-9. [pmid: 11198839].
97 Birnbaum M L, Robinson N E, Kuska B M, et al. Effect of advanced cardiac life-support training in rural, community hospitals. Crit Care Med. 1994;22(5):741-9. [pmid: 8181281].
98 Patton D V, Landers D R, Agarwal I T. Legal considerations of sleep deprivation among resident physicians. J Health Law. 2001;34(3):377-417. [pmid: 11571893].
99 Kogi K. Improving shift workers' health and tolerance to shiftwork: recent advances. Appl Ergon. 1996;27:5-10. [pmid: 15676306].
100 Monk T H, Folkard S, Wedderburn A I. Maintaining safety and high performance on shiftwork. Appl Ergon. 1996;27:17-24. [pmid: 11542593].
101 Samkoff J S, Jacques C H M. A review of studies concerning effects of sleep deprivation and fatigue on residents' performance. Acad Med. 1991;66:687-693. [pmid: 1747181].
102 Rosa R R, Bonnet M H. Performance and alertness on 8 h and 12 h rotating shifts at a natural gas utility. Ergonomics. 1993;36(10):1177-1193. [pmid: 8223409].
103 Bell C M, Redelmeier D A. Mortality among patients admitted to hospitals on weekends as compared with weekdays. N Engl J Med. 2001;345(9):663-8. [pmid: 11547721].
104 Bollschweiler E, Krings A, Fuchs K H, et al. Alternative shift models and the quality of patient care. An empirical study in surgical intensive care units. Langenbecks Arch Surg. 2001;386(2):104-9. [pmid: 11374042].
105 Booker J M, Roseman C. A seasonal pattern of hospital medication errors in Alaska. Psychiatry Res. 1995;57:251-257. [pmid: 7501735].
106 Gold D R, Rogacz S, Bock N, et al. Rotating shift work, sleep, and accidents related to sleepiness in hospital nurses. Am J Public Health. 1992;82(7):1011-4. [pmid: 1609900].
107 Novak RO, Smalensky MH. Shift work and industrial injuries at a chemical plant in Southeast Texas. In: Human Factors Society 32nd Annual Meeting; 1988.
108 Smith L, Totterdell P, Folkard S. Shiftwork effects in nuclear power workers: A field study using portable computers. Work Stress. 1995;9(23):235-244.
109 Palinkas L A. Health and performance of Antarctic winter-over personnel: A follow-up study. Aviat Space Environ Med. 1986;57(10):954-959. [pmid: 3778394].
110 Northrup H R, Wilson J T, Rose K M. The twelve-hour shift in the petroleum and chemical industries. Indus Labor Rel Rev. 1979;32:312-26.
111 Mouloua M, Koonce JM, editors. Human-automation interaction: Research and practice. Hillsdale, NJ: Lawrence Erlbaum Associates Inc.; 1997.
112 Flynn E A, Barker K N, Gibson J T, et al. Impact of interruptions and distractions on dispensing errors in an ambulatory care pharmacy. Am J Health Syst Pharm. 1999;56(13):1319-25. [pmid: 10683129].
113 Dismukes K, Young G, Sumwalt R. Cockpit interruptions and distractions: effective management requires a careful balancing act. ASRS Directline 1998;Dec:4–9.
114 Dornheim M A. Crew distractions emerge as new safety focus. Aviat Wk Space Technol. 2000;153(3):58-60.
115 Leape L L. Error in medicine. JAMA. 1994;272(23):1851-7. [pmid: 7503827].
116 Treisman A M. Selective attention in man. Br Med Bull. 1964;20:12-16. [pmid: 14104089].
117 Welford A T. Single-channel operation in the brain. Acta Psychol. 1967;27:5-22.
118 Griffon-Fouco M, Ghertman F. Recueil de donnes sur les facteurs humains a Electricite de France. In: Operational safety of nuclear power plants. Vienna: International Atomic Energy Agency; 1984. p. 157–72.
119 Eyrolle H, Cellier J M. The effects of interruptions in work activity: field and laboratory results. Appl Ergon. 2000;31(5):537-43. [pmid: 11059468].
120 Davis N M. Concentrating on interruptions. Am J Nurs. 1994;94(3):14.
121 Cooper J B, Newbower R S, Kitz R J. An analysis of major errors and equipment failures in anesthesia management: considerations for prevention and detection. Anesthesiology. 1984;60(1):34-42. [pmid: 6691595].
122 Blum N J, Lieu T A. Interrupted care. The effects of paging on pediatric resident activities. Am J Dis Child. 1992;146(7):806-8. [pmid: 1496947].
123 Katz M H, Schroeder S A. The sounds of the hospital. Paging patterns in three teaching hospitals. N Engl J Med. 1988;319(24):1585-9. [pmid: 3200267].
124 Nerenz D, Rosman H, Newcomb C, et al. The on-call experience of interns in internal medicine. Medical Education Task Force of Henry Ford Hospital. Arch Intern Med. 1990;150(11):2294-7. [pmid: 2241437].
125 Lurie N, Rank B, Parenti C, et al. How do house officers spend their nights? A time study of internal medicine house staff on call. N Engl J Med. 1989;320(25):1673-7. [pmid: 2725617].
126 Chisholm C D, Collison E K, Nelson D R, et al. Emergency department workplace interruptions: are emergency physicians “interrupt-driven” and “multitasking”?. Acad Emerg Med. 2000;7(11):1239-43. [pmid: 11073472].
127 Chisholm C D, Dornfeld A M, Nelson D R, et al. Work interrupted: a comparison of workplace interruptions in emergency departments and primary care offices. Ann Emerg Med. 2001;38(2):146-51. [pmid: 11468609].
128 Hymel G, Severyn F. Typical shiftwork interruptions faced by supervising EM faculty in an EM residency setting. In: Abstract presented at: Society for Academic Emergency Medicine Midwest Regional Meeting; 1999; Ann Arbor, MI.
129 Paxton F, Heaney D, Howie J, et al. A study of interruption rates for practice nurses and GPs. Nurs Stand. 1996;10(43):33-6.
130 Beebe S A. Nurses' perception of beeper calls. Implications for resident stress and patient care. Arch Pediatr Adolesc Med. 1995;149(2):187-91. [pmid: 7849881].
131 Peterson G M, Wu M S, Bergin J K. Pharmacist's attitudes towards dispensing errors: their causes and prevention. J Clin Pharm Ther. 1999;24(1):57-71. [pmid: 10319909].
132 Gladstone J. Drug administration errors: a study into the factors underlying the occurrence and reporting of drug errors in a district general hospital. J Adv Nurs. 1995;22(4):628-37. [pmid: 8708180].
133 Ely J W, Levinson W, Elder N C, et al. Perceived causes of family physicians' errors. J Fam Pract. 1995;40(4):337-44. [pmid: 7699346].
134 Pape T. The effect of nurses' use of focused protocol to decrease distractions during medication administration. Denton, TX: Texas Women's University; 2002.
135 Murtaugh C M, Litke A. Transitions through post-acute and long-term care settings: patterns of use and outcomes for a national cohort of elders. Med Care. 2002;40(3):227-36. [pmid: 11880795].
136 Williams E I, Fitton F. Factors affecting early unplanned readmission of elderly patients to hospital. BMJ. 1988;297(6651):784-7. [pmid: 3142550].
137 Anderson G F, Steinberg E P. Hospital readmissions in the Medicare population. N Engl J Med. 1984;311(21):1349-53. [pmid: 6436703].
138 Berkman B, Campion E, Swagerty E, et al. Geriatric consultation teams: alternate approach to social work discharge planning. J Gerontol Soc Wk. 1983;5:77-88.
139 Naylor M D, Bowles K H, Brooten D. Patient problems and advanced practice nurse interventions during transitional care. Public Health Nurs. 2000;17(2):94-102. [pmid: 10760191].
140 Rogers W H, Draper D, Kahn K L, et al. Quality of care before and after implementation of the DRG-based prospective payment system. A summary of effects. JAMA. 1990;264(15):1989-94. [pmid: 2120478].
141 Naylor M D, Brooten D, Campbell R, et al. Comprehensive discharge planning and home follow-up of hospitalized elders: a randomized clinical trial. JAMA. 1999;281(7):613-20. [pmid: 10029122].
142 Williams S, Moore C R, Wisnivesky J, et al. Assessing medical errors related to the continuity of care from an inpatient to an outpatient setting [abstract]. J Gen Intern Med. 2002;17(Suppl. 1):218.
143 Diem S J, Prochazka A V, Meyer T J. Effects of a postdischarge clinic on housestaff satisfaction and utilization of hospital services. J Gen Intern Med. 1996;11(3):179-181. [pmid: 8667097].
144 Himmel W, Tabache M, Kochen M M. What happens to long-term medication when general practice patients are referred to hospital?. Eur J Clin Pharmacol. 1996;50(4):253-7. [pmid: 8803514].
145 Burns J M, Sneddon I, Lovell M, et al. Elderly patients and their medication: a post-discharge follow-up study. Age Ageing. 1992;21(3):178-81. [pmid: 1615779].
146 Beers M H, Sliwkowski J, Brooks J. Compliance with medication orders among the elderly after hospital discharge. Hosp Formul. 1992;27(7):720-4. [pmid: 10119187].
147 Parkin D M, Henney C R, Quirk J, et al. Deviation from prescribed drug treatment after discharge from hospital. BMJ. 1976;2(6037):686-8. [pmid: 974539].
148 Murff H J, Kannry J. Physician satisfaction with two order entry systems. J Am Med Inform Assoc. 2001;8(5):499-509. [pmcid: 131047]. [pmid: 11522770].
149 Cleary P D, Edgman-Levitan S, Roberts M, et al. Patients evaluate their hospital care: a national survey. Health Aff. 1991;10(4):254-67.
150 Charles C, Gauld M, Chambers L, et al. How was your hospital stay? Patients' reports about their care in Canadian hospitals. CMAJ. 1994;150(11):1813-22. [pmid: 8199958].
151 Calkins D R, Davis R B, Reiley P, et al. Patient-physician communication at hospital discharge and patients' understanding of the postdischarge treatment plan. Arch Intern Med. 1997;157(9):1026-30. [pmid: 9140275].
152 Brook R H, Appel F A, Avery C, et al. Effectiveness of inpatient follow-up care. N Engl J Med. 1971;285(27):1509-14. [pmid: 4331354].
153 Michels N. The transition from hospital to home: an exploratory study. Home Health Care Serv Q. 1988;9(1):29-44. [pmid: 10291783].
154 Peters P, Fleuren M, Wijkel D. The quality of the discharge planning process: the effect of a liaison nurse. Int J Qual Health Care. 1997;9(4):283-7. [pmid: 9304427].
155 Proctor E K, Morrow-Howell N. Complications in discharge planning with Medicare patients. Health Soc Work. 1990;15(1):45-54. [pmid: 2156767].
156 Graham H, Livesley B. Can readmissions to a geriatric medical unit be prevented?. Lancet. 1983;1(8321):404-6. [pmid: 6130389].
157 Parkes, J, Shepperd, S. Discharge planning from hospital to home (Cochrane Review). The Cochrane Library, Issue 3. Oxford: Update Software 2002(2).
158 Smith D M, Weinberger M, Katz B P, et al. Postdischarge care and readmissions. Med Care. 1988;26(7):699-708. [pmid: 2839742].
159 Weinberger M, Oddone E Z, Henderson W G. Does increased access to primary care reduce hospital readmissions? Veterans Affairs Cooperative Study Group on Primary Care and Hospital Readmission. N Engl J Med. 1996;334(22):1441-7. [pmid: 8618584].
160 Townsend J, Piper M, Frank A O, et al. Reduction in hospital readmission stay of elderly patients by a community based hospital discharge scheme: a randomised controlled trial. BMJ. 1988;297(6647):544-7. [pmid: 2844356].
161 Martin F, Oyewole A, Moloney A. A randomized controlled trial of a high support hospital discharge team for elderly people. Age Ageing. 1994;23(3):228-34. [pmid: 8085509].
162 Lipton H L, Bero L A, Bird J A, et al. The impact of clinical pharmacists' consultations on physicians geriatric drug prescribing. A randomized controlled trial. Med Care. 1992;30(7):646-58. [pmid: 1614233].
163 Hansen F R, Spedtsberg K, Schroll M. Geriatric follow-up by home visits after discharge from hospital: a randomized controlled trial. Age Ageing. 1992;21(6):445-50. [pmid: 1471584].
164 Naylor M, Brooten D, Jones R, et al. Comprehensive discharge planning for the hospitalized elderly. A randomized clinical trial. Ann Intern Med. 1994;120(12):999-1006. [pmid: 8185149].
165 Siu A L, Kravitz R L, Keeler E, et al. Postdischarge geriatric assessment of hospitalized frail elderly patients. Arch Intern Med. 1996;156(1):76-81. [pmid: 8526700].
166 Markey B T, Igou J F. Medication discharge planning for the elderly. Patient Educ Couns. 1987;9(3):241-9. [pmid: 10282841].
167 Sandler D A, Mitchell J R, Fellows A, et al. Is an information booklet for patients leaving hospital helpful and useful?. BMJ. 1989;298(6677):870-4. [pmid: 2497830].
168 MacDonald E T, MacDonald J B, Phoenix M. Improving drug compliance after hospital discharge. BMJ. 1977;2(6087):618-21. [pmid: 902005].
169 Weinberger M, Smith D M, Katz B P, et al. The cost-effectiveness of intensive postdischarge care. A randomized trial. Med Care. 1988;26(11):1092-102. [pmid: 2846971].
170 Tamblyn R M, McLeod P J, Abrahamowicz M, et al. Do too many cooks spoil the broth? Multiple physician involvement in medical management of elderly patients and potentially inappropriate drug combinations. CMAJ. 1996;154(8):1177-84. [pmid: 8612253].
171 Classen D C, Evans R S, Pestotnik S L, et al. The timing of prophylactic administration of antibiotics and the risk of surgical wound infection. N Engl J Med. 1992;326:281-286. [pmid: 1728731].
172 Rind D, Safran C, Phillips R S, et al. Effect of computer-based alerts on the treatment and outcomes of hospitalized patients. Arch Intern Med. 1994;154:1511-1517. [pmid: 8018007].
173 Kuperman G, Sittig D F, Shabot M, et al. Clinical decision support for hospital and critical care. J Healthc Inform Manage Sys Soc. 1999;13:81-96.
174 Balas, EA, Boren, SA, Griffing, G. Computerized management of diabetes: a synthesis of controlled trials. In: Proc Am Med Inform Assoc; 1998. p. 295–299.
175 Balas E A, Weingarten S, Garb C T, et al. Improving preventive care by prompting physicians. Arch Intern Med. 2000;160:301-308. [pmid: 10668831].
176 Jha A K, Kuperman G J, Teich J M, et al. Identifying adverse drug events: development of a computer-based monitor and comparison with chart review and stimulated voluntary report. J Am Med Inform Assoc. 1998;5:305-314. [pmcid: 61304]. [pmid: 9609500].
177 Classen D C, Pestonik S L, Evans R S, et al. Computerized surveillance of adverse drug events in hospital patients. JAMA. 1991;266:2847-2851. [pmid: 1942452].
178 Bates D W. Using information technology to reduce rates of medication errors in hospital. BMJ. 2000;320:788-791. [pmid: 10720369].
179 Klein H J, Kim J S. A field study of the influence of situational constraints, leader-member exchange, and goal commitment on performance. Acad Manage J. 1998;41(1):88-95.
180 Bogner, MS, editor. Human error in medicine. Hillsdale, NJ: Lawrence Erlbaum Associates Inc.; 1994.
181 Thronesbery, CG, Malin, JT. Field guide for designing human interaction with intelligent systems Report No. TM-1998-208470. Houston, TX: NASA; 1998.
182 Staggers N, Kobus D. Comparing response time, errors, and satisfaction between text-based and graphical user interfaces during nursing order tasks. J Am Med Inform Assoc. 2000;7(2):164-76. [pmcid: 61470]. [pmid: 10730600].
183 Wastell D G, Newman M. Stress, control and computer system design: A psychophysiological field study. Behav Inform Tech. 1996;15(3):183-192.
184 Smith A M, Ortiguera S A, Laskowski E R, et al. A preliminary analysis of psychophysiological variables and nursing performance in situations of increasing criticality. Mayo Clin Proc. 2001;76(3):275-84. [pmid: 11243274].
185 Levine, S. Stress and performance. In: Background papers: stress management. Washington, DC: National Academy Press; 1988.
186 Jones J G, Hardy L. Stress and cognitive functioning in sport. J Sports Sci. 1989;7:41-63. [pmid: 2659817].
187 Maslach, C, Jackson, SE, Leiter, MP. The Maslach burnout inventory (3rd ed.). Palo Alto, CA: Consulting Psychologists Press; 1996.
188 Judge T A, Thoresen C J, Bono J E, et al. The job satisfaction-job performance relationship: A qualitative and quantitative review. Psychol Bull. 2001;127(3):376-407. [pmid: 11393302].
189 Carey, TP. Error orientation, collectivism and job stress: A timely examination: U South Florida, US.; 2001.
190 Blegen M A. Nurses' job satisfaction: a meta-analysis of related variables. Nurs Res. 1993;42(1):36-41. [pmid: 8424066].
191 Lundberg, GD. A pendulum swings and a rocking horse rocks. JAMA 1997;278:(20):1704; discussion 1703.
192 Crawshaw R. Patient-physician covenant. JAMA. 1995;273(19):1553. [pmid: 7739086].
193 Clever L H. Some things have not changed. Ann Intern Med. 2000;132(1):85-9. [pmid: 10627257].
194 Dugan J, Lauer E, Bouquot Z, et al. Stressful nurses: the effect on patient outcomes. J Nurs Care Qual. 1996;10(3):46-58. [pmid: 8634470].
195 Jones J W, Barge B N, Steffy B D, et al. Stress and medical malpractice: Organizational risk assessment and intervention. J Appl Psychol. 1988;73(4):727-735. [pmid: 3209582].
196 Bond C A, Raehl C L. Pharmacists' assessment of dispensing errors: risk factors, practice sites, professional functions, and satisfaction. Pharmacotherapy. 2001;21(5):614-26. [pmid: 11349750].
197 DeVoe J, Fryer G E J, Hargraves J L, et al. Does career dissatisfaction affect the ability of family physicians to deliver high-quality patient care?. J Fam Pract. 2002;51(3):223-228. [pmid: 11978232].
198 Firth-Cozens J, Greenhalgh J. Doctors' perceptions of the links between stress and lowered clinical care. Soc Sci Med. 1997;44(7):1017-22. [pmid: 9089922].
199 Shanafelt T D, Bradley K A, Wipf J E, et al. Burnout and self-reported patient care in an internal medicine residency program. Ann Intern Med. 2002;136:358-367. [pmid: 11874308].
200 Leppa C J. Nurse relationships and work group disruption. J Nurs Adm. 1996;26(10):23-7. [pmid: 8858011].
201 Allan E L, Suchanek-Hudmon K L, Berger B A, et al. Patient treatment adherence. Facility design and counseling skills. J Pharm Technol. 1992;8(6):242-51. [pmid: 10122647].
202 Jossy. The impact of design on employee productivity. San Diego Bus J. 1999;20(37):18.
203 Carr T, Webster C S. Recovery care centers. An innovative approach to caring for healthy surgical patients. AORN J. 1991;53(4):986-95. [pmid: 2039226].
204 Davis T R. The influence of the physical environment in offices. Acad Manage Rev. 1984;9(2):271-283. [pmid: 10266030].
205 Coile, RC, Jr. Competing by design: hospitals of the future offer healing environments. Russ Coiles Health Trends 2001;13:(11):1, 4–8.
206 Volzer R. Safe passages. Lose the institutional look without sacrificing safety. Comtemp Longterm Care. 2001;24(6):21-2.
207 Auer T. Survey finds office performance rises with design improvements. Bus Pr. 1999;11(45):30-31.
208 Neumann, T. The healing power of design. Houston, TX; 1993.
209 Ruga W. A healing environment, by design. Mod Healthc. 2000;30(44):24. [pmid: 11141839].
210 Boothby S. Patient-friendly design: the right Rx for the ED blues. Health Facil Manage. 1998;11(6):20-1. [pmid: 10181835].
211 Birdsong C, Leibrock C. Patient-centered design. Healthc Forum J. 1990;33(3):40-5. [pmid: 10104845].
212 Megaw, E. The visual environment. In: Smith, AP, Jones DM, editors. Handbook of human performance, Vol. 1: The physical environment; Vol. 2: Health and performance; Vol. 3: State and trait. San Diego, CA, US: Academic Press, Inc; 1992. p. 261–296.
213 Flynn E A, Barker K N, Gibson J T, et al. Relationships between ambient sounds and the accuracy of pharmacists' prescription-filling performance. Hum Factors. 1996;38(4):614-622. [pmid: 8976624].
214 Nightingale, F. Notes on nursing: what it is and what it is not. London: Harrison; 1860.
215 Rubin H R. Status report--an investigation to determine whether the built environment affects patients' medical outcomes. J Healthc Des. 1998;10:11-3. [pmid: 10539237].
216 Walsh-Sukys D M. Reducing light and sound in the neonatal intensive care unit: an evaluation of patient safety, staff satisfaction, and costs. J Perinatol. 2001;21(8):572.
217 Knez I, Enmarker I. Effects of office lighting on mood and cognitive performance and a gender effect in work-related judgment. Environ Behav. 1998;30(4):553-561.
218 Stone N J. Windows and environmental cues on performance and mood. Environ Behav. 1998;30(3):306-22.
219 Kwallek N, Woodson H, Lewis C M, et al. Impact of three interior color schemes on worker mood and performance relative to individual environmental sensitivity. Color Res Appl. 1997;22(2):121-132.
220 Kwallek N, Lewis C M, Lin-Hsiao J W D, et al. Effects of nine monochromatic office interior colors on clerical tasks and worker mood. Color Res Appl. 1996;21(6):448-458.
221 Ainsworth R A, Simpson L, Cassell D. Effects of three colors in an office interior on mood and performance. Percept Mot Skills. 1993;76(1):235-241. [pmid: 8451130].
222 Stone N J, Irvine J M. Performance, mood, satisfaction, and task type in various work environments: A preliminary study. J Gen Psychol. 1993;120(4):489-497. [pmid: 8189213].
223 Buchanan T L, Barker K N, Gibson J T, et al. Illumination and errors in dispensing. Am J Hosp Pharm. 1991;48:2137-2145. [pmid: 1781468].
224 Rosenberg E L, Haines R F, Jordan K. The effects of window shape and reticle presence on performance in a vertical alignment task. Aviat Space Environ Med. 1989;60(6):543-9. [pmid: 2751584].
225 Noweir M H. Noise exposure as related to productivity, disciplinary actions, absenteeism, and accidents among textile workers. J Safe Res. 1984;15(4):163-174.
226 Kwallek N, Lewis C M, Robbins A S. Effects of office interior color on workers' mood and productivity. Percept Mot Skills. 1988;66(1):123-128.
227 Enander A. Effects of moderate cold on performance of psychomotor and cognitive tasks. Ergonomics. 1987;30(10):1431-1445. [pmid: 3428250].
228 Smith A. Noise, performance efficiency and safety. Int Arch Occup Environ Health. 1990;62(1):1-5. [pmid: 2403982].
229 Enander, AE. Effects of thermal stress on human performance. Scand J Work Environ Health 1989;15(Suppl 1) 1989:(Suppl 1):27–33.
230 Hygge, S. Heat and performance. In: Smith, Andrew P. (Ed); Jones, Dylan M. (Ed). (1992). Handbook of human performance, Vol. 1: The physical environment; Vol. 2: Health and performance; Vol. 3: State and trait. San Diego, CA, US: Academic Press, Inc; 1992. p. 79–104.
231 Hancock, PA, Vasmatzidis, I. Human occupational and performance limits under stress: The thermal environment as a prototypical example. Ergonomics 1998;41(8) Aug 1998:(8):1169–1191.
232 Enander A. Performance and sensory aspects of work in cold environments: A review. Ergonomics. 1984;27(4):365-378. [pmid: 6734591].
233 Enander, AE, Hygge, S. Thermal stress and human performance. Scand J Work Environ Health 1990;16(Suppl 1) 1990:(Suppl 1):44–50.
234 Cook, RI, Woods, DD. Operating at the sharp end: The complexity of human error. In: Bogner, MS, editor. Human error in medicine. Hillsdale, NJ ; Hillsdale, NJ: Lawrence Erlbaum Associates, Inc; Lawrence Erlbaum Associates, Inc; 1994. p. 255–310.
235 Barach P, Small S D. Reporting and preventing medical mishaps: lessons from non-medical near miss reporting systems. BMJ. 2000;320(7237):759-63. [pmid: 10720361].
236 Sutcliffe, KM. A mindful infrastructure for increasing reliability. Ambul Outreach 2000 30–4.
237 Shaubhut R M, Jones C. A systems approach to medication error reduction. J Nurs Care Qual. 2000;14(3):13-27. [pmid: 10826231].
238 Leape L L. A systems analysis approach to medical error. J Eval Clin Prac. 1997;3(3):213-22.
239 Reason J. Education and debate. Human error: models and management. BMJ. 2000;320(7237):768-70. [pmid: 10720363].
240 Rex J H, Turnbull J E, Allen S J, et al. Systematic root cause analysis of adverse drug events in a tertiary referral hospital. Jt Comm J Qual Improv. 2000;26(10):563-75. [pmid: 11042820].
241 Farbstein K, Clough J. Improving medication safety across a multihospital system. Jt Comm J Qual Improv. 2001;27(3):123-37. [pmid: 11242719].
242 Fletcher C E. Failure mode and effects analysis. An interdisciplinary way to analyze and reduce medication errors. J Nurs Adm. 1997;27(12):19-26. [pmid: 9418753].
243 Raines D A. Making mistakes: Prevention is key to error-free health care. AWHONN Lifelines. 2000;4(1):35-39. [pmid: 11033615].
244 Krizek T J. Surgical error: Ethical issues of adverse events. Arch Surg. 2000;135:1359-1366. [pmid: 11074896].
245 Roland M, Campbell S, Wilkin D. Clinical governance: a convincing strategy for quality improvement?. J Manage Med. 2001;15(3):188-201.
246 Glavin, MP, Chilingerian, JA. Hospital care production and medical errors: Organizational responses to improve care. In: Rahim, M. Afzalur (Ed); Golembiewski, Robert T. (Ed); et al. (1998). Current topics in management, Vol. 3. Stamford, CT: JAI Press, Inc; 1998. p. 193–215.
247 Hart E, Hazelgrove J. Understanding the organisational context for adverse events in the health services: The role of cultural censorship. Qual Health Care. 2001;10(4):157-262.
248 Grabowski M, Roberts K H. Human and organizational error in large scale systems. IEEE Trans Syst Man Cybern. 1996;26(1):2-16.
249 Weeks W B, Bagian J P. Developing a culture of safety in the Veterans Health Administration. Effect Clin Pract. 2000;3(6):270-6.
250 Benner P. Creating a culture of safety and improvement: a key to reducing medical error. Am J Crit Care. 2001;10(4):281-4. [pmid: 11432216].
251 Nystrom P C. Organizational cultures, strategies, and commitments in health care organizations. Health Care Manage Rev. 1993;18(1):43-49. [pmid: 8444614].
252 Weick K E. Organizational culture as a source of high reliability. Calif Manage Rev. 1987;29(2):112-127.
253 Gardner, RL. Benchmarking organizational culture: Organizational as an primary factor in safety performance. Prof Saf 1999 26–32.
254 Havens D S, Aiken L H. Shaping systems to promote desired outcomes. The magnet hospital model. J Nurs Adm. 1999;29(2):14-20. [pmid: 10029797].
255 Scott J G, Sochalski J, Aiken L. Review of magnet hospital research: findings and implications for professional nursing practice. J Nurs Adm. 1999;29(1):9-19. [pmid: 9921144].
256 Kramer M K, Schmalenberg C. The magnet hospitals: Institutions of excellence. Part I. J Nurs Adm. 1988;18(1):13-24.
257 Kramer M K, Schmalenberg C. The magnet hospitals: Institutions of excellence. Part II. J Nurs Adm. 1988;18(2):11-19.
258 Denison D R. What is the difference between organization culture and organizational climate? A native's point of view on a decade of paradigm wars. Acad Manage Rev. 1996;21(3):619-654.
259 Morgan, G. Imaginization. Newbury Park: Sage; 1993.
260 Stetzer A, Morgeson F P, Anderson E L. Organizational climate and ineffectiveness: Evidence from 25 outdoor work crew divisions. J Qual Manage. 1997;2(2):251-265.
261 Sleutel M R. Climate, culture, context, or work environment?: Organizational factors that influence nursing practice. J Nurs Adm. 2000;30(2):53-58. [pmid: 10689396].
262 Helmreich, RL, Merritt, AC. Culture at work in aviation and medicine: national, organizational, and professional influences. Brookfield, VT: Ashgate; 1998.
263 Sorenson J N. Safety culture: a survey of the state-of-the-art. Reliab Engin Syst Saf. 2002;76:189-204.
264 Pizzi, LT, Goldfarb, NI, Nash, DB. Promoting a culture of safety. In: Making Health Care Safer: A Critical Analysis of Patient Safety Practices; 2001.
265 Shortell S M, Jones R H, Rademaker A W, et al. Assessing the impact of total quality management and organizational culture on multiple outcomes of care for coronary artery bypass graft surgery patients. Med Care. 2000;38(2):207-17. [pmid: 10659694].
266 Aiken L H, Smith H L, Lake E T. Lower Medicare mortality among a set of hospitals known for good nursing care. Med Care. 1994;32(8):771-87. [pmid: 8057694].
267 Maierhofer N I, Griffin M A, Sheehan M. Linking manager values and behavior with employee values and behavior: a study of values and safety in the hairdressing industry. J Occup Health Psych. 2000;5(4):417-427.
268 Boreham N C, Shea C E, Mackway-Jones K. Clinical risk and collective competence in the hospital emergency department in the UK. Soc Sci Med. 2000;51(1):83-91. [pmid: 10817471].
269 Edmondson A C. Learning from mistakes is easier said than done: Group and organizational influences on the detection and correction of human error. J Appl Behav Sci. 1996;32(1):5-28.
270 Hechanova-Alampay R, Beehr T. Empowerment, span of control, and safety performance in work teams after workforce reduction. J Occup Health Psych. 2001;6(4):275-282.
271 Wakefield B J, Blegen M A, Uden-Holman T, et al. Organizational culture, continuous quality improvement, and medication administration error reporting. Am J Med Qual. 2001;16(4):128-34. [pmid: 11477957].
272 Jones K R, Redman R W. Organizational Culture and Work Redesign. J Nurs Adm. 2000;30(12):604-610. [pmid: 11132349].
273 Orbe M P, King G 3rd. Negotiating the tension between policy and reality: exploring nurses' communication about organizational wrongdoing. Health Commun. 2000;12(1):41-61. [pmid: 10938906].
274 Shortell S M, O'Brian J L, Carman J M, et al. Assessing the impact of continuous quality improvement/total quality management: Concept versus implementation. Health Serv Res. 1995;30(2):377-402. [pmid: 7782222].
275 Buller P F. Long term performance effects of goal setting and team building interventions in an underground silver mine. Organ Dev J. 1988;6(2):82-93.
276 Edkins G D, Pollock C M. The influence of sustained attention on railway accidents. Accid Anal Prev. 1997;29(4):533-539. [pmid: 9248512].
277 Harter J K, Schmidt F L, Hayes T I. Business-unit-level relationship between employee satisfaction, employee engagement, and business outcomes: A meta-analysis. J Appl Psychol. 2002;87(2):268-279. [pmid: 12002955].
278 Kaminski M. Unintended consequences: organizational practices and their impact on workplace safety and productivity. J Occup Health Psych. 2001;6(2):127-38.
279 Schultz M A, van Servellen G, Litwin M S, et al. Can hospital structural and financial characteristics explain variations in mortality caused by acute myocardial infarction?. Appl Nurs Res. 1999;12(4):210-214. [pmid: 10589110].
280 Rasmussen P G, Revzin A M. Scanning and monitoring performance: Effects of the reinforcement values of the events being monitored. Aviat Med. 1994;10:94-98.
281 Turner J A, Karasek R A. Software ergonomics: Effects of computer application design parameters on operator task performance and health. Ergonomics. 1984;27(6):663-690. [pmid: 6383818].
282 Scerbo, MW, Mouloua, M, editors. Automation technology and human performance: Current research and trends: Mahwah, NJ, US: Lawrence Erlbaum Associates, Inc., Publishers. (1999). xiii, 339pp.; 1999.
283 Carroll J M. Human-computer interaction: psychology as a science of design. Annu Rev Psychol. 1997;48:61-83. [pmid: 15012476].
284 Kontogiannis T, Embrey D. A user-centred design approach for introducing computer-based process information systems. Appl Ergon. 1997;28(2):109-119. [pmid: 9414346].