# Bibliography

Abdalla I A. Work environment, job structure, and behavior orientation as predictors of skill utilization in Kuwait: The moderating effect of ability. Genet Soc Gen Psychol Monogr. 1988;114(2):175-189.
Abraham I L, Foley T S. The Work Environment Scale and the Ward Atmosphere Scale (Short Forms): Psychometric data. Percept Mot Skills. 1984;58(1):319-322. [pmid: 6718198].
Adams A, Bond S, Arber S. Development and validation of scales to measure organisational features of acute hospital wards. Int J Nurs Stud. 1995;32(6):612-27. [pmid: 8926161].
Adams I D, Chan M, Clifford P C, et al. Computer aided diagnosis of acute abdominal pain: a multicentre study. BMJ. 1986;293(6550):800-4. [pmid: 3094664].
Adams J M. Health information systems: improving nursing care and cutting cost. Medsurg Nurs. 1998;7(5):308-9. [pmid: 10036434].
Adams R. Computerization of patient acuity and nursing care planning: new approach to improved patient care and cost-effective staffing. J Nurs Adm. 1995;25(1):8. [pmid: 7823208].
Adeyemi-Bello T. A test of the performance implications of locus of control and task orientation in the not-for-profit sector. Psychol Rep. 1993;73(73):1327-1330.
Ahern M. Survey of Florida physicians. Characteristics and satisfaction. J Fla Med Assoc. 1993;80(11):752-7. [pmid: 8277235].
Ahmed D S, Fecik S. The fatigue factor. When long shifts harm patients. Am J Nurs. 1999;99(9):12.
Ahmed D S, Fecik S. Floating faux pas. Is there such a thing as ‘only giving meds'?. Am J Nurs. 1999;99(7):12.
Ahmed D S, Hamrah P M. Labeling lapse. When the bottle doesn't contain what you think you're giving. Am J Nurs. 1999;99(3):12.
Aiken L H, Clarke S P, Sloane D M. Hospital restructuring: does it adversely affect care and outcomes?. J Nurs Adm. 2000;30(10):457-65. [pmid: 11045104].
Aiken L H, Clarke S P, Sloane D M, et al. Hospital nurse staffing and patient mortality, nurse burnout, and job dissatisfaction. JAMA. 2002;288(16):1987-1993. [pmid: 12387650].
Aiken L H, Clarke S P, Sloane D M, et al. Nurses' reports on hospital care in five countries: the ways in which nurses' work is structured have left nurses among the least satisfied workers, and the problem is getting worse. Health Aff. 2001;20(3):43-53.
Aiken LH, Havens DS and Sloane DM. The Magnet Nursing Services Recognition Program. Am J Nurs 2000;100(3):26–35; quiz 35–6.
Aiken L H, Sloane D M, Lake E T, et al. Organization and outcomes of inpatient AIDS care. Med Care. 1999;37(8):760-772. [pmid: 10448719].
Aiken L H, Smith H L, Lake E T. Lower Medicare mortality among a set of hospitals known for good nursing care. Med Care. 1994;32(8):771-87. [pmid: 8057694].
Ainsworth R A, Simpson L, Cassell D. Effects of three colors in an office interior on mood and performance. Percept Mot Skills. 1993;76(1):235-241. [pmid: 8451130].
Akerkar G A, Yee J, Hung R, et al. Patient experience and preferences toward colon cancer screening: a comparison of virtual colonoscopy and conventional colonoscopy. Gastrointest Endosc. 2001;54(3):310-5. [pmid: 11522970].
Albicka K, Metz H S, Albicki A, et al. Computer-assisted diagnosis of strabismus. J Pediatr Ophthalmol Strabismus. 1987;24(5):228-31. [pmid: 3316590].
Alexander J A. The effects of patient care unit organization on nursing turnover. Health Care Manage Rev. 1988;13(2):61-72. [pmid: 3384655].
Allan E L, Suchanek-Hudmon K L, Berger B A, et al. Patient treatment adherence. Facility design and counseling skills. J Pharm Technol. 1992;8(6):242-51. [pmid: 10122647].
Allander T, Gruber A, Naghavi M, et al. Frequent patient-to-patient transmission of hepatitis C virus in a haematology ward. Lancet. 1995;345(8950):603-7. [pmid: 7898176].
Allen A, Culbertson M. Environmental safety: an essential element of quality care. J Post Anesth Nurs. 1990;5(4):291-4. [pmid: 2388174].
Allen D. Record-keeping and routine nursing practice: the view from the wards. J Adv Nurs. 1998;27(6):1223-30. [pmid: 9663874].
Allen P. Conflict-management program designed to give managers mediator's tools. Bus J (Cent NY). 2000;14(16):4. [pmcid: 386872].
Alley L G. The influence of an organizational pain management policy on nurses' pain management practices. Oncol Nurs Forum. 2001;28(5):867-74. [pmid: 11421146].
Altschuler E L. Prospective, randomised trial of sleep deprived versus rested surgeons. Lancet. 1999;353(9151):501. [pmid: 9989749].
Alvarez M, Lopez Ponga B, Rayon C, et al. Nosocomial outbreak caused by Scedosporium prolificans (inflatum): four fatal cases in leukemic patients. J Clin Microbiol. 1995;33(12):3290-5. [pmcid: 228690]. [pmid: 8586719].
Amaravadi R K, Dimick J B, Pronovost P J, et al. ICU nurse-to-patient ratio is associated with complications and resource use after esophagectomy. Intensive Care Med. 2000;26(12):1857-62. [pmid: 11271096].
Ameigh A Y. The role of the corporate nurse executive: providing balance and perspective for patient care and the corporate structure. Nurs Adm Q. 1996;20(2):74-9. [pmid: 8700388].
American Nurses Association. Implementing nursing's report card: a study of RN staffing, length of stay and patient outcomes. Washington, DC: American Nurses Publishing; 1997.
Amjad H, Jafary H A, Amjad L Q. Hospital-acquired morbidity and circadian rhythms in patients in the ICU. Chest. 1995;107(1):295-6. [pmid: 7813302].
Anderson F D, Maloney J P, Beard L W. A descriptive, correlational study of patient satisfaction, provider satisfaction, and provider workload at an army medical center. Mil Med. 1998;163(2):90-4. [pmid: 9503899].
Anderson F D, Maloney J P, Knight C D, et al. Utilization of supplemental agency nurses in an Army medical center. Mil Med. 1996;161(1):48-53. [pmid: 11082752].
Anderson G F, Steinberg E P. Hospital readmissions in the Medicare population. N Engl J Med. 1984;311(21):1349-53. [pmid: 6436703].
Anderson J D, Bonner M, Scheifele D W, et al. Lack of nosocomial spread of Varicella in a pediatric hospital with negative pressure ventilated patient rooms. Infec Cont. 1985;6(3):120-1.
Anderson K, Morris G, Kennedy H, et al. Aspergillosis in immunocompromised paediatric patients: associations with building hygiene, design, and indoor air. Thorax. 1996;51(3):256-61. [pmid: 8779127].
Anderson R A, Hsieh P, Su H. Resource allocation and resident outcomes in nursing homes: comparisons between the best and worst. Res Nurs Health. 1998;21(4):297-313. [pmid: 9679807].
Anderson S C. The effect of clinical simulations on error rate, when error rate is an index of professional attitude. J Med Technol. 1986;3(4):237-42.
Andrews L B, Stocking C, Krizek T, et al. An alternative strategy for studying adverse events in medical care. Lancet. 1997;349(9048):309-13. [pmid: 9024373].
Anonymous. Lack of sleep in junior doctors. BMJ 1989;298(6670):381–2.
Anonymous. Specialist societies and Royal College tackle thorny problem of competence. Can J Ophthalmol 1989;24(1):31–2.
Anonymous. Obstetric accidents. BMJ 1990;301(6743):118–9.
Anonymous. New safety flooring enhances the working environment. N Z Health Hosp 1994;46(4):17–8.
Anonymous. National survey finds cutbacks in nursing care diminish the safety of care patients receive. Mass Nurse 1995;65(3):3–4.
Anonymous. The science of making mistakes. Lancet 1995;345(8954):871–2.
Anonymous. Staffing problems cause hospital's errors. Oreg Nurse 1995;60(2):10.
Anonymous. Survey finds loss of RNs jeopardizes patient safety. Nev Rnformation 1995;4(2):18–9.
Anonymous. Workplace issues. Safety and quality patient care in hospitals. Fla Nurse 1995;43(7):12–13.
Anonymous. Concerns mounting about link between nursing ratios and infections, injuries. Hosp Infec Control 1996;23(11):137–40.
Anonymous. Zeroing in on medication errors. Lancet 1997;349(9049):369.
Anonymous. Empower yourself, empower your profession. 10 things you can do protect [sic] your patients and your practice. Mass Nurse 1998;68(2):4.
Anonymous. Five times: coincidence or something more serious? BMJ 1998;316(7146):1736–7.
Anonymous. Nursing staff levels at U.S. nursing homes continue to be lower than recommended. Res Act 1998;222(12):12.
Anonymous. Patients undergoing major surgery in hospitals with limited nursing staffs suffer more complications. Res Act 1998;222(7):7.
Anonymous. Sentinel events: approaches to error reduction and prevention. Jt Comm J Qual Improv 1998;24(4):175–86.
Anonymous. From the Centers for Disease Control and Prevention. Improvements in workplace safety--United States, 1900-1999. JAMA 1999;282(4):319–21.
Anonymous. Managing to avoid human error. Pharm Manuf Rev 1999;11(1):20.
Anonymous. New study confirms critical role of low nurse-to-patient ratio. Mass Nurse 1999;69(1):5.
Anonymous. Studies link RNs staffing to patient safety. Calif Nurs 1999;95(6):7.
Anonymous. AHRQ to cosponsor conference on working conditions and patient safety. Res Act 2000;239(19):19
Anonymous. Appropriateness of minimum nurse staffing ratios in nursing homes. Report to Congress. Baltimore, MD: Health Care Financing Administration; 2000.
Anonymous. Avoidable errors in emergency practice. Distracted by distraction. Emerg Med 2000;32(9):79,88.
Anonymous. Doing what counts for patient safety: federal actions to reduce medical errors and their impact. Washington, DC: Quality Interagency Coordination Task Force.; 2000.
Anonymous. Recommended practices for safety through identification of potential hazards in the perioperative environment. AORN J 2000;72(4):690–2, 695–8.
Anonymous. Research commissioned by the UKCC demonstrates how the expansion of professional roles promotes better patient care. J Adv Nurs 2000;32(4):778.
Anonymous. Researchers are studying the relationship between nurse staffing levels and nursing-sensitive patient outcomes. Res Act 2000;235:19.
Anonymous. Appropriateness of minimum nurse staffing ratios in nursing homes. Phase II final report. Baltimore, MD: Centers for Medicare and Medicaid Services; 2001.
Anonymous. Confidentially. Mixing medications: dangerous distraction. Nursing 2001;31(11):26.
Anonymous. Creating a safer workplace to provide quality care. Qual Lett Healthc Lead 2001;13(4):2–11, 1.
Anonymous. Enhancing working conditions and patient safety. Healthc Haz Manage Mon 2001;14(6):1–6.
Anonymous. HHS study finds strong link between patient outcomes & nurse staffing in hospitals. S D Nurs 2001;43(2):27.
Anonymous. Leapfrog Group outlines what is acceptable. Healthc Risk Manage 2001;23(1):4–6.
Anonymous. Nurse staffing levels strongly linked to patient outcomes. Clin J Oncol Nurs 2001;5(5):188.
Anonymous. Nurse workloads and distractions lead to medication errors in 1999 -- a report from the USP. Nev Rnformation 2001;10(1):22.
Anonymous. Levels of Evidence and Grades of Recommendations. In: Centre for Evidence Based Medicine: http://www.minervation.com/cebm/documents/levels_cebm_23nov99.rtf; 2002.
Arlian L G, Estes S A, Vyszenski-Moher D L. Prevalence of Sarcoptes scabiei in the homes and nursing homes of scabietic patients. J Am Acad Dermatol. 1988;19(5 Pt 1):806-11. [pmid: 3142938].
Arnow P M, Houchins S G, Richards J M, et al. Aspergillus fumigatus contamination of lymphokine-activated killer cells infused into cancer patients. J Clin Microbiol. 1991;29(5):1038-41. [pmcid: 269930]. [pmid: 2056038].
Arnstein F. Catalogue of human error. Br J Anaesth. 1997;79(5):645-56. [pmid: 9422906].
Aronson S. Adherence to physician training guidelines for pediatric transesophageal echocardiography affects the outcome of patients undergoing repair of congenital cardiac defects. J Am Soc Echocardiogr. 1999;12(11):1008. [pmid: 10610097].
Ashton P R. American Society for Cytotechnology quality assurance survey data. Summary report. Acta Cytol. 1989;33(4):451-4. [pmid: 2750434].
Astrom J, Thorell L H, Holmlund U, et al. Handshaking, personality, and psychopathology in psychiatric patients, a reliability and correlational study. Percept Mot Skills. 1993;77(3 Pt 2):1171-86. [pmid: 8170766].
Auer T. Survey finds office performance rises with design improvements. Bus Pr. 1999;11(45):30-31.
Bach D S. Management of specific medical conditions in the perioperative period. Prog Cardiovasc Dis. 1998;40(5):469-76. [pmid: 9585378].
Backstrom T. Intra-organization work for change: A model and two tools. Am J Ind Med. 1999;36(suppl 1):61-3. [pmid: 10519787].
Baer D M, Belsey R E. The evolving regulatory environment and bedside metabolic monitoring of the acute care patient. Chest. 1990;97(5 Suppl):191S-197S. [pmid: 2183975].
Baer DM, Petersen J, Belsey RE, et al. Bedside testing, Part 3. Quality management of bedside glucose testing. MLO Med Lab Obs 1993;25(6):46–8, 50, 52 passim.
Baggs J G, Schmitt M H, Mushlin A I, et al. Association between nurse-physician collaboration and patient outcomes in three intensive care units. Crit Care Med. 1999;27(9):1991-8. [pmid: 10507630].
Baker C F. Discomfort to environmental noise: heart rate responses of SICU patients. Crit Care Nurs Q. 1992;15(2):75-90. [pmid: 1628246].
Baker C F. Annoyance to ICU noise: a model of patient discomfort. Crit Care Nurs Q. 1993;16(2):83-90. [pmid: 8353802].
Baker C F, Garvin B J, Kennedy C W, et al. The effect of environmental sound and communication on CCU patients' heart rate and blood pressure. Res Nurs Health. 1993;16(6):415-21. [pmid: 8248568].
Baker H, Naphthine R. Nurses and medication. Part 6. Ritual+workloads = medication error. Aust Nurs J. 1994;2(5):34-6. [pmid: 7728238].
Balas EA, Boren SA and Griffing G. Computerized management of diabetes: a synthesis of controlled trials. In: Proceedings of the American Medical Informatics Symposium; 1998. 295–299.
Balas E A, Li Z R, Spencer D C, et al. An expert system for performance-based direct delivery of published clinical evidence. J Am Med Inform Assoc. 1996;3(1):56-65. [pmcid: 116287]. [pmid: 8750390].
Balas E A, Weingarten S, Garb C T, et al. Improving preventive care by prompting physicians. Arch Intern Med. 2000;160:301-308. [pmid: 10668831].
Baldwin P J, Dodd M, Wrate R M. Junior doctors making mistakes. Lancet. 1998;351(9105):804. [pmid: 9519958].
Baldwin P J, Dodd M, Wrate R W. Young doctors' health--I. How do working conditions affect attitudes, health and performance?. Soc Sci Med. 1997;45(1):35-40. [pmid: 9203268].
Baltes B B, Briggs T E, Huff J W, et al. Flexible and compressed workweek schedules: A meta-analysis of their effects on work-related criteria. J Appl Psychol. 1999;84(4):496-513.
Barach P, Moss F. Delivering safe health care. BMJ. 2001;323(7313):585-6. [pmid: 11557691].
Barach P, Small S D. How the NHS can improve safety and learning: by learning free lessons from near misses. BMJ. 1683;320(7251):1683-4. [pmid: 10864524].
Barach P, Small S D. Reporting and preventing medical mishaps: lessons from non-medical near miss reporting systems. BMJ. 2000;320(7237):759-63. [pmid: 10720361].
Baratta J E, McManus M A. The effect of contextual factors on individuals' job performance. J Appl Soc Psychol. 1992;22(21):1702-1710.
Barker K N. Data Collection Techniques: Observation. Am J Hosp Pharm. 1980;37:1235-43. [pmid: 7416180].
Barnes A M, Frantz R A. Do oxygen-enriched atmospheres exist beneath surgical drapes and contribute to fire hazard potential in the operating room?. AANA J. 2000;68(2):153-61. [pmid: 10876463].
Barr D A. The effects of organizational structure on primary care outcomes under managed care. Ann Intern Med. 1995;122(5):353-9. [pmid: 7847647].
Bartels P H, Thompson D, Weber J E. Expert systems in histopathology. IV. The management of uncertainty. Anal Quant Cytol Histol. 1992;14(1):1-13. [pmid: 1558613].
Barton C F. Paging patterns: a nurse's view. [letter; comment.]. N Engl J Med. 1989;320(17):1151-2. [pmid: 2710187].
Batalden P B, Cronenwett L R, Brown L L, et al. Forum: Collaboration in improving care for patients: how can we find out what we haven't been able to figure out yet?. Jt Comm J Qual Improv. 1998;24(10):609-18. [pmid: 9801960].
Bates D W. Using information technology to reduce rates of medication errors in hospital. BMJ. 2000;320:788-791. [pmid: 10720369].
Bates D W, Cohen M, Leape L L, et al. Reducing the frequency of errors in medicine using information technology. J Am Med Inform Assoc. 2001;8(4):299-308. [pmcid: 130074]. [pmid: 11418536].
Bates D W, O'Neil A C, Boyle D, et al. Potential identifiability and preventability of adverse events using information systems. J Am Med Inform Assoc. 1994;1(5):404-11. [pmcid: 116222]. [pmid: 7850564].
Bates D W, Teich J M, Lee J, et al. The impact of computerized physician order entry on medication error prevention. J Am Med Inform Assoc. 1999;6(4):313-21. [pmcid: 61372]. [pmid: 10428004].
Baxendale S, Clancy J, McVicar A. Clinical implications of circadian rhythmicity for nurses and patients. Br J Nurs. 1997;6(6):303-9. [pmid: 9155295].
Beck-Friis B, Strang P, Sjoden P O. Caring for severely ill cancer patients. A comparison of working conditions in hospital-based home care and in hospital. Support Care Cancer. 1993;1(3):145-51. [pmid: 8149142].
Beckmann U, West L F, Groombridge G J, et al. The Australian Incident Monitoring Study in Intensive Care: AIMS-ICU. The development and evaluation of an incident reporting system in intensive care. Anaesth Intensive Care. 1996;24(3):314-9. [pmid: 8805885].
Beebe S A. Nurses' perception of beeper calls. Implications for resident stress and patient care. Arch Pediatr Adolesc Med. 1995;149(2):187-91. [pmid: 7849881].
Beers M H, Sliwkowski J, Brooks J. Compliance with medication orders among the elderly after hospital discharge. Hosp Formul. 1992;27(7):720-4. [pmid: 10119187].
Bell C M, Redelmeier D A. Mortality among patients admitted to hospitals on weekends as compared with weekdays. N Engl J Med. 2001;345(9):663-8. [pmid: 11547721].
Bellelli G, Frisoni G B, Barbisoni P, et al. The management of adverse clinical events in nursing homes: a 1-year survey study. J Am Geriatr Soc. 2001;49(7):915-25. [pmid: 11527483].
Benner P. Creating a culture of safety and improvement: a key to reducing medical error. Am J Crit Care. 2001;10(4):281-4. [pmid: 11432216].
Bensley L, Nelson N, Kaufman J, et al. Patient and staff views of factors influencing assaults on psychiatric hospital employees. Issues Ment Health Nurs. 1995;16(5):433-46. [pmid: 7558793].
Benstein B, Kennedy M, Wagner E. Distraction index, part III: coping with distractions. Diagn Cytopathol. 2000;23(4):225-7. [pmid: 11002360].
Bergeron H P, Hinton D A. Aircraft automation: The problem of the pilot interface. Aviat Space Environ Med. 1985;56(2):144-148. [pmid: 3985891].
Bergman A B. Resident stress. Pediatrics. 1988;82(2):260-3. [pmid: 3399299].
Bergman R, Golander H. Evaluation of care for the aged: a multipurpose guide. J Adv Nurs. 1982;7(3):203-10. [pmid: 6811642].
Berkman B, Campion E, Swagerty E, et al. Geriatric consultation teams: alternate approach to social work discharge planning. J Gerontol Soc Wk. 1983;5:77-88.
Berman J, Mayhew J. Patient safety and scented pediatric anesthesia facemasks. J Clin Anesth. 1998;10(3):262-3. [pmid: 9603602].
Bernstein G, Cleary J P, Heldt G P, et al. Response time and reliability of three neonatal patient-triggered ventilators. Am Rev Rspir Dis. 1993;148(2):358-64.
Bertram D A. Managing an emergency department: the effect of patient flow on physician performance. QRB Qual Rev Bull. 1983;9(6):175-80. [pmid: 6412191].
Berwick D M. Developing and testing changes in delivery of care. Ann Intern Med. 1998;128(8):651-6. [pmid: 9537939].
Beyer A J 3rd, Land G, Zaritsky A. Nonphysician transport of intubated pediatric patients: a system evaluation. Crit Care Med. 1992;20(7):961-6. [pmid: 1617990].
Biordi D L. Nursing error and caring in the workplace. Nurs Adm Q. 1993;17(2):38-45. [pmid: 8437752].
Birdsong C, Leibrock C. Patient-centered design. Healthc Forum J. 1990;33(3):40-5. [pmid: 10104845].
Birkmeyer J D, Finlayson S R, Tosteson A N, et al. Effect of hospital volume on in-hospital mortality with pancreaticoduodenectomy. Surgery. 1999;125(3):250-6. [pmid: 10076608].
Birnbaum M L, Robinson N E, Kuska B M, et al. Effect of advanced cardiac life-support training in rural, community hospitals. Crit Care Med. 1994;22(5):741-9. [pmid: 8181281].
Black N, Johnston A. Volume and outcome in hospital care: evidence, explanations and implications. Health Serv Manage Res. 1990;3(2):108-14. [pmid: 10171409].
Black P, McKenna H, Deeny P. A concept analysis of the sensoristrain experienced by intensive care patients. Intensive Crit Care Nurs. 1997;13(4):209-15. [pmid: 9355425].
Blackburn LH. “Living room” represents oncology unit's focus on total patient care. Hosp Prog 1983;64(3):50–1, 70.
Blecher M B. Accident scenes. Hosp Health Netw. 1997;71(10):46-8. [pmid: 9179039].
Blegen M A. Nurses' job satisfaction: a meta-analysis of related variables. Nurs Res. 1993;42(1):36-41. [pmid: 8424066].
Blegen M A. Health Care Challenges Beyond 2001: Mapping the Journey for Research and Practice, proceedings from the 34th Annual Communicating Nursing Research Conference/15th Annual WIN Assembly, April 19–21, 2001 Seattle, Washington. Commun Nurs Res. 2001;34(9):3-16.
Blegen M A, Goode C J, Reed L. Nurse staffing and patient outcomes. Nurs Res. 1998;47(1):43-50. [pmid: 9478183].
Blegen M A, Vaughn T. A multisite study of nurse staffing and patient occurrences. Nurs Econ. 1998;16(4):196-203. [pmid: 9748985].
Blegen M A, Vaughn T E, Goode C J. Nurse experience and education: effect on quality of care. J Nurs Adm. 2001;31(1):33-9. [pmid: 11198839].
Blum N J, Lieu T A. Interrupted care. The effects of paging on pediatric resident activities. Am J Dis Child. 1992;146(7):806-8. [pmid: 1496947].
Boden L I. Policy evaluation: better living through research. Am J Ind Med. 1996;29(4):346-52. [pmid: 8728137].
Bogner MS, editor. Human error in medicine. Hillsdale, NJ: Lawrence Erlbaum Associates Inc.; 1994.
Boisaubin E V, Levine R E. Identifying and assisting the impaired physician. Am J Med Sci. 2001;322(1):31-6. [pmid: 11465244].
Boling P A. The value of targeted case management during transitional care. JAMA. 1999;281(7):656-7. [pmid: 10029129].
Bollschweiler E, Krings A, Fuchs K H, et al. Alternative shift models and the quality of patient care. An empirical study in surgical intensive care units. Langenbecks Arch Surg. 2001;386(2):104-9. [pmid: 11374042].
Bolsin S. Hospital mortality and staff workload. Lancet. 2000;356(9238):1356. [pmid: 11073051].
Bolton L B, Jones D, Aydin C E, et al. A response to California's mandated nursing ratios. J Nurs Sch. 2001;33(2):179-84.
Bond C A, Raehl C L. Pharmacists' assessment of dispensing errors: risk factors, practice sites, professional functions, and satisfaction. Pharmacotherapy. 2001;21(5):614-26. [pmid: 11349750].
Bond C A, Raehl C L, Pitterle M E, et al. Health care professional staffing, hospital characteristics, and hospital mortality rates. Pharmacotherapy. 1999;19(2):130-8. [pmid: 10030762].
Booker J M, Roseman C. A seasonal pattern of hospital medication errors in Alaska. Psychiatry Res. 1995;57:251-257. [pmid: 7501735].
Boothby S. Patient-friendly design: the right Rx for the ED blues. Health Facil Manage. 1998;11(6):20-1. [pmid: 10181835].
Boreham N C, Shea C E, Mackway-Jones K. Clinical risk and collective competence in the hospital emergency department in the UK. Soc Sci Med. 2000;51(1):83-91. [pmid: 10817471].
Boucek C, Freeman J A, Bircher N G, et al. Impairment of anesthesia task performance by laser protection goggles. Anesth Analg. 1993;77(6):1232-7. [pmid: 8250318].
Bowies KH. The barriers and benefits of nursing information systems. Comput Nurs 1997;15(4):191–6; quiz 197–8.
Bowles S, Ursin H, Picano J. Aircrew perceived stress: Examining crew performance, crew position and captains personality. Aviat Space Environ Med. 1093;71(11, Sect 1):1093-1097. [pmid: 11086661].
Boyce C A, Brow M B, Cote K C, et al. End the debate. Entry level into practice should be the master's degree. J Nurs Adm. 2001;31(4):166-8. [pmid: 11324326].
Boyer M M. Root cause analysis in perinatal care: health care professionals creating safer health care systems. J Perinat Neonatal Nurs. 2001;15(1):40-54. [pmid: 12095006].
Bracco D, Favre J B, Bissonnette B, et al. Human errors in a multidisciplinary intensive care unit: a 1-year prospective study. Intensive Care Med. 2001;27(1):137-45. [pmid: 11280625].
Bradburn B G, Hewitt P B. The effect of the intensive therapy ward environment on patients' subjective impression: a follow-up study. Intensive Care Med. 1980;7(1):15-8. [pmid: 7451715].
Braybrooke S. Sunlit setting and multibed rooms ease hospice patients. Hospitals. 1984;58(4):106. [pmid: 6693096].
Brennan T A. Reporting of errors: how much should the public know?. Effect Clin Pract. 2000;3:298-299.
Brennan T A, Leape L L, Laird N M, et al. Incidence of adverse effects and negligence in hospitalized patients. N Engl J Med. 1991;324:370-376. [pmid: 1987460].
Briss P A, Zaza S, Pappaionou M, et al. Developing an evidence-based Guide to Community Preventive Services - methods. Am J Prev Med. 2000;18(1S):35-43. [pmid: 10806978].
Britten N, Shaw A. Patients' experiences of emergency admission: how relevant is the British government's Patients Charter?. J Adv Nurs. 1994;19(6):1212-20. [pmid: 7930103].
Brook R H, Appel F A, Avery C, et al. Effectiveness of inpatient follow-up care. N Engl J Med. 1971;285(27):1509-14. [pmid: 4331354].
Brooten D and Naylor M. Transitional environments that optimize outcomes. In: Hinshaw, AS, Feetham, S and Shaver, J, editors. Handbook of clinical nursing research. Thousand Oaks, CA: Sage Publications; 1998. p. 641–653.
Brooten D, Naylor M, York R. Effects of nurse specialist transitional care on patient outcomes and cost: results of five randomized trials. Am J Manag Care. 1995;1(1):35-41.
Broughall J M, Marshman C, Jackson B, et al. An automatic monitoring system for measuring handwashing frequency in hospital wards. J Hosp Infect. 1984;5(4):447-53. [pmid: 6085102].
Brown P P, Mack M J, Simon A W, et al. Comparing clinical outcomes in high-volume and low-volume off-pump coronary bypass operation programs. Ann Thorac Surg. 2001;72(3):S1009-15. [pmid: 11565717].
Brown S P, Leigh T W. A new look at psychological climate and its relationship to job involvement, effort, and performance. J Appl Psychol. 1996;81(4):358-368. [pmid: 8751453].
Bryan B M, Reineke L A. Assessing patient care devices: an objective methodology. Nurs Manage. 1989;20(6):57-60. [pmid: 2740003].
Buchanan T L, Barker K N, Gibson J T, et al. Illumination and errors in dispensing. Am J Hosp Pharm. 1991;48:2137-2145. [pmid: 1781468].
Budreau G, Balakrishnan R, Titler M, et al. Caregiver-patient ratio: capturing census and staffing variability. Nurs Econ. 1999;17(6):317-24. [pmid: 10711184].
Buerhaus P I, Needleman J. Policy implications of research on nurse staffing and quality of patient care. Policy Politics Nurs Prac. 2000;1(1):5-15.
Buggs C, Valadez A M, Lund C A. Evaluating the effectiveness of an intravenous therapy team. Nurs Econ. 1993;11(4):249-55. [pmid: 8232644].
Buller P F. Long term performance effects of goal setting and team building interventions in an underground silver mine. Organ Dev J. 1988;6(2):82-93.
Burger G T, Van Ginneken A M, Hollema H. Computer-based diagnostic support systems in histopathology: what should they do?. Medinfo. 2001;10(Pt 2):1120-4.
Burghart C R, Hassfeld S, Soler L, et al. Safety in computer assisted surgery. Stud Health Technol Inf. 2001;81:82-4.
Burns J M, Sneddon I, Lovell M, et al. Elderly patients and their medication: a post-discharge follow-up study. Age Ageing. 1992;21(3):178-81. [pmid: 1615779].
Buss P. Medical errors. Organisational ethos is important. BMJ. 2001;322(7299):1421. [pmid: 11417541].
Butrej T. Fatigue and driving performance. Lamp. 1997;54(6):31-2. [pmid: 9335773].
Byers J F, Smyth K A. Effect of a music intervention on noise annoyance, heart rate, and blood pressure in cardiac surgery patients. Am J Crit Care. 1997;6(3):183-91. [pmid: 9131197].
Byrne A J, Jones J G. Responses to simulated anaesthetic emergencies by anaesthetists with different durations of clinical experience. Br J Anaesth. 1997;78(5):553-6. [pmid: 9175971].
Byrne A J, Sellen A J, Jones J G. Errors on anaesthetic record charts as a measure of anaesthetic performance during simulated critical incidents. Br J Anaesth. 1998;80(1):58-62. [pmid: 9505779].
Byrne M. Critical incident technique as a qualitative research method. AORN J. 2001;74(4):536-9. [pmid: 11665387].
Cahill J. Patient's perceptions of bedside handovers. J Clin Nurs. 1998;7(4):351-9. [pmid: 9830976].
California Medical Association. Report on the medical insurance feasibility study. Sutton, CA: California Medical Association; 1977.
Calkins D R, Davis R B, Reiley P, et al. Patient-physician communication at hospital discharge and patients' understanding of the postdischarge treatment plan. Arch Intern Med. 1997;157(9):1026-30. [pmid: 9140275].
Calmbacher C W. The goal of safety training rules: reducing the threat of injury. Occup Health Saf. 1993;62(3):80-4. [pmid: 8464601].
Campbell R L, Banner R, Konick-McMahan J, et al. Discharge planning and home follow-up of the elderly patient with heart failure. Nurs Clin North Am. 1998;33(3):497-513. [pmid: 9719694].
Campbell R S. Managing the patient-ventilator system: system checks and circuit changes. Respir Care. 1994;39(3):227-36. [pmid: 10145990].
Campion M A. Interdisciplinary approaches to job design: A constructive replication with extensions. J Appl Psychol. 1988;73(3):467-481.
Cannava E. ‘Gerodesign’: safe and comfortable living spaces for older adults. Geriatrics 1994;49(11):45–9; quiz 50–1.
Canter D. In search of objectives. Hum Behav Environ Adv Theory Res. 1990;11:315-338.
Cape R D, McKay D. Special facilities for patients with Alzheimer's disease. CMAJ. 1986;135(5):434-5. [pmid: 3742383].
Caplan RD. Person-environment fit theory and organizations: Commensurate dimensions, time perspectives, and mechanisms. J Vocat Behav 1987;31(3) Dec 1987(3):248–267.
Carayon P. Stressful jobs and non-stressful jobs: a cluster analysis of office jobs. Ergonomics. 1994;37(2):311-23. [pmid: 8119263].
Carey TP. Error orientation, collectivism and job stress: A timely examination: U South Florida, US.; 2001.
Carlisle D. Warned in the USA… in the USA today, support workers are suturing wounds, injecting intravenous drugs into cardiac patients, monitoring vital signs, administering medication, inserting catheters and taking care of wounds after surgery. Nurs Times. 1995;91(16):19-25.
Carlson R W, Weiland D E, Srivathsan K. Does a full-time, 24-hour intensivist improve care and efficiency?. Crit Care Clin. 1996;12(3):525-51. [pmid: 8839588].
Carr T, Webster C S. Recovery care centers. An innovative approach to caring for healthy surgical patients. AORN J. 1991;53(4):986-95. [pmid: 2039226].
Carr-Hill R A, Dixon P, Griffiths M, et al. The impact of nursing grade on the quality and outcome of nursing care. Health Econ. 1995;4(1):57-72. [pmid: 7780528].
Carroll J M. Human-computer interaction: psychology as a science of design. Annu Rev Psychol. 1997;48:61-83. [pmid: 15012476].
Carthey J, de Leval M R, Reason J T. Institutional resilience in healthcare systems. Qual Health Care. 2001;10(1):29-32. [pmid: 11239141].
Cartwright K, Turner H. Safety aspects of outstationed laboratory equipment. J Hosp Infect. 1992;20(4):225-31. [pmid: 1350599].
Casalena J A, Badre-Alam A, Ovaert T C, et al. The Penn State Safety Floor: Part II--Reduction of fall-related peak impact forces on the femur. J Biomech Eng. 1998;120(4):527-32. [pmid: 10412424].
Castle N G. Deficiency citations for physical restraint use in nursing homes. J Gerontol B Psychol Sci Soc Sci. 2000;1(40):S33-40. [pmid: 10728128].
Castledine G. Importance of the nursing practice environment. Br J Nurs. 1999;8(3):186. [pmid: 10222881].
Cellier J M, Eyrolle H. Interference between switched tasks. Ergonomics. 1992;35(1):25-36.
Cetta F, Baldi C, Montalto G, et al. Short-term complications after endoscopic sphincterotomy (ES) are not increased in relatively young and healthy patients with small bile ducts, when sphincterotomy for stones is performed by an expert. Ann Surg. 1998;228(4):624-5. [pmid: 9790354].
Chapman M D, Tsay A, Vailes L D. Home allergen monitoring and control--improving clinical practice and patient benefits. Allergy. 2001;56(7):604-10. [pmid: 11421917].
Charles C, Gauld M, Chambers L, et al. How was your hospital stay? Patients' reports about their care in Canadian hospitals. CMAJ. 1994;150(11):1813-22. [pmid: 8199958].
Charlton J E. Checklists and patient safety. Anaesthesia. 1990;45(6):425-6. [pmid: 2200297].
Chavigny K, Lewis A. Team or primary nursing care?. Nurs Outlook. 1984;32(6):322-7. [pmid: 6567848].
Chen H. Theory-driven evaluations. Newbury Park: Sage; 1990.
Chen P P, Ma M, Chan S, et al. Incident reporting in acute pain management. Anaesthesia. 1998;53(8):730-5. [pmid: 9797515].
Chervenak FA and McCullough LB. The moral foundation of medical leadership: the professional virtues of the physician as fiduciary of the patient. Am J Obset Gyn 2001;184(5):875–9; discussion 879–80.
Chester J, Britton D. Elective and emergency surgery for colorectal cancer in a district general hospital: impact of surgical training on patient survival. Ann R Coll Surg Engl. 1989;71(6):370-4. [pmid: 2604346].
Chisakuta A M. Nurse-call button on a patient-controlled analgesia pump?. Anaesthesia. 1993;48(1):90. [pmid: 8434772].
Chisholm C D. The moonlighting paradox. Am J Emerg Med. 2000;18(2):224-6. [pmid: 10750938].
Chisholm C D, Collison E K, Nelson D R, et al. Emergency department workplace interruptions: are emergency physicians “interrupt-driven” and “multitasking”?. Acad Emerg Med. 2000;7(11):1239-43. [pmid: 11073472].
Chisholm C D, Dornfeld A M, Nelson D R, et al. Work interrupted: a comparison of workplace interruptions in emergency departments and primary care offices. Ann Emerg Med. 2001;38(2):146-51. [pmid: 11468609].
Chmiel N. Safety at work. In: Chmiel, Nik (Ed). (2000). Introduction to work and organizational psychology: A European perspective. Malden, MA, US; Malden, MA, US: Blackwell Publishers Inc.; Blackwell Publishers Inc.; 2000. p. 255–273.
Cho S. Nurse staffing and adverse patient outcomes: a systems approach. Nurs Outlook. 2001;49(2):78-85. [pmid: 11309562].
Chopra V, Bovill J G, Spierdijk J, et al. Reported significant observations during anaesthesia: a prospective analysis over an 18-month period. Br J Anaesth. 1992;68(1):13-7. [pmid: 1739559].
Christakis N A, Lamont E B. Extent and determinants of error in doctors' prognoses in terminally ill patients: prospective cohort study. BMJ. 2000;320(7233):469-72. [pmcid: 27288]. [pmid: 10678857].
Cislo R, Rasaiah B. Electrical safety in patient care areas. CMAJ. 1990;143(9):873-4. [pmid: 2224714].
Clark A L, Brennan A G, Robertson L J, et al. Factors affecting patient radiation exposure during routine coronary angiography in a tertiary referral centre. Br J Radiol. 2000;73(866):184-9. [pmid: 10884732].
Clarke M, Kadhom H M. The nursing prevention of pressure sores in hospital and community patients. J Adv Nurs. 1988;13(3):365-73. [pmid: 3417931].
Clarke M, Liu B, Schuller H, et al. Automatic adjustment of pacemaker stimulation output correlated with continuously monitored capture thresholds: a multicenter study. European Microny Study Group. Pacing Clin Electrophysiol. 1998;21(8):1567-75. [pmid: 9725155].
Clarke T, Mackinnon E, England K, et al. A review of intensive care nurse staffing practices overseas: what lessons for Australia?. Intensive Crit Care Nurs. 2000;16(4):228-42. [pmid: 10922188].
Classen D C, Evans R S, Pestotnik S L, et al. The timing of prophylactic administration of antibiotics and the risk of surgical wound infection. N Engl J Med. 1992;326:281-286. [pmid: 1728731].
Classen D C, Pestonik S L, Evans R S, et al. Computerized surveillance of adverse drug events in hospital patients. JAMA. 1991;266:2847-2851. [pmid: 1942452].
Cleary M, Edwards C, Meehan T. Factors influencing nurse-patient interaction in the acute psychiatric setting: an exploratory investigation. Aust N Z J Ment Health Nurs. 1999;8(3):109-16. [pmid: 10661080].
Cleary P D, Edgman-Levitan S, Roberts M, et al. Patients evaluate their hospital care: a national survey. Health Aff. 1991;10(4):254-67.
Clever L H. Some things have not changed. Ann Intern Med. 2000;132(1):85-9. [pmid: 10627257].
Cochrane Collaboration Secretatiat. The Cochrane manual. Oxford, UK: The Cochrane Library; 2002.
Cohen A. An examination of the relationship between work commitment and work outcomes among hospital nurses. Scan J Manage. 1998;14(12):1-17.
Coile RC, Jr. Competing by design: hospitals of the future offer healing environments. Russ Coiles Health Trends 2001;13(11):1, 4–8.
Coker RJ and Poznansky MC. Physicians' experience and survival in patients with AIDS. N Engl J Med 1996;335(5):349; discussion 350–1.
Collette C L, Costa M J, Guglielmi C L. Ambulatory surgery approach fosters excellence in patient-centered care and a better workplace. AORN J. 1999;70(1):115-9. [pmid: 10429792].
Collins J F, Ellsworth R B, Casey N A, et al. Treatment characteristics of psychiatric programs that correlate with patient community adjustment. J Clin Psychol. 1985;41(3):299-308. [pmid: 2860129].
Comer M B, Newman D K, George N D, et al. Who should manage primary retinal detachments?. Eye. 2000;14(Pt 4):572-8. [pmid: 11040902].
Conti A, Beare P G. Performance on a mathematics/drug calculation test: relationship to subsequent reported medication errors. J Nurs Staff Dev. 1988;4(2):54-8. [pmid: 3357048].
Cook DJ, Mulrow CD and R.B. H. Systematic reviews: synthesis of best evidence for clinical decisions. Ann Intern Med 1997;126(5):376–80.
Cook R I, Render M, Woods D D. Gaps in the continuity of care and progress on patient safety. BMJ. 2000;320(7237):791-4. [pmid: 10720370].
Cook RI and Woods DD. Operating at the sharp end: The complexity of human error. In: Bogner, MS, editor. Human error in medicine. Hillsdale, NJ ; Hillsdale, NJ: Lawrence Erlbaum Associates, Inc; Lawrence Erlbaum Associates, Inc; 1994. p. 255–310.
Cooke M. Supporting health care workers in the treatment of HIV-infected patients. Prim Care. 1992;19(1):245-56. [pmid: 1594701].
Cookson S T, Ihrig M, O'Mara E M, et al. Increased bloodstream infection rates in surgical patients associated with variation from recommended use and care following implementation of a needleless device. Infect Control Hosp Epidemiol. 1998;19(1):23-7. [pmid: 9475345].
Cooper A, Hannan EL, Bessey PQ, et al. An examination of the volume-mortality relationship for New York State trauma centers. J Trauma Inj Infect Crit Care 2000;48(1):16–23; discussion 23–4.
Cooper C L, Rout U, Faragher B. Mental health, job satisfaction, and job stress among general practitioners. BMJ. 1989;298(6670):366-70. [pmid: 2493939].
Cooper J B, Newbower R S, Kitz R J. An analysis of major errors and equipment failures in anesthesia management: considerations for prevention and detection. Anesthesiology. 1984;60(1):34-42. [pmid: 6691595].
Cooper J B, Newbower R S, Long C D, et al. Critical incidents associated with intraoperative changes of anesthesia personnel. Anesthesiology. 1982;56:456-461. [pmid: 7081730].
Copeland G P, Sagar P, Brennan J, et al. Risk-adjusted analysis of surgeon performance: a 1-year study. Br J Surg. 1995;82(3):408-11. [pmid: 7796028].
Corrigan J M, Martin J B. Identification of factors associated with hospital readmission and development of a predictive model. Health Serv Res. 1992;27(1):81-101. [pmid: 1563955].
Cote CJ. Patient safety and scented pediatric anesthesia facemasks. J Clin Anesth 1998;10(3):262; discussion 262–3.
Cote C J, Notterman D A, Karl H W, et al. Adverse sedation events in pediatrics: a critical incident analysis of contributing factors. Pediatrics. 2000;105(4 Pt 1):805-14. [pmid: 10742324].
Counsell S R, Holder C M, Liebenauer L L, et al. Effects of a multicomponent intervention on functional outcomes and process of care in hospitalized older patients: a randomized controlled trial of Acute Care for Elders (ACE) in a community hospital. J Am Geriatr Soc. 2000;48(12):1572-81. [pmid: 11129745].
Covinsky K E, Palmer R M, Kresevic D M, et al. Improving functional outcomes in older patients: lessons from an acute care for elders unit. Jt Comm J Qual Improv. 1998;24(2):63-76. [pmid: 9547681].
Cragg D K, McKinley R K, Roland M O, et al. Comparison of out of hours care provided by patients' own general practitioners and commercial deputising services: a randomised controlled trial. I: The process of care. BMJ. 1997;314(7075):187-9. [pmid: 9022434].
Crawshaw R. Patient-physician covenant. JAMA. 1995;273(19):1553. [pmid: 7739086].
Criss E. Latex allergies. A growing concern for both EMS providers & patients. J Emerg Med Serv JEMS. 2000;25(10):42-9. [pmid: 11141765].
Crouch A G, Nimran U. Perceived facilitators and inhibitors of work performance in an office environment. Environ Behav. 1989;21(2):206-226.
Crowe H M, Lichtenberg D A, Craven D E. Nosocomial infection in adult patients with sickle cell anemia. Infect Control Hosp Epidemiol. 1988;9(9):405-8. [pmid: 3171139].
Cullen D J, Sweitzer B J, Bates D W, et al. Preventable adverse drug events in hospitalized patients: a comparative study of intensive care and general care units. Crit Care Med. 1997;25(8):1289-97. [pmid: 9267940].
Cuschieri A. Human reliability assessment in surgery--a new approach for improving surgical performance and clinical outcome. Ann R Coll Surg Engl. 2000;82(2):83-7. [pmid: 10743422].
Czaplinski C, Diers D. The effect of staff nursing on length of stay and mortality. Med Care. 1998;36(12):1626-38. [pmid: 9860053].
Dahl R W. Creating the environment necessary to ensure quality patient care in the community setting. Seminars for Nurse Managers. 1995;3(3):146-51. [pmid: 7552457].
Daponte A, Guidozzi F, Marineanu A. Maternal mortality in a tertiary center after introduction of free antenatal care. Int J Gynaecol Obstet. 2000;71(2):127-33. [pmid: 11064009].
Darchy B, Le Miere E, Figueredo B, et al. Iatrogenic diseases as a reason for admission to the intensive care unit: incidence, causes, and consequences. Arch Intern Med. 1999;159(1):71-8. [pmid: 9892333].
David F R, Pearce J A, Randolph W. Linking technology and structure to enhance group performance. J Appl Psychol. 1989;74(2):233-241.
Davies H T O, Nutler S M, Mannion R. Organizational culture and quality of health care. Qual Health Care. 2000;9(2):111-9. [pmid: 11067249].
Davies J, Tamhane R, Scholefield C, et al. Does the introduction of HDU reduce surgical mortality?. Ann R Coll Surg Engl. 1999;81(5):343-7. [pmid: 10645179].
Davis J B. Channeling calm. Hospitals turn to innovative TV to promote healing in their patients. Mod Healthc. 2001;31(22):26. [pmid: 11409252].
Davis M Z. The organizational, interactional and care-oriented conditions for patient participation in continuity of care: a framework for staff intervention. Soc Sci Med. 1980;14A(1):39-47. [pmid: 7367916].
Davis NM. Detection and prevention of ambulatory care pharmacy dispensing errors. Hosp Pharm 1990;25(1):18–22, 28.
Davis N M. Concentrating on interruptions. Am J Nurs. 1994;94(3):14.
Davis NM and Cohen MR. Distractions as a cause of error. Am Pharm 1995;NS35(6):11.
Davis S H. The use of registry nurses in critical care: a cost-benefit analysis. Dimens Crit Care Nurs. 1982;1(2):88-96. [pmid: 6813086].
Davis T R. The influence of the physical environment in offices. Acad Manage Rev. 1984;9(2):271-283. [pmid: 10266030].
Davis-Smith C. Patient safety and clinical engineering. Biomed Instrum Technol. 2000;34(3):151-2. [pmid: 10868257].
Dawdy M R, Munter D W, Gilmore R A. Correlation of patient entry rates and physician documentation errors in dictated and handwritten emergency treatment records. Am J Emerg Med. 1997;15(2):115-7. [pmid: 9115506].
Dawes B S. World Conference on Surgical Patient Care--XI brings nurses together to define essence of patient care. Sunday, July 25, to Friday, July 30, 1999. AORN J. 1999;70(4):593-607. [pmid: 10610669].
Day K, Carreon D, Stump C. The therapeutic design of environments for people with dementia: a review of the empirical research. Gerontologist. 2000;40(4):397-416. [pmid: 10961029].
de Leval M R. Human factors and surgical outcomes: a Cartesian dream. Lancet. 1997;349(9053):723-5. [pmid: 9078214].
de Wildt G, Heath I, Gill P. Performance of doctors. Lancet. 1999;354(9173):165. [pmid: 10408520].
Dean P J, Dean M R, Rebalsky R M. Employee perceptions of workplace factors that will most improve their performance. Perform Improv Q. 1996;9(2):75-89.
Degoulet P, Chatellier G, Devries C, et al. Computer-assisted techniques for evaluation and treatment of hypertensive patients. Am J Hypertens. 1990;3(2):156-63. [pmid: 2407267].
DeHaemer M J, Wallace W A. The effects on decision task performance of computer synthetic voice output. Int J Man Mach Stud. 1992;36(1):65-80.
DeLamielleure J L. The impact of surgical physician assistants on the delivery of modern healthcare. Best Pract Benchmarking Healthc. 1997;2(3):136-41. [pmid: 9304909].
Dellefield M E. The relationship between nurse staffing in nursing homes and quality indicators: a literature review. J Gerontol Nurs. 2000;26(6):14-28. [pmid: 11249266].
Demerouti E, Bakker A B, Nachreiner F, et al. A model of burnout and life satisfaction amongst nurses. J Adv Nurs. 2000;32(2):454-64. [pmid: 10964195].
Demerouti E, Bakker A B, Nachreiner F, et al. The job demands-resources model of burnout. J App Psychol. 2001;86(3):499-512.
Denison D R. What is the difference between organization culture and organizational climate? A native's point of view on a decade of paradigm wars. Acad Manage Rev. 1996;21(3):619-654.
DePasquale J P, Geller E S. Critical success factors for behavior-based safety: A study of twenty industry-wide applications. J Safe Res. 1999;30(4):237-249.
Derman H. Quality and liability issues with the Papanicolaou smear: lessons from the science of error prevention. Arch Path Lab Med. 1997;121(3):287-91. [pmid: 9111120].
DeVoe J, Fryer G E J, Hargraves J L, et al. Does career dissatisfaction affect the ability of family physicians to deliver high-quality patient care?. J Fam Pract. 2002;51(3):223-228. [pmid: 11978232].
Dewhurst A G, Cooper M J, Khan S M, et al. Invasive aspergillosis in immunosuppressed patients: potential hazard of hospital building work. BMJ. 1990;301(6755):802-4. [pmid: 2224271].
Dharan S, Mourouga P, Copin P, et al. Routine disinfection of patients' environmental surfaces. Myth or reality?. J Hosp Infect. 1999;42(2):113-7. [pmid: 10389060].
Dick W, Eberle B, Friesdorf W. Future working conditions of anesthesiologists. Attempt at an analysis. Anaesthesist. 1987;36(1):1-8. [pmid: 3555150].
Diehl A E. Human performance and systems safety considerations in aviation mishaps. Int J Aviat Psychol. 1991;1(2):97-106.
Diem S J, Prochazka A V, Meyer T J. Effects of a postdischarge clinic on housestaff satisfaction and utilization of hospital services. J Gen Intern Med. 1996;11(3):179-181. [pmid: 8667097].
Diffey B L. The suitability of sunglasses worn by PUVA patients. Br J Dermatol. 1988;119(4):553-4. [pmid: 3191024].
Dimick J B, Swoboda S M, Provonost P J, et al. Effect of nurse-to-patient ratio in the intensive care unit on pulmonary complications and resource use after hepatectomy. Am J Crit Care. 2001;10(6):376-382. [pmid: 11688604].
Dinges D F, Whitehouse W G, Orne E C, et al. The benefits of a nap during prolonged work and wakefulness. Work Stress. 1988;2(2):139-153.
Disch J. The nurse executive. Healthy work environments for all nurses. J Prof Nurs. 2000;16(2):75. [pmid: 10748567].
Dismukes K, Young G and Sumwalt R. Cockpit interruptions and distractions: effective management requires a careful balancing act. ASRS Directline 1998;Dec:4–9.
Dojat M, Brochard L, Lemaire F, et al. A knowledge-based system for assisted ventilation of patients in intensive care units. Int J Clin Monit Comput. 1992;9(4):239-50. [pmid: 1484275].
Donaldson N E, Brown D S, Aydin C E, et al. Nurse staffing in California hospitals 1998-2000: findings from the California Nursing Outcomes Coalition Database Project. Policy Politics Nurs Prac. 2001;2(1):19-28.
Donchin Y, Gopher D, Olin M, et al. A look into the nature and causes of human errors in the intensive care unit. Crit Care Med. 1995;23(2):294-300. [pmid: 7867355].
Donderi D C. Visual acuity, color vision, and visual search performance at sea. Hum Factors. 1994;36(1):129-144. [pmid: 8026836].
Doolin EJ, Browne AM and DiScala C. Pediatric trauma center criteria: an outcomes analysis. J Pediatr Surg 1999;34(5):885–9; discussion 889–90.
Dornheim M A. Crew distractions emerge as new safety focus. Aviat Wk Space Technol. 2000;153(3):58-60.
Dorrance H R, Docherty G M, O'Dwyer P J. Effect of surgeon specialty interest on patient outcome after potentially curative colorectal cancer surgery. Dis Colon Rectum. 2000;43(4):492-8. [pmid: 10789744].
Doyle D J, Vicente K J. Patient-controlled analgesia. CMAJ. 2001;164(5):620-1. [pmcid: 80811]. [pmid: 11258206].
Dracup K, Bryan-Brown C W. Intensive care units: achieving utopia. Am J Crit Care. 1999;8(2):68-9. [pmid: 10071695].
Dreyfuss D, Djedaini K, Gros I, et al. Mechanical ventilation with heated humidifiers or heat and moisture exchangers: effects on patient colonization and incidence of nosocomial pneumonia. Am J Respir Crit Care Med. 1995;151(4):986-92. [pmid: 7697277].
Driscoll P A, Vincent C A. Variation in trauma resuscitation and its effect on patient outcome. Injury. 1992;23(2):111-5. [pmid: 1572705].
Drury C G. The Ergonomics Society Lecture 1996: Ergonomics and the quality movement. Ergonomics. 1997;40(3):249-264.
du Moulin G C, Hedley-Whyte J. Bacterial interactions between anesthesiologists, their patients, and equipment. Anesthesiology. 1982;57(1):37-41. [pmid: 7046515].
Duffin C. Profile. US survey finds link between patient recovery and nurse numbers. Nurs Manage. 2000;7(3):4.
Duffy V G, Salvendy G. The impact of organizational ergonomics on work effectiveness: with special reference to concurrent engineering in manufacturing industries. Ergonomics. 1999;42(4):614-628.
Dugan J, Lauer E, Bouquot Z, et al. Stressful nurses: the effect on patient outcomes. J Nurs Care Qual. 1996;10(3):46-58. [pmid: 8634470].
Duguay D. Job satisfaction from job safety. Occup Health Nurs. 1981;29(10):38-42. [pmid: 6912965].
Dyer C. Bristol inquiry condemns hospital's “club culture”. BMJ. 2001;323(7306):181. [pmid: 11473900].
Dyson M. Intensive care unit psychosis, the therapeutic nurse-patient relationship and the influence of the intensive care setting: analyses of interrelating factors. J Clin Nurs. 1999;8(3):284-90. [pmid: 10578751].
Eagle K A, Mulley A G, Skates S J, et al. Length of stay in the intensive care units. Effects of practice guidelines and feedback. JAMA. 1990;264:992-997. [pmid: 2376892].
Eaton P, Gottselig S. Effects of longer hours, shorter week for intensive care nurses. Dimens Health Serv. 1980;57(8):25-7. [pmid: 7429054].
Edelson J T. Physician use of information technology in ambulatory medicine: an overview. J Ambul Care Manage. 1995;18(3):9-19. [pmid: 10143483].
Edkins G D, Pollock C M. The influence of sustained attention on railway accidents. Accid Anal Prev. 1997;29(4):533-539. [pmid: 9248512].
Edlin B R, Tokars J I, Grieco M H, et al. An outbreak of multidrug-resistant tuberculosis among hospitalized patients with the acquired immunodeficiency syndrome. N Engl J Med. 1992;326(23):1514-21. [pmid: 1304721].
Edmondson A C. Learning from mistakes is easier said than done: Group and organizational influences on the detection and correction of human error. J Appl Behav Sci. 1996;32(1):5-28.
Edwards J R, Scully J A, Brtek M D. The nature and outcomes of work: a replication and extension of interdisciplinary work-design research. J Appl Psychol. 2000;85(6):860-868. [pmid: 11125651].
Edwardson SR. Relationship of nurse staffing to patient outcome in coronary care: some preliminary findings. NLN Publications 1987(20-2191):299–318.
Eklund J A E. Relationships between ergonomics and quality in assembly work. Appl Ergon. 1995;26(1):15-20. [pmid: 15676996].
Eldar S, Kunin J, Chouri H, et al. Safety of laparoscopic cholecystectomy on a teaching service: a prospective trial. Surg Laparosc Endosc Percut Tech. 1996;6(3):218-20.
Ellenbecker C H, Warren K. Nursing practice and patient care in a changing home healthcare environment. Home Healthc Nurse. 1998;16(8):531-9. [pmid: 9807300].
Ellis J I. Stabilizing and resuscitating patients with automatic implantable cardioverter-defibrillators. West J Med. 1993;159(5):595-6. [pmid: 8279158].
Ellis S G. Expertise in primary angioplasty--implications for optimal patient care. J Invasive Card. 2000;12(6):309-10.
Ellis S G, Weintraub W, Holmes D, et al. Relation of operator volume and experience to procedural outcome of percutaneous coronary revascularization at hospitals with high interventional volumes. Circulation. 1997;95(11):2479-84. [pmid: 9184577].
Elson R B, Connelly D P. Computerized patient records in primary care. Their role in mediating guideline-driven physician behavior change. Arch Fam Med. 1995;4(8):698-705. [pmid: 7620600].
Ely J W, Levinson W, Elder N C, et al. Perceived causes of family physicians' errors. J Fam Pract. 1995;40(4):337-44. [pmid: 7699346].
Enander A. Performance and sensory aspects of work in cold environments: A review. Ergonomics. 1984;27(4):365-378. [pmid: 6734591].
Enander A. Effects of moderate cold on performance of psychomotor and cognitive tasks. Ergonomics. 1987;30(10):1431-1445. [pmid: 3428250].
Enander AE. Effects of thermal stress on human performance. Scand J Work Environ Health 1989;15(Suppl 1) 1989(Suppl 1):27–33.
Enander AE and Hygge S. Thermal stress and human performance. Scand J Work Environ Health 1990;16(Suppl 1) 1990(Suppl 1):44–50.
Engle J H, Ploessl J, Sutton R. Oxygenator evaluation: Maxima 1380 versus Maxima Plus. J Extra Corpor Technol. 1995;27(1):15-8. [pmid: 10150756].
Enser J, Maclnnes D. The relationship between building design and escapes from secure units. J R Soc Health. 1999;119(3):170-4.
Eriksen L R, Quandt B, Teinert D, et al. A registered nurse-licensed vocational nurse partnership model for critical care nursing. J Nurs Adm. 1992;22(12):28-38. [pmid: 1469485].
Eurlings F, van Asten A, Cozijn H, et al. Effects of a nursing information system in 5 Dutch hospitals. Stud Health Technol Inf. 1997;46:50-5.
Evans O, Steptoe A. The contribution of gender-role orientation, work factors and home stressors to psychological well-being and sickness absence in male- and female-dominated occupational groups. Soc Sci Med. 2002;54(4):481-92. [pmid: 11848269].
Evans R S, Pestotnik S L, Burke J P, et al. Reducing the duration of prophylactic antibiotic use through computer monitoring of surgical patients. DICP. 1990;24(4):351-4. [pmid: 2327113].
Every N R, Maynard C, Schulman K, et al. The association between institutional primary angioplasty procedure volume and outcome in elderly Americans. J Invasive Card. 2000;12(6):303-8.
Eyrolle H, Cellier J M. The effects of interruptions in work activity: field and laboratory results. Appl Ergon. 2000;31(5):537-43. [pmid: 11059468].
Ezell M, Menefee D, Patti R J. Managerial leadership and service quality: toward a model of social work administration. Admin Soc Work. 1989;13(34):73-98.
Facchinetti N J, Campbell G M, Jones D P. Evaluating dispensing error detection rates in a hospital pharmacy. Med Care. 1999;37(1):39-43. [pmid: 10413391].
Fairbanks J E. Primary nursing: more data. Nurs Adm Q. 1981;5(3):51-62. [pmid: 6909580].
Farbstein K, Clough J. Improving medication safety across a multihospital system. Jt Comm J Qual Improv. 2001;27(3):123-37. [pmid: 11242719].
Fauber W S, Cosnotti S J, Mady R L. Offsite intravenous admixture center shared by health-system facilities. Am J Health Syst Pharm. 1995;52(22):2550-5. [pmid: 8590238].
Feachem R G A, Sekhri N K, White K L. Getting more for their dollar: a comparison of the NHS with California's Kaiser Permanente. BMJ. 2002;324(7330):135-43. [pmcid: 64512]. [pmid: 11799029].
Feather J. Factors in perceived hospital discharge planning effectiveness. Soc Work Health Care. 1993;19(1):1-14. [pmid: 8296219].
Federman D, Hogan D, Taylor J R, et al. A comparison of diagnosis, evaluation, and treatment of patients with dermatologic disorders. J Am Acad Dermatol. 1995;32(5 Pt 1):726-9. [pmid: 7722015].
Federman D G, Kirsner R S. The primary care physician and the treatment of patients with skin disorders. Dermatol Clin. 2000;18(2):215-21. [pmid: 10791147].
Felver L. Patient-environment interactions in critical care. Crit Care Nurs Clin North Am. 1995;7(2):327-35. [pmid: 7619375].
Fenyo G, Clamp S E, de Dombal F T, et al. Computer-aided diagnosis of 233 acute abdominal cases at Nacka Hospital Sweden. Sand J Gastroenterol Suppl. 1987;128:178.
Fernandez C V. Can we prevent cytotoxic disasters?. Br J Haematol. 2000;108(3):464-9. [pmid: 10759700].
Field L. Are nurses still underestimating patients' pain postoperatively?. Br J Nurs. 1996;5(13):778-84. [pmid: 8974522].
Firestone A R, Sema D, Heaven T J, et al. The effect of a knowledge-based, image analysis and clinical decision support system on observer performance in the diagnosis of approximal caries from radiographic images. Caries Res. 1998;32(2):127-34. [pmid: 9544861].
Firriolo F J, Wang T. Diagnosis of selected pulpal pathoses using an expert computer system. Oral Surg Oral Med Oral Pathol. 1993;76(3):390-6. [pmid: 8378060].
Firth-Cozens J, Greenhalgh J. Doctors' perceptions of the links between stress and lowered clinical care. Soc Sci Med. 1997;44(7):1017-22. [pmid: 9089922].
Fischer G, Fetters M D, Munro A P, et al. Adverse events in primary care identified from a risk-management database. J Fam Pract. 1997;45:40-46. [pmid: 9228913].
Fitzpatrick J M, While A E, Roberts J D. The measurement of nurse performance and its differentiation by course of preparation. J Adv Nurs. 1994;20(4):761-8. [pmid: 7822614].
Fleischer A B Jr, Feldman S R, Barlow J O, et al. The specialty of the treating physician affects the likelihood of tumor-free resection margins for basal cell carcinoma: results from a multi-institutional retrospective study. J Am Acad Dermatol. 2001;44(2):224-30. [pmid: 11174379].
Fleming S T, Boles K E. Financial and clinical performance: bridging the gap. Health Care Manage Rev. 1994;19(1):11-7. [pmid: 8206757].
Fletcher C E. Failure mode and effects analysis. An interdisciplinary way to analyze and reduce medication errors. J Nurs Adm. 1997;27(12):19-26. [pmid: 9418753].
Flood SD and Diers D. Nurse staffing, patient outcome and cost. Nurs Manage 1988;19(5):34–5, 38–9, 42–3.
Flynn E A, Barker K N, Gibson J T, et al. Impact of interruptions and distractions on dispensing errors in an ambulatory care pharmacy. Am J Health Syst Pharm. 1999;56(13):1319-25. [pmid: 10683129].
Flynn E A, Barker K N, Gibson J T, et al. Relationships between ambient sounds and the accuracy of pharmacists' prescription-filling performance. Hum Factors. 1996;38(4):614-622. [pmid: 8976624].
Flynn E A, Barker K N, Pepper G A, et al. Comparison of methods for detecting medication errors in 36 hospitals and skilled-nursing facilities. Am J Health Syst Pharm. 2002;59:436-46. [pmid: 11887410].
Folkard S. Black times: temporal determinants of transport safety. Accid Anal Prev. 1997;29(4):417-30. [pmid: 9248500].
Fontanesi J, De Guire M, Chiang J, et al. Applying workflow analysis tools to assess immunization delivery in outpatient primary care settings. Jt Comm J Qual Improv. 2000;26(11):654-60. [pmid: 11098428].
Fottler MD, Ford RC, Roberts V, et al. Creating a healing environment: the importance of the service setting in the new consumer-oriented healthcare system. J Healthc Manage 2000;45(2):91–106; discussion 106–7.
Fowler B, Bock O, Comfort D. Is dual-task performance necessarily impaired in space?. Hum Factors. 2000;42(2):318-326. [pmid: 11022887].
Fox D, Byrne V, Rouault F. Performance improvement: what to keep in mind. Train Dev. 1999;53(8):38-40.
Fox G N. Minimizing prescribing errors in infants and children. Am Fam Physician. 1996;53(4):1319-25. [pmid: 8629575].
Francois P, Robert C, Astruc J, et al. Comparative study of human expertise and an expert system: application to the diagnosis of child's meningitis. Comput Biomed Res. 1993;26(4):383-92. [pmid: 8403861].
Frederick JL and Duffy T. Responsive design in HIV/AIDS facilities. Health Facil Manage 1996;9(1):22, 24, 26.
Frey B, Kehrer B, Losa M, et al. Comprehensive critical incident monitoring in a neonatal-pediatric intensive care unit: experience with the system approach. Intensive Care Med. 2000;26(1):69-74. [pmid: 10663283].
Fridkin S K, Pear S M, Williamson T H, et al. The role of understaffing in central venous catheter-associated bloodstream infections. Infect Control Hosp Epidemiol. 1996;17:150-158. [pmid: 8708352].
Friedemann M L. Do nurse clinicians influence the working climate and the quality of care? 2. Results. Pflege. 1997;10(3):132-7. [pmid: 9239076].
Funk M, Parkosewich J A, Johnson C R, et al. Effect of dedicated monitor watchers on patients' outcomes. Am J Crit Care. 1997;6(4):318-23. [pmid: 9215430].
Fuss M A, Bryan Y E, Hitchings K S, et al. Measuring critical care redesign: impact on satisfaction and quality. Nurs Adm Q. 1998;23(1):1-14. [pmid: 9856048].
Gaba D M. Anaesthesiology as a model for patient safety in health care. BMJ. 2000;320(7237):785-8. [pmid: 10720368].
Galinsky T L, Swanson N G, Sauter S L, et al. A field study of supplementary rest breaks for data-entry operators. Ergonomics. 2000;43(5):622-638. [pmid: 10877480].
Gallagher M. Not-so-friendly faces. Psychol Today. 1999;32(3):14.
Gander P H, Graeber R, Connell L J, et al. Flight crew fatigue I: Objectives and methods. Aviat Space Environ Med. 1998;69(9):B1-B7. [pmid: 9749935].
Gander P H, Merry A, Millar M M, et al. Hours of work and fatigue-related error: a survey of New Zealand anaesthetists. Anaesth Intensive Care. 2000;28(2):178-83. [pmid: 10788970].
Gardella A. Tracking ED patients without task-specific computer software. J Emerg Nurs. 1999;25(5):397-400. [pmid: 10508466].
Gardner K. A summary of findings of a five-year comparison study of primary and team nursing. Nurs Res. 1991;40(2):113-7. [pmid: 2003070].
Gardner RL. Benchmarking organizational culture: Organizational as an primary factor in safety performance. Prof Saf 1999:26–32.
Gast P L, Baker C F. The CCU patient: anxiety and annoyance to noise. Crit Care Nurs Q. 1989;12(3):39-54. [pmid: 2819537].
Gathers B. Implementing nursing diagnosis in the hospital setting: a model program. J Adv Med Surg Nurs. 1989;1(3):21-31. [pmid: 2746188].
Gawande A, Thoma E, Zinner M, et al. The incidence and nature of surgical adverse events in Colorado and Utah. Surgery. 1999;126(1):66-75. [pmid: 10418594].
Gawron VJ, Dennison TW and Biferno MA. Mockups, physical and electronic human models, and simulations. In: O'Brien, TG and Charlton, SG, editors. Handbook of human factors testing and evaluation. Hillsdale, NJ: Lawrence Erlbaum Associates, Inc; 1996. p. 43–80.
Gemmill J D, Lifson W K, Rae A P, et al. Assessment by general practitioners of suitability of thrombolysis in patients with suspected acute myocardial infarction. Br Heart J. 1993;70(6):503-6. [pmid: 8280513].
Gerbert B, Maurer T, Berger T, et al. Primary care physicians as gatekeepers in managed care. Primary care physicians' and dermatologists' skills at secondary prevention of skin cancer. Arch Dermatol. 1996;132(9):1030-8. [pmid: 8795541].
Gershon R R, Karkashian C D, Grosch J W, et al. Hospital safety climate and its relationship with safe work practices and workplace exposure incidents. Am J Infect Control. 2000;28(3):211-21. [pmid: 10840340].
Gibbs I, McCaughan D, Griffiths M. Skill mix in nursing: a selective review of the literature. J Adv Nurs. 1991;16(2):242-9. [pmid: 2013667].
Gillespie A, Curzio J. A comparison of a 12-hour and eight-hour shift system. Nurs Times. 1996;92(39):36-9. [pmid: 8949104].
Gilpin K, Rundell V M. ANA House of Delegates report. Calls for improvements in RN working conditions and patient safety. Kans Nurs. 2000;75(7):4-5.
Giraud T, Dhainaut J, Vaxelaire J, et al. Iatrogenic complications in adult intensive care units: a prospective two-center study. Crit Care Med. 1993;21(1):40-51. [pmid: 8420729].
Gladstone J. Drug administration errors: a study into the factors underlying the occurrence and reporting of drug errors in a district general hospital. J Adv Nurs. 1995;22(4):628-37. [pmid: 8708180].
Glavin MP and Chilingerian JA. Hospital care production and medical errors: Organizational responses to improve care. In: Rahim, M. Afzalur (Ed); Golembiewski, Robert T. (Ed); et al. (1998). Current topics in management, Vol. 3. Stamford, CT: JAI Press, Inc; 1998. p. 193–215.
Glazner J E, Borgerding J, Bondy J, et al. Contractor safety practices and injury rates in construction of the Denver International Airport. Am J Ind Med. 1999;35(2):175-85. [pmid: 9894541].
Gnauck K, Lungo J B, Scalzo A, et al. Emergency intubation of the pediatric medical patient: use of anesthetic agents in the emergency department. Ann Emerg Med. 1994;23(6):1242-7. [pmid: 8198297].
Gold D R, Rogacz S, Bock N, et al. Rotating shift work, sleep, and accidents related to sleepiness in hospital nurses. Am J Public Health. 1992;82(7):1011-4. [pmid: 1609900].
Goldberg H I, Rund D A, Hopkins J R. The Midpeninsula Health Service: action research using small primary care groups to provide evidence-based medicine that empowers patients while continuously improving quality and lowering costs. Med Care. 2002;40(4 Suppl):1132-1139.
Goldstein E T. Outcomes of anorectal disease in a health maintenance organization setting. The need for colorectal surgeons. Dis Colon Rectum. 1996;39(11):1193-8. [pmid: 8918423].
Goodman S A, Svyantek D J. Person-organization fit and contextual performance: Do shared values matter. J Vocat Behav. 1999;55(2):254-275.
Goodwin A T, Birdi I, Ramesh T P, et al. Effect of surgical training on outcome and hospital costs in coronary surgery. Heart. 2001;85(4):454-7. [pmid: 11250976].
Gordon T A, Bowman H M, Bass E B, et al. Complex gastrointestinal surgery: impact of provider experience on clinical and economic outcomes. J Am Coll Surg. 1999;189(1):46-56. [pmid: 10401740].
Gosbee J W. Communication among health professionals. BMJ. 1998;316(7132):642. [pmid: 9522773].
Grabowski M, Roberts K H. Human and organizational error in large scale systems. IEEE Trans Syst Man Cybern. 1996;26(1):2-16.
Grad R, Tamblyn R, McLeod P J, et al. Does knowledge of drug prescribing predict drug management of standardized patients in office practice?. Med Educ. 1997;31(2):132-7. [pmid: 9231109].
Graham H, Livesley B. Can readmissions to a geriatric medical unit be prevented?. Lancet. 1983;1(8321):404-6. [pmid: 6130389].
Grasha A F, Schell K. Psychosocial factors, workload, and human error in a simulated pharmacy dispensing task. Percept Mot Skills. 2001;92(1):53-71. [pmid: 11322606].
Grasso BC and Genest R. Clinical computing: Use of a personal digital assistant in reducing medication error rates. Psychiatr Serv 2001;52(7):883–4, 886.
Graveley E A, Littlefield J H. A cost-effectiveness analysis of three staffing models for the delivery of low-risk prenatal care. Am J Public Health. 1992;82(2):180-4. [pmid: 1739143].
Graven SN. Clinical research data illuminating the relationship between the physical environment & patient medical outcomes. J Healthc Des 1997;9:15–9; discussion 21–4.
Gray B, Hsu J D, Furumasu J. Fractures caused by falling from a wheelchair in patients with neuromuscular disease. Dev Med Child Neurol. 1992;34(7):589-92. [pmid: 1387372].
Green J, Wintfeld N. Report cards on cardiac surgeons. Assessing New York State's approach. N Engl J Med. 1995;332(18):1229-32. [pmid: 7700321].
Green R. The psychology of human error. Eur J Anaesthesiol. 1999;16(3):148-55. [pmid: 10225162].
Green T P. Education, physician presence, and the quality of care in pediatric intensive care units. Crit Care Med. 1997;25(10):1621-2. [pmid: 9377867].
Greiner B A, Krause N, Ragland D R, et al. Objective stress factors, accidents, and absenteeism in transit operators: A theoretical framework and empirical evidence. J Occup Health Psych. 1998;3(2):130-146.
Griffin M A, Neal A. Perceptions of safety at work: a framework for linking safety climate to safety performance, knowledge, and motivation. J Occup Health Psych. 2000;5(3):347-58.
Griffith C H, Rich E C, Hillson S D, et al. Internal medicine residency training and outcomes. J Gen Intern Med. 1997;12(6):390-6. [pmid: 9192258].
Griffon-Fouco M and Ghertman F. Recueil de donnes sur les facteurs humains a Electricite de France. In: Operational safety of nuclear power plants. Vienna: International Atomic Energy Agency; 1984. p. 157–72.
Grove DD. Error in medicine. JAMA 1995;274(6):458–9; discussion 460–1.
Grover FL. The Society of Thoracic Surgeons National Database: current status and future directions. Ann Thorac Surg 1999;68(2):367–73; discussion 374–6.
Groves J E, Lavori P W, Rosenbaum J F. In-hospital injuries of medical and surgical patients: The predictive effect of a prior injury. Psychosom Med. 1992;54(3):264-274. [pmid: 1620803].
Guadagnoli E, Soumerai S B, Gurwitz J H, et al. Improving discussion of surgical treatment options for patients with breast cancer: local medical opinion leaders versus audit and performance feedback. Breast Cancer Res Treat. 2000;61(2):171-5. [pmid: 10942103].
Guarnieri M. Error in medicine. JAMA 1995;274(6):459; discussion 460–1.
Guldvog B. How do working conditions of hospital personnel affect patients?. Nord Med. 1997;112(7):246-51. [pmid: 9380492].
Gulick E E, Yam M, Touw M M. Work performance by persons with multiple sclerosis: Conditions that impede or enable the performance of work. Int J Nurs Stud. 1989;26(4):301-311. [pmid: 2613450].
Guzzo RA and Gannett BA. The nature of facilitators and inhibitors of effective task performance. In: Schoorman, FD and Schneider, B, editors. Facilitating work effectiveness. Issues in organization and management series. Lexington, MA: Lexington Books; 1988. p. 21–41.
Hackel R, Butt L and Banister G. How nurses perceive medication errors. Nurs Manage 1996;27(1):31, 33–4.
Haddon W. A logical framework for categorizing highway safety phenomena and activity. J Trauma. 1972;12:197-207.
Haga S. An experimental study of signal vigilance errors in train driving. Ergonomics 1984;27(7) Jul 1984(7):755–765.
Hahn J E, Jones M R, Waszkiewicz M. Renovation of a semiprivate patient room. Bowman Center Geriatric Rehabilitation Unit. Nurs Clin North Am. 1995;30(1):97-115. [pmid: 7885928].
Halbur B T, Fears N. Nursing personnel turnover rates turned over: potential positive effects on resident outcomes in nursing homes. Gerontologist. 1986;26(1):70-6. [pmid: 3699484].
Hall J M, Stevens P E, Meleis A I. Experiences of women clerical workers in patient care areas. J Nurs Adm. 1992;22(5):11-7. [pmid: 1578283].
Hallberg I R. Systematic clinical supervision in a child psychiatric ward: satisfaction with nursing care, tedium, burnout, and the nurses' own report on the effects of it. Arch Psychiatr Nurs. 1994;8(1):44-52. [pmid: 8203944].
Halm E A, Chassin M R. Why do hospital death rates vary? [letter; comment]. N Engl J Med. 2001;345(9):692-4. [pmid: 11547726].
Halm EA, Lee C and Chassin M. How is volume related to quality in health care? A systematic review of the literature: Institute of Medicine; 2000.
Halpern M T, Palmer C S, Simpson K N, et al. The economic and clinical efficiency of point-of-care testing for critically ill patients: a decision-analysis model. Am J Med Qual. 1998;13(1):3-12. [pmid: 9509589].
Halpert A P, Pearson S D, LeWine H E, et al. The impact of an inpatient physician program on quality, utilization, and satisfaction. Am J Manag Care. 2000;6(5):549-55. [pmid: 10977463].
Halvorsen J G, Kunian A, Gjerdingen D, et al. The interpretation of office radiographs by family physicians. J Fam Pract. 1989;28(4):426-32. [pmid: 2703813].
Hammer J S, et al. Measurement of occupational stress in hospital settings: Two validity studies of a measure of self-reported stress in medical emergency rooms. Gen Hosp Psychiatry. 1985;7(2):156-162. [pmid: 3996905].
Hammond C J, Shackleton J, Flanagan D W, et al. Comparison between an ophthalmic optician and an ophthalmologist in screening for diabetic retinopathy. Eye. 1996;10(Pt 1):107-12. [pmid: 8763314].
Hampers L C, Cha S, Gutglass D J, et al. Fast track and the pediatric emergency department: resource utilization and patients outcomes. Acad Emerg Med. 1999;6(11):1153-9. [pmid: 10569389].
Hancock PA and Vasmatzidis I. Human occupational and performance limits under stress: The thermal environment as a prototypical example. Ergonomics 1998;41(8) Aug 1998(8):1169–1191.
Hannan E L. Percutaneous coronary interventions: heed the American College of Cardiology volume recommendations, but strive to improve quality. J Am Coll Cardiol. 1999;34(5):1481-3. [pmid: 10551695].
Hannan E L, Racz M, Kavey R E, et al. Pediatric cardiac surgery: the effect of hospital and surgeon volume on in-hospital mortality. Pediatrics. 1998;101(6):963-9. [pmid: 9606220].
Hannan E L, Siu A L, Kumar D, et al. The decline in coronary artery bypass graft surgery mortality in New York State. The role of surgeon volume. JAMA. 1995;273(3):209-13. [pmid: 7807659].
Hansen F R, Spedtsberg K, Schroll M. Geriatric follow-up by home visits after discharge from hospital: a randomized controlled trial. Age Ageing. 1992;21(6):445-50. [pmid: 1471584].
Hansson L E, Ekstrom A M, Bergstrom R, et al. Surgery for stomach cancer in a defined Swedish population: current practices and operative results. Swedish Gastric Cancer Study Group. Eur J Surg. 2000;166(10):787-95. [pmid: 11071166].
Hargraves J L, Palmer R H, Orav E J, et al. Practice characteristics and performance of primary care practitioners. Med Care. 1996;34(9 Suppl):SS67-76. [pmid: 8792790].
Harris R P, Helfand M, Woolf S H, et al. Current methods of the third U.S. Preventive Services Task Force. Am J Prev Med. 2001;20(3S):21-35. [pmid: 11306229].
Harrison A J. Managing safety and health. Labor Law J. 1981;32(10):635-58. [pmid: 10253201].
Hart E, Hazelgrove J. Understanding the organisational context for adverse events in the health services: The role of cultural censorship. Qual Health Care. 2001;10(4):157-262.
Harter J K, Schmidt F L, Hayes T I. Business-unit-level relationship between employee satisfaction, employee engagement, and business outcomes: A meta-analysis. J Appl Psychol. 2002;87(2):268-279. [pmid: 12002955].
Hartz A J, Kranauer H, Kuhn E M, et al. Hospital characteristics and mortality rates. N Engl J Med. 1989;321:1720-1725. [pmid: 2594031].
Hartz A J, Kuhn E M, Kayser K L. Coronary artery bypass graft mortality: patient risk of physician practice? [letter; comment]. JAMA. 1993;270(24):2928. [pmid: 8254849].
Hartz A J, Kuhn E M, Pulido J. Prestige of training programs and experience of bypass surgeons as factors in adjusted patient mortality rates. Med Care. 1999;37(1):93-103. [pmid: 10413397].
Harvey R, Jarrett P G, Peltekian K M. Patterns of paging medical interns during night calls at two teaching hospitals. CMAJ. 1994;151:307-11. [pmid: 8039084].
Haug P J, Gardner R M, Tate K E, et al. Decision support in medicine: examples from the HELP system. Comput Biomed Res. 1994;27(5):396-418. [pmid: 7813202].
Havens D S, Aiken L H. Shaping systems to promote desired outcomes. The magnet hospital model. J Nurs Adm. 1999;29(2):14-20. [pmid: 10029797].
Hayes B E, Perandan J, Smecko T, et al. Measuring perceptions of workplace safety: Development and validation of the Work Safety Scale. J Safe Res. 1998;29(3):145-161.
Heath ED. Management interest, involvement in workplace safety, health grows. Occup Health Saf 1987;56(5):89–90, 92–3.
Heathfield H, Pitty D, Hanka R. Evaluating information technology in health care: barriers and challenges. BMJ. 1998;316:1959-61. [pmid: 9641938].
Hechanova-Alampay R, Beehr T. Empowerment, span of control, and safety performance in work teams after workforce reduction. J Occup Health Psych. 2001;6(4):275-282.
Hecht F M, Wilson I B, Wu A W, et al. Optimizing care for persons with HIV infection. Society of General Internal Medicine AIDS Task Force. Ann Intern Med. 1999;131(2):136-43. [pmid: 10419430].
Heck DA, Robinson RL, Partridge CM, et al. Patient outcomes after knee replacement. Clin Orthop 1998(356):93–110.
Held P J, Pauly M V, Diamond L. Survival analysis of patients undergoing dialysis. JAMA. 1987;257(5):645-50. [pmid: 3795446].
Helmreich R L. Culture and error in space: Implications from analog environments. Aviat Space Environ Med. 2000;71(9 Sect 2 Suppl):A133-9. [pmid: 10993326].
Helmreich R L. Education and debate. On error management: lessons from aviation. BMJ. 2000;320(7237):781-5. [pmid: 10720367].
Helmreich RL and Foushee HC. Why crew resource management? Empirical and theoretical bases of human factors training in aviation. In: Wiener, Earl L. (Ed); Kanki, Barbara G. (Ed); et al. Cockpit resource management. San Diego, CA, US: Academic Press, Inc; 1993. p. 3–45.
Helmreich RL and Merritt AC. Culture at work in aviation and medicine: national, organizational, and professional influences. Brookfield, VT: Ashgate; 1998.
Helmreich RL, Wilhelm JA, Kl iJR, et al. Culture, error, and crew resource management. In: Salas, Eduardo (Ed); Bowers, Clint A. (Ed); et al. (2001). Improving teamwork in organizations: Applications of resource management training. Mahwah, NJ, US; Mahwah, NJ, US: Lawrence Erlbaum Associates, Inc., Publishers; Lawrence Erlbaum Associates, Inc., Publishers; 2001. p. 305–331.
Henry B. Quality of care, health system errors, and nurses. J Adv Nurs. 2000;32(4):773. [pmid: 11095210].
Hertzer N R. Outcome assessment in vascular surgery--results mean everything. J Vasc Surg. 1995;21(1):6-15. [pmid: 7823363].
Hess S M, Detweiler M C, Ellis R D. The utility of display space in keeping track of rapidly changing information. Hum Factors. 1999;41(2):257-281.
Higgins G L 3rd, Lambrew C T, Hunt E, et al. Expediting the early hospital care of the adult patient with nontraumatic chest pain: impact of a modified ED triage protocol. Am J Emerg Med. 1993;11(6):576-82. [pmid: 8240555].
Hillner B E, Smith T J, Desch C E. Hospital and physician volume or specialization and outcomes in cancer treatment: importance in quality of cancer care. J Clin Oncol. 2000;18(11):2327-40. [pmid: 10829054].
Hillson S D, Rich E C, Dowd B, et al. Call nights and patients care: effects on inpatients at one teaching hospital. J Gen Intern Med. 1992;7(4):405-10. [pmid: 1506946].
Hillson S D, Rich E C, Dowd B E, et al. The impact of intern workload on length of hospital stay for elderly patients. Gerontol Geriatr Educ. 1993;14(2):33-41.
Hilton B A. Noise in acute patient care areas. Res Nurs Health. 1985;8(3):283-91. [pmid: 3852363].
Himmel W, Tabache M, Kochen M M. What happens to long-term medication when general practice patients are referred to hospital?. Eur J Clin Pharmacol. 1996;50(4):253-7. [pmid: 8803514].
Hinkle A J. Patient safety and scented pediatric anesthesia facemasks. J Clin Anesth. 1997;9(6):521-2. [pmid: 9278846].
Hinshaw A S, Scofield R, Atwood J R. Staff, patient, and cost outcomes of all-registered nurse staffing. J Nurs Adm. 1981;11(1112):30-6. [pmid: 6915081].
Hirshberg A, Wall M J Jr, Allen M K, et al. Causes and patterns of missed injuries in trauma. Am J Surg. 1994;168(4):299-303. [pmid: 7943582].
Hjertberg H, Jorfeldt L, Schelin S. Use of ethanol as marker substance to increase patient safety during transurethral prostatic resection. Screening investigation of irrigating fluid absorption in four hospitals and comparison of experienced and inexperienced urologists. Urology. 1991;38(5):423-8. [pmid: 1949451].
Hockey GRJ. Work environments and performance. In: Chmiel, N, editor. Introduction to work and organizational psychology: A European perspective. Malden, MA: Blackwell Publishers Inc.; 2000. p. 206–230.
Hodgson D C, Fuchs C S, Ayanian J Z. Impact of patient and provider characteristics on the treatment and outcomes of colorectal cancer. J Natl Cancer Inst. 2001;93(7):501-15. [pmid: 11287444].
Hofmann D A, Jacobs R R, Landy F. High reliability process industries: Individual, micro, and macro organizational influences on safety performance. J Safe Res. 1995;26(3):131-149.
Holden M K, Daniele C A. Comparison of seven- and five-day physical therapy coverage in patients with acute orthopedic disorders. Phys Ther. 1987;67(8):1240-6. [pmid: 3112811].
Hollenbeck J R, Ilgen D R. Team performance on monitoring tasks. J Appl Psychol. 1995;80(6):685-697.
Hong Z, Wang Z. Error at work: Conceptualization and management. Psychol Sci. 2000;23(5):542-546.
Hood JC and Murphy JE. Patient noncompliance can lead to hospital readmissions. Hospitals 1978;52(1):79–82, 84.
Horbar J D, Badger G J, Lewit E M, et al. Hospital and patient characteristics associated with variation in 28-day mortality rates for very low birth weight infants. Vermont Oxford Network. Pediatrics. 1997;99(2):149-56. [pmid: 9024438].
Houghton A. Variation in outcome of surgical procedures. Br J Surg. 1994;81(5):653-60. [pmid: 8044538].
Houston D M, Allt S K. Psychological distress and error making among junior house officers. Br J Health Psychol. 1997;2(Part 2):141-151.
Houtman I L, Goudswaard A, Dhondt S, et al. Dutch monitor on stress and physical load: risk factors, consequences, and preventive action. Occup Environ Med. 1998;55(2):73-83. [pmid: 9614390].
Howard S K, Gaba D M, Tish K J, et al. Anesthesia crisis resource management training: teaching anesthesiologists to handle critical incidents. Aviat Space Environ Med. 1992;63:763-70. [pmid: 1524531].
Howie J G, Porter A M, Forbes J F. Quality and the use of time in general practice: widening the discussion. BMJ. 1989;298(6679):1008-10. [pmid: 2499368].
Huber D L, Maas M, McCloskey J, et al. Evaluating Nursing Administration Instruments. J Nurs Adm. 2000;30(5):251-272. [pmid: 10823178].
Huddleston H F, Samuel G D. Attempts to improve perceptual clarity in an aircraft display. Nature. 1967;215:787-788. [pmid: 6053095].
Hughes R G, Hunt S S, Luft H S. Effects of surgeon volume and hospital volume on quality of care in hospitals. Med Care. 1987;25(6):489-503. [pmid: 3695658].
Hunt J, Hagen S. Nurse to patient ratios and patient outcomes. Nurs Times. 1998;94(45):63-6. [pmid: 9919285].
Hygge S. Heat and performance. In: Smith, Andrew P. (Ed); Jones, Dylan M. (Ed). (1992). Handbook of human performance, Vol. 1: The physical environment; Vol. 2: Health and performance; Vol. 3: State and trait. San Diego, CA, US: Academic Press, Inc; 1992. p. 79–104.
Hymel G and Severyn F. Typical shiftwork interruptions faced by supervising EM faculty in an EM residency setting. In: Abstract presented at: Society for Academic Emergency Medicine Midwest Regional Meeting; 1999; Ann Arbor, MI.
Ingersoll G L, Spitzer R, Cook J A. Managed-care research, Part 2: Researching the domain. J Nurs Adm. 1999;29(12):10-6. [pmid: 10608934].
Ioannidis J P, Lau J. Evidence on interventions to reduce medical errors: an overview and recommendations for future research. J Gen Intern Med. 2001;16(5):325-34. [pmid: 11359552].
Ireland R H, James H V, Howes M, et al. Design of a summary screen for an ICU patient data management system. Med Biol Eng Comput. 1997;35(4):397-401. [pmid: 9327619].
Ivandic M, Hofmann W, Guder W G. The use of knowledge-based systems to improve medical knowledge about urine analysis. Clin Chim Acta. 2000;297(12):251-60. [pmid: 10841926].
Iwashyna T J, Christakis N A. Physicians, patients, and prognosis. West J Med. 2001;174(4):253-4. [pmid: 11290679].
Jackson L. Nurse/patient ratio too high. Nursing. 1991;21(12):6. [pmid: 1749554].
Jackson S. Does organizational culture affect out-patient DNA rates?. Health Manpow Manage. 1997;23(6):233-236. [pmid: 10179096].
Jadad A R, Moore R A, Carroll D, et al. Assessing the quality of reports of randomized clinical trials: is blinding necessary?. Control Clin Trials. 1996;17(1):1-12. [pmid: 8721797].
Jansen P G, Kerkstra A, Abu-Saad H H, et al. Models of differentiated practice and specialization in community nursing: a review of the literature. J Adv Nurs. 1996;24(5):968-80. [pmid: 8933257].
Jarhult J. The importance of volume for outcome in cancer surgery--an overview. Eur J Surg Oncol. 1996;22(3):205-10. [pmid: 8654596].
Jelinek G A, Mountain D, O'Brien D, et al. Re-engineering an Australian emergency department: can we measure success?. J Qual Clin Pract. 1999;19(3):133-8. [pmid: 10482320].
Jenkins C, Campbell J. Catchment areas in general practice and their relation to size and quality of practice and deprivation: a descriptive study in one London borough. BMJ. 1996;313(7066):1189-92. [pmid: 8916754].
Jenkins K J, Newburger J W, Lock J E, et al. In-hospital mortality for surgical repair of congenital heart defects: preliminary observations of variation by hospital caseload. Pediatrics. 1995;95(3):323-30. [pmid: 7862467].
Jennings N. Patient-controlled analgesia: a serious incident. Anaesthesia. 1992;47(12):1093-4. [pmid: 1489044].
Jewkes R, Abrahams N, Mvo Z. Why do nurses abuse patients? Reflections from South African obstetric services. Soc Sci Med. 1998;47(11):1781-95. [pmid: 9877348].
Jha A K, Kuperman G J, Teich J M, et al. Identifying adverse drug events: development of a computer-based monitor and comparison with chart review and stimulated voluntary report. J Am Med Inform Assoc. 1998;5:305-314. [pmcid: 61304]. [pmid: 9609500].
Johnson D S, Ranzenberger J, Herbert R D, et al. A computerized alert program for acutely ill patients. J Nurs Adm. 1980;10(6):26-35. [pmid: 6991651].
Johnston M, Clarke A, Mundy K, et al. Facilitating comprehension of discharge medication in elderly patients. Age Ageing. 1986;15(5):304-6. [pmid: 3776753].
Johnston M E, Langton K B, Haynes R B, et al. Effects of computer-based clinical decision support systems on clinician performance and patient outcome. A critical appraisal of research. Ann Intern Med. 1994;120(2):135-42. [pmid: 8256973].
Joice P, Hanna G B, Cuschieri A. Errors enacted during endoscopic surgery--a human reliability analysis. Appl Ergon. 1998;29(6):409-14. [pmid: 9796785].
Joint Commission for Accreditation of Healthcare Organizations. Health Care at the Crossroads: Strategies for Addrssing the Evolving Nursing Crisis; 2002.
Jollis J G. Practice still makes perfect. Am Heart J. 1999;138(3 Pt 1):394-5. [pmid: 10467185].
Jollis J G, Peterson E D, Nelson C L, et al. Relationship between physician and hospital coronary angioplasty volume and outcome in elderly patients. Circulation. 1997;95(11):2485-91. [pmid: 9184578].
Jolly K, Bradley F, Sharp S, et al. Follow-up care in general practice of patients with myocardial infarction or angina pectoris: initial results of the SHIP trial. Southampton Heart Integrated Care Project. Fam Pract. 1998;15(6):548-55. [pmid: 10078796].
Jolly K, Bradley F, Sharp S, et al. Randomised controlled trial of follow up care in general practice of patients with myocardial infarction and angina: final results of the Southampton heart integrated care project (SHIP). The SHIP Collaborative Group. BMJ. 1999;318(7185):706-11. [pmcid: 27782]. [pmid: 10074017].
Jones J G, Hardy L. Stress and cognitive functioning in sport. J Sports Sci. 1989;7:41-63. [pmid: 2659817].
Jones J W, Barge B N, Steffy B D, et al. Stress and medical malpractice: Organizational risk assessment and intervention. J Appl Psychol. 1988;73(4):727-735. [pmid: 3209582].
Jones K, Yancer D A, McGinley S J, et al. An agency-staffed nursing unit project. Nurs Manage. 1990;21(10):36-7. [pmid: 2216160].
Jones K R, Redman R W. Organizational Culture and Work Redesign. J Nurs Adm. 2000;30(12):604-610. [pmid: 11132349].
Jones M C, Johnston D W. A critical review of the relationship between perception of the work environment, coping and mental health in trained nurses, and patient outcomes. Clin Effect Nurs. 2000;4(2):74-85.
Jonsson P, Stegmayr B G. Current leakage in hemodialysis machines may be a safety risk for patients. Artif Organs. 2000;24(12):977-81. [pmid: 11121978].
Joseph C. Effect of a monitored care unit on resource utilization in a pediatric ICU. Am J Crit Care. 1997;6(4):296-301. [pmid: 9215427].
Jossy. The impact of design on employee productivity. San Diego Bus J. 1999;20(37):18.
Judge T A, Thoresen C J, Bono J E, et al. The job satisfaction-job performance relationship: A qualitative and quantitative review. Psychol Bull. 2001;127(3):376-407. [pmid: 11393302].
Kaminski M. Unintended consequences: organizational practices and their impact on workplace safety and productivity. J Occup Health Psych. 2001;6(2):127-38.
Kan L, Olivotto I A, Warren Burhenne L J, et al. Standardized abnormal interpretation and cancer detection ratios to assess reading volume and reader performance in a breast screening program. Radiology. 2000;215(2):563-7. [pmid: 10796940].
Kanak M F. Interventions related to patient safety. Nurs Clin North Am. 1992;27(2):371-95. [pmid: 1584696].
Kangas S, Kee C C, McKee-Waddle R. Organizational factors, nurses' job satisfaction, and patient satisfaction with nursing care. J Nurs Adm. 1999;29(1):32-42. [pmid: 9921147].
Kanter R K, Zimmerman J J, Strauss R H, et al. Central venous catheter insertion by femoral vein: safety and effectiveness for the pediatric patient. Pediatrics. 1986;77(6):842-7. [pmid: 3714376].
Kaplan H S, Battles J B, Van der Schaaf T W, et al. Identification and classification of the causes of events in transfusion medicine. Transfusion. 1998;38(1112):1071-81. [pmid: 9838940].
Kastrati A, Neumann F J, Schomig A. Operator volume and outcome of patients undergoing coronary stent placement. J Am Coll Cardiol. 1998;32(4):970-6. [pmid: 9768719].
Katz M H, Schroeder S A. The sounds of the hospital. Paging patterns in three teaching hospitals. N Engl J Med. 1988;319(24):1585-9. [pmid: 3200267].
Katz S G, Kohl R D. Ruptured abdominal aortic aneurysms. A community experience. Arch Surg. 1994;129(3):285-90. [pmid: 8129605].
Kaushal R, Barker K N, Bates D W. How can information technology improve patient safety and reduce medication errors in children's health care?. Arch Pediatr Adolesc Med. 2001;155(9):1002-7. [pmid: 11529801].
Kayser-Jones J. Inadequate staffing at mealtime. Implications for nursing and health policy. J Gerontol Nurs. 1997;23(8):14-21. [pmid: 9287609].
Kayser-Jones J S. The impact of the environment on the quality of care in nursing homes: a social-psychological perspective. Holist Nurs Pract. 1991;5(3):29-38. [pmid: 2045437].
Kenny C. Everyone makes mistakes. Nurs Times. 2000;96(48):14-5. [pmid: 11965979].
Khuri S F, Daley J, Henderson W, et al. Relation of surgical volume to outcome in eight common operations. Results from the VA National Surgical Quality Improvement Program. Ann Surg. 1999;230:414-432. [pmid: 10493488].
Kidd P, Scharf T, Veazie M. Linking stress and injury in the farming environment: A secondary analysis of qualitative data. Health Educ Q. 1996;23(2):224-237. [pmid: 8744874].
Kirkman B L, Rosen B. Powering up teams. Organ Dyn. 2000;28(3):48-66.
Kirmeyer S L. Coping with competing demands: Interruption and the Type A pattern. J Appl Psychol. 1988;73(4):621-629. [pmid: 3209581].
Kistner U A, Keith M R, Sergeant K A, et al. Accuracy of dispensing in a high-volume, hospital-based outpatient pharmacy. Am J Hosp Pharm. 1994;51(22):2793-7. [pmid: 7856602].
Kjellberg A. Psychological aspects of occupational vibration. Scand J Work Environ Health. 1990;16(suppl 1):39-43. [pmid: 2189218].
Kleeman A. Our patients deserve better i.v. locks. RN. 1985;48(7):16-17. [pmid: 3848080].
Klein H J, Kim J S. A field study of the influence of situational constraints, leader-member exchange, and goal commitment on performance. Acad Manage J. 1998;41(1):88-95.
Klein L W, Schaer G L, Calvin J E, et al. Does low individual operator coronary interventional procedural volume correlate with worse institutional procedural outcome? [see comments]. J Am Coll Cardiol. 1997;30(4):870-7. [pmid: 9316511].
Klein M D, Rabbani A B, Rood K D, et al. Three quantitative approaches to the diagnosis of abdominal pain in children: practical applications of decision theory. J Pediatr Surg. 2001;36(9):1375-80. [pmid: 11528609].
Kliger A S, Diamond L H. Patient safety in end-stage renal disease: how do we create a safe environment?. Adv Ren Replace Ther. 2001;8(2):131-137. [pmid: 11349254].
Knez I, Enmarker I. Effects of office lighting on mood and cognitive performance and a gender effect in work-related judgment. Environ Behav. 1998;30(4):553-561.
Kobus D A, Amundson D, Moses J D, et al. A computerized medical incident reporting system for errors in the intensive care unit: initial evaluation of interrater agreement. Mil Med. 2001;166(4):350-3. [pmid: 11315479].
Kogi K. Improving shift workers' health and tolerance to shiftwork: recent advances. Appl Ergon. 1996;27:5-10. [pmid: 15676306].
Kohn LT, Corrigan JM and Donaldson MS, editors. To err is human: building a safer health system. Washington DC: National Academy Press; 2000.
Kolski C, Le Strugeon E. A review of intelligent human-machine interfaces in the light of the ARCH model. I J Hum-Comput Interaction. 1998;10(3):193-231.
Kontogiannis T, Embrey D. A user-centred design approach for introducing computer-based process information systems. Appl Ergon. 1997;28(2):109-119. [pmid: 9414346].
Kovner C, Gergen P J. Nurse staffing levels and adverse effects following surgery in US hospitals. Image J Nurs Sch. 1998;30(4):315-321. [pmid: 9866290].
Kovner C, Jones C, Zhan C, et al. Nurse staffing and postsurgical adverse events: an analysis of administrative data from a sample of US hospitals, 1990-1996. Health Serv Res. 2002;37(3):611-629. [pmid: 12132597].
Krainovich-Miller B, Sedhom L N, Bidwell-Cerone S, et al. A review of nursing research on the use of unlicensed assistive personnel (UAP). J N Y State Nurses Assoc. 1997;28(3):8-15. [pmid: 9369655].
Kramer M K, Schmalenberg C. The magnet hospitals: Institutions of excellence. Part I. J Nurs Adm. 1988;18(1):13-24. [pmid: 3339454].
Kramer M K, Schmalenberg C. The magnet hospitals: Institutions of excellence. Part II. J Nurs Adm. 1988;18(2):11-19. [pmid: 3339460].
Krizek T J. Surgical error: Ethical issues of adverse events. Arch Surg. 2000;135:1359-1366. [pmid: 11074896].
Kuperman G, Sittig D F, Shabot M, et al. Clinical decision support for hospital and critical care. J Healthc Inform Manage Sys Soc. 1999;13:81-96.
Kuperman G J, Teich J M, Gandhi T K, et al. Patient safety and computerized medication ordering at Brigham and Women's Hospital. Jt Comm J Qual Improv. 2001;27(10):509-21. [pmid: 11593885].
Kushniruk A W, Patel V L. Cognitive evaluation of decision making processes and assessment of information technology in medicine. Int J Med Inf. 1998;51:83-90.
Kushniruk AW, Patel VL and Cimino JJ. Usability testing in medical informatics: cognitive approaches to evaluation of information systems and user interfaces. In: American Medical Informatics Association Annual Fall Symposium; 1997. 218–222.
Kwallek N, Lewis C M. Effects of environmental colour on males and females: A red or white or green office. Appl Ergon. 1990;21(4):275-278. [pmid: 15676782].
Kwallek N, Lewis C M, Lin-Hsiao J W D, et al. Effects of nine monochromatic office interior colors on clerical tasks and worker mood. Color Res Appl. 1996;21(6):448-458.
Kwallek N, Lewis C M, Robbins A S. Effects of office interior color on workers' mood and productivity. Percept Mot Skills. 1988;66(1):123-128.
Kwallek N, Woodson H, Lewis C M, et al. Impact of three interior color schemes on worker mood and performance relative to individual environmental sensitivity. Color Res Appl. 1997;22(2):121-132.
Kyriacou D N, Ricketts V, Dyne P L, et al. A 5-year time study analysis of emergency department patient care efficiency. Ann Emerg Med. 1999;34(3):326-35. [pmid: 10459088].
Laks M, Arzbaecher R, Bailey J, et al. Will relaxing safe current limits for electromedical equipment increase hazards to patients?. Circulation. 1994;89(2):909-10. [pmid: 8313582].
Laks M M, Arzbaecher R, Geselowitz D, et al. Revisiting the question: will relaxing safe current limits for electromedical equipment increase hazards to patients? [letter; comment]. Circulation. 2000;102(8):823-5. [pmid: 10952946].
Lambert V. Patient restraints. Improving safety, reducing use. FDA Consum. 1992;26(8):9-13. [pmid: 10121976].
Landefeld C S, Palmer R M, Kresevic D M, et al. A randomized trial of care in a hospital medical unit especially designed to improve the functional outcomes of acutely ill older patients. N Engl J Med. 1995;332(20):1338-44. [pmid: 7715644].
Lanza M L, Kayne H L, Hicks C, et al. Environmental characteristics related to patient assault. Issues Ment Health Nurs. 1994;15(3):319-35. [pmid: 7829320].
Larsen L, Adams J, Deal B, et al. Plants in the workplace: The effects of plant density on productivity, attitudes, and perceptions. Environ Behav 1998;30(3) May 1998(3):261–269.
Larsen R A, Evans R S, Burke J P, et al. Improved perioperative antibiotic use and reduced surgical wound infections through use of computer decision analysis. Infect Control Hosp Epidemiol. 1989;10(7):316-20. [pmid: 2745959].
Laschniger H K S, Shamian J, Thomson D. Impact of magnet hospital characteristics on nurses' perceptions of trust, burnout, quality of care, and work satisfaction. Nurs Econ. 2001;19(5):209-19.
Latif A Z, Signorini D F, Whittle I R. Treatment by a specialist surgical neuro-oncologist does not provide any survival advantage for patients with a malignant glioma. Br J Neurosurg. 1998;12(1):29-32. [pmid: 11013644].
Lauber JK. Cockpit resource management: background and overview. In: Orlady, HW and Foushee, HC, editors. Cockpit resource management training: proceedings of the NASA/MAC workshop NASA Conference Publication No. 2455. Moffet Field, CA: NASA-Ames Research Center.
Lazaro F, Kulinskaya E, Tobiansky R. Crisis intervention: The professionals' perspective: A questionnaire survey. Psychiatr Bull. 2001;25(3):614-626.
Leape L L. Error in medicine. JAMA. 1994;272(23):1851-7. [pmid: 7503827].
Leape L L. A systems analysis approach to medical error. J Eval Clin Prac. 1997;3(3):213-22.
Leape L L, Bates D W, Cullen D J, et al. Systems analysis of adverse drug events. JAMA. 1995;274:35-43. [pmid: 7791256].
Leape L L, Berwick D M. Safe health care: are we up to it?. BMJ. 2000;320(7237):725-6. [pmid: 10720335].
Leape L L, Berwick D M, Bates D W. What practices will most improve safety? Evidence-based medicine meets patient safety. JAMA. 2002;288(4):501-7. [pmid: 12132984].
Leape L L, Lawthers A G, Brennan T A, et al. The preventability of medical injury. QRB Qual Rev Bull. 1992;19:144-9. [pmid: 8332330].
Leino-Kilpi H, Suominen T. Research in intensive care nursing. J Clin Nurs. 1997;6(1):69-76. [pmid: 9052111].
Leiter M P, Robichaud L. Relationships of occupational hazards with burnout: An assessment of measures and models. J Occup Health Psych. 1997;2(1):35-44.
Leppa C J. Nurse relationships and work group disruption. J Nurs Adm. 1996;26(10):23-7. [pmid: 8858011].
Lerner E B, Billittier A J t, Sikora J, et al. Use of a geographic information system to determine appropriate means of trauma patient transport. Acad Emerg Med. 1999;6(11):1127-33. [pmid: 10569385].
Lester H, Tritter J Q. Medical error: A discussion of the medical construction of error and suggestions for reforms of medical education to decrease error. Med Educ. 2001;35(9):855-861. [pmid: 11555223].
Levin M. Safe current limits for electromedical equipment and hazards to patients. Circulation. 1994;90(4):2160-2. [pmid: 7923705].
Levine S. Stress and performance. In: Background papers: stress management. Washington, DC: National Academy Press; 1988.
Levy BS and Wegman DH. Occupational health : recognizing and preventing work-related disease and injury. Philadelphia, PA: Lippincott Williams & Wilkins; 2000.
Lichtig L K, Knauf R A, Milholland D K. Some impacts of nursing on acute care hospital outcomes. J Nurs Adm. 1999;29(2):25-33. [pmid: 10029799].
Lilley L L, Guanci R. Distraction delays a dose. Am J Nurs. 1998;98(2):12.
Lin H X, Salvendy G. Warning effect on human error reduction. Int J Cognit Ergonomics. 2000;4(2):145-161.
Lin L, Isla R, Doniz K, et al. Applying human factors to the design of medical equipment: patient-controlled analgesia. J Clin Monit Comput. 1998;14(4):253-63. [pmid: 9754614].
Lindell M K. Occupational safety and health inspection scores predict rates of workers' lost-time injuries. Accid Anal Prev. 1997;29(5):563-71. [pmid: 9316705].
Linden J V. Errors in transfusion medicine. Scope of the problem. Arch Path Lab Med. 1999;123(7):563-5. [pmid: 10388907].
Linden J V, Wagner K, Voytovich A E, et al. Transfusion errors in New York State: an analysis of 10 years' experience. Transfusion. 2000;40(10):1207-13. [pmid: 11061857].
Lipton H L, Bero L A, Bird J A, et al. The impact of clinical pharmacists' consultations on physicians' geriatric drug prescribing. A randomized controlled trial. Med Care. 1992;30(7):646-58. [pmid: 1614233].
Liu Y-C. Comparative study of the effects of auditory, visual and multimodality displays on drivers' performance in advanced traveller information systems. Ergonomics. 2001;44(4):425-442. [pmid: 11291824].
Loewenstein J C, Wolmark Y, Bourdel M C, et al. Longitudinal study of the relation between environmental conditions and the health of patients in a long-stay hospital. Rev Epidemiol Sante Publique. 1985;33(45):262-6. [pmid: 4095328].
Lomas C J. Theatre design and behaviour of staff determining the number of bacteria during surgery. Natnews. 1987;24(2):9-11. [pmid: 3645304].
Lundberg GD. A pendulum swings and a rocking horse rocks. JAMA 1997;278(20):1704; discussion 1703.
Lupfer P A, Altieri M, Sheridan M J, et al. Patient flow in the emergency department: the chest pain patient. Am J Emerg Med. 1991;9(2):127-30. [pmid: 1994938].
Lurie N, Rank B, Parenti C, et al. How do house officers spend their nights? A time study of internal medicine house staff on call. N Engl J Med. 1989;320(25):1673-7. [pmid: 2725617].
Lyman K A. Day care for persons with dementia: the impact of the physical environment on staff stress and quality of care. Gerontologist. 1989;29(4):557-60. [pmid: 2521118].
Macaulay E M, Cooper G G, Engeset J, et al. Prospective audit of discharge summary errors. Br J Surg. 1996;83(6):788-90. [pmid: 8696741].
MacDonald E T, MacDonald J B, Phoenix M. Improving drug compliance after hospital discharge. BMJ. 1977;2(6087):618-21. [pmid: 902005].
Macintyre P E. Safety and efficacy of patient-controlled analgesia. Br J Anaesth. 2001;87(1):36-46. [pmid: 11460812].
MacReady N. Second stories, sharp ends: dissecting medical errors. Lancet. 2000;355(9208):994. [pmid: 10768445].
Maddox P J, Wakefield M, Bull J. Patient safety and the need for professional and educational change. Nurs Outlook. 2001;49(1):8-13. [pmid: 11182719].
Maierhofer N I, Griffin M A, Sheehan M. Linking manager values and behavior with employee values and behavior: a study of values and safety in the hairdressing industry. J Occup Health Psych. 2000;5(4):417-427.
Malenka D J, McGrath P D, Wennberg D E, et al. The relationship between operator volume and outcomes after percutaneous coronary interventions in high volume hospitals in 1994-1996: the northern New England experience. Northern New England Cardiovascular Disease Study Group. J Am Coll Cardiol. 1999;34(5):1471-80. [pmid: 10551694].
Mango L J. Reducing false negatives in clinical practice: the role of neural network technology. Am J Obset Gyn. 1996;175(4 Pt 2):1114-9.
Mann F A, Danz P L. The night stalker effect: quality improvements with a dedicated night-call rotation. Invest Radiol. 1993;28(1):92-6. [pmid: 8425860].
Margulies DR, Cryer HG, McArthur DL, et al. Patient volume per surgeon does not predict survival in adult level I trauma centers. J Trauma Inj Infect Crit Care 2001;50(4):597–601; discussion 601–3.
Markey B T, Igou J F. Medication discharge planning for the elderly. Patient Educ Couns. 1987;9(3):241-9. [pmid: 10282841].
Marko M, Kreitzer M J. Creating a safer work environment for staff and patients. Nurs Qual Connect. 1994;3(6):8-9. [pmid: 7767271].
Martin D F, England R, Martin O. The safety sphincterotome: the device, the technique and preliminary results. Endoscopy. 1998;30(4):375-8. [pmid: 9689512].
Martin F, Oyewole A, Moloney A. A randomized controlled trial of a high support hospital discharge team for elderly people. Age Ageing. 1994;23(3):228-34. [pmid: 8085509].
Maslach C, Jackson SE and Leiter MP. The Maslach burnout inventory (3rd ed.). Palo Alto, CA: Consulting Psychologists Press; 1996.
Matz R. Errors in medicine. Lancet. 1999;353(9161):1365. [pmid: 10218563].
McAdam W A, Brock B M, Armitage T, et al. Twelve years' experience of computer-aided diagnosis in a district general hospital. Ann R Coll Surg Engl. 1990;72(2):140-6. [pmid: 2185682].
McCall T B. The impact of long working hours on resident physicians. N Engl J Med. 1988;318(12):775-8. [pmid: 3347227].
McClelland D B, Phillips P. Errors in blood transfusion in Britain: survey of hospital haematology departments. BMJ. 1994;308(6938):1205-6. [pmid: 8180537].
McCloskey J M. Nurse staffing and patient outcomes. Nurs Outlook. 1998;46(5):199-200. [pmid: 9805336].
McCormack J. Beeping clinicians with vital information. Health Data Manag 1998;6(3):30, 32.
McGhan W F, Smith W E, Adams D W. A randomized trial comparing pharmacists and technicians as dispensers of prescriptions for ambulatory patients. Med Care. 1983;21(4):445-53. [pmid: 6843197].
McGovern P G, Pankow J S, Shahar A M, et al. Recent trends in acute coronary heart disease: mortality, morbidity, medical care and risk factors. N Engl J Med. 1996;334:884-890. [pmid: 8596571].
McGurgan P L. Potential hazard to cardioversion patients. Med Instrum. 1984;18(4):237. [pmid: 6493096].
McKee M, Priest P, Ginzler M, et al. Which general surgical operations must be done at night? Ann R Coll Surg Engl 1991;73(5):295–301; discussion 301–2.
McKeon E. Washington watch. Nursing home staffing crisis: the ANA responds. Am J Nurs. 2001;101(5):25. [pmid: 11355492].
McLain D L. Responses to health and safety risk in the work environment. Acad Manage J. 1995;38(6):1726-1743. [pmid: 10169684].
Meese G B, Lewis M I, Wyon D P, et al. A laboratory study of the effects of moderate thermal stress on the performance of factory workers. Ergonomics. 1984;27(1):19-43. [pmid: 6705759].
Megaw E. The visual environment. In: Smith, AP and Jones, DM, editors. Handbook of human performance, Vol. 1: The physical environment; Vol. 2: Health and performance; Vol. 3: State and trait. San Diego, CA, US: Academic Press, Inc; 1992. p. 261–296.
Mermel L A, Parenteau S, Tow S M. The risk of midline catheterization in hospitalized patients. A prospective study. Ann Intern Med. 1995;123(11):841-4. [pmid: 7486466].
Metnitz P G, Lenz K. Patient data management systems in intensive care--the situation in Europe. Intensive Care Med. 1995;21(9):703-15. [pmid: 8847425].
Meurier C E. Understanding the nature of errors in nursing: using a model to analyse critical incident reports of errors which had resulted in an adverse or potentially adverse event. J Adv Nurs. 2000;32(1):202-7. [pmid: 10886452].
Michels N. The transition from hospital to home: an exploratory study. Home Health Care Serv Q. 1988;9(1):29-44. [pmid: 10291783].
Miller E T, Deets C, Miller R V. Nurse call systems: impact on nursing performance. J Nurs Care Qual. 1997;11(3):36-43. [pmid: 9029852].
Miller M W, Brayman A A, Abramo wicz J S. Obstetric ultrasonography: a biophysical consideration of patient safety--the “rules” have changed. Am J Obset Gyn. 1998;179(1):241-54.
Minnick A, Leahey M, Pischke-Winn K. The impact of patient point-of-view pharmacy delivery on labor and quality. Nurs Econ. 1994;12(1):45-50. [pmid: 8008103].
Miro O, Sanchez M, Milla J. Hospital mortality and staff workload. Lancet. 2000;356(9238):1356-7. [pmid: 11073052].
Mitchell P H, Shortell S M. Adverse outcomes and variations in organization of care delivery. Med Care. 1997;35(11 Supplement):NS19-NS32. [pmid: 9366876].
Molnar K K, Kletke M G. The impacts on user performance and satisfaction of a voice-based front-end interface for a standard software tool. Int J Hum Comp Studies. 1996;45(3):287-303.
Monk T H, Folkard S, Wedderburn A I. Maintaing safety and high performance on shiftwork. Appl Ergon. 1996;27:17-24. [pmid: 11542593].
Moos R H, Moos B S. The staff workplace and the quality and outcome of substance abuse treatment. J Stud Alcohol. 1998;59(1):43-51. [pmid: 9498314].
Morgan G. Imaginization. Newbury Park: Sage; 1993.
Morris A H. Computerized protocols and bedside decision support. Crit Care Clin. 1999;15(3):523-45. [pmid: 10442261].
Morris A H, Wallace C J, Menlove R L, et al. Randomized clinical trial of pressure-controlled inverse ratio ventilation and extracorporeal CO2 removal for adult respiratory distress syndrome. Am J Respir Crit Care Med. 1994;149(2 Pt 1):295-305. [pmid: 8306022].
Morris G P, Morris R W. Anaesthesia and fatigue: an analysis of the first 10 years of the Australian Incident Monitoring Study 1987-1997. Anaesth Intensive Care. 2000;28(3):300-4. [pmid: 10853213].
Mouloua M and Koonce JM, editors. Human-automation interaction: Research and practice. Hillsdale, NJ: Lawrence Erlbaum Associates Inc.; 1997.
Muckart D J, Thomson S R. Undetected injuries: a preventable cause of increased morbidity and mortality. Am J Surg. 1991;162(5):457-60. [pmid: 1951909].
Mullett C J, Evans R S, Christenson J C, et al. Development and impact of a computerized pediatric antiinfective decision support program. Pediatrics. 2001;108(4):E75. [pmid: 11581483].
Murff H J, Kannry J. Physician satisfaction with two order entry systems. J Am Med Inform Assoc. 2001;8(5):499-509. [pmcid: 131047]. [pmid: 11522770].
Murphy D J, Knaus W A, Lynn J. Study population in SUPPORT: patients (as defined by disease categories and mortality projections), surrogates, and physicians. J Clin Epidemiol. 1990;43(suppl):11S-28S. [pmid: 2174967].
Murphy E C, Ruch S, Pepicello J, et al. Managing an increasingly complex system. Nurs Manage. 1997;28(10):33-8. [pmid: 9369720].
Murtaugh C M, Kemper P, Spillman B C. The risk of nursing home use in later life. Med Care. 1990;28(10):952-62. [pmid: 2232925].
Murtaugh C M, Kemper P, Spillman B C, et al. The amount, distribution, and timing of lifetime nursing home use. Med Care. 1997;35(3):204-18. [pmid: 9071254].
Murtaugh C M, Litke A. Transitions through post-acute and long-term care settings: patterns of use and outcomes for a national cohort of elders. Med Care. 2002;40(3):227-36. [pmid: 11880795].
Narayanan V, Nath R. The influence of group cohesiveness on some changes induced by flexitime: A quasi-experiment. J Appl Behav Sci. 1984;20(3):1486-1495.
Narumi J, Miyazawa S, Miyata H, et al. Analysis of human error in nursing care. Accid Anal Prev. 1999;31(6):625-629. [pmid: 10487337].
Nash I S, Corrato R R, Dlutowski M J, et al. Generalist versus specialist care for acute myocardial infarction. Am J Cardiol. 1999;83(5):650-654. [pmid: 10080413].
Nash I S, Nash D B, Fuster V. Do cardiologists do it better?. J Am Coll Cardiol. 1997;29(3):475-8. [pmid: 9060880].
Nawar M, Wilburn S. Hazards in the workplace. Am J Nurs. 2000;100(3):96. [pmid: 10738408].
Naylor M, Brooten D, Jones R, et al. Comprehensive discharge planning for the hospitalized elderly. A randomized clinical trial. Ann Intern Med. 1994;120(12):999-1006. [pmid: 8185149].
Naylor M D. Comprehensive home care after hospitalization of elderly patients [letter]. JAMA. 1999;282(12):1129. [pmid: 10501107].
Naylor MD. A decade of transitional care research with vulnerable elders. J Cardiovasc Nurs 2000;14(3):1–14; quiz 88–9.
Naylor M D, Bowles K H, Brooten D. Patient problems and advanced practice nurse interventions during transitional care. Public Health Nurs. 2000;17(2):94-102. [pmid: 10760191].
Naylor M D, Brooten D, Campbell R, et al. Comprehensive discharge planning and home follow-up of hospitalized elders: a randomized clinical trial. JAMA. 1999;281(7):613-20. [pmid: 10029122].
Naylor M D, McCauley K M. The effects of a discharge planning and home follow-up intervention on elders hospitalized with common medical and surgical cardiac conditions. J Cardiovasc Nurs. 1999;14(1):44-54. [pmid: 10533691].
Needleman J, Buerhaus P, Mattke S, et al. Nurse-staffing levels and the quality of care in hospitals. N Engl J Med. 2002;346(22):1715-1722. [pmid: 12037152].
Nelson L S, Gordon P E, Simmons M D, et al. The benefit of houseofficer education on proper medication dose calculation and ordering. Acad Emerg Med. 2000;7(11):1311-6. [pmid: 11073484].
Nerenz D, Rosman H, Newcomb C, et al. The on-call experience of interns in internal medicine. Medical Education Task Force of Henry Ford Hospital. Arch Intern Med. 1990;150(11):2294-7. [pmid: 2241437].
Ness J E, Sullivan S D, Stergachis A. Accuracy of technicians and pharmacists in identifying dispensing errors. Am J Hosp Pharm. 1994;51:354-357. [pmid: 8160687].
Neuman G A, Wagner S H, Christiansen N D. The relationship between work-team personality composition and the job performance of teams. Group Organiz Manage. 1999;24(1):28-45.
Neumann M E. Starting from scratch. What makes the ultimate dialysis facility? Wife of ESRD patient asked, and then helped to build it. Nephrol News Issues. 1997;11(9):31-2. [pmid: 9348870].
Neumann T. The healing power of design. Houston, TX; 1993.
Nightingale F. Notes on nursing: what it is and what it is not. London: Harrison; 1860.
Niklewski B. Building safer health care systems for informed patients. Md Nurs. 2000;3(2):28.
Noguchi T, Miyazaki S, Yasuda S, et al. A randomised controlled trial of Prostar Plus for haemostasis in patients after coronary angioplasty. Eur J Vasc Endovasc Surg. 2000;19(5):451-5. [pmid: 10828223].
Nolan T W. System changes to improve patient safety. BMJ. 2000;320:771-773. [pmid: 10720364].
Northrup H R, Wilson J T, Rose K M. The twelve-hour shift in the petroleum and chemical industries. Indus Labor Rel Rev. 1979;32:312-26.
Norton E C, Garfinkel S A, McQuay L J, et al. The effect of hospital volume on the in-hospital complication rate in knee replacement patients. Health Serv Res. 1998;33(5 Pt 1):1191-210. [pmid: 9865217].
Novak RO and Smalensky MH. Shift work and industrial injuries at a chemical plant in Southeast Texas. In: Human Factors Society 32nd Annual Meeting; 1988.
Noweir M H. Noise exposure as related to productivity, disciplinary actions, absenteeism, and accidents among textile workers. J Safe Res. 1984;15(4):163-174.
Nuovo J, Melnikow J, Howell L P. New tests for cervical cancer screening. Am Fam Physician. 2001;64(5):780-6. [pmid: 11563569].
Nystrom P C. Organizational cultures, strategies, and commitments in health care organizations. Health Care Manage Rev. 1993;18(1):43-49. [pmid: 8444614].
O'Brien E. Environmental dangers for the patient with a pacemaker. BMJ. 1982;285(6356):1677-8. [pmid: 6816326].
O'Brodovich M and Rappaport P. A study pre and post unit dose conversion in a pediatric hospital. Can J Hosp Pharm 1991;44(1):5–15, 50.
O'Hare D. The ‘Wheel of Misfortune’: a taxonomic approach to human factors in accident investigation and analysis in aviation and other complex systems. Ergonomics. 2000;43(12):2001-19. [pmid: 11191782].
Oldham G R, Kulik C T, Stepina L P. Physical environments and employee reactions: Effects of stimulus-screening skills and job complexity. Acad Manage J. 1991;34(4):929-938.
Olson D M, Borman W C. More evidence on relationships between the work environment and job performance. Hum Perf. 1989;2(2):113-130.
Olson L G, Ambrogetti A. Working harder--working dangerously? Fatigue and performance in hospitals. Med J Aust. 1998;168(12):614-6. [pmid: 9673624].
O'Neil E, Seago J A. Meeting the challenge of nursing and the nation's health. JAMA. 2002;288(16):2040-2041. [pmid: 12387657].
Ontai S C. Computerization of obstetrical patient tracking in a family medicine residency program. J Ambul Care Manage. 1992;15(4):1-8. [pmid: 10122093].
Orbe M P, King G 3rd. Negotiating the tension between policy and reality: exploring nurses' communication about organizational wrongdoing. Health Commun. 2000;12(1):41-61. [pmid: 10938906].
Ormiston J A, Dixon B, Webster M W, et al. 5 French guide catheters for percutaneous coronary intervention: a feasibility study in 100 consecutive patients. Cathet Cardiovasc Interven. 2001;52(1):45-8.
O'Shea E. Factors contributing to medication errors: a literature review. J Clin Nurs. 1999;8(5):496-504. [pmid: 10786520].
Overhage J M, Tierney W M, Zhou X H, et al. A randomized trial of “corollary orders” to prevent errors of omission. J Am Med Inform Assoc. 1997;4(5):364-75. [pmcid: 61254]. [pmid: 9292842].
Paauw D S, Wenrich M D, Curtis J R, et al. Ability of primary care physicians to recognize physical findings associated with HIV infection. JAMA. 1995;274(17):1380-1382. [pmid: 7563564].
Palinkas L A. Health and performance of Antarctic winter-over personnel: A follow-up study. Aviat Space Environ Med. 1986;57(10):954-959. [pmid: 3778394].
Palmer H C, Armistead N S, Elnicki D M, et al. The effect of a hospitalist service with nurse discharge planner on patient care in an academic teaching hospital. Am J Med. 2001;111:627-632. [pmid: 11755506].
Papa M J. Communication network patterns and employee performance with new technology. Communic Res. 1990;17(3):344-68.
Pape T. The effect of nurses' use of focused protocol to decrease distractions during medication administration. Denton, TX: Texas Women's University; 2002.
Parikh C R, Karnad D R. Quality, cost, and outcome of intensive care in a public hospital in Bombay, India. Crit Care Med. 1999;27(9):1754-9. [pmid: 10507594].
Paris C R, Salas E, Cannon-Bowers J A. Teamwork in multi-person systems: A review and analysis. Ergonomics. 2000;43(8):1052-1075. [pmid: 10975173].
Parkes J and Shepperd S. Discharge planning from hospital to home (Cochrane Review). The Cochrane Library, Issue 4. Oxford: Update Software 2000(4).
Parkes J and Shepperd S. Discharge planning from hospital to home (Cochrane Review). The Cochrane Library, Issue 3. Oxford: Update Software 2002(2).
Parkes K R. Psychosocial aspects of stress, health and safety on North Sea installations. Scand J Work Environ Health. 1998;24(5):321-333. [pmid: 9869303].
Parkin D M, Henney C R, Quirk J, et al. Deviation from prescribed drug treatment after discharge from hospital. BMJ. 1976;2(6037):686-8. [pmid: 974539].
Parry J M, Collins S, Mathers J, et al. Influence of volume of work on the outcome of treatment for patients with colorectal cancer. Br J Surg. 1999;86(4):475-81. [pmid: 10215817].
Patel V L, Kushniruk A W. Understanding, navigating and communicating knowledge: issues and challenges. Methods Inf Med. 1998;37:460-470. [pmid: 9865044].
Patel V L, Kushniruk A W, Yang S, et al. Impact of a computer-based patient record system on data collection, knowledge organization, and reasoning. J Am Med Inform Assoc. 2000;7(6):569-85. [pmcid: 129666]. [pmid: 11062231].
Pattison H M, Robertson C E. The effect of ward design on the well-being of post-operative patients. J Adv Nurs. 1996;23(4):820-6. [pmid: 8675902].
Patton D V, Landers D R, Agarwal I T. Legal considerations of sleep deprivation among resident physicians. J Health Law. 2001;34(3):377-417. [pmid: 11571893].
Paul N. Admission to discharge. Tracking a patient's progress using wireless bar coding. Health Manag Technol 2001;22(2):30, 32.
Paxton F, Heaney D, Howie J, et al. A study of interruption rates for practice nurses and GPs. Nurs Stand. 1996;10(43):33-6.
Payne D. Patient deaths ‘linked to staffing levels’… intensive care wards. Nurs Times. 2000;96(29):20-26.
Peachey-Hill C, Law M. Impact of environmental sensitivity on occupational performance. Can J Occup Ther. 2000;67(5):304-313. [pmid: 11140144].
Penington G R. Integrated electronic health records. Med J Aust. 2000;172(7):350. [pmid: 10844929].
Perrow C. Normal accidents. New York, NY: Basic Books; 1984.
Personius C D. Patients, health care workers, and latex allergy. MLO Med Lab Obs. 1995;27(3):30-2. [pmid: 10143149].
Peters P, Fleuren M, Wijkel D. The quality of the discharge planning process: the effect of a liaison nurse. Int J Qual Health Care. 1997;9(4):283-7. [pmid: 9304427].
Peterson G M, Wu M S, Bergin J K. Pharmacist's attitudes towards dispensing errors: their causes and prevention. J Clin Pharm Ther. 1999;24(1):57-71. [pmid: 10319909].
Petrosillo N, Gilli P, Serraino D, et al. Prevalence of infected patients and understaffing have a role in hepatitis C virus transmission in dialysis. Am J Kidney Dis. 2001;37(5):1004-10. [pmid: 11325683].
Petrosino A, Boruch R F, Rounding C, et al. The Campbell Collaboration Social, Psychological, Educational and Criminological Trials Register (C2-SPECTR) to facilitate the preparation and maintenance of systematic reviews of social and educational interventions. Evaluation and Research in Education. 2000;14(34):206-219.
Pizzi L, Goldfarb NI and Nash DB. Crew resource management and its applications in medicine. In: Making healthcare safer: a critical analysis of patient safety practices AHRQ publication 01-E058. p. 505–513.
Pizzi LT, Goldfarb NI and Nash DB. Promoting a culture of safety. In: Making Health Care Safer: A Critical Analysis of Patient Safety Practices; 2001.
Pollack M M, Cuerdon T T, Patel K M, et al. Impact of quality-of-care factors onpediatric intensive care unit mortality. JAMA. 1994;272:941-6. [pmid: 8084061].
Pollack M M, Patel K M, Ruttimann U E. Pediatric critical care training programs have a positive effect on pediatric intensive care mortality. Crit Care Med. 1997;25:1637-42. [pmid: 9377876].
Poole C J, Harrington J M, Aw T C, et al. Guidance on standards of health for clinical health care workers. Occup Med (Oxford). 2002;52(1):17-24.
Pope D S. Music, noise, and the human voice in the nurse-patient environment. Image J Nurs Sch. 1995;27(4):291-6. [pmid: 8530117].
Porcu S, Bellatreccia A, Ferrara M, et al. Sleepiness, alertness and performance during a laboratory simulation of an acute shift of the wake-sleep cycle. Ergonomics. 1998;41(8):1192-1202. [pmid: 9715676].
Porter J M, Ursic C. Trauma attending in the resuscitation room: does it affect outcome?. Am Surg. 2001;67(7):611-4. [pmid: 11450770].
Porterfield J G, Porterfield L M, Smith B A, et al. Experience with three different third-generation cardioverter-defibrillators in patients with coronary artery disease or cardiomyopathy. Am J Cardiol. 1993;72(3):301-4. [pmid: 8342508].
Poses R M, Bekes C, Winkler R L, et al. Are two (inexperienced) heads better than one (experienced) head? Averaging house officers' prognostic judgments for critically ill patients. Arch Intern Med. 1990;150(9):1874-8. [pmid: 2393319].
Posner K L, Freund P R. Trends in quality of anesthesia care associated with changing staffing patterns, productivity, and concurrency of case supervision in a teaching hospital. Anesthesiology. 1999;91(3):839-47. [pmid: 10485796].
Potts M J, Phelan K W. Deficiencies in calculation and applied mathematics skills in pediatrics among primary care interns. Arch Pediatr Adolesc Med. 1996;150(7):748-52. [pmid: 8673202].
Pransky G, Snyder T, Dembe A, et al. Under-reporting of work-related disorders in the workplace: A case study and review of the literature. Ergonomics. 1999;42(1):171-182. [pmid: 9973879].
Price C. A national uprising. United actions push mandatory overtime, inadequate staffing to forefront. Am J Nurs. 2000;100(12):75-6. [pmid: 11202790].
Price C. U.S. Nursing Corp. comes under fire: strikebreakers prolong labor disputes, endanger patients. Am Nurs 2000;32(6):1,13.
Prichard J S, Stanton N A. Testing Belbin's team role theory of effective groups. J Manage Dev. 1999;18(8):652-665.
Primarolo D. What has skill mix got to do with improving client care?. Health Visit. 1993;66(5):183. [pmid: 8514518].
Proctor E K, Morrow-Howell N. Complications in discharge planning with Medicare patients. Health Soc Work. 1990;15(1):45-54. [pmid: 2156767].
Proctor T F, Yarcheski A, Oriscello R G. The relationship of hospital process variables to patient outcome post-myocardial infarction. Int J Nurs Stud. 1996;33(2):121-30. [pmid: 8675373].
Pronovost P J, Dang D, Dorman T, et al. Intensive care unit nurse staffiing and the risk for complications after abdominal aortic surgery. Effect Clin Pract. 2001;4:199-206.
Pryor F, Messmer P R. The effect of traffic patterns in the OR on surgical site infections. AORN J. 1998;68(4):649-60. [pmid: 9795720].
Puckett F. Medication-management component of a point-of-care information system. Am J Health Syst Pharm. 1995;52(12):1305-9. [pmid: 7656117].
Pulakos E D, Arad S, Donovan M A, et al. Adaptability in the workplace: Development of a taxonomy of adaptive performance. J Appl Psychol. 2000;85(4):612-624. [pmid: 10948805].
Quigley P, Janzen S K, King I, et al. Nurse staffing and patient outcomes from one acute care setting within the Department of Veteran's Affairs. Fla Nurse. 1999;47(2):34. [pmid: 11995138].
Racette K. A matter of safety: two radiation therapists per unit, per patient. Asrt Scanner. 1998;30(11):6-7.
Rahman A, Haque S. Perceived workload and performance of shift workers. J Hum Ergol. 1992;21(1):99-103.
Raines D A. Making mistakes: Prevention is key to error-free health care. AWHONN Lifelines. 2000;4(1):35-39. [pmid: 11033615].
Rait C. The nurse of the 1990s: not too bright, believes in voodoo, often kills patients. Neonatal Netw. 1996;15(5):7-8. [pmid: 8868692].
Rashed M S, Bucknall M P, Little D, et al. Screening blood spots for inborn errors of metabolism by electrospray tandem mass spectrometry with a microplate batch process and a computer algorithm for automated flagging of abnormal profiles. Clin Chem. 1997;43(7):1129-41. [pmid: 9216448].
Rasmussen P G, Revzin A M. Scanning and monitoring performance: Effects of the reinforcement values of the events being monitored. Aviat Med. 1994;10:94-98.
Ray C D, Levinson R. Noise pollution in the operating room: a hazard to surgeons, personnel, and patients. J Spinal Disord. 1992;5(4):485-8. [pmid: 1490048].
Rayman R B. Passenger safety, health, and comfort: a review. Aviat Space Environ Med. 1997;68(5):432-40. [pmid: 9143755].
Raynor D K, Booth T G, Blenkinsopp A. Effects of computer generated reminder charts on patients' compliance with drug regimens. BMJ. 1993;306(6886):1158-61. [pmid: 8499815].
Reason J. Human error. Cambridge: Cambridge University Press; 1990.
Reason J. A system approach to organizational error. Ergonomics. 1995;38(8):1708-1721.
Reason J. Education and debate. Human error: models and management. BMJ. 2000;320(7237):768-70. [pmid: 10720363].
Rebeiro K L. Enabling occupation: The importance of an affirming environment. Can J Occup Ther. 2001;68(2):80-89. [pmid: 11355619].
Reiber G E, McDonnell M B, Schleyer A M, et al. A comprehensive system for quality improvement in ambulatory care: assessing the quality of diabetes care. Patient Educ Couns. 1995;26:337-341. [pmid: 7494747].
Reichert M. Laparoscopic instruments. Patient care, cost issues. AORN J 1993;57(3):637–51, 654–5.
Reid W H. Recognizing and dealing with impaired clinicians, Part 1: Recognition and reporting. J Med Prac Manage. 2001;17(2):97-9.
Reuben D B, Frank J C, Hirsch S H, et al. A randomized clinical trial of outpatient comprehensive geriatric assessment coupled with an intervention to increase adherence to recommendations. J Am Geriatr Soc. 1999;47(3):269-76. [pmid: 10078887].
Rex J H, Turnbull J E, Allen S J, et al. Systematic root cause analysis of adverse drug events in a tertiary referral hospital. Jt Comm J Qual Improv. 2000;26(10):563-75. [pmid: 11042820].
Rich J. In pursuit of a B.S.N. Nursing. 1990;20(2):118-120. [pmid: 2300300].
Rich M W, Beckham V, Wittenberg C, et al. A multidisciplinary intervention to prevent the readmission of elderly patients with congestive heart failure. N Engl J Med. 1995;333(18):1190-5. [pmid: 7565975].
Rind D, Safran C, Phillips R S, et al. Effect of computer-based alerts on the treatment and outcomes of hospitalized patients. Arch Intern Med. 1994;154:1511-1517. [pmid: 8018007].
Risser D T, Rice M M, Salisbury M L, et al. The potential for improved teamwork to reduce medical errors in the emergency department. Ann Emerg Med. 1999;34:373-83. [pmid: 10459096].
Risser DT, Simon R, Rice MM, et al. A structured teamwork system to reduce clinical errors. In: Error reduction in health care: a systems approach to improving patient safety. San Francisco: Jossey-Bass Publ; 2000. p. 235–78.
Roberts K H, Bea R G. When systems fail. Organ Dyn. 2001;29(3):179-191.
Robertson R, Dowd S B. The effects of hospital downsizing on staffing and quality of care. Health Care Superv. 1996;14(3):50-6. [pmid: 10154921].
Robertson R H, Hassan M. Staffing intensity, skill mix and mortality outcomes: the case of chronic obstructive lung disease. Health Serv Manage Res. 1999;12(4):258-68. [pmid: 10622804].
Robinson J C. Worker responses to workplace hazards. J Health Polit Policy Law. 1987;12(4):665-82. [pmid: 3429802].
Rochlin G I. Safe operation as a social construct. Ergonomics. 1999;42(11):1549-61.
Roe RA, Zijlstra FRH and Leonova AB. Interruptions in mental information work. Effects on work activity and psychological well-being WORC Report 96.06.003/4. Tilburg: Tilburg University Press; 1996.
Rogers A, Spencer M, Stone B, et al. The influence of a 1 h nap on performance overnight. Ergonomics. 1989;32(10):1193-1205. [pmid: 2598905].
Rogers FB, Simons R, Hoyt DB, et al. In-house board-certified surgeons improve outcome for severely injured patients: a comparison of two university centers. J Trauma Inj Infect Crit Care 1993;34(6):871–5; discussion 875–7.
Rogers W H, Draper D, Kahn K L, et al. Quality of care before and after implementation of the DRG-based prospective payment system. A summary of effects. JAMA. 1990;264(15):1989-94. [pmid: 2120478].
Rohe D. Visual control: using simple graphics can eliminate errors and boost quality. QRC Advisor. 1998;14(8):1-6. [pmid: 10179837].
Roland M, Campbell S, Wilkin D. Clinical governance: a convincing strategy for quality improvement?. J Manage Med. 2001;15(3):188-201.
Rosa R R. Performance, alertness, and sleep after 3.5 yrs of 12 h shifts: A follow-up study. Work Stress. 1991;5(2):107-116.
Rosa R R. Napping at home and alertness on the job in rotating shift workers. Sleep. 1993;16(8):727-735. [pmid: 8165387].
Rosa R R, Bonnet M H. Performance and alertness on 8 h and 12 h rotating shifts at a natural gas utility. Ergonomics. 1993;36(10):1177-1193. [pmid: 8223409].
Rosa R R, Colligan M J. Long workdays versus restdays: Assessing fatigue and alertness with a portable performance battery. Hum Factors. 1988;30(3):305-317. [pmid: 3169791].
Roseman C, Booker J M. Workload and environmental factors in hospital medication errors. Nurs Res. 1995;44(4):226-30. [pmid: 7624233].
Rosenberg E L, Haines R F, Jordan K. The effects of window shape and reticle presence on performance in a vertical alignment task. Aviat Space Environ Med. 1989;60(6):543-9. [pmid: 2751584].
Rosness R, Hakonsen G, Steiro T, et al. The vulnerable robustness of high reliabilty organisations: a case study report from an offshore oil production platform. In: http://webster.iot.ntnu.no/fag/1049/faginformasjon/; 2001.
Ross J, Bradley A. Visual performance and patient preference: a comparison of anti-reflection coated and uncoated spectacle lenses. J Am Optom Assoc. 1997;68(6):361-6. [pmid: 9190135].
Rossi S, Buzzi F, Paparella A, et al. Complications and safety associated with ICP monitoring: a study of 542 patients. Acta Neurochir Suppl. 1998;71:91-3. [pmid: 9779154].
Rothblum AM and Carvalhais AB. Maritime applications of human factors test and evaluation. In: O'Brien, TG and Charlton, SG, editors. Handbook of human factors testing and evaluation. Hillsdale, NJ: Lawrence Erlbaum Associates, Inc; 1996. p. 287–300.
Rothman M. Designing work environments to influence productivity. J Bus Psychol. 1987;1(4):390-395.
Rothrock J C. Quality care must transcend reform measures and workplace redesign efforts. AORN J. 1994;60(1):9-11. [pmid: 8085808].
Rowe C, Koren T, Koren G. Errors by paediatric residents in calculating drug doses. Arch Dis Child. 1998;79(1):56-8. [pmid: 9771254].
Rowell P A, Milholland D K. Nursing and threats to patient and nurse safety and quality of patient care. J Nurs Care Qual. 1998;12(4):9-13. [pmid: 9529792].
Rubin H. The relationship between environmental design & patient medical outcomes. J Healthc Des 1997;9:13–4; discussion 21–4.
Rubin H R. Status report--an investigation to determine whether the built environment affects patients' medical outcomes. J Healthc Des. 1998;10:11-3. [pmid: 10539237].
Ruga W. A healing environment, by design. Mod Healthc. 2000;30(44):24. [pmid: 11141839].
Rugg G, Blandford A, Scown PJA, et al. Product design and evaluation. In: Harris, Don (Ed). (1997). Engineering psychology and cognitive ergonomics, Vol. 2: Job design and product design. Burlington, VT, US: Ashgate Publishing Co. xiv, 474pp.; 1997.
Rusinova V, Popova A, Radoslavova M. Specificities of a 24-hour cycle and quality of work with shift system. Stud Psychol. 1986;28(34):259-264.
Sackett D L, Wennberg J E. Choosing the best research design for each question. BMJ. 1997;315:1636. [pmid: 9448521].
Saksena S, Giorgberidze I. Patient safety during radiofrequency catheter ablation: a clinical and regulatory dilemma. Pacing Clin Electrophysiol. 1994;17(10):1577-80. [pmid: 7800558].
Samkoff J S, Jacques C H M. A review of studies concerning effects of sleep deprivation and fatigue on residents' performance. Acad Med. 1991;66:687-693. [pmid: 1747181].
Sandler D A, Mitchell J R, Fellows A, et al. Is an information booklet for patients leaving hospital helpful and useful?. BMJ. 1989;298(6677):870-4. [pmid: 2497830].
Sandrick K. Learning from experience. In AIDS treatment, knowledge means quality. Hospitals. 1993;67(7):32-5. [pmid: 8458622].
Saw C B, Ayyangar K M, Zhen W, et al. Quality assurance procedures for the Peacock system. Med Dosim. 2001;26(1):83-90. [pmid: 11417512].
Scerbo MW and Mouloua M, editors. Automation technology and human performance: Current research and trends: Mahwah, NJ, US: Lawrence Erlbaum Associates, Inc., Publishers. (1999). xiii, 339pp.; 1999.
Schenkel S. Promoting patient safety and preventing medical error in emergency departments. Acad Emerg Med. 2000;7(11):1204-22. [pmid: 11073469].
Schulmeister L. Chemotherapy medication errors: descriptions, severity, and contributing factors. Oncol Nurs Forum. 1999;26(6):1033-42. [pmid: 10420421].
Schultz M A, van Servellen G, Chang B L, et al. The relationship of hospital structural and financial characteristics to mortality and length of stay in acute myocardial infarction patients. Outcomes Manag Nurs Prac. 1998;2(3):130-6.
Schultz M A, van Servellen G, Litwin M S, et al. Can hospital structural and financial characteristics explain variations in mortality caused by acute myocardial infarction?. Appl Nurs Res. 1999;12(4):210-214. [pmid: 10589110].
Schultz M A, van Servellen G, Litwin M S, et al. Research briefs. Can hospital structural and financial characteristics explain variations in mortality caused by acute myocardial infarction?. Appl Nurs Res. 1999;12(4):210-4. [pmid: 10589110].
Schweitzer P K, Muehlbach M J, Walsh J K. Countermeasures for night work performance deficits: The effect of napping or caffeine on continuous performance at night. Work Stress. 1992;6(4):355-365.
Scott A J. Chronobiological considerations in shiftworker sleep and performance and shiftwork scheduling. Hum Perf. 1994;7(3):207-233.
Scott J G, Sochalski J, Aiken L. Review of magnet hospital research: findings and implications for professional nursing practice. J Nurs Adm. 1999;29(1):9-19. [pmid: 9921144].
Sebok A. Team performance in process control: Influences of interface design and staffing levels. Ergonomics. 2000;43(8):1210-1236. [pmid: 10975181].
Sexton J B, Helmreich R L. Analyzing cockpit communications: The links between language, performance, error, and workload. Hum Perf Extreme Environ. 2000;5(1):63-68.
Sexton J B, Thomas E J, Helmreich R L. Error, stress, and teamwork in medicine and aviation: cross sectional surveys. BMJ. 2000;320(7237):745-9. [pmcid: 27316]. [pmid: 10720356].
Sexton J B, Thomas E J, Helmreich R L. Error, stress, and teamwork in medicine and aviation: Cross sectional surveys. Hum Perf Extreme Environ. 2001;6(1):6-11.
Shanafelt T D, Bradley K A, Wipf J E, et al. Burnout and self-reported patient care in an internal medicine residency program. Ann Intern Med. 2002;136:358-367. [pmid: 11874308].
Shanazarov AS. Characteristics of uncommon forms of activity and assessment of working capacity in uncomfortable high-altitude bioclimatic conditions. Hum Physiol 1999;25(2) Mar-Apr 1999(2):228–233.
Shaubhut R M, Jones C. A systems approach to medication error reduction. J Nurs Care Qual. 2000;14(3):13-27. [pmid: 10826231].
Shaw A, Davis P D, Anderson I M. Tapered connectors in patient breathing systems. Anaesthesia. 1982;37(2):201-3. [pmid: 6952774].
Shedd P P, Kobokovich L J, Slattery M J. Confused patients in the acute care setting: prevalence, interventions, and outcomes. J Gerontol Nurs. 1995;21(4):5-12. [pmid: 7602057].
Shepherd E. Arena. Holding our hands up. Nurs Times. 2000;96(49):7-13.
Sheridan T B. Function allocation: Algorithm, alchemy or apostasy?. Int J Hum Comp Studies. 2000;52(2):203-216.
Shindul-Rothschild J, Berry D, Long-Middleton E. Where have all the nurses gone? Final results of our patient care survey. Am J Nurs. 1996;96(11):24-39.
Shinn J A. Impact of staffing levels on job stress, injuries and quality of care. Prog Cardiovasc Nurs. 1995;10(2):47-8.
Shirani K Z, McManus A T, Vaughan G M, et al. Effects of environment on infection in burn patients. Arch Surg. 1986;121(1):31-6. [pmid: 3942497].
Shojania KG, Duncan BW, McDonald KM, et al. Making healthcare safer: a critical analysis of patient safety practices Evidence Report/Technology Assessment No. 43 AHRQ publication 01-E058. Rockville, MD: Agency for Healthcare Research and Quality; 2001.
Shojania K G, Duncan B W, McDonald K M, et al. Safe but sound: patient safety meets evidence-based medicine. JAMA. 2002;288(4):508-13. [pmid: 12132985].
Shortell SM, Bennett CL and Byck GR. Assessing the impact of continuous quality improvement on clinical practice: what it will take to accelerate progress. Milbank Q 1998;76(4):593–624, 510.
Shortell S M, Jones R H, Rademaker A W, et al. Assessing the impact of total quality management and organizational culture on multiple outcomes of care for coronary artery bypass graft surgery patients. Med Care. 2000;38(2):207-17. [pmid: 10659694].
Shortell S M, O'Brian J L, Carman J M, et al. Assessing the impact of continuous quality improvement/total quality management: Concept versus implementation. Health Serv Res. 1995;30(2):377-402. [pmid: 7782222].
Shortell S M, Zimmerman J E, Rousseau D M, et al. The performance of intensive care units: does good management make a difference?. Med Care. 1994;32(5):508-25. [pmid: 8182978].
Shryane N M, Westerman S J, Crawshaw C M, et al. Task analysis for the investigation of human error in safety-critical software design: a convergent methods approach. Ergonomics. 1998;41(11):1719-36. [pmid: 9819583].
Shulkin D J. The July phenomenon revisited: are hospital complications associated with new house staff?. Am J Med Qual. 1995;10(1):14-7. [pmid: 7727983].
Simard M, Marchand A. Workgroups' propensity to comply with safety rules: The influence of micro-macro organisational factors. Ergonomics. 1997;4(2):172-188.
Singer G, Dekker S W A. Pilot performance during multiple failures: an empirical study of different warning systems. Transport Hum Fact. 2000;2(1):63-77.
Singh J V. Technology, size, and organizational structure: A reexamination of the Okayama study data. Acad Manage J. 1986;29(4):800-812.
Siu A L, Kravitz R L, Keeler E, et al. Postdischarge geriatric assessment of hospitalized frail elderly patients. Arch Intern Med. 1996;156(1):76-81. [pmid: 8526700].
Sivaram C A, Johnson S, Tirmizi S N, et al. Morning report: a forum for reporting adverse drug reactions. Jt Comm J Qual Improv. 1996;22(4):259-63. [pmid: 8743062].
Sleutel M R. Climate, culture, context, or work environment?: Organizational factors that influence nursing practice. J Nurs Adm. 2000;30(2):53-58. [pmid: 10689396].
Smith A. Noise, performance efficiency and safety. Int Arch Occup Environ Health. 1990;62(1):1-5. [pmid: 2403982].
Smith A M, Ortiguera S A, Laskowski E R, et al. A preliminary analysis of psychophysiological variables and nursing performance in situations of increasing criticality. Mayo Clin Proc. 2001;76(3):275-84. [pmid: 11243274].
Smith A P, Miles C. The effects of lunch on cognitive vigilance tasks. Ergonomics. 1986;29(10):1251-1261. [pmid: 3780663].
Smith D B. The ideal environment for patient care. Dimens Oncol Nurs. 1991;5(3):37-8. [pmid: 1823570].
Smith D M, Weinberger M, Katz B P, et al. Postdischarge care and readmissions. Med Care. 1988;26(7):699-708. [pmid: 2839742].
Smith K R. Outcomes management of mechanically ventilated patients: utilizing informatics technology. Crit Care Nurs Q. 1998;21(3):61-72. [pmid: 10646422].
Smith L, Totterdell P, Folkard S. Shiftwork effects in nuclear power workers: A field study using portable computers. Work Stress. 1995;9(23):235-244.
Smith N. Medical errors. Medical profession must take drug errors seriously. BMJ. 2001;322(7299):1424-5. [pmid: 11417555].
Smolensky MW. The effect of work load history on operational errors in air traffic control simulation: The hysteresis effect--expectancy perseverance or short-term memory overload? : Texas Tech U, US.; 1991.
Smythe M, Loughlin K, Schad R F, et al. Patient-controlled analgesia versus intramuscular analgesic therapy. Am J Hosp Pharm. 1994;51(11):1433-40. [pmid: 7942878].
Sochalski J. Quality of care, nurse staffing, and patient outcomes. Policy Politics Nurs Prac. 2001;2(1):9-18.
Sonnenfeld J A. Shedding light on the Hawthorne Studies. J Occup Behav. 1985;6:111-130.
Sorenson J N. Safety culture: a survey of the state-of-the-art. Reliab Engin Syst Saf. 2002;76:189-204.
Sowden A J, Sheldon T A. Does volume really affect outcome? Lessons from the evidence. J Health Serv Res Pol. 1998;3(3):187-90.
Spath P. Equipment-related errors in the workplace. Hosp Peer Rev 2001;26(4):56–8, 46.
Spear M. Current issues: designing the universal patient care room. J Healthc Des. 1997;9:81-3. [pmid: 10539159].
Spelten E, Totterdell P, Barton J, et al. Effects of age and domestic commitment on the sleep and alertness of female shiftworkers. Work Stress. 1995;9(23):165-175.
Spiegelhalter D, Thomas A and Best N. WinBUGS Version 1.2 User Manual. In. 1.2 ed. Cambridge: MRC Biostatistics Unit; 1999.
Spokane A R, Meir E I, Catalano M. Person-environment congruence and Holland's theory: A review and reconsideration. J Vocat Behav. 2000;57(2):137-187.
Staes C, Balk S, Ford K, et al. Environmental factors to consider when designing and maintaining a child's day-care environment. Pediatrics. 1994;94(6 Pt 2):1048-50. [pmid: 7971054].
Staggers N, Kobus D. Comparing response time, errors, and satisfaction between text-based and graphical user interfaces during nursing order tasks. J Am Med Inform Assoc. 2000;7(2):164-76. [pmcid: 61470]. [pmid: 10730600].
Stair T O. Reduction of redundant laboratory orders by access to computerized patient records. J Emerg Med. 1998;16(6):895-7. [pmid: 9848709].
Stanley S, Foer S R. Nurse staffing: preserving patient safety and quality nursing care. Nurs Pol Forum. 1996;2(3):18-20.
Starfield B. Medical errors and adverse effects. Br J Gen Pract. 2001;51(464):232. [pmid: 11255916].
Stetzer A, Morgeson F P, Anderson E L. Organizational climate and ineffectiveness: Evidence from 25 outdoor work crew divisions. J Qual Manage. 1997;2(2):251-265.
Stevens D S, Cohen R I, Kanzaria R V, et al. “Air in the syringe”: patient-controlled analgesia machine tampering. Anesthesiology. 1991;75(4):697-9. [pmid: 1681763].
Stevenson J G. Adherence to physician training guidelines for pediatric transesophageal echocardiography affects the outcome of patients undergoing repair of congenital cardiac defects. J Am Soc Echocardiogr. 1999;12(3):165-72. [pmid: 10070180].
Stone N J. Windows and environmental cues on performance and mood. Environ Behav. 1998;30(3):306-22.
Stone N J, Irvine J M. Performance, mood, satisfaction, and task type in various work environments: A preliminary study. J Gen Psychol. 1993;120(4):489-497. [pmid: 8189213].
Stout R J, Salas E, Fowlkes J E. Enhancing teamwork in complex environments through team training. J Group Psychother Psychodram Sociometry. 1997;49(4):163-186.
Straker J. Reliability of OSCAR occupancy, census and staff data: a comparison with the Ohio Department of Health annual survey of long-term care facilities. Miami, FL: Scripps Gerontology Center, Miami University; 1999.
Strasen L. Redesigning hospitals around patients and technology. Nurs Econ. 1991;9(4):233-8. [pmid: 1922423].
Strzalka A, Havens D S. Nursing care quality: comparison of unit-hired, hospital float pool, and agency nurses. J Nurs Care Qual. 1996;10(4):59-65. [pmid: 8783546].
Stuck A E, Aronow H U, Steiner A, et al. A trial of annual in-home comprehensive geriatric assessments for elderly people living in the community. N Engl J Med. 1995;333(18):1184-9. [pmid: 7565974].
Stump L S. Re-engineering the medication error-reporting process: removing the blame and improving the system. Am J Health Syst Pharm. 2000;57(suppl 4):S10-7. [pmid: 11148939].
Sutcliffe KM. A mindful infrastructure for increasing reliability. Ambul Outreach 2000:30–4.
Tai T W, Robinson C D. Reducing staff turnover: a case study of dialysis facilities. Health Care Manage Rev. 1998;23(4):21-42. [pmid: 9803317].
Tamblyn R M, McLeod P J, Abrahamowicz M, et al. Do too many cooks spoil the broth? Multiple physician involvement in medical management of elderly patients and potentially inappropriate drug combinations. CMAJ. 1996;154(8):1177-84. [pmid: 8612253].
Tan G B, Cohen H, Taylor F C, et al. Referral of patients to an anticoagulant clinic: implications for better management. Qual Health Care. 1993;2(2):96-9. [pmid: 10131640].
Taris T W. The mutual effects between job resources and mental health: a prospective study among Dutch youth. Genet Soc Gen Psychol Monogr. 1999;125(4):433-50. [pmid: 10570822].
Tarnow-Mordi W O, Hau C, Warden A, et al. Hospital mortality in relation to staff workload: a 4-year study in an adult intensive-care unit. Lancet. 2000;356(9225):185-9. [pmid: 10963195].
Tasker R C. Training and dealing with errors or mistakes in medical practical procedures. Arch Dis Child. 2000;83(2):95-8. [pmid: 10906010].
Taswell H F, Galbreath J L, Harmsen W S. Errors in transfusion medicine. Detection, analysis, frequency, and prevention. Arch Path Lab Med. 1994;118(4):405-10. [pmid: 8166590].
Taunton R L, Kleinbeck S V, Stafford R, et al. Patient outcomes. Are they linked to registered nurse absenteeism, separation, or work load?. J Nurs Adm. 1994;24(4 Suppl):48-55. [pmid: 8068081].
Thackray R I, Touchstone R M. Effects of high visual taskload on the behaviours involved in complex monitoring. Ergonomics. 1989;32(1):27-38.
Thomas E J, Lipsitz S R, Studdert D M, et al. The reliability of medical record review for estimating adverse event rates. Ann Intern Med. 2002;136(11):812-6. [pmid: 12044129].
Thomas E J, Studdert D M, Burstin H R, et al. Incidence and types of adverse events and negligent care in Utah and Colorado. Med Care. 2000;38:261-271. [pmid: 10718351].
Thompson TG. Letter to the Honorable Richard B. Cheney. In: Centers for Medicare and Medicaid Services http://www.cms.hhs.gov/medicaid/reports/rp1201ltr.asp; 2002.
Thronesbery CG and Malin JT. Field guide for designing human interaction with intelligent systems Report No. TM-1998-208470. Houston, TX: NASA; 1998.
Thull B, Janssens U, Rau G, et al. Approach to computer-based medication planning and coordination support in intensive care units. Technol Health Care. 1997;5(3):219-33. [pmid: 9263371].
Tierney W M, Overhage J M, McDonald C J. A plea for controlled trials in medical informatics. J Am Med Inform Assoc. 1994;1(4):353-5. [pmcid: 116217]. [pmid: 7719821].
Ting H H, Lee T H, Soukup J R, et al. Impact of physician experience on triage of emergency room patients with acute chest pain at three teaching hospitals. Am J Med. 1991;91(4):401-8. [pmid: 1951384].
Titler M G. Technology dependency and iatrogenic injuries. Nurs Clin North Am. 1993;28(2):459-73. [pmid: 8516185].
Todd C, Reid N, Robinson G. The quality of nursing care on wards working eight and twelve hour shifts: a repeated measures study using the MONITOR index of quality of care. Int J Nurs Stud. 1989;26(4):359-68. [pmid: 2613453].
Todd C, Reid N, Robinson G. The impact of 12-hour nursing shifts. Nurs Times. 1991;87(31):47-50. [pmid: 1866305].
Tone B. What works? Nurse-patient ratios and safety. Nurseweek. 1999;12(9):34-5.
Tong D A. Weaning patients from mechanical ventilation. A knowledge-based system approach. Comput Methods Programs Biomed. 1991;35(4):267-78. [pmid: 1752122].
Topf M. Theoretical considerations for research on environmental stress and health. Image J Nurs Sch. 1994;26(4):289-293. [pmid: 7829114].
Totterdell P, Spelten E, Barton J, et al. On-shift and daily variations in self-report and performance measures in rotating-shift and permanent night nurses. Work Stress. 1995;9(23):187-197.
Townsend J, Piper M, Frank A O, et al. Reduction in hospital readmission stay of elderly patients by a community based hospital discharge scheme: a randomised controlled trial. BMJ. 1988;297(6647):544-7. [pmid: 2844356].
Treasure T. Do you admit to working within the system? If we see errors being made how can we be expected to stay silent?. BMJ. 2000;321(7263):768. [pmid: 11041642].
Treisman A M. Selective attention in man. Br Med Bull. 1964;20:12-16. [pmid: 14104089].
Tribble D A. How automated systems can (and do) fail. Am J Health Syst Pharm. 1996;53(21):2622-7. [pmid: 8913393].
Trilla A and Faura T. Error in medicine. JAMA 1995;274(6):460; discussion 460–1.
Turner J A, Karasek R A. Software ergonomics: Effects of computer application design parameters on operator task performance and health. Ergonomics. 1984;27(6):663-690. [pmid: 6383818].
Tutuarima J A, de Haan R J, Limburg M. Number of nursing staff and falls: a case-control study on falls by stroke patients in acute-care settings. J Adv Nurs. 1993;18(7):1101-5. [pmid: 8370900].
Ungs T J. Fixed vs. formed aircrews and safety. Aviat Space Environ Med. 1994;65(12):1160-1. [pmid: 7872925].
Vaernes R J, Knudsen G, Pasche A, et al. Performance under simulated offshore climate conditions. Scand J Psychol. 1988;29(2):111-122. [pmid: 3222679].
van Berkestijn L G, Kastein M R, Lodder A, et al. Do better quality consultations result in better health? Relationship between quality of consultations and health status of patients with non-acute abdominal complaints in general practice. Fam Pract. 1999;16(6):566-72. [pmid: 10625128].
Varonen U, Mattila M. The safety climate and its relationship to safety practices, safety of the work environment and occupational accidents in eight wood-processing companies. Accid Anal Prev. 2000;32(6):761-9. [pmid: 10994603].
Vega A, Gilbert M J. Longer days, shorter weeks: Compressed work weeks in policing. Public Personnel Manage. 1997;26(3):391-402.
Veitch J A, Newsham G R. Exercised control, lighting choices, and energy use: An office simulation experiment. J Environ Psychol. 2000;20:219-237.
Vidacek S, Kaliterna L, Radoesvic-Vidacek B. Productivity on a weekly rotating shift system: Circadian adjustment and sleep deprivation effects?. Ergonomics. 1986;29(12):1583-90. [pmid: 3816750].
Vigoda E. Organizational politics, job attitudes, and work outcomes: Exploration and implications for the public sector. J Vocat Behav. 2000;57(3):326-347.
Vincent C, Stanhope N, Crowley-Murphy M. Reasons for not reporting adverse incidents: an empirical study. J Eval Clin Prac. 1999;5(1):13-21.
Vincent C, Taylor-Adams S, Chapman E J, et al. Education and debate. How to investigate and analyse clinical incidents: clinical risk unit and association of litigation and risk management protocol. BMJ. 2000;320(7237):777-81. [pmid: 10720366].
Vincent C A. Research into medical accidents: a case of negligence?. BMJ. 1989;299(6708):1150-3. [pmid: 2513030].
Vinen J. Incident monitoring in emergency departments: an Australian model. Acad Emerg Med. 2000;7(11):1290-7. [pmid: 11073481].
Virvou M. Automatic reasoning and help about human errors in using an operating system. Interact Comput. 1999;11(5):545-573.
Visveshwara N, Freeman B, Peck M, et al. Patient-triggered synchronized assisted ventilation of newborns. Report of a preliminary study and three years' experience. J Perinatol. 1991;11(4):347-54. [pmid: 1770392].
Volzer R. Safe passages. Lose the institutional look without sacrificing safety. Comtemp Longterm Care. 2001;24(6):21-2.
Wachter R M. An introduction to the hospitalist model. Ann Intern Med. 1999;130(4 Pt 2):338-42. [pmid: 10068402].
Wakefield B J, Blegen M A, Uden-Holman T, et al. Organizational culture, continuous quality improvement, and medication administration error reporting. Am J Med Qual. 2001;16(4):128-34. [pmid: 11477957].
Wakefield BJ, Wakefield DS and Uden-Holman T. Improving medication administration error reporting systems. Why do errors occur? Ambul Outreach 2000:16–20.
Waldman DA and Spangler WD. Putting together the pieces: A closer look at the determinants of job performance. Hum Perf 1989;2(1) 1989(1):29–59.
Walsh-Sukys D M. Reducing light and sound in the neonatal intensive care unit: an evaluation of patient safety, staff satisfaction, and costs. J Perinatol. 2001;21(8):572.
Walter A, Merboth H, Boger S. Requirements of optimal working conditions and patient-centered care in hospital nursing. Pflege. 1997;10(6):341-9. [pmid: 9456781].
Walters J A. Nurses' perceptions of reportable medication errors and factors that contribute to their occurrence. Appl Nurs Res. 1992;5(2):86-8. [pmid: 1642491].
Walther S M, Jonasson U. A prospective cohort study of 6-month mortality in a community hospital experiencing a gradual reduction in critical care services. Intensive Care Med. 2001;27(4):700-5. [pmid: 11398696].
Walts A E, Marchevsky A M. Computerized interactive morphometry. An expert system for the diagnosis of lymphoid-rich effusions. Am J Clin Pathol. 1989;92(6):765-72. [pmid: 2686396].
Wann J, Mon-Williams M. “What does virtual reality NEED?: Human factors issues in the design of three-dimensional computer environments”: Erratum. Int J Hum Comp Studies. 1996;44:829-847.
Wastell D G, Newman M. Stress, control and computer system design: A psychophysiological field study. Behav Inform Tech. 1996;15(3):183-192.
Waters A. A matter of life and death. Nurs Stand. 1999;13(41):12-3.
Waters A. Putting safety first. Nurs Stand. 1999;13(38):12-3.
Way B B, Braff J L, Hafemeister T L, et al. The relationship between patient-staff ratio and reported patient incidents. Hosp Community Psychiatry. 1992;43(4):361-5. [pmid: 1577427].
Wears R L, Leape L L. Human error in emergency medicine. Ann Emerg Med. 1999;34:370-372. [pmid: 10459095].
Webber S S, Donahue L M. Impact of highly and less job-related diversity on work group cohesion and performance: A meta-analysis. J Manage. 2001;27(2):141-162.
Weber J E, Bartels P H, Griswold W, et al. Colonic lesion expert system. Performance evaluation. Anal Quant Cytol Histol. 1988;10(2):150-9. [pmid: 3291892].
Weber S F, Peacock J E, Do K A, et al. Interaction of granulocytopenia and construction activity as risk factors for nosocomial invasive filamentous fungal disease in patients with hematologic disorders. Infect Control Hosp Epidemiol. 1990;11(5):235-42. [pmid: 2351809].
Wedderburn A A. How fast should the night shift rotate? A rejoinder. Ergonomics. 1992;35(12):1447-1451. [pmid: 1490438].
Weed L L. New connections between medical knowledge and patient care. BMJ. 1997;315(7102):231-5. [pmid: 9253272].
Weeks W B, Bagian J P. Developing a culture of safety in the Veterans Health Administration. Effect Clin Pract. 2000;3(6):270-6.
Weeks W B, Mills P D, Dittus R S, et al. Using an improvement model to reduce adverse drug events in VA facilities. Jt Comm J Qual Improv. 2001;27(5):243-54. [pmid: 11367772].
Weick K E. Organizational culture as a source of high reliability. Calif Manage Rev. 1987;29(2):112-127.
Weick K E. The vulnerable system: An analysis of the Tenerife air disaster. J Manage. 1990;16(3):571-593.
Weick K E, Roberts K H. Collective mind in organizations: Heedful interrelating on flight decks. Admin Sci Q. 1993;38(3):357-381.
Weinberger M, Oddone E Z, Henderson W G. Does increased access to primary care reduce hospital readmissions? Veterans Affairs Cooperative Study Group on Primary Care and Hospital Readmission. N Engl J Med. 1996;334(22):1441-7. [pmid: 8618584].
Weinberger M, Smith D M, Katz B P, et al. The cost-effectiveness of intensive postdischarge care. A randomized trial. Med Care. 1988;26(11):1092-102. [pmid: 2846971].
Weingart S N. House officer education and organizational obstacles to quality improvement. Jt Comm J Qual Improv. 1996;22(9):640-6. [pmid: 8904692].
Weingart S N, Wilson R M, Gibberd R W, et al. Epidemiology of medical error. BMJ. 2000;320(7237):774-7. [pmid: 10720365].
Weisberg J. Differential teamwork performance: the impact of general and specific human capital levels. Int J Manpower. 1996;17(8):18-29.
Weisman E and Hagland M. Built-in care. One hospital sees the future in patient-centered design. Hosp Health Netw 1994;68(22):54, 56, 58 passim.
Welch D L. Human factors in the health care facility. Biomed Instrum Technol. 1998;32(3):311-6. [pmid: 9619261].
Welford A T. Single-channel operation in the brain. Acta Psychol. 1967;27:5-22.
Werner A. Importance of the quality of human-software interaction in expert systems. Behav Inform Tech. 1996;15(5):331-335.
Wertheim A. Working in a moving environment. Ergonomics. 1998;41(2):1845-1859. [pmid: 9857842].
West E. Organisational sources of safety and danger: sociological contributions to the study of adverse events. Qual Health Care. 2000;9(2):120-6. [pmid: 11067250].
West E. Management matters: the link between hospital organisation and quality of patient care. Qual Health Care. 2001;10(1):40-8. [pmid: 11239143].
West J A, Miller N H, Parker K M, et al. A comprehensive management system for heart failure improves clinical outcomes and reduces medical resource utilization. Am J Cardiol. 1997;79(1):58-63. [pmid: 9024737].
West S, King V, Carey TS, et al. Systems to rate the strength of scientific evidence. Evidence report/technology assessment no. 47 (prepared by the Research Triangle Institute - University of North Carolina evidence-based practice center under contract no. 290-97-0011). AHRQ publication no. 02-E016. Rockville, MD: Agency for Healthcare Research and Quality; 2002.
Westaby J D. Presence of others and task performance in Japan and the United States: A laboratory investigation. Int J Psychol. 1995;30(4):451-460.
Westhorpe R N, Cass N M. The role of the anaesthetist in patient monitoring. Anaesth Intensive Care. 1988;16(1):47-9. [pmid: 3364691].
White NR, Rice RB and Colleagues in Caring Practice Task F. Collaboration to nurture the nursing work environment. The Colleagues in Caring Practice Task Force. J Nurs Adm 2001;31(2):63–6.
Whitman J, Van Beusekom R, Olson S, et al. Preliminary evaluation of high-frequency chest compression for secretion clearance in mechanically ventilated patients. Respir Care. 1993;38(10):1081-7. [pmid: 10145892].
Whitmore M, McQuilkin M L, Woolford B J. Habitability and performance issues for long duration space flights. Hum Perf Extreme Environ. 1998;3(1):64-74.
Whitsett C F, Robichaux M G. Assessment of blood administration procedures: problems identified by direct observation and administrative incident reporting. Transfusion. 2001;41(5):581-6. [pmid: 11346689].
Whittaker S. SNAs lobby for safer care environments. Am J Nurs. 1998;98(8):56-8. [pmid: 9711154].
Wickens CD. Processing resources in attention. In: Parasuraman, R and Davies, PR, editors. Varieties of attention. Orlando, FL: Academic Press; 1984. p. 63–102.
Wiegmann D A, Shappell S A. Human factors analysis of postaccident data: Applying theoretical taxonomies of human error. Int J Aviat Psychol. 1997;7(1):67-81.
Williams E I, Fitton F. Factors affecting early unplanned readmission of elderly patients to hospital. BMJ. 1988;297(6651):784-7. [pmid: 3142550].
Williams M, Murphy J D. Noise in critical care units: a quality assurance approach. J Nurs Care Qual. 1991;6(1):53-9. [pmid: 1912621].
Williams M A. The physical environment and patient care. Annu Rev Nurs Res. 1988;6:61-84. [pmid: 3291917].
Williams M A. Physical environment of the intensive care unit and elderly patients. Crit Care Nurs Q. 1989;12(1):52-60. [pmid: 2720471].
Williams M A. Executive forum: design for therapeutic outcomes. J Healthc Des. 1992;4:35-41. [pmid: 10183789].
Williams R. Cultural safety--what does it mean for our work practice?. Aust NZ J Public Health. 1999;23(2):213-4.
Williams S, Moore C R, Wisnivesky J, et al. Assessing medical errors related to the continuity of care from an inpatient to an outpatient setting [abstract]. J Gen Intern Med. 2002;17(suppl. 1):218.
Wilson JP and Solimando DA. Aseptic technique as a safety precaution in the preparation of antineoplastic agents. Hosp Pharm 1981;16(11):575–6, 579–81.
Wilson S, Ruscoe W, Chapman M, et al. General practitioner-hospital communications: a review of discharge summaries. J Qual Clin Pract. 2001;21(4):104-8. [pmid: 11856404].
Winkel G H, Holahan C J. The environmental psychology of the hospital: Is the cure worse than the illness?. Prev Hum Serv. 1985;4(12):11-33. [pmid: 10274891].
Wong S, Glennie K, Muise M, et al. An exploration of environmental variables and patient falls. Dimens Health Serv. 1981;58(6):9-11. [pmid: 7239044].
Woods D, Dekker S. Anticipating the effects of technological change: a new era of dynamics for human factors. Theor Issues Ergonomics Sci. 2000;1(3):272-282.
Woolsen RF. Statistical Methods for the Analysis of Biomedical Data. New York: John Wiley and Sons; 1987.
Xiao Y, Hunter W A, Mackenzie C F, et al. Task complexity in emergency medical care and its implications for team coordination. Hum Factors. 1996;38:636-45. [pmid: 8976626].
Yeatts D E, Seward R R. Reducing turnover and improving health care in nursing homes: the potential effects of self-managed work teams. Gerontologist. 2000;40(3):358-63. [pmid: 10853530].
Yedidia M J, Lipkin M, Schwartz M D, et al. Doctors as workers: work-hour regulations and interns' perceptions of responsibility, quality of care, and training. J Gen Intern Med. 1993;8(8):429-35. [pmid: 8410408].
Youngs P J. Suboptimal ward care of critically ill patients. Inadequate staffing means problems are missed. BMJ. 1999;318(7175):52. [pmid: 10068219].
Zaat J O, Van Eijk J T, Bonte H A. Laboratory test form design influences test ordering by general practitioners in the Netherlands. Med Care. 1992;30:189-198. [pmid: 1538607].
Zernikow B, Michel E, Fleischhack G, et al. Accidental iatrogenic intoxications by cytotoxic drugs: error analysis and practical preventive strategies. Drug Saf. 1999;21(1):57-74. [pmid: 10433353].
Zevola D R, Maier B. Improving the care of cardiothoracic surgery patients through advanced nursing skills. Crit Care Nurs. 1999;19(1):34-44.
Zimmerman P G. More RNs mean better care… “Do staffing levels influence drug errors? The jury's out,”. Nurs Spectr. 2000;13(23):13.