# Acknowledgments

Valuable assistance for this project was provided by several groups of individuals, including an expert panel, a technical advisory panel, and external peer reviewers. The names of these individuals are included in Appendix A, and the research team would like to acknowledge their helpful contributions to the project. We also acknowledge the efforts of the Evidence-based Practice Center support staff, specifically Patty Davies, MS, Maria Shaffer, Crystal Swails, and Susan Wingenfeld. Our Task Order Officer from the Agency for Healthcare Research and Quality, Ernestine Murray, RN, MAS, provided invaluable assistance. We also acknowledge the assistance of Eric Coleman, MD, University of Colorado, Denver, CO; Harvey J. Murff, MD, Harvard Medical School, Boston, MA; Dean Sittig, PhD, Kaiser Center for Health Research, Portland, OR; and Robert M. Wachter, MD, University of California, San Francisco, CA, for advice during the course of the project.